# Appendix F. TEP and Peer Reviewers

Table F1. Technical Expert Panel members

[underlined: Name] | [underlined: Institution]
Kathleen Folye, M.D | Memorial Sloan-Kettering Cancer Center
Irene Higginson, M.D. | Kings College London
Margaret Heitkemper, PhD, RN, FAAN | University of Washington
Marianne Matzo, PhD, APRN, BC, GNP, FAAN | University of Massachusetts-Worcester
Diane Meier, M.D. | Mount Sinai School of Medicine
Richard Payne, M.D. | Duke University Divinity School
Joan Teno, M.D., M.S. | Brown Medical School

Table F2. Peer Reviewers

[underlined: Name] | [underlined: Institution]
Robert Arnold, M.D. | University of Pittsburgh
Eduardo Bruera, M.D. | University of Texas
Betty Rolling Ferrell, PhD, RN | City of Hope National Medical Center and Beckman Research Institute
Rolfe Sean Morrison, M.D. | Mount Sinai School of Medicine
Virginia P. Tilden, DNSc, RN | University of Nebraska Medical Center
Susan W. Tolle, M.D. | Oregon Health Sciences University