# Appendix E. Intervention Studies Evidence Tables

Evidence Table E1. IS - Advance Care Planning Evidence Table

First Author Year ID | Study Characteristics | Population | Interventions | Outcomes
| | | | Results
Anderson, 1994 ^1^ | Design: Intervention, comparison group | Sample size: 104-I, 100-C | Let Me Decide advance directive forms. | Outcomes: Level of quality of well being.
| Jadad: 2 | Disease: Other | | Results: No differences between health status and psych well being between intervention and control groups.
| Setting: Clinical services in 2 large hospitals | Severity: Advanced
| Funding: Not reported | Race: Not reported
| | Gender: Not reported
Campbell, 2003 ^2^ | Design: Intervention, comparison group | Sample size: 40-retrospective analysis vs. 41-proactive cohort | Meet with family daily to discuss patient's prognosis & treatment goals, Implementing DNR orders and Comfort measures. | Outcomes: Hospital - length of stay, Death/Mortality.
| Jadad: 0 | Disease: Single disease: Stroke or other neurode | | Results: Proactive case finding approach decreased hospital length of stay, decreased time between identification of poor prognosis and establishment of comfort care goals, and decreased use of non-beneficial resources.
| Setting: Hospital (ICU) | Severity: Advanced
| Funding: Not reported | Race: Not reported
| | Gender: Not reported
Heffner, 1997 ^3^ | Design: Intervention, without comparison group | Sample size: 50-I vs. 43-C | Educational workshop on AD and other end-of-life issues, Patients given pamphlets on AD, printed living will, durable powers of attorney for health care. | Outcomes: Physician-patient agreement/understanding on goals of care, including DNR, Patient report of living will &/or is in chart, Patient report of DPAHC &/or is in chart, Patient report of life support discussion with MD, Patient report of advance directives discussion with MD.
| Jadad: 1 | Disease: Single disease: Advanced chronic lung disease | | Results: The educational group had an increase in all five study outcomes, while control group had an increase in three of the outcomes.
| Setting: Ambulatory/outpt medical care | Severity: Unclear
| Funding: Greenwall Foundation | Race: Not reported
| | Gender: Males and females
Holzpfel, 2002 ^4^ | Design: Intervention, without comparison group | Sample size: 475-I | 4-step protocol for decision making in end-of-life care, Changes in treatment pattern required agreement. | Outcomes: Simplified acute physiologic score (SAPS), Use of mechanical vent, Use of mechanical vent > 48 hours, ICU - length of stay, Death/Mortality, Death after withholding, withdrawing life support (vent or other).
| Jadad: 1 | Disease: Mixed disease | | Results: Withdrawal of life support was performed in 17% of ICU patients. Mean ICU stay was 10 days.
| Setting: Hospital (ICU) | Severity: Advanced
| Funding: Not reported | Race: Not reported
| | Gender: Males
Jack, 2004 ^5^ | Design: Intervention, comparison group | Sample size: 50-I vs. 50-C | Palliative care team consultation. | Outcomes: Palliative Care Assessment Tool.
| Jadad: 1 | Disease: Single disease: Advanced cancer | | Results: Patients in the intervention group had significantly greater improvement in their insight scores.
| Setting: Hospital (non-ICU) | Severity: Advanced
| Funding: Not reported | Race: Not reported
| | Gender: Males and females
Lilly, 2000 ^6^ | Design: Intervention, without comparison group | Sample size: 134-pre-I vs. 396-I | Attending physician-led meetings with patients and their families. | Outcomes: Mortality rate, Consensus among providers.
| Jadad: 0 | Disease: Mixed disease | | Results: Intensive communication significantly reduced the median length of stay.
| Setting: Hospital (ICU) | Severity: Advanced
| Funding: Brigham and Women's Hospital, Boston, MA | Race: African-American, Hispanic and other
| | Gender: Males
Lilly, 2003 ^7^ | Design: Intervention, comparison group | Sample size: 134-pre-I vs. 396-I vs. 2361-4-year follow-up | Intensive communication sessions among providers, patients and families. | Outcomes: ICU - length of stay.
| Jadad: 0 | Disease: Mixed disease | | Results: Intensive communication produced significant and durable reductions in both length of stay and ICU mortality.
| Setting: Hospital–ICU | Severity: Advanced
| Funding: Brigham and Women's Hospital, Boston, MA | Race: African-American, Hispanic and other
| | Gender: Males and females
Ratner, 2001 ^8^ | Design: Intervention, without comparison group | Sample size: 83 | Discussion of ACP process with patients and their families during home visits, Documentation of health care directives using an ACP tool. | Outcomes: Chart based completion of advance directive, Time between ACP and death, Location of death, Use of hospice and palliative care.
| Jadad: 0 | Disease: Unclear | | Results: Of patients expressing a clear preference for location of end-of-life care, 82% wanted this care to be at home.
| Setting: Home health care | Severity: Unclear
| Funding: Allina Foundation | Race: Not reported
| | Gender: Not reported
Schwartz, 2002 ^9^ | Design: Intervention, comparison group | Sample size: 31-I vs. 30-C | Facilitated “Respecting Choices” interview with informational pamphlet vs. nondirective interview. | Outcomes: Attitudes towards end of life decision-making (questionnaire), Patient-surrogate concurrence in end-of-life care, Change in treatment preferences.
| Jadad: 3 | Disease: Unclear | | Results: Intervention achieved higher congruence between agents and patients in their understanding of patients' end of life care preferences. Intervention patients became less willing to undergo life-sustaining treatments for a new serious medical problem and less willing to tolerate poor health states.
| Setting: Ambulatory/outpt medical care | Severity: Unclear
| Funding: Fairlawn Foundation, the Umass Memorial Foundation, and the Stoddard Charitable Trust in Worcester, MA | Race: Other
| | Gender: Males and females
Stuart, 2003 ^10^ | Design: Intervention, without comparison group | Sample size: 208 | Implementing the “CHOICES” home care management program. | Outcomes: Location of death, Use of hospice and palliative care.
| Jadad: 1 | Disease: Mixed disease | | Results: Preliminary evidence supports the program's feasibility and acceptability to patients, families, physicians, and agency partners.
| Setting: Home health care | Severity: Advanced
| Funding: RWJ Foundation | Race: Not reported
| | Gender: Males and females
Weisbord, 2003 ^11^ | Design: Intervention, without comparison group | Sample size: 19 | Palliative care physicians performed an initial evaluation (using a standard intake form and doing a comprehensive history and physical exam) during dialysis visit, Written recommendations developed at weekly team meeting given to patient and their nephrologists. | Outcomes: Patient report of advance directives discussion with MD, Completion of AD/DPA and treatment preferences, Satisfaction with palliative care.
| Jadad: 1 | Disease: Single disease: Kidney disease/Renal failure | | Results: No differences were observed in symptoms, HRQoL or number of patients establishing advance directives as a result of the intervention.
| Setting: Ambulatory/outpt medical care | Severity: Unclear
| Funding: The Project on Death in America Faculty Scholars Program, the Greenwall Foundation, Ladies Hospital Aid Society of Western Pennsylvania, the International Union Against Cancer, Yamagiwa-Yoshida Memorial International Cancer Study Grant Fellowship, and the LAS Trust Foundation. | Race: Not reported
| | Gender: Not reported
Teno, 1997 ^12^ | Design: RCT/CCT | Sample size: 9,105 patients (4,301 in Phase I 4,804 in Phase II), patients & physicians randomized into T (n=2,652) or C (n= 2,152). | Physicians in the intervention group received computer- based estimates of the likelihood of 6 month survival for every day up to 6 months, outcomes of CPR, and functional disability at 2 months, A trained RN communicated w/ patients & families regarding treatment preferences, communicated these preferences to care team to improve understanding and patient-physician communication. | Outcomes: Time to comfort care goals/time when written/DNR, Physician-patient agreement/understanding on goals of care, including DNR, Frequency, severity of pain, Cost of care / resource intensity.
| Jadad: 3 | Disease: Mixed disease | | Results: No evidence that the intervention enhanced the effect of advance directives on 3 measures of resuscitation decision-making.
| Setting: Hospital (ICU and non-ICU) | Severity: Advanced
| Funding: RWJ Foundation | Race: African-American and other
| | Gender: Males and females
Dowdy, 1998 ^13^ | Design: Intervention, comparison group | Sample size: 37-C1, 31-C2 vs. 31-I | Ethics service intervention after patient received >96 hours of continuous mechanical ventilation. | Outcomes: Frequency and documentation of treatment discussions with patient, Completion of AD/DPA and treatment preferences, ICU - length of stay, Cost of care / resource intensity, Death/Mortality.
| Jadad: 1 | Disease: Unclear | | Results: More frequent and documented communications, more frequent decisions to forgo life-sustaining treatment, and reduced length of stay in the ICU for the proactive consultation group.
| Setting: Hospital (ICU) | Severity: Unclear
| Funding: Bon Secours-St. Mary's Health Care Foundation and the Trigon Blue Cross and Blue Shield of Virginia | Race: Not reported
| | Gender: Females
Schneiderman, 2003 ^14^ | Design: RCT/CCT | Sample size: 278-I vs. 273-C | Ethics consultation (not the standard of care at the time). | Outcomes: ICU - length of stay, Hospital - length of stay, Life-sustaining treatments in patients not surviving to discharge.
| Jadad: 3 | Disease: Mixed disease | | Results: The intervention and usual care groups showed no difference in mortality. The intervention was associated with reductions in hospital and ICU days and life-sustaining treatments with ventilation in those patients who ultimately did not survive to discharge.
| Setting: Hospital (ICU) | Severity: Advanced
| Funding: AHRQ Grant | Race: African-American, Hispanic, Asian and other
| | Gender: Females
Molloy, 2000 ^15^ | Design: RCT/CCT | Sample size: 636-I vs. 656-C | Let Me Decide AD program involving education of staff, residents, and families about Ads and forms to complete. | Outcomes: Patient satisfaction, Cost of care / resource intensity, Completion of AD/DPA and treatment preferences, Death after withholding, withdrawing life support (vent or other), Death/Mortality.
| Jadad: 3 | Disease: Unclear | | Results: Satisfaction was not significantly different between interventional and control nursing homes. Intervention nursing homes reported fewer hospitalizations per resident and less resource use.
| Setting: Nursing home | Severity: Unclear
| Funding: AHRQ Grant (RO1 HS07878-02S1) | Race: Other
| | Gender: Females
Dexter, 1998 ^16^ | Design: RCT/CCT | Sample size: 1009 (253-Control group, 219-Instruction directive group, 260-proxy directive group, 277-instruction directive and proxy directive group | Computer-generated reminders to discuss ADs, Computer-generated reminders for proxy directives, Computer-generated reminders to both instruction and proxy directives. | Outcomes: Completion of AD/DPA and treatment preferences.
| Jadad: 3 | Disease: Mixed disease | | Results: MDs who received reminders discussed advance directives with 24% of patients, compared to only 4% of patients with control group MDs.
| Setting: Ambulatory/outpt medical care | Severity: Advanced
| Funding: AHRQ Grant | Race: Asian
| | Gender: Females
Rubin, 1994 ^17^ | Design: RCT/CCT | Sample size: 1001 (552-I, 549-C) | Patients mailed durable power of attorney (DPA) informational brochure and DPA form. | Outcomes: Frequency and documentation of treatment discussions with patient.
| Jadad: 0 | Disease: Mixed disease | | Results: 18.5% of the intervention group completed a durable power of attorney compared to 0.4% of the control group.
| Setting: Ambulatory/outpt medical care | Severity: Unclear
| Funding: Kaiser Foundation Research Institute, Institute of Mental Health grant, and RWJ Foundation | Race: African-American, Hispanic, Asian and other
| | Gender: Males
^18^ | Design: RCT/CCT | Sample size: 95-I vs. 92-C | Educational workshop on AD and other end-of-life issues, Patients given pamphlets on AD, printed living will, durable powers of attorney for health care. | Outcomes: Completion of AD/DPA and treatment preferences.
| Jadad: 1 | Disease: Unclear | | Results: At one-month follow-up, the AD intervention group revealed a 38% completion versus control group's 24% completion of advance directive. Further, 73% of the AD group discussed advance planning as compared to 57% of control group.
| Setting: Ambulatory/outpt medical care | Severity: Unclear
| Funding: Department of Clinical Investigations, Walter Reed Army Medical Center | Race: Other
| | Gender: Not reported
^19^ | Design: RCT/CCT | Sample size: 386-I vs. 331-C | A trained RN communicated w/ patients & families/surrogates regarding treatment preferences to promote patient-surrogate agreement. | Outcomes: Patient-surrogate concurrence in end-of-life care.
| Jadad: 2 | Disease: Mixed disease | | Results: The SUPPORT intervention was not successful in increasing agreement between patients and surrogates. Other findings suggest that improvements in communication are particularly needed when patients are older and when the surrogate is not a patient's immediate relative.
| Setting: Hospital (ICU and non-ICU) | Severity: Advanced
| Funding: RWJ Foundation | Race: Not reported
| | Gender: Not reported
^20^ | Design: RCT/CCT | Sample size: 85-I vs. 15-C | Physician-initiated discussion of AD. | Outcomes: Attitudes towards end of life decision-making (questionnaire), Patient perception of MD - pt agreement / understanding of preferences, Patient mood or affective state.
| Jadad: 1 | Disease: Unclear | | Results: Neither group had adverse emotional or attitudinal responses. The AD group showed positive affective and attitudinal responses to the discussion, including an increase in positive affect, an increased sense of physician-patient understanding, and increased thought and discussion about life-support issues in the week following the AD.
| Setting: Ambulatory/outpt medical care | Severity: Unclear
| Funding: Summa Health System Foundation, Family Practice Clinical Research Center, Kent State University Applied Psychology Center and the Department of Family Medicine at the Northeastern Ohio Universities College of Medicine grant D15 PE55048-01 from the Depart | Race: Not reported
| | Gender: Not reported

I = Intervention group, C = Control group, RCT/CCT = Randomized Controlled Trial/Clinical Controlled Trial, ICU = Intensive Care Unit, CPR = Cardiopulmonary Resuscitation, RN = Registered Nurse, DNR = Do Not Resuscitate, outpt = Outpatient, AD = Advance Directive, MD = Physician, ACP = Advance Care Planning, AD/DPA = Advance Directive/Durable Power of Attorney, HRQoL = Health Related Quality of Life, T = Treatment group, DPA = Durable Power of Attorney

Evidence Table E2. IS - Continuity/Coordination Interventions Evidence Table

First Author Year ID | Study Characteristics | Population | Interventions | Outcomes
| | | | Results
Ahrens, 2003 ^1^ | Design: Intervention, comparison group | Sample size: 151 (43 - I, 108 - C) | Communication - MD / nurse specialist communication team. | Outcomes: ICU length of stay, Charges/costs, ICU mortality, Hospital LOS.
| Jadad: 0 | Disease: Mixed disease | | Results: Compared with the control group, patients in the intervention group had significantly shorter stays in both the intensive care unit and the hospital and had lower fixed and variable costs.
| Setting: Hospital (ICU) | Severity: Advanced
| Funding: Local grant (Barnes-Jewish Foundation) | Race: Not reported
| | Gender: Not reported
SUPPORT, 1995 ^2^ | Design: RCT/CCT | Sample size: 4804 (2652 - I, 2152 - C) | Communication - MD / nurse specialist communication team, Feedback/benchmarking, Pain assessment, Eliciting patient preferences. | Outcomes: Pain, ICU mortality, DNR orders, Physician awareness of pts HRQOL (physician agreement with patient report).
| Jadad: 2 | Disease: Mixed disease | | Results: Compared to control patients, intervention patients experienced no difference in patient-physician communication, or in the 5 targeted outcomes. The intervention also did not reduce use of hospital resources.
| Setting: Hospital (non-ICU) | Severity: Advanced
| Funding: RWJ | Race: Not reported
| | Gender: Not reported
Detmar, 2003 ^3^ | Design: RCT/CCT | Sample size: 214 patients, 10 physicians (pairs) | Pre-visit HRQOL questionnaire with standardized reporting to the physician. | Outcomes: Communication summary score - audiotape derived, Physician awareness of pts HRQOL (physician agreement with patient report), HRQOL-related patient management, Patient satisfaction, and Physician satisfaction.
| Jadad: 3 | Disease: Predominately one disease: Breast cancer | | Results: Health-related quality of life issues were discussed significantly more in the intervention than in the control group. MDs in the intervention group identified a higher percentage of patients with moderate-to-severe health problems. All MDs and 87% of patients believed that the intervention facilitated communication and expressed interest in its continued use.
| Setting: Ambulatory/outpt medical care | Severity: Advanced
| Funding: Dutch Cancer Society | Race: Not reported
| | Gender: Not reported
Hughes, 2000 ^4^ | Design: RCT/CCT | Sample size: 981 -I, 985- C - 289 of these were “terminally ill” | Nursing palliative care / case managers, 24- hour availability, Discharge planning, Home-based primary care. | Outcomes: Quality of life, Charges/costs, Patient satisfaction, Caregiver burden.
| Jadad: 3 | Disease: Mixed disease | | Results: Team-managed home base primary care improved most HR-QoL measures among terminally ill patients and satisfaction among non-terminally ill patients. It improved caregiver HR-QoL, satisfaction with care, and caregiver burden and also reduced hospital readmission.
| Setting: Home health care | Severity: Advanced
| Funding: VA HSR&D and Cooperative Studies Program | Race: Not reported
| | Gender: Not reported
Latimer, 1998 ^5^ | Design: RCT/CCT | Sample size: 21 (12 - I, 9 - C) out of 46 randomized | Patient-carried medical record (Patient Care Traveling Record). | Outcomes: Pain, Mood, Patient satisfaction, Utilization, Patient uncertainty.
| Jadad: 2 | Disease: Mixed disease | | Results: 21 patients completed the trial. With the exception of those aged 65+, patients using the Patient Care Traveling Record reported decreased levels of uncertainty on follow-up. There was no additional use of health care services, no differences in mood states, pain relief, or satisfaction with health care.
| Setting: Ambulatory/outpt medical care | Severity: Advanced
| Funding: Local grant (Hamilton, Ontario civic hospitals) | Race: Not reported
| | Gender: Not reported
Marbella, 1998 ^6^ | Design: RCT/CCT | Sample size: 386 - I, 331 - C | Communication - MD / nurse specialist communication team, Feedback/benchmarking, Pain assessment, Eliciting patient preferences. | Outcomes: Patient - surrogate agreement on preferences for care.
| Jadad: 2 | Disease: Mixed disease | | Results: Intervention did not have an effect on surrogates' agreement with patients' resuscitation wishes.
| Setting: Hospital (non-ICU) | Severity: Advanced
| Funding: RWJ | Race: Not reported
| | Gender: Not reported
Smeenk, 1998 ^7^ | Design: Intervention, comparison group | Sample size: 79-I, 37-C | Discharge planning, 24- hour availability, Patient-carried medical record (Patient Care Traveling Record), Eare protocols. | Outcomes: Quality of life, Re-hospitalization.
| Jadad: 1 | Disease: Single disease: Mixed cancer | | Results: Patients in the intervention group underwent significantly less re-hospitalization during the terminal phase of their illness. The intervention contributed significantly to the patients' physical quality of life. A higher, but not significant (p=.06) percentage of patients in the intervention group died at home.
| Setting: Home health care | Severity: Advanced
| Funding: National Committee of Chronic Diseases in the Netherlands | Race: Not reported
| Scientific Fund of the Catharina Hospital, Eindhoven | Gender: Not reported
Grande, 1999 ^8^ | Design: RCT/CCT | Sample size: 186 - I, 43 - C | 24 / 7 in home nursing care. | Outcomes: Home death / site of death.
| Jadad: 2 | Disease: Predominately one disease: Mixed cancer | | Results: Results were inconclusive; study attained less statistical power than initially planned.
| Setting: Home health care | Severity: Advanced
| Funding: Elizabeth Clark Charitable Trust and NHS R&D program | Race: Not reported
| | Gender: Not reported
Goldberg, 2003 ^9^ | Design: RCT/CCT | Sample size: 280 (138 - I, 142 - C) | AlereNet (electronic monitoring system for weights and symptoms). | Outcomes: Quality of life, Patient satisfaction, Mortality, Emergency department use.
| Jadad: 1 | Disease: Single disease: Heart failure | | Results: No differences in hospitalization rates were observed, but there was a significant reduction in mortality for the intervention group.
| Setting: Ambulatory/outpt medical care | Severity: Moderate
| Funding: Alere Medical, Inc. | Race: Not reported
| | Gender: Not reported
Gorski, 2003 ^10^ | Design: Intervention, without comparison group | Sample size: 74-I, unclear -C | Disease management, Home care. | Outcomes: Patient satisfaction, Re-hospitalization, Self-care management.
| Jadad: 1 | Disease: Single disease: Heart failure | | Results: 35% decrease in hospitalization of patients.
| Setting: Home health care | Severity: Moderate
| Funding: Not reported | Race: Not reported
| | Gender: Not reported
Heidenreich, 1999 ^11^ | Design: Intervention, comparison group | Sample size: 68 - I, 86 - C (historical controls) | Comprehensive education and telephone reporting, follow-up protocol. | Outcomes: Quality of life, Patient satisfaction, Utilization, Charges/costs.
| Jadad: 0 | Disease: Single disease: Heart failure | | Results: Medical claims per year decreased in the intervention group, while they increased in the control group. Same was true for hospitalizations and hospital days.
| Setting: Ambulatory/outpt medical care | Severity: Moderate
| Funding: LifeMasters Supported Self Care, AHRQ training grant 00028-10 | Race: Not reported
| | Gender: Males
Jaarsma, 1999 ^12^ | Design: RCT/CCT | Sample size: 84 - I, 95 - C | Intensive patient education, Telephone case management. | Outcomes: Self-care management, Self-care ability, Utilization.
| Jadad: 1 | Disease: Single disease: Heart failure | | Results: Patients from both the intervention and control groups increased their self-care behavior within a month of discharge, but the increase in the intervention group was significantly more after one month. No significant effects on resource utilization were found.
| Setting: Ambulatory/outpt medical care | Severity: Advanced
| Funding: Netherlands Heart Foundation Grant 43.033 | Race: Not reported
| | Gender: Not reported
Philbin, 2000 ^13^ | Design: RCT/CCT | Sample size: 5-I, 5-C (about 1500 patients, 10 total hospitals) | Complex hospital level program (QI). | Outcomes: Re-hospitalization, Appropriate med use, Hospital LOS, Ladder of Life, Functional status, Mortality.
| Jadad: 1 | Disease: Single disease: Heart failure | | Results: Non-significant decreases in length of stay and hospital charges in the intervention group.
| Setting: Ambulatory/outpt medical care | Severity: Moderate
| Funding: VHA Empire State, Inc NY State Dept of Health grants | Race: Not reported
| | Gender: Not reported
Riegel, 2002 ^14^ | Design: RCT/CCT | Sample size: 281 MD's randomized, unit of analysis is patient (358 / 573 eligible participate in analysis) | Nursing case management using decision support tool for CHF. | Outcomes: Patient satisfaction, Cost of care, Re-admission to hospital, Days of hospitalization.
| Jadad: 3 | Disease: Single disease: Heart failure | | Results: Heart failure hospitalization rate, hospital days, multiple readmissions, and costs were all significantly lower in the intervention group. The intervention group had higher patient satisfaction.
| Setting: Ambulatory/outpt medical care | Severity: Moderate
| Funding: Pfizer, Inc | Race: Not reported
| | Gender: Not reported
Stewart, 1999 ^15^ | Design: RCT/CCT | Sample size: 100 - I, 100 - C | Post-discharge nurse focused on broad range of concerns including ensuring supportive, safe home and specific education and medical treatment of CHF, coordination of services. | Outcomes: Quality of life, Re-hospitalization, Functional status, Mortality.
| Jadad: 3 | Disease: Single disease: Heart failure | | Results: There were fewer unplanned readmissions and associated days in the hospital among intervention group patients.
| Setting: Home health care | Severity: Moderate
| Funding: National Heart Foundation of Australia Postgraduate Research Scholarship | Race: Not reported
| | Gender: Not reported
Mann, 1999 ^16^ | Design: RCT/CCT | Sample size: 52 - I, 52 - C | Physical therapist in home assessment, Assistive devices and modifications to home environment, Nurse and home technician assistance. | Outcomes: Functional independence, Pain, Charges/costs.
| Jadad: 2 | Disease: Mixed disease | | Results: Pain scores increased significantly more for the control group. The control group required significantly more expenditures for institutional care.
| Setting: Ambulatory/outpt medical care | Severity: Advanced
| Funding: National Institute on Disability and Rehabilitation Research H133E60006, Administration on Aging of DHHS, and Andrus Foundation | Race: Not reported
| | Gender: Not reported
Melin, 1992 ^17^ | Design: RCT/CCT | Sample size: 249 randomized, 150 - I, 99 - C | MD / nurse home care, Interdisciplinary team management, 24- hour availability. | Outcomes: Functional status, Social contact and support, Utilization.
| Jadad: 1 | Disease: Mixed disease | | Results: Significant improvement in instrumental activities of daily living, outdoor walking, and medical condition was found in the intervention group compared to control group.
| Setting: Ambulatory/outpt medical care | Severity: Advanced
| Funding: Aldre Centrum Foundation, Stockholm County Council, and Central Stockholm Public Health District | Race: Not reported
| | Gender: Not reported
Jerant, 2001 ^18^ | Design: RCT/CCT | Sample size: 13 - I1, 12 - I2, 12 - C | Video-based telecare, Telephone case management. | Outcomes: Re-admission to hospital, Charges/costs, Quality of life, Emergency department use.
| Jadad: 3 | Disease: Single disease: Heart failure | | Results: Both intervention groups had significantly fewer CHF related emergency department visits and costs than the usual care group. Trends favoring both interventions were found on all other utilization outcomes; these results were not statistically significant (very small N).
| Setting: Home health care | Severity: Advanced
| Funding: UC Davis intramural grant | Race: Not reported
| | Gender: Not reported
Stewart, 1999 ^19^ | Design: RCT/CCT | Sample size: 49 - I, 48 - C | Post-discharge nurse and pharmacist follow-up focused on medication knowledge and compliance. | Outcomes: Re-admission to hospital, Mortality, Emergency department use, Charges/costs.
| Jadad: 1 | Disease: Single disease: Heart failure | | Results: Intervention group had fewer unplanned readmissions, fewer out-of-hospital deaths, fewer days of hospitalization, and fewer total deaths.
| Setting: Ambulatory/outpt medical care | Severity: Moderate
| Funding: Australian Dept of Health and Family Services, Canberra (grant 95/34956) | Race: Not reported
| | Gender: Not reported
Bruera, 1999 ^20^ | Design: RCT/CCT | Sample size: 60 | Tape recording of consultation with MD. | Outcomes: Patient satisfaction, Pt-family communication about illness, Understanding of treatment plan and illness.
| Jadad: 5 | Disease: Single disease: Mixed cancer | | Results: Addition of an audiocassette to written communications significantly increased patient satisfaction and improved recall of the information given during the consultation.
| Setting: Ambulatory/outpt medical care | Severity: Advanced
| Funding: Not reported | Race: Not reported
| | Gender: Not reported
Schneiderman, 2000 ^21^ | Design: RCT/CCT | Sample size: 74 (35 - I, 35 - C) | Ethics consultation. | Outcomes: Variety of life-extending or sustaining treatments non-beneficial treatments, ICU length of stay, Family and provider perception of usefulness and stressfulness.
| Jadad: 2 | Disease: Mixed disease | | Results: No differences in overall mortality between control and intervention groups. Intervention was associated with reductions in ICU days and life-sustaining treatments in those patients who ultimately failed to survive to discharge.
| Setting: Hospital (ICU) | Severity: Advanced
| Funding: AHCPR PAR-96-028 | Race: Not reported
| | Gender: Not reported
Schneiderman, 2003 ^22^ | Design: RCT/CCT | Sample size: 278 - I, 273 - C | Ethics consultation. | Outcomes: ICU length of stay, Hospital LOS, Mortality, Non-beneficial treatment (hi-tech care).
| Jadad: 3 | Disease: Mixed disease | | Results: Ethics consultations were useful in resolving conflicts that may have inappropriately prolonged non-beneficial or unwanted treatments in the intensive care unit.
| Setting: Hospital (ICU) | Severity: Advanced
| Funding: AHRQ RO1 HS10251 | Race: Not reported
| | Gender: Not reported
Raftery, 1996 ^23^ | Design: RCT/CCT | Sample size: 86-I, 81-C | Nurse coordinator. | Outcomes: Hospital LOS, Charges/costs.
| Jadad: 2 | Disease: Predominately one disease: Mixed cancer | | Results: The mean total costs incurred by the co-ordination group were significantly less than those of control group. The co-ordination groups used significantly fewer inpatient days and nurse home visits.
| Setting: Home health care | Severity: Advanced
| Funding: Medical Research Council | Race: Not reported
| | Gender: Not reported
Selwy, 2003 ^24^ | Design: Intervention, without comparison group | Sample size: 132 | Palliative care consult service. | Outcomes: Symptoms, Mortality, Survival duration, Discharge disposition, Conflict.
| Jadad: 0 | Disease: Single disease: HIV/AIDS | | Results: HIV palliative care services resolved the patients' problems including a mix of medical and psychosocial issues.
| Setting: Hospital (non ICU) | Severity: Advanced
| Funding: HRSA | Race: Not reported
| | Gender: Not reported
Stockelberg, 1997 ^25^ | Design: Intervention, without comparison group | Sample size: 17 | Home care. | Outcomes: Utilization.
| Jadad: 0 | Disease: Single disease: Other cancer | | Results: Supportive treatment of patients with haematological disorders, given by a nurse, is safe and well accepted. The cost for transportation and hospital care were reduced.
| Setting: Home health care | Severity: Advanced
| Funding: FoU-fondation, Södra Älvsborg, Borås Bil & Traktor AB | Race: Not reported
| | Gender: Not reported
Goodyer, 1995 ^26^ | Design: RCT/CCT | Sample size: 100 (50-I, 50-C) | Intensive medication counseling. | Outcomes: Symptoms, Functional status, Adherence.
| Jadad: 1 | Disease: Single disease: Heart failure | | Results: Intensive medication counseling in a group of elderly patients with chronic heart failure improved exercise capacity and signs of oedema. Exercise tolerance for the patients who received no counseling worsened over the study period. No subjective benefit could be detected by VAS or the NHP.
| Setting: Ambulatory/outpt medical care | Severity: Moderate
| Funding: Not reported | Race: Not reported
| | Gender: Not reported
Topp, 1998 ^27^ | Design: Intervention, comparison group | Sample size: 491 (88 -I) | Disease management. | Outcomes: Hospital LOS.
| Jadad: 0 | Disease: Single disease: Heart failure | | Results: The patients who were case managed by the CCM/CNS demonstrated significantly shorter length of stay and lower hospital charges than the patients who were not case managed.
| Setting: Hospital (non ICU) | Severity: Unclear
| Funding: Not reported | Race: Not reported
| | Gender: Not reported
Roglieri, 1997 ^28^ | Design: RCT/CCT | Sample size: unclear - C I-149 | Disease management. | Outcomes: Utilization.
| Jadad: 0 | Disease: Single disease: Heart failure | | Results: A comprehensive congestive heart failure (CHF) disease management program significantly reduced admission and readmission rates for patients with the pure CHF diagnosis.
| Setting: Ambulatory/outpt medical care | Severity: Unclear
| Funding: Not reported | Race: Not reported
| | Gender: Females

ICU = Intensive Care Unit, I = Intervention group, C = Control group, MD = Physician, LOS = Length of Stay, RCT/CCT = Randomized Controlled Trial / Clinical Controlled Trial, DNR = Do Not Resuscitate, HRQoL = Health Related Quality of Life, ICU = Intensive Care Unit, outpt = Outpatient, QI = Quality Improvement, CHF = Chronic Heart Failure, Pt(s) = Patient(s)

Evidence Table E3. IS - Family/Caregiver Concerns Interventions Evidence Table

First Author Year ID | Study Characteristics | Population | Interventions | Outcomes
| | | | Results
Baker, 2000 ^1^ | Design: RCT/CCT | Sample size: 767 | Clinical nurse specialist to assist in symptom control and facilitation of communication and decision-making. | Outcomes: Family CG satisfaction with communication, Family CG satisfaction with decision-making.
| Jadad: 2 | Disease: Mixed disease: Not reported | | Results: Sub-sample of the SUPPORT study. Used prospective cohort design to examine factors associated with family satisfaction with end of life care. Larger study was an RCT. RESULTS: 16% of respondents reported dissatisfaction w/ patient comfort and 30% reported dissatisfaction w/ communication and decision-making. Factors significantly associated w/ satisfaction w/ communication & decision-making: hospital site, whether death occurred during the index hospitalization (AOR 2.2, 95% CI, 1.3–3.9), and for pts who died following discharge: whether pt. received SUPPORT intervention (AOR 2.0, 1.2–3.2). For satisfaction w/ comfort, male surrogates reported less satisfaction (0.6, 0.4–1.0), surrogates who reported patients preferences were followed moderately to not at all had less satisfaction (0.2, 0.1–0.4), and surrogates who reported the patient's illness had greater effect on family finances had less satisfaction (0.4, 0.2–0.8).
| Setting: Hospital (non-ICU) | Severity: Advanced
| Funding: RWJ | Race: Other
| | Gender: Not reported
SUPPORT, 1995 ^2^ | Design: RCT/CCT | Sample size: 9,105 seriously ill hospitalized adults w/ 6 mo. Mortality of 47% | Telephone Palliative Care: telephone advice. | Outcomes: Family CG satisfaction with communication, Family CG satisfaction with decision-making, Physical symptoms other than pain.
| Jadad: 5 | Disease: Mixed disease: Not reported | | Results: No difference in outcomes on pain, communication, DNR, CPR, decision-making, and ADs in medical record.
| Setting: Hospital (ICU) | Severity: Advanced
| Funding: RWJ | Race: Other
| | Gender: Not reported
Hanks, 1996^3^ | Design: RCT/CCT | Sample size: 261 (175 allocated to FULL PCT, 86 to telephone PCT) | Palliative care unit in hospital w/ outpatient clinic and multidisciplinary palliative care consult team, Home-based primary care program in VA | Outcomes: Pain, Physical symptoms other than pain, 2, Provider satisfaction, Family satisfaction with care, Patient satisfaction with care.
| Jadad: 1 | 2:1 randomization | pts managed by team after discharge. | Results: Significant improvements in symptoms, HRQoL, mood and “emotional bother” in FULL-PCT at 1 week, maintained over the 4 week FU. A smaller effect was seen in the “Telephone PCT”; there were no significant differences between the groups. Satisfaction w/ care in both groups w/ no significant difference between groups. No difference found between the two models of palliative care delivery.
| Setting: Unclear | N=191 reassessed at 1 week
| Funding: Need article | Disease: Unclear
| | Severity: Advanced
| | Race: African-American and other
| | Gender: Not reported
Hughes, 2000 ^4^ | Design: RCT/CCT | Sample size: N=1966, mean age: 70 years w/ 2 or more ADL limitations or a terminal illness, CHF or COPD. T=981=HBPC in community | Hospital at Home Service-RN, REACH Intervention 1. | Outcomes: Family CG satisfaction with decision-making, Mental status, Psychiatric morbidity, CG problems/unmet needs.
| Jadad: 2 | C=985= usual post-discharge care) | | Results: No difference in pt/cg at baseline. Terminal pts improved significantly vs. controls on 8 HR-QoL scales (emotional, social, bodily pain, mental health, vitality, general health) with greatest improvement in emotional function. No difference in terminal pt. satisfaction over study period. CG to terminal pts showed significant HR-QoL improvements (P<.05 overall) vs. controls in all but 2 dimensions (vitality, general health) with greatest improvement in emotional function (13 point gain vs. controls); CG showed significant gains in satisfaction w/ pt care (P<.001) except for personal satisfaction item. A 8% reduction in hospitalizations and mean number of hospitalizations in intervention in first 6 months but not sustained to 12 months with 22% reduction in those w/ most disability. Pt./CG benefits accompanied by a 6.8% increase in total costs of care at 6 months and 12.1% increase at 12 months.
| Setting: Home | Disease: Mixed disease: Not reported
| Funding: HRSA and Cooperative Studies Program, Dept. of VA | Severity: Advanced and moderate
| | Race: Other
| | Gender: Males
Ringdal, 2002 ^5^ | Design: RCT/CCT | Sample size: n=180 (112 T caregivers and 68 C caregivers) | Palliative care unit in hospital w/ outpatient clinic and multidisciplinary palliative care consult team. | Outcomes: Place of death, Hospital utilization, 2.
| Jadad: 2 | Disease: Single disease: Mixed cancer diagnoses | | Results: Satisfaction with care was measured in 49% of caregivers in the intervention group and 36% of caregivers in the control group. Reasons for refusal not recorded due to confidentiality concerns. Respondents were primarily women, median age: 56 years (57% under 60 years of age), most were spouses. No statistical significant differences between T and C at baseline. Place of death: more T pts died at home (27% vs. 14%) (not significant); most respondents reported being very satisfied or satisfied w/ care (right skewed); some lower satisfaction w/ issues related to time to diagnosis, referral to specialists, symptom management, information provided; T cg's had significantly higher satisfaction scores than C. Intervention generally improved satisfaction among close family members. Intervention stressed information on prognosis and planning ahead, pain and symptom management, family conferences, availability of physicians to family, and systematic symptom assessment (information and attention domains). Intervention allowed more pts able to die at home.
| Setting: Hospital (ICU) | Severity: Advanced
| Funding: Norwegian and Swedish Cancer Society, Norwegian Medical Assn Fund for Quality Improvement | Race: African-American and other
| | Gender: Females
Ringdal, 2004 ^6^ | Design: Intervention, comparison group | Sample size: N=517 (285 in T232 in C) in 2 sites | Palliative care unit in hospital w/ outpatient clinic and multidisciplinary palliative care consult team. | Outcomes: Family CG satisfaction with decision-making.
| Jadad: 3 | Disease: Single disease: Mixed cancer diagnoses | | Results: Five of eight subscales of Health-related quality of life scores decline (RP, VT, SF, RE, & MH) to T 4 (1–2 months after patient's death) and return to baseline by the end of the study. Scores for PF, BP, & GH showed smaller and almost linear decline. Low response rates in both groups undermines the findings in this study.
| Setting: Hospital (ICU) | Severity: Advanced
| Funding: Norwegian and Swedish Cancer Society, Norwegian Medical Assn Fund for Quality Improvement | Race: African-American and other
| | Gender: Females
Walsh, 2003 ^7^ | Design: Intervention, comparison group | Sample size: n=9 | RN care coordination in the community. | Outcomes: CG Burden, Depression, Social support, Reaction at EOL: panic, blame, detachment, disorganization and despair.
| Jadad: 1 | Disease: Single disease: Mixed cancer diagnoses | | Results: CG depression scores decreased from a mean of 20.2 +/- 9.25 to 12.8 +/-9.57. However, CG's felt more burdened (38.5 +/- 2.38 POST vs. 93.2 +/-5.93 PRE). Disorganization decreased, CGs reported less dispair. No change in panic, bloame, detachment, personal growth, or social support.
| Setting: Home | Severity: Advanced
| Funding: University of Miami School of Nursing Dean's Award | Race: Other
| | Gender: Not reported
Addington-Hall, 1992 ^8^ | Design: RCT/CCT | Sample size: 554 referred, (203 with evaluable outcomes), 35% (n=194) died/too ill to interview, 7% (40) moved, 39 (7%) declined to be interviewed. N=281 (51% of initial sample) at baseline | REACH Intervention 1. | Outcomes: Family CG satisfaction with communication, Family satisfaction with care, Time from Final follow-up to death, Place of death, Need for more help.
| Jadad: 3 | 203 (72%) =1 FU. T=104, C=99. | | Results: Time between last FU and death did not differ significantly between groups. No significant difference in symptom experience (except T more likely to suffer from vomiting than C, P=.05). Few statistically significant differences in severity of symptoms, concern about symptoms, or effectiveness of treatments. No group differences in type of analgesics taken, nor in proportions of patients taking anti-emetics, laxatives, antidepressants, sedatives, or anxiolytics. A few significant differences found in CG reports of type, severity, and effectiveness of treatment of pt's symptoms in last week of life: T pts more likely to report pt symptoms (cough, constipation) and less likely to report treatment effectiveness for anxiety. No differences between groups on hospital anxiety and depression scale, social support, and quality of life, ADL assistance needs, unmet needs, financial impact, use of social services, and satisfaction w/ care. Overall, few differences found in symptoms and symptom control, service provision, coordination, and satisfaction, and social and psychological support between T and C. Intervention had no discernable impact.
| Setting: Home | Disease: Single disease: Mixed cancer diagnoses
| Funding: UK Medical Research Council | Severity: Advanced
| | Race: Other
| | Gender: Not reported
Grande, 2000 ^9^ | Design: RCT/CCT | Sample size: N=198 (86% of 229 referred pts) and 144 CGs (73% of 198 referred CGs) | REACH Intervention 2. | Outcomes: Family CG satisfaction with communication, Family satisfaction with care, Depression, Pt functional status, Place of death.
| Jadad: 0 | Disease: Predominately one disease: Mixed cancer | | Results: There was no clear evidence that the hospital-at-home service for terminally ill patients increased the likelihood of remaining at home during the final 2 weeks of life. However, the service was associated with fewer GP out of hurs visits. All respondent groups rated CHAH favorably when compared to standard care but emphasized different aspects (GP, RN, CG respondents). RN's rated services as a better than standard care in terms of adequacy of night care and support for the carer, GPs in terms of reduction of anxiety and depression, and CGs in terms of control of pain and nausea. Overall, service provided better quality of care.
| Setting: Home | Severity: Advanced
| Funding: Elizabeth Clark Charitable Trust and NHS R&D Primary / Secondary Care Interface Programme | Race: Other
| | Gender: Not reported
Gitlin, 2003 ^10^ | Design: RCT/CCT | Sample size: 1,222 racially & ethnically diverse cg | REACH Intervention 3. | Outcomes: Depression, CG Burden.
| Jadad: 2 | Disease: Single disease: Dementia | | Results: REACH designed to examine the feasibility and effectiveness of multiple intervention approaches for family caregivers to pts w/ dementia. Each site conducted as a RCT. The combined effects of active interventions vs. control at 6 months on burden and CG depression. Using meta-analysis, the pooled T effect fro burden was statistically significant p=.022, though the difference was small. Overall, CGs across REACh sites showed lower values in burden w/ behavior problems of pts vs. controls. There were no statistically significant effects for any one intervention for burden although all scores were in hypothesized direction. In contrast to burden, the pooled treatment effect for CES-D was not statistically significant. Modest intervention effect.
| Setting: Home | Severity: Other
| Funding: NIA & NINR funding | Race: Other
| | Gender: Not reported
Smeenk, 1998 ^11^ | Design: Intervention, comparison group | Sample size: 45 (T=34 C=11) | Transmural home care intervention | Outcomes: Mental status.
| Jadad: 2 | Disease: Single disease: Mixed cancer diagnoses | | Results: The intervention contributed positively to the direct caregivers quality of life at time 2 (p=<.05) with improvements on fear, general well-being, and loneliness scales. Improvement at (p=<.05) was due to improvements on the SIP and fear scales compared with standard care.
| Setting: Home | Severity: Advanced
| Funding: National Committee of Chronic Diseases and the Scientific Fund of the Catharina Hospital, Eindhoven | Race: Not reported
| | Gender: Not reported
Bucher, 2001 ^12^ | Design: Intervention, comparison group | Sample size: 103 (49/49 Ca patients and 49/54 Ca pt. Caregivers) | Behavior Care. | Outcomes: Problem solving score, Problem solving ability, CG appraisal of pt behavior problems, Anxiety.
| Jadad: 0 | Disease: Single disease: Mixed cancer diagnoses | | Results: There was no statistically significant difference in perception of ability to provide care after the intervention for either patients or caregivers. However, a significant difference in feeling informed about community resources for both patients and caregivers was found after intervention. Caregivers significantly increased their total problem solving score (.05) after the intervention.
| Setting: Home | Severity: Unclear
| Funding: The Open Society Institute, Project Death in America | Race: Other
| | Gender: Not reported
Burgio, 2003 ^13^ | Design: Intervention, comparison group | Sample size: 118 of 140 caregivers to dementia patients (70 White 48 African-American) completed 6 mo. FU | Enhanced Care. | Outcomes: Pt behavior problems, Social support, Depression, Anxiety, Desire to institutionalize.
| Jadad: 3 | Disease: Single disease: Dementia | | Results: White caregivers were more likely to be older, report higher household income, and be spouses while African American caregivers more likely to be non-spouses. African American care receivers had lower educational attainment and demonstrated greater cognitive impairment than White care receivers. White caregivers showed more improvement in the minimal support control condition and African American caregivers showed the greatest improvements in the skills training condition. A significant treatment by race by relationship interaction was found with the largest decreases in the number of problem behaviors found for White spouses in the MS condition and for African American spouses in the ST condition.
| Setting: Home | Severity: Unclear
| Funding: NIA & NINR funding - Alabama REACH | Race: Other
| | Gender: Females
Burns, 2003 ^14^ | Design: RCT/CCT | Sample size: 76 of 167 caregiver-pt dyads completed 24 FU | Structural Ecosystems Therapy (SET), SET + Computer Telephone Integrated System (CTIS). | Outcomes: CG well-being, Depression, Pt behavior problems.
| Jadad: 2 | Disease: Single disease: Dementia | | Results: Significant differences in general well-being were found by group and time (p=.045). BC only had significantly worse general well-being and a trend toward increased risk of depression. Both groups improved on bother associated with care recipient. BC had significantly greater distress at FU.
| Setting: Ambulatory/outpt medical care | Severity: Unclear
| Funding: NIA & NINR funding - Memphis REACH | Race: Other
| | Gender: Females
Eisdorfer, 2003 ^15^ | Design: Intervention, comparison group | Sample size: 225 dementia patient caregivers (114 Cuban American and 111 White American) | Environmental Skill-Building Program (ESP), Automated Telecare System (TLC). | Outcomes: Not reported.
| Jadad: 2 | Disease: Single disease: Dementia | | Results: Caregivers in the combined family therapy group (SET+CTIS) experienced a significant reduction in depressive symptoms at 6 months. The combined intervention was most effective at 18 months for Cuban American husband and daughter caregivers.
| Setting: Ambulatory/outpt medical care | Severity: Unclear
| Funding: NIA & NINR funding - Miami REACH | Race: Other
| | Gender: Not reported
Gitlin, 2003 ^16^ | Design: RCT/CCT | Sample size: 190 of 255 dementia patient caregivers at 6 mo. FU | The ESP (Environmental Skill-Building Program). | Outcomes: Costs, CG Depression, CG Mastery, Stress reduction, CG enhancement.
| Jadad: 3 | Disease: Single disease: Dementia | | Results: Intervention caregivers reported less upset with memory-related behaviors, less need for assistance from others, and better affect. Intervention spouses reported less upset with disruptive behaviors; men reported spending less time in daily oversight; women reported less need for help from others, better affect, and enhanced management ability, overall well-being, and mastery relative to controls.
| Setting: Home | Severity: Unclear
| Funding: NIA & NINR funding - Philadelphia REACH | Race: African-American, Hispanic and other
| | Gender: Not reported
Mahoney, 2003 ^17^ | Design: RCT/CCT | Sample size: 100 (49 in T, 51 in C) | A computer-mediated automated interactive voice response intervention. | Outcomes: CG well-being, CG Bother, Mastery.
| Jadad: 2 | Disease: Single disease: Dementia | | Results: No significant main effect of the intervention on bother, depression, or anxiety. Participants w/ low-mastery at baseline experienced a greater decline in bother scores (p=.04), depressive symptoms p=.007), and anxiety (.01). No difference for high-mastery groups.
| Setting: Home | Severity: Unclear
| Funding: NIA & NINR funding - Boston REACH | Race: Other
| | Gender: Females

RCT/CCT = Randomized Controlled Trial/Clinical Controlled Trial, ICU = Intensive Care Unit, CG = Care-Giver, AOR = Adjusted Odds Ration, CI =Confidence Interval, pt(s) = Patient(s), DNR = Do Not Resuscitate, CPR = Cardiopulmonary Resuscitation, ADs = Advance Directive, PCT = Palliative Care Team, HRQoL = Health Related Quality of Life, FU = Follow Up, ADL = Activities of Daily Living, CHF = Chronic Heart Failure, COPD = Chronic obstructive pulmonary disease, T = Treatment group, HBPC = Home Based Primary Care (VA specific), C = Control group, RN = Registered Nurse, EOL = End-of-Life

Evidence Table E4 IS - Satisfaction Interventions Evidence Table

First Author Year ID | Study Characteristics | Population | Interventions | Outcomes Results
Bookbinder, 1996 ^1^ | Design: Intervention, without comparison group | Sample size: 698 patients, 1210 RN interviews, 335 focus groups with RN staff | Comprehensive pain management care team, CQI type intervention. | Outcomes: Pain, Patient satisfaction, Medical provider satisfaction, Provider knowledge, Patient concerns, Patient preference of treatment.
| Jadad: 0 | 2000 vital sign records | | Results: Overall high rate of patient satisfaction (92%). Significant moderate correlations were found between overall dissatisfaction and longest time to wait for medication, extent of pain relief, and time to change medication.
| Setting: Hospital (non-ICU) | Disease: Mixed disease: Not reported
| Funding: Not reported | Severity: Unclear
| | Race: Not reported
| | Gender: Not reported
Brumley, 2003 ^2^ | Design: Intervention, comparison group | Sample size: N=300 | Comprehensive palliative care team, Usual care. | Outcomes: Patient satisfaction, Utilization of health care services, Cost.
| Jadad: 0 | Disease: Mixed disease: Not reported | | Results: The labor of care giving emerged as the organizing core theme. The role of the caregiver in contributing to the quality of life of the patient was apparent in the initial phase of an illness as well as at the time of death.
| Setting: Home health care | Severity: Advanced
| Funding: Garfield Memorial Fund | Race: Not reported
| | Gender: Not reported
Hanks, 2002 ^3^ | Design: RCT/CCT | Sample size: 261 | Comprehensive palliative care team. | Outcomes: Quality of life (patient), Patient satisfaction, Family/caregiver satisfaction, Medical provider satisfaction, Utilization of health care services, Re-admission to hospital.
| Jadad: 2 | Disease: Mixed disease: Not reported | | Results: Satisfaction with care in both groups was high and there was no significant difference between them.
| Setting: Hospital (non-ICU) | Severity: Advanced
| Funding: NHS (UK) National Cancer R&D Programme grant | Race: Not reported
| | Gender: Not reported
Hughes, 2000 ^4^ | Design: RCT/CCT | Sample size: 981 -I, 985- C - 289 of these were “terminally ill” | Discharge planning, 24 hour availability, Home-based primary care, Nursing palliative care, case managers. | Outcomes: Quality of life (patient), Cost, Patient satisfaction, Caregiver burden, Re-admission to hospital.
| Jadad: 3 | Disease: Mixed disease: Not reported | | Results: Team-managed home base primary care improved most HR-QoL measures among terminally ill patients and satisfaction among non-terminally ill patients. It improved caregiver HR-QoL, satisfaction with care and caregiver burden and reduced hospital readmission at 6 months.
| Setting: Home health care | Severity: Advanced
| Funding: VA HSR&D and Cooperative Studies Program | Race: Not reported
| | Gender: Not reported
Latimer, 1998 ^5^ | Design: RCT/CCT | Sample size: 46 randomized/21 completed study | Portable patient-controlled health record, Patient Care Traveling Record. | Outcomes: Pain, Patient satisfaction, Utilization of health care services, Mood, Uncertainty regarding present situation.
| Jadad: 2 | Disease: Unclear | | Results: 21 patients completed the trial. With the exception of those aged 65+, patients using the Patient Care Traveling Record reported decreased levels of uncertainty on follow-up. There was no additional use of health care services, no differences in mood states, pain relief, or satisfaction with health care.
| Setting: Hospice | Severity: Moderate
| Funding: Hamilton Civic Hospitals (Canada) | Race: Not reported
| | Gender: Not reported
Rabow, 2004 ^6^ | Design: RCT/CCT | Sample size: 90 | Comprehensive palliative care team, Usual care, Outpatient Palliative Medicine Consultation. | Outcomes: Quality of life (patient), Physical symptoms (general), Utilization of health care services, Affective/behavioral symptoms, Degree dyspnea interferes, Frequency dyspnea limits activities, Sleep, Spirituality, Cost, Pain, Anxiety, Depression, Patient satisfaction.
| Jadad: 3 | Disease: Mixed disease: Not reported | | Results: The intervention group patients had less dyspnea and anxiety, and improved sleep quality and spiritual well being, but no change in pain, depression, quality of life or satisfaction with care.
| Setting: Ambulatory/outpt medical care | Severity: Moderate
| Funding: Robert Wood Johnson Foundation | Race: Not reported
| | Gender: Not reported
Ringdal, 2002 ^7^ | Design: RCT/CCT | Sample size: 180 | Comprehensive palliative care team, Usual care. | Outcomes: Family/caregiver satisfaction.
| Jadad: 2 | Disease: Mixed disease: Not reported | | Results: The majority of respondents reported high satisfaction with care. The respondents related to the patients in the intervention group reported significantly higher satisfaction with care than the respondents related to patients in the control group.
| Setting: Hospice | Severity: Advanced
| Funding: Norwegian Cancer Society, Swedish Cancer Society, Norwegian Medical Association Fund for Quality Improvement | Race: Not reported
| | Gender: Not reported
Grande, 2000 ^8^ | Design: RCT/CCT | Sample size: 229 | Intensive home-based palliative care, Usual care. | Outcomes: Physical symptoms (general), Medical provider satisfaction, Place of death or care at end of life, Provider workload.
| Jadad: 3 | Disease: Mixed disease: Not reported | | Results: While the Cambridge hospital at home service was not found to increase the likelihood of remaining at home during the final two weeks of life, it appeared to be associated with better quality home care.
| Setting: Hospice | Severity: Advanced
| Funding: Elizabeth Clark Charitable Trust, NHS (UK) | Race: Not reported
| | Gender: Not reported
Scneiderman, 2003 ^9^ | Design: RCT/CCT | Sample size: 278 - I, 273 - C | Ethics team consultation. | Outcomes: Patient satisfaction, Family/caregiver satisfaction, Hospital length of stay, ICU length of stay, TISS reduction (hospital resource use measure), Death.
| Jadad: 3 | Disease: Mixed disease: Not reported | | Results: Ethics consultations were useful in resolving conflicts that may have inappropriately prolonged non-beneficial or unwanted treatments in the intensive care unit.
| Setting: Hospital (ICU) | Severity: Advanced
| Funding: AHRQ RO1 HS10251 | Race: Not reported
| | Gender: Not reported
Molloy, 2000 ^10^ | Design: Intervention, without comparison group | Sample size: 527-I, 656-C | Let-Me-Decide advance directive forms, Skilled nurse advance directive facilitator - patient / proxy meetings. | Outcomes: Patient satisfaction, Family/caregiver satisfaction, Completion of Let Me Decide advance directive, Utilization of health care services.
| Jadad: 1 | Disease: Mixed disease: Not reported | | Results: Systematic implementation of a program to increase use of advance directives reduced health care utilization without affecting satisfaction or mortality.
| Setting: Nursing home | Severity: Advanced
| Funding: AHRQ Grant (RO1 HS07878-02S1) | Race: Not reported
| | Gender: Not reported
Weisbord, 2003 ^11^ | Design: Intervention, without comparison group | Sample size: 19 | Palliative care team consultation. | Outcomes: patient report of DPAHC, patient report of advance directives discussion with MD, quality of life, symptom burden.
| Jadad: 1 | Disease: Single disease: End stage renal disease | | Results: No differences were observed in symptoms, HRQoL or number of patients establishing advance directives as a result of the intervention.
| Setting: Ambulatory/outpt medical care | Severity: Advanced
| Funding: Project Death in America Faculty Scholars Program, Greenwall Foundation, Ladies Hospital Aid, International Union Against Cancer, LAS Trust Foundation, American Society of Nephrology, NIH T32HL07820-05 | Race: Not reported
| | Gender: Not reported
Reigel, 2002 ^12^ | Design: RCT/CCT | Sample size: 281 MD's randomized, unit of analysis is patient (358 / 573 eligibles participate in analysis) | Dextromethorphan (DM). | Outcomes: Pain rating scale using VAS, Pain intensity, Edmonton staging system for cancer pain, Medication effectiveness, Patient satisfaction.
| Jadad: 3 | Disease: Single disease: Heart failure | | Results: Heart failure hospitalization rate, hospital days, multiple readmissions, and costs were all significantly lower in the intervention group. The intervention group had higher patient satisfaction.
| Setting: Ambulatory/outpt medical care | Severity: Moderate
| Funding: Pfizer, Inc | Race: Not reported
| | Gender: Not reported
Bruera, 1994 ^13^ | Design: RCT/CCT | Sample size: 60 | Tape recording of consultation with MD. | Outcomes: Satisfaction with care (general), Pt-family communication about illness, Understanding of treatment plan and illness.
| Jadad: 5 | Disease: Single disease: Mixed cancer | | Results: Addition of an audiocassette to written communications significantly increased patient satisfaction and improved recall of the information given during the consultation.
| Setting: Ambulatory/outpt medical care | Severity: Advanced
| Funding: Not reported | Race: Not reported
| | Gender: Not reported
Pietersma, 2003 ^14^ | Design: Intervention, without comparison group | Sample size: 27 | Electric food cart, Usual care. | Outcomes: Satisfaction with food provided.
| Jadad: 1 | Disease: Mixed disease: Not reported | | Results: The patients on oncology/palliative unit significantly preferred their meals to be delivered via a food cart rather than thermal trays, with respect to the timing and appeal of the meal, appropriateness of food types and food portions and the variety of the food choices.
| Setting: Hospital (non ICU) | Severity: Advanced
| Funding: Alberta Palliative Care Research Initiative | Race: Not reported
| | Gender: Not reported

ICU = Intensive Care Unit, RN = Registered Nurse, CQI = Continuous Quality Improvement, RCT/CCT = Randomized Controlled Trial/Clinical Controlled Trial, I = Intervention group, C = Control group, HRQoL = Health Related Quality of Life, outpt = Outpatient

Evidence Table E5. IS - Symptoms Evidence Table

First Author Year ID | Study Characteristics | Population | Interventions | Outcomes Results
Booth, 1996 ^1^ | Design: RCT/CCT | Sample size: 45 | Oxygen, Air. | Outcomes: Dyspnea rating using VAS, Modified Borg scale, SaO2 - O2 saturation.
| Jadad: 2 | Disease: Predominately one disease: Lung cancer | | Results: Both oxygen and air had a significant effect in reducing dyspnea at rest in patients with advanced cancer.
| Setting: Hospice | Severity: Advanced
| Funding: Dame Cicely Saunders Research Fund & Help the Hospices | Race: Other
| | Gender: Not reported
Bruera, 1993 ^2^ | Design: RCT/CCT | Sample size: 14 | Oxygen, Air. | Outcomes: Dyspnea rating using VAS.
| Jadad: 2 | Disease: Predominately one disease: Lung cancer | | Results: Oxygen was better than air for treatment of dyspnea, as measured by visual analogue scale and patient preference.
| Setting: Hospital (non-ICU) | Severity: Advanced
| Funding: Not reported | Race: Other
| | Gender: Not reported
Jack, 2003 ^3^ | Design: Intervention, comparison group | Sample size: 100 | Hospital palliative care team, Usual care. | Outcomes: Anorexia, Nausea, Insomnia, Constipation, Pain.
| Jadad: 1 | Disease: Mixed disease: Mixed disease | | Results: The intervention groups had a greater improvement in all their symptoms, particularly for pain and anorexia.
| Setting: Hospital (non-ICU) | Severity: Unclear
| Funding: Not reported | Race: Other
| | Gender: Not reported
Latimer, 1998 ^4^ | Design: RCT/CCT | Sample size: 46 | Patient Care Traveling Record. | Outcomes: Pain, Mood, Health care utilization, Patient satisfaction.
| Jadad: 2 | Disease: Unclear: Mixed disease | | Results: 21 patients completed the trial. With the exception of those aged 65+, patients using the Patient Care Traveling Record reported decreased levels of uncertainty on follow-up. There was no additional use of health care services, no differences in mood states, pain relief, or satisfaction with health care.
| Setting: Ambulatory/outpt medical care | Severity: Unclear
| Funding: Hamilton Civic Hospitals | Race: Other
| | Gender: Not reported
Mazzacato, 1999 ^5^ | Design: RCT/CCT | Sample size: 10 | Subcutaneous morphine sulfate, Placebo. | Outcomes: Dyspnea rating using VAS, Modified Borg scale, Pain rating scale using VAS, Somnolence, Anxiety.
| Jadad: 2 | Disease: Predominately one disease: Lung cancer | | Results: Morphine was effective for cancer dyspnea, and did not compromise respiratory function at the dose used.
| Setting: Hospital (non-ICU) | Severity: Advanced
| Funding: Not reported | Race: Other
| | Gender: Not reported
Mercadante, 2002 ^6^ | Design: RCT/CCT | Sample size: 50 | Morphine, Keterolac. | Outcomes: Pain, Nausea, Vomiting, Daytime drowsiness, Confusion, Constipation, Gastric discomfort.
| Jadad: 3 | Disease: Mixed disease: Mixed cancer diagnoses | | Results: Patients who received ketorolac in addition to morphine showed a better analgesia after a week in comparison to the group treated with morphine only. Thereafter, morphine escalation was slower and the maximum morphine dose was lower in the group treated with ketorolac. The incidence and the severity of gastric discomfort were more evident in patients treated with ketorolac, while constipation was significantly increased in patients who received morphine only.
| Setting: Home health care | Severity: Advanced
| Funding: Not reported | Race: Other
| | Gender: Not reported
Rabow, 2004 ^7^ | Design: Intervention, comparison group | Sample size: 90 | Outpatient Palliative Medicine Consultation, Usual care. | Outcomes: Degree dyspnea interferes, Frequency dyspnea limits activities, Sleep, Spirituality, Health care costs, Pain, Quality of life, Anxiety, Depression, Patient satisfaction.
| Jadad: 3 | Disease: Mixed disease: Mixed disease | | Results: The intervention group patients had less dyspnea and anxiety, and improved sleep quality and spiritual well being, but no change in pain, depression, quality of life or satisfaction with care.
| Setting: Ambulatory/outpt medical care | Severity: Advanced
| Funding: Robert Wood Johnson Foundation | Race: Other
| | Gender: Not reported
Schofield, 2003 ^8^ | Design: RCT/CCT | Sample size: 26 | Snoezelen (multisensory environment), Quiet room. | Outcomes: Anxiety, Depression.
| Jadad: 3 | Disease: Mixed disease: Mixed disease | | Results: A significant reduction in anxiety was seen in the experimental group, but no changes were observed in any of the quality of life subscales.
| Setting: Hospice | Severity: Advanced
| Funding: Wilkes Fellowship | Race: Other
| | Gender: Males
Simmons, 2002 ^9^ | Design: RCT/CCT | Sample size: 51 | Exercise and toileting program, Usual care. | Outcomes: Geriatric pain measure (13-item), Physical mobility.
| Jadad: 1 | Disease: Mixed disease: Mixed disease | | Results: No significant changes in pain reports were attributable to exercise despite significant improvements in physical performance.
| Setting: Nursing home | Severity: Unclear
| Funding: NIH/NIA, Claude Pepper OAIC | Race: Other
| | Gender: Females
Soden, 2004 ^10^ | Design: RCT/CCT | Sample size: 42 | Usual care, Massage with aromatherapy, Massage alone. | Outcomes: Pain rating scale using VAS, Verran and Snyder-Halpern sleep scale, Hospital Anxiety and Depression scale, Rotterdam Symptom Checklist.
| Jadad: 5 | Disease: Mixed disease: Mixed disease | | Results: No significant long-term benefits of aromatherapy or massage in terms of pain control, anxiety, or quality of life. However, sleep scores improved significantly in both the massage and the combined massage / aromatherapy group. Depression scores were reduced in the massage group.
| Setting: Unclear | Severity: Advanced
| Funding: Foundation for Integrated Medicine | Race: Other
| | Gender: Females
Wilkinson, 1999 ^11^ | Design: RCT/CCT | Sample size: 103 | Massage with aromatherapy, Massage alone. | Outcomes: Rotterdam Symptom Checklist, Patient preference of treatment, Quality of life, Activity.
| Jadad: 3 | Disease: Mixed disease: Mixed cancer diagnoses | | Results: Massage with or without essential oils reduced levels of anxiety. The addition of essential oil resulted in improvement in physical and psychological symptoms, as well as quality of life.
| Setting: Hospice | Severity: Advanced
| Funding: Not reported | Race: Other
| | Gender: Females
Addingon-Hall, 1992 ^12^ | Design: RCT/CCT | Sample size: 554 | Palliative care coordination, Usual care. | Outcomes: Time to death, Pain, Vomiting, Nausea, Constipation, Insomnia, Anxiety, Depression, Loss of appetite, Difficulty swallowing, Dyspnea, Cough, Itchy skin, Diarrhea, Incontinence/retention, Patient satisfaction, Caregiver burden, Health care utilization
| Jadad: 2 | Disease: Mixed disease: Mixed cancer diagnoses | | Results: Few differences between groups were significant. Coordination group patients were less likely to suffer from vomiting, more likely to report effective treatment for it, and less likely to be concerned about itchy skin.
| Setting: Ambulatory/outpt medical care | Severity: Advanced
| Funding: Medical Research Council | Race: Other
| | Gender: Not reported
Grande, 2000 ^13^ | Design: RCT/CCT | Sample size: 262 | Usual care, Cambridge Hospital at home service. | Outcomes: Patient satisfaction, Pain, Vomiting, Nausea, Constipation, Diarrhea, Dyspnea, Anxiety, Depression, Health care utilization, Caregiver satisfaction.
| Jadad: 3 | Disease: Mixed disease: Mixed disease | | Results: While the Cambridge hospital at home service was not found to increase the likelihood of remaining at home during the final two weeks of life, it appeared to be associated with better quality home care.
| Setting: Home health care | Severity: Advanced
| Funding: Elizabeth Clark Charitable Trust | Race: Other
| | Gender: Not reported
Rogers, 1999 ^14^ | Design: Intervention, comparison group | Sample size: 84 | Usual care, Skill elicitation, Habit training. | Outcomes: Functional status, Disruptive behavior.
| Jadad: 0 | Disease: Mixed disease: Mixed disease | | Results: Compared with usual care, during skill elicitation participants increased the proportion of time engaged in non-assisted and assisted dressing significantly and increased their overall participation in activities of daily living, with a decrease in disruptive behavior. These functional gains were demonstrated within 5 days of initiating the behavioral rehab intervention and maintained for 3 weeks during habit training.
| Setting: Nursing home | Severity: Unclear
| Funding: NINR | Race: Other
| | Gender: Not reported
Rovner, 1996 ^15^ | Design: RCT/CCT | Sample size: 118 | A.G.E. Dementia Care program, Usual care. | Outcomes: Disruptive behavior, Use of anti-psychotics, Restraints, Participation in activities.
| Jadad: 3 | Disease: Single disease: Dementia | | Results: Controls were more than twice as likely as intervention patients to receive anti-psychotics, to be restrained during activity times and to be restrained on nursing units.
| Setting: Nursing home | Severity: Unclear
| Funding: NIMH | Race: Other
| | Gender: Females
Sulzer, 2001 ^16^ | Design: RCT/CCT | Sample size: 28 | Haloperidol, Trazodone. | Outcomes: Delusion Scale, Hamilton Depression Rating Scale, Cohen-Mansfield Agitation Inventory.
| Jadad: 2 | Disease: Single disease: Dementia | | Results: Agitation scores improved in each treatment group over the 9 weeks of treatment.
| Setting: Hospital (non-ICU) | Severity: Moderate
| Funding: NIMH | Race: Other
| | Gender: Not reported
Weiner, 1999 ^17^ | Design: RCT/CCT | Sample size: 20 | Specific inspiratory muscle training, Placebo. | Outcomes: Spirometry, Respiratory muscle strength, Inspiratory muscle endurance, 12-minute walk, Exercise tolerance test, Dyspnea index.
| Jadad: 2 | Disease: Single disease: Heart failure | | Results: Patients in the training group showed an increase in inspiratory muscle strength, PImax, and endurance.
| Setting: Unclear | Severity: Moderate
| Funding: Not reported | Race: Other
| | Gender: Males
Manfredi, 2003 ^18^ | Design: Intervention, without comparison group | Sample size: 47 | Long-acting opioid, Placebo. | Outcomes: Cohen-Mansfield Agitation Inventory, Adverse events.
| Jadad: 0 | Disease: Single disease: Dementia | | Results: Among the 13 patients >=85 years old the agitation level at the end of the opioid phase was significantly lower than at the end of the placebo phase.
| Setting: Nursing home | Severity: Advanced
| Funding: New York State Dept. of Health, Bureau of Long Term Care Services | Race: Other
| Purdue Pharma | Gender: Females
Sittl, 2003 ^19^ | Design: RCT/CCT | Sample size: 157 | Transdermal delivery system for buprenorphine, 35.0 ug/h, Transdermal delivery system for buprenorphine, 52.5 ug/h, Transdermal delivery system for buprenorphine, 70.0 ug/h, Placebo. | Outcomes: Pain, Intake of extra doses of analgesics, Pain intensity.
| Jadad: 3 | Disease: Mixed disease: Mixed disease | | Results: Buprenorphine TDS was associated with significantly higher response rates than was placebo at the 35.0 and 52.5 ug/h dosages, and a numerically higher response rate at 70.0 ug/h, although this difference did not reach statistical significance.
| Setting: Ambulatory/outpt medical care | Severity: Advanced
| Funding: Grunenthal GmbH | Race: Other
| | Gender: Not reported
Smith, 2002 ^20^ | Design: RCT/CCT | Sample size: 202 | Implantable intrathecal drug delivery system and comprehensive medication management, Comprehensive medication management. | Outcomes: Pain rating scale using VAS, Adverse events, Common toxicity criteria.
| Jadad: 3 | Disease: Mixed disease: Mixed disease | | Results: Implantable intrathecal drug delivery systems (IDDSs) improved clinical success in pain control, reduced pain, significantly relieved common drug toxicities, and improved survival.
| Setting: Ambulatory/outpt medical care | Severity: Advanced
| Funding: Medtronic, Inc. | Race: Other
| | Gender: Not reported
Detmar, 2003 ^21^ | Design: RCT/CCT | Sample size: 214 | HRQL questionnaire, Usual care. | Outcomes: Patient/physician communication
| Jadad: 2 | Disease: Mixed disease: Mixed disease | | Results: The HRQL-related issues were discussed significantly more frequently in the intervention than in the control group. Physicians in the intervention group identified a greater percentage of patients with moderate-to-severe health problems in several HRQL domains than did those in the control group. All physicians and 87% of the patients believed that the intervention facilitated communication and expressed interest in its continued use.
| Setting: Ambulatory/outpt medical care | Severity: Unclear
| Funding: Dutch Cancer Society | Race: Other
| | Gender: Females
Jordoy, 2002 ^22^ | Design: RCT/CCT | Sample size: 434 | Palliative Medicine Unit program, Usual care. | Outcomes: Quality of life, Impact of event scale.
| Jadad: 3 | Disease: Mixed disease: Mixed disease | | Results: Neither on pain, emotional and physical functioning, and psychologic distress, nor on any other HRQL dimension did the scores of patients in the intervention program show improvement in comparison with controls.
| Setting: Unclear | Severity: Advanced
| Funding: Norwegian Cancer Society, Norwegian Medical Association Fund for Quality Improvement, Swedish Cancer Society | Race: Other
| | Gender: Not reported
Bruera, 1994 ^23^ | Design: Intervention, comparison group | Sample size: 10 | Morphine, Placebo. | Outcomes: Dyspnea, SaO2 - O2 saturation, Respiratory rate, Pain.
| Jadad: 0 | Disease: Mixed disease: Mixed disease | | Results: Intermittent injections of morphine are safe and effective for the management of dyspnea in terminal cancer.
| Setting: Hospital (non ICU) | Severity: Advanced
| Funding: Not reported | Race: Other
| | Gender: Not reported
Gottlieb, 1999 ^24^ | Design: RCT/CCT | Sample size: 33 | Usual care, Exercise. | Outcomes: Six-minute walk, Depression, Quality of life, Peak VO2, Activities of daily living.
| Jadad: 2 | Disease: Single disease: Heart failure | | Results: Elderly patients with severe heart failure can safely exercise, with an improvement in peak exercise tolerance. However, not all patients will benefit, and daily energy expenditure and quality of life do not improve to the same extent as peak exercise.
| Setting: Ambulatory/outpt medical care | Severity: Advanced and moderate
| Funding: National Institute on Aging, Claude D. Pepper Older Americans Independence Center | Race: Other
| | Gender: Males
Sarna, 1998 ^25^ | Design: RCT/CCT | Sample size: 48 | Usual care, Structured symptom assessment. | Outcomes: Nausea, Dyspnea, Pain frequency, Pain severity, Bowel function, Sleep, Fatique.
| Jadad: 2 | Disease: Single disease: Lung cancer | | Result: High score in depression and more functional limitation were related to higher levels of overall distress. Subjects with more depression and greater functional limitations had greater symptom distress.
| Setting: Ambulatory/outpt medical care | Severity: Advanced
| Funding: American Cancer Society | Race: Other
| | Gender: Not reported
Stephenson, 2000 ^26^ | Design: Intervention, comparison group | Sample size: 23 | Foot reflexology, Usual care. | Outcomes: Pain, Anxiety.
| Jadad: 1 | Disease: Mixed disease: Mixed disease | | Results: Following the foot relexology intervention, patients with breast and lung cancer experienced a significant decrease in anxiety.Patients with breast cancer experienced a significant decrease in pain on one of three measures.
| Setting: Hospital (non ICU) | Severity: Unclear
| Funding: Not reported | Race: Other
| | Gender: Not reported
Abernethy, 2003 ^27^ | Design: RCT/CCT | Sample size: 48 | Morphine, Placebo. | Outcomes: Dyspnea rating using VAS, Side effects, Sleep, Performance on physical exertion.
| Jadad: 5 | Disease: Predominately one disease: Advanced chronic lung disease | | Results: In a community setting, sustained release morphine (oral) at low dosage provided significant improvement in refractory dyspnea.
| Setting: Ambulatory/outpt medical care | Severity: Advanced
| Funding: Flinders Medical Centre Foundation, Doris Duke Charitable Foundation | Race: Other
| | Gender: Not reported

RCT/CCT = Randomized Controlled Trial/Clinical Controlled Trial, VAS = Visual Analogue Scale, ICU = Intensive Care Unit, outpt = Outpatient, TDS = Transdermal Delivery System

## Reference List for Appendix E Evidence Tables

### Reference List for Evidence Table E1

1 Anderson J P, Kaplan R M, Schneiderman L J. Effects of offering advance directives on quality adjusted life expectancy and psychological well-being among ill adults. J Clin Epidemiol. 1994;47(7):761-72. [pmid: 7722589].
2 Campbell ML, Guzman JA. Impact of a proactive approach to improve end-of-life care in a medical ICU. Chest 2003;123(1):266–71. Comment in: Chest 2003 Jan;123(1)16–8.PMID: 12527596.
3 Heffner J E, Fahy B, Hilling L, et al. Outcomes of advance directive education of pulmonary rehabilitation patients. Am J Respir Crit Care Med. 1997;155(3):1055-9. [pmid: 9116986].
4 Holzapfel L, Demingeon G, Piralla B, et al. A four-step protocol for limitation of treatment in terminal care. An observational study in 475 intensive care unit patients. Intensive Care Med 2002;28(9):1309–15. Comment in: Intensive Care Med. 2002 Sep;28(9):1197–9. PMID: 12400561.
5 Jack B, Hillier V, Williams A, et al. Hospital based palliative care teams improve the insight of cancer patients into their disease. Palliat Med. 2004;18(1):46-52. [pmid: 14982207].
6 Lilly C M, De Meo D L, Sonna L A, et al. An intensive communication intervention for the critically ill. Am J Med. 2000;109(6):469-75. [pmid: 11042236].
7 Lilly C M, Sonna L A, Haley K J, et al. Intensive communication: four-year follow-up from a clinical practice study. Crit Care Med. 2003;31(5 Suppl):S394-9. [pmid: 12771590].
8 Ratner E, Norlander L, McSteen K. Death at home following a targeted advance-care planning process at home: the kitchen table discussion. J Am Geriatr Soc 2001;49(6):778–81. Comment in: J Am Geriatr Soc. Jun. 2001;49(6):833-4. PMID: 11454127.
9 Schwartz C E, Wheeler H B, Hammes B, et al. Early intervention in planning end-of-life care with ambulatory geriatric patients: results of a pilot trial. Arch Intern Med. 2002;162(14):1611-8. [pmid: 12123405].
10 Stuart B, D'Onofrio C N, Boatman S, et al. CHOICES: promoting early access to end-of-life care through home-based transition management. J Palliat Med. 2003;6(4):671-83. [pmid: 14516514].
11 Weisbord S D, Carmody S S, Bruns F J, et al. Symptom burden, quality of life, advance care planning and the potential value of palliative care in severely ill haemodialysis patients. Nephrol Dial Transplant 2003;18(7):1345–52. Comment in: Nephrol Dial Transplant. Dec. 2003;18(12):2688. PMID: 14605313.
12 Teno J, Lynn J, Wenger N, et al. Advance directives for seriously ill hospitalized patients: effectiveness with the patient self-determination act and the SUPPORT intervention. SUPPORT Investigators. Study to Understand Prognoses and Preferences for Outcomes and Risks of Treatment. J Am Geriatr Soc 1997;45(4):500–7. Comment in: J Am Geriatr Soc. Apr. 1997;45(4):519-20. PMID: 9100724.
13 Dowdy M D, Robertson C, Bander J A. A study of proactive ethics consultation for critically and terminally ill patients with extended lengths of stay. Critical Care Medicine. 1998;26(2):252-9. [pmid: 9468161].
14 Schneiderman L J, Gilmer T, Teetzel H D, et al. Effect of ethics consultations on nonbeneficial life-sustaining treatments in the intensive care setting: a randomized controlled trial. JAMA. 2003;290(9):1166-72. [pmid: 12952998].
15 Molloy D W, Guyatt G H, Russo R, et al. Systematic implementation of an advance directive program in nursing homes: a randomized controlled trial. JAMA. 2000;283(11):1437-44. [pmid: 10732933].
16 Dexter P R, Wolinsky F D, Gramelspacher G P, et al. Effectiveness of computer-generated reminders for increasing discussions about advance directives and completion of advance directive forms. A randomized, controlled trial. Ann Intern Med. 1998;128(2):102-10.
17 Rubin S M, Strull W M, Fialkow M F, et al. Increasing the completion of the durable power of attorney for health care. A randomized, controlled trial. JAMA. 1994;271(3):209-12.
18 Landry F J, Kroenke K, Lucas C, et al. Increasing the use of advance directives in medical outpatients. J Gen Intern Med. 1997;12(7):412-5. [pmid: 9229279]. [pmcid: 1497131].
19 Marbella A M, Desbiens N A, Mueller-Rizner N, et al. Surrogates' agreement with patients' resuscitation preferences: effect of age, relationship, and SUPPORT intervention Study to Understand Prognoses and Preferences for Outcomes and Risks of Treatment. J Crit Care. 1998;13(3):140-5. [pmid: 9758029].
20 Smucker W D, Ditto P H, Moore K A, et al. Elderly outpatients respond favorably to a physician-initiated advance directive discussion. J Am Board Fam Pract. 1993;6(5):473-82. [pmid: 8213238].

### Reference List for Evidence Table E2

1 Ahrens T, Yancey V, Kollef M. Improving family communications at the end of life: implications for length of stay in the intensive care unit and resource use. Am J Crit Care. 2003;12(4):317-23. discussion 324. [pmid: 12882061].
2 The SUPPORT Principal Investigators. A controlled trial to improve care for seriously ill hospitalized patients. The study to understand prognoses and preferences for outcomes and risks of treatments (SUPPORT). JAMA 1995;274(20):1591–8. Comment in: JAMA. 1995 Nov 22–29;274(20):1634–6. PMID: 7474253. Comment in: JAMA. 1996 Apr 24;275(16):1227–8; author reply 1230–1. PMID: 8601945. Comment in: JAMA. 1996 Apr 24;275(16):1227; author reply 1230–1. PMID: 8601944. Comment in: JAMA. 199.
3 Detmar S B, Muller M J, Schornagel J H, et al. Health-related quality-of-life assessments and patient-physician communication: a randomized controlled trial. JAMA 2002;288(23):3027–34. Comment in: JAMA. 2003 Apr 2;289(13):1636; author reply 1636–7. PMID: 12672729. Erratum in: JAMA. Feb26. 2003;289(8):987.
4 Hughes S L, Weaver F M, Giobbie-Hurder A, et al. Effectiveness of team-managed home-based primary care: a randomized multicenter trial. JAMA. 2000;284(22):2877-85. [pmid: 11147984].
5 Latimer E J, Crabb M R, Roberts J G, et al. The Patient Care Travelling Record in palliative care: effectiveness and efficiency. J Pain Symptom Manage. 1998;16(1):41-51. [pmid: 9707656].
6 Marbella A M, Desbiens N A, Mueller-Rizner N, et al. Surrogates' agreement with patients' resuscitation preferences: effect of age, relationship, and SUPPORT intervention. Study to Understand Prognoses and Preferences for Outcomes and Risks of Treatment. J Crit Care. 1998;13(3):140-5. [pmid: 9758029].
7 Smeenk F W, de Witte L P, van Haastregt J C, et al. Transmural care. A new approach in the care for terminal cancer patients: its effects on re-hospitalization and quality of life. Patient Educ Couns. 1998;35(3):189-99. [pmid: 9887851].
8 Grande G, Todd C J, Barclay S I, et al. Does hospital at home for palliative care facilitate death at home? Randomised controlled trial. BMJ 1999;319(7223):1472–5. Comment in: BMJ. Dec 4. 1999;319(7223):1447-8. PMID: 10582909.
9 Goldberg L R, Piette J D, Walsh M N, et al. Randomized trial of a daily electronic home monitoring system in patients with advanced heart failure: the Weight Monitoring in Heart Failure (WHARF) trial. Am Heart J. 2003;146(4):705-12. [pmid: 14564327].
10 Gorski L A, Johnson K. A disease management program for heart failure: collaboration between a home care agency and a care management organization. Lippincotts Case Manag. 2003;8(6):265-73. [pmid: 14646784].
11 Heidenreich P A, Ruggerio C M, Massie B M. Effect of a home monitoring system on hospitalization and resource use for patients with heart failure. Am Heart J 1999;138(4 Pt 1):633–40. Comment in: Am Heart J. Oct. 1999;138(4 Pt 1):599-601. PMID: 10502199.
12 Jaarsma T, Halfens R, Huijer Abu-Saad H, et al. Effects of education and support on self-care and resource utilization in patients with heart failure. Eur Heart J 1999;20(9):673–82. Comment in: Eur Heart J. May. 1999;20(9):632-3. PMID: 10419340.
13 Philbin E F, Rocco T A, Lindenmuth N W, et al. The results of a randomized trial of a quality improvement intervention in the care of patients with heart failure. The MISCHF Study Investigators. Am J Med 2000;109(6):443–9. Comment in: Am J Med. Oct 15. 2000;109(6):501-3. PMID: 11042244.
14 Riegel B, Carlson B, Kopp Z, et al. Effect of a standardized nurse case-management telephone intervention on resource use in patients with chronic heart failure. Arch Intern Med 2002;162(6):705–12. Comment in: Arch Intern Med. Oct 14. 2002;162(18):2142-3. author reply 2143. PMID: 12374530.
15 Stewart S, Marley J E, Horowitz J D. Effects of a multidisciplinary, home-based intervention on unplanned readmissions and survival among patients with chronic congestive heart failure: a randomised controlled study. Lancet. 1999;354(9184):1077-83. [pmid: 10509499].
16 Mann W C, Ottenbacher K J, Fraas L, et al. Effectiveness of assistive technology and environmental interventions in maintaining independence and reducing home care costs for the frail elderly. A randomized controlled trial. Arch Fam Med 1999;8(3):210–7. Comment in: ACP J Club. Nov-Dec. 1999;131(3):71.
17 Melin A L, Bygren L O. Efficacy of the rehabilitation of elderly primary health care patients after short-stay hospital treatment. Med Care. 1992;30(11):1004-15. [pmid: 1331632].
18 Jerant A F, Azari R, Nesbitt T S. Reducing the cost of frequent hospital admissions for congestive heart failure: a randomized trial of a home telecare intervention. Med Care. 2001;39(11):1234-45. [pmid: 11606877].
19 Stewart S, Pearson S, Horowitz J D. Effects of a home-based intervention among patients with congestive heart failure discharged from acute hospital care. Arch Intern Med. 1998;158(10):1067-72. [pmid: 9605777].
20 Bruera E, Pituskin E, Calder K, et al. The addition of an audiocassette recording of a consultation to written recommendations for patients with advanced cancer: A randomized, controlled trial. Cancer. 1999;86(11):2420-5. [pmid: 10590386].
21 Schneiderman L J, Gilmer T, Teetzel H D. Impact of ethics consultations in the intensive care setting: a randomized, controlled trial. Critical Care Medicine. 2000;28(12):3920-4. [pmid: 11153636].
22 Schneiderman L J, Gilmer T, Teetzel H D, et al. Effect of ethics consultations on nonbeneficial life-sustaining treatments in the intensive care setting: a randomized controlled trial. JAMA. 2003;290(9):1166-72. [pmid: 12952998].
23 Raftery J P, Addington-Hall J M, MacDonald L D, et al. A randomized controlled trial of the cost-effectiveness of a district co-ordinating service for terminally ill cancer patients. Palliat Med. 1996;10(2):151-61. [pmid: 8800823].
24 Selwyn P A, Rivard M, Kappell D, et al. Palliative care for AIDS at a large urban teaching hospital: program description and preliminary outcomes. J Palliat Med. 2003;6(3):461-74. [pmid: 14509496].
25 Stockelberg D, Lehtola P, Noren I. Palliative treatment at home for patients with haematological disorders. Support Care Cancer. 1997;5(6):506-8. [pmid: 9406366].
26 Goodyer L I, Miskelly F, Milligan P. Does encouraging good compliance improve patients' clinical condition in heart failure? Br J Clin Pract 1995;49(4):173–6. Comment in: Br J Clin Pract. Jul-Aug. 1995;49(4):171. PMID: 7547152.
27 Topp R, Tucker D, Weber C. Effect of a clinical case manager/clinical nurse specialist on patients hospitalized with congestive heart failure. Nurs Case Manag. 1998;3(4):140-5. quiz 146–7, 182. [pmid: 9856058].
28 Roglieri J L, Futterman R, McDonough K L, et al. Disease management interventions to improve outcomes in congestive heart failure. Am J Manag Care. 1997;3(12):1831-9. [pmid: 10178473].

### Reference List for Evidence Table E3

1 Baker R, Wu A W, Teno J M, et al. Family satisfaction with end-of-life care in seriously ill hospitalized adults. J Am Geriatr Soc. 2000;48(5 Suppl):S61-9. [pmid: 10809458].
2 The SUPPORT Principal Investigators. A controlled trial to improve care for seriously ill hospitalized patients. The study to understand prognoses and preferences for outcomes and risks of treatments (SUPPORT). JAMA 1995;274(20):1591–8. Comment in: JAMA. 1995 Nov 22–29;274(20):1634–6. PMID: 7474253. Comment in: JAMA. 1996 Apr 24;275(16):1227–8; author reply 1230–1. PMID: 8601945. Comment in: JAMA. Apr 24. 1996;275(16):1227. author reply 1230–1. PMID: 8601944. Comment in: JAMA. 199.
3 Hanks G W, Robbins M, Sharp D, et al. The imPaCT study: a randomised controlled trial to evaluate a hospital palliative care team. Br J Cancer. 2002;87(7):733-9. [pmid: 12232756].
4 Hughes S L, Weaver F M, Giobbie-Hurder A, et al. Effectiveness of team-managed home-based primary care: a randomized multicenter trial. JAMA. 2000;284(22):2877-85. [pmid: 11147984].
5 Ringdal G I, Jordhoy M S, Kaasa S. Family satisfaction with end-of-life care for cancer patients in a cluster randomized trial. J Pain Symptom Manage. 2002;24(1):53-63. [pmid: 12183095].
6 Ringdal G I, Ringdal K, Jordhoy M S, et al. Health-related quality of life (HRQOL) in family members of cancer victims: results from a longitudinal intervention study in Norway and Sweden. Palliat Med. 2004;18(2):108-20. [pmid: 15046407].
7 Walsh S M, Schmidt L A. Telephone support for caregivers of patients with cancer. Cancer Nurs. 2003;26(6):448-53. [pmid: 15022976].
8 Addington-Hall J M, MacDonald L D, Anderson H R, et al. Randomised controlled trial of effects of coordinating care for terminally ill cancer patients. BMJ. 1992;305(6865):1317-22. [pmid: 1483075]. [pmcid: 1883850].
9 Grande G E, Todd C J, Barclay S I, et al. A randomized controlled trial of a hospital at home service for the terminally ill. Palliat Med. 2000;14(5):375-85. [pmid: 11064784].
10 Gitlin L N, Belle S H, Burgio L D, et al. Effect of multicomponent interventions on caregiver burden and depression: the REACH multisite initiative at 6-month follow-up. Psychol Aging. 2003;18(3):361-74. [pmid: 14518800].
11 Smeenk F W, de Witte L P, van Haastregt J C, et al. Transmural care of terminal cancer patients: effects on the quality of life of direct caregivers. Nurs Res. 1998;47(3):129-36. [pmid: 9610646].
12 Bucher J A, Loscalzo M, Zabora J, et al. Problem-solving cancer care education for patients and caregivers. Cancer Practice. 2001;9(2):66-70. [pmid: 11879281].
13 Burgio L, Stevens A, Guy D, et al. Impact of two psychosocial interventions on white and African American family caregivers of individuals with dementia. Gerontologist. 2003;43(4):568-79. [pmid: 12937335].
14 Burns R, Nichols L O, Martindale-Adams J, et al. Primary care interventions for dementia caregivers: 2-year outcomes from the REACH study. Gerontologist. 2003;43(4):547-55. [pmid: 12937333].
15 Eisdorfer C, Czaja S J, Loewenstein D A, et al. The effect of a family therapy and technology-based intervention on caregiver depression. Gerontologist. 2003;43(4):521-31. [pmid: 12937331].
16 Gitlin L N, Winter L, Corcoran M, et al. Effects of the home environmental skill-building program on the caregiver-care recipient dyad: 6-month outcomes from the Philadelphia REACH Initiative. Gerontologist. 2003;43(4):532-46. [pmid: 12937332].
17 Mahoney D F, Tarlow B J, Jones R N. Effects of an automated telephone support system on caregiver burden and anxiety: findings from the REACH for TLC intervention study. Gerontologist. 2003;43(4):556-67. [pmid: 12937334].

### Reference List for Evidence Table E4

1 Bookbinder M, Coyle N, Kiss M. Implementing national standards for cancer pain management: program model and evaluation. J Pain Symptom Manage. 1996;12(6):334-47. discussion 331–3. [pmid: 8973043].
2 Brumley R D, Enguidanos S, Cherin D A. Effectiveness of a home-based palliative care program for end-of-life. J Palliat Med. 2003;6(5):715-24. [pmid: 14622451].
3 Hanks G W, Robbins M, Sharp D, et al. The imPaCT study: a randomised controlled trial to evaluate a hospital palliative care team. Br J Cancer. 2002;87(7):733-9. [pmid: 12232756].
4 Hughes S L, Weaver F M, Giobbie-Hurder A, et al. Effectiveness of team-managed home-based primary care: a randomized multicenter trial. JAMA. 2000;284(22):2877-85. [pmid: 11147984].
5 Latimer E J, Crabb M R, Roberts J G, et al. The Patient Care Travelling Record in palliative care: effectiveness and efficiency. J Pain Symptom Manage. 1998;16(1):41-51. [pmid: 9707656].
6 Rabow M W, Dibble S L, Pantilat S Z, et al. The comprehensive care team: a controlled trial of outpatient palliative medicine consultation. Arch Intern Med. 2004;164(1):83-91. [pmid: 14718327].
7 Ringdal G I, Jordhoy M S, Kaasa S. Family satisfaction with end-of-life care for cancer patients in a cluster randomized trial. J Pain Symptom Manage. 2002;24(1):53-63. [pmid: 12183095].
8 Grande G E, Todd C J, Barclay S I, et al. A randomized controlled trial of a hospital at home service for the terminally ill. Palliat Med. 2000;14(5):375-85. [pmid: 11064784].
9 Schneiderman L J, Gilmer T, Teetzel H D, et al. Effect of ethics consultations on nonbeneficial life-sustaining treatments in the intensive care setting: a randomized controlled trial. JAMA. 2003;290(9):1166-72. [pmid: 12952998].
10 Molloy D W, Guyatt G H, Russo R, et al. Systematic implementation of an advance directive program in nursing homes: a randomized controlled trial. JAMA. 2000;283(11):1437-44. [pmid: 10732933].
11 Weisbord S D, Carmody S S, Bruns F J, et al. Symptom burden, quality of life, advance care planning and the potential value of palliative care in severely ill haemodialysis patients. Nephrol Dial Transplant 2003;18(7):1345–52. Comment in: Nephrol Dial Transplant. 2003;18(7):2688. PMID: 14605313.
12 Riegel B, Carlson B, Kopp Z, et al. Effect of a standardized nurse case-management telephone intervention on resource use in patients with chronic heart failure. Arch Intern Med 2002;162(6):705–12. Comment in: Arch Intern Med. Oct 14. 2002;162(18):2142-3. ; author reply 2143. PMID: 12374530.
13 Bruera E, Pituskin E, Calder K, et al. The addition of an audiocassette recording of a consultation to written recommendations for patients with advanced cancer: A randomized, controlled trial. Cancer. 1999;86(11):2420-5. [pmid: 10590386].
14 Pietersma P, Follett-Bick S, Wilkinson B, et al. A bedside food cart as an alternate food service for acute and palliative oncological patients. Support Care Cancer. 2003;11(9):611-4. [pmid: 12883966].

### Reference List for Evidence Table E5

1 Booth S, Kelly M J, Cox N P, et al. Does oxygen help dyspnea in patients with cancer?. Am J Respir Crit Care Med. 1996;153(5):1515-8. [pmid: 8630595].
2 Bruera E, de Stoutz N, Velasco-Leiva A, et al. Effects of oxygen on dyspnea in hypoxaemic terminal-cancer patients. Lancet. 1993;342(8862):13-4. [pmid: 8100289].
3 Jack B, Hillier V, Williams A, et al. Hospital based palliative care teams improve the symptoms of cancer patients. Palliat Med. 2003;17(6):498-502. [pmid: 14526882].
4 Latimer E J, Crabb M R, Roberts J G, et al. The Patient Care Travelling Record in palliative care: effectiveness and efficiency. J Pain Symptom Manage. 1998;16(1):41-51. [pmid: 9707656].
5 Mazzocato C, Buclin T, Rapin C H. The effects of morphine on dyspnea and ventilatory function in elderly patients with advanced cancer: a randomized double-blind controlled trial. Ann Oncol. 1999;10 (12):1511-4. [pmid: 10643545].
6 Mercadante S, Fulfaro F, Casuccio A. A randomised controlled study on the use of anti-inflammatory drugs in patients with cancer pain on morphine therapy: effects on dose-escalation and a pharmacoeconomic analysis. Eur J Cancer. 2002;38(10):1358-63. [pmid: 12091067].
7 Rabow M W, Dibble S L, Pantilat S Z, et al. The comprehensive care team: a controlled trial of outpatient palliative medicine consultation. Arch Intern Med. 2004;164(1):83-91. [pmid: 14718327].
8 Schofield P, Payne S. A pilot study into the use of a multisensory environment (Snoezelen) within a palliative day-care setting. Int J Palliat Nurs 2003;9(3):124–30. Erratum in: Int J Palliat Nurs. Apr. 2003;9(4):178.
9 Simmons S F, Ferrell B A, Schnelle J F. Effects of a controlled exercise trial on pain in nursing home residents. Clin J Pain. 2002;18(6):380-5. [pmid: 12441832].
10 Soden K, Vincent K, Craske S, et al. A randomized controlled trial of aromatherapy massage in a hospice setting. Palliat Med. 2004;18(2):87-92. [pmid: 15046404].
11 Wilkinson S, Aldridge J, Salmon I, et al. An evaluation of aromatherapy massage in palliative care. Palliat Med. 1999;13(5):409-17. [pmid: 10659113].
12 Addington-Hall J M, MacDonald L D, Anderson H R, et al. Randomised controlled trial of effects of coordinating care for terminally ill cancer patients. BMJ. 1992;305(6865):1317-22. [pmid: 1483075]. [pmcid: 1883850].
13 Grande G E, Todd C J, Barclay S I, et al. A randomized controlled trial of a hospital at home service for the terminally ill. Palliat Med. 2000;14(5):375-85. [pmid: 11064784].
14 Rogers J C, Holm M B, Burgio L D, et al. Improving morning care routines of nursing home residents with dementia. J Am Geriatr Soc 1999;47(9):1049–57. Comment in: J Am Geriatr Soc. Sep. 1999;47(9):1151-2. PMID: 10484262.
15 Rovner B W, Steele C D, Shmuely Y, et al. A randomized trial of dementia care in nursing homes. J Am Geriatr Soc 1996;44(1):7–13. Comment in: J Am Geriatr Soc. 1996 Jan;44(1):91–2. PMID: 8537599. Comment in: J Am Geriatr Soc. Oct. 1996;44(10):1277-8. PMID: 8856018.
16 Sultzer D L, Gray K F, Gunay I, et al. Does behavioral improvement with haloperidol or trazodone treatment depend on psychosis or mood symptoms in patients with dementia?. J Am Geriatr Soc. 2001;49(10):1294-300. [pmid: 11890487].
17 Weiner P, Waizman J, Magadle R, et al. The effect of specific inspiratory muscle training on the sensation of dyspnea and exercise tolerance in patients with congestive heart failure. Clin Cardiol. 1999;22(11):727-32. [pmid: 10554688].
18 Manfredi P L, Breuer B, Wallenstein S, et al. Opioid treatment for agitation in patients with advanced dementia. International Journal of Geriatric Psychiatry. 2003;18(8):700-5. [pmid: 12891637].
19 Sittl R, Griessinger N, Likar R. Analgesic efficacy and tolerability of transdermal buprenorphine in patients with inadequately controlled chronic pain related to cancer and other disorders: a multicenter, randomized, double-blind, placebo-controlled trial. Clinical Therapeutics. 2003;25(1):150-68. [pmid: 12637117].
20 Smith T J, Staats P S, Deer T, et al. Randomized clinical trial of an implantable drug delivery system compared with comprehensive medical management for refractory cancer pain: impact on pain, drug-related toxicity, and survival. Journal of Clinical Oncology. 2002;20(19):4040-9. [pmid: 12351602].
21 Detmar S B, Muller M J, Schornagel J H, et al. Health-related quality-of-life assessments and patient-physician communication: a randomized controlled trial. JAMA 2002;288(23):3027–34. Comment in: JAMA. 2003 Apr 2;289(13):1636; author reply 1636–7. PMID: 12672729. Erratum in: JAMA. Feb 26. 2003;289(8):987.
22 Jordhoy M S, Fayers P, Loge J H, et al. Quality of life in palliative cancer care: results from a cluster randomized trial. J Clin Oncol 2001;19(18):3884–94. Comment in: J Clin Oncol. Mar 15. 2002;20(6):1704-5. PMID: 11896122.
23 Bruera E, MacEachern T, Ripamonti C, et al. Subcutaneous morphine for dyspnea in cancer patients. Ann Intern Med 1993;119(9):906–7. Comment in: Ann Intern Med. Apr 15. 1994;120(8):692-3. PMID: 8192764.
24 Gottlieb S S, Fisher M L, Freudenberger R, et al. Effects of exercise training on peak performance and quality of life in congestive heart failure patients. J Card Fail. 1999;5(3):188-94. [pmid: 10496191].
25 Sarna L. Effectiveness of structured nursing assessment of symptom distress in advanced lung cancer. Oncol Nurs Forum. 1998;25(6):1041-8. [pmid: 9679262].
26 Stephenson N L, Weinrich S P, Tavakoli A S. The effects of foot reflexology on anxiety and pain in patients with breast and lung cancer. Oncol Nurs Forum 2000;27(1):67–72. Comment in: Oncol Nurs Forum. Apr. 2001;28(3):445-6. PMID: 11338752.
27 Abernethy A P, Currow D C, Frith P, et al. Randomised, double blind, placebo controlled crossover trial of sustained release morphine for the management of refractory dyspnoea. BMJ. 2003;327(7414):523-8. [pmid: 12958109]. [pmcid: 192892].