# Appendix D

## Appendix D1. Sample: Abstract Screening Form

End of Life Care and Outcomes

FINAL ABSTRACT SCREENER

## Appendix D2. Sample: Systematic Review Short Form

End of Life Care and Outcomes

SYSTEMATIC REVIEW FINAL SCREENER