# Appendix C. Health Canada Reports

Table C1. Health Canada Reports- Relevant to Key Questions

Study | Report Title | Relevant to Key Questions
Wilson, D (in press) ^1^ | Outcomes and Evaluation of end of life care | Yes
Wilson, D (in press) ^2^ | The needs of dying persons | Yes
Wilson, D (in press) ^3^ | End of life case management | Yes
Wilson, D (in press) ^4^ | The needs of the families of dying persons | Yes
Wilson, D (in press) ^5^ | Continuity of end of life care | Yes
Wilson, D (in press) ^6^ | Managing End of life pain and other symptoms through non-pharmacological means | Yes
Wilson, D (in press) ^7^ | End of life spiritual and psychosocial issues | Yes
Wilson, D (in press) ^8^ | End of life care in acute care hospitals | Yes
Wilson, D (in press) ^9^ | End of life care in residential continuing-care facilities | Yes
Wilson, D (in press) ^10^ | Culture and end of life care | Yes
Wilson, D (in press) ^11^ | The home as a place of end of life care | Yes
Wilson, D (in press) ^12^ | Gender differences in the experience of the dying process | Yes
Wilson, D (in press) ^13^ | End of life care in intensive care units | Yes
Wilson, D (in press) ^14^ | End of life care in rural or remote areas | Yes

Table C2. Health Canada Reports - Not Relevant to Key Questions

Author | Report Title | Relevant to Key Questions
Wilson, D (in press) | Australia site visit report | No
Wilson, D (in press) | Bereavement | No
Wilson, D (in press) | Canadian end of life care programs, models, and approaches | No
Wilson, D (in press) | End of life topics addressed in randomized controlled clinical trials research | No
Wilson, D (in press) | Palliative day care | No
Wilson, D (in press) | Integrated end of life care: a Health Canada synthesis research project | No
Wilson, D (in press) | New developments in end of life care | No
Wilson, D (in press) | Pediatric end of life care | No
Wilson, D (in press) | End of life prognostication | No
Wilson, D (in press) | Web-based questionnaire data analysis report | No
Wilson, D (in press) | End of life respite care | No
Wilson, D (in press) | Literature reviews that have focused on end of life care | No
Wilson, D (in press) | New Zealand site visit report | No
Wilson, D (in press) | International end of life care delivery models or approaches | No
Wilson, D (in press) | Provincial home care data analysis report | No
Wilson, D (in press) | Education in Canada for end of life care | No
Wilson, D (in press) | Canada site visit report | No
Wilson, D (in press) | Aboriginal end of life care | No

## Reference List

1 In: Wilson D. Outcomes and Evaluation of end of life care. Edmonton, Alberta Canada: University of Alberta. draft in press.
2 In: Wilson D. The needs of dying persons. Edmonton, Alberta Canada: University of Alberta. draft in press.
3 In: Wilson D. End of life case management. Edmonton, Alberta Canada: University of Alberta. draft in press.
4 In: Wilson D. The needs of the families of dying persons. Edmonton, Alberta Canada: University of Alberta. draft in press.
5 In: Wilson D. Continuity of end of life care. Edmonton, Alberta Canada: University of Alberta. draft in press.
6 In: Wilson D. Managing End of life pain and other symptoms through non-pharmacological means. Edmonton, Alberta Canada: University of Alberta. draft in press.
7 In: Wilson D. End of life spiritual and psychosocial issues. Edmonton, Alberta Canada: University of Alberta. draft in press.
8 In: Wilson D. End of life care in acute care hospitals. Edmonton, Alberta Canada: University of Alberta. draft in press.
9 In: Wilson D. End of life care in residential continuing-care facilities. Edmonton, Alberta Canada: University of Alberta. draft in press.
10 In: Wilson D. Culture and end of life care. Edmonton, Alberta Canada: University of Alberta. draft in press.
11 In: Wilson D. The home as a place of end of life care. Edmonton, Alberta Canada: University of Alberta. draft in press.
12 In: Wilson D. Gender differences in the experience of the dying process. Edmonton, Alberta Canada: University of Alberta. draft in press.
13 In: Wilson D. End of life care in intensive care units. Edmonton, Alberta Canada: University of Alberta. draft in press.
14 In: Wilson D. End of life care in rural or remote areas. Edmonton, Alberta Canada: University of Alberta. draft in press.