# Appendix M. Included Studies

Abernethy A P, Currow D C, Frith P, Fazekas B S, McHugh A, Bui C. Randomised, double blind, placebo controlled crossover trial of sustained release morphine for the management of refractory dyspnoea. BMJ. 2003;327(7414):523-8. [Rec#: 50928] INCLUDE: considered for evidence table. [pmid: 12958109]. [pmcid: 192892].
Abratt R, Viljoen G. Assessment of quality of life by clinicians—experience of a practical method in lung cancer patients. S Afr Med J. 95;85(9):896-8. [Rec#: 30022] INCLUDE: considered for evidence table. [pmid: 8545754].
Addington-Hall J, Fakhoury W, McCarthy M. Specialist palliative care in nonmalignant disease. Palliat Med. 98;12(6):417-27. [Rec#: 9055] INCLUDE: considered for evidence table. [pmid: 10621861].
Addington-Hall J M, MacDonald L D, Anderson H R, Chamberlain J, Freeling P, Bland J M, Raftery J. Randomised controlled trial of effects of coordinating care for terminally ill cancer patients. BMJ. 92;305(6865):1317-22. [Rec#: 9059] INCLUDE: considered for evidence table.
Addington-Hall J, Altmann D, McCarthy M. Which terminally ill cancer patients receive hospice in-patient care?. Social Science & Medicine. 98;46(8):1011-6. [Rec#: 50168] INCLUDE: considered for evidence table. [pmid: 9579752].
Addington-Hall J, Lay M, Altmann D, McCarthy M. Symptom control, communication with health professionals, and hospital care of stroke patients in the last year of life as reported by surviving family, friends, and officials. Stroke. 95;26(12):2242-8. [Rec#: 50169] INCLUDE: considered for evidence table.
Ahrens T, Yancey V, Kollef M. Improving family communications at the end of life: implications for length of stay in the intensive care unit and resource use. Am J Crit Care. 2003;12(4):317-23. discussion 324. [Rec#: 77] INCLUDE: considered for evidence table. [pmid: 12882061].
Ahronheim J C, Morrison R S, Baskin S A, Morris J, Meier D E. Treatment of the dying in the acute care hospital. Advanced dementia and metastatic cancer. Arch Intern Med. 96;156(18):2094-100. [Rec#: 79] INCLUDE: considered for evidence table.
Albanese M C, Plewka M, Gregori D, Fresco C, Avon G, Caliandro D, Grassi L, Rossi P, Udina P, Bulfoni A, Colle R, Cuzzato A L, Fioretti P M. Use of medical resources and quality of life of patients with chronic heart failure: a prospective survey in a large Italian community hospital. Eur J Heart Fail. 99;1(4):411-7. [Rec#: 30090] INCLUDE: considered for evidence table.
Albert S M, Murphy P L, Del Bene M L, Rowland L P. Prospective study of palliative care in ALS: choice, timing, outcomes. J Neurol Sci. 99;169(12):108-13. [Rec#: 103] INCLUDE: considered for evidence table. [pmid: 10540017].
Allen R S, DeLaine S R, Chaplin W F, Marson D C, Bourgeois M S, Dijkstra K, Burgio L D. Advance care planning in nursing homes: correlates of capacity and possession of advance directives. Gerontologist. 2003;43(3):309-17. [Rec#: 50173] INCLUDE: considered for evidence table. [pmid: 12810894].
Allen R S, Haley W E, Small B J, McMillan S C. Pain reports by older hospice cancer patients and family caregivers: the role of cognitive functioning. Gerontologist. 2002;42(4):507-14. [Rec#: 50174] INCLUDE: considered for evidence table. [pmid: 12145378].
Anderson H, Ward C, Eardley A, Gomm S A, Connolly M, Coppinger T, Corgie D, Williams J L, Makin W P. The concerns of patients under palliative care and a heart failure clinic are not being met. Palliat Med. 2001;15(4):279-86. [Rec#: 183] INCLUDE: considered for evidence table. [pmid: 12054145].
Anderson J P, Kaplan R M, Schneiderman L J. Effects of offering advance directives on quality adjusted life expectancy and psychological well-being among ill adults. J Clin Epidemiol. 94;47(7):761-72. [Rec#: 186] INCLUDE: considered for evidence table.
Andrews S C. Caregiver burden and symptom distress in people with cancer receiving hospice care. Oncol Nurs Forum. 2001;28(9):1469-74. [Rec#: 196] INCLUDE: considered for evidence table. [pmid: 11683316].
Ankrom M, Zelesnick L, Barofsky I, Georas S, Finucane T E, Greenough W B 3rd. Elective discontinuation of life-sustaining mechanical ventilation on a chronic ventilator unit. J Am Geriatr Soc. 2001;49(11):1549-54. [Rec#: 202] INCLUDE: considered for evidence table. [pmid: 11890598].
Aranda S K, Hayman-White K. Home caregivers of the person with advanced cancer: an Australian perspective. Cancer Nurs. 2001;24(4):300-7. [Rec#: 221] INCLUDE: considered for evidence table. [pmid: 11502039].
Arblaster G, Brooks D, Hudson R, Petty M. Terminally ill patients' expectations of nurses. Aust J Adv Nurs. 90;7(3):34-43. [Rec#: 9201] INCLUDE: considered for evidence table. [pmid: 2242256].
Armes P J, Higginson I J. What constitutes high-quality HIV/AIDS palliative care?. J Palliat Care. 99;15(4):5-12. [Rec#: 9215] INCLUDE: considered for evidence table. [pmid: 10693300].
Asch D A, Faber-Langendoen K, Shea J A, Christakis N A. The sequence of withdrawing life-sustaining treatment from patients. Am J Med. 99;107(2):153-6. [Rec#: 242] INCLUDE: considered for evidence table. [pmid: 10460047].
Ashbury F D, Findlay H, Reynolds B, McKerracher K. A Canadian survey of cancer patients' experiences: are their needs being met?. J Pain Symptom Manage. 98;16(5):298-306. [Rec#: 245] INCLUDE: considered for evidence table. [pmid: 9846024].
Astradsson E, Granath L, Heedman P A, Starkhammar H. Cancer patients hospitalised for palliative reasons. Symptoms and needs presented at a university hospital. Support Care Cancer. 2001;9(2):97-102. [Rec#: 254] INCLUDE: considered for evidence table. [pmid: 11305076].
Azoulay E, Chevret S, Leleu G, Pochard F, Barboteu M, Adrie C, Canoui P, Le Gall J R, Schlemmer B. Half the families of intensive care unit patients experience inadequate communication with physicians. Critical Care Medicine. 2000;28(8):3044-9. [Rec#: 50193] INCLUDE: considered for evidence table. [pmid: 10966293].
Baer W M, Hanson L C. Families' perception of the added value of hospice in the nursing home. J Am Geriatr Soc 2000;48(8):879–82. Comment in: J Am Geriatr Soc. 2000 Aug;48(8):1017–8. PMID: 10968312. Comment in: J Am Geriatr Soc. Apr. 2001;49(4):492. PMID: 11347800. [Rec#: 296] INCLUDE: considered for evidence table.
Baines B K, Norlander L. The relationship of pain and suffering in a hospice population. Am J Hosp Palliat Care. 2000;17(5):319-26. [Rec#: 309] INCLUDE: considered for evidence table. [pmid: 11886056].
Bakas T, Lewis R R, Parsons J E. Caregiving tasks among family caregivers of patients with lung cancer. Oncol Nurs Forum. 2001;28(5):847-54. [Rec#: 30289] INCLUDE: considered for evidence table. [pmid: 11421144].
Baker N T, Seager R D. A comparison of the psychosocial needs of hospice patients with AIDS and those with other diagnoses. Hosp J. 91;7(12):61-9. [Rec#: 323] INCLUDE: considered for evidence table. [pmid: 1937439].
Baker R, Wu A W, Teno J M, Kreling B, Damiano A M, Rubin H R, Roach M J, Wenger N S, Phillips R S, Desbiens N A, Connors A F Jr, Knaus W, Lynn J. Family satisfaction with end-of-life care in seriously ill hospitalized adults. J Am Geriatr Soc. 2000;48(5 Suppl):S61-9. [Rec#: 324] INCLUDE: considered for evidence table. [pmid: 10809458].
Balmer C E, Thomas P, Osborne R J. Who wants second-line, palliative chemotherapy?. Psychooncology. 2001;10(5):410-8. [Rec#: 351] INCLUDE: considered for evidence table. [pmid: 11536419].
Barry L C, Kasl S V, Prigerson H G. Psychiatric disorders among bereaved persons: the role of perceived circumstances of death and preparedness for death. Am J Geriatr Psychiatry. 2002;10(4):447-57. [Rec#: 394] INCLUDE: considered for evidence table. [pmid: 12095904].
Bass D M, Bowman K. The transition from caregiving to bereavement: the relationship of care-related strain and adjustment to death. Gerontologist. 90;30(1):35-42. [Rec#: 412] INCLUDE: considered for evidence table. [pmid: 2311960].
Bass D M, Bowman K, Noelker L S. The influence of caregiving and bereavement support on adjusting to an older relative's death. Gerontologist. 91;31(1):32-42. [Rec#: 413] INCLUDE: considered for evidence table. [pmid: 2007473].
Bauduer F, Capdupuy C, Renoux M. Characteristics of deaths in a department of oncohaematology within a general hospital. A study of 81 cases. Support Care Cancer. 2000;8(4):302-6. [Rec#: 433] INCLUDE: considered for evidence table. [pmid: 10923770].
Beck-Friis B, Strang P. The family in hospital-based home care with special reference to terminally ill cancer patients. J Palliat Care. 93;9(1):5-13. [Rec#: 447] INCLUDE: considered for evidence table. [pmid: 8492238].
Beguin C, France F R, Ninane J. Systematic analysis of in-patients' circumstances and causes of death: a tool to improve quality of care. Int J Qual Health Care. 97;9(6):427-33. [Rec#: 40235] INCLUDE: considered for evidence table.
Bennett S J, Perkins S M, Lane K A, Deer M, Brater D C, Murray M D. Social support and health-related quality of life in chronic heart failure patients. Qual Life Res. 2001;10(8):671-82. [Rec#: 30411] INCLUDE: considered for evidence table. [pmid: 11871588].
Bercovitch M, Waller A, Adunsky A. High dose morphine use in the hospice setting. A database survey of patient characteristics and effect on life expectancy. Cancer 99;86(5):871–7. Comment in: Cancer. Jul 1. 2000;89(1):220-1. PMID: 10897022. [Rec#: 499] INCLUDE: considered for evidence table.
Bernabei R, Gambassi G, Lapane K, Landi F, Gatsonis C, Dunlop R, Lipsitz L, Steel K, Mor V. Management of pain in elderly patients with cancer. SAGE Study Group. Systematic Assessment of Geriatric Drug Use via Epidemiology. JAMA. 98;279(23):1877-82. [Rec#: 50214] INCLUDE: considered for evidence table.
Blackhall L J, Frank G, Murphy S T, Michel V, Palmer J M, Azen S P. Ethnicity and attitudes towards life sustaining technology. Soc Sci Med. 99;48(12):1779-89. [Rec#: 591] INCLUDE: considered for evidence table. [pmid: 10405016].
Blackhall L J, Murphy S T, Frank G, Michel V, Azen S. Ethnicity and attitudes toward patient autonomy. JAMA 95;274(10):820–5. Comment in: JAMA. 1995 Sep 13;274(10):844–5. PMID: 7650810. Comment in: JAMA. 1996 Jan 10;275(2):107; author reply 109–10. PMID: 8531296. Comment in: JAMA. Jan 10. 1996;275(2):107. author reply 109–10. PMID: 8531297. [Rec#: 592] INCLUDE: considered for evidence table.
Bodnar J C, Kiecolt-Glaser J K. Caregiver depression after bereavement: chronic stress isn't over when it's over. Psychol Aging. 94;9(3):372-80. [Rec#: 623] INCLUDE: considered for evidence table. [pmid: 7999322].
Bookbinder M, Coyle N, Kiss M, Goldstein M L, Holritz K, Thaler H, Gianella A, Derby S, Brown M, Racolin A, Ho M N, Portenoy R K. Implementing national standards for cancer pain management: program model and evaluation. J Pain Symptom Manage. 96;12(6):334-47. discussion 331–3. [Rec#: 659] INCLUDE: considered for evidence table.
Bookwala J, Coppola K M, Fagerlin A, Ditto P H, Danks J H, Smucker W D. Gender differences in older adults' preferences for life-sustaining medical treatments and end-of-life values. Death Stud. 2001;25(2):127-49. [Rec#: 660] INCLUDE: considered for evidence table. [pmid: 11708352].
Booth S, Kelly M J, Cox N P, Adams L, Guz A. Does oxygen help dyspnea in patients with cancer?. Am J Respir Crit Care Med. 96;153(5):1515-8. [Rec#: 665] INCLUDE: considered for evidence table. [pmid: 8630595].
Borum M L, Lynn J, Zhong Z. The effects of patient race on outcomes in seriously ill patients in SUPPORT: an overview of economic impact, medical intervention, and end-of-life decisions. Study to Understand Prognoses and Preferences for Outcomes and Risks of Treatments. J Am Geriatr Soc. 2000;48(5 Suppl):S194-8. [Rec#: 685] INCLUDE: considered for evidence table. [pmid: 10809475].
Bosek M S, Lowry E, Lindeman D A, Burck J R, Gwyther L P. Promoting a good death for persons with dementia in nursing facilities: family caregivers' perspectives. JONAS Healthc Law Ethics Regul. 2003;5(2):34-41. [Rec#: 690] INCLUDE: considered for evidence table. [pmid: 12789031].
Bostrom B, Sandh M, Lundberg D, Fridlund B. A comparison of pain and health-related quality of life between two groups of cancer patients with differing average levels of pain. J Clin Nurs. 2003;12(5):726-35. [Rec#: 697] INCLUDE: considered for evidence table. [pmid: 12919219].
Bostrom B, Sandh M, Lundberg D, Fridlund B. Cancer-related pain in palliative care: patients' perceptions of pain management. J Adv Nurs. 2004;45(4):410-9. [Rec#: 696] INCLUDE: considered for evidence table. [pmid: 14756835].
Boyd K J, Kelly M. Oral morphine as symptomatic treatment of dyspnoea in patients with advanced cancer. Palliat Med. 97;11(4):277-81. [Rec#: 731] INCLUDE: considered for evidence table. [pmid: 9373578].
Bradley E H, Hallemeier A G, Fried T R, Johnson-Hurzeler R, Cherlin E J, Kasl S V, Horwitz S M. Documentation of discussions about prognosis with terminally ill patients. Am J Med. 2001;111(3):218-23. [Rec#: 743] INCLUDE: considered for evidence table. [pmid: 11530033].
Bradley E H, Peiris V, Wetle T. Discussions about end-of-life care in nursing homes. J Am Geriatr Soc. 98;46(10):1235-41. [Rec#: 744] INCLUDE: considered for evidence table. [pmid: 9777905].
Brazil K, Bedard M, Willison K, Hode M. Caregiving and its impact on families of the terminally ill. Aging and Mental Health. 2003;7(5):376-82. [Rec#: 50230] INCLUDE: considered for evidence table. [pmid: 12959807].
Breitbart W, Gibson C, Tremblay A. The delirium experience: delirium recall and delirium-related distress in hospitalized patients with cancer, their spouses/caregivers, and their nurses. Psychosomatics. 2002;43(3):183-94. [Rec#: 50234] INCLUDE: considered for evidence table. [pmid: 12075033].
Breitbart W, McDonald M V, Rosenfeld B, Passik S D, Hewitt D, Thaler H, Portenoy R K. Pain in ambulatory AIDS patients. I: Pain characteristics and medical correlates. Pain. 96;68(23):315-21. [Rec#: 50236] INCLUDE: considered for evidence table.
Breitbart W, Tremblay A, Gibson C. An open trial of olanzapine for the treatment of delirium in hospitalized cancer patients. Psychosomatics. 2002;43(3):175-82. [Rec#: 50237] INCLUDE: considered for evidence table. [pmid: 12075032].
Brown D, Roberts J A, Elkins T E, Larson D, Hopkins M. Hard choices: the gynecologic cancer patient's end-of-life preferences. Gynecol Oncol. 94;55(3 Pt 1):355-62. [Rec#: 835] INCLUDE: considered for evidence table. [pmid: 7835774].
Brown J E, Brown R F, Miller R M, Dunn S M, King M T, Coates A S, Butow P N. Coping with metastatic melanoma: the last year of life. Psychooncology. 2000;9(4):283-92. [Rec#: 844] INCLUDE: considered for evidence table. [pmid: 10960926].
Brown R, Butow P N, Boyer M J, Tattersall M H. Promoting patient participation in the cancer consultation: evaluation of a prompt sheet and coaching in question-asking. British Journal of Cancer. 99;80(12):242-8. [Rec#: 50244] INCLUDE: considered for evidence table.
Bruera E, de Stoutz N, Velasco-Leiva A, Schoeller T, Hanson J. Effects of oxygen on dyspnea in hypoxaemic terminal-cancer patients. Lancet. 93;342(8862):13-4. [Rec#: 866] INCLUDE: considered for evidence table. [pmid: 8100289].
Bruera E, Kuehn N, Emery B, Macmillan K, Hanson J. Social and demographic characteristics of patients admitted to a palliative care unit. J Palliat Care. 90;6(4):16-20. [Rec#: 867] INCLUDE: considered for evidence table. [pmid: 1704909].
Bruera E, MacEachern T, Ripamonti C, Hanson J. Subcutaneous morphine for dyspnea in cancer patients. Ann Intern Med 93;119(9):906–7. Comment in: Ann Intern Med. Apr 15. 1994;120(8):692-3. PMID: 8192764. [Rec#: 9839] INCLUDE: considered for evidence table.
Bruera E, Miller M J, Kuehn N, MacEachern T, Hanson J. Estimate of survival of patients admitted to a palliative care unit: a prospective study. J Pain Symptom Manage. 92;7(2):82-6. [Rec#: 870] INCLUDE: considered for evidence table.
Bruera E, Neumann C M, Gagnon B, Brenneis C, Kneisler P, Selmser P, Hanson J. Edmonton Regional Palliative Care Program: impact on patterns of terminal cancer care. CMAJ. 99;161(3):290-3. [Rec#: 9842] INCLUDE: considered for evidence table.
Bruera E, Sloan P, Mount B, Scott J, Suarez-Almazor M. A randomized, double-blind, double-dummy, crossover trial comparing the safety and efficacy of oral sustained-release hydromorphone with immediate-release hydromorphone in patients with cancer pain. Canadian Palliative Care Clinical Trials Group. J Clin Oncol. 96;14(5):1713-7. [Rec#: 877] INCLUDE: considered for evidence table.
Bruera E, Sweeney C, Calder K, Palmer L, Benisch-Tolley S. Patient preferences versus physician perceptions of treatment decisions in cancer care. J Clin Oncol. 2001;19(11):2883-5. [Rec#: 879] INCLUDE: considered for evidence table. [pmid: 11387361].
Bruera E, Sweeney C, Willey J, Palmer J L, Strasser F, Strauch E. Perception of discomfort by relatives and nurses in unresponsive terminally ill patients with cancer: a prospective study. J Pain Symptom Manage. 2003;26(3):818-26. [Rec#: 881] INCLUDE: considered for evidence table. [pmid: 12967730].
Bruera E, Belzile M, Neumann C M, Ford I, Harsanyi Z, Darke A. Twice-daily versus once-daily morphine sulphate controlled-release suppositories for the treatment of cancer pain. A randomized controlled trial. Supportive Care in Cancer. 99;7(4):280-3. [Rec#: 50246] INCLUDE: considered for evidence table.
Bruera E, Brenneis C, Michaud M, Bacovsky R, Chadwick S, Emeno A, MacDonald N. Use of the subcutaneous route for the administration of narcotics in patients with cancer pain. Cancer. 88;62(2):407-11. [Rec#: 50249] INCLUDE: considered for evidence table.
Bruera E, Brenneis C, Michaud M, Chadwick S, MacDonald R N. Continuous sc infusion of narcotics using a portable disposable device in patients with advanced cancer. Cancer Treatment Reports. 87;71(6):635-7. [Rec#: 50250] INCLUDE: considered for evidence table.
Bruera E, Carraro S, Roca E, Cedaro L, Chacon R. Association between malnutrition and caloric intake, emesis, psychological depression, glucose taste, and tumor mass. Cancer Treatment Reports. 84;68(6):873-6. [Rec#: 50259] INCLUDE: considered for evidence table.
Bruera E, Macmillan K, Hanson J, MacDonald R N. The cognitive effects of the administration of narcotic analgesics in patients with cancer pain. Pain. 89;39(1):13-6. [Rec#: 50277] INCLUDE: considered for evidence table. [pmid: 2812850].
Bruera E, MacMillan K, Hanson J, MacDonald R N. The Edmonton staging system for cancer pain: preliminary report. Pain. 89;37(2):203-9. [Rec#: 50279] INCLUDE: considered for evidence table. [pmid: 2748193].
Bruera E, Macmillan K, Kuehn N, Miller M J. Circadian distribution of extra doses of narcotic analgesics in patients with cancer pain: a preliminary report. Pain. 92;49(3):311-4. [Rec#: 50281] INCLUDE: considered for evidence table.
Bruera E, Michaud M, Vigano A, Neumann C M, Watanabe S, Hanson J. Multidisciplinary symptom control clinic in a cancer center: a retrospective study. Supportive Care in Cancer. 2001;9(3):162-8. [Rec#: 50286] INCLUDE: considered for evidence table. [pmid: 11401100].
Bruera E, Miller M J, Macmillan K, Kuehn N. Neuropsychological effects of methylphenidate in patients receiving a continuous infusion of narcotics for cancer pain. Pain. 92;48(2):163-6. [Rec#: 50288] INCLUDE: considered for evidence table.
Bruera E, Pituskin E, Calder K, Neumann C M, Hanson J. The addition of an audiocassette recording of a consultation to written recommendations for patients with advanced cancer: A randomized, controlled trial. Cancer. 99;86(11):2420-5. [Rec#: 50294] INCLUDE: considered for evidence table.
Bruera E, Watanabe S, Fainsinger R L, Spachynski K, Suarez-Almazor M, Inturrisi C. Custom-made capsules and suppositories of methadone for patients on high-dose opioids for cancer pain. Pain. 95;62(2):141-6. [Rec#: 50305] INCLUDE: considered for evidence table.
Bruera E, Willey J S, Palmer J L, Rosales M. Treatment decisions for breast carcinoma: patient preferences and physician perceptions. Cancer. 2002;94(7):2076-80. [Rec#: 50306] INCLUDE: considered for evidence table. [pmid: 11932912].
Brumley R D, Enguidanos S, Cherin D A. Effectiveness of a home-based palliative care program for end-of-life. J Palliat Med. 2003;6(5):715-24. [Rec#: 885] INCLUDE: considered for evidence table. [pmid: 14622451].
Buchanan R J, Choi M, Wang S, Huang C. Analyses of nursing home residents in hospice care using the minimum data set. Palliat Med. 2002;16(6):465-80. [Rec#: 897] INCLUDE: considered for evidence table. [pmid: 12465693].
Bucher J A, Loscalzo M, Zabora J, Houts P S, Hooker C, BrintzenhofeSzoc K. Problem-solving cancer care education for patients and caregivers. Cancer Practice. 2001;9(2):66-70. [Rec#: 50309] INCLUDE: considered for evidence table. [pmid: 11879281].
Burge F, Lawson B, Johnston G. Family physician continuity of care and emergency department use in end-of-life cancer care. Med Care. 2003;41(8):992-1001. [Rec#: 917] INCLUDE: considered for evidence table. [pmid: 12886178].
Burge F, Lawson B, Johnston G, Cummings I. Primary care continuity and location of death for those with cancer. J Palliat Med. 2003;6(6):911-8. [Rec#: 919] INCLUDE: considered for evidence table. [pmid: 14733683].
Burgio L, Stevens A, Guy D, Roth D L, Haley W E. Impact of two psychosocial interventions on white and African American family caregivers of individuals with dementia. Gerontologist. 2003;43(4):568-79. [Rec#: 50915] INCLUDE: considered for evidence table. [pmid: 12937335].
Burns C M, Dixon T, Broom D, Smith W T, Craft P S. Family caregiver knowledge of treatment intent in a longitudinal study of patients with advanced cancer. Support Care Cancer. 2003;11(10):629-37. [Rec#: 40484] INCLUDE: considered for evidence table. [pmid: 12898369].
Burns R, Nichols L O, Martindale-Adams J, Graney M J, Lummus A. Primary care interventions for dementia caregivers: 2-year outcomes from the REACH study. Gerontologist. 2003;43(4):547-55. [Rec#: 50916] INCLUDE: considered for evidence table. [pmid: 12937333].
Busse R, Wagner H P, Krauth C, Klein-Lange M, Schwartz F W. Sentinel practices in evaluating longer periods of care: quality of life and drug therapy of terminally ill persons in Lower Saxony (Germany). J Epidemiol Community Health. 98;52(Suppl 1):56S-60S. [Rec#: 945] INCLUDE: considered for evidence table.
Butler J V, Pooviah P K, Cunningham D, Hasan M. Improving decision-making and documentation relating to do not attempt resuscitation orders. Resuscitation. 2003;57(2):139-44. [Rec#: 40494] INCLUDE: considered for evidence table. [pmid: 12745181].
Butow P N, Maclean M, Dunn S M, Tattersall M H, Boyer M J. The dynamics of change: cancer patients' preferences for information, involvement and support. Annals of Oncology. 97;8(9):857-63. [Rec#: 50312] INCLUDE: considered for evidence table.
Cameron J I, Franche R L, Cheung A M, Stewart D E. Lifestyle interference and emotional distress in family caregivers of advanced cancer patients. Cancer. 2002;94(2):521-7. [Rec#: 985] INCLUDE: considered for evidence table. [pmid: 11900237].
Campbell M L, Guzman J A. Impact of a proactive approach to improve end-of-life care in a medical ICU. Chest 2003;123(1):266–71. Comment in: Chest. Jan. 2003;123(1):16-8. PMID: 12527596. [Rec#: 999] INCLUDE: considered for evidence table.
Campbell M L, Bizek K S, Thill M. Patient responses during rapid terminal weaning from mechanical ventilation: a prospective study. Crit Care Med 99;27(1):73–7. Comment in: Crit Care Med. Jan. 1999;27(1):9-10. PMID: 9934874. [Rec#: 997] INCLUDE: considered for evidence table.
Carlson R W, Devich L, Frank R R. Development of a comprehensive supportive care team for the hopelessly ill on a university hospital medical service. JAMA. 88;259(3):378-83. [Rec#: 50321] INCLUDE: considered for evidence table.
Carson M G, Fitch M I, Vachon M L. Measuring patient outcomes in palliative care: a reliability and validity study of the Support Team Assessment Schedule. Palliat Med. 2000;14(1):25-36. [Rec#: 10067] INCLUDE: considered for evidence table. [pmid: 10717720].
Casarett D J, Crowley R, Hirschman K B. Surveys to assess satisfaction with end-of-life care: does timing matter?. J Pain Symptom Manage. 2003;25(2):128-32. [Rec#: 10091] INCLUDE: considered for evidence table. [pmid: 12590028].
Catalan-Fernandez J G, Pons-Sureda O, Recober-Martinez A, Avella-Mestre A, Carbonero-Malberti J M, Benito-Oliver E, Garau-Llinas I. Dying of cancer. The place of death and family circumstances. Med Care. 91;29(9):841-52. [Rec#: 10122] INCLUDE: considered for evidence table.
Centeno-Cortes C, Nunez-Olarte J M. Questioning diagnosis disclosure in terminal cancer patients: a prospective study evaluating patients' responses. Palliat Med. 94;8(1):39-44. [Rec#: 10138] INCLUDE: considered for evidence table.
Chambers C V, Diamond J J, Perkel R L, Lasch L A. Relationship of advance directives to hospital charges in a Medicare population. Arch Intern Med 94;154(5):541–7. Comment in: Arch Intern Med. 1995 Jan 23;155(2):217–8. PMID: 7811135. Comment in: Arch Intern Med. Jan 9. 1995;155(1):116-7. PMID: 7802514. [Rec#: 1144] INCLUDE: considered for evidence table.
Chang V T, Thaler H T, Polyak T A, Kornblith A B, Lepore J M, Portenoy R K. Quality of life and survival: the role of multidimensional symptom assessment. Cancer. 98;83(1):173-9. [Rec#: 50333] INCLUDE: considered for evidence table. [pmid: 9655308].
Chelluri L, Im K A, Belle S H, Schulz R, Rotondi A J, Donahoe M P, Sirio C A, Mendelsohn A B, Pinsky M R. Long-term mortality and quality of life after prolonged mechanical ventilation. Crit Care Med 2004;32(1):61–9. Comment in: Crit Care Med. Jan. 2004;32(1):291-3. PMID: 14707597. [Rec#: 40593] INCLUDE: considered for evidence table.
Chen H, Haley W E, Robinson B E, Schonwetter R S. Decisions for hospice care in patients with advanced cancer. J Am Geriatr Soc. 2003;51(6):789-97. [Rec#: 1199] INCLUDE: considered for evidence table. [pmid: 12757565].
Chen J H, Bierhals A J, Prigerson H G, Kasl S V, Mazure C M, Jacobs S. Gender differences in the effects of bereavement-related psychological distress in health outcomes. Psychol Med. 99;29(2):367-80. [Rec#: 1201] INCLUDE: considered for evidence table.
Chentsova-Dutton Y, Shuchter S, Hutchin S, Strause L, Burns K, Zisook S. The psychological and physical health of hospice caregivers. Ann Clin Psychiatry. 2000;12(1):19-27. [Rec#: 1211] INCLUDE: considered for evidence table. [pmid: 10798822].
Chin M H, Goldman L. Correlates of early hospital readmission or death in patients with congestive heart failure. Am J Cardiol. 97;79(12):1640-4. [Rec#: 40615] INCLUDE: considered for evidence table. [pmid: 9202355].
Chochinov H M, Hack T, Hassard T, Kristjanson L J, McClement S, Harlos M. Dignity in the terminally ill: a cross-sectional, cohort study. Lancet 2002;360(9350):2026–30. Comment in: Lancet. 2002 Dec 21–28;360(9350):1997–8. PMID: 12504390. Comment in: Lancet. Mar 1. 2003;361(9359):783. PMID: 12620760. [Rec#: 1252] INCLUDE: considered for evidence table.
Chochinov H M, Tataryn D J, Wilson K G, Ennis M, Lander S. Prognostic awareness and the terminally ill. Psychosomatics. 2000;41(6):500-4. [Rec#: 1253] INCLUDE: considered for evidence table. [pmid: 11110113].
Chochinov H M, Wilson K G, Enns M, Lander S. “Are you depressed?” Screening for depression in the terminally ill. Am J Psychiatry 97;154(5):674–6. Comment in: Am J Psychiatry. Jul. 1998;155(7):994-5. PMID: 9659876. [Rec#: 1254] INCLUDE: considered for evidence table.
Chochinov H M, Wilson K G, Enns M, Lander S. Prevalence of depression in the terminally ill: effects of diagnostic criteria and symptom threshold judgments. Am J Psychiatry. 94;151(4):537-40. [Rec#: 1256] INCLUDE: considered for evidence table.
Chow E, Andersson L, Wong R, Vachon M, Hruby G, Franssen E, Fung K W, Harth T, Pach B, Pope J, Connolly R, Schueller T, Stefaniuk K, Szumacher E, Hayter C, Finkelstein J, Danjoux C. Patients with advanced cancer: a survey of the understanding of their illness and expectations from palliative radiotherapy for symptomatic metastases. Clin Oncol (R Coll Radiol). 2001;13(3):204-8. [Rec#: 1265] INCLUDE: considered for evidence table. [pmid: 11527297].
Chow E, Wong R, Connolly R, Hruby G, Franzcr, Franssen E, Fung K W, Vachon M, Andersson L, Pope J, Holden L, Szumacher E, Schueller T, Stefaniuk K, Finkelstein J, Hayter C, Danjoux C. Prospective assessment of symptom palliation for patients attending a rapid response radiotherapy program. Feasibility of telephone follow-up. J Pain Symptom Manage. 2001;22(2):649-56. [Rec#: 1268] INCLUDE: considered for evidence table. [pmid: 11495711].
Christakis N A, Iwashyna T J. The health impact of health care on families: a matched cohort study of hospice use by decedents and mortality outcomes in surviving, widowed spouses. Soc Sci Med. 2003;57(3):465-75. [Rec#: 1279] INCLUDE: considered for evidence table. [pmid: 12791489].
Christakis N A. Timing of referral of terminally ill patients to an outpatient hospice. J Gen Intern Med. 94;9(6):314-20. [Rec#: 1276] INCLUDE: considered for evidence table. [pmid: 8077995].
Clark C, Heidenreich T. Spiritual care for the critically ill. Am J Crit Care. 95;4(1):77-81. [Rec#: 40640] INCLUDE: considered for evidence table. [pmid: 7894561].
Clifford CA, Jolley DJ, and Giles GG. Where people die in Victoria. Med J Aust 91;155(7):446–51, 456. [Rec#: 1342] INCLUDE: considered for evidence table
Clipp E C, George L K. Patients with cancer and their spouse caregivers. Perceptions of the illness experience. Cancer. 92;69(4):1074-9. [Rec#: 50862] INCLUDE: considered for evidence table. [pmid: 1735074].
Cohen L M, Germain M J, Poppel D M, Woods A L, Pekow P S, Kjellstrand C M. Dying well after discontinuing the life-support treatment of dialysis. Arch Intern Med. 2000;160(16):2513-8. [Rec#: 1372] INCLUDE: considered for evidence table. [pmid: 10979064].
Cohen L M, McCue J D, Germain M, Woods A. Denying the dying. Advance directives and dialysis discontinuation. Psychosomatics. 97;38(1):27-34. [Rec#: 1373] INCLUDE: considered for evidence table. [pmid: 8997113].
Cohen L M, McCue J D, Germain M, Kjellstrand C M. Dialysis discontinuation. A ‘good’ death?. Archives of Internal Medicine. 95;155(1):42-7. [Rec#: 50344] INCLUDE: considered for evidence table. [pmid: 7802519].
Cohen S R, Mount B M, Tomas J J, Mount L F. Existential well-being is an important determinant of quality of life. Evidence from the McGill Quality of Life Questionnaire. Cancer. 96;77(3):576-86. [Rec#: 50346] INCLUDE: considered for evidence table.
Cohen-Mansfield J, Libin A, Lipson S. Differences in presenting advance directives in the chart, in the minimum data set, and through the staff's perceptions. Gerontologist. 2003;43(3):302-8. [Rec#: 1376] INCLUDE: considered for evidence table. [pmid: 12810893].
Colantonio A, Kositsky A J, Cohen C, Vernich L. What support do caregivers of elderly want? Results from the Canadian Study of Health and Aging. Can J Public Health. 2001;92(5):376-9. [Rec#: 31020] INCLUDE: considered for evidence table. [pmid: 11702494].
Coll P P, Duffy J D, Micholovich E, Cohen S. Best practices in hospital end-of-life care. Conn Med. 2002;66(11):671-5. [Rec#: 10330] INCLUDE: considered for evidence table. [pmid: 12476509].
Collins C, Stommel M, Wang S, Given C W. Caregiving transitions: changes in depression among family caregivers of relatives with dementia. Nurs Res. 94;43(4):220-5. [Rec#: 1405] INCLUDE: considered for evidence table. [pmid: 8047426].
Colon M, Lyke J. Comparison of hospice use and demographics among European Americans, African Americans, and Latinos. Am J Hosp Palliat Care. 2003;20(3):182-90. [Rec#: 1410] INCLUDE: considered for evidence table. [pmid: 12785039].
Conill C, Verger E, Henriquez I, Saiz N, Espier M, Lugo F, Garrigos A. Symptom prevalence in the last week of life. J Pain Symptom Manage. 97;14(6):328-31. [Rec#: 1422] INCLUDE: considered for evidence table. [pmid: 9409097].
Connolly M, O'Neill J. Teaching a research-based approach to the management of breathlessness in patients with lung cancer. Eur J Cancer Care (Engl). 99;8(1):30-6. [Rec#: 31056] INCLUDE: considered for evidence table. [pmid: 10362951].
Cools H J, Berkhout A M, De Bock G H. Subcutaneous morphine infusion by syringe driver for terminally ill patients. Age Ageing. 96;25(3):206-8. [Rec#: 10391] INCLUDE: considered for evidence table. [pmid: 8670553].
Corner J, Halliday D, Haviland J, Douglas H R, Bath P, Clark D, Normand C, Beech N, Hughes P, Marples R, Seymour J, Skilbeck J, Webb T. Exploring nursing outcomes for patients with advanced cancer following intervention by Macmillan specialist palliative care nurses. J Adv Nurs. 2003;41(6):561-74. [Rec#: 1463] INCLUDE: considered for evidence table. [pmid: 12622865].
Correa-Velez I, Clavarino A, Barnett A G, Eastwood H. Use of complementary and alternative medicine and quality of life: changes at the end of life. Palliat Med. 2003;17(8):695-703. [Rec#: 1467] INCLUDE: considered for evidence table. [pmid: 14694921].
Costantini M, Balzi D, Garronec E, Orlandini C, Parodi S, Vercelli M, Bruzzi P. Geographical variations of place of death among Italian communities suggest an inappropriate hospital use in the terminal phase of cancer disease. Public Health. 2000;114(1):15-20. [Rec#: 1476] INCLUDE: considered for evidence table. [pmid: 10787020].
Costantini M, Higginson I J, Boni L, Orengo M A, Garrone E, Henriquet F, Bruzzi P. Effect of a palliative home care team on hospital admissions among patients with advanced cancer. Palliat Med. 2003;17(4):315-21. [Rec#: 1478] INCLUDE: considered for evidence table. [pmid: 12822847].
Costantini M, Toscani F, Gallucci M, Brunelli C, Miccinesi G, Tamburini M, Paci E, Di Giulio P, Peruselli C, Higginson I, Addington-Hall J. Terminal cancer patients and timing of referral to palliative care: a multicenter prospective cohort study. Italian Cooperative Research Group on Palliative Medicine. J Pain Symptom Manage. 99;18(4):243-52. [Rec#: 1479] INCLUDE: considered for evidence table.
Covinsky K E, Fuller J D, Yaffe K, Johnston C B, Hamel M B, Lynn J, Teno J M, Phillips R S. Communication and decision-making in seriously ill patients: findings of the SUPPORT project. The Study to Understand Prognoses and Preferences for Outcomes and Risks of Treatments. J Am Geriatr Soc. 2000;48(5 Suppl):S187-93. [Rec#: 1501] INCLUDE: considered for evidence table. [pmid: 10809474].
Covinsky K E, Goldman L, Cook E F, Oye R, Desbiens N, Reding D, Fulkerson W, Connors A F Jr, Lynn J, Phillips R S. The impact of serious illness on patients' families. SUPPORT Investigators. Study to Understand Prognoses and Preferences for Outcomes and Risks of Treatment. JAMA. 94;272(23):1839-44. [Rec#: 40727] INCLUDE: considered for evidence table.
Covinsky K E, Kahana E, Chin M H, Palmer R M, Fortinsky R H, Landefeld C S. Depressive symptoms and 3-year mortality in older hospitalized medical patients. Annals of Internal Medicine. 99;130(7):563-9. [Rec#: 50359] INCLUDE: considered for evidence table.
Cowley A J, Skene A M. Treatment of severe heart failure: quantity or quality of life? A trial of enoximone. Enoximone Investigators. Br Heart J 94;72(3):226–30. Comment in: Br Heart J. Jun. 1995;73(6):584. PMID: 7626364. [Rec#: 31102] INCLUDE: considered for evidence table.
Cullinane C A, Borneman T, Smith D D, Chu D Z, Ferrell B R, Wagman L D. The surgical treatment of cancer: a comparison of resource utilization following procedures performed with a curative and palliative intent. Cancer. 2003;98(10):2266-73. [Rec#: 1572] INCLUDE: considered for evidence table. [pmid: 14601098].
Curtis J R, Patrick D L, Caldwell E S, Collier A C. The attitudes of patients with advanced AIDS toward use of the medical futility rationale in decisions to forego mechanical ventilation. Arch Intern Med 2000;160(11):1597–601. Comment in: Arch Intern Med. 2000 Jun 12;160(11):1565–6. PMID: 10847247. Comment in: Arch Intern Med. Jan 8. 2001;161(1):128-30. PMID: 11146716. [Rec#: 1586] INCLUDE: considered for evidence table.
Curtis J R, Patrick D L, Caldwell E S, Collier A C. Why don't patients and physicians talk about end-of-life care? Barriers to communication for patients with acquired immunodeficiency syndrome and their primary care clinicians. Arch Intern Med 2000;160(11):1690–6. Comment in: Arch Intern Med. Jun 12. 2000;160(11):1565-6. PMID: 10847247. [Rec#: 1587] INCLUDE: considered for evidence table.
Curtisa J R, Patrick D L, Caldwell E, Greenlee H, Collier A C. The quality of patient-doctor communication about end-of-life care: a study of patients with advanced AIDS and their primary care clinicians. AIDS. 99;13(9):1123-31. [Rec#: 1585] INCLUDE: considered for evidence table.
Dales R E, O'Connor A, Hebert P, Sullivan K, McKim D, Llewellyn-Thomas H. Intubation and mechanical ventilation for COPD: development of an instrument to elicit patient preferences. Chest. 99;116(3):792-800. [Rec#: 1620] INCLUDE: considered for evidence table.
Danis M, Southerland L I, Garrett J M, Smith J L, Hielema F, Pickard C G, Egner D M, Patrick D L. A prospective study of advance directives for life-sustaining care. N Engl J Med 91;324(13):882–8. Comment in: N Engl J Med. Oct 24. 1991;325(17):1254-6. PMID: 1922218. [Rec#: 40771] INCLUDE: considered for evidence table.
Davies H T, Crombie I K, Brown J H, Martin C. Diminishing returns or appropriate treatment strategy?--an analysis of short-term outcomes after pain clinic treatment. Pain. 97;70(23):203-8. [Rec#: 1671] INCLUDE: considered for evidence table.
Davison B J, Gleave M E, Goldenberg S L, Degner L F, Hoffart D, Berkowitz J. Assessing information and decision preferences of men with prostate cancer and their partners. Cancer Nursing. 2002;25(1):42-9. [Rec#: 50368] INCLUDE: considered for evidence table. [pmid: 11838719].
Dawson N J. Need satisfaction in terminal care settings. Soc Sci Med. 91;32(1):83-7. [Rec#: 10637] INCLUDE: considered for evidence table. [pmid: 2008626].
De Conno F, Boffi R, Brunelli C, Panzeri C. Age-related differences in patients admitted to a palliative home care service. Tumori. 2002;88(2):117-22. [Rec#: 1702] INCLUDE: considered for evidence table. [pmid: 12088250].
De Conno F, Caraceni A, Groff L, Brunelli C, Donati I, Tamburini M, Ventafridda V. Effect of home care on the place of death of advanced cancer patients. Eur J Cancer. 96;32A(7):1142-7. [Rec#: 1703] INCLUDE: considered for evidence table. [pmid: 8758244].
De Conno F, Saita L, Ripamonti C, Ventafridda V. Subcutaneous octreotide in the treatment of pain in advanced cancer patients. J Pain Symptom Manage. 94;9(1):34-8. [Rec#: 31225] INCLUDE: considered for evidence table. [pmid: 8169458].
De Jonge K E, Sulmasy D P, Gold K G, Epstein A, Harper M G, Eisenberg J M, Schulman K A. The timing of do-not-resuscitate orders and hospital costs. J Gen Intern Med. 99;14(3):190-2. [Rec#: 1712] INCLUDE: considered for evidence table. [pmid: 10203626].
de Vos R, Koster R W, de Haan R J. Impact of survival probability, life expectancy, quality of life and patient preferences on do-not-attempt-resuscitation orders in a hospital. Resuscitation Committee. Resuscitation. 98;39(12):15-21. [Rec#: 40833] INCLUDE: considered for evidence table.
de Wit R, van Dam F, Abu-Saad H H, Loonstra S, Zandbelt L, van Buuren A, van der Heijden K, Leenhouts G. Empirical comparison of commonly used measures to evaluate pain treatment in cancer patients with chronic pain. J Clin Oncol. 99;17(4):1280. [Rec#: 1733] INCLUDE: considered for evidence table.
de Wit R, van Dam F, Vielvoye-Kerkmeer A, Mattern C, Abu-Saad H H. The treatment of chronic cancer pain in a cancer hospital in The Netherlands. J Pain Symptom Manage. 99;17(5):333-50. [Rec#: 10666] INCLUDE: considered for evidence table.
DeCourtney C A, Jones K, Merriman M P, Heavener N, Branch P K. Establishing a culturally sensitive palliative care program in rural Alaska Native American communities. J Palliat Med. 2003;6(3):501-10. [Rec#: 10682] INCLUDE: considered for evidence table. [pmid: 14509499].
Degenholtz H B, Arnold R A, Meisel A, Lave J R. Persistence of racial disparities in advance care plan documents among nursing home residents. J Am Geriatr Soc. 2002;50(2):378-81. [Rec#: 40841] INCLUDE: considered for evidence table. [pmid: 12028224].
Delbridge T R, Fosnocht D E, Garrison H G, Auble T E. Field termination of unsuccessful out-of-hospital cardiac arrest resuscitation: acceptance by family members. Ann Emerg Med. 96;27(5):649-54. [Rec#: 1757] INCLUDE: considered for evidence table.
Dendaas N, Pellino T A, Roberts K F, Cleary J. Responding to SUPPORT: an academic medical center examines its end-of-life care practices. Study to Understand Prognoses and Preferences for Outcomes and Risks of Treatments. J Pain Symptom Manage. 2001;21(2):121-8. [Rec#: 1777] INCLUDE: considered for evidence table. [pmid: 11226763].
Desbiens N A, Mueller-Rizner N, Connors A F Jr, Wenger N S, Lynn J. The symptom burden of seriously ill hospitalized patients. SUPPORT Investigators. Study to Understand Prognoses and Preferences for Outcome and Risks of Treatment. J Pain Symptom Manage. 99;17(4):248-55. [Rec#: 40862] INCLUDE: considered for evidence table.
Desbiens N A, Mueller-Rizner N, Hamel M B, Connors A F Jr. Preference for comfort care does not affect the pain experience of seriously ill patients. The SUPPORT Investigators. Study to Understand Prognoses and Preferences for Outcomes and Risks of Treatment. J Pain Symptom Manage. 98;16(5):281-9. [Rec#: 1787] INCLUDE: considered for evidence table.
Detmar SB, Muller MJ, Schornagel JH, Wever LD, and Aaronson NK. Health-related quality-of-life assessments and patient-physician communication: a randomized controlled trial. JAMA 2002;288(23):3027–34. Comment in: JAMA. 2003 Apr 2;289(13):1636; author reply 1636–7. PMID: 12672729. Erratum in: JAMA. 2003 Feb 26;289(8):987. [Rec#: 1794] INCLUDE: considered for evidence table
Detmar S B, Muller M J, Schornagel J H, Wever L D, Aaronson N K. Role of health-related quality of life in palliative chemotherapy treatment decisions. J Clin Oncol. 2002;20(4):1056-62. [Rec#: 1795] INCLUDE: considered for evidence table. [pmid: 11844830].
Detmar S B, Muller M J, Wever L D, Schornagel J H, Aaronson N K. The patient-physician relationship. Patient-physician communication during outpatient palliative treatment visits: an observational study. JAMA. 2001;285(10):1351-7. [Rec#: 1796] INCLUDE: considered for evidence table. [pmid: 11255393].
Devery K, Lennie I, Cooney N. Health outcomes for people who use palliative care services. J Palliat Care. 99;15(2):5-12. [Rec#: 10719] INCLUDE: considered for evidence table. [pmid: 10425872].
Devulder J, Ghys L, Dhondt W, Rolly G. Spinal analgesia in terminal care: risk versus benefit. J Pain Symptom Manage. 94;9(2):75-81. [Rec#: 10730] INCLUDE: considered for evidence table. [pmid: 8021538].
Dexter P R, Wolinsky F D, Gramelspacher G P, Zhou X H, Eckert G J, Waisburd M, Tierney W M. Effectiveness of computer-generated reminders for increasing discussions about advance directives and completion of advance directive forms. A randomized, controlled trial. Ann Intern Med. 98;128(2):102-10. [Rec#: 50914] INCLUDE: considered for evidence table.
Ditto P H, Danks J H, Smucker W D, Bookwala J, Coppola K M, Dresser R, Fagerlin A, Gready R M, Houts R M, Lockhart L K, Zyzanski S. Advance directives as acts of communication: a randomized controlled trial. Arch Intern Med. 2001;161(3):421-30. [Rec#: 1852] INCLUDE: considered for evidence table. [pmid: 11176768].
Dobratz M C. Analysis of variables that impact psychological adaptation in home hospice patients. Hosp J. 95;10(1):75-88. [Rec#: 1865] INCLUDE: considered for evidence table. [pmid: 7789942].
Dobratz M C. Patterns of advanced cancer pain in home hospice patients. Cancer Nurs. 2001;24(4):294-9. [Rec#: 1870] INCLUDE: considered for evidence table. [pmid: 11502038].
Donaldson N, Carter H, Green R. Quality of information on hospice referral. Br J Gen Pract. 2000;50(452):219-20. [Rec#: 10793] INCLUDE: considered for evidence table. [pmid: 10750234]. [pmcid: 1313656].
Donnelly S, Walsh D. The symptoms of advanced cancer. Semin Oncol. 95;22(2 Suppl 3):67-72. [Rec#: 1896] INCLUDE: considered for evidence table. [pmid: 7537907].
Donovan K A, Greene P G, Shuster J L, Partridge E E, Tucker D C. Treatment preferences in recurrent ovarian cancer. Gynecol Oncol. 2002;86(2):200-11. [Rec#: 1899] INCLUDE: considered for evidence table. [pmid: 12144829].
Doorenbos A Z, Nies M A. The use of advance directives in a population of Asian Indian Hindus. J Transcult Nurs. 2003;14(1):17-24. [Rec#: 1903] INCLUDE: considered for evidence table. [pmid: 12593266].
Dowdy M D, Robertson C, Bander J A. A study of proactive ethics consultation for critically and terminally ill patients with extended lengths of stay. Critical Care Medicine. 98;26(2):252-9. [Rec#: 50384] INCLUDE: considered for evidence table.
Dowsett S M, Saul J L, Butow P N, Dunn S M, Boyer M J, Findlow R, Dunsmore J. Communication styles in the cancer consultation: preferences for a patient-centred approach. Psycho-Oncology. 2000;9(2):147-56. [Rec#: 50385] INCLUDE: considered for evidence table. [pmid: 10767752].
Doyle C J. Effect of staff turnover and the social environment on depressive symptoms in nursing home residents. Int Psychogeriatr. 95;7(1):51-61. [Rec#: 40917] INCLUDE: considered for evidence table. [pmid: 7579021].
Draper B, MacCuspie-Moore C, Brodaty H. Suicidal ideation and the ‘wish to die’ in dementia patients: the role of depression. Age Ageing. 98;27(4):503-7. [Rec#: 1934] INCLUDE: considered for evidence table. [pmid: 9884008].
Dudgeon D J, Lertzman M. Dyspnea in the advanced cancer patient. J Pain Symptom Manage 98;16(4):212–9. Comment in: J Pain Symptom Manage. Nov. 1999;18(5):313-5. PMID: 10584452. [Rec#: 40930] INCLUDE: considered for evidence table.
Dudgeon DJ, Raubertas R, Doerner K, O'Connor T, Tobin M, and Rosenthal SN. When does palliative care begin? A needs assessment of cancer patients with recurrent disease. J Palliat Care 95;11(1):5–9. Comment in: J Palliat Care. 1995 Autumn;11(3):53. PMID: 7472797. Erratum in: J Palliat Care. 1995 Autumn;11(3):53. PMID: 7472797. [Rec#: 1955] INCLUDE: considered for evidence table
Duggleby W, Alden C. Implementation and evaluation of a quality improvement process to improve pain management in a hospice setting. Am J Hosp Palliat Care. 98;15(4):209-16. [Rec#: 10867] INCLUDE: considered for evidence table.
Dull S M, Graves J R, Larsen M P, Cummins R O. Expected death and unwanted resuscitation in the prehospital setting. Ann Emerg Med. 94;23(5):997-1002. [Rec#: 40939] INCLUDE: considered for evidence table. [pmid: 8185118].
Dumot J A, Burval D J, Sprung J, Waters J H, Mraovic B, Karafa M T, Mascha E J, Bourke D L. Outcome of adult cardiopulmonary resuscitations at a tertiary referral center including results of “limited” resuscitations. Arch Intern Med. 2001;161(14):1751-8. [Rec#: 40940] INCLUDE: considered for evidence table. [pmid: 11485508].
Duthie E, Mark D, Tresch D, Kartes S, Neahring J, Aufderheide T. Utilization of cardiopulmonary resuscitation in nursing homes in one community: rates and nursing home characteristics. J Am Geriatr Soc 93;41(4):384–8. Comment in: J Am Geriatr Soc. Nov. 1993;41(11):1275-6. PMID: 8227908. [Rec#: 40956] INCLUDE: considered for evidence table.
DuVal G, Clarridge B, Gensler G, Danis M. A national survey of U.S internists' experiences with ethical dilemmas and ethics consultation. J Gen Intern Med. 2004;19(3):251-8. [Rec#: 1989] INCLUDE: considered for evidence table. [pmid: 15009780]. [pmcid: 1492156].
Ehman J W, Ott B B, Short T H, Ciampa R C, Hansen-Flaschen J. Do patients want physicians to inquire about their spiritual or religious beliefs if they become gravely ill?. Archives of Internal Medicine. 99;159(15):1803-6. [Rec#: 50396] INCLUDE: considered for evidence table.
Eisdorfer C, Czaja S J, Loewenstein D A, Rubert M P, Arguelles S, Mitrani V B, Szapocznik J. The effect of a family therapy and technology-based intervention on caregiver depression. Gerontologist. 2003;43(4):521-31. [Rec#: 50917] INCLUDE: considered for evidence table. [pmid: 12937331].
Eldridge A D, Severance-Lossin L, Nicholas P K, Leuner J D. Prevalence and characteristics of pain in persons with terminal-stage AIDS. J Adv Nurs. 94;20(2):260-8. [Rec#: 2059] INCLUDE: considered for evidence table. [pmid: 7930143].
Eleazer G P, Hornung C A, Egbert C B, Egbert J R, Eng C, Hedgepeth J, McCann R, Strothers H 3rd, Sapir M, Wei M, Wilson M. The relationship between ethnicity and advance directives in a frail older population. J Am Geriatr Soc. 96;44(8):938-43. [Rec#: 40988] INCLUDE: considered for evidence table.
Elfrink E J, van der Rijt C C, van Boxtel R J, Elswijk-de Vries P, van Zuijlen L, Stoter G. Problem solving by telephone in palliative care: use of a predetermined assessment tool within a program of home care technology. J Palliat Care. 2002;18(2):105-10. [Rec#: 2061] INCLUDE: considered for evidence table. [pmid: 12164098].
Elmstahl S, Ingvad B, Annerstedt L. Family caregiving in dementia: prediction of caregiver burden 12 months after relocation to group-living care. Int Psychogeriatr. 98;10(2):127-46. [Rec#: 50026] INCLUDE: considered for evidence table.
Emanuel E J, Fairclough D L, Slutsman J, Alpert H, Baldwin D, Emanuel L L. Assistance from family members, friends, paid care givers, and volunteers in the care of terminally ill patients. N Engl J Med. 99;341(13):956-63. [Rec#: 2092] INCLUDE: considered for evidence table.
Emanuel E J, Weinberg D S, Gonin R, Hummel L R, Emanuel L L. How well is the Patient Self-Determination Act working?: an early assessment. Am J Med. 93;95(6):619-28. [Rec#: 2093] INCLUDE: considered for evidence table. [pmid: 8259779].
Emanuel E J, Fairclough D L, Slutsman J, Emanuel L L. Understanding economic and other burdens of terminal illness: the experience of patients and their caregivers. Annals of Internal Medicine. 2000;132(6):451-9. [Rec#: 50398] INCLUDE: considered for evidence table. [pmid: 10733444].
Emanuel L L, Barry M J, Stoeckle J D, Ettelson L M, Emanuel E J. Advance directives for medical care—a case for greater use. N Engl J Med. 91;324(13):889-95. [Rec#: 50864] INCLUDE: considered for evidence table. [pmid: 2000111].
Escalante C P, Martin C G, Elting L S, Cantor S B, Harle T S, Price K J, Kish S K, Manzullo E F, Rubenstein E B. Dyspnea in cancer patients. Etiology, resource utilization, and survival—implications in a managed care world. Cancer. 96;78(6):1314-9. [Rec#: 2131] INCLUDE: considered for evidence table.
Evangelista L S, Dracup K, Doering L, Westlake C, Fonarow G C, Hamilton M. Emotional well-being of heart failure patients and their caregivers. J Card Fail. 2002;8(5):300-5. [Rec#: 31516] INCLUDE: considered for evidence table. [pmid: 12411980].
Evers M M, Meier D E, Morrison R S. Assessing differences in care needs and service utilization in geriatric palliative care patients. J Pain Symptom Manage. 2002;23(5):424-32. [Rec#: 2157] INCLUDE: considered for evidence table. [pmid: 12007760].
Evers M M, Purohit D, Perl D, Khan K, Marin D B. Palliative and aggressive end-of-life care for patients with dementia. Psychiatr Serv. 2002;53(5):609-13. [Rec#: 2158] INCLUDE: considered for evidence table. [pmid: 11986512].
Faber-Langendoen K, Bartels D M. Process of forgoing life-sustaining treatment in a university hospital: an empirical study. Crit Care Med. 92;20(5):570-7. [Rec#: 2163] INCLUDE: considered for evidence table. [pmid: 1374002].
Faber-Langendoen K. A multi-institutional study of care given to patients dying in hospitals. Ethical and practice implications. Archives of Internal Medicine. 96;156(18):2130-6. [Rec#: 50403] INCLUDE: considered for evidence table.
Fainsinger R, Miller M J, Bruera E, Hanson J, Maceachern T. Symptom control during the last week of life on a palliative care unit. J Palliat Care. 91;7(1):5-11. [Rec#: 2171] INCLUDE: considered for evidence table.
Fainsinger R L, De Moissac D, Mancini I, Oneschuk D. Sedation for delirium and other symptoms in terminally ill patients in Edmonton. J Palliat Care. 2000;16(2):5-10. [Rec#: 2172] INCLUDE: considered for evidence table. [pmid: 10887726].
Fainsinger R L, Louie K, Belzile M, Bruera E, Hanson J. Decreased opioid doses used on a palliative care unit. J Palliat Care. 96;12(4):6-9. [Rec#: 2176] INCLUDE: considered for evidence table. [pmid: 9019031].
Fainsinger R L, MacEachern T, Hanson J, Bruera E. The use of urinary catheters in terminally ill cancer patients. J Pain Symptom Manage. 92;7(6):333-8. [Rec#: 2177] INCLUDE: considered for evidence table. [pmid: 1517648].
Fainsinger R L, MacEachern T, Miller M J, Bruera E, Spachynski K, Kuehn N, Hanson J. The use of hypodermoclysis for rehydration in terminally ill cancer patients. J Pain Symptom Manage. 94;9(5):298-302. [Rec#: 2178] INCLUDE: considered for evidence table.
Fainsinger RL, Nunez-Olarte JM, and Demoissac DM. The cultural differences in perceived value of disclosure and cognition: Spain and Canada. J Palliat Care 2003;19(1):43–8. Comment in: J Palliat Care. 2003 Spring;19(1):7–8. PMID: 12710109. [Rec#: 2179] INCLUDE: considered for evidence table
Fainsinger R L, Spachynski K, Hanson J, Bruera E. Symptom control in terminally ill patients with malignant bowel obstruction (MBO). J Pain Symptom Manage. 94;9(1):12-8. [Rec#: 2181] INCLUDE: considered for evidence table. [pmid: 7513332].
Fakhoury W, McCarthy M, Addington-Hall J. Determinants of informal caregivers' satisfaction with services for dying cancer patients. Soc Sci Med. 96;42(5):721-31. [Rec#: 2190] INCLUDE: considered for evidence table. [pmid: 8685740].
Fakhoury W K, McCarthy M, Addington-Hall J. Carers' health status: is it associated with their evaluation of the quality of palliative care?. Scand J Soc Med. 97;25(4):296-301. [Rec#: 2192] INCLUDE: considered for evidence table.
Fakhoury W K, McCarthy M, Addington-Hall J. The effects of the clinical characteristics of dying cancer patients on informal caregivers' satisfaction with palliative care. Palliat Med. 97;11(2):107-15. [Rec#: 2193] INCLUDE: considered for evidence table.
Farran C J, Miller B H, Kaufman J E, Donner E, Fogg L. Finding meaning through caregiving: development of an instrument for family caregivers of persons with Alzheimer's disease. J Clin Psychol. 99;55(9):1107-25. [Rec#: 31551] INCLUDE: considered for evidence table.
Fernsler J I, Klemm P, Miller M A. Spiritual well-being and demands of illness in people with colorectal cancer. Cancer Nurs. 99;22(2):134-40. quiz 141–2. [Rec#: 2253] INCLUDE: considered for evidence table.
Ferrell B A, Ferrell B R, Rivera L. Pain in cognitively impaired nursing home patients. J Pain Symptom Manage. 95;10(8):591-8. [Rec#: 41059] INCLUDE: considered for evidence table. [pmid: 8594119].
Ferry P, Hancock R, Newton C, Taylor J, Horton K. Perspectives of relatives and health care workers on care of terminally ill patients in the UK. Am J Hosp Palliat Care. 2002;19(2):121-8. [Rec#: 11176] INCLUDE: considered for evidence table. [pmid: 11926443].
Feuz A, Rapin C H. An observational study of the role of pain control and food adaptation of elderly patients with terminal cancer. J Am Diet Assoc. 94;94(7):767-70. [Rec#: 2279] INCLUDE: considered for evidence table. [pmid: 7517412].
Field D, McGaughey J. An evaluation of palliative care services for cancer patients in the Southern Health and Social Services Board of Northern Ireland. Palliat Med. 98;12(2):83-97. [Rec#: 2286] INCLUDE: considered for evidence table.
Fine R L, Mayo T W. Resolution of futility by due process: early experience with the Texas Advance Directives Act. Ann Intern Med 2003;138(9):743–6. Comment in: Ann Intern Med. 2004 Mar 2;140(5):402–3; author reply 404. PMID: 14996685. Comment in: Ann Intern Med. 2004 Mar 2;140(5):403–4; author reply 404. PMID: 14996687. Comment in: Ann Intern Med. Mar 2. 2004;140(5):403. author reply 404. PMID. [Rec#: 2304] INCLUDE: considered for evidence table.
Finlay I G, Jones O L. Hypnotherapy in palliative care. J R Soc Med. 96;89(9):493-6. [Rec#: 2311] INCLUDE: considered for evidence table. [pmid: 8949516].
Finn J W, Walsh T D, MacDonald N, Bruera E, Krebs L U, Shepard K V. Placebo-blinded study of morphine sulfate sustained-release tablets and immediate-release morphine sulfate solution in outpatients with chronic pain due to advanced cancer. Journal of Clinical Oncology. 93;11(5):967-72. [Rec#: 50428] INCLUDE: considered for evidence table.
Fins J J, Miller F G, Acres C A, Bacchetta M D, Huzzard L L, Rapkin B D. End-of-life decision-making in the hospital: current practice and future prospects. J Pain Symptom Manage. 99;17(1):6-15. [Rec#: 2314] INCLUDE: considered for evidence table.
Fisher ES, Wennberg DE, Stukel TA, Gottlieb DJ, Lucas FL, and Pinder EL. The implications of regional variations in Medicare spending. Part 2: health outcomes and satisfaction with care. Ann Intern Med 2003;138(4):288–98. Comment in: Ann Intern Med. 2003 Feb 18;138(4):347–8. PMID: 12585834. Comment in: Ann Intern Med. 2003 Feb 18;138(4):348–9. PMID: 12585835. Comment in: Ann Intern Med. 2003 Feb 18;138(4):350–1. PMID: 12585836. Comment in: Ann Intern Med. 2004 Jan . [Rec#: 2326] INCLUDE: considered for evidence table
Fitzpatrick M O, Goyal K, Barlow P. Treatment limiting decisions in a neurosurgical unit. Scott Med J. 99;44(2):47-8. [Rec#: 11252] INCLUDE: considered for evidence table. [pmid: 10370981].
Fogel B S, Mor V. Depressed mood and care preferences in patients with AIDS. Gen Hosp Psychiatry. 93;15(4):203-7. [Rec#: 2360] INCLUDE: considered for evidence table. [pmid: 8344508].
Fortner B V, Demarco G, Irving G, Ashley J, Keppler G, Chavez J, Munk J. Description and predictors of direct and indirect costs of pain reported by cancer patients. J Pain Symptom Manage. 2003;25(1):9-18. [Rec#: 11303] INCLUDE: considered for evidence table. [pmid: 12565184].
Fountain A. Visual hallucinations: a prevalence study among hospice inpatients. Palliat Med. 2001;15(1):19-25. [Rec#: 2388] INCLUDE: considered for evidence table. [pmid: 11212463].
Fowell A, Finlay I, Johnstone R, Minto L. An integrated care pathway for the last two days of life: Wales-wide benchmarking in palliative care. Int J Palliat Nurs 2002;8(12):566–73. Comment in: Int J Palliat Nurs. Jan. 2003;9(1):39. PMID: 12560796. [Rec#: 11314] INCLUDE: considered for evidence table.
Fried T R, Bradley E H. What matters to seriously ill older persons making end-of-life treatment decisions?: A qualitative study. J Palliat Med. 2003;6(2):237-44. [Rec#: 2435] INCLUDE: considered for evidence table. [pmid: 12854940].
Fried T R, Mor V. Frailty and hospitalization of long-term stay nursing home residents. J Am Geriatr Soc 97;45(3):265–9. Comment in: J Am Geriatr Soc. Mar. 1997;45(3):378-9. PMID: 9063288. [Rec#: 41137] INCLUDE: considered for evidence table.
Fried T R, Bradley E H, O'Leary J. Prognosis communication in serious illness: perceptions of older patients, caregivers, and clinicians. J Am Geriatr Soc. 2003;51(10):1398-403. [Rec#: 2436] INCLUDE: considered for evidence table. [pmid: 14511159].
Fried T R, Bradley E H, Towle V R. Assessment of patient preferences: integrating treatments and outcomes. J Gerontol B Psychol Sci Soc Sci. 2002;57(6):S348-54. [Rec#: 2437] INCLUDE: considered for evidence table. [pmid: 12426443].
Fried T R, Bradley E H, Towle V R. Valuing the outcomes of treatment: do patients and their caregivers agree?. Arch Intern Med. 2003;163(17):2073-8. [Rec#: 2438] INCLUDE: considered for evidence table. [pmid: 14504121].
Fried T R, Bradley E H, Towle V R, Allore H. Understanding the treatment preferences of seriously ill patients. N Engl J Med 2002;346(14):1061–6. Comment in: N Engl J Med. 2002 Apr 4;346(14):1087–9. PMID: 11932479. Comment in: N Engl J Med. 2002 Aug 15;347(7):533–5; author reply 533–5. PMID: 12181411. Comment in: N Engl J Med. Aug 15. 2002;347(7):533-5. author reply 533–5. PMID: 12182184. Co. [Rec#: 2439] INCLUDE: considered for evidence table.
Fried T R, Pollack D M, Drickamer M A, Tinetti M E. Who dies at home? Determinants of site of death for community-based long-term care patients. J Am Geriatr Soc. 99;47(1):25-9. [Rec#: 2441] INCLUDE: considered for evidence table.
Fried T R, van Doorn C, O'Leary J R, Tinetti M E, Drickamer M A. Older person's preferences for home vs hospital care in the treatment of acute illness. Arch Intern Med. 2000;160(10):1501-6. [Rec#: 41139] INCLUDE: considered for evidence table. [pmid: 10826465].
Fried T R, Gillick M R, Lipsitz L A. Short-term functional outcomes of long-term care residents with pneumonia treated with and without hospital transfer. Journal of the American Geriatrics Society. 97;45(3):302-6. [Rec#: 50437] INCLUDE: considered for evidence table.
Friedman M M, Griffin J A. Relationship of physical symptoms and physical functioning to depression in patients with heart failure. Heart Lung. 2001;30(2):98-104. [Rec#: 31732] INCLUDE: considered for evidence table. [pmid: 11248712].
Friedrichsen M J, Strang P M, Carlsson M E. Cancer patients' perceptions of their participation and own resources after receiving information about discontinuation of active tumour treatment. Acta Oncol. 2000;39(8):919-25. [Rec#: 2451] INCLUDE: considered for evidence table. [pmid: 11206997].
Fry P S. A factor analytic investigation of home-bound elderly individuals' concerns about death and dying, and their coping responses. J Clin Psychol. 90;46(6):737-48. [Rec#: 2469] INCLUDE: considered for evidence table.
Fudin J, Smith H S, Toledo-Binette C S, Kenney E, Yu A B, Boutin R. Use of continuous ambulatory infusions of concentrated subcutaneous (s.q.) hydromorphone versus intravenous (i.v.) morphine: cost implications for palliative care. Am J Hosp Palliat Care 2000;17(5):347–53. Comment in: Am J Hosp Palliat Care. Sep-Oct. 2000;17(5):292-3. PMID: 11886046. [Rec#: 11399] INCLUDE: considered for evidence table.
Fulop G, Strain J J, Stettin G. Congestive heart failure and depression in older adults: clinical course and health services use 6 months after hospitalization. Psychosomatics. 2003;44(5):367-73. [Rec#: 31762] INCLUDE: considered for evidence table. [pmid: 12954910].
Fulton C. Patients with metastatic breast cancer: their physical and psychological rehabilitation needs. Int J Rehabil Res. 99;22(4):291-301. [Rec#: 31763] INCLUDE: considered for evidence table. [pmid: 10669979].
Fulton C L. The physical and psychological symptoms experienced by patients with metastatic breast cancer before death. Eur J Cancer Care (Engl). 97;6(4):262-6. [Rec#: 2489] INCLUDE: considered for evidence table. [pmid: 9460344].
Furuta M, Hayakawa K, Saito Y, Nakayama Y, Katano S, Sakurai H, Takahashi T, Ohno T, Mitsuhashi N, Niibe H. Clinical implication of symptoms in patients with non-small cell lung cancer treated with definitive radiation therapy. Lung Cancer. 95;13(3):275-83. [Rec#: 31769] INCLUDE: considered for evidence table.
Gagnon P, Allard P, Masse B, DeSerres M. Delirium in terminal cancer: a prospective study using daily screening, early diagnosis, and continuous monitoring. J Pain Symptom Manage. 2000;19(6):412-26. [Rec#: 2512] INCLUDE: considered for evidence table. [pmid: 10908822].
Gagnon B, Bielech M, Watanabe S, Walker P, Hanson J, Bruera E. The use of intermittent subcutaneous injections of oxycodone for opioid rotation in patients with cancer pain. Supportive Care in Cancer. 99;7(4):265-70. [Rec#: 50440] INCLUDE: considered for evidence table.
Gallicchio L, Siddiqi N, Langenberg P, Baumgarten M. Gender differences in burden and depression among informal caregivers of demented elders in the community. Int J Geriatr Psychiatry. 2002;17(2):154-63. [Rec#: 31785] INCLUDE: considered for evidence table. [pmid: 11813279].
Gallo W T, Baker M J, Bradley E H. Factors associated with home versus institutional death among cancer patients in Connecticut. J Am Geriatr Soc 2001;49(6):771–7. Comment in: J Am Geriatr Soc. Jun. 2001;49(6):831-2. PMID: 11454126. [Rec#: 2527] INCLUDE: considered for evidence table.
Ganzini L, Lee M A, Heintz R T, Bloom J D. Do-not-resuscitate orders for depressed psychiatric inpatients. Hosp Community Psychiatry. 92;43(9):915-9. [Rec#: 2543] INCLUDE: considered for evidence table. [pmid: 1427701].
Ganzini L, Goy E R, Miller L L, Harvath T A, Jackson A, Delorit M A. Nurses' experiences with hospice patients who refuse food and fluids to hasten death. New England Journal of Medicine. 2003;349(4):359-65. [Rec#: 50444] INCLUDE: considered for evidence table. [pmid: 12878744].
Ganzini L, Johnston W S, Hoffman W F. Correlates of suffering in amyotrophic lateral sclerosis. Neurology. 99;52(7):1434-40. [Rec#: 50445] INCLUDE: considered for evidence table. [pmid: 10227631].
Gattellari M, Voigt K J, Butow P N, Tattersall M H. When the treatment goal is not cure: are cancer patients equipped to make informed decisions?. J Clin Oncol. 2002;20(2):503-13. [Rec#: 2565] INCLUDE: considered for evidence table. [pmid: 11786580].
Gaudette L A, Shi F, Lipskie T, Allard P, Fainsinger R L, Maxwell D, Harlos M. Developing palliative care surveillance in Canada: results of a pilot study. J Palliat Care. 2002;18(4):262-9. [Rec#: 2567] INCLUDE: considered for evidence table. [pmid: 12611316].
Ghusn H F, Teasdale T A, Jordan D. Continuity of do-not-resuscitate orders between hospital and nursing home settings. J Am Geriatr Soc. 97;45(4):465-9. [Rec#: 41196] INCLUDE: considered for evidence table. [pmid: 9100716].
Gift A G, Stommel M, Jablonski A, Given W. A cluster of symptoms over time in patients with lung cancer. Nurs Res. 2003;52(6):393-400. [Rec#: 2633] INCLUDE: considered for evidence table. [pmid: 14639086].
Giladi N, Treves T A, Paleacu D, Shabtai H, Orlov Y, Kandinov B, Simon E S, Korczyn A D. Risk factors for dementia, depression and psychosis in long-standing Parkinson's disease. J Neural Transm. 2000;107(1):59-71. [Rec#: 31892] INCLUDE: considered for evidence table. [pmid: 10809404].
Gill P, Kaur J S, Rummans T, Novotny P J, Sloan J A. The hospice patient's primary caregiver. What is their quality of life?. J Psychosom Res. 2003;55(5):445-51. [Rec#: 2643] INCLUDE: considered for evidence table. [pmid: 14581099].
Giorgi F, Cellerino R, Gramazio A, Tummarello D, Menichetti E T, Giordani P, Antognoli S, Carle F, Piga A. Assessing quality of life in patients with cancer: a comparison of a visual-analogue and a categorical model. Am J Clin Oncol. 96;19(4):394-9. [Rec#: 31911] INCLUDE: considered for evidence table.
Gitlin L N, Belle S H, Burgio L D, Czaja S J, Mahoney D, Gallagher-Thompson D, Burns R, Hauck W W, Zhang S, Schulz R, Ory M G. REACH Investigators. Effect of multicomponent interventions on caregiver burden and depression: the REACH multisite initiative at 6-month follow-up. Psychol Aging. 2003;18(3):361-74. [Rec#: 31919] INCLUDE: considered for evidence table. [pmid: 14518800].
Gitlin L N, Winter L, Corcoran M, Dennis M P, Schinfeld S, Hauck W W. Effects of the home environmental skill-building program on the caregiver-care recipient dyad: 6-month outcomes from the Philadelphia REACH Initiative. Gerontologist. 2003;43(4):532-46. [Rec#: 50918] INCLUDE: considered for evidence table. [pmid: 12937332].
Given B, Given C, Azzouz F, Stommel M. Physical functioning of elderly cancer patients prior to diagnosis and following initial treatment. Nurs Res. 2001;50(4):222-32. [Rec#: 31922] INCLUDE: considered for evidence table. [pmid: 11480531].
Gochman D S, Bonham G S. The social structure of the hospice decision. Hosp J. 90;6(1):15-36. [Rec#: 11560] INCLUDE: considered for evidence table. [pmid: 2379921].
Goldberg L R, Piette J D, Walsh M N, Frank T A, Jaski B E, Smith A L, Rodriguez R, Mancini D M, Hopton L A, Orav E J, Loh E. WHARF Investigators. Randomized trial of a daily electronic home monitoring system in patients with advanced heart failure: the Weight Monitoring in Heart Failure (WHARF) trial. Am Heart J. 2003;146(4):705-12. [Rec#: 31947] INCLUDE: considered for evidence table. [pmid: 14564327].
Goldberg R J, Goldberg J. Risperidone for dementia-related disturbed behavior in nursing home residents: a clinical experience. Int Psychogeriatr. 97;9(1):65-8. [Rec#: 31950] INCLUDE: considered for evidence table. [pmid: 9195280].
Goldstone I, Kuhl D, Johnson A, Le R, McLeod A. Patterns of care in advanced HIV disease in a tertiary treatment centre. AIDS Care. 95;7(Suppl 1):S47-56. [Rec#: 2714] INCLUDE: considered for evidence table. [pmid: 7543290].
Golin C E, Wenger N S, Liu H, Dawson N V, Teno J M, Desbiens N A, Lynn J, Oye R K, Phillips R S. A prospective study of patient-physician communication about resuscitation. J Am Geriatr Soc. 2000;48(5 Suppl):S52-60. [Rec#: 2716] INCLUDE: considered for evidence table. [pmid: 10809457].
Goncalves J F, Alvarenga M, Silva A. The last forty-eight hours of life in a Portuguese palliative care unit: does it differ from elsewhere?. J Palliat Med. 2003;6(6):895-900. [Rec#: 2720] INCLUDE: considered for evidence table. [pmid: 14733681].
Gonzalez-Salvador M T, Arango C, Lyketsos C G, Barba A C. The stress and psychological morbidity of the Alzheimer patient caregiver. Int J Geriatr Psychiatry. 99;14(9):701-10. [Rec#: 31971] INCLUDE: considered for evidence table. [pmid: 10479740].
Goodkin K, Feaster D J, Asthana D, Blaney N T, Kumar M, Baldewicz T, Tuttle R S, Maher K J, Baum M K, Shapshak P, Fletcher M A. A bereavement support group intervention is longitudinally associated with salutary effects on the CD4 cell count and number of physician visits. Clin Diagn Lab Immunol. 98;5(3):382-91. [Rec#: 2725] INCLUDE: considered for evidence table.
Goodlin S J, Winzelberg G S, Teno J M, Whedon M, Lynn J. Death in the hospital. Arch Intern Med. 98;158(14):1570-2. [Rec#: 2729] INCLUDE: considered for evidence table. [pmid: 9679799].
Goodlin S J, Zhong Z, Lynn J, Teno J M, Fago J P, Desbiens N, Connors A F Jr, Wenger N S, Phillips R S. Factors associated with use of cardiopulmonary resuscitation in seriously ill hospitalized adults. JAMA. 99;282(24):2333-9. [Rec#: 2730] INCLUDE: considered for evidence table.
Goodwin D M, Higginson I J, Myers K, Douglas H R, Normand C E. Effectiveness of palliative day care in improving pain, symptom control, and quality of life. J Pain Symptom Manage 2003;25(3):202–12. Comment in: J Pain Symptom Manage. Oct. 2003;26(4):886-7. author reply 888–9. PMID: 14527753. [Rec#: 2735] INCLUDE: considered for evidence table.
Goodwin D M, Higginson I J, Myers K, Douglas H R, Normand C E. What is palliative day care? A patient perspective of five UK services. Support Care Cancer. 2002;10(7):556-62. [Rec#: 2736] INCLUDE: considered for evidence table. [pmid: 12324811].
Goodyer L I, Miskelly F, Milligan P. Does encouraging good compliance improve patients' clinical condition in heart failure? Br J Clin Pract 95;49(4):173–6. Comment in: Br J Clin Pract. Jul-Aug. 1995;49(4):171. PMID: 7547152. [Rec#: 31978] INCLUDE: considered for evidence table.
Gordon N P, Shade S B. Advance directives are more likely among seniors asked about end-of-life care preferences. Arch Intern Med. 99;159(7):701-4. [Rec#: 2742] INCLUDE: considered for evidence table. [pmid: 10218749].
Gore J M, Brophy C J, Greenstone M A. How well do we care for patients with end stage chronic obstructive pulmonary disease (COPD)? A comparison of palliative care and quality of life in COPD and lung cancer. Thorax 2000;55(12):1000–6. Comment in: Thorax. Dec. 2000;55(12):979-81. PMID: 11083879. [Rec#: 2745] INCLUDE: considered for evidence table.
Gorski L A, Johnson K. A disease management program for heart failure: collaboration between a home care agency and a care management organization. Lippincotts Case Manag. 2003;8(6):265-73. [Rec#: 31989] INCLUDE: considered for evidence table. [pmid: 14646784].
Gottlieb S S, Fisher M L, Freudenberger R, Robinson S, Zietowski G, Alves L, Krichten C, Vaitkevicus P, McCarter R. Effects of exercise training on peak performance and quality of life in congestive heart failure patients. J Card Fail. 99;5(3):188-94. [Rec#: 31996] INCLUDE: considered for evidence table.
Grande G E, McKerral A, Todd C J. Which cancer patients are referred to Hospital at Home for palliative care?. Palliat Med. 2002;16(2):115-23. [Rec#: 2777] INCLUDE: considered for evidence table. [pmid: 11969142].
Grande G E, Todd C J, Barclay S I, Farquhar M C. A randomized controlled trial of a hospital at home service for the terminally ill. Palliat Med. 2000;14(5):375-85. [Rec#: 11650] INCLUDE: considered for evidence table. [pmid: 11064784].
Grande G E, Todd C J, Barclay S I, Farquhar M C. Does hospital at home for palliative care facilitate death at home? Randomised controlled trial. BMJ 99;319(7223):1472–5. Comment in: BMJ. Dec 4. 1999;319(7223):1447-8. PMID: 10582909. [Rec#: 11649] INCLUDE: considered for evidence table.
Grant I, Adler K A, Patterson T L, Dimsdale J E, Ziegler M G, Irwin M R. Health consequences of Alzheimer's caregiving transitions: effects of placement and bereavement. Psychosom Med. 2002;64(3):477-86. [Rec#: 2781] INCLUDE: considered for evidence table. [pmid: 12021421].
Grant M, Golant M, Rivera L, Dean G, Benjamin H. Developing a community program on cancer pain and fatigue. Cancer Practice. 2000;8(4):187-94. [Rec#: 50465] INCLUDE: considered for evidence table. [pmid: 11898258].
Green C P, Porter C B, Bresnahan D R, Spertus J A. Development and evaluation of the Kansas City Cardiomyopathy Questionnaire: a new health status measure for heart failure. J Am Coll Cardiol. 2000;35(5):1245-55. [Rec#: 32030] INCLUDE: considered for evidence table. [pmid: 10758967].
Green C R, Wheeler J R. Physician variability in the management of acute postoperative and cancer pain: a quantitative analysis of the Michigan experience. Pain Med 2003;4(1):8–20. Comment in: Pain Med. Mar. 2003;4(1):1-3. PMID: 12873272. [Rec#: 11670] INCLUDE: considered for evidence table.
Greenberg S M, Tennis M K, Brown L B, Gomez-Isla T, Hayden D L, Schoenfeld D A, Walsh K L, Corwin C, Daffner K R, Friedman P, Meadows M E, Sperling R A, Growdon J H. Donepezil therapy in clinical practice: a randomized crossover study. Arch Neurol 2000;57(1):94–9. Comment in: Arch Neurol. Sep. 2000;57(9):1380. PMID: 10987910. [Rec#: 32039] INCLUDE: considered for evidence table.
Griffith C H 3rd, Wilson J F, Emmett K R, Ramsbottom-Lucier M, Rich E C. Knowledge and experience with Alzheimer's disease. Relationship to resuscitation preference. Arch Fam Med. 95;4(9):780-4. [Rec#: 32062] INCLUDE: considered for evidence table.
Groff L, Zecca E, De Conno F, Brunelli C, Boffi R, Panzeri C, Cazzaniga M, Ripamonti C. The role of disodium pamidronate in the management of bone pain due to malignancy. Palliat Med. 2001;15(4):297-307. [Rec#: 2834] INCLUDE: considered for evidence table. [pmid: 12054147].
Grond S, Zech D, Lynch J, Diefenbach C, Schug S A, Lehmann K A. Validation of World Health Organization guidelines for pain relief in head and neck cancer. A prospective study. Ann Otol Rhinol Laryngol. 93;102(5):342-8. [Rec#: 2837] INCLUDE: considered for evidence table.
Gross M D. What do patients express as their preferences in advance directives? Arch Intern Med 98;158(4):363–5. Comment in: Arch Intern Med. Feb 23. 1998;158(4):321-4. PMID: 9487228. [Rec#: 11731] INCLUDE: considered for evidence table.
Guo H, Fine P G, Mendoza T R, Cleeland C S. A preliminary study of the utility of the brief hospice inventory. J Pain Symptom Manage. 2001;22(2):637-48. [Rec#: 2870] INCLUDE: considered for evidence table. [pmid: 11495710].
Guthrie B, Nelson M, Gazzard B. Are people with HIV in London able to die where they plan?. AIDS Care. 96;8(6):709-13. [Rec#: 11769] INCLUDE: considered for evidence table. [pmid: 8993721].
Gutzmann H, Kuhl K P, Hadler D, Rapp M A. Safety and efficacy of idebenone versus tacrine in patients with Alzheimer's disease: results of a randomized, double-blind, parallel-group multicenter study. Pharmacopsychiatry. 2002;35(1):12-8. [Rec#: 32110] INCLUDE: considered for evidence table. [pmid: 11819153].
Guyatt G H, Berman L B, Townsend M, Pugsley S O, Chambers L W. A measure of quality of life for clinical trials in chronic lung disease. Thorax. 87;42(10):773-8. [Rec#: 50867] INCLUDE: considered for evidence table. [pmid: 3321537].
Haggmark C, Bachner M, Theorell T. A follow-up of psychological state in relatives of cancer patients one year after the patient's death. Effects of an activation programme. Acta Oncol. 91;30(6):677-84. [Rec#: 2911] INCLUDE: considered for evidence table.
Hakim R B, Teno J M, Harrell F E Jr, Knaus W A, Wenger N, Phillips R S, Layde P, Califf R, Connors A F Jr, Lynn J. Factors associated with do-not-resuscitate orders: patients' preferences, prognoses, and physicians' judgments. SUPPORT Investigators. Study to Understand Prognoses and Preferences for Outcomes and Risks of Treatment. Ann Intern Med. 96;125(4):284-93. [Rec#: 41337] INCLUDE: considered for evidence table.
Haley W E, LaMonde L A, Han B, Burton A M, Schonwetter R. Predictors of depression and life satisfaction among spousal caregivers in hospice: application of a stress process model. J Palliat Med. 2003;6(2):215-24. [Rec#: 2937] INCLUDE: considered for evidence table. [pmid: 12854938].
Hall P, Schroder C, Weaver L. The last 48 hours of life in long-term care: a focused chart audit. J Am Geriatr Soc. 2002;50(3):501-6. [Rec#: 2945] INCLUDE: considered for evidence table. [pmid: 11943047].
Hall S, Gallagher R M, Gracely E, Knowlton C, Wescules D. The terminal cancer patient: effects of age, gender, and primary tumor site on opioid dose. Pain Med. 2003;4(2):125-34. [Rec#: 2947] INCLUDE: considered for evidence table. [pmid: 12873262].
Hamel M B, Lynn J, Teno J M, Covinsky K E, Wu A W, Galanos A, Desbiens N A, Phillips R S. Age-related differences in care preferences, treatment decisions, and clinical outcomes of seriously ill hospitalized adults: lessons from SUPPORT. J Am Geriatr Soc. 2000;48(5 Suppl):S176-82. [Rec#: 2954] INCLUDE: considered for evidence table. [pmid: 10809472].
Hamel M B, Phillips R S, Davis R B, Teno J, Connors A F, Desbiens N, Lynn J, Dawson N V, Fulkerson W, Tsevat J. Outcomes and cost-effectiveness of ventilator support and aggressive care for patients with acute respiratory failure due to pneumonia or acute respiratory distress syndrome. American Journal of Medicine. 2000;109(8):614-20. [Rec#: 50474] INCLUDE: considered for evidence table. [pmid: 11099680].
Hamel M B, Phillips R S, Teno J M, Lynn J, Galanos A N, Davis R B, Connors A F Jr, Oye R K, Desbiens N, Reding D J, Goldman L. Seriously ill hospitalized adults: do we spend less on older patients? Support Investigators. Study to Understand Prognoses and Preference for Outcomes and Risks of Treatments. Journal of the American Geriatrics Society. 96;44(9):1043-8. [Rec#: 50476] INCLUDE: considered for evidence table.
Hammes B J, Rooney B L. Death and end-of-life planning in one midwestern community. Arch Intern Med. 98;158(4):383-90. [Rec#: 2961] INCLUDE: considered for evidence table. [pmid: 9487236].
Hanks G W, Robbins M, Sharp D, Forbes K, Done K, Peters T J, Morgan H, Sykes J, Baxter K, Corfe F, Bidgood C. The imPaCT study: a randomised controlled trial to evaluate a hospital palliative care team. Br J Cancer. 2002;87(7):733-9. [Rec#: 2978] INCLUDE: considered for evidence table. [pmid: 12232756].
Hanrahan P, Luchins D J. Access to hospice programs in end-stage dementia: a national survey of hospice programs. J Am Geriatr Soc 95;43(1):56–9. Comment in: J Am Geriatr Soc. 1995 Oct;43(10):1174. PMID: 7560715. Comment in: J Am Geriatr Soc. Oct. 1995;43(10):1174-6. PMID: 7560716. [Rec#: 11846] INCLUDE: considered for evidence table.
Hanson L C, Rodgman E. The use of living wills at the end of life. A national study. Arch Intern Med. 96;156(9):1018-22. [Rec#: 11861] INCLUDE: considered for evidence table. [pmid: 8624167].
Hanson L C, Earp J A, Garrett J, Menon M, Danis M. Community physicians who provide terminal care. Arch Intern Med. 99;159(10):1133-8. [Rec#: 2992] INCLUDE: considered for evidence table. [pmid: 10335692].
Harding R, Higginson I J, Donaldson N. The relationship between patient characteristics and carer psychological status in home palliative cancer care. Support Care Cancer. 2003;11(10):638-43. [Rec#: 3008] INCLUDE: considered for evidence table. [pmid: 12905058].
Hardy J R, Rees E, Ling J, Burman R, Feuer D, Broadley K, Stone P. A prospective survey of the use of dexamethasone on a palliative care unit. Palliat Med 2001;15(1):3–8. Comment in: Palliat Med. Nov. 2001;15(6):521. PMID: 12403513. [Rec#: 11877] INCLUDE: considered for evidence table.
Hardy J R, Rees E A, Gwilliam B, Ling J, Broadley K, A'Hern R. A phase II study to establish the efficacy and toxicity of sodium valproate in patients with cancer-related neuropathic pain. J Pain Symptom Manage 2001;21(3):204–9. Comment in: J Pain Symptom Manage. Jan. 2002;23(1):1. PMID: 11779658. [Rec#: 3015] INCLUDE: considered for evidence table.
Harrell L E, Callaway R, Morere D, Falgout J. The effect of long-term physostigmine administration in Alzheimer's disease. Neurology. 90;40(9):1350-4. [Rec#: 32179] INCLUDE: considered for evidence table. [pmid: 2392216].
Harrison J, Haddad P, Maguire P. The impact of cancer on key relatives: a comparison of relative and patient concerns. European Journal of Cancer. 95;31A(11):1736-40. [Rec#: 50483] INCLUDE: considered for evidence table. [pmid: 8541091].
Haydar Z R, Lowe A J, Kahveci K L, Weatherford W, Finucane T. Differences in end-of-life preferences between congestive heart failure and dementia in a medical house calls program. J Am Geriatr Soc. 2004;52(5):736-40. [Rec#: 50854] INCLUDE: considered for evidence table. [pmid: 15086654].
Hays J C, Kasl S V, Jacobs S C. The course of psychological distress following threatened and actual conjugal bereavement. Psychol Med. 94;24(4):917-27. [Rec#: 3084] INCLUDE: considered for evidence table. [pmid: 7892360].
Heap M J, Munglani R, Klinck J R, Males A G. Elderly patients' preferences concerning life-support treatment. Anaesthesia 93;48(12):1027–33. Comment in: Anaesthesia. Dec. 1993;48(12):1025-6. PMID: 8285319. [Rec#: 3095] INCLUDE: considered for evidence table.
Heaven C M, Maguire P. The relationship between patients' concerns and psychological distress in a hospice setting. Psychooncology. 98;7(6):502-7. [Rec#: 3097] INCLUDE: considered for evidence table. [pmid: 9885091].
Heedman P A, Strang P. Pain and pain alleviation in hospital-based home care: demographic, biological and treatment factors. Support Care Cancer. 2003;11(1):35-40. [Rec#: 3103] INCLUDE: considered for evidence table. [pmid: 12527952].
Heeren O, Menon A S, Raskin A, Ruskin P. Religion and end of life treatment preferences among geriatric patients. Int J Geriatr Psychiatry. 2001;16(2):203-8. [Rec#: 3105] INCLUDE: considered for evidence table. [pmid: 11241726].
Heffner J E, Barbieri C. End-of-life care preferences of patients enrolled in cardiovascular rehabilitation programs. Chest 2000;117(5):1474–81. Comment in: Chest. May. 2000;117(5):1228-31. PMID: 10807804. [Rec#: 3107] INCLUDE: considered for evidence table.
Heffner J E, Barbieri C. Involvement of cardiovascular rehabilitation programs in advance directive education. Arch Intern Med. 96;156(15):1746-51. [Rec#: 11989] INCLUDE: considered for evidence table. [pmid: 8694675].
Heffner J E, Barbieri C, Casey K. Procedure-specific do-not-resuscitate orders. Effect on communication of treatment limitations. Arch Intern Med. 96;156(7):793-7. [Rec#: 41447] INCLUDE: considered for evidence table. [pmid: 8615713].
Heffner J E, Barbieri C, Fracica P, Brown L K. Communicating do-not-resuscitate orders with a computer-based system. Arch Intern Med. 98;158(10):1090-5. [Rec#: 41448] INCLUDE: considered for evidence table. [pmid: 9605780].
Heffner J E, Fahy B, Hilling L, Barbieri C. Attitudes regarding advance directives among patients in pulmonary rehabilitation. Am J Respir Crit Care Med. 96;154(6 Pt 1):1735-40. [Rec#: 3108] INCLUDE: considered for evidence table.
Heffner J E, Fahy B, Hilling L, Barbieri C. Outcomes of advance directive education of pulmonary rehabilitation patients. Am J Respir Crit Care Med. 97;155(3):1055-9. [Rec#: 3109] INCLUDE: considered for evidence table. [pmid: 9116986].
Heidenreich P A, Ruggerio C M, Massie B M. Effect of a home monitoring system on hospitalization and resource use for patients with heart failure. Am Heart J 99;138(4 Pt 1):633–40. Comment in: Am Heart J. Oct. 1999;138(4 Pt 1):599-601. PMID: 10502199. [Rec#: 32251] INCLUDE: considered for evidence table.
Helft P R, Hlubocky F, Wen M, Daugherty C K. Associations among awareness of prognosis, hopefulness, and coping in patients with advanced cancer participating in phase I clinical trials. Support Care Cancer. 2003;11(10):644-51. [Rec#: 41456] INCLUDE: considered for evidence table. [pmid: 12883963].
Heller R F, Fisher J D, D'Este C A, Lim L L, Dobson A J, Porter R. Death and readmission in the year after hospital admission with cardiovascular disease: the Hunter Area Heart and Stroke Register. Med J Aust. 2000;172(6):261-5. [Rec#: 50036] INCLUDE: considered for evidence table. [pmid: 10860090].
Herndon J E 2nd, Fleishman S, Kosty M P, Green M R. A longitudinal study of quality of life in advanced non-small cell lung cancer: Cancer and Leukemia Group B (CALGB) 8931. Control Clin Trials 97;18(4):286–300. Comment in: Control Clin Trials. 1997 Aug;18(4):306–10. PMID: 9257069. Comment in: Control Clin Trials. Aug. 1997;18(4):311-7. PMID: 9257070. [Rec#: 32303] INCLUDE: considered for evidence table.
Hesse K A. Terminal care of the very old. Changes in the way we die. Arch Intern Med. 95;155(14):1513-8. [Rec#: 3180] INCLUDE: considered for evidence table. [pmid: 7605153].
Heyland D K, Konopad E, Noseworthy T W, Johnston R, Gafni A. Is it ‘worthwhile’ to continue treating patients with a prolonged stay (>14 days) in the ICU? An economic evaluation. Chest. 98;114(1):192-8. [Rec#: 41500] INCLUDE: considered for evidence table.
Heyland D K, Lavery J V, Tranmer J E, Shortt S E, Taylor S J. Dying in Canada: is it an institutionalized, technologically supported experience?. J Palliat Care. 2000;16(Suppl):S10-6. [Rec#: 12051] INCLUDE: considered for evidence table. [pmid: 11075528].
Heyland D K, Rocker G M, O'Callaghan C J, Dodek P M, Cook D J. Dying in the ICU: perspectives of family members. Chest 2003;124(1):392–7. Comment in: Chest. Jul. 2003;124(1):11-2. PMID: 12853494. [Rec#: 3184] INCLUDE: considered for evidence table.
Heyland D K, Tranmer J, O'Callaghan C J, Gafni A. The seriously ill hospitalized patient: preferred role in end-of-life decision making?. J Crit Care. 2003;18(1):3-10. [Rec#: 3186] INCLUDE: considered for evidence table. [pmid: 12640606].
Hickok J T, Morrow G R, McDonald S, Bellg A J. Frequency and correlates of fatigue in lung cancer patients receiving radiation therapy: implications for management. J Pain Symptom Manage. 96;11(6):370-7. [Rec#: 32326] INCLUDE: considered for evidence table.
Higginson I, Priest P. Predictors of family anxiety in the weeks before bereavement. Soc Sci Med. 96;43(11):1621-5. [Rec#: 3198] INCLUDE: considered for evidence table. [pmid: 8961406].
Higginson I, Priest P, McCarthy M. Are bereaved family members a valid proxy for a patient's assessment of dying?. Soc Sci Med. 94;38(4):553-7. [Rec#: 12063] INCLUDE: considered for evidence table. [pmid: 7514313].
Higginson I J, Costantini M. Communication in end-of-life cancer care: a comparison of team assessments in three European countries. J Clin Oncol. 2002;20(17):3674-82. [Rec#: 3202] INCLUDE: considered for evidence table. [pmid: 12202669].
Hill K M, Amir Z, Muers M F, Connolly C K, Round C E. Do newly diagnosed lung cancer patients feel their concerns are being met?. Eur J Cancer Care (Engl). 2003;12(1):35-45. [Rec#: 32331] INCLUDE: considered for evidence table. [pmid: 12641555].
Hilliard R E. The effects of music therapy on the quality and length of life of people diagnosed with terminal cancer. J Music Ther. 2003;40(2):113-37. [Rec#: 3213] INCLUDE: considered for evidence table. [pmid: 14505443].
Hinds C. Personal and contextual factors predicting patients' reported quality of life: exploring congruency with Betty Neuman's assumptions. J Adv Nurs. 90;15(4):456-62. [Rec#: 32340] INCLUDE: considered for evidence table.
Hines SC, Glover JJ, Babrow AS, Holley JL, Badzek LA, and Moss AH. Improving advance care planning by accommodating family preferences. J Palliat Med 2001;4(4):481–9. Comment in: J Palliat Med. 2001 Winter;4(4):453–6. PMID: 11798476. [Rec#: 3226] INCLUDE: considered for evidence table
Hines S C, Glover J J, Holley J L, Babrow A S, Badzek L A, Moss A H. Dialysis patients' preferences for family-based advance care planning. Ann Intern Med. 99;130(10):825-8. [Rec#: 3227] INCLUDE: considered for evidence table. [pmid: 10366372].
Hinkka H, Kosunen E, Kellokumpu-Lehtinen P, Lammi U K. Assessment of pain control in cancer patients during the last week of life: comparison of health centre wards and a hospice. Support Care Cancer 2001;9(6):428–34. Comment in: Support Care Cancer. Sep. 2001;9(6):401-2. PMID: 11585265. [Rec#: 3228] INCLUDE: considered for evidence table.
Hinton J. Can home care maintain an acceptable quality of life for patients with terminal cancer and their relatives?. Palliat Med. 94;8(3):183-96. [Rec#: 3236] INCLUDE: considered for evidence table. [pmid: 7952369].
Hinton J. How reliable are relatives' retrospective reports of terminal illness? Patients and relatives' accounts compared. Soc Sci Med. 96;43(8):1229-36. [Rec#: 3237] INCLUDE: considered for evidence table. [pmid: 8903127].
Hinton J. Services given and help perceived during home care for terminal cancer. Palliat Med. 96;10(2):125-34. [Rec#: 3239] INCLUDE: considered for evidence table. [pmid: 8800820].
Hinton J. Which patients with terminal cancer are admitted from home care?. Palliat Med. 94;8(3):197-210. [Rec#: 3240] INCLUDE: considered for evidence table. [pmid: 7952370].
Hodgson C, Higginson I, McDonnell M, Butters E. Family anxiety in advanced cancer: a multicentre prospective study in Ireland. Br J Cancer. 97;76(9):1211-4. [Rec#: 3261] INCLUDE: considered for evidence table. [pmid: 9365171].
Hodgson H. Does reflexology impact on cancer patients' quality of life?. Nurs Stand. 2000;14(31):33-8. [Rec#: 3262] INCLUDE: considered for evidence table. [pmid: 11973949].
Holden C M. Anorexia in the terminally ill cancer patient: the emotional impact on the patient and the family. Hosp J. 91;7(3):73-84. [Rec#: 3285] INCLUDE: considered for evidence table. [pmid: 1820305].
Holden J D. Auditing palliative care in one general practice over eight years. Scand J Prim Health Care. 96;14(3):136-41. [Rec#: 12149] INCLUDE: considered for evidence table. [pmid: 8885024].
Hollen P J, Gralla R J, Kris M G, Eberly S W, Cox C. Normative data and trends in quality of life from the Lung Cancer Symptom Scale (LCSS). Support Care Cancer. 99;7(3):140-8. [Rec#: 32384] INCLUDE: considered for evidence table. [pmid: 10335932].
Holley J L, Hines S C, Glover J J, Babrow A S, Badzek L A, Moss A H. Failure of advance care planning to elicit patients' preferences for withdrawal from dialysis. Am J Kidney Dis. 99;33(4):688-93. [Rec#: 3291] INCLUDE: considered for evidence table.
Holtzman J, Chen Q, Kane R. The effect of HMO status on the outcomes of home-care after hospitalization in a Medicare population. J Am Geriatr Soc. 98;46(5):629-34. [Rec#: 50040] INCLUDE: considered for evidence table. [pmid: 9588380].
Holtzman J, Pheley A M, Lurie N. Changes in orders limiting care and the use of less aggressive care in a nursing home population. J Am Geriatr Soc. 94;42(3):275-9. [Rec#: 41540] INCLUDE: considered for evidence table. [pmid: 8120312].
Holzapfel L, Demingeon G, Piralla B, Biot L, Nallet B. A four-step protocol for limitation of treatment in terminal care. An observational study in 475 intensive care unit patients. Intensive Care Med 2002;28(9):1309–15. Comment in: Intensive Care Med. Sep. 2002;28(9):1197-9. PMID: 12400561. [Rec#: 3303] INCLUDE: considered for evidence table.
Holzheimer A, McMillan S C, Weitzner M. Improving pain outcomes of hospice patients with cancer. Oncol Nurs Forum. 99;26(9):1499-504. [Rec#: 3304] INCLUDE: considered for evidence table. [pmid: 11064881].
Homsi J, Walsh D, Nelson K A, LeGrand S B, Davis M, Khawam E, Nouneh C. The impact of a palliative medicine consultation service in medical oncology. Support Care Cancer. 2002;10(4):337-42. [Rec#: 3311] INCLUDE: considered for evidence table. [pmid: 12029434].
Hopwood P, Stephens R J. Depression in patients with lung cancer: prevalence and risk factors derived from quality-of-life data. J Clin Oncol. 2000;18(4):893-903. [Rec#: 3332] INCLUDE: considered for evidence table. [pmid: 10673533].
Hopwood P, Harvey A, Davies J, Stephens R J, Girling D J, Gibson D, Parmar M K. Survey of the Administration of quality of life (QL) questionnaires in three multicentre randomised trials in cancer. The Medical Research Council Lung Cancer Working Party the CHART Steering Committee. Eur J Cancer. 98;34(1):49-57. [Rec#: 32409] INCLUDE: considered for evidence table.
Hopwood P, Howell A, Maguire P. Psychiatric morbidity in patients with advanced cancer of the breast: prevalence measured by two self-rating questionnaires. British Journal of Cancer. 91;64(2):349-52. [Rec#: 50499] INCLUDE: considered for evidence table.
Hopwood P, Howell A, Maguire P. Screening for psychiatric morbidity in patients with advanced breast cancer: validation of two self-report questionnaires. British Journal of Cancer. 91;64(2):353-6. [Rec#: 50500] INCLUDE: considered for evidence table.
Houts R M, Smucker W D, Jacobson J A, Ditto P H, Danks J H. Predicting elderly outpatients' life-sustaining treatment preferences over time: the majority rules. Med Decis Making. 2002;22(1):39-52. [Rec#: 3364] INCLUDE: considered for evidence table. [pmid: 11833664].
Hugel H, Ellershaw J E, Cook L, Skinner J, Irvine C. The prevalence, key causes and management of insomnia in palliative care patients. J Pain Symptom Manage. 2004;27(4):316-21. [Rec#: 3394] INCLUDE: considered for evidence table. [pmid: 15050659].
Hughes S L, Weaver F M, Giobbie-Hurder A, Manheim L, Henderson W, Kubal J D, Ulasevich A, Cummings J. Department of Veterans Affairs Cooperative Study Group on Home-Based Primary Care. Effectiveness of team-managed home-based primary care: a randomized multicenter trial. JAMA. 2000;284(22):2877-85. [Rec#: 3399] INCLUDE: considered for evidence table. [pmid: 11147984].
Hunt R, Fazekas B, Thorne D, Brooksbank M. A comparison of subcutaneous morphine and fentanyl in hospice cancer patients. J Pain Symptom Manage. 99;18(2):111-9. [Rec#: 3422] INCLUDE: considered for evidence table. [pmid: 10484858].
Hunt R W, Fazekas B S, Luke C G, Roder D M. Where patients with cancer die in South Australia, 1990-1999: a population-based review. Med J Aust 2001;175(10):526–9. Comment in: Med J Aust. Nov 19. 2001;175(10):534-6. PMID: 11795543. [Rec#: 3426] INCLUDE: considered for evidence table.
Hutt E, Ecord M, Eilertsen T B, Frederickson E, Kramer A M. Precipitants of emergency room visits and acute hospitalization in short-stay medicare nursing home residents. J Am Geriatr Soc. 2002;50(2):223-9. [Rec#: 32478] INCLUDE: considered for evidence table. [pmid: 12028202].
Hwang S S, Chang V T, Fairclough D L, Kasimis B. Development of a cancer pain prognostic scale. J Pain Symptom Manage. 2002;24(4):366-78. [Rec#: 3448] INCLUDE: considered for evidence table. [pmid: 12505205].
Ibbotson T, Maguire P, Selby P, Priestman T, Wallace L. Screening for anxiety and depression in cancer patients: the effects of disease and treatment. European Journal of Cancer. 94;30A(1):37-40. [Rec#: 50502] INCLUDE: considered for evidence table.
Im K, Belle S H, Schulz R, Mendelsohn A B, Chelluri L. QOL-MV Investigators. Prevalence and outcomes of caregiving after prolonged (> or =48 hours) mechanical ventilation in the ICU. Chest. 2004;125(2):597-606. [Rec#: 41609] INCLUDE: considered for evidence table. [pmid: 14769744].
Incalzi R A, Gemma A, Marra C, Capparella O, Fuso L, Carbonin P. Verbal memory impairment in COPD: its mechanisms and clinical relevance. Chest. 97;112(6):1506-13. [Rec#: 32517] INCLUDE: considered for evidence table. [pmid: 9404746].
Ingleton C, Morgan J, Hughes P, Noble B, Evans A, Clark D. Carer satisfaction with end-of-life care in Powys, Wales: a cross-sectional survey. Health Soc Care Community. 2004;12(1):43-52. [Rec#: 3473] INCLUDE: considered for evidence table. [pmid: 14675364].
Jaagosild P, Dawson N V, Thomas C, Wenger N S, Tsevat J, Knaus W A, Califf R M, Goldman L, Vidaillet H, Connors A F Jr. Outcomes of acute exacerbation of severe congestive heart failure: quality of life, resource use, and survival. SUPPORT Investigators. The Study to Understand Prognosis and Preferences for Outcomes and Risks of Treatments. Arch Intern Med. 98;158(10):1081-9. [Rec#: 32575] INCLUDE: considered for evidence table.
Jaarsma T, Dracup K, Walden J, Stevenson L W. Sexual function in patients with advanced heart failure. Heart Lung. 96;25(4):262-70. [Rec#: 32580] INCLUDE: considered for evidence table. [pmid: 8836742].
Jaarsma T, Halfens R, Huijer Abu-Saad H, Dracup K, Gorgels T, van Ree J, Stappers J. Effects of education and support on self-care and resource utilization in patients with heart failure. Eur Heart J 99;20(9):673–82. Comment in: Eur Heart J. May. 1999;20(9):632-3. PMID: 10419340. [Rec#: 32582] INCLUDE: considered for evidence table.
Jaarsma T, Halfens R, Tan F, Abu-Saad H H, Dracup K, Diederiks J. Self-care and quality of life in patients with advanced heart failure: the effect of a supportive educational intervention. Heart Lung. 2000;29(5):319-30. [Rec#: 32583] INCLUDE: considered for evidence table. [pmid: 10986526].
Jaarsma T. Sexual problems in heart failure patients. Eur J Cardiovasc Nurs. 2002;1(1):61-7. [Rec#: 32578] INCLUDE: considered for evidence table. [pmid: 14622869].
Jack B, Hillier V, Williams A, Oldham J. Hospital based palliative care teams improve the insight of cancer patients into their disease. Palliat Med. 2004;18(1):46-52. [Rec#: 3510] INCLUDE: considered for evidence table. [pmid: 14982207].
Jack B, Hillier V, Williams A, Oldham J. Hospital based palliative care teams improve the symptoms of cancer patients. Palliat Med. 2003;17(6):498-502. [Rec#: 3511] INCLUDE: considered for evidence table. [pmid: 14526882].
Jacobs L G, Bonuck K, Burton W. Can “Palliative Care Reports” improve end-of-life care for hospitalized patients?. J Pain Symptom Manage. 2002;24(3):299-311. [Rec#: 3530] INCLUDE: considered for evidence table. [pmid: 12458111].
Jacobs S, Hansen F, Kasl S, Ostfeld A, Berkman L, Kim K. Anxiety disorders during acute bereavement: risk and risk factors. J Clin Psychiatry 90;51(7):269–74. Comment in: J Clin Psychiatry. May. 1991;52(5):241. PMID: 2033034. [Rec#: 3534] INCLUDE: considered for evidence table.
Jacobson J A, Kasworm E, Battin M P, Francis L P, Green D, Botkin J, Johnson S. Advance directives in Utah. Information from death certificates and informants. Arch Intern Med. 96;156(16):1862-8. [Rec#: 41636] INCLUDE: considered for evidence table.
Jacoby A, Lecouturier J, Bradshaw C, Lovel T, Eccles M. Feasibility of using postal questionnaires to examine carer satisfaction with palliative care: a methodological assessment. South Tyneside MAAG Palliative Care Study Group. Palliat Med. 99;13(4):285-98. [Rec#: 12351] INCLUDE: considered for evidence table.
Janjan N A, Payne R, Gillis T, Podoloff D, Libshitz H I, Lenzi R, Theriault R, Martin C, Yasko A. Presenting symptoms in patients referred to a multidisciplinary clinic for bone metastases. J Pain Symptom Manage. 98;16(3):171-8. [Rec#: 3561] INCLUDE: considered for evidence table.
Jayes R L, Zimmerman J E, Wagner D P, Knaus W A. Variations in the use of do-not-resuscitate orders in ICUS. Findings from a national study. Chest 96;110(5):1332–9. Comment in: Chest. Nov. 1996;110(5):1141-2. PMID: 8915210. [Rec#: 12388] INCLUDE: considered for evidence table.
Jenkins C A, Schulz M, Hanson J, Bruera E. Demographic, symptom, and medication profiles of cancer patients seen by a palliative care consult team in a tertiary referral hospital. J Pain Symptom Manage. 2000;19(3):174-84. [Rec#: 3578] INCLUDE: considered for evidence table. [pmid: 10760622].
Jenkins C A, Taube A W, Turner K, Hanson J, Bruera E. Initial demographic, symptom, and medication profiles in patients admitted to continuing palliative care units. J Pain Symptom Manage. 98;16(3):163-70. [Rec#: 3579] INCLUDE: considered for evidence table.
Jerant A F, Azari R, Nesbitt T S. Reducing the cost of frequent hospital admissions for congestive heart failure: a randomized trial of a home telecare intervention. Med Care. 2001;39(11):1234-45. [Rec#: 50047] INCLUDE: considered for evidence table. [pmid: 11606877].
Jerant A F, Azari R S, Nesbitt T S, Meyers F J. The TLC model of palliative care in the elderly: preliminary application in the assisted living setting. Ann Fam Med. 2004;2(1):54-60. [Rec#: 3591] INCLUDE: considered for evidence table. [pmid: 15053284]. [pmcid: 1466621].
Jezewski M A, Finnell D S. The meaning of DNR status: oncology nurses' experiences with patients and families. Cancer Nurs. 98;21(3):212-21. [Rec#: 3599] INCLUDE: considered for evidence table. [pmid: 9615512].
Jiang W, Alexander J, Christopher E, Kuchibhatla M, Gaulden L H, Cuffe M S, Blazing M A, Davenport C, Califf R M, Krishnan R R, O'Connor C M. Relationship of depression to increased risk of mortality and rehospitalization in patients with congestive heart failure. Arch Intern Med 2001;161(15):1849–56. Comment in: Arch Intern Med. 2002 Feb 11;162(3):362. PMID: 11822938. Comment in: Arch Intern Med. Feb 11. 2002;162(3):362-4. PMID: 11822939. [Rec#: 50048] INCLUDE: considered for evidence table.
Johnson I S. Use of bisphosphonates for the treatment of metastatic bone pain. A survey of palliative physicians in the UK. Palliat Med. 2001;15(2):141-7. [Rec#: 12440] INCLUDE: considered for evidence table. [pmid: 11301665].
Johnson M F, Lin M, Mangalik S, Murphy D J, Kramer A M. Patients' perceptions of physicians' recommendations for comfort care differ by patient age and gender. J Gen Intern Med. 2000;15(4):248-55. [Rec#: 3624] INCLUDE: considered for evidence table. [pmid: 10760000]. [pmcid: 1495435].
Johnston G, Abraham C. The WHO objectives for palliative care: to what extent are we achieving them?. Palliat Med. 95;9(2):123-37. [Rec#: 12456] INCLUDE: considered for evidence table. [pmid: 7541683].
Johnston S C, Johnson S C. Advance directives: from the perspective of the patient and the physician. J R Soc Med 96;89(10):568–70. Erratum in: J R Soc Med. Feb. 1997;90(2):120. Johnson SC[corrected to Johnston SC]. [Rec#: 12461] INCLUDE: considered for evidence table.
Johnstone P A, Polston G R, Niemtzow R C, Martin P J. Integration of acupuncture into the oncology clinic. Palliat Med. 2002;16(3):235-9. [Rec#: 3635] INCLUDE: considered for evidence table. [pmid: 12047000].
Jordhoy M S, Fayers P, Loge J H, Ahlner-Elmqvist M, Kaasa S. Quality of life in palliative cancer care: results from a cluster randomized trial. J Clin Oncol 2001;19(18):3884–94. Comment in: J Clin Oncol. Mar 15. 2002;20(6):1704-5. PMID: 11896122. [Rec#: 3660] INCLUDE: considered for evidence table.
Jordhoy M S, Saltvedt I, Fayers P, Loge J H, Ahlner-Elmqvist M, Kaasa S. Which cancer patients die in nursing homes? Quality of life, medical and sociodemographic characteristics. Palliat Med. 2003;17(5):433-44. [Rec#: 3664] INCLUDE: considered for evidence table. [pmid: 12882262].
Jorm AF, Henderson S, Scott R, Mackinnon AJ, Korten AE, and Christensen H. The disabled elderly living in the community: care received from family and formal services. Med J Aust 93;158(6):383–5, 388. [Rec#: 41697] INCLUDE: considered for evidence table
Junod Perron N, Morabia A, de Torrente A. Quality of life of Do-Not-Resuscitate (DNR) patients: how good are physicians in assessing DNR patients' quality of life?. Swiss Med Wkly. 2002;132(3940):562-5. [Rec#: 41704] INCLUDE: considered for evidence table. [pmid: 12571762].
Kaasa S, Malt U, Hagen S, Wist E, Moum T, Kvikstad A. Psychological distress in cancer patients with advanced disease. Radiother Oncol. 93;27(3):193-7. [Rec#: 3687] INCLUDE: considered for evidence table. [pmid: 7692472].
Kaldjian L C, Jekel J F, Friedland G. End-of-life decisions in HIV-positive patients: the role of spiritual beliefs. AIDS. 98;12(1):103-7. [Rec#: 12530] INCLUDE: considered for evidence table. [pmid: 9456260].
Kalra L, Evans A, Perez I, Knapp M, Donaldson N, Swift C G. Alternative strategies for stroke care: a prospective randomised controlled trial. Lancet 2000;356(9233):894–9. Comment in: Lancet. 2000 Sep 9;356(9233):869–70. PMID: 11036886. Comment in: Lancet. 2001 Jan 13;357(9250):146–7. PMID: 11197428. Comment in: Lancet. Jan 13. 2001;357(9250):146. author reply 147. PMID: 11197429. [Rec#: 3712] INCLUDE: considered for evidence table.
Kalso E, Heiskanen T, Rantio M, Rosenberg P H, Vainio A. Epidural and subcutaneous morphine in the management of cancer pain: a double-blind cross-over study. Pain. 96;67(23):443-9. [Rec#: 3713] INCLUDE: considered for evidence table.
Kane R L, Homyak P, Bershadsky B, Lum Y S. Consumer responses to the Wisconsin Partnership Program for Elderly Persons: a variation on the PACE Model. J Gerontol A Biol Sci Med Sci. 2002;57(4):M250-8. [Rec#: 41719] INCLUDE: considered for evidence table. [pmid: 11909892].
Kane R L, Keckhafer G, Flood S, Bershadsky B, Siadaty M S. The effect of Evercare on hospital use. J Am Geriatr Soc. 2003;51(10):1427-34. [Rec#: 41721] INCLUDE: considered for evidence table. [pmid: 14511163].
Karetzky M, Zubair M, Parikh J. Cardiopulmonary resuscitation in intensive care unit and non-intensive care unit patients. Immediate and long-term survival. Arch Intern Med 95;155(12):1277–80. Comment in: Arch Intern Med. Jan 22. 1996;156(2):215-6. PMID: 8546559. [Rec#: 41729] INCLUDE: considered for evidence table.
Karlin N J, Retzlaff P D. Psychopathology in caregivers of the chronically ill: personality and clinical syndromes. Hosp J. 95;10(3):55-61. [Rec#: 12550] INCLUDE: considered for evidence table. [pmid: 8606052].
Keay T J, Taler G A, Fredman L, Levenson S A. Assessing medical care of dying residents in nursing homes. Am J Med Qual. 97;12(3):151-6. [Rec#: 3799] INCLUDE: considered for evidence table. [pmid: 9287453].
Keefe F J, Ahles T A, Porter L S, Sutton L M, McBride C M, Pope M S, McKinstry E T, Furstenberg C P, Dalton J, Baucom D H. The self-efficacy of family caregivers for helping cancer patients manage pain at end-of-life. Pain. 2003;103(12):157-62. [Rec#: 3801] INCLUDE: considered for evidence table. [pmid: 12749970].
Keegan O, McGee H, Hogan M, Kunin H, O'Brien S, O'Siorain L. Relatives' views of health care in the last year of life. Int J Palliat Nurs. 2001;7(9):449-56. [Rec#: 12596] INCLUDE: considered for evidence table. [pmid: 11832849].
Keenan S P, Busche K D, Chen L M, Esmail R, Inman K J, Sibbald W J. Withdrawal and withholding of life support in the intensive care unit: a comparison of teaching and community hospitals. The Southwestern Ontario Critical Care Research Network. Critical Care Medicine. 98;26(2):245-51. [Rec#: 50513] INCLUDE: considered for evidence table.
Keenan S P, Busche K D, Chen L M, McCarthy L, Inman K J, Sibbald W J. A retrospective review of a large cohort of patients undergoing the process of withholding or withdrawal of life support. Critical Care Medicine. 97;25(8):1324-31. [Rec#: 50514] INCLUDE: considered for evidence table.
Keene J, Hope T, Fairburn C G, Jacoby R. Death and dementia. Int J Geriatr Psychiatry 2001;16(10):969–74. Comment in: Int J Geriatr Psychiatry. Nov. 2002;17(11):1078. PMID: 12404661. [Rec#: 41748] INCLUDE: considered for evidence table.
Kehayia E, Korner-Bitensky N, Singer F, Becker R, Lamarche M, Georges P, Retik S. Differences in pain medication use in stroke patients with aphasia and without aphasia. Stroke. 97;28(10):1867-70. [Rec#: 3803] INCLUDE: considered for evidence table.
Kellogg F R, Ramos A. Code status decision-making in a nursing home population: processes and outcomes. J Am Geriatr Soc. 95;43(2):113-21. [Rec#: 3815] INCLUDE: considered for evidence table. [pmid: 7836634].
Kelly B, Edwards P, Synott R, Neil C, Baillie R, Battistutta D. Predictors of bereavement outcome for family carers of cancer patients. Psychooncology. 99;8(3):237-49. [Rec#: 3819] INCLUDE: considered for evidence table. [pmid: 10390736].
Kennard M J, Speroff T, Puopolo A L, Follen M A, Mallatratt L, Phillips R, Desbiens N, Califf R M, Connors A F Jr. Participation of nurses in decision making for seriously ill adults. Clin Nurs Res. 96;5(2):199-219. [Rec#: 3840] INCLUDE: considered for evidence table.
Kernerman P, Cook D J, Griffith L E. Documenting life-support preferences in hospitalized patients. J Crit Care. 97;12(4):155-60. [Rec#: 41760] INCLUDE: considered for evidence table. [pmid: 9459110].
Kerridge I H, Pearson S A, Rolfe I E, Lowe M. Decision making in CPR: attitudes of hospital patients and healthcare professionals. Med J Aust 98;169(3):128–31. Comment in: Med J Aust. 1998 Aug 3;169(3):124–5. PMID: 9734504. Comment in: Med J Aust. 1999 Jan 4;170(1):45–6. PMID: 10026675. Comment in: Med J Aust. 1999 Jan 4;170(1):45; author reply 45–6. PMID: 10026674. Comment in: Med J Aust. May. 1999;3:170. [Rec#: 3855] INCLUDE: considered for evidence table.
Kiely D K, Mitchell S L, Marlow A, Murphy K M, Morris J N. Racial and state differences in the designation of advance directives in nursing home residents. J Am Geriatr Soc. 2001;49(10):1346-52. [Rec#: 12673] INCLUDE: considered for evidence table. [pmid: 11890494].
Kimball L R, McCormick W C. The pharmacologic management of pain and discomfort in persons with AIDS near the end of life: use of opioid analgesia in the hospice setting. J Pain Symptom Manage. 96;11(2):88-94. [Rec#: 3892] INCLUDE: considered for evidence table.
Kirschling J M, Stewart B J, Archbold P G. Family caregivers of post-hospitalized older persons and persons receiving hospice: similarities and differences. Home Health Care Serv Q. 94;14(4):117-40. [Rec#: 3923] INCLUDE: considered for evidence table.
Kish Wallace S, Martin C G, Shaw A D, Price K J. Influence of an advance directive on the initiation of life support technology in critically ill cancer patients. Crit Care Med 2001;29(12):2294–8. Comment in: Crit Care Med. Dec. 2001;29(12):2391-2. PMID: 11801850. [Rec#: 41781] INCLUDE: considered for evidence table.
Kissane D W, McKenzie M, McKenzie D P, Forbes A, O'Neill I, Bloch S. Psychosocial morbidity associated with patterns of family functioning in palliative care: baseline data from the Family Focused Grief Therapy controlled trial. Palliat Med. 2003;17(6):527-37. [Rec#: 3934] INCLUDE: considered for evidence table. [pmid: 14526887].
Knol H R, Haken L, Kempen G I. Disablement process and the utilization of home care among non-institutionalized elderly people: contrasting results between cross-sectional and panel data. Disabil Rehabil. 2003;25(15):845-55. [Rec#: 41806] INCLUDE: considered for evidence table. [pmid: 12851095].
Koeberle D, Bacchus L, Thuerlimann B, Senn H J. Pamidronate treatment in patients with malignant osteolytic bone disease and pain: a prospective randomized double-blind trial. Support Care Cancer 99;7(1):21–7. Comment in: Support Care Cancer. Jan. 1999;7(1):1-3. PMID: 9926966. [Rec#: 3980] INCLUDE: considered for evidence table.
Koedoot C G, Oort F J, de Haan R J, Bakker P J, de Graeff A, de Haes J C. The content and amount of information given by medical oncologists when telling patients with advanced cancer what their treatment options are Palliative chemotherapy and watchful-waiting. Eur J Cancer. 2004;40(2):225-35. [Rec#: 3984] INCLUDE: considered for evidence table. [pmid: 14728937].
Koenig H G. Depression in hospitalized older patients with congestive heart failure. Gen Hosp Psychiatry. 98;20(1):29-43. [Rec#: 41814] INCLUDE: considered for evidence table. [pmid: 9506252].
Koffman J, Higginson I J, Donaldson N. Symptom severity in advanced cancer, assessed in two ethnic groups by interviews with bereaved family members and friends. J R Soc Med. 2003;96(1):10-6. [Rec#: 12762] INCLUDE: considered for evidence table. [pmid: 12519796]. [pmcid: 539365].
Kolarik R C, Arnold R M, Fischer G S, Hanusa B H. Advance care planning. J Gen Intern Med. 2002;17(8):618-24. [Rec#: 3998] INCLUDE: considered for evidence table. [pmid: 12213143]. [pmcid: 1495096].
Kongsgaard U E, Meidell N K. Mechanical ventilation in critically ill cancer patients: outcome and utilisation of resources. Support Care Cancer. 99;7(2):95-9. [Rec#: 4010] INCLUDE: considered for evidence table. [pmid: 10089090].
Kornblith A B, Herndon J E, Zuckerman E, Viscoli C M, Horwitz R I, Cooper M R, Harris L, Tkaczuk K H, Perry M C, Budman D, Norton L C, Holland J. Breast Cancer and Leukemia Group. Social support as a buffer to the psychological impact of stressful life events in women with breast cancer. Cancer. 2001;91(2):443-54. [Rec#: 50526] INCLUDE: considered for evidence table. [pmid: 11180093].
Kramer B J, Kipnis S. Eldercare and work-role conflict: toward an understanding of gender differences in caregiver burden. Gerontologist. 95;35(3):340-8. [Rec#: 41841] INCLUDE: considered for evidence table. [pmid: 7622087].
Kristjanson L J, Leis A, Koop P M, Carriere K C, Mueller B. Family members' care expectations, care perceptions, and satisfaction with advanced cancer care: results of a multi-site pilot study. J Palliat Care. 97;13(4):5-13. [Rec#: 4063] INCLUDE: considered for evidence table.
Kristjanson L J, Sloan J A, Dudgeon D, Adaskin E. Family members' perceptions of palliative cancer care: predictors of family functioning and family members' health. J Palliat Care. 96;12(4):10-20. [Rec#: 4066] INCLUDE: considered for evidence table.
Kristjanson L J. Validity and reliability testing of the FAMCARE Scale: measuring family satisfaction with advanced cancer care. Social Science & Medicine. 93;36(5):693-701. [Rec#: 50531] INCLUDE: considered for evidence table.
Kristjansson B, Breithaupt K, McDowell I. Development and validation of an indicator of support for community-residing older Canadians. Int Psychogeriatr. 2001;13(Supp 1):125-35. [Rec#: 41855] INCLUDE: considered for evidence table. [pmid: 11892959].
Krout R E. The effects of single-session music therapy interventions on the observed and self-reported levels of pain control, physical comfort, and relaxation of hospice patients. Am J Hosp Palliat Care. 2001;18(6):383-90. [Rec#: 4074] INCLUDE: considered for evidence table. [pmid: 11712719].
Krumholz H M, Phillips R S, Hamel M B, Teno J M, Bellamy P, Broste S K, Califf R M, Vidaillet H, Davis R B, Muhlbaier L H, Connors A F Jr, Lynn J, Goldman L. Resuscitation preferences among patients with severe congestive heart failure: results from the SUPPORT project. Study to Understand Prognoses and Preferences for Outcomes and Risks of Treatments. Circulation 98;98(7):648–55. Comment in: Circulation. Aug 18. 1998;98(7):619-22. PMID: 9715851. [Rec#: 4078] INCLUDE: considered for evidence table.
Kuin A, Courtens A M, Deliens L, Vernooij-Dassen M J, van Zuylen L, van der Linden B, van der Wal G. Palliative care consultation in The Netherlands: a nationwide evaluation study. J Pain Symptom Manage. 2004;27(1):53-60. [Rec#: 4092] INCLUDE: considered for evidence table. [pmid: 14711469].
Kunik M E, Benton C L, Snow-Turek A L, Molinari V, Orengo C A, Workman R. The contribution of cognitive impairment, medical burden, and psychopathology to the functional status of geriatric psychiatric inpatients. Gen Hosp Psychiatry. 98;20(3):183-8. [Rec#: 41867] INCLUDE: considered for evidence table.
Kurlowicz L H, Evans L K, Strumpf N E, Maislin G. A psychometric evaluation of the Cornell Scale for Depression in Dementia in a frail, nursing home population. Am J Geriatr Psychiatry. 2002;10(5):600-8. [Rec#: 41869] INCLUDE: considered for evidence table. [pmid: 12213695].
Kurti L G, O'Dowd T C. Dying of non-malignant diseases in general practice. J Palliat Care. 95;11(3):25-31. [Rec#: 4112] INCLUDE: considered for evidence table. [pmid: 7472788].
Kutner J S, Kassner C T, Nowels D E. Symptom burden at the end of life: hospice providers' perceptions. J Pain Symptom Manage. 2001;21(6):473-80. [Rec#: 4121] INCLUDE: considered for evidence table. [pmid: 11397605].
Kuuppelomaki M. Pain management problems in patients' terminal phase as assessed by nurses in Finland. J Adv Nurs. 2002;40(6):701-9. [Rec#: 4126] INCLUDE: considered for evidence table. [pmid: 12473050].
Labrecque M S, Blanchard C G, Ruckdeschel J C, Blanchard E B. The impact of family presence on the physician-cancer patient interaction. Social Science & Medicine. 91;33(11):1253-61. [Rec#: 50534] INCLUDE: considered for evidence table.
Lammi U K, Kosunen E, Kellokumpu-Lehtinen P. Palliative cancer care in two health centres and one hospice in Finland. Support Care Cancer. 2001;9(1):25-31. [Rec#: 4170] INCLUDE: considered for evidence table. [pmid: 11147139].
Lamont E B, Christakis N A. Physician factors in the timing of cancer patient referral to hospice palliative care. Cancer. 2002;94(10):2733-7. [Rec#: 4171] INCLUDE: considered for evidence table. [pmid: 12173344].
Landi F, Onder G, Cesari M, Gambassi G, Steel K, Russo A, Lattanzio F, Bernabei R. Pain management in frail, community-living elderly patients. Arch Intern Med. 2001;161(22):2721-4. [Rec#: 41890] INCLUDE: considered for evidence table. [pmid: 11732938].
Landry F J, Kroenke K, Lucas C, Reeder J. Increasing the use of advance directives in medical outpatients. J Gen Intern Med. 97;12(7):412-5. [Rec#: 4175] INCLUDE: considered for evidence table. [pmid: 9229279].
Larsson B W, Larsson G, Carlson S R. Advanced home care: patients' opinions on quality compared with those of family members. J Clin Nurs. 2004;13(2):226-33. [Rec#: 4213] INCLUDE: considered for evidence table. [pmid: 14723675].
Lasater M. The effect of a nurse-managed CHF clinic on patient readmission and length of stay. Home Healthc Nurse. 96;14(5):351-6. [Rec#: 50057] INCLUDE: considered for evidence table. [pmid: 8847218].
Latimer E J, Crabb M R, Roberts J G, Ewen M, Roberts J. The Patient Care Travelling Record in palliative care: effectiveness and efficiency. J Pain Symptom Manage. 98;16(1):41-51. [Rec#: 4220] INCLUDE: considered for evidence table. [pmid: 9707656].
Lawlor P, Turner K, Hanson J, Bruera E. Dose ratio between morphine and hydromorphone in patients with cancer pain: a retrospective study. Pain. 97;72(12):79-85. [Rec#: 4245] INCLUDE: considered for evidence table. [pmid: 9272790].
Lawlor P G, Nekolaichuk C, Gagnon B, Mancini I L, Pereira J L, Bruera E D. Clinical utility, factor analysis, and further validation of the memorial delirium assessment scale in patients with advanced cancer: Assessing delirium in advanced cancer. Cancer. 2000;88(12):2859-67. [Rec#: 4246] INCLUDE: considered for evidence table. [pmid: 10870073].
Lawlor P G, Gagnon B, Mancini I L, Pereira J L, Hanson J, Suarez-Almazor M E, Bruera E D. Occurrence, causes, and outcome of delirium in patients with advanced cancer: a prospective study. Archives of Internal Medicine. 2000;160(6):786-94. [Rec#: 50538] INCLUDE: considered for evidence table. [pmid: 10737278].
Lee M A, Brummel-Smith K, Meyer J, Drew N, London M R. Physician orders for life-sustaining treatment (POLST): outcomes in a PACE program. Program of All-Inclusive Care for the Elderly. J Am Geriatr Soc 2000;48(10):1219–25. Comment in: J Am Geriatr Soc. Oct. 2000;48(10):1343-4. PMID: 11037027. [Rec#: 4290] INCLUDE: considered for evidence table.
Leff B, Kaffenbarger K P, Remsburg R. Prevalence, effectiveness, and predictors of planning the place of death among older persons followed in community-based long term care. J Am Geriatr Soc. 2000;48(8):943-8. [Rec#: 4306] INCLUDE: considered for evidence table. [pmid: 10968299].
Levenson J W, McCarthy E P, Lynn J, Davis R B, Phillips R S. The last six months of life for patients with congestive heart failure. J Am Geriatr Soc. 2000;48(5 Suppl):S101-9. [Rec#: 4361] INCLUDE: considered for evidence table. [pmid: 10809463].
Levin J R, Wenger N S, Ouslander J G, Zellman G, Schnelle J F, Buchanan J L, Hirsch S H, Reuben D B. Life-sustaining treatment decisions for nursing home residents: who discusses, who decides and what is decided?. J Am Geriatr Soc. 99;47(1):82-7. [Rec#: 41975] INCLUDE: considered for evidence table.
Lewis S, Bridge M, Roughton D, Barelds J, Brenton S, Cotter S, Hagebols M L, Woolman K, Annells M, Koch T. Quality of life issues identified by palliative care clients using two tools. Contemp Nurse. 2002;12(1):31-41. [Rec#: 4385] INCLUDE: considered for evidence table. [pmid: 12013515].
Lilly C M, De Meo D L, Sonna L A, Haley K J, Massaro A F, Wallace R F, Cody S. An intensive communication intervention for the critically ill. Am J Med. 2000;109(6):469-75. [Rec#: 4424] INCLUDE: considered for evidence table. [pmid: 11042236].
Lilly C M, Sonna L A, Haley K J, Massaro A F. Intensive communication: four-year follow-up from a clinical practice study. Crit Care Med. 2003;31(5 Suppl):S394-9. [Rec#: 4425] INCLUDE: considered for evidence table. [pmid: 12771590].
Lloyd-Williams M, Payne S. Can multidisciplinary guidelines improve the palliation of symptoms in the terminal phase of dementia?. Int J Palliat Nurs. 2002;8(8):370-5. [Rec#: 4501] INCLUDE: considered for evidence table. [pmid: 12271257].
Lloyd-Williams M, Riddleston H. The stability of depression scores in patients who are receiving palliative care. J Pain Symptom Manage. 2002;24(6):593-7. [Rec#: 4503] INCLUDE: considered for evidence table. [pmid: 12551809].
Lloyd-Williams M. An audit of palliative care in dementia. Eur J Cancer Care (Engl). 96;5(1):53-5. [Rec#: 4490] INCLUDE: considered for evidence table. [pmid: 8715471].
Lloyd-Williams M. Screening for depression in palliative care patients: a review. Eur J Cancer Care (Engl). 2001;10(1):31-5. [Rec#: 13136] INCLUDE: considered for evidence table. [pmid: 11827265].
Lobchuk M M, Vorauer J D. Family caregiver perspective-taking and accuracy in estimating cancer patient symptom experiences. Soc Sci Med. 2003;57(12):2379-84. [Rec#: 13154] INCLUDE: considered for evidence table. [pmid: 14572844].
Lockhart L K, Ditto P H, Danks J H, Coppola K M, Smucker W D. The stability of older adults' judgments of fates better and worse than death. Death Stud. 2001;25(4):299-317. [Rec#: 4521] INCLUDE: considered for evidence table. [pmid: 11803982].
Long K, Sudha S, Mutran E J. Elder-proxy agreement concerning the functional status and medical history of the older person: the impact of caregiver burden and depressive symptomatology. J Am Geriatr Soc. 98;46(9):1103-11. [Rec#: 42038] INCLUDE: considered for evidence table.
Luthi J C, Lund M J, Sampietro-Colom L, Kleinbaum D G, Ballard D J, McClellan W M. Readmissions and the quality of care in patients hospitalized with heart failure. Int J Qual Health Care. 2003;15(5):413-21. [Rec#: 50064] INCLUDE: considered for evidence table. [pmid: 14527985].
Lutz S, Norrell R, Bertucio C, Kachnic L, Johnson C, Arthur D, Schwarz M, Palardy G. Symptom frequency and severity in patients with metastatic or locally recurrent lung cancer: a prospective study using the Lung Cancer Symptom Scale in a community hospital. J Palliat Med. 2001;4(2):157-65. [Rec#: 4607] INCLUDE: considered for evidence table. [pmid: 11441624].
Lynn J, Teno J M, Phillips R S, Wu A W, Desbiens N, Harrold J, Claessens M T, Wenger N, Kreling B, Connors A F Jr. Perceptions by family members of the dying experience of older and seriously ill patients. SUPPORT Investigators. Study to Understand Prognoses and Preferences for Outcomes and Risks of Treatments. Ann Intern Med 97;126(2):97–106. Comment in: Ann Intern Med. 1997 Aug 1;127(3):242–3. PMID: 9245235. Comment in: Ann Intern Med. 1997 Aug 1;127(3):242; author reply 243. PMID: 9245234. Comment in: Ann Intern Med. Aug 1. 1997;127(3):243. PMID: 9245236. Comment in: Ann Intern Med. 1. [Rec#: 4628] INCLUDE: considered for evidence table.
Macdonald A J, Carpenter G I, Box O, Roberts A, Sahu S. Dementia and use of psychotropic medication in non-‘Elderly Mentally Infirm’ nursing homes in South East England. Age Ageing. 2002;31(1):58-64. [Rec#: 42083] INCLUDE: considered for evidence table. [pmid: 11850309].
Macias C, Jones D, Harvey J, Barreira P, Harding C, Rodican C. Bereavement in the context of serious mental illness. Psychiatr Serv. 2004;55(4):421-6. [Rec#: 4653] INCLUDE: considered for evidence table. [pmid: 15067155].
Maguire P, Walsh S, Jeacock J, Kingston R. Physical and psychological needs of patients dying from colo-rectal cancer. Palliat Med. 99;13(1):45-50. [Rec#: 4682] INCLUDE: considered for evidence table. [pmid: 10320875].
Mahoney D F, Tarlow B J, Jones R N. Effects of an automated telephone support system on caregiver burden and anxiety: findings from the REACH for TLC intervention study. Gerontologist. 2003;43(4):556-67. [Rec#: 50919] INCLUDE: considered for evidence table. [pmid: 12937334].
Mak J M, Clinton M. Promoting a good death: an agenda for outcomes research--a review of the literature. Nurs Ethics. 99;6(2):97-106. [Rec#: 13351] INCLUDE: considered for evidence table. [pmid: 10358525].
Maksoud A, Jahnigen D W, Skibinski C I. Do not resuscitate orders and the cost of death. Arch Intern Med 93;153(10):1249–53. Comment in: Arch Intern Med. Feb 14. 1994;154(3):348. PMID: 8297204. [Rec#: 4710] INCLUDE: considered for evidence table.
Malacrida R, Bettelini C M, Degrate A, Martinez M, Badia F, Piazza J, Vizzardi N, Wullschleger R, Rapin C H. Reasons for dissatisfaction: a survey of relatives of intensive care patients who died. Crit Care Med 98;26(7):1187–93. Comment in: Crit Care Med. 1998 Jul;26(7):1150–1. PMID: 9671355. Comment in: Crit Care Med. Jan. 2000;28(1):289-90. PMID: 10667559. [Rec#: 4712] INCLUDE: considered for evidence table.
Manara A R, Pittman J A, Braddon F E. Reasons for withdrawing treatment in patients receiving intensive care. Anaesthesia. 98;53(6):523-8. [Rec#: 4740] INCLUDE: considered for evidence table. [pmid: 9709135].
Manfredi P L, Breuer B, Meier D E, Libow L. Pain assessment in elderly patients with severe dementia. J Pain Symptom Manage. 2003;25(1):48-52. [Rec#: 33456] INCLUDE: considered for evidence table. [pmid: 12565188].
Manfredi P L, Morrison R S, Morris J, Goldhirsch S L, Carter J M, Meier D E. Palliative care consultations: how do they impact the care of hospitalized patients?. J Pain Symptom Manage. 2000;20(3):166-73. [Rec#: 4747] INCLUDE: considered for evidence table. [pmid: 11018334].
Manfredi R, Mastroianni A, Coronado O, Chiodo F. Therapeutic and diagnostic procedures in hospitalized AIDS patients with terminal illness. AIDS Care. 96;8(3):373-6. [Rec#: 4748] INCLUDE: considered for evidence table. [pmid: 8827128].
Manfredi P L, Breuer B, Wallenstein S, Stegmann M, Bottomley G, Libow L. Opioid treatment for agitation in patients with advanced dementia. International Journal of Geriatric Psychiatry. 2003;18(8):700-5. [Rec#: 50584] INCLUDE: considered for evidence table. [pmid: 12891637].
Manfredi P L, Chandler S, Pigazzi A, Payne R. Outcome of cancer pain consultations. Cancer. 2000;89(4):920-4. [Rec#: 50585] INCLUDE: considered for evidence table. [pmid: 10951358].
Mann W C, Ottenbacher K J, Fraas L, Tomita M, Granger C V. Effectiveness of assistive technology and environmental interventions in maintaining independence and reducing home care costs for the frail elderly. A randomized controlled trial. Arch Fam Med 99;8(3):210–7. Comment in: ACP J Club. Nov-Dec. 1999;131(3):71. [Rec#: 42117] INCLUDE: considered for evidence table.
Mansfield D R, Gollogly N C, Kaye D M, Richardson M, Bergin P, Naughton M T. Controlled trial of continuous positive airway pressure in obstructive sleep apnea and heart failure. Am J Respir Crit Care Med 2004;169(3):361–6. Comment in: Am J Respir Crit Care Med. Feb 1. 2004;169(3):329-31. PMID: 14739130. [Rec#: 33472] INCLUDE: considered for evidence table.
Marbella A M, Desbiens N A, Mueller-Rizner N, Layde P M. Surrogates' agreement with patients' resuscitation preferences: effect of age, relationship, and SUPPORT intervention. Study to Understand Prognoses and Preferences for Outcomes and Risks of Treatment. J Crit Care. 98;13(3):140-5. [Rec#: 4767] INCLUDE: considered for evidence table.
Mark D H, Bahr J, Duthie E H, Tresch D D. Characteristics of residents with do-not-resuscitate orders in nursing homes. Arch Fam Med. 95;4(5):463-7. [Rec#: 42135] INCLUDE: considered for evidence table. [pmid: 7742971].
Markowitz J S, Gutterman E M, Sadik K, Papadopoulos G. Health-related quality of life for daregivers of patients With Alzheimer disease. Alzheimer Disease and Associated Disorders. 2003;17(4):209-214. [Rec#: 50592] INCLUDE: considered for evidence table. [pmid: 14657784].
Marrie T J, Fine M J, Kapoor W N, Coley C M, Singer D E, Obrosky D S. Community-acquired pneumonia and do not resuscitate orders. J Am Geriatr Soc. 2002;50(2):290-9. [Rec#: 42142] INCLUDE: considered for evidence table. [pmid: 12028211].
Martensson J, Dracup K, Fridlund B. Decisive situations influencing spouses' support of patients with heart failure: a critical incident technique analysis. Heart Lung. 2001;30(5):341-50. [Rec#: 33506] INCLUDE: considered for evidence table. [pmid: 11604976].
Martensson J, Dracup K, Canary C, Fridlund B. Living with heart failure: depression and quality of life in patients and spouses. J Heart Lung Transplant. 2003;22(4):460-7. [Rec#: 33505] INCLUDE: considered for evidence table. [pmid: 12681424].
Martikainen P, Valkonen T. Do education and income buffer the effects of death of spouse on mortality?. Epidemiology. 98;9(5):530-4. [Rec#: 4800] INCLUDE: considered for evidence table. [pmid: 9730032].
Mattimor T J, Wenger N S, Desbiens N A, Teno J M, Hamel M B, Liu H, Califf R, Connors A F Jr, Lynn J, Oye R K. Surrogate and physician understanding of patients' preferences for living permanently in a nursing home. Journal of the American Geriatrics Society. 97;45(7):818-24. [Rec#: 50595] INCLUDE: considered for evidence table.
Mausbach B T, Coon D W, Depp C, Rabinowitz Y G, Wilson-Arias E, Kraemer H C, Thompson L W, Lane G, Gallagher-Thompson D. Ethnicity and time to institutionalization of dementia patients: a comparison of latina and caucasian female family caregivers. J Am Geriatr Soc. 2004;52(7):1077-84. [Rec#: 50856] INCLUDE: considered for evidence table. [pmid: 15209644].
Mazzocato C, Buclin T, Rapin C H. The effects of morphine on dyspnea and ventilatory function in elderly patients with advanced cancer: a randomized double-blind controlled trial. Ann Oncol. 99;10(12):1511-4. [Rec#: 4881] INCLUDE: considered for evidence table.
McAuley W J, Travis S S. Advance care planning among residents in long-term care. Am J Hosp Palliat Care 2003;20(5):353–9. Comment in: Am J Hosp Palliat Care. Sep-Oct. 2003;20(5):329-30. PMID: 14529032. [Rec#: 42193] INCLUDE: considered for evidence table.
McCann R M, Hall W J, Groth-Juncker A. Comfort care for terminally ill patients. The appropriate use of nutrition and hydration. JAMA 94;272(16):1263–6. Comment in: JAMA. 1995 Jun 14;273(22):1736–7. PMID: 7769756. Comment in: JAMA. 1995 Jun 14;273(22):1736; author reply 1737. PMID: 7769755. Comment in: JAMA. Jun 14. 1995;273(22):1736. author reply 1737. PMID: 7632249. Comment in: JAMA. 1995 Jun 14. [Rec#: 4900] INCLUDE: considered for evidence table.
McCarthy E P, Burns R B, Davis R B, Phillips R S. Barriers to hospice care among older patients dying with lung and colorectal cancer. J Clin Oncol. 2003;21(4):728-35. [Rec#: 4908] INCLUDE: considered for evidence table. [pmid: 12586813].
McCarthy E P, Phillips R S, Zhong Z, Drews R E, Lynn J. Dying with cancer: patients' function, symptoms, and care preferences as death approaches. J Am Geriatr Soc. 2000;48(5 Suppl):S110-21. [Rec#: 4910] INCLUDE: considered for evidence table. [pmid: 10809464].
McCarthy M, Addington-Hall J, Altmann D. The experience of dying with dementia: a retrospective study. Int J Geriatr Psychiatry. 97;12(3):404-9. [Rec#: 4911] INCLUDE: considered for evidence table. [pmid: 9152728].
McCarthy M, Hall J A, Ley M. Communication and choice in dying from heart disease. J R Soc Med. 97;90(3):128-31. [Rec#: 13520] INCLUDE: considered for evidence table. [pmid: 9135608].
McCarthy M, Lay M, Addington-Hall J. Dying from heart disease. J R Coll Physicians Lond. 96;30(4):325-8. [Rec#: 4912] INCLUDE: considered for evidence table. [pmid: 8875378].
McClain C S, Rosenfeld B, Breitbart W. Effect of spiritual well-being on end-of-life despair in terminally-ill cancer patients. Lancet 2003;361(9369):1603–7. Comment in: Lancet. Aug 2. 2003;362(9381):408. PMID: 12907029. [Rec#: 4914] INCLUDE: considered for evidence table.
McCormack A, Hunter-Smith D, Piotrowski Z H, Grant M, Kubik S, Kessel K. Analgesic use in home hospice cancer patients. J Fam Pract. 92;34(2):160-4. [Rec#: 4932] INCLUDE: considered for evidence table. [pmid: 1371139].
McCracken L M, Matthews A K, Tang T S, Cuba S L. A comparison of blacks and whites seeking treatment for chronic pain. Clinical Journal of Pain. 2001;17(3):249-55. [Rec#: 50600] INCLUDE: considered for evidence table. [pmid: 11587117].
McCusker J, Cole M, Dendukuri N, Han L, Belzile E. The course of delirium in older medical inpatients: a prospective study. J Gen Intern Med 2003;18(9):696–704. Comment in: J Gen Intern Med. Sep. 2003;18(9):770-1. PMID: 12950488. [Rec#: 33618] INCLUDE: considered for evidence table.
McDaniel K D, Edland S D, Heyman A. Relationship between level of insight and severity of dementia in Alzheimer disease. CERAD Clinical Investigators. Consortium to Establish a Registry for Alzheimer's Disease. Alzheimer Dis Assoc Disord. 95;9(2):101-4. [Rec#: 33620] INCLUDE: considered for evidence table.
McDonald D D, Deloge J A, Joslin N, Petow W A, Severson J S, Votino R, Shea M D, Drenga J M, Brennan M T, Moran A B, Del Signore E. Communicating end-of-life preferences. West J Nurs Res. 2003;25(6):652-66. discussion 667–75. [Rec#: 4943] INCLUDE: considered for evidence table. [pmid: 14528616].
McKinley E D, Garrett J M, Evans A T, Danis M. Differences in end-of-life decision making among black and white ambulatory cancer patients. J Gen Intern Med. 96;11(11):651-6. [Rec#: 5001] INCLUDE: considered for evidence table. [pmid: 9120650].
McMillan S C, Mahon M. A study of quality of life of hospice patients on admission and at week 3. Cancer Nurs. 94;17(1):52-60. [Rec#: 5019] INCLUDE: considered for evidence table. [pmid: 8180977].
McMillan S C, Mahon M. The impact of hospice services on the quality of life of primary caregivers. Oncol Nurs Forum. 94;21(7):1189-95. [Rec#: 5017] INCLUDE: considered for evidence table. [pmid: 7971429].
McMillan S C, Moody L E. Hospice patient and caregiver congruence in reporting patients' symptom intensity. Cancer Nurs. 2003;26(2):113-8. [Rec#: 5020] INCLUDE: considered for evidence table. [pmid: 12660560].
McNamara P. Opioid switching from morphine to transdermal fentanyl for toxicity reduction in palliative care. Palliat Med. 2002;16(5):425-34. [Rec#: 5028] INCLUDE: considered for evidence table. [pmid: 12380661].
McParland E, Likourezos A, Chichin E, Castor T, Paris B E BE. Stability of preferences regarding life-sustaining treatment: a two-year prospective study of nursing home residents. Mt Sinai J Med. 2003;70(2):85-92. [Rec#: 42225] INCLUDE: considered for evidence table. [pmid: 12634900].
McQuellon R P, Moose D B, Russell G B, Case L D, Greven K, Stevens M, Shaw E G. Supportive use of megestrol acetate (Megace) with head/neck and lung cancer patients receiving radiation therapy. Int J Radiat Oncol Biol Phys. 2002;52(5):1180-5. [Rec#: 33660] INCLUDE: considered for evidence table. [pmid: 11955728].
McWhinney I R, Bass M J, Donner A. Evaluation of a palliative care service: problems and pitfalls. BMJ 94;309(6965):1340–2. Comment in: BMJ. 1994 Nov 19;309(6965):1315–6. PMID: 7532500. Comment in: BMJ. 1995 Jan 14;310(6972):125. PMID: 7530537. Comment in: BMJ. 1995 Jan 14;310(6972):125. PMID: 7530536. Comment in: BMJ. Jan 14. 1995;310(6972):125. PMID: 7530535. Comment . [Rec#: 13642] INCLUDE: considered for evidence table.
Mead G E, Turnbull C J. Cardiopulmonary resuscitation in the elderly: patients' and relatives' views. J Med Ethics 95;21(1):39–44. Comment in: J Med Ethics. Jun. 1996;22(3):181-2. PMID: 8798943. [Rec#: 5041] INCLUDE: considered for evidence table.
Melin A L, Bygren L O. Efficacy of the rehabilitation of elderly primary health care patients after short-stay hospital treatment. Med Care. 92;30(11):1004-15. [Rec#: 42249] INCLUDE: considered for evidence table. [pmid: 1331632].
Melltorp G, Nilstun T. Decisions to forego life-sustaining treatment and the duty of documentation. Intensive Care Med 96;22(10):1015–9. Comment in: Intensive Care Med. Oct. 1996;22(10):1003-5. PMID: 8923060. [Rec#: 42253] INCLUDE: considered for evidence table.
Mercadante S, Casuccio A, Genovese G. Ineffectiveness of dextromethorphan in cancer pain. J Pain Symptom Manage. 98;16(5):317-22. [Rec#: 5086] INCLUDE: considered for evidence table. [pmid: 9846026].
Mercadante S, Casuccio A, Pumo S, Fulfaro F. Factors influencing the opioid response in advanced cancer patients with pain followed at home: the effects of age and gender. Support Care Cancer. 2000;8(2):123-30. [Rec#: 5087] INCLUDE: considered for evidence table. [pmid: 10739359].
Mercadante S, Fulfaro F, Casuccio A. A randomised controlled study on the use of anti-inflammatory drugs in patients with cancer pain on morphine therapy: effects on dose-escalation and a pharmacoeconomic analysis. Eur J Cancer. 2002;38(10):1358-63. [Rec#: 5092] INCLUDE: considered for evidence table. [pmid: 12091067].
Mercadante S, Fulfaro F, Casuccio A. The impact of home palliative care on symptoms in advanced cancer patients. Support Care Cancer. 2000;8(4):307-10. [Rec#: 5090] INCLUDE: considered for evidence table. [pmid: 10923771].
Mercadante S, Fulfaro F, Casuccio A, Barresi L. Investigation of an opioid response categorization in advanced cancer patients. J Pain Symptom Manage. 99;18(5):347-52. [Rec#: 5094] INCLUDE: considered for evidence table. [pmid: 10584458].
Mercadante S, Girelli D, and Casuccio A. Sleep disorders in advanced cancer patients: prevalence and factors associated. Support Care Cancer 2004. [Rec#: 5096] INCLUDE: considered for evidence table
Mercadante S, Villari P, Ferrera P, Casuccio A, Fulfaro F. Rapid titration with intravenous morphine for severe cancer pain and immediate oral conversion. Cancer. 2002;95(1):203-8. [Rec#: 50607] INCLUDE: considered for evidence table. [pmid: 12115334].
Merimsky O, Kollender Y, Inbar M, Chaitchik S, Meller I. Palliative major amputation and quality of life in cancer patients. Acta Oncol. 97;36(2):151-7. [Rec#: 5102] INCLUDE: considered for evidence table. [pmid: 9140431].
Meyer H A, Sinnott C, Seed P T. Depressive symptoms in advanced cancer. Part 2. Depression over time; the role of the palliative care professional. Palliat Med. 2003;17(7):604-7. [Rec#: 13718] INCLUDE: considered for evidence table. [pmid: 14594151].
Mezey M, Kluger M, Maislin G, Mittelman M. Life-sustaining treatment decisions by spouses of patients with Alzheimer's disease. J Am Geriatr Soc. 96;44(2):144-50. [Rec#: 42276] INCLUDE: considered for evidence table. [pmid: 8576503].
Miceli P J, Mylod D E. Satisfaction of families using end-of-life care: current successes and challenges in the hospice industry. Am J Hosp Palliat Care. 2003;20(5):360-70. [Rec#: 5136] INCLUDE: considered for evidence table. [pmid: 14529039].
Middelboe T, Ovesen L, Mortensen E L, Bech P. Depressive symptoms in cancer patients undergoing chemotherapy: a psychometric analysis. Psychother Psychosom. 94;61(34):171-7. [Rec#: 33742] INCLUDE: considered for evidence table. [pmid: 8066154].
Middlewood S, Gardner G, Gardner A. Dying in hospital: medical failure or natural outcome?. J Pain Symptom Manage. 2001;22(6):1035-41. [Rec#: 5153] INCLUDE: considered for evidence table. [pmid: 11738166].
Miettinen T T, Tilvis R S, Karppi P, Arve S. Why is the pain relief of dying patients often unsuccessful? The relatives' perspectives. Palliat Med. 98;12(6):429-35. [Rec#: 5155] INCLUDE: considered for evidence table. [pmid: 10621862].
Milberg A, Strang P, Carlsson M, Borjesson S. Advanced palliative home care: next-of-kin's perspective. J Palliat Med. 2003;6(5):749-56. [Rec#: 13733] INCLUDE: considered for evidence table. [pmid: 14622454].
Miller B, McFall S. The effect of caregiver's burden on change in frail older persons' use of formal helpers. J Health Soc Behav. 91;32(2):165-79. [Rec#: 42289] INCLUDE: considered for evidence table. [pmid: 1861051].
Miller S C, Mor V, Teno J. Hospice enrollment and pain assessment and management in nursing homes. J Pain Symptom Manage. 2003;26(3):791-9. [Rec#: 5181] INCLUDE: considered for evidence table. [pmid: 12967728].
Miller S C, Mor V, Wu N, Gozalo P, Lapane K. Does receipt of hospice care in nursing homes improve the management of pain at the end of life?. J Am Geriatr Soc. 2002;50(3):507-15. [Rec#: 5182] INCLUDE: considered for evidence table. [pmid: 11943048].
Minagawa H, Uchitomi Y, Yamawaki S, Ishitani K. Psychiatric morbidity in terminally ill cancer patients. A prospective study. Cancer 96;78(5):1131–7. Comment in: Cancer. May 1. 1997;79(9):1848-50. PMID: 9129008. [Rec#: 5197] INCLUDE: considered for evidence table.
Mirotznik J. Does cognitive status moderate the health effects of single-person room transfers on nursing home residents?. Gerontologist. 2002;42(5):634-42. [Rec#: 50077] INCLUDE: considered for evidence table. [pmid: 12351798].
Mitchell S L, Buchanan J L, Littlehale S, Hamel M B. Tube-feeding versus hand-feeding nursing home residents with advanced dementia: a cost comparison. J Am Med Dir Assoc. 2004;5(2 Suppl):S22-9. [Rec#: 33780] INCLUDE: considered for evidence table. [pmid: 14984607].
Mitchell S L, Kiely D K, Hamel M B. Dying with advanced dementia in the nursing home. Arch Intern Med. 2004;164(3):321-6. [Rec#: 5221] INCLUDE: considered for evidence table. [pmid: 14769629].
Mitchell S L, Kiely D K, Gillick M R. Nursing home characteristics associated with tube feeding in advanced cognitive impairment. Journal of the American Geriatrics Society. 2003;51(1):75-9. [Rec#: 50613] INCLUDE: considered for evidence table. [pmid: 12534849].
Mitchell S L, Kiely D K, Lipsitz L A. The risk factors and impact on survival of feeding tube placement in nursing home residents with severe cognitive impairment. Archives of Internal Medicine. 97;157(3):327-32. [Rec#: 50615] INCLUDE: considered for evidence table.
Moadel A, Morgan C, Fatone A, Grennan J, Carter J, Laruffa G, Skummy A, Dutcher J. Seeking meaning and hope: self-reported spiritual and existential needs among an ethnically-diverse cancer patient population. Psycho-Oncology. 99;8(5):378-85. [Rec#: 50616] INCLUDE: considered for evidence table.
Mogielnicki R P, Nelson W A, Dulac J. A study of the dying process in elderly hospitalized males. J Cancer Educ. 90;5(2):135-45. [Rec#: 5246] INCLUDE: considered for evidence table. [pmid: 2206934].
Molloy D W, Guyatt G H, Russo R, Goeree R, O'Brien B J, Bedard M, Willan A, Watson J, Patterson C, Harrison C, Standish T, Strang D, Darzins P J, Smith S, Dubois S. Systematic implementation of an advance directive program in nursing homes: a randomized controlled trial. JAMA. 2000;283(11):1437-44. [Rec#: 50889] INCLUDE: considered for evidence table. [pmid: 10732933].
Montazeri A, Milroy R, Hole D, McEwen J, Gillis C R. Anxiety and depression in patients with lung cancer before and after diagnosis: findings from a population in Glasgow, Scotland. J Epidemiol Community Health. 98;52(3):203-4. [Rec#: 33819] INCLUDE: considered for evidence table.
Monteleoni C, Clark E. Using rapid-cycle quality improvement methodology to reduce feeding tubes in patients with advanced dementia: before and after study. BMJ. 2004;329(7464):491-4. [Rec#: 50912] INCLUDE: considered for evidence table. [pmid: 15331474]. [pmcid: 515202].
Moody L E, McMillan S. Dyspnea and quality of life indicators in hospice patients and their caregivers. Health Qual Life Outcomes. 2003;1(1):9. [Rec#: 5277] INCLUDE: considered for evidence table. [pmid: 12740034]. [pmcid: 155633].
Mor V, Intrator O, Fries B E, Phillips C, Teno J, Hiris J, Hawes C, Morris J. Changes in hospitalization associated with introducing the Resident Assessment Instrument. J Am Geriatr Soc 97;45(8):1002–10. Comment in: J Am Geriatr Soc. 1997 Aug;45(8):1025–6. PMID: 9256858. Comment in: J Am Geriatr Soc. 1997 Aug;45(8):1027–8. PMID: 9256859. Comment in: J Am Geriatr Soc. Aug. 1997;45(8):975-6. PMID: 9256851. [Rec#: 42330] INCLUDE: considered for evidence table.
Morita T, Hirai K, Sakaguchi Y, Tsuneto S, Shima Y. Family-perceived distress from delirium-related symptoms of terminally ill cancer patients. Psychosomatics. 2004;45(2):107-13. [Rec#: 5322] INCLUDE: considered for evidence table. [pmid: 15016923].
Morita T, Tei Y, Inoue S. Impaired communication capacity and agitated delirium in the final week of terminally ill cancer patients: prevalence and identification of research focus. J Pain Symptom Manage. 2003;26(3):827-34. [Rec#: 5329] INCLUDE: considered for evidence table. [pmid: 12967731].
Morita T, Tei Y, Tsunoda J, Inoue S, Chihara S. Increased plasma morphine metabolites in terminally ill cancer patients with delirium: an intra-individual comparison. J Pain Symptom Manage 2002;23(2):107–13. Comment in: J Pain Symptom Manage. Sep. 2002;24(3):273. author reply 273–4. PMID: 12458096. [Rec#: 5333] INCLUDE: considered for evidence table.
Morita T, Tsunoda J, Inoue S, Chihara S. Contributing factors to physical symptoms in terminally-ill cancer patients. J Pain Symptom Manage. 99;18(5):338-46. [Rec#: 5335] INCLUDE: considered for evidence table. [pmid: 10584457].
Morita T, Tsunoda J, Inoue S, Chihara S, Oka K. Communication Capacity Scale and Agitation Distress Scale to measure the severity of delirium in terminally ill cancer patients: a validation study. Palliat Med. 2001;15(3):197-206. [Rec#: 5344] INCLUDE: considered for evidence table. [pmid: 11407191].
Moss M S, Lawton M P, Glicksman A. The role of pain in the last year of life of older persons. J Gerontol. 91;46(2):P51-7. [Rec#: 42355] INCLUDE: considered for evidence table. [pmid: 1997576].
Mouton C, Teno J M, Mor V, Piette J. Communication of preferences for care among human immunodeficiency virus-infected patients. Barriers to informed decisions?. Arch Fam Med. 97;6(4):342-7. [Rec#: 5387] INCLUDE: considered for evidence table.
Muers M F, Round C E. Palliation of symptoms in non-small cell lung cancer: a study by the Yorkshire Regional Cancer Organisation Thoracic Group. Thorax. 93;48(4):339-43. [Rec#: 5394] INCLUDE: considered for evidence table. [pmid: 7685550].
Munn B, Worobec F. Data collection as the first step in program development: the experience of a chronic care palliative unit. J Palliat Care. 97;13(2):39-42. [Rec#: 5410] INCLUDE: considered for evidence table. [pmid: 9231586].
Murberg T A, Bru E, Aarsland T, Svebak S. Social support, social disability and their role as predictors of depression among patients with congestive heart failure. Scand J Soc Med. 98;26(2):87-95. [Rec#: 33917] INCLUDE: considered for evidence table.
Murphy K, Hanrahan P, Luchins D. A survey of grief and bereavement in nursing homes: the importance of hospice grief and bereavement for the end-stage Alzheimer's disease patient and family. J Am Geriatr Soc 97;45(9):1104–7. Comment in: J Am Geriatr Soc. Sep. 1997;45(9):1147-9. PMID: 9288027. [Rec#: 13938] INCLUDE: considered for evidence table.
Musgrave C F, Bartal N, Opstad J. The sensation of thirst in dying patients receiving i.v. hydration. J Palliat Care. 95;11(4):17-21. [Rec#: 5450] INCLUDE: considered for evidence table. [pmid: 8648517].
Mutran E J, Danis M, Bratton K A, Sudha S, Hanson L. Attitudes of the critically ill toward prolonging life: the role of social support. Gerontologist. 97;37(2):192-9. [Rec#: 5453] INCLUDE: considered for evidence table. [pmid: 9127975].
Mystakidou K, Parpa E, Tsilika E, Kalaidopoulou O, Vlahos L. The families evaluation on management, care and disclosure for terminal stage cancer patients. BMC Palliat Care. 2002;1(1):3. [Rec#: 5460] INCLUDE: considered for evidence table. [pmid: 11945181]. [pmcid: 102762].
Nekolaichuk C L, Maguire T O, Suarez-Almazor M, Rogers W T, Bruera E. Assessing the reliability of patient, nurse, and family caregiver symptom ratings in hospitalized advanced cancer patients. J Clin Oncol. 99;17(11):3621-30. [Rec#: 5510] INCLUDE: considered for evidence table.
Nelson C J, Rosenfeld B, Breitbart W, Galietta M. Spirituality, religion, and depression in the terminally ill. Psychosomatics. 2002;43(3):213-20. [Rec#: 5512] INCLUDE: considered for evidence table. [pmid: 12075036].
Nelson K A, Glare P A, Walsh D, Groh E S. A prospective, within-patient, crossover study of continuous intravenous and subcutaneous morphine for chronic cancer pain. J Pain Symptom Manage. 97;13(5):262-7. [Rec#: 5516] INCLUDE: considered for evidence table.
Newton M, Bell D, Lambert S, Fearing A. Concerns of hospice patient caregivers. ABNF J. 2002;13(6):140-4. [Rec#: 5549] INCLUDE: considered for evidence table. [pmid: 12592831].
Ng K, von Gunten C F. Symptoms and attitudes of 100 consecutive patients admitted to an acute hospice/palliative care unit. J Pain Symptom Manage. 98;16(5):307-16. [Rec#: 5552] INCLUDE: considered for evidence table. [pmid: 9846025].
Ngo-Metzger Q, McCarthy E P, Burns R B, Davis R B, Li F P, Phillips R S. Older Asian Americans and Pacific Islanders dying of cancer use hospice less frequently than older white patients. Am J Med. 2003;115(1):47-53. [Rec#: 5554] INCLUDE: considered for evidence table. [pmid: 12867234].
Nolan M T. Could lack of clarity in written advance directives contribute to their ineffectiveness? A study of the content of written advance directives. Appl Nurs Res. 2003;16(1):65-9. [Rec#: 5587] INCLUDE: considered for evidence table. [pmid: 12624865].
Nordgren L, Sorensen S. Symptoms experienced in the last six months of life in patients with end-stage heart failure. Eur J Cardiovasc Nurs. 2003;2(3):213-7. [Rec#: 5603] INCLUDE: considered for evidence table. [pmid: 14622629].
Northouse L L, Dorris G, Charron-Moore C. Factors affecting couples' adjustment to recurrent breast cancer. Social Science & Medicine. 95;41(1):69-76. [Rec#: 50646] INCLUDE: considered for evidence table. [pmid: 7667674].
Norton L E, Malloy P F, Salloway S. The impact of behavioral symptoms on activities of daily living in patients with dementia. Am J Geriatr Psychiatry. 2001;9(1):41-8. [Rec#: 34082] INCLUDE: considered for evidence table. [pmid: 11156751].
Nourhashemi F, Andrieu S, Sastres N, Ducasse J L, Lauque D, Sinclair A J, Albarede J L, Vellas B J. Descriptive analysis of emergency hospital admissions of patients with Alzheimer disease. Alzheimer Dis Assoc Disord. 2001;15(1):21-5. [Rec#: 50082] INCLUDE: considered for evidence table. [pmid: 11236821].
Nowels D, Lee J T. Cancer pain management in home hospice settings: a comparison of primary care and oncologic physicians. J Palliat Care. 99;15(3):5-9. [Rec#: 5622] INCLUDE: considered for evidence table. [pmid: 10540791].
O'Brien L A, Grisso J A, Maislin G, LaPann K, Krotki K P, Greco P J, Siegert E A, Evans L K. Nursing home residents' preferences for life-sustaining treatments. JAMA. 95;274(22):1775-9. [Rec#: 50649] INCLUDE: considered for evidence table. [pmid: 7500508].
O'Connell L J. Changing the culture of dying. A new awakening of spirituality in America heightens sensitivity to needs of dying persons. Health Prog. 96;77(6):16-20. [Rec#: 14115] INCLUDE: considered for evidence table. [pmid: 10163231].
Oneschuk D, Hanson J, Bruera E. A survey of mouth pain and dryness in patients with advanced cancer. Supportive Care in Cancer. 2000;8(5):372-6. [Rec#: 50654] INCLUDE: considered for evidence table. [pmid: 10975686].
Owen A, Croucher L. Effect of an exercise programme for elderly patients with heart failure. Eur J Heart Fail. 2000;2(1):65-70. [Rec#: 34210] INCLUDE: considered for evidence table. [pmid: 10742705].
Pace J C, Stables J L. Correlates of spiritual well-being in terminally ill persons with AIDS and terminally ill persons with cancer. J Assoc Nurses AIDS Care. 97;8(6):31-42. [Rec#: 5791] INCLUDE: considered for evidence table.
Paris B E, Carrion V G, Meditch J S Jr, Capello C F, Mulvihill M N. Roadblocks to do-not-resuscitate orders. A study in policy implementation. Arch Intern Med 93;153(14):1689–95. Comment in: Arch Intern Med. Jul 26. 1993;153(14):1641-8. PMID: 8333801. [Rec#: 5833] INCLUDE: considered for evidence table.
Parshall M B, Welsh J D, Brockopp D Y, Heiser R M, Schooler M P, Cassidy K B. Dyspnea duration, distress, and intensity in emergency department visits for heart failure. Heart Lung. 2001;30(1):47-56. [Rec#: 34266] INCLUDE: considered for evidence table. [pmid: 11174367].
Passik S D, Kirsh K L, Rosenfeld B, McDonald M V, Theobald D E. The changeable nature of patients' fears regarding chemotherapy: implications for palliative care. J Pain Symptom Manage. 2001;21(2):113-20. [Rec#: 5864] INCLUDE: considered for evidence table. [pmid: 11226762].
Patrick D L, Pearlman R A, Starks H E, Cain K C, Cole W G, Uhlmann R F. Validation of preferences for life-sustaining treatment: implications for advance care planning. Ann Intern Med. 97;127(7):509-17. [Rec#: 5877] INCLUDE: considered for evidence table.
Payne J L, Sheppard J M, Steinberg M, Warren A, Baker A, Steele C, Brandt J, Lyketsos C G. Incidence, prevalence, and outcomes of depression in residents of a long-term care facility with dementia. Int J Geriatr Psychiatry. 2002;17(3):247-53. [Rec#: 34296] INCLUDE: considered for evidence table. [pmid: 11921153].
Payne S, Hillier R, Langley-Evans A, Roberts T. Impact of witnessing death on hospice patients. Soc Sci Med. 96;43(12):1785-94. [Rec#: 5900] INCLUDE: considered for evidence table. [pmid: 8961421].
Payne S, Smith P, Dean S. Identifying the concerns of informal carers in palliative care. Palliat Med. 99;13(1):37-44. [Rec#: 5901] INCLUDE: considered for evidence table. [pmid: 10320874].
Payne S A. A study of quality of life in cancer patients receiving palliative chemotherapy. Soc Sci Med. 92;35(12):1505-9. [Rec#: 5903] INCLUDE: considered for evidence table. [pmid: 1283035].
Pearson I Y, Bazeley P, Spencer-Plane T, Chapman J R, Robertson P. A survey of families of brain dead patients: their experiences, attitudes to organ donation and transplantation. Anaesth Intensive Care. 95;23(1):88-95. [Rec#: 5910] INCLUDE: considered for evidence table.
Pekmezaris R, Breuer L, Zaballero A, Wolf-Klein G, Jadoon E, D'Olimpio J T, Guzik H, Foley C J, Weiner J, Chan S. Predictors of site of death of end-of-life patients: the importance of specificity in advance directives. J Palliat Med. 2004;7(1):9-17. [Rec#: 5923] INCLUDE: considered for evidence table. [pmid: 15000779].
Pelletier-Hibbert M, Sohi P. Sources of uncertainty and coping strategies used by family members of individuals living with end stage renal disease. Nephrol Nurs J. 2001;28(4):411-7. [Rec#: 5926] INCLUDE: considered for evidence table. [pmid: 12143463].
Pereira J, Hanson J, Bruera E. The frequency and clinical course of cognitive impairment in patients with terminal cancer. Cancer. 97;79(4):835-42. [Rec#: 5946] INCLUDE: considered for evidence table. [pmid: 9024722].
Pereira J, Watanabe S, Wolch G. A retrospective review of the frequency of infections and patterns of antibiotic utilization on a palliative care unit. J Pain Symptom Manage. 98;16(6):374-81. [Rec#: 5947] INCLUDE: considered for evidence table.
Perkins H S, Geppert C M, Gonzales A, Cortez J D, Hazuda H P. Cross-cultural similarities and differences in attitudes about advance care planning. J Gen Intern Med. 2002;17(1):48-57. [Rec#: 5956] INCLUDE: considered for evidence table. [pmid: 11903775]. [pmcid: 1494998].
Peruselli C, Di Giulio P, Toscani F, Gallucci M, Brunelli C, Costantini M, Tamburini M, Paci E, Miccinesi G, Addington-Hall J M, Higginson I J. Home palliative care for terminal cancer patients: a survey on the final week of life. Palliat Med. 99;13(3):233-41. [Rec#: 5970] INCLUDE: considered for evidence table.
Peruselli C, Paci E, Franceschi P, Legori T, Mannucci F. Outcome evaluation in a home palliative care service. J Pain Symptom Manage. 97;13(3):158-65. [Rec#: 5971] INCLUDE: considered for evidence table. [pmid: 9114634].
Pfeifer M P, Mitchell C K, Chamberlain L. The value of disease severity in predicting patient readiness to address end-of-life issues. Arch Intern Med. 2003;163(5):609-12. [Rec#: 6002] INCLUDE: considered for evidence table. [pmid: 12622608].
Philbin E F, Rocco T A, Lindenmuth N W, Ulrich K, McCall M, Jenkins P L. The results of a randomized trial of a quality improvement intervention in the care of patients with heart failure. The MISCHF Study Investigators. Am J Med 2000;109(6):443–9. Comment in: Am J Med. Oct 15. 2000;109(6):501-3. PMID: 11042244. [Rec#: 34368] INCLUDE: considered for evidence table.
Phillips R S, Hamel M B, Teno J M, Soukup J, Lynn J, Califf R, Vidaillet H, Davis R B, Bellamy P, Goldman L. Patient race and decisions to withhold or withdraw life-sustaining treatments for seriously ill hospitalized adults. SUPPORT Investigators Study to Understand Prognoses and Preferences for Outcomes and Risks of Treatments. American Journal of Medicine. 2000;108(1):14-9. [Rec#: 50672] INCLUDE: considered for evidence table. [pmid: 11059436].
Phipps E, True G, Harris D, Chong U, Tester W, Chavin S I, Braitman L E. Approaching the end of life: attitudes, preferences, and behaviors of African-American and white patients and their family caregivers. J Clin Oncol. 2003;21(3):549-54. [Rec#: 6014] INCLUDE: considered for evidence table. [pmid: 12560448].
Pietersma P, Follett-Bick S, Wilkinson B, Guebert N, Fisher K, Pereira J. A bedside food cart as an alternate food service for acute and palliative oncological patients. Support Care Cancer. 2003;11(9):611-4. [Rec#: 14452] INCLUDE: considered for evidence table. [pmid: 12883966].
Pijnenborg L, van der Maas P J, Kardaun J W, Glerum J J, van Delden J J, Looman C W. Withdrawal or withholding of treatment at the end of life. Results of a nationwide study. Arch Intern Med. 95;155(3):286-92. [Rec#: 6028] INCLUDE: considered for evidence table.
Porock D, Oliver D P, Zweig S C, Rantz M, Petroski G F. A profile of residents admitted to long-term care facilities for end-of-life care. J Am Med Dir Assoc. 2003;4(1):16-22. [Rec#: 14520] INCLUDE: considered for evidence table. [pmid: 12807592].
Portenoy R K, Miransky J, Thaler H T, Hornung J, Bianchi C, Cibas-Kong I, Feldhamer E, Lewis F, Matamoros I, Sugar M Z, et al. Pain in ambulatory patients with lung or colon cancer. Prevalence, characteristics, and effect. Cancer. 92;70(6):1616-24. [Rec#: 34455] INCLUDE: considered for evidence table.
Portenoy R K, Thaler H T, Kornblith A B, Lepore J M, Friedlander-Klar H, Coyle N, Smart-Curley T, Kemeny N, Norton L, Hoskins W. Symptom prevalence, characteristics and distress in a cancer population. Quality of Life Research. 94;3(3):183-9. [Rec#: 50679] INCLUDE: considered for evidence table.
Porter L S, Keefe F J, McBride C M, Pollak K, Fish L, Garst J. Perceptions of patients' self-efficacy for managing pain and lung cancer symptoms: correspondence between patients and family caregivers. Pain. 2002;98(12):169-78. [Rec#: 6088] INCLUDE: considered for evidence table. [pmid: 12098629].
Potkins D, Bradley S, Shrimanker J, O'Brien J, Swann A, Ballard C. End of life treatment decisions in people with dementia: carers' views and the factors which influence them. Int J Geriatr Psychiatry. 2000;15(11):1005-8. [Rec#: 6099] INCLUDE: considered for evidence table. [pmid: 11113979].
Potter J, Hami F, Bryan T, Quigley C. Symptoms in 400 patients referred to palliative care services: prevalence and patterns. Palliat Med 2003;17(4):310–4. Comment in: Palliat Med. 2003 Dec;17(8):723–4. PMID: 14694928. Comment in: Palliat Med. Jan. 2004;18(1):75-6. PMID: 14982215. [Rec#: 6102] INCLUDE: considered for evidence table.
Powazki R D, Walsh D. Acute care palliative medicine: psychosocial assessment of patients and primary caregivers. Palliat Med 99;13(5):367–74. Erratum in: Palliat Med. Mar. 2000;14(2):168. [Rec#: 6110] INCLUDE: considered for evidence table.
Powazki R D, Walsh D. Family distress in palliative medicine: a pilot study of the family APGAR scale. Am J Hosp Palliat Care. 2002;19(6):392-6. [Rec#: 6111] INCLUDE: considered for evidence table. [pmid: 12442974].
Pratheepawanit N, Salek M S, Finlay I G. The applicability of quality-of-life assessment in palliative care: comparing two quality-of-life measures. Palliat Med. 99;13(4):325-34. [Rec#: 6126] INCLUDE: considered for evidence table.
Prigerson H G, Cherlin E, Chen J H, Kasl S V, Hurzeler R, Bradley E H. The Stressful Caregiving Adult Reactions to Experiences of Dying (SCARED) Scale: a measure for assessing caregiver exposure to distress in terminal care. Am J Geriatr Psychiatry. 2003;11(3):309-19. [Rec#: 6143] INCLUDE: considered for evidence table. [pmid: 12724110].
Pronzato P, Bertelli G, Losardo P, Landucci M. What do advanced cancer patients know of their disease? A report from Italy. Support Care Cancer. 94;2(4):242-4. [Rec#: 6162] INCLUDE: considered for evidence table. [pmid: 7522106].
Quirt C F, Mackillop W J, Ginsburg A D, Sheldon L, Brundage M, Dixon P, Ginsburg L. Do doctors know when their patients don't? A survey of doctor-patient communication in lung cancer. Lung Cancer. 97;18(1):1-20. [Rec#: 34546] INCLUDE: considered for evidence table.
Rabow M W, Dibble S L, Pantilat S Z, McPhee S J. The comprehensive care team: a controlled trial of outpatient palliative medicine consultation. Arch Intern Med. 2004;164(1):83-91. [Rec#: 6208] INCLUDE: considered for evidence table. [pmid: 14718327].
Rabow M W, Petersen J, Schanche K, Dibble S L, McPhee S J. The comprehensive care team: a description of a controlled trial of care at the beginning of the end of life. J Palliat Med. 2003;6(3):489-99. [Rec#: 6211] INCLUDE: considered for evidence table. [pmid: 14509498].
Radbruch L, Sabatowski R, Elsner F, Loick G, Kohnen N. Patients' associations with regard to analgesic drugs and their forms for application—a pilot study. Supportive Care in Cancer. 2002;10(6):480-5. [Rec#: 50689] INCLUDE: considered for evidence table. [pmid: 12353127].
Raftery J P, Addington-Hall J M, MacDonald L D, Anderson H R, Bland J M, Chamberlain J, Freeling P. A randomized controlled trial of the cost-effectiveness of a district co-ordinating service for terminally ill cancer patients. Palliat Med. 96;10(2):151-61. [Rec#: 6221] INCLUDE: considered for evidence table.
Ramsay A. Care of cancer patients in a home-based hospice program: a comparison of oncologists and primary care physicians. J Fam Pract. 92;34(2):170-4. [Rec#: 6245] INCLUDE: considered for evidence table. [pmid: 1371140].
Ratner E, Norlander L, McSteen K. Death at home following a targeted advance-care planning process at home: the kitchen table discussion. J Am Geriatr Soc 2001;49(6):778–81. Comment in: J Am Geriatr Soc. Jun. 2001;49(6):833-4. PMID: 11454127. [Rec#: 6278] INCLUDE: considered for evidence table.
Redinbaugh E M, Baum A, Tarbell S, Arnold R. End-of-life caregiving: what helps family caregivers cope?. J Palliat Med. 2003;6(6):901-9. [Rec#: 6308] INCLUDE: considered for evidence table. [pmid: 14733682].
Resnick B, Andrews C. End-of-life treatment preferences among older adults: a nurse practitioner initiated intervention. J Am Acad Nurse Pract. 2002;14(11):517-22. [Rec#: 6369] INCLUDE: considered for evidence table. [pmid: 12479154].
Reynolds K, Henderson M, Schulman A, Hanson L C. Needs of the dying in nursing homes. J Palliat Med. 2002;5(6):895-901. [Rec#: 6379] INCLUDE: considered for evidence table. [pmid: 12685536].
Riegel B, Carlson B, Kopp Z, LePetri B, Glaser D, Unger A. Effect of a standardized nurse case-management telephone intervention on resource use in patients with chronic heart failure. Arch Intern Med 2002;162(6):705–12. Comment in: Arch Intern Med. Oct 14. 2002;162(18):2142-3. author reply 2143. PMID: 12374530. [Rec#: 34682] INCLUDE: considered for evidence table.
Ringdal G I, Jordhoy M S, Kaasa S. Family satisfaction with end-of-life care for cancer patients in a cluster randomized trial. J Pain Symptom Manage. 2002;24(1):53-63. [Rec#: 6433] INCLUDE: considered for evidence table. [pmid: 12183095].
Ringdal G I, Ringdal K, Jordhoy M S, Ahlner-Elmqvist M, Jannert M, Kaasa S. Health-related quality of life (HRQOL) in family members of cancer victims: results from a longitudinal intervention study in Norway and Sweden. Palliat Med. 2004;18(2):108-20. [Rec#: 6437] INCLUDE: considered for evidence table. [pmid: 15046407].
Roberts J A, Brown D, Elkins T, Larson D B. Factors influencing views of patients with gynecologic cancer about end-of-life decisions. Am J Obstet Gynecol. 97;176(1 Pt 1):166-72. [Rec#: 6456] INCLUDE: considered for evidence table.
Rogers A, Karlsen S, Addington-Hall J. ‘All the services were excellent. It is when the human element comes in that things go wrong’: dissatisfaction with hospital care in the last year of life. J Adv Nurs. 2000;31(4):768-74. [Rec#: 14826] INCLUDE: considered for evidence table. [pmid: 10759972].
Rogers J C, Holm M B, Burgio L D, Granieri E, Hsu C, Hardin J M, McDowell B J. Improving morning care routines of nursing home residents with dementia. J Am Geriatr Soc 99;47(9):1049–57. Comment in: J Am Geriatr Soc. Sep. 1999;47(9):1151-2. PMID: 10484262. [Rec#: 34752] INCLUDE: considered for evidence table.
Roglieri J L, Futterman R, McDonough K L, Malya G, Karwath K R, Bowman D, Skelly J, Warburton S W Jr. Disease management interventions to improve outcomes in congestive heart failure. Am J Manag Care. 97;3(12):1831-9. [Rec#: 50093] INCLUDE: considered for evidence table.
Rohrbaugh M J, Cranford J A, Shoham V, Nicklas J M, Sonnega J S, Coyne J C. Couples coping with congestive heart failure: role and gender differences in psychological distress. J Fam Psychol. 2002;16(1):3-13. [Rec#: 34761] INCLUDE: considered for evidence table. [pmid: 11915408].
Rokach A. Terminal illness and coping with loneliness. J Psychol. 2000;134(3):283-96. [Rec#: 6495] INCLUDE: considered for evidence table. [pmid: 10907706].
Rose J H, O'Toole E E, Dawson N V, Thomas C, Connors A F Jr, Wenger N, Phillips R S, Hamel M B, Reding D T, Cohen H J, Lynn J. Generalists and oncologists show similar care practices and outcomes for hospitalized late-stage cancer patients. SUPPORT Investigators Study to Understand Prognoses and Preferences for Outcomes and Risks for Treatment. Med Care. 2000;38(11):1103-18. [Rec#: 6506] INCLUDE: considered for evidence table. [pmid: 11078051].
Rosenfeld B, Breitbart W, McDonald M V, Passik S D, Thaler H, Portenoy R K. Pain in ambulatory AIDS patients. II: Impact of pain on psychological functioning and quality of life. Pain. 96;68(23):323-8. [Rec#: 50708] INCLUDE: considered for evidence table.
Rothenbacher D, Lutz M P, Porzsolt F. Treatment decisions in palliative cancer care: patients' preferences for involvement and doctors' knowledge about it. Eur J Cancer 97;33(8):1184–9. Comment in: Eur J Cancer. Jul. 1997;33(8):1169-70. PMID: 9301436. [Rec#: 6543] INCLUDE: considered for evidence table.
Rovner B W, Steele C D, Shmuely Y, Folstein M F. A randomized trial of dementia care in nursing homes. J Am Geriatr Soc 96;44(1):7–13. Comment in: J Am Geriatr Soc. 1996 Jan;44(1):91–2. PMID: 8537599. Comment in: J Am Geriatr Soc. Oct. 1996;44(10):1277-8. PMID: 8856018. [Rec#: 34801] INCLUDE: considered for evidence table.
Rubin S M, Strull W M, Fialkow M F, Weiss S J, Lo B. Increasing the completion of the durable power of attorney for health care. A randomized, controlled trial. JAMA. 94;271(3):209-12. [Rec#: 50913] INCLUDE: considered for evidence table.
Rumsfeld J S, Havranek E, Masoudi F A, Peterson E D, Jones P, Tooley J F, Krumholz H M, Spertus J A. Cardiovascular Outcomes Research Consortium. Depressive symptoms are the strongest predictors of short-term declines in health status in patients with heart failure. J Am Coll Cardiol. 2003;42(10):1811-7. [Rec#: 34822] INCLUDE: considered for evidence table. [pmid: 14642693].
Rutecki G W, Rodriguez L, Cugino A, Jarjoura D, Hastings F, Whittier F C. End of life issues in ESRD. A study of three decision variables that affect patient attitudes. ASAIO J. 94;40(3):M798-802. [Rec#: 6600] INCLUDE: considered for evidence table.
Sahlberg-Blom E, Ternestedt B M, Johansson J E. Is good ‘quality of life’ possible at the end of life? An explorative study of the experiences of a group of cancer patients in two different care cultures. J Clin Nurs. 2001;10(4):550-62. [Rec#: 6629] INCLUDE: considered for evidence table. [pmid: 11822503].
Santa-Emma P H, Roach R, Gill M A, Spayde P, Taylor R M. Development and implementation of an inpatient acute palliative care service. Journal of Palliative Medicine. 2002;5(1):93-100. [Rec#: 50717] INCLUDE: considered for evidence table. [pmid: 11839231].
Sapir R, Catane R, Kaufman B, Isacson R, Segal A, Wein S, Cherny N I. Cancer patient expectations of and communication with oncologists and oncology nurses: the experience of an integrated oncology and palliative care service. Support Care Cancer 2000;8(6):458–63. Comment in: Support Care Cancer. Nov. 2000;8(6):437-8. PMID: 11094986. [Rec#: 6690] INCLUDE: considered for evidence table.
Sarna L. Effectiveness of structured nursing assessment of symptom distress in advanced lung cancer. Oncol Nurs Forum. 98;25(6):1041-8. [Rec#: 34893] INCLUDE: considered for evidence table. [pmid: 9679262].
Sarna L. Women with lung cancer: impact on quality of life. Qual Life Res. 93;2(1):13-22. [Rec#: 34896] INCLUDE: considered for evidence table. [pmid: 8387854].
Schiff G D, Fung S, Speroff T, McNutt R A. Decompensated heart failure: symptoms, patterns of onset, and contributing factors. Am J Med 2003;114(8):625–30. Comment in: Am J Med. Jun 1. 2003;114(8):695-6. PMID: 12798459. [Rec#: 34959] INCLUDE: considered for evidence table.
Schneiderman L J, Pearlman R A, Kaplan R M, Anderson J P, Rosenberg E M. Relationship of general advance directive instructions to specific life-sustaining treatment preferences in patients with serious illness. Arch Intern Med. 92;152(10):2114-22. [Rec#: 6779] INCLUDE: considered for evidence table.
Schneiderman L J, Gilmer T, Teetzel H D. Impact of ethics consultations in the intensive care setting: a randomized, controlled trial. Critical Care Medicine. 2000;28(12):3920-4. [Rec#: 50723] INCLUDE: considered for evidence table. [pmid: 11153636].
Schneiderman L J, Gilmer T, Teetzel H D, Dugan D O, Blustein J, Cranford R, Briggs K B, Komatsu G I, Goodman-Crews P, Cohn F, Young E W. Effect of ethics consultations on nonbeneficial life-sustaining treatments in the intensive care setting: a randomized controlled trial. JAMA. 2003;290(9):1166-72. [Rec#: 50724] INCLUDE: considered for evidence table. [pmid: 12952998].
Schofield P, Payne S. A pilot study into the use of a multisensory environment (Snoezelen) within a palliative day-care setting. Int J Palliat Nurs 2003;9(3):124–30. Erratum in: Int J Palliat Nurs. Apr. 2003;9(4):178. [Rec#: 6786] INCLUDE: considered for evidence table.
Schulz R, Beach S R, Lind B, Martire L M, Zdaniuk B, Hirsch C, Jackson S, Burton L. Involvement in caregiving and adjustment to death of a spouse: findings from the caregiver health effects study. JAMA. 2001;285(24):3123-9. [Rec#: 6820] INCLUDE: considered for evidence table. [pmid: 11427141].
Schulz R, Mendelsohn A B, Haley W E, Mahoney D, Allen R S, Zhang S, Thompson L, Belle S H. Resources for Enhancing Alzheimer's Caregiver Health Investigators. End-of-life care and the effects of bereavement on family caregivers of persons with dementia. N Engl J Med 2003;349(20):1936–42. Comment in: N Engl J Med. 2003 Nov 13;349(20):1891–2. PMID: 14614164. Comment in: N Engl J Med. Feb 12. 2004;350(7):733-4. author reply 733–4. PMID: 14960754. [Rec#: 6823] INCLUDE: considered for evidence table.
Schwartz C E, Mazor K, Rogers J, Ma Y, Reed G. Validation of a new measure of concept of a good death. J Palliat Med. 2003;6(4):575-84. [Rec#: 6841] INCLUDE: considered for evidence table. [pmid: 14516499].
Schwartz C E, Wheeler H B, Hammes B, Basque N, Edmunds J, Reed G, Ma Y, Li L, Tabloski P, Yanko J. UMass End-of-Life Working Group. Early intervention in planning end-of-life care with ambulatory geriatric patients: results of a pilot trial. Arch Intern Med. 2002;162(14):1611-8. [Rec#: 6842] INCLUDE: considered for evidence table. [pmid: 12123405].
Schwarz K A, Dunphy G. An examination of perceived stress in family caregivers of older adults with heart failure. Exp Aging Res. 2003;29(2):221-35. [Rec#: 35004] INCLUDE: considered for evidence table. [pmid: 12623730].
Scott G. A study of family carers of people with a life-threatening illness. 2: Implications of the needs assessment. Int J Palliat Nurs. 2001;7(7):323-30. [Rec#: 6864] INCLUDE: considered for evidence table. [pmid: 11951400].
Scott H R, McMillan D C, Brown D J, Forrest L M, McArdle C S, Milroy R. A prospective study of the impact of weight loss and the systemic inflammatory response on quality of life in patients with inoperable non-small cell lung cancer. Lung Cancer. 2003;40(3):295-9. [Rec#: 35010] INCLUDE: considered for evidence table. [pmid: 12781428].
Seale C, Addington-Hall J, McCarthy M. Awareness of dying: prevalence, causes and consequences. Soc Sci Med. 97;45(3):477-84. [Rec#: 6876] INCLUDE: considered for evidence table. [pmid: 9232741].
Seale C. Communication and awareness about death: a study of a random sample of dying people. Soc Sci Med. 91;32(8):943-52. [Rec#: 15124] INCLUDE: considered for evidence table. [pmid: 2031210].
Seamark D A, Thorne C P, Lawrence C, Gray D J. Appropriate place of death for cancer patients: views of general practitioners and hospital doctors. Br J Gen Pract 95;45(396):359–63. Comment in: Br J Gen Pract. Nov. 1995;45(400):630-1. PMID: 8554847. [Rec#: 15133] INCLUDE: considered for evidence table.
Seamark D A, Williams S, Hall M, Lawrence C J, Gilbert J. Dying from cancer in community hospitals or a hospice: closest lay carers' perceptions. Br J Gen Pract. 98;48(431):1317-21. [Rec#: 15134] INCLUDE: considered for evidence table.
Sela R A, Bruera E, Conner-spady B, Cumming C, Walker C. Sensory and affective dimensions of advanced cancer pain. Psychooncology. 2002;11(1):23-34. [Rec#: 6899] INCLUDE: considered for evidence table. [pmid: 11835590].
Selwyn P A, Rivard M, Kappell D, Goeren B, LaFosse H, Schwartz C, Caraballo R, Luciano D, Post L F. Palliative care for AIDS at a large urban teaching hospital: program description and preliminary outcomes. J Palliat Med. 2003;6(3):461-74. [Rec#: 6907] INCLUDE: considered for evidence table. [pmid: 14509496].
Seward E, Greig E, Preston S, Harris R A, Borrill Z, Wardle T D, Burnham R, Driscoll P, Harrison B D, Lowe D C, Pearson M G. A confidential study of deaths after emergency medical admission: issues relating to quality of care. Clinical Medicine. 2003;3(5):425-34. [Rec#: 50730] INCLUDE: considered for evidence table. [pmid: 14601941].
Seymour J, Ingleton C, Payne S, Beddow V. Specialist palliative care: patients' experiences. J Adv Nurs. 2003;44(1):24-33. [Rec#: 15175] INCLUDE: considered for evidence table. [pmid: 12956666].
Seymour J. Technology and “natural death”: a study of older people. Z Gerontol Geriatr. 2003;36(5):339-46. [Rec#: 6934] INCLUDE: considered for evidence table. [pmid: 14579060].
Sherr L, Hedge B, Steinhart K, Davey T, Petrack J. Unique patterns of bereavement in HIV: implications for counselling. Genitourin Med. 92;68(6):378-81. [Rec#: 7001] INCLUDE: considered for evidence table. [pmid: 1487258].
Sikkema K J, Kalichman S C, Hoffmann R, Koob J J, Kelly J A, Heckman T G. Coping strategies and emotional wellbeing among HIV-infected men and women experiencing AIDS-related bereavement. AIDS Care. 2000;12(5):613-24. [Rec#: 7067] INCLUDE: considered for evidence table. [pmid: 11218547].
Silveira M J, DiPiero A, Gerrity M S, Feudtner C. Patients' knowledge of options at the end of life: ignorance in the face of death. JAMA. 2000;284(19):2483-2488. [Rec#: 50737] INCLUDE: considered for evidence table. [pmid: 11074778].
Silvestri G A, Knittig S, Zoller J S, Nietert P J. Importance of faith on medical decisions regarding cancer care. J Clin Oncol. 2003;21(7):1379-82. [Rec#: 35151] INCLUDE: considered for evidence table. [pmid: 12663730].
Simmons S F, Ferrell B A, Schnelle J F. Effects of a controlled exercise trial on pain in nursing home residents. Clin J Pain. 2002;18(6):380-5. [Rec#: 7089] INCLUDE: considered for evidence table. [pmid: 12441832].
Singer P A, Martin D K, Lavery J V, Thiel E C, Kelner M, Mendelssohn D C. Reconceptualizing advance care planning from the patient's perspective. Arch Intern Med. 98;158(8):879-84. [Rec#: 7109] INCLUDE: considered for evidence table. [pmid: 9570174].
Sittl R, Griessinger N, Likar R. Analgesic efficacy and tolerability of transdermal buprenorphine in patients with inadequately controlled chronic pain related to cancer and other disorders: a multicenter, randomized, double-blind, placebo-controlled trial. Clinical Therapeutics. 2003;25(1):150-68. [Rec#: 50740] INCLUDE: considered for evidence table. [pmid: 12637117].
Smedira N G, Evans B H, Grais L S, Cohen N H, Lo B, Cooke M, Schecter W P, Fink C, Epstein-Jaffe E, May C, et al. Withholding and withdrawal of life support from the critically ill. N Engl J Med 90;322(5):309–15. Comment in: N Engl J Med. Jun 28. 1990;322(26):1891-2. PMID: 2348849. [Rec#: 43148] INCLUDE: considered for evidence table.
Smeenk F W, de Witte L P, Nooyen I W, Crebolder H F. Effects of transmural care on coordination and continuity of care. Patient Educ Couns. 2000;41(1):73-81. [Rec#: 7154] INCLUDE: considered for evidence table. [pmid: 10900369].
Smeenk F W, de Witte L P, van Haastregt J C, Schipper R M, Biezemans H P, Crebolder H F. Transmural care of terminal cancer patients: effects on the quality of life of direct caregivers. Nurs Res. 98;47(3):129-36. [Rec#: 7156] INCLUDE: considered for evidence table.
Smeenk F W, de Witte L P, van Haastregt J C, Schipper R M, Biezemans H P, Crebolder H F. Transmural care. A new approach in the care for terminal cancer patients: its effects on re-hospitalization and quality of life. Patient Educ Couns. 98;35(3):189-99. [Rec#: 7155] INCLUDE: considered for evidence table.
Smeets P M, Beusmans G H, Weber W E. Prospective study of home morphine infusion in 62 terminally ill patients. J Pain Symptom Manage. 99;18(6):390-400. [Rec#: 7157] INCLUDE: considered for evidence table. [pmid: 10641464].
Smith C, Da Silva-Gane M, Chandna S, Warwicker P, Greenwood R, Farrington K. Choosing not to dialyse: evaluation of planned non-dialytic management in a cohort of patients with end-stage renal failure. Nephron Clin Pract 2003;95(2):c40–6. Comment in: Nephron Clin Pract. 2003;95(2):c37-9. PMID: 14610333. [Rec#: 7160] INCLUDE: considered for evidence table.
Smith D C, Maher M F. Achieving a healthy death: the dying person's attitudinal contributions. Hosp J. 93;9(1):21-32. [Rec#: 15341] INCLUDE: considered for evidence table. [pmid: 8406400].
Smith E L, Hann D M, Ahles T A, Furstenberg C T, Mitchell T A, Meyer L, Maurer L H, Rigas J, Hammond S. Dyspnea, anxiety, body consciousness, and quality of life in patients with lung cancer. J Pain Symptom Manage. 2001;21(4):323-9. [Rec#: 35213] INCLUDE: considered for evidence table. [pmid: 11312047].
Smith T J, Staats P S, Deer T, Stearns L J, Rauck R L, Boortz-Marx R L, Buchser E, Catala E, Bryce D A, Coyne P J, Pool G E. Implantable Drug Delivery Systems Study Group. Randomized clinical trial of an implantable drug delivery system compared with comprehensive medical management for refractory cancer pain: impact on pain, drug-related toxicity, and survival. Journal of Clinical Oncology. 2002;20(19):4040-9. [Rec#: 50745] INCLUDE: considered for evidence table. [pmid: 12351602].
Smucker W D, Ditto P H, Moore K A, Druley J A, Danks J H, Townsend A. Elderly outpatients respond favorably to a physician-initiated advance directive discussion. J Am Board Fam Pract. 93;6(5):473-82. [Rec#: 7190] INCLUDE: considered for evidence table.
Soden K, Vincent K, Craske S, Lucas C, Ashley S. A randomized controlled trial of aromatherapy massage in a hospice setting. Palliat Med. 2004;18(2):87-92. [Rec#: 7202] INCLUDE: considered for evidence table. [pmid: 15046404].
Somogyi-Zalud E, Zhong Z, Lynn J, Hamel M B. Elderly persons' last six months of life: findings from the Hospitalized Elderly Longitudinal Project. J Am Geriatr Soc. 2000;48(5 Suppl):S131-9. [Rec#: 7221] INCLUDE: considered for evidence table. [pmid: 10809466].
Somogyi-Zalud E, Zhong Z, Lynn J, Dawson N V, Hamel M B, Desbiens N A. Dying with acute respiratory failure or multiple organ system failure with sepsis. J Am Geriatr Soc. 2000;48(5 Suppl):S140-5. [Rec#: 7220] INCLUDE: considered for evidence table. [pmid: 10809467].
Soskis C W. End-of-life decisions in the home care setting. Soc Work Health Care. 97;25(12):107-16. [Rec#: 7238] INCLUDE: considered for evidence table. [pmid: 9313307].
Sprung C L, Cohen S L, Sjokvist P, Baras M, Bulow H H, Hovilehto S, Ledoux D, Lippert A, Maia P, Phelan D, Schobersberger W, Wennberg E, Woodcock T. Ethicus Study Group. End-of-life practices in European intensive care units: the Ethicus Study. JAMA 2003;290(6):790–7. Comment in: JAMA. 2003 Aug 13;290(6):820–2. PMID: 12915438. Comment in: JAMA. 2003 Dec 10; 290(22):2938–9; author reply 2939–40. PMID: 14665649. Comment in: JAMA. Dec 10. 2003;290(22):2939. author reply 2939–40. PMID: 14665650. [Rec#: 7283] INCLUDE: considered for evidence table.
Stalfelt A M, Brodin H, Pettersson S, Eklof A. The final phase in acute myeloid leukaemia (AML). A study on bleeding, infection and pain. Leuk Res. 2003;27(6):481-8. [Rec#: 7296] INCLUDE: considered for evidence table. [pmid: 12648506].
Steel K, Ljunggren G, Topinkova E, Morris J N, Vitale C, Parzuchowski J, Nonemaker S, Frijters D H, Rabinowitz T, Murphy K M, Ribbe M W, Fries B E. The RAI-PC: an assessment instrument for palliative care in all settings. Am J Hosp Palliat Care. 2003;20(3):211-9. [Rec#: 7316] INCLUDE: considered for evidence table. [pmid: 12785043].
Steele R G, Fitch M I. Coping strategies of family caregivers of home hospice patients with cancer. Oncol Nurs Forum. 96;23(6):955-60. [Rec#: 7320] INCLUDE: considered for evidence table. [pmid: 8829165].
Stein W M, Miech R P. Cancer pain in the elderly hospice patient. J Pain Symptom Manage. 93;8(7):474-82. [Rec#: 7334] INCLUDE: considered for evidence table. [pmid: 7963774].
Steinberg M A, Cartwright C M, MacDonald S M, Najman J M, Williams G M. Self-determination in terminal care. A comparison of GP and community members' responses. Aust Fam Physician. 97;26(6):703-7. [Rec#: 7337] INCLUDE: considered for evidence table.
Steinhauser K E, Christakis N A, Clipp E C, McNeilly M, Grambow S, Parker J, Tulsky J A. Preparing for the end of life: preferences of patients, families, physicians, and other care providers. J Pain Symptom Manage. 2001;22(3):727-37. [Rec#: 7340] INCLUDE: considered for evidence table. [pmid: 11532586].
Steinhauser K E, Christakis N A, Clipp E C, McNeilly M, McIntyre L, Tulsky J A. Factors considered important at the end of life by patients, family, physicians, and other care providers. JAMA. 2000;284(19):2476-82. [Rec#: 50885] INCLUDE: considered for evidence table. [pmid: 11074777].
Stephens R J, Hopwood P, Girling D J, Machin D. Randomized trials with quality of life endpoints: are doctors' ratings of patients' physical symptoms interchangeable with patients' self-ratings?. Qual Life Res. 97;6(3):225-36. [Rec#: 15541] INCLUDE: considered for evidence table.
Stephenson N L, Weinrich S P, Tavakoli A S. The effects of foot reflexology on anxiety and pain in patients with breast and lung cancer. Oncol Nurs Forum 2000;27(1):67–72. Comment in: Oncol Nurs Forum. Apr. 2001;28(3):445-6. PMID: 11338752. [Rec#: 35336] INCLUDE: considered for evidence table.
Steptoe A, Mohabir A, Mahon N G, McKenna W J. Health related quality of life and psychological wellbeing in patients with dilated cardiomyopathy. Heart. 2000;83(6):645-50. [Rec#: 35337] INCLUDE: considered for evidence table. [pmid: 10814621]. [pmcid: 1760850].
Stern S G, Orlowski J P. DNR or CPR--the choice is ours. Crit Care Med. 92;20(9):1263-72. [Rec#: 15547] INCLUDE: considered for evidence table. [pmid: 1521441].
Stetz K M, Hanson W K. Alterations in perceptions of caregiving demands in advanced cancer during and after the experience. Hosp J. 92;8(3):21-34. [Rec#: 7358] INCLUDE: considered for evidence table. [pmid: 1294448].
Stewart S, Horowitz J D. Detecting early clinical deterioration in chronic heart failure patients post-acute hospitalisation-a critical component of multidisciplinary, home-based intervention?. Eur J Heart Fail. 2002;4(3):345-51. [Rec#: 50098] INCLUDE: considered for evidence table. [pmid: 12034161].
Stewart S, Marley J E, Horowitz J D. Effects of a multidisciplinary, home-based intervention on unplanned readmissions and survival among patients with chronic congestive heart failure: a randomised controlled study. Lancet. 99;354(9184):1077-83. [Rec#: 35361] INCLUDE: considered for evidence table.
Stewart S, Pearson S, Horowitz J D. Effects of a home-based intervention among patients with congestive heart failure discharged from acute hospital care. Arch Intern Med. 98;158(10):1067-72. [Rec#: 50100] INCLUDE: considered for evidence table.
Stillman M J, Syrjala K L. Differences in physician access patterns to hospice care. J Pain Symptom Manage. 99;17(3):157-63. [Rec#: 7376] INCLUDE: considered for evidence table. [pmid: 10098358].
Stirling L C, Kurowska A, Tookman A. The use of phenobarbitone in the management of agitation and seizures at the end of life. J Pain Symptom Manage 99;17(5):363–8. Comment in: J Pain Symptom Manage. Feb. 2000;19(2):80-1. PMID: 10766573. [Rec#: 7379] INCLUDE: considered for evidence table.
Stockelberg D, Lehtola P, Noren I. Palliative treatment at home for patients with haematological disorders. Support Care Cancer. 97;5(6):506-8. [Rec#: 7381] INCLUDE: considered for evidence table. [pmid: 9406366].
Stommel M, Given B A, Given C W. Depression and functional status as predictors of death among cancer patients. Cancer. 2002;94(10):2719-27. [Rec#: 43238] INCLUDE: considered for evidence table. [pmid: 12173342].
Straton J B, Wang N Y, Meoni L A, Ford D E, Klag M J, Casarett D, Gallo J J. Physical functioning, depression, and preferences for treatment at the end of life: the johns hopkins precursors study. J Am Geriatr Soc. 2004;52(4):577-82. [Rec#: 7406] INCLUDE: considered for evidence table. [pmid: 15066074].
Stromgren A S, Goldschmidt D, Groenvold M, Petersen M A, Jensen P T, Pedersen L, Hoermann L, Helleberg C, Sjogren P. Self-assessment in cancer patients referred to palliative care: a study of feasibility and symptom epidemiology. Cancer. 2002;94(2):512-20. [Rec#: 7414] INCLUDE: considered for evidence table. [pmid: 11900236].
Stuart B, D'Onofrio C N, Boatman S, Feigelman G. CHOICES: promoting early access to end-of-life care through home-based transition management. J Palliat Med. 2003;6(4):671-83. [Rec#: 7422] INCLUDE: considered for evidence table. [pmid: 14516514].
Sugarman J, Weinberger M, Samsa G. Factors associated with veterans' decisions about living wills. Arch Intern Med. 92;152(2):343-7. [Rec#: 7429] INCLUDE: considered for evidence table. [pmid: 1739364].
Sullivan M A, Muskin P R, Feldman S J, Haase E. Effects of religiosity on patients' perceptions of do-not-resuscitate status. Psychosomatics. 2004;45(2):119-28. [Rec#: 43261] INCLUDE: considered for evidence table. [pmid: 15016925].
Sulmasy D P, McIlvane J M. Patients' ratings of quality and satisfaction with care at the end of life. Arch Intern Med. 2002;162(18):2098-104. [Rec#: 7440] INCLUDE: considered for evidence table. [pmid: 12374518].
Sulmasy D P, Sood J R. Factors associated with the time nurses spend at the bedsides of seriously ill patients with poor prognoses. Med Care. 2003;41(4):458-66. [Rec#: 7442] INCLUDE: considered for evidence table. [pmid: 12665710].
Sulmasy D P, McIlvane J M, Pasley P M, Rahn M. A scale for measuring patient perceptions of the quality of end-of-life care and satisfaction with treatment: the reliability and validity of QUEST. J Pain Symptom Manage. 2002;23(6):458-70. [Rec#: 7441] INCLUDE: considered for evidence table. [pmid: 12067770].
Sulmasy D P, Terry P B, Weisman C S, Miller D J, Stallings R Y, Vettese M A, Haller K B. The accuracy of substituted judgments in patients with terminal diagnoses. Ann Intern Med 98;128(8):621–9. Comment in: Ann Intern Med. Dec 15. 1998;129(12):1082-3. PMID: 9867782. [Rec#: 7443] INCLUDE: considered for evidence table.
Sultzer D L, Gray K F, Gunay I, Wheatley M V, Mahler M E. Does behavioral improvement with haloperidol or trazodone treatment depend on psychosis or mood symptoms in patients with dementia?. J Am Geriatr Soc. 2001;49(10):1294-300. [Rec#: 35426] INCLUDE: considered for evidence table. [pmid: 11890487].
The SUPPORT Principal Investigators. A controlled trial to improve care for seriously ill hospitalized patients. The study to understand prognoses and preferences for outcomes and risks of treatments (SUPPORT). JAMA 95;274(20):1591–8. Comment in: JAMA. 1995 Nov 22–29;274(20):1634–6. PMID: 7474253. Comment in: JAMA. 1996 Apr 24;275(16):1227–8; author reply 1230–1. PMID: 8601945. Comment in: JAMA. Apr 24. 1996;275(16):1227. author reply 1230–1. PMID: 8601944. Comment in: JAMA. 199. [Rec#: 1440] INCLUDE: considered for evidence table.
Suri D N, Egleston B L, Brody J A, Rudberg M A. Nursing home resident use of care directives. J Gerontol A Biol Sci Med Sci. 99;54(5):M225-9. [Rec#: 7463] INCLUDE: considered for evidence table. [pmid: 10362004].
Syrett E, Taylor J. Non-pharmacological management of breathlessness: a collaborative nurse--physiotherapist approach. Int J Palliat Nurs. 2003;9(4):150-6. [Rec#: 15684] INCLUDE: considered for evidence table. [pmid: 12734451].
Talmi Y P, Roth Y, Waller A, Chesnin V, Adunski A, Lander M I, Kronenberg J. Care of the terminal head and neck cancer patient in the hospice setting. Laryngoscope. 95;105(3 Pt 1):315-8. [Rec#: 7523] INCLUDE: considered for evidence table.
Tanaka K, Akechi T, Okuyama T, Nishiwaki Y, Uchitomi Y. Factors correlated with dyspnea in advanced lung cancer patients: organic causes and what else?. J Pain Symptom Manage. 2002;23(6):490-500. [Rec#: 35493] INCLUDE: considered for evidence table. [pmid: 12067773].
Tanaka K, Akechi T, Okuyama T, Nishiwaki Y, Uchitomi Y. Impact of dyspnea, pain, and fatigue on daily life activities in ambulatory patients with advanced lung cancer. J Pain Symptom Manage. 2002;23(5):417-23. [Rec#: 35494] INCLUDE: considered for evidence table. [pmid: 12007759].
Tang S T, Mccorkle R. Determinants of congruence between the preferred and actual place of death for terminally ill cancer patients. J Palliat Care. 2003;19(4):230-7. [Rec#: 7547] INCLUDE: considered for evidence table. [pmid: 14959592].
Tang S T. Determinants of hospice home care use among terminally ill cancer patients. Nurs Res. 2003;52(4):217-25. [Rec#: 7544] INCLUDE: considered for evidence table. [pmid: 12867778].
Tang W R, Aaronson L S, Forbes S A. Quality of life in hospice patients with terminal illness. West J Nurs Res. 2004;26(1):113-28. [Rec#: 7548] INCLUDE: considered for evidence table. [pmid: 14984656].
Tanvetyanon T, Leighton J C. Life-sustaining treatments in patients who died of chronic congestive heart failure compared with metastatic cancer. Crit Care Med 2003;31(1):60–4. Comment in: Crit Care. Apr. 2003;7(2):111-3. PMID: 12720553. [Rec#: 43305] INCLUDE: considered for evidence table.
Tardy B, Venet C, Zeni F, Berthet O, Viallon A, Lemaire F, Bertrand J C. Death of terminally ill patients on a stretcher in the emergency department: a French speciality?. Intensive Care Med. 2002;28(11):1625-8. [Rec#: 7553] INCLUDE: considered for evidence table. [pmid: 12415451].
Tarraza H M, Ellerkmann R M. A view from the family: years after a loved one has died of ovarian cancer. Obstet Gynecol. 99;93(1):38-40. [Rec#: 15739] INCLUDE: considered for evidence table. [pmid: 9916953].
Tchen N, Bedard P, Yi Q L, Klein M, Cella D, Eremenco S, Tannock I F. Quality of life and understanding of disease status among cancer patients of different ethnic origin. British Journal of Cancer. 2003;89(4):641-7. [Rec#: 50769] INCLUDE: considered for evidence table. [pmid: 12915871].
Temkin-Greener H, Mukamel D B. Predicting place of death in the program of all-inclusive care for the elderly (PACE): participant versus program characteristics. J Am Geriatr Soc. 2002;50(1):125-35. [Rec#: 7588] INCLUDE: considered for evidence table. [pmid: 12028257].
Temkin-Greener H, Meiners M R, Petty E A, Szydlowski J S. The use and cost of health services prior to death: a comparison of the Medicare-only and the Medicare-Medicaid elderly populations. Milbank Q. 92;70(4):679-701. [Rec#: 7587] INCLUDE: considered for evidence table.
Teno J, Lynn J, Wenger N, Phillips R S, Murphy D P, Connors A F Jr, Desbiens N, Fulkerson W, Bellamy P, Knaus W A. Advance directives for seriously ill hospitalized patients: effectiveness with the patient self-determination act and the SUPPORT intervention. SUPPORT Investigators. Study to Understand Prognoses and Preferences for Outcomes and Risks of Treatment. J Am Geriatr Soc 97;45(4):500–7. Comment in: J Am Geriatr Soc. Apr. 1997;45(4):519-20. PMID: 9100724. [Rec#: 43327] INCLUDE: considered for evidence table.
Teno J M, Branco K J, Mor V, Phillips C D, Hawes C, Morris J, Fries B E. Changes in advance care planning in nursing homes before and after the patient Self-Determination Act: report of a 10-state survey. J Am Geriatr Soc. 97;45(8):939-44. [Rec#: 43328] INCLUDE: considered for evidence table.
Teno J M, Clarridge B, Casey V, Edgman-Levitan S, Fowler J. Validation of Toolkit After-Death Bereaved Family Member Interview. J Pain Symptom Manage. 2001;22(3):752-8. [Rec#: 7592] INCLUDE: considered for evidence table. [pmid: 11532588].
Teno J M, Clarridge B R, Casey V, Welch L C, Wetle T, Shield R, Mor V. Family perspectives on end-of-life care at the last place of care. JAMA 2004;291(1):88–93. Comment in: JAMA. Mar 24. 2004;291(12):1445-6. author reply 1446. PMID: 15039410. [Rec#: 7593] INCLUDE: considered for evidence table.
Teno J M, Fisher E, Hamel M B, Wu A W, Murphy D J, Wenger N S, Lynn J, Harrell F E Jr. Decision-making and outcomes of prolonged ICU stays in seriously ill patients. J Am Geriatr Soc. 2000;48(5 Suppl):S70-4. [Rec#: 7594] INCLUDE: considered for evidence table. [pmid: 10809459].
Teno JM, Lynn J, Phillips RS, Murphy D, Youngner SJ, Bellamy P, Connors AF Jr, Desbiens NA, Fulkerson W, and Knaus WA. Do formal advance directives affect resuscitation decisions and the use of resources for seriously ill patients? SUPPORT Investigators. Study to Understand Prognoses and Preferences for Outcomes and Risks of Treatments. J Clin Ethics 94;5(1):23–30. Comment in: J Clin Ethics. 1994 Spring;5(1):55–6. PMID: 8003727. Comment in: J Clin Ethics. 1994 Spring;5(1):57–60. PMID: 8003728. Comment in: J Clin Ethics. 1994 Spring;5(1):60–1. PMID: 8003729. [Rec#: 43330] INCLUDE: considered for evidence table
Teno J M, Licks S, Lynn J, Wenger N, Connors A F Jr, Phillips R S, O'Connor M A, Murphy D P, Fulkerson W J, Desbiens N, Knaus W A. Do advance directives provide instructions that direct care? SUPPORT Investigators. Study to Understand Prognoses and Preferences for Outcomes and Risks of Treatment. Journal of the American Geriatrics Society. 97;45(4):508-12. [Rec#: 50772] INCLUDE: considered for evidence table.
Teno J M, Stevens M, Spernak S, Lynn J. Role of written advance directives in decision making: insights from qualitative and quantitative data. Journal of General Internal Medicine. 98;13(7):439-46. [Rec#: 50776] INCLUDE: considered for evidence table.
The A M, Hak T, Koeter G, van der Wal G. Collusion in doctor-patient communication about imminent death: an ethnographic study. West J Med. 2001;174(4):247-53. [Rec#: 7612] INCLUDE: considered for evidence table. [pmid: 11290678]. [pmcid: 1071348].
Thompsell A, Lovestone S. Out of sight out of mind? Support and information given to distant and near relatives of those with dementia. Int J Geriatr Psychiatry. 2002;17(9):804-7. [Rec#: 35581] INCLUDE: considered for evidence table. [pmid: 12221652].
Thompson E A, Reillly D. The homeopathic approach to symptom control in the cancer patient: a prospective observational study. Palliat Med. 2002;16(3):227-33. [Rec#: 7629] INCLUDE: considered for evidence table. [pmid: 12046999].
Tierney R M, Horton S M, Hannan T J, Tierney W M. Relationships between symptom relief, quality of life, and satisfaction with hospice care. Palliat Med. 98;12(5):333-44. [Rec#: 7661] INCLUDE: considered for evidence table. [pmid: 9924596].
Tierney W M, Dexter P R, Gramelspacher G P, Perkins A J, Zhou X H, Wolinsky F D. The effect of discussions about advance directives on patients' satisfaction with primary care. J Gen Intern Med 2001;16(1):32–40. Comment in: J Gen Intern Med. Jan. 2001;16(1):68-9. PMID: 11251753. [Rec#: 7662] INCLUDE: considered for evidence table.
Tilden V P, Tolle S W, Drach L L, Perrin N A. Out-of-Hospital Death: Advance Care Planning, Decedent Symptoms, and Caregiver Burden. J Am Geriatr Soc. 2004;52(4):532-9. [Rec#: 7664] INCLUDE: considered for evidence table. [pmid: 15066067].
Tilden V P, Tolle S W, Garland M J, Nelson C A. Decisions about life-sustaining treatment. Impact of physicians' behaviors on the family. Archives of Internal Medicine. 95;155(6):633-8. [Rec#: 50780] INCLUDE: considered for evidence table.
Tolle S W, Hickman S E, Tilden V P, Bubalo J S, Fromme E K. Trends in opioid use over time: 1997 to 1999. J Palliat Med. 2004;7(1):39-45. [Rec#: 7678] INCLUDE: considered for evidence table. [pmid: 15000781].
Tolle S W, Rosenfeld A G, Tilden V P, Park Y. Oregon's low in-hospital death rates: what determines where people die and satisfaction with decisions on place of death?. Ann Intern Med. 99;130(8):681-5. [Rec#: 15876] INCLUDE: considered for evidence table.
Tolle S W, Tilden V P, Hickman S E, Rosenfeld A G. Family reports of pain in dying hospitalized patients: a structured telephone survey. West J Med. 2000;172(6):374-7. [Rec#: 7680] INCLUDE: considered for evidence table. [pmid: 10854381]. [pmcid: 1070920].
Tolle S W, Tilden V P, Rosenfeld A G, Hickman S E. Family reports of barriers to optimal care of the dying. Nurs Res. 2000;49(6):310-7. [Rec#: 7681] INCLUDE: considered for evidence table. [pmid: 11093695].
Tong E, McGraw S A, Dobihal E, Baggish R, Cherlin E, Bradley E H. What is a good death? Minority and non-minority perspectives. J Palliat Care. 2003;19(3):168-75. [Rec#: 15884] INCLUDE: considered for evidence table. [pmid: 14606328].
Topp R, Tucker D, Weber C. Effect of a clinical case manager/clinical nurse specialist on patients hospitalized with congestive heart failure. Nurs Case Manag. 98;3(4):140-5. quiz 146–7, 182. [Rec#: 35631] INCLUDE: considered for evidence table.
Torelli G F, Campos A C, Meguid M M. Use of TPN in terminally ill cancer patients. Nutrition. 99;15(9):665-7. [Rec#: 7700] INCLUDE: considered for evidence table. [pmid: 10467610].
Townsend J, Frank A O, Fermont D, Dyer S, Karran O, Walgrove A, Piper M. Terminal cancer care and patients' preference for place of death: a prospective study. BMJ 90;301(6749):415–7. Comment in: BMJ. Jun 26. 1993;306(6894):1754. PMID: 8343651. [Rec#: 15899] INCLUDE: considered for evidence table.
Trail M, Nelson N D, Van J N, Appel S H, Lai E C. A study comparing patients with amyotrophic lateral sclerosis and their caregivers on measures of quality of life, depression, and their attitudes toward treatment options. J Neurol Sci. 2003;209(12):79-85. [Rec#: 7711] INCLUDE: considered for evidence table. [pmid: 12686407].
Tranmer J E, Heyland D, Dudgeon D, Groll D, Squires-Graham M, Coulson K. Measuring the symptom experience of seriously ill cancer and noncancer hospitalized patients near the end of life with the memorial symptom assessment scale. J Pain Symptom Manage. 2003;25(5):420-9. [Rec#: 7716] INCLUDE: considered for evidence table. [pmid: 12727039].
Travis S S, Bernard M A, McAuley W J, Thornton M, Kole T. Development of the family caregiver medication administration hassles scale. Gerontologist. 2003;43(3):360-8. [Rec#: 35655] INCLUDE: considered for evidence table. [pmid: 12810899].
Trojano L, Antonelli Incalzi R, Acanfora D, Picone C, Mecocci P, Rengo F. Congestive Heart Failure Italian Study Investigators. Cognitive impairment: a key feature of congestive heart failure in the elderly. J Neurol. 2003;250(12):1456-63. [Rec#: 35669] INCLUDE: considered for evidence table. [pmid: 14673579].
Trollor J. Cancer inpatients morphine usage: a new England area survey. Aust J Rural Health. 2003;11(4):163-8. [Rec#: 7729] INCLUDE: considered for evidence table. [pmid: 14641227].
Tschann J M, Kaufman S R, Micco G P. Family involvement in end-of-life hospital care. J Am Geriatr Soc. 2003;51(6):835-40. [Rec#: 7742] INCLUDE: considered for evidence table. [pmid: 12757572].
Tulsky J A, Chesney M A, Lo B. See one, do one, teach one? House staff experience discussing do-not-resuscitate orders. Arch Intern Med. 96;156(12):1285-9. [Rec#: 15939] INCLUDE: considered for evidence table. [pmid: 8651836].
Turhal N S, Erdal S, Karacay S. Efficacy of treatment to relieve mucositis-induced discomfort. Support Care Cancer. 2000;8(1):55-8. [Rec#: 7760] INCLUDE: considered for evidence table. [pmid: 10650899].
Uhlmann R F, Pearlman R A. Perceived quality of life and preferences for life-sustaining treatment in older adults. Arch Intern Med. 91;151(3):495-7. [Rec#: 7791] INCLUDE: considered for evidence table. [pmid: 2001131].
Vainio A, Auvinen A. Prevalence of symptoms among patients with advanced cancer: an international collaborative study. Symptom Prevalence Group. J Pain Symptom Manage. 96;12(1):3-10. [Rec#: 16012] INCLUDE: considered for evidence table.
Valdimarsdottir U, Helgason A R, Furst C J, Adolfsson J, Steineck G. The unrecognised cost of cancer patients' unrelieved symptoms:a nationwide follow-up of their surviving partners. Br J Cancer. 2002;86(10):1540-5. [Rec#: 7811] INCLUDE: considered for evidence table. [pmid: 12085201].
van der Steen J T, Ooms M E, van der Wal G, Ribbe M W. Pneumonia: the demented patient's best friend? Discomfort after starting or withholding antibiotic treatment. J Am Geriatr Soc. 2002;50(10):1681-8. [Rec#: 7835] INCLUDE: considered for evidence table. [pmid: 12366622].
Vandecreek L, Frankowski D. Barriers that predict resistance to completing a living will. Death Stud. 96;20(1):73-82. [Rec#: 7860] INCLUDE: considered for evidence table. [pmid: 10160533].
Ventafridda V, De Conno F, Ripamonti C, Gamba A, Tamburini M. Quality-of-life assessment during a palliative care programme. Ann Oncol 90;1(6):415–20. Comment in: Ann Oncol. 1990 Nov;1(6):396–8. PMID: 1707296. Comment in: Ann Oncol. Oct. 1991;2(9):693-4. PMID: 1720657. [Rec#: 7879] INCLUDE: considered for evidence table.
Ventafridda V, Ripamonti C, De Conno F, Tamburini M, and Cassileth BR. Symptom prevalence and control during cancer patients' last days of life. J Palliat Care 90;6(3):7–11. Comment in: J Palliat Care. 1991 Summer;7(2):50–1. PMID: 1714500. [Rec#: 7881] INCLUDE: considered for evidence table
Vigano A, Bruera E, Suarez-Almazor M E. Age, pain intensity, and opioid dose in patients with advanced cancer. Cancer. 98;83(6):1244-50. [Rec#: 50796] INCLUDE: considered for evidence table. [pmid: 9740092].
Vincent I, D'Herouville D, Moulin P, Bugler C, Fraval J, Mallet D, Salamagne M H, Vilde J L, Jodelet D, Leport C. Modalities of palliative care in hospitalized patients with advanced AIDS. AIDS Care. 2000;12(2):211-9. [Rec#: 7911] INCLUDE: considered for evidence table. [pmid: 10827862].
Virik K, Glare P. Profile and evaluation of a palliative medicine consultation service within a tertiary teaching hospital in Sydney, Australia. J Pain Symptom Manage. 2002;23(1):17-25. [Rec#: 7921] INCLUDE: considered for evidence table. [pmid: 11779664].
Virmani J, Schneiderman L J, Kaplan R M. Relationship of advance directives to physician-patient communication. Arch Intern Med. 94;154(8):909-13. [Rec#: 7922] INCLUDE: considered for evidence table. [pmid: 8154954].
Visapaa J. Significant changes in the terminal care of aged patients in the long-term care in Helsinki. Scand J Soc Med. 98;26(1):53-5. [Rec#: 7927] INCLUDE: considered for evidence table. [pmid: 9526764].
Volicer L, Hurley A C, Blasi Z V. Characteristics of dementia end-of-life care across care settings. Am J Hosp Palliat Care. 2003;20(3):191-200. [Rec#: 7948] INCLUDE: considered for evidence table. [pmid: 12785040].
Volicer L, Hurley A C, Blasi Z V. Scales for evaluation of End-of-Life Care in Dementia. Alzheimer Dis Assoc Disord. 2001;15(4):194-200. [Rec#: 7949] INCLUDE: considered for evidence table. [pmid: 11723370].
Voltz R, Akabayashi A, Reese C, Ohi G, Sass H M. End-of-life decisions and advance directives in palliative care: a cross-cultural survey of patients and health-care professionals. J Pain Symptom Manage. 98;16(3):153-62. [Rec#: 7952] INCLUDE: considered for evidence table.
Wakefield M, Ashby M. Attitudes of surviving relatives to terminal care in South Australia. J Pain Symptom Manage. 93;8(8):529-38. [Rec#: 16145] INCLUDE: considered for evidence table. [pmid: 7963778].
Walker R J, Pomeroy E C. The impact of anticipatory grief on caregivers of persons with Alzheimer's disease. Home Health Care Serv Q. 97;16(12):55-76. [Rec#: 7988] INCLUDE: considered for evidence table. [pmid: 10173050].
Wallace S K, Ewer M S, Price K J, Feeley T W. Outcome and cost implications of cardiopulmonary resuscitation in the medical intensive care unit of a comprehensive cancer center. Support Care Cancer. 2002;10(5):425-9. [Rec#: 43541] INCLUDE: considered for evidence table. [pmid: 12136227].
Walsh D, Nelson K A. Communication of a cancer diagnosis: patients' perceptions of when they were first told they had cancer. Am J Hosp Palliat Care. 2003;20(1):52-6. [Rec#: 8000] INCLUDE: considered for evidence table. [pmid: 12568437].
Walsh D, Donnelly S, Rybicki L. The symptoms of advanced cancer: relationship to age, gender, and performance status in 1,000 patients. Support Care Cancer. 2000;8(3):175-9. [Rec#: 7999] INCLUDE: considered for evidence table. [pmid: 10789956].
Walsh S M, Schmidt L A. Telephone support for caregivers of patients with cancer. Cancer Nurs. 2003;26(6):448-53. [Rec#: 8006] INCLUDE: considered for evidence table. [pmid: 15022976].
Ward S E, Gordon D B. Patient satisfaction and pain severity as outcomes in pain management: a longitudinal view of one setting's experience. J Pain Symptom Manage. 96;11(4):242-51. [Rec#: 16192] INCLUDE: considered for evidence table.
Ward S E, Berry P E, Misiewicz H. Concerns about analgesics among patients and family caregivers in a hospice setting. Res Nurs Health. 96;19(3):205-11. [Rec#: 8031] INCLUDE: considered for evidence table. [pmid: 8628909].
Ward S E, Goldberg N, Miller-McCauley V, Mueller C, Nolan A, Pawlik-Plank D, Robbins A, Stormoen D, Weissman D E. Patient-related barriers to management of cancer pain. Pain. 93;52(3):319-24. [Rec#: 8032] INCLUDE: considered for evidence table. [pmid: 7681557].
Warden V, Hurley A C, Volicer L. Development and psychometric evaluation of the Pain Assessment in Advanced Dementia (PAINAD) scale. J Am Med Dir Assoc 2003;4(1):9–15. Comment in: J Am Med Dir Assoc. Jan-Feb. 2003;4(1):50-1. PMID: 12807599. [Rec#: 35921] INCLUDE: considered for evidence table.
Warren S C, Emmett M K, Zinn C, Warren L M. Dying in a West Virginia acute care hospital: what is it like?. W V Med J. 2002;98(3):110-3. [Rec#: 8041] INCLUDE: considered for evidence table. [pmid: 12099097].
Watanabe S, Belzile M, Kuehn N, Hanson J, Bruera E. Capsules and suppositories of methadone for patients on high-dose opioids for cancer pain: clinical and economic considerations. Cancer Treatment Reviews. 96;22(Suppl A):131-6. [Rec#: 50811] INCLUDE: considered for evidence table.
Waters C M. End-of-life care directives among African Americans: lessons learned--a need for community-centered discussion and education. J Community Health Nurs. 2000;17(1):25-37. [Rec#: 8055] INCLUDE: considered for evidence table. [pmid: 10778027].
Webb M, Moody L E, Mason L A. Dyspnea assessment and management in hospice patients with pulmonary disorders. Am J Hosp Palliat Care. 2000;17(4):259-64. [Rec#: 8078] INCLUDE: considered for evidence table. [pmid: 11883802].
Weeks J C, Cook E F, O'Day S J, Peterson L M, Wenger N, Reding D, Harrell F E, Kussin P, Dawson N V, Connors A F Jr, Lynn J, Phillips R S. Relationship between cancer patients' predictions of prognosis and their treatment preferences. JAMA 98;279(21):1709–14. Comment in: JAMA. 1998 Jun 3;279(21):1746–8. PMID: 9624031. Comment in: JAMA. 1998 Oct 28;280(16):1403–4. PMID: 9800998. Comment in: JAMA. 1998 Oct 28;280(16):1403; author reply 1404. PMID: 9800997. Erratum in: JAMA. Jan 12. 2000;283(2):203. [Rec#: 8089] INCLUDE: considered for evidence table.
Weiner P, Waizman J, Magadle R, Berar-Yanay N, Pelled B. The effect of specific inspiratory muscle training on the sensation of dyspnea and exercise tolerance in patients with congestive heart failure. Clin Cardiol. 99;22(11):727-32. [Rec#: 35953] INCLUDE: considered for evidence table.
Weisbord S D, Carmody S S, Bruns F J, Rotondi A J, Cohen L M, Zeidel M L, Arnold R M. Symptom burden, quality of life, advance care planning and the potential value of palliative care in severely ill haemodialysis patients. Nephrol Dial Transplant 2003;18(7):1345–52. Comment in: Nephrol Dial Transplant. Dec. 2003;18(12):2688. PMID: 14605313. [Rec#: 8104] INCLUDE: considered for evidence table.
Weiss S C, Emanuel L L, Fairclough D L, Emanuel E J. Understanding the experience of pain in terminally ill patients. Lancet 2001;357(9265):1311–5. Comment in: Lancet. 2001 Apr 28;357(9265):1304–5. PMID: 11343728. Comment in: Lancet. Sep 22. 2001;358(9286):1014-5. PMID: 11583773. [Rec#: 8110] INCLUDE: considered for evidence table.
Weitzner M A, McMillan S C, Jacobsen P B. Family caregiver quality of life: differences between curative and palliative cancer treatment settings. J Pain Symptom Manage. 99;17(6):418-28. [Rec#: 8117] INCLUDE: considered for evidence table.
Wenger N S, Kanouse D E, Collins R L, Liu H, Schuster M A, Gifford A L, Bozzette S A, Shapiro M F. End-of-life discussions and preferences among persons with HIV. JAMA. 2001;285(22):2880-7. [Rec#: 8131] INCLUDE: considered for evidence table. [pmid: 11401609].
Wenger N S, Phillips R S, Teno J M, Oye R K, Dawson N V, Liu H, Califf R, Layde P, Hakim R, Lynn J. Physician understanding of patient resuscitation preferences: insights and clinical implications. J Am Geriatr Soc. 2000;48(5 Suppl):S44-51. [Rec#: 8134] INCLUDE: considered for evidence table. [pmid: 10809456].
Wenger N S, Lynn J, Oye R K, Liu H, Teno J M, Phillips R S, Desbiens N A, Sehgal A, Kussin P, Taub H, Harrell F, Knaus W. Withholding versus withdrawing life-sustaining treatment: patient factors and documentation associated with dialysis decisions. Journal of the American Geriatrics Society. 2000;48(5 Suppl):S75-83. [Rec#: 50816] INCLUDE: considered for evidence table. [pmid: 10809460].
Wennberg J E, Fisher E S, Stukel T A, Skinner J S, Sharp S M, Bronner K K. Use of hospitals, physician visits, and hospice care during last six months of life among cohorts loyal to highly respected hospitals in the United States. BMJ 2004;328(7440):607. Comment in: BMJ. Mar 13. 2004;328(7440):610. PMID: 15016693. [Rec#: 8138] INCLUDE: considered for evidence table.
Wenrich M D, Curtis J R, Ambrozy D A, Carline J D, Shannon S E, Ramsey P G. Dying patients' need for emotional support and personalized care from physicians: perspectives of patients with terminal illness, families, and health care providers. J Pain Symptom Manage. 2003;25(3):236-46. [Rec#: 8139] INCLUDE: considered for evidence table. [pmid: 12614958].
Westlake C, Dracup K, Creaser J, Livingston N, Heywood J T, Huiskes B L, Fonarow G, Hamilton M. Correlates of health-related quality of life in patients with heart failure. Heart Lung. 2002;31(2):85-93. [Rec#: 35984] INCLUDE: considered for evidence table. [pmid: 11910383].
Westlake C, Dracup K, Walden J A, Fonarow G. Sexuality of patients with advanced heart failure and their spouses or partners. J Heart Lung Transplant. 99;18(11):1133-8. [Rec#: 35985] INCLUDE: considered for evidence table. [pmid: 10598738].
Weze C, Leathard H L, Grange J, Tiplady P, Stevens G. Evaluation of healing by gentle touch in 35 clients with cancer. Eur J Oncol Nurs. 2004;8(1):40-9. [Rec#: 8156] INCLUDE: considered for evidence table. [pmid: 15003743].
Wielenga R P, Erdman R A, Huisveld I A, Bol E, Dunselman P H, Baselier M R, Mosterd W L. Effect of exercise training on quality of life in patients with chronic heart failure. J Psychosom Res. 98;45(5):459-64. [Rec#: 36014] INCLUDE: considered for evidence table.
Wilcock A, Crosby V, Hughes A, Fielding K, Corcoran R, Tattersfield A E. Descriptors of breathlessness in patients with cancer and other cardiorespiratory diseases. J Pain Symptom Manage. 2002;23(3):182-9. [Rec#: 36025] INCLUDE: considered for evidence table. [pmid: 11888716].
Wilkie D J, Keefe F J. Coping strategies of patients with lung cancer-related pain. Clin J Pain. 91;7(4):292-9. [Rec#: 36033] INCLUDE: considered for evidence table. [pmid: 1809442].
Wilkie D J, Huang H Y, Reilly N, Cain K C. Nociceptive and neuropathic pain in patients with lung cancer: a comparison of pain quality descriptors. J Pain Symptom Manage. 2001;22(5):899-910. [Rec#: 36032] INCLUDE: considered for evidence table. [pmid: 11728793].
Wilkinson S, Aldridge J, Salmon I, Cain E, Wilson B. An evaluation of aromatherapy massage in palliative care. Palliat Med. 99;13(5):409-17. [Rec#: 8212] INCLUDE: considered for evidence table. [pmid: 10659113].
Willert M G, Beckwith B E, Holm J E, Beckwith S K. A preliminary study of the impact of terminal illness on spouses: social support and coping strategies. Hosp J. 95;10(4):35-48. [Rec#: 8220] INCLUDE: considered for evidence table.
Wilson D. A report of an investigation of end-of-life care practices in health care facilities and the influences on those practices. J Palliat Care. 97;13(4):34-40. [Rec#: 8230] INCLUDE: considered for evidence table. [pmid: 9447810].
Wilson D M, Truman C D. Addressing myths about end-of-life care: research into the use of acute care hospitals over the last five years of life. J Palliat Care. 2002;18(1):29-38. [Rec#: 8234] INCLUDE: considered for evidence table. [pmid: 12001400].
Wilson D M, Smith S L, Anderson M C, Northcott H C, Fainsinger R L, Stingl M J, Truman C D. Twentieth-century social and health-care influences on location of death in Canada. Can J Nurs Res. 2002;34(3):141-61. [Rec#: 16390] INCLUDE: considered for evidence table. [pmid: 12425015].
Wilson D M. End-of-life care preferences of Canadian senior citizens with caregiving experience. J Adv Nurs. 2000;31(6):1416-21. [Rec#: 8232] INCLUDE: considered for evidence table. [pmid: 10849154].
Witkowski A and Carlsson ME. Support group programme for relatives of terminally ill cancer patients. Support Care Cancer 2004. [Rec#: 8271] INCLUDE: considered for evidence table
Witteveen P O, Jacobs H M, van Groenestijn M A, Lodder A C, van Boxtel A H, Nieuwland M, Post M W, Touw-Otten F W, Blijham G H. Assessment of the quality of life of patients with advanced and end-stage cancer or serious infections with a symptom-based or an impact-based instrument. Support Care Cancer. 99;7(2):64-70. [Rec#: 8275] INCLUDE: considered for evidence table.
Witteveen P O, van Groenestijn M A, Blijham G H, Schrijvers A J. Use of resources and costs of palliative care with parenteral fluids and analgesics in the home setting for patients with end-stage cancer. Ann Oncol 99;10(2):161–5. Comment in: Ann Oncol. Feb. 1999;10(2):135-6. PMID: 10093679. [Rec#: 8276] INCLUDE: considered for evidence table.
Wood B C, Mynors-Wallis L M. Problem-solving therapy in palliative care. Palliat Med. 97;11(1):49-54. [Rec#: 8299] INCLUDE: considered for evidence table. [pmid: 9068685].
Wright E P, Kiely M A, Lynch P, Cull A, Selby P J. Social problems in oncology. Br J Cancer. 2002;87(10):1099-104. [Rec#: 8324] INCLUDE: considered for evidence table. [pmid: 12402148].
Wrubel J, Richards T A, Folkman S, Acree M C. Tacit definitions of informal caregiving. J Adv Nurs. 2001;33(2):175-81. [Rec#: 16481] INCLUDE: considered for evidence table. [pmid: 11168700].
Wu N, Miller S C, Lapane K, Gozalo P. The problem of assessment bias when measuring the hospice effect on nursing home residents' pain. J Pain Symptom Manage. 2003;26(5):998-1009. [Rec#: 8335] INCLUDE: considered for evidence table. [pmid: 14585551].
Yancey D, Greger H A, Coburn P. Determinants of grief resolution in cancer death. J Palliat Care. 90;6(4):24-31. [Rec#: 8352] INCLUDE: considered for evidence table. [pmid: 2286858].
Yang C T, Kirschling J M. Exploration of factors related to direct care and outcomes of caregiving. Caregivers of terminally ill older persons. Cancer Nurs. 92;15(3):173-81. [Rec#: 8353] INCLUDE: considered for evidence table.
Yoshioka H. Rehabilitation for the terminal cancer patient. Am J Phys Med Rehabil. 94;73(3):199-206. [Rec#: 8385] INCLUDE: considered for evidence table. [pmid: 7515247].
Yurk R, Morgan D, Franey S, Stebner J B, Lansky D. Understanding the continuum of palliative care for patients and their caregivers. J Pain Symptom Manage. 2002;24(5):459-70. [Rec#: 8401] INCLUDE: considered for evidence table. [pmid: 12547046].
Zallman L, Sanchez J, Choi H, Selwyn P. Unmet need for chronic disease and end-of-life care at urban family health centers in the Bronx, NY. Fam Med. 2003;35(9):637-42. [Rec#: 8407] INCLUDE: considered for evidence table. [pmid: 14523661].
Zeppetella G, O'Doherty C A, Collins S. Prevalence and characteristics of breakthrough pain in patients with non-malignant terminal disease admitted to a hospice. Palliat Med. 2001;15(3):243-6. [Rec#: 8426] INCLUDE: considered for evidence table. [pmid: 11407195].
Zhukovsky D S, Gorowski E, Hausdorff J, Napolitano B, Lesser M. Unmet analgesic needs in cancer patients. J Pain Symptom Manage. 95;10(2):113-9. [Rec#: 8433] INCLUDE: considered for evidence table. [pmid: 7537317].
Zisook S, Paulus M, Shuchter S R, Judd L L. The many faces of depression following spousal bereavement. J Affect Disord. 97;45(12):85-94. discussion 94–5. [Rec#: 8443] INCLUDE: considered for evidence table.
Zweig S C, Kruse R L, Binder E F, Szafara K L, Mehr D R. Effect of do-not-resuscitate orders on hospitalization of nursing home residents evaluated for lower respiratory infections. J Am Geriatr Soc. 2004;52(1):51-8. [Rec#: 50932] INCLUDE: considered for evidence table. [pmid: 14687315].