# Appendix L. Observational Studies Evidence Tables

Evidence table 1. OS Continuity and Coordination Evidence Table

First Author Year ID | Study Characteristics | Population | Exposure, Outcomes Duration, Dropouts | Results
Bradley, 2001 ^1^ | Design: Cross sectional | Sample size: 223 | Exposure: Demographic, clinical factors, hospice enrollment | Results: Only 38% of charts included a documented discussion about prognosis, 29–45% of charts included discussions related to advance care planning. Non-physicians directed such discussion in 20/89 cases. Only emergency admission and length of stay, and hospital death were associated with increased odds of prognostic discussion in adjusted models.
| Quality: N/A | Disease: Single disease: Cancer | Outcomes: Chart documentation of a discussion about prognosis
| Setting: Hospital (ICU and non-ICU) | Severity: Advanced | Duration: N/A
| Funding: Not reported | Race: White, Hispanic, Black | Withdrawals: 232 / 325 approached agreed to medical record review
| | Gender: Males and females
Burge, 2003 ^2^ | Design: Retrospective cohort secondary data analysis | Sample size: 8702 | Exposure: MMCI as measured by family physician care - number of visits adjusted by number of physicians involved | Results: Patients with low continuity, MMCI < 0.5, made more emergency department visits (rate ratio 3.93) and those with intermediate continuity, MMCI 0.5–0.8 made more emergency visits (rate ratio 2.28) compared with those experiencing high continuity (MMCI > 0.8). Absolute number of visits approximately 2 in the lowest continuity group. Women and older patients less likely, and rural lower income, not enrolled in palliative care, receiving specialty treatment patients more likely to have emergency visits.
| Quality: N/A | Disease: Single disease: Cancer | Outcomes: Emergency department use
| Setting: Unclear | Severity: Advanced | Duration: 6 months
| Funding: Cancer Research and Education Nova Scotia (CaRE) | Race: Not reported | Withdrawals: N/A
| | Gender: Males and females
Burge, 2003 ^3^ | Design: Retrospective cohort secondary data analysis | Sample size: 8702 | Exposure: MMCI as measured by family physician care - number of visits adjusted by number of physicians involved | Results: Patients with low continuity, MMCI < 0.5, made more emergency department visits (rate ratio 3.93) and those with intermediate continuity, MMCI 0.5–0.8 made more emergency visits (rate ratio 2.28) compared with those experiencing high continuity (MMCI > 0.8). Absolute number of visits approximately 2 in the lowest continuity group. Women and older patients less likely, and rural lower income, not enrolled in palliative care, receiving specialty treatment patients more likely to have emergency visits.
| Quality: N/A | Disease: Single disease: Cancer | Outcomes: Emergency department use
| Setting: Unclear | Severity: Advanced | Duration: 6 months
| Funding: Cancer Research and Education Nova Scotia (CaRE) | Race: Not reported | Withdrawals: N/A
| | Gender: Males and females
Tang, 2003 ^4^ | Design: Prospective Cohort | Sample size: 127 | Exposure: Not reported | Results: 50% used hospice home care. Use of home care predicted use of hospice. Number and length of re-hospitalizations were higher for hospice home care group.
| Quality: Good | Disease: Single disease: mixed cancer | Outcomes: hospice home care use
| Setting: Home health care | Severity: Advanced | Duration: 2–293 days
| Funding: Roxane Laboratories | Race: Not reported | Withdrawals: Not reported
| | Gender: Males and females
Tang, 2003 ^5^ | Design: Prospective Cohort | Sample size: 180 | Exposure: Demographic and clinical characteristics, social support, health system factors | Results: Only 30% of patients died at the site they preferred to die. In a limited model developed using variables selected for significance, re-hospitalization was significantly associated with a lower likelihood, hospice and perceived family support associated with a higher likelihood of achieving death in preferred site.
| Quality: Fair | Disease: Single disease: Cancer | Outcomes: Site of death
| Setting: Unclear | Severity: Advanced | Duration: median of 36 days
| Funding: Not reported | Race: Non-hispanic white, other | Withdrawals: 127 / 180 enrollees (207 approached) were eligible for analysis of site of death
| | Gender: Males and females
Wennberg, 2004 ^6^ | Design: Retrospective cohort secondary data analysis | Sample size: 115089 | Exposure: High quality geriatric, cardiovascular, cancer, or pulmonary disease as indicated by US News and World Report rankings. | Results: On average, 37% of the cohort saw more than 10 physicians in the last 6 months of life, 40% died in hospital and 27% were admitted to hospice. There was widespread variation in the use of resources and intensity of care over the last 6 months of life in hospitals with high quality perceived care.
| Quality: N/A | Disease: Mixed Disease | Outcomes: Healthcare resource use, number of days spent in hospital or ICU, % of patients seeing 10 or more physicians, % enrolled in hospice - in last 6 months of life.
| Setting: Hospice and Hospital (ICU & non ICU) | Severity: Advanced | Duration: 6 months
| Funding: RWJF, NIA 1PO1AG19783-01 | Race: Black, non-black | Withdrawals: N/A
| | Gender: Males and females
Townsend, 1990 ^7^ | Design: Prospective Cohort | Sample size: 84 | Exposure: Not reported | Results: Preference for site of death on initial interview: 58% at home, 20% in hospital, 20% in hospice, 2% other. Preference at final interview: 49% at home, 24% hospital, 25% in hospice. Of 32 who died in hospital, 63% had stated preference to die elsewhere.
| Quality: Poor | Disease: Single disease: mixed cancer | Outcomes: congruence between preference for location of death and actual site of death
| Setting: Home health care | Severity: Advanced | Duration: 5–18 mos (or until death)
| Funding: Harrow Health Authority, Rehabilitation Research Fund | Race: Not reported | Withdrawals: 6
| | Gender: Not reported
Hutt, 2002 ^8^ | Design: Retrospective cohort secondary data analysis | Sample size: 636 | Exposure: Demographic, clinical factors, advance directives | Results: For three tracer conditions (UTI, CHF, and pneumonia), hospitalization varied greatly during acute illness in the nursing home (UTI 11%, pneumonia 46%, CHF 58%). Older age decreased and male gender increased odds of hospitalization for CHF, male gender increased and DNR decreased odds of hospitalization for pneumonia. Weekend and night / evening shifts increased odds of hospitalization for UTI.
| Quality: N/A | Disease: Mixed Disease | Outcomes: Hospitalization vs. no hospitalization during acute illness in the nursing home
| Setting: Nursing home | Severity: Advanced | Duration: N/A
| Funding: CMS Contract No. 94-058 | Race: Not reported | Withdrawals: N/A
| | Gender: Males and females
Burns, 2003 ^9^ | Design: Prospective Cohort | Sample size: 136 caregivers | Exposure: time | Results: There was little change over time in caregiver's knowledge of treatment intent. 40% at week 1 vs 48% at week 12 understood that treatment would not cure. However, patient prognosis was associated with knowledge: only 10% of caregivers of patients with less than six months to live believed that the treatment intent was curative. IN bivariate analyses at baseline, multiple factors were statistically significantly associated with the view that treatment intent was curative, including male caregiver gender, older caregiver age, those who were still working, retired or unemployed (compared to those who had stopped work to care for the patient). Patient clinical characteristics associated with lack of caregiver understanding included breast or ovarian cancer and recruitment through radiation oncology.
| Quality: Poor | Disease: Single disease: mixed cancer | Outcomes: Caregiver's knowledge of treatment intent
| Setting: Ambulatory/outpt medical care | Severity: Mixed | Duration: 12 weeks
| Funding: Australian Commonwealth Department of Health and Community Services | Race: Not reported | Withdrawals: 51 (unclear)
| | Gender: Males and females
Chin, 1997 ^10^ | Design: Prospective Cohort | Sample size: 257 | Exposure: Not reported | Results: 31% were re-hospitalized within 60 days. In multivariate analysis, neither race nor gender predicted re-hospitalization.
| Quality: Good | Disease: Single disease: CHF | Outcomes: hospitalization
| Setting: Ambulatory/outpt medical care | Severity: Moderate | Duration: 60 days
| Funding: Not reported | Race: Not reported | Withdrawals: None
| | Gender: Not reported
Chin, 1997 ^10^ | Design: Prospective Cohort | Sample size: 257 | Exposure: Demographic, clinical, and social characteristics | Results: Single marital status, comorbidity, and other clinical variables were independently associated with risk of readmission. Risk of re-admission was 31% at 60 days.
| Quality: Fair | Disease: Single disease: CHF | Outcomes: Readmission
| Setting: Ambulatory/outpt medical care and Hospital (non ICU) | Severity: Moderate | Duration: 60 days
| Funding: NIA K12-AG-00488 award | Race: White, non-white | Withdrawals: Not reported
| | Gender: Males and females
Fried, 1997 ^11^ | Design: Retrospective cohort secondary data analysis | Sample size: 3782 | Exposure: Demographic, clinical, functional factors, advance directives. | Results: Older, female residents hospitalized less frequently. Stage 2 or greater pressure ulcer, feeding tube, recent medication prescription associated with higher risk of hospitalization. Advance directives not associated with hospitalization. Moderate to severe cognitive impairment associated with lower risk and severe functional impairment a higher risk of hospitalization.
| Quality: N/A | Disease: Mixed Disease | Outcomes: Hospitalization vs. no hospitalization during a six month period
| Setting: Nursing home | Severity: Advanced | Duration: N/A
| Funding: Not reported | Race: Not reported | Withdrawals: N/A
| | Gender: Males and females
Kane, 2003 ^12^ | Design: Prospective Cohort | Sample size: ~4800 | Exposure: Evercare | Results: Evercare is a capitated HMO for ong-stay nursing home residents. The model seeks to increase primary care intensity by employing nurse practitioners in contracted nursing homes to supplement the care of the primary care physicians and train nursing home staff. They enrolled 44 Evercare and control facilities and compared 3 groups: Evercare patients, patients in Evercare-contracted nursing homes not receiving Evercare, and patients in non-Evercare-contracted nursing homes. Patients were matched by admission date. Multivariate analyses controlling for multiple patient variables (but not accounting for clustering by facility) found fewer hospitalizations and less hospital use in the Evercare group, mainly by substituting nursing home care for hospital care. Preventable hospitalizations were also reduced. Patient attention was more than twice as high. No information is given on the terminally ill or those who died.
| Quality: Good | Disease: Mixed Disease | Outcomes: resource utilization: hospital, ER, physician, and psychotherapy use
| Setting: Nursing home | Severity: Moderate | Duration: 15 months
| Funding: CMS | Race: Not reported | Withdrawals: 3% disenrollment in Evercare per month, “almost all due to death”
| | Gender: Not reported
Knol, 2003 ^13^ | Design: Prospective Cohort | Sample size: 555 | Exposure: time | Results: Patients who died or couldn't participate in interviews due to illness were excluded. 25% were receiving home care initially, compared to 35% 2 years later. The best predictors of new home care use were high chronic morbidity, older age, and a high level of mastery. Lower income and less self-efficacy had borderline statistical significance. Disability and the amount of informal help did not play a role in prospectively determining home care use.
| Quality: Good | Disease: Mixed Disease | Outcomes: utilization of professional home care
| Setting: Home health care | Severity: Moderate | Duration: 2 years
| Funding: Dutch government, University of Groningen, Faculty of Medical Sciences, Dutch Cancer Foundation, Netherlands Organization for Scientific Research | Race: Not reported | Withdrawals: 555 are of an original sample of 753.
| | Gender: Not reported
Heller, 2000 ^14^ | Design: Prospective Cohort | Sample size: 4981 | Exposure: Disease group (post-MI, other heart disease, CHF, or stroke), Demographic and clinical characteristics | Results: Patients with CHF had the highest risk for re-admission or death (49%) the year after index hospitalization. Stroke had a low re-admission rate of about 11%. Age was the most important consistent prognostic indicators.
| Quality: Good | Disease: Predominately one disease: Cardiovascular disease | Outcomes: Death and readmission to a hospital the year after discharge for an index condition
| Setting: Hospital (ICU and non-ICU) | Severity: Moderate | Duration: 1 year post-index discharge
| Funding: Not reported | Race: Not reported | Withdrawals: None
| | Gender: Males and females
Holtzman, 1998 ^15^ | Design: Prospective Cohort | Sample size: 970 | Exposure: HMO care | Results: This study compared Medicare patients discharged after a CVA, COPD, CHF, hip replacement, or hip fracture repair. Information on end-of-life issues (such as mortality rate) is not reported. In multivariate analyses, there were no significant differences in hospital readmissions or ADL status by HMO or fee-for-service status.
| Quality: Good | Disease: Mixed Disease | Outcomes: ADL function, hospital readmission
| Setting: Home health care | Severity: Moderate | Duration: 6 months
| Funding: HCFA, Assistant Secretary for Planning and Evaluation | Race: Not reported | Withdrawals: None in 6 weeks
| | Gender: Not reported
Nourhashemi, 2001 ^16^ | Design: Cross sectional | Sample size: 118 | Exposure: Not reported | Results: Behavioral problems followed by falls.
| Quality: N/A | Disease: Single disease: Dementia | Outcomes: Emergency hospital admission
| Setting: Hospital (non ICU) | Severity: Advanced | Duration: N/A
| Funding: Not reported | Race: Not reported | Withdrawals: 118 / 118 cases described
| | Gender: Not reported
Stewart, 2002 ^17^ | Design: Prospective Cohort | Sample size: 90 | Exposure: Not reported | Results: Among 90 patients with chronic heart failure assigned to a multidisciplinary, home-based intervention and followed for 14 days, 2 died, 5 had an unplanned readmission, and 28 were clinically unstable at a planned home visit. The outcome of Early Clinical Deterioration (ECD) was defined as the combination of these 3 outcomes. In multivariate analysis, greater age and greater comorbidity were associated with ECD. ECD was associated with greatly reduced event-free survival (death or hospitalization) in the next six months.
| Quality: Fair | Disease: Single disease: CHF | Outcomes: Early Clinical Deterioration
| Setting: Home health care | Severity: Moderate | hospital utilization
| Funding: National Heart Foundation of Australia | Race: Not reported | Duration: 6 months
| | Gender: Not reported | Withdrawals: None
Zweig, 2004 ^18^ | Design: Prospective Cohort | Sample size: 1031 | Exposure: Evaluation for a lower respiratory tract infection | Results: In logistic regression model, there was no significant difference in the adjusted odds of hospitalization within 30 days of evaluation for a lower respiratory infection for African-Americans. The adjusted odds ratio for males was borderline significant (1.42 (0.99–2.03). DNR orders decreased the odds of hospitalization (0.69 (0.49–0.97)).
| Quality: Good | Disease: Mixed Disease | Outcomes: Hospitalization
| Setting: Nursing home | Severity: Unclear | Duration: 30 days
| Funding: AHRQ, HRSA, RWJ | Race: White, Black | Withdrawals: 21
| | Gender: Males and females

I = Intervention group, C = Control group, RCT/CCT = Randomized Controlled Trial/Clinical Controlled Trial, ICU = Intensive Care Unit, CPR = Cardiopulmonary Resuscitation, RN = Registered Nurse, DNR = Do Not Resuscitate, outpt = Outpatient, AD = Advance Directive, MD = Physician, ACP = Advance Care Planning, AD/DPA = Advance Directive/Durable Power of Attorney,HRQoL = Health Related Quality of Life, T = Treatment group, DPA = Durable Power of Attorney

Evidence table 2. OS Family/Caregiver Concerns Evidence Table

First Author Year ID | Study Characteristics | Population | Exposure, Outcomes Duration, Dropouts | Results
Collins, 1994 ^1^ | Design: Prospective Cohort | Sample size: N=142 (46 residential CGs vs. 49 CGs of institutionalized vs. 47 bereaved CGs) | Exposure: Three 60–90 minute interviews and complete a self-administered booklet (Intake, 22 months, 37 months) | Results: No statistically significant differences were found among residential, institution, and bereaved caregivers on demographic characteristics. No statistically significant differences were found between the three groups on depression. Female bereaved caregivers experienced a pattern of decreasing depression following their relative's death while male bereaved caregivers experienced an increase.
| Quality: Good | Disease: Single disease: Dementia | Outcomes: Depression.
| Setting: Nursing home and home | Severity: Unclear | Duration: 3 years
| Funding: NIMH | Race: Caucasian (98%), African-American (2%) | Withdrawals: Not reported
| | Gender: Males and females
Emanuel, 1999 ^2^ | Design: Survey | Sample size: 988 terminally ill patients and 893 caregivers in 6 randomly selected areas of the US. 59% were over the age of 65 years and 51.5% were women (cancer 52%, heart disease-18%, and chronic obstructive pulmonary disease-11%). 4% were in a nursing home, hos | Exposure: Once | Results: A need for assistance was reported by 87% of the patients, including help with transportation (reported by 62%), homemaking services (55%), nursing care (29%), and personal care (26%). Seventy-two percent of caregivers were women and 96% of caregivers were family members. Most patients relied completely on family members and friends for assistance. Only 15.5% of patients relied totally on paid assistance for more than half of the care they needed. Volunteers (unpaid helpers who were not family members) provided less than 3% of all care. In addition to medical care, dying patients often need many types of assistance. Family members, primarily women, provided the majority of assistance with non-medical care.
| Quality: Good | Disease: Mixed Disease | Outcomes: Type of assistance needed.
| Setting: Home, nursing home, hospital (ICU) and hospice | Severity: Advanced | Duration: None
| Funding: Commonwealth Fund & Nathan Cummings Foundation | Race: White (79%), Black (14%), Hispanic (3%), Other (4%) | Withdrawals: Not reported
| | Gender: Not reported
Grant, 2002 ^3^ | Design: Prospective Cohort | Sample size: N=167 (119 CG and 48 non-caregiving comparison CG) | Exposure: baseline, 6 months, 12 months, 18 months | Results: CG who placed the care recipient in a NH or whose care recipient died showed improvement in depressive and physical symptoms compared to CG who continued to provide care and non-caregiving comparisons. Both placement and death of pt associated with higher blood pressure during transitions. However, there were continued symptoms long term after transtions.
| Quality: Good | Disease: Single disease: Alzheimer's Disease | Outcomes: CG physical and mental health.
| Setting: Nursing home and home | Severity: Mixed | Duration: 18 months
| Funding: NIA | Race: Not reported | Withdrawals: Not reported
| | Gender: Females
Hays, 1994 ^4^ | Design: Prospective Cohort | Sample size: N=1,112 caregivers | Exposure: Baseline, 2 mo., 6 mo., 13 mo., and 25 mo. After enrollment | Results: Distress was related to the severity of the patient's illness, the actuality and timing of the bereavement, as well as the gender and age of the respondent.
| Quality: Good | Disease: Mixed Disease | Outcomes: Depression, General Anxiety, Feelings of Helplessness and Hopelessness.
| Setting: Not reported | Severity: Advanced and moderate | Duration: 2 years
| Funding: NIMH & NIA | Race: White (91%), African American (8.5%), Hispanic (.5%) | Withdrawals: 371 (25% of eligible respondents)
| | Gender: Females
Hodgson, 1997 ^5^ | Design: Prospective Cohort | Sample size: N=757 pts (508 died while in HH) and 747 caregivers | Exposure: Baseline, 2 weeks, week of death | Results: 75% of patients died at home. 32% of families had severe or overwhelming anxiety. During the last week of care, anxiety remained severe for 26% of CGs. Patient and family well-being were inter-related and there were significant interactions between family anxiety and patient physical and psychological symptoms and communication. Family anxiety at referral strongly predicts family anxiety at last week of life. Excluding family anxiety at referral, other predictors for family anxiety were patient symptom control, sex of patient, diagnosis, and patient age.
| Quality: Good | Disease: Single disease: Cancer | Outcomes: Cg function and ability to self-care, patient and family physical symptoms, psychological functioning, and communication.
| Setting: Home health care | Severity: Advanced | Duration: 6 months
| Funding: Cancer Society, Europe Against Cancer | Race: White (100%) | Withdrawals: Not reported
| | Gender: Females
Martikainen, 1998 ^6^ | Design: Prospective Cohort | Sample size: N=5,500 widowed decedents | Exposure: Baseline, 5 years later | Results: Results indicated that both men and women experience excess mortality after the death of a spouse and that the relative excess mortality among the bereaved is broadly similar in all education and income subgroups analyzed. The absolute mortality difference between widowed and married persons, however, tends to be larger among less educated and, especially, low-income persons.
| Quality: Good | Disease: Mixed Disease | Outcomes: Mortality.
| Setting: Not reported | Severity: Advanced | Duration: 5 year
| Funding: Social Science Research Council, Academy of Finland | Race: Caucasian (100%) | Withdrawals: Not reported
| | Gender: Not reported
Schulz, 2001 ^7^ | Design: Prospective Cohort | Sample size: N=129 caregivers | Exposure: Baseline, 3 annual in-person interviews, 2 years after | Results: CES-D scores remained high but did not change among strained caregivers (p=.76)while CES-D scores increased for both non-caregivers (p=<.001) and non-strained caregivers (p=.04). Non-caregivers signifcantly more likely to be using antidepressant medications following the death than non-strained group (p=.05). The strained CG group experienced significant improvement in health reisk behaviors following the death of their spouse (P<.001) while the non-caregiver and non-strained CG groups showed little change. Non-caregivers expereinced significant weight loss following the death while the strianed and non-strained CG groups did not. The impact of losing one's spouse among older persons varies as a function of the caregiving experiences that precede the death. Among individuals who are already strained prior to the death, the death itself does not increase their level of distress.
| Quality: Good | Disease: Single disease: Cardiovascular Disease | Outcomes: Depressive symptoms, anitdepressant medication use, 6 health risk behaviors, weight.
| Setting: Unclear | Severity: Advanced and moderate | Duration: 4 years
| Funding: NIMH | Race: White (90%) | Withdrawals: 103
| | Gender: Males and females
Schulz, 2003 ^8^ | Design: Prospective Cohort | Sample size: N=217 caregivers | Exposure: Baseline, 6 months, 12 months, 18 months | Results: Overall, caregivers exhibited high levels of depressive symptoms while providing care to the relative with dementia (mean CES-D score: 15.8+ 11.7; median, 13). Forty-three percent of caregivers had scores above 15. At the death of the relative, depressive symptom scores spike to 22. However, within three months of the death of the relative, caregivers had clinically significant declines in the level of depressive symptoms, declining to a level similar to pre-bereavement levels 9mean, 16.2+12.3; median, 14). Within one year the levels of symptoms were substantially lower than at baseline (mean 11.5+9.4; median, 9) (P=0.03). Caregivers who cared for and then placed their relative in a nursing home had mean scores for depression of 17.1+11.9 (median, 15) before placement and mean depression scores of 18.1+13.0 (median, 15) after placement. One year after placement, depression scores remained high among and were significantly higher among caregivers of patients who had been institutionalized than among those caregivers of patients who had died (mean, 16.2 vs. 11.5; median, 14 vs. 9; P=0.02). Use of antidepressant medication and anxiolytic drugs increased after the death of the relative (16.6% and 19.4% before the death, 21% and 18% after the death). While the death of a close relative is generally viewed as a powerful source of psychological stress, the caregivers in this study showed remarkable resilience in adapting to the death of their relatives.
| Quality: Good | Disease: Single disease: Alzheimer's Disease | Outcomes: Number of hours/wk spent helping pt, type of assistance provided patient, CG burden and depression, medication use, impact of caregiving on employment, formal health service use, CG response to death of patient.
| Setting: Home | Severity: Advanced and moderate | Duration: 18 months
| Funding: NIMH | Race: White (66%), Black (20%), Hispanic (14%) | Withdrawals: 48
| | Gender: Females
Teno, 2004 ^9^ | Design: Telephone Survey | Sample size: N=1578 respondents | Exposure: Survey | Results: Sixty-seven percent of decedents died in an institutional setting while 33% died at home. Of those dying at home, 38% did not receive nursing services, 13% used home nursing services, and 49% had home hospice services. About 25% of all patients with pain or dyspnea at the end of life did not receive adequate treatment and one quarter reported concerns with physician communication. More than one-third of respondents cared for by a home health agency, nursing home, or hospital reported insufficient emotional support for the patient and/or 1 or more concerns with family emotional support, compared with about 1/5 of those receiving home hospice services. Nursing home residents were less likely than those care for in a hospital or by home hospice services to always have been treated with respect at the end of life (68% vs. 77% and 96% respectively). Family members of patients receiving hospice services were more satisfied with overall quality of care: 71% rated care as “excellent” compared with less than 50% of those dying in an institutional setting or with home health services. These data suggest that those dying in institutions have unmet needs for symptom management, physician communication, emotional support and being treated with respect. Family members of decedents who died with home hospice services were more likely to report a favorable dying experience.
| Quality: Good | Disease: Mixed Disease | Outcomes: Patient and family centered end of life care.
| Setting: Home, hospice, nursing home, and hospital (ICU and non-ICU) | Severity: Advanced | Duration: None
| Funding: RWJ | Race: White (83%), Black (12%), Hispanic (3%) | Withdrawals: 1697
| | Gender: Males and females
Tilden, 2004 ^10^ | Design: Telephone Survey | Sample size: N=1,089 widowed caregivers | Exposure: Once | Results: Results showed that most decedents had an advance directive (78.3%) and were enrolled in hospice (62.4%). Although perceived decedent symptom distress was low overall, certain symptoms (e.g., pain, dyspnea, constipation) were distressing for approximately half of decedents experiencing them. Financial hardship, out-of-pocket expenses, and caregiver strain were frequently reported. American Indian race and younger age were associated with decedent symptom distress. Greater perceived decedent symptom distress, hospice enrollment, more caregiver involvement, and more financial burden were associated with greater caregiver strain. Thus, despite high rates of advance directives and hospice enrollment, perceived symptom distress was high for a subset of decedents, and caregiver strain was common.
| Quality: Good | Disease: Mixed Disease | Outcomes: Advance directives, hospice enrollment, use of life-sustaining treatments, perceived decedent symptom distress, financial hardship, out-of-pocket costs, family caregiver strain.
| Setting: Home, nursing home, hospice and other | Severity: Advanced | Duration: None
| Funding: NINR and RWJ | Race: White (83%), Black (4.4%), Hispanic (3.9%), Asian-Pacific Islander (4.3%), American Indian (4.1%) | Withdrawals: 471
| | Gender: Males and females
Volicer, 2003 ^11^ | Design: Mail Survey | Sample size: n=156 Caregivers | Exposure: Once | Results: 22% of pts died at home. Results suggest that end of life experiences of individuals with dementia differ according to setting of care. Patients cared for at home and receiving hospice care during last 90 days had fewer symptoms vs. other groups and fewer signs of physical distress during the dying process. Hospice use did not affect caregiver burden but these patients stayed at home 23 days longer and were twice as likely to die at home than in an institution. Caregivers of patients dying at home had increased time dependence burden but other burden scores were similar among all groups. Caregivers with patients dying both at home and in an institution were less satisfied with care than those cared for in only one setting. No effect on burden was found for use of formal or informal assistance. Psychiatric symptoms in the patient increased caregiver burden and were the most common cause of institutionalization. Receipt of psychiatric care was associated with longer stay at home. Presence of advance directive decreased hospital stays and increased the likelihood of dying in a nursing home. These results indicate that quality end of life dementia care can be provided at home by hospice and psychiatric care.
| Quality: Good | Disease: Single disease: Alzheimer's Disease | Outcomes: Severity of dementia, Place of death, CG burden, CG satisfaction with care, enrollment in hospice, amount and type of help received by CG.
| Setting: Home, nursing home, hospital (ICU and non-ICU) | Severity: Advanced | Duration: None
| Funding: Alzheimer's Association and Dept. of Veterans Affairs | Race: Caucasian (97%) | Withdrawals: Not reported
| | Gender: Males and females
McCarthy, 1997 ^12^ | Design: Telephone Survey | Sample size: 600 Caregivers | Exposure: Once | Results: Just under half (47%) of caregivers felt they had not been able to get all the information regarding the deceased's illness that they had wanted or when they had wanted it. Thirty-seven percent of caregivers said they had known the deceased was likely to die and 26% said they had “half-known,” whereas 26% of deceased patients were reported to have known and 25% were reported to have “probably” known that they were likely to die. Of those deceased patients who were reported to have known or probably known they were likely to die, most were reported to have had to work this out for themselves: only 8% were said to have been told by a GP or hospital doctor. Moreover, only 44% of caregivers were told of the terminal prognosis. Half of the patients (54%) died in hospitals, 30% at home, and 4% in other places. Patients under age 75 were less likely to die in an institution and more likely to die at home than patients 75 or older. Women aged 75 or older more frequently died in residential or nursing homes than males. A quarter of the deceased were reported to have expressed a wish to die sooner; more women than men were said to have expressed such a wish (30% vs. 17%, P<0.01). Moreover, decedents who were aged 75 or older were 2.6 times more likely to have expressed a wish to die sooner; those with four or more symptoms perceived as “very distressing” were 2.3 times more likely; and those who had a poor quality of life wee 1.9 times more likely to expressed such a wish.
| Quality: Good | Disease: Single disease: Cardiovascular Disease | Outcomes: Information about illness, Knowledge of prognosis, Learning about dying, Support in dying, Place of death, Time to death.
| Setting: Hospital (ICU and non-ICU), home and other | Severity: Advanced | Duration: None
| Funding: North East Thames Regional Health Authority, East Anglia Regional Health Authority, South East Thames Regional Health Authority, The Care Foundation, Tunbridge Wells, the Stanley Luff Bequest Fund | Race: Not reported | Withdrawals: 75
| | Gender: Not reported
Evangelista, 2002 ^13^ | Design: Prospective Cohort | Sample size: 103 CG/PT dyads | Exposure: Once | Results: Caregivers were predominantly female (71%) and spouses of patients with HF (83%). Patients had significantly lower (poorer) emotional well-being scores than caregivers. Both gender and age were associated with patients' emotional well-being; male and younger respondents had higher (better) scores than female and older patients (P<.05). Patient's age, gender, and caregivers' emotional well-being accounted for 54% of the variance in patients' emotional well-being. Findings suggest that caregiver emotional well-being is associated with HF patient well-being. A focus on supporting caregivers and providing them with methods to support their loved ones would be beneficial to patients.
| Quality: Good | Disease: Single disease: Cardiovascular Disease | Outcomes: Emotional well-being.
| Setting: Home | Severity: Advanced | Duration: None
| Funding: American Heart Association Western Division and the UCSF School of Nursing | Race: White (77%), Black (6%), Other (17%) | Withdrawals: Not reported
| | Gender: Males and females
Covinsky, 1994 ^14^ | Design: Prospective Cohort | Sample size: N=2,129 caregivers | Exposure: Baseline, 2 months, 6 months | Results: One third (34%) of patients required considerable caregiving assistance from a family member. In 20% of cases, a family member had to quit work or make another major life change to provide care for the patient. Loss of most or all of the family savings was reported by 31% of families, whereas 29% reported the loss of the major source of income. Patient factors independently associated with loss of the family's savings included poor functional status (OR 1.40; 95% CI 1.10 to 1.78), lower family income (OR 1.74; 95% CI 1.37 to 2.21 for those with annual incomes below $25,000_, and young age (OR, 2.85; 95% CI 2.13 to 3.82 for those younger than 45 years of age compared to those 65 or older). Families of younger, poorer, and more functionally dependent patients are the most likely to report loss of most or all of the family's savings to a serious or fatal illness.
| Quality: Good | Disease: Mixed Disease | Outcomes: Frequency of adverse caregiving and economic burdens, patient functional status.
| Setting: Hospital (ICU & non ICU) | Severity: Advanced | Duration: 6 months
| Funding: RWJ | Race: White (81%), Black (16%), Other (3%) | Withdrawals: Not reported
| | Gender: Males and females
Brazil, 2003 ^15^ | Design: Interview Survey | Sample size: N=151 caregivers | Exposure: Once | Results: The majority of respondents were the female spouses (79%) of the patient. The numbers of caregivers providing assistance in specific functional activities were: bathing (88%); mobility 81%); dressing and undressing (76%); TOILETING (67%); and assistance at night (64%). 41% reported that they had been providing some form of care for over 1 year. CGs reported that physical demands in caregiving increased substantially during the last three months of the care recipient's life. As family caregivers provided more assistance in ADLs, they were at greater risk of reporting high caregiver burden.
| Quality: Fair | Disease: Predominately one disease: Cancer | Outcomes: Physical restrictions, need for assistance, CG burden.
| Setting: Home, nursing home, hospital (ICU) and nursing home | Severity: Advanced | Duration: None
| Funding: N/R | Race: Not reported | Withdrawals: Not reported
| | Gender: Males and females
Emanuel, 2000 ^16^ | Design: Interview Survey | Sample size: 988 terminally ill patients and 893 caregivers in 6 randomly selected areas of the US. 59% were over the age of 65 years and 51.5% were women (cancer 52%, heart disease-18%, and chronic obstructive pulmonary disease-11%). 4% were in a nursing home, hos | Exposure: Once | Results: 35% of the sample had substantial care needs and that those with substantial care needs were more likely to report that they had a subjective sense of economic burden (44.9% vs. 35.3%; difference 9.6 percentage points [95% CI, 3.1 to 16.1]; P=0.005). In addition, 10% of these families household income was spent on health care (28% vs. 17%; difference, 11 percentage points [CI 4.8 to 17.1]; P<0.001) and that they or their families had to take out a loan or mortgage spend their savings, or obtain an additional job (16.3% vs. 10.2%; difference, 6.1 percentage points [CI 1.4 to 10.6]; P=0.004). Patients with substantial care needs were more likely to consider euthanasia or physician-assisted suicide (P=0.001). Caregivers of thee patients were more likely to have depressive symptoms (P=0.01) and to report that caring for the patients interfered with their lives (P=0.001). Caregivers of patients whose physicians listened to patients' and caregivers' needs had fewer burdens.
| Quality: Good | Disease: Mixed Disease | Outcomes: Economic and non-economic burdens of caregiving.
| Setting: Home, nursing home, hospital (ICU) and hospice | Severity: Advanced | Duration: None
| Funding: Commonwealth Fund & Nathan Cummings Foundation | Race: White (79%), Black (14%), Hispanic (3%), Other (4%) | Withdrawals: Not reported
| | Gender: Not reported
Markowitz, 2003 ^17^ | Design: Interview Survey | Sample size: 2,477 dementia caregivers | Exposure: Once | Results: Compared with a normative, age-adjusted sample, the dementia caregivers had lower mental and physical scores (for the latter, only those 54 years of age or older). Increased caregiver mental functioning was associated with caregiver support and perceived quality of patient medical care, fewer hus of caregiving, and fewer patient behavioral symptoms.
| Quality: Good | Disease: Single disease: Alzheimer's Disease | Outcomes: Health related quality of life, difficulty of caregiving, patient functioning level, IADLs, health care use.
| Setting: Nursing home and home | Severity: Advanced and moderate | Duration: None
| Funding: Janssen Pharmaceutica Products, L.P. | Race: Not reported | Withdrawals: Not reported
| | Gender: Males and females
Steinhauser, 2000 ^18^ | Design: Telephone Survey | Sample size: N=1,462 (340 seriously ill patients, 332 recently bereaved family members, 361 physicians and 429 other health care providers = nurses, social workers, chaplains, and hospice volunteers) | Exposure: Once | Results: Twenty-six items consistently were rated as being important by greater than 70% of respondents, including pain and symptom management, preparation for death, achieving a sense of completion, decisions about treatment preferences, and being treated as a “whole person.” Additionally, respondents expressed a strong preference for human development at the end of life. Results also highlighted differences among the respondent groups. Eight items received strong endorsement from patients but less from physicians (P<.001), including being mentally aware, having funeral arrangements planned, not being a burden, helping others, and coming to peace with God. Ten items had broad variation within as well as among the 4 groups, including decisions about life-sustaining treatments, dying at home, and talking about the meaning of death. Participants ranked freedom from pain most important and dying at home least important among 9 major attributes. Thus, although pain and symptom management, communication with one's physician, preparation for death, and the opportunity to achieve a sense of completion are important to most, other factors important to quality at the end of life differ by role and by individual.
| Quality: Good | Disease: Other: | Outcomes: End of Life factors considered important by patients, families, physicians and other health care providers.
| Setting: Hospital (ICU and non-ICU) | Severity: Other | Duration: None
| Funding: VA Health Services Research and Development award | Race: White (82%), African American (7.4%), Asian American (3.6%), Latino (2.2%), Native American (3.4%), Other (1.9%) | Withdrawals: Not reported
| | Gender: Males and females

I = Intervention group, C = Control group, RCT/CCT = Randomized Controlled Trial/Clinical Controlled Trial, ICU = Intensive Care Unit, CPR = Cardiopulmonary Resuscitation, RN = Registered Nurse, DNR = Do Not Resuscitate, outpt = Outpatient, AD = Advance Directive, MD = Physician, ACP = Advance Care Planning, AD/DPA = Advance Directive/Durable Power of Attorney,HRQoL = Health Related Quality of Life, T = Treatment group, DPA = Durable Power of Attorney

Evidence table 3. OS Satisfaction Evidence Table

First Author Year ID | Study Characteristics | Population | Exposure, Outcomes | Results
| | | Duration, Dropouts
Baker, 2000 ^1^ | Design: Prospective Cohort | Sample size: 726 | Exposure: pain, disease category, functional status, use of life sustaining treatment, circumstances of death | Results: Gender of surrogate (male) associated with lower and death and intervention status associated with higher satisfaction with comfort. Not following preferences, and great and moderate impact on family finances associated with lower satisfaction with communication.
| Quality: Good | Disease: Mixed Disease | Outcomes: Satisfaction with communication and comfort
| Setting: Hospital (ICU and non-ICU) | Severity: Advanced | pain, disease category, functional status, use of life sustaining treatment, circumstances of death.
| Funding: RWJF | Race: White, non-white | Duration: up to 6 months
| | Gender: Males and females | Withdrawals: 216 / 983 deaths
Correa-Velez, 2003 ^2^ | Design: Prospective Cohort | Sample size: 111 | Exposure: physical symptoms, psychological symptoms, satisfaction with conventional medical care, | Results: Complementary and alternative medicine (CAM) use was associated with lower satisfaction with conventional medical (e.g. oncology) care, non-users of CAM were even more dissatisfied in last 3 months of life.
| Quality: Good | Disease: Single disease: Cancer | Outcomes: Physical symptoms, psychological symptoms, satisfaction with conventional medical care, complementary and alternative medicine (CAM) use.
| Setting: Ambulatory/outpt medical care | Severity: Advanced | Duration: 12 months
| Funding: National Health and Medical Research Council #991215 | Race: Not reported | Withdrawals: 11/111 too ill to participate in longitudinal phase
| | Gender: Not reported
Curtisa, 1999 ^3^ | Design: Prospective Cohort | Sample size: 57 | Exposure: degree of MD-patient communication about end of life care | Results: Lower income patients noted lower quality of communication, higher quality of communication associated with higher overall satisfaction with care.
| Quality: Good | Disease: Single disease: AIDS | Outcomes: Presence and quality of patient-physician communication about end of life care, preferences for life-sustaining treatment, satisfaction with care.
| Setting: Ambulatory/outpt medical care | Severity: Advanced | Duration: 6 months
| Funding: University of Washington Intramural funds | Race: Not reported | Withdrawals: 5 / 57 (baseline only)
| | Gender: Not reported
Fakhoury, 1996 ^4^ | Design: Retrospective cohort | Sample size: 1858 | Exposure: service characteristics of end of life care | Results: High level of satisfaction for nurses, GP's, and hospital MDs noted. Stepwise procedures used to select from expansive regressor set.
| Quality: N/A | Disease: Single disease: Cancer | Outcomes: satisfaction with district nurse, general practitioner, and hospital physician care
| Setting: Unclear | Severity: Advanced | multiple sociodemographic, informal caregiver, and service characteristics.
| Funding: Hariri Foundation, ORS award, UK regional health authorities, Care Foundation Tunbridge Wells | Race: White, non-white | Duration: N/A
| | Gender: Males and females | Withdrawals: N/A
Fakhoury, 1997 ^5^ | Design: Retrospective cohort | Sample size: 1858 | Exposure: service characteristics of end of life care | Results: Owner-occupiers, older patients, spouses vs non spouses, those with short duration of several symptoms somewhat higher satisfaction measures. Multiple comparisons.
| Quality: N/A | Disease: Single disease: Cancer | Outcomes: Satisfaction with district nurse, general practitioner, and hospital physician care
| Setting: Unclear | Severity: Advanced | multiple sociodemographic, informal caregiver, and service characteristics.
| Funding: Hariri Foundation, ORS award, UK regional health authorities, Care Foundation Tunbridge Wells | Race: White, non-white | Duration: N/A
| | Gender: Males and females | Withdrawals: N/A
Fisher, 2003 ^6^ | Design: Retrospective cohort secondary data analysis | Sample size: ~1,000,000 | Exposure: Clinical and demographic characteristics, End of Life Exposure Index (EOL-EI) | Results: Higher spending at the end of life not associated with reducted mortality, improved functional status, or greater satisfaction with care in any cohort.
| Quality: N/A | Disease: Predominately one disease: 3 cohorts (hip fracture, colorectal cancer, acute myocardial infarction) | Outcomes: Mortality, functional status change, and satisfaction with care.
| Setting: Unclear | Severity: Advanced | Duration: N/A
| Funding: RWJF, NIH CA52192, NIA 1PO1 AG19783-01 | Race: Not reported | Withdrawals: N/A
| | Gender: Not reported
Heyland, 2003 ^7^ | Design: Prospective Cohort | Sample size: 256 | Exposure: overall experience related to death of a loved one, communication | Results: Higher percieved courtesy and compassion, satisfaction with overall level of care, completeness of information provided were all associated with higher overall satisfaction with ICU care.
| Quality: Good | Disease: Mixed Disease | Outcomes: Overall death experience, communication, overall satisfaction.
| Setting: Hospital (ICU) | Severity: Advanced | Duration: 4 weeks
| Funding: Canadian ICU Foundation, Queen Elizabeth II Hleath Sciences Center Research Foundation. | Race: N/A | Withdrawals: 256 / 413 responded
| | Gender: Not reported
Higginson, 2002 ^8^ | Design: Prospective Cohort | Sample size: 1326 | Exposure: enrollment in palliative care service | Results: No gender differences in communication (trend toward lower difficulties in professional / pt / family communication among women, but not significant (p=0.09)), nor differences in interprofessional or professional / pt / family communication by site of death were observed.
| Quality: Good | Disease: Mixed Disease | Outcomes: Quality of life including communication.
| Setting: Hospice | Severity: Advanced | Duration: median, approximately 30 days
| Funding: European Commission, International Union Against Cancer for the International Cancer Fellowship | Race: N/A | Withdrawals: Not reported
| | Gender: Males and females
Kristjanson, 1997 ^9^ | Design: Cross sectional cohort | Sample size: 72 | Exposure: family expectations and functioning | Results: Satisfaction differed by geographic province, higher among younger families, discrepancy score between expectations and perception of care was significantly related to satisfaction, site of care unrelated.
| Quality: N/A | Disease: Mixed Disease | Outcomes: Family care expectations, family functioning, satisfaction.
| Setting: Home health care and hospice | Severity: Advanced | Duration: N/A
| Funding: NCI Canada, Manitoba Health Research Council | Race: N/A | Withdrawals: 72 / 82 responded
| | Gender: Not reported
Larsson, 2004 ^10^ | Design: Cross sectional cohort | Sample size: 67 | Exposure: gender, age, and status (spouse, child, other) of family member, frequency of contact | Results: Family members with more frequent contact both perceived better care and rated the perceived importance of those aspects of care to the patient's wellbeing higher than family members with less frequent contact.
| Quality: N/A | Disease: Unclear | Outcomes: Patient and family perceptions of care.
| Setting: Home health care | Severity: Advanced | Duration: N/A
| Funding: Not reported | Race: N/A | Withdrawals: 67 / 100 responded
| | Gender: Not reported
Malacrida, 1998 ^11^ | Design: Retrospective cohort | Sample size: 123 | Exposure: quality of the ICU experience | Results: Multiple bivariate comparisons up to eight years after death.
| Quality: N/A | Disease: Mixed Disease | Outcomes: Family members perceptions of care delivered in the ICU.
| Setting: Hospital (ICU) | Severity: Advanced | Duration: N/A
| Funding: 125th Jubileum Basle Insurance Company | Race: N/A | Withdrawals: 123 / 390 respondents
| | Gender: Males and females
Sulmasy, 2002 ^12^ | Design: Cross sectional cohort | Sample size: 84 | Exposure: pain, depression, nature of nursing and physician care | Results: Only +DNR status, house-staff vs. private physician service status, and depression significant in multivariate models. All were associated with lower satisfaction with physician and nursing care.
| Quality: N/A | Disease: Mixed Disease | Outcomes: Symptoms severity, anxiety and depression, perceptions and satisfaction with physicians and nurses.
| Setting: Hospital (non ICU) | Severity: Advanced | Duration: N/A
| Funding: Altman Foundation | Race: White, non-white | Withdrawals: 110 /367 refused
| | Gender: Males and females | 84 / 88 remaining eligibles for current survey.
Teno, 2004 ^13^ | Design: Retrospective cohort | Sample size: 1578 | Exposure: services and setting of care at the end of life | Results: Death in home hospice associated with improved satisfaction by all unadjusted measures, and improved emotional support, family emotional support, perceptions of treating patient respectfully, and overall quality compared to home care, nursing home, and hospital dying. Inadequate physician involvement, coordination noted in hospital and nursing home settings in particular.
| Quality: N/A | Disease: Mixed Disease | Outcomes: Family perceptions of end of life care.
| Setting: Hospice, nursing home and Hospital | Severity: Advanced | Duration: N/A
| Funding: RWJF | Race: Not reported | Withdrawals: 1578 / 3275 deaths
| | Gender: Not reported
Tierney, 1998 ^14^ | Design: Prospective Cohort | Sample size: 42 (26 witth 2 measurements) | Exposure: inpatient hospice treatment | Results: Higher satisfaction highly correlated with better quality of life on admission, and also with better symptom control at follow-up.
| Quality: Good | Disease: Mixed Disease | Outcomes: Satisfaction, quality of life, symptoms.
| Setting: Hospital (non ICU) | Severity: Advanced | Duration: 3–4 days
| Funding: AHRQ (RO1 - HS07632, 07763, 09083 | Race: Not reported | Withdrawals: 16/42 (baseline only)
| | Gender: Not reported
Tolle, 2000 ^15^ | Design: Retrospective cohort | Sample size: 475 | Exposure: services and setting of care at the end of life | Results: Transfers in care settings associated with respecting treatment preferences, pain management. Neither advance care planning and respect for treatment preferences, nor satisfaction with support from clinicians differed by setting of care. Report of pain comparable to Teno et.al., worse in hospital. Most difficulties in management of pain associated with home death. Difficulties with respect for treatment preferences and support from clinicians associated wtih worse pain management.
| Quality: N/A | Disease: Mixed Disease | Outcomes: Family perceptions of end of life care
| Setting: Hospice, nursing home and Hospital | Severity: Advanced | Duration: N/A
| Funding: Proejct on Death in American, Meyer Memorial Trust, RWJF, Nathan Cummings Foundation | Race: Not reported | Withdrawals: 475 / 1,458 deaths
| | Gender: Not reported
Volicer, 2001 ^16^ | Design: Retrospective cohort | Sample size: 156 | Exposure: services and setting of care at the end of life | Results: Unclear sampling frame. Symptom scale and comfort scales modestly (~0.30) correlated with scale assessing aspects of health care and decision making.
| Quality: N/A | Disease: Single disease: Dementia | Outcomes: Family perceptions of end of life care.
| Setting: Unclear | Severity: Advanced | Duration: N/A
| Funding: Alzheimer's Association, USPHS P30 AG13846 | Race: Not reported | Withdrawals: 156 / 572 surveys returned
| | Gender: Not reported
Zhukovsky, 1995 ^17^ | Design: Cross sectional cohort | Sample size: 101 | Exposure: pain and physician management of pain | Results: Worse pain, belief that physician not adequately concerned about pain, and desire for more control in pain regimen associated with dissatisfaction with pain management.
| Quality: N/A | Disease: Single disease: Cancer | Outcomes: Pain, satisfaction with pain control.
| Setting: Hospital (non ICU) | Severity: Unclear | Duration: N/A
| Funding: Not reported | Race: Not reported | Withdrawals: 101 / 171 approached
| | Gender: Not reported
Dawson, 1991 ^18^ | Design: Retrospective cohort | Sample size: 100 | Exposure: site of care and death | Results: Hospice users who died at home more satisfied by all measures than hospice users who died in other settings or non-hospice users who died in hospital.
| Quality: N/A | Disease: Unclear | Outcomes: Emotional needs of patient and family, satisfaction with psycho-social support of nurse caregivers, overall satisfaction with medical care.
| Setting: Home health care, hospice and hospital | Severity: Advanced | Duration: N/A
| Funding: Not reported | Race: Not reported | Withdrawals: 100 / 179 surveys returned
| | Gender: Not reported
Jacoby, 1999 ^19^ | Design: Retrospective cohort | Sample size: 156 | Exposure: service quality and site of care | Results: Satisfaction with different practitioners and settings of care correlated with perceived efforts to relieve symptoms and communication.
| Quality: N/A | Disease: Unclear | Outcomes: Family perceptions of end of life care.
| Setting: Hospice, nursing home and Hospital | Severity: Advanced | Duration: N/A
| Funding: Not reported | Race: Not reported | Withdrawals: 156 / 355 surveys returned
| | Gender: Not reported
Kane, 2002 ^20^ | Design: Cross sectional cohort | Sample size: 1161 | Exposure: Wisconsin Partnership Program participation | Results: WPP participants demonstrated much higher levels of advance care planning and preference for limiting care compared with in-area controls.Satisfaction with care was largely no different, although in-area and out-of-area controls were more likely to report that their doctor treats them with respect, and that their care is well coordinated. Few to no differences in care-giving burden.
| Quality: N/A | Disease: Mixed Disease | Outcomes: Functional status, caregiver burden, advance directives, service attributes and satisfaction.
| Setting: Ambulatory/outpt medical care | Severity: Moderate | Duration: N/A
| Funding: HCFA #500-96-0008 | Race: Not reported | Withdrawals: 1161 / 1372
| | Gender: Not reported
Steinhauser, 2000 ^21^ | Design: Cross sectional cohort | Sample size: 1462 | Exposure: N/A | Results: Areas of concordance and discordance identified in the relative importance of 44 items related to symptoms or personal care, preparation for end of life, achieving a sense of completion, care planning, being treated as a ‘whole person’, and relationships with health professionals as noted by patients, physicians, family, and other providers. Race / gender, religiousness / spirituality, and relationship to deceased all related to various items or groups of items.
| Quality: N/A | Disease: Mixed Disease | Outcomes: Ratings of attributes of experiences at the end of life.
| Setting: Unclear | Severity: Advanced | Duration: N/A
| Funding: VA HSR&D IIR 96-066 | Race: White, African-American, Asian-American, Latino, Native American, Other | Withdrawals: 1462 / 2000
| | Gender: Males and females

I = Intervention group, C = Control group, RCT/CCT = Randomized Controlled Trial/Clinical Controlled Trial, ICU = Intensive Care Unit, CPR = Cardiopulmonary Resuscitation, RN = Registered Nurse, DNR = Do Not Resuscitate, outpt = Outpatient, AD = Advance Directive, MD = Physician, ACP = Advance Care Planning, AD/DPA = Advance Directive/Durable Power of Attorney,HRQoL = Health Related Quality of Life, T = Treatment group, DPA = Durable Power of Attorney

Evidence table 4. OS Symptoms Evidence Table

First Author Year ID | Study Characteristics | Population | Exposure, Outcomes | Results
| | | Duration, Dropouts
Desbiens, 1998 ^1^ | Design: Prospective Cohort | Sample size: 9105 | Exposure: Hospitalization | Results: Preference of care does not affect patients' overall pain experience in later stages of disease.
| Quality: Good | Disease: Mixed Disease | Outcomes: Pain, preferences of care
| Setting: Hospital (non ICU) | Severity: Advanced | Duration: 10 days
| Funding: Robert Wood Johnson Foundation | Race: Not reported | Withdrawals: 6437
| | Gender: Not reported
Gagnon, 2000 ^2^ | Design: Prospective Cohort | Sample size: 94 | Exposure: Delirium | Results: Delirium as an outcome may not be as poor as previously considered in cancer.
| Quality: Fair | Disease: Single disease: Cancer | Outcomes: Delirium
| Setting: Hospital (non ICU) | Severity: Advanced | Duration: Not reported
| Funding: NCI of Canada | Race: Not reported | Withdrawals: 5
| | Gender: Not reported
Goodwin, 2003 ^3^ | Design: Prospective Cohort | Sample size: 173 | Exposure: Palliative Day Care | Results: Palliative day care was not found to improve health related quality of life relative to usual care.
| Quality: Good | Disease: Mixed Disease | Outcomes: Pain, symptom control, palliative day care, QOL
| Setting: Ambulatory/outpt medical care | Severity: Advanced | Duration: 18 weeks
| Funding: London Region NHS Research and Development Program | Race: Not reported | Withdrawals: 56
| | Gender: Not reported
Lammi, 2001 ^4^ | Design: Prospective Cohort | Sample size: 100 | Exposure: Palliative care | Results: Awaresness of the multidimensional needs of hospice patients in primary health care centers is needed.
| Quality: Fair | Disease: Single disease: Cancer | Outcomes: Anxiety, depression
| Setting: Hospice | Severity: Advanced | Duration: >180 days
| Funding: Europe Against Cancer Program of the European Union | Race: Not reported | Withdrawals: 28
| | Gender: Not reported
van der Steen, 2002 ^5^ | Design: Prospective Cohort | Sample size: 706 | Exposure: Antibiotic treatment for pneumonia | Results: Level of comfort is generally higher in demented patients who are not receiving antibiotics.
| Quality: Fair | Disease: Unclear | Outcomes: Discomfort associated with pneumonia
| Setting: Nursing home | Severity: Advanced | Duration: 3 months
| Funding: Dutch Ministry of Public Health | Race: Not reported | Withdrawals: 44
| | Gender: Not reported
de Wit, 1999 ^6^ | Design: Prospective Cohort | Sample size: 383 | Exposure: Pain treatment | Results: Structural resoruces were not the major cause of suboptimal pain management rather, the major cause was the process component.
| Quality: Good | Disease: Single disease: Cancer | Outcomes: Pain management
| Setting: Hospital (non ICU) | Severity: Advanced | Duration: 20 months
| Funding: Ducth Cancer Society | Race: Not reported | Withdrawals: 77
| | Gender: Not reported
Friedman, 2001 ^7^ | Design: Prospective Cohort | Sample size: 212 | Exposure: Depression | Results: High levels of physical symptoms and poor functioning patients reported higher levels of depression.
| Quality: Good | Disease: Single disease: CHF | Outcomes: Physical symptoms, functioning, depression
| Setting: Hospital (non ICU) | Severity: Advanced | Duration: 6 weeks
| Funding: American Heart Association | Race: Not reported | Withdrawals: 142
| | Gender: Not reported
Fulop, 2003 ^8^ | Design: Prospective Cohort | Sample size: 263 | Exposure: Depression | Results: High prevalence of depression in CHF patients at discharge depressed patients utilized more medical services.
| Quality: Good | Disease: Single disease: CHF | Outcomes: Hospitalization, health services utilization
| Setting: Hospital (non ICU) | Severity: Advanced | Duration: 6 months
| Funding: NIMH Grant | Race: Not reported | Withdrawals: 42
| | Gender: Not reported
Goldberg, 1997 ^9^ | Design: Prospective Cohort | Sample size: 109 | Exposure: Risperidone | Results: Risperidone was well tolerated overall among nursing home residents and deemed helpful in 38% of sample, moderately helpful in 26% of sample, slightly helpful in 17% of sample and not helpful in 19% of sample.
| Quality: Fair | Disease: Single disease: Dementia | Outcomes: Dementia-related bahavioral disturbances
| Setting: Nursing home | Severity: Unclear | Duration: 6 months
| Funding: Not reported | Race: Not reported | Withdrawals: 46
| | Gender: Not reported
Payne, 2002 ^10^ | Design: Prospective Cohort | Sample size: 201 | Exposure: Depression | Results: Incidence and prevalence of dementia is high in long term care facility residents incidence of depression seems to decrease within a year of admission is appropriate diagnosis and treatment were initiated.
| Quality: Good | Disease: Single disease: Dementia | Outcomes: Depression
| Setting: Nursing home | Severity: Advanced | Duration: One year
| Funding: R-01 The depression in Alzheimer Disease Study | Race: Not reported | Withdrawals: Not reported
| | Gender: Not reported
Rumsfeld, 2003 ^11^ | Design: Prospective Cohort | Sample size: 460 | Exposure: Depression | Results: Depressive symptoms are strong predictors of short term worsening HF specific health status.
| Quality: Good | Disease: Single disease: CHF | Outcomes: Heart failure health status
| Setting: Hospital (non ICU) | Severity: Advanced | Duration: 6 weeks
| Funding: Pharmacia Corporation | Race: Not reported | Withdrawals: Not reported
| | Gender: Not reported
Keene, 2002 ^12^ | Design: Prospective Cohort | Sample size: 100 | Exposure: Behavioral symptoms | Results: Family members might benefit from prognostic information in terms of caregiving concerns.
| Quality: Good | Disease: Single disease: Dementia | Outcomes: Symptom experience, behavior, causes of death
| Setting: Home health care | Severity: Advanced | Duration: 11 years
| Funding: Medical Research Council, Eli Lilly | Race: Not reported | Withdrawals: 9
| | Gender: Not reported
Jiang, 2002 ^13^ | Design: Prospective Cohort | Sample size: 374 | Exposure: Depression | Results: Major depression common in hospitalized patients and is associated with poor prognosis.
| Quality: Good | Disease: Single disease: CHF | Outcomes: Depression, mortality, re-hospitalization
| Setting: Hospital (non ICU) | Severity: Advanced | Duration: One year
| Funding: National Institute of Aging | Race: Not reported | Withdrawals: 43
| | Gender: Not reported
Breitbart, 2002 ^14^ | Design: Prospective Cohort | Sample size: 83 | Exposure: Olanzapine | Results: Olanzapine effective and safe for treatment of delirium in cancer patients.
| Quality: Fair | Disease: Single disease: Cancer | Outcomes: Delirium
| Setting: Hospital (non ICU) | Severity: Advanced | Duration: 7 days
| Funding: Not reported | Race: Not reported | Withdrawals: 4
| | Gender: Not reported

I = Intervention group, C = Control group, RCT/CCT = Randomized Controlled Trial/Clinical Controlled Trial, ICU = Intensive Care Unit, CPR = Cardiopulmonary Resuscitation, RN = Registered Nurse, DNR = Do Not Resuscitate, outpt = Outpatient, AD = Advance Directive, MD = Physician, ACP = Advance Care Planning, AD/DPA = Advance Directive/Durable Power of Attorney,HRQoL = Health Related Quality of Life, T = Treatment group, DPA = Durable Power of Attorney

Evidence table 5. OS Advance Care Planning

First Author Year ID | Study Characteristics | Population | Exposure, Outcomes | Results
| | | Duration, Dropouts
Curtis, 1999 ^1^ | Design: Prospective Cohort | Sample size: 57 | Exposure: Initial interview. | Results: Occurrence of concordance on the presence of a LW associated with EOL communication. Better communication with higher patient income and non-Hispanic whites.
| Quality: Good | Disease: Single disease: AIDS | Outcomes: Quality of patient-clinician communication about EOL care.
| Setting: Not reported | Severity: Moderate | Duration: 6 months
| Funding: 1) Pickner/ Commonwealth Scholars Program, 2) University of Washington Royalty Research Fund, 3) University of Washington Center for AIDS Research | Race: Not reported | Withdrawals: 4 pts.
| | Gender: Not reported
Curtis, 2000 ^2^ | Design: Prospective Cohort | Sample size: 57 | Exposure: One-time. | Results: Patients identified barriers associated with EOL education, EOL counseling, health care system changes. Clinicians identified more barriers than patients. Nonwhite patients reported more barriers: fear of talking about death and its impact on available care and unwillingness to talk about future health status.
| Quality: Fair | Disease: Single disease: AIDS | Outcomes: Barriers and facilitators of patient-clinician communication about EOL.
| Setting: Ambulatory/outpt medical care | Severity: Moderate | Duration: Unclear
| Funding: 1) Project on Death in America, 2) Parker B. Francis Fellowship Program, 3) University of Washington Royalty Research Fund | Race: Not reported | Withdrawals: Not reported
| | Gender: Males and females
Golin, 2000 ^3^ | Design: Prospective Cohort | Sample size: 1288 | Exposure: Pts enrolled in SUPPORT. | Results: 30% of pts communicated resuscitation preferences to physicians. Pts wanting to forgo CPR and whose preferences changed from desiring to forge CPR were more likely to communicate their preference than pts who continued to prefer to receive CPR. 50% of pts maintain preference to forgo CPR communicated their preferences over the study period. Having an AD and remaining in hospital associated with communication.
| Quality: Good | Disease: Mixed disease: Cancer, Chronic disease | Outcomes: Communication of pts resuscitation preferences with their physicians.
| Setting: Hospital (ICU & non ICU) | Severity: Advanced | Duration: 2 month follow up
| Funding: RWJ (SUPPORT) | Race: Black, Other | Withdrawals: Not reported
| | Gender: Males
Higginson, 2002 ^4^ | Design: Prospective Cohort | Sample size: 1326 | Exposure: Time between first visit and death. | Results: 40% of EOL patients had severe communication. Communication problems associated with respiratory & breast cancers, shorter time in care, and hospice death.
| Quality: Good | Disease: Single disease: Cancer (Digestive, Respiratory, Breast, Genitourinary, Other) | Outcomes: Responsiveness to clinically important changes, correlation with other measures, correlation between patient self-assessment, family assessment, and team assessment.
| Setting: Hospice and Home | Severity: Advanced | Duration: Data collected over a 6-month period
| Funding: 1) European Commission & 2) International Union Against Cancer for the International Cancer Fellowship | Race: Not reported | Withdrawals: Not reported
| | Gender: Males and females
Lockhart, 2001 ^5^ | Design: Prospective Cohort | Sample size: 50 | Exposure: Initial interview - pts asked to imagine 7 different states. | Results: Moderate stability in ratings of state that were better or worse than death.
| Quality: Fair | Disease: 8: | Outcomes: Participant rating of 7 states better/worse than death.
| Setting: Community | Severity: Unclear | Duration: Sub sample of 50 participants re-contacted, 5–16 months, asked same questions
| Funding: AHRQ-HS08180 | Race: Not reported | Withdrawals: 0
| | Gender: Not reported
Rose, 2000 ^6^ | Design: Prospective Cohort | Sample size: 642 | Exposure: Beginning of SUPPORT. | Results: Generalists more pessimistic than specialists in prognostication. Similar LOS, discharge with supportive care, and hosp. readmission. Proportionally, more hospital deaths with generalists.
| Quality: Good | Disease: Single disease: Cancer | Outcomes: Compare 844 oncologist pts. to 449 generalist pts.
| Setting: Hospital (ICU & non ICU) | Severity: Advanced | Duration: 6 months or pt. death
| Funding: RWJF (SUPPORT) | Race: Not reported | Withdrawals: Not reported
| | Gender: Not reported
Tierney, 2001 ^7^ | Design: Prospective Cohort | Sample size: 686 | Exposure: Pt. visit when physician received computer reminder - part of the Dexter RCT. | Results: Discussing advance directives associated with greater satisfaction with primary care physician. Elderly, chronically ill patients are more satisfied when they discuss ADs with their primary care physician.
| Quality: Good | Disease: Mixed Disease | Outcomes: Level of patient satisfaction.
| Setting: Ambulatory/outpt medical care | Severity: Unclear | Duration: Interview in waiting room following visit
| Funding: AHRQ Grant-Ro1-HS07632 | Race: African American | Withdrawals: 74
| | Gender: Males
Weeks, 1998 ^8^ | Design: Prospective Cohort | Sample size: 917 | Exposure: Pts enrolled in SUPPORT. | Results: Pts estimating at least 6-month survival favored life-extending therapy over comfort care. Pts overestimated survival time.
| Quality: Good | Disease: Predominately one disease: Lung cancer or colon cancer metastatic to liver | Outcomes: Relationship between pts prognostic estimates and their treatment preferences.
| Setting: Hospital (non ICU) | Severity: Advanced | Duration: After enrollment in SUPPORT
| Funding: 1) RWJF (SUPPORT) & 2) American Society of Clinical Oncology | Race: Not reported | Withdrawals: Not reported
| | Gender: Not reported
Wenger, 2000 ^9^ | Design: Prospective Cohort | Sample size: 5055 | Exposure: Pts enrolled in SUPPORT. | Results: Physicians did not know of pts CPR preferences.
| Quality: Good | Disease: Not reported | Outcomes: Physician understanding of pts CPR preferences.
| Setting: Hospital (ICU & non ICU) | Severity: Advanced | Duration: Between second to sixth day after study enrollment
| Funding: RWJF (SUPPORT)+C191 | Race: White | Withdrawals: Not reported
| | Gender: Males
McCarthy, 1997 ^10^ | Design: Prospective Cohort | Sample size: 600 | Exposure: Pt Death. | Results: Despite recognizing they were going to die, clinical staff rarely discussed the pts. Likelihood of death. Lack of discussion with pt on preferred place of death.
| Quality: Good | Disease: Single disease: Heart disease | Outcomes: Information about illness, knowledge of prognosis, learning about dying, support in dying, place of death, and timing of death.
| Setting: Unclear | Severity: Advanced | Duration: Follow-up with spouse, another relative, friend or neighbor, or formal carers.
| Funding: 1) North East Thames, South East Thames, and East Anglia Regional Health Authorities, 2) South East Thames Regional Health Authority, 3) Care Foundation Tunbridge Wells, 4) Stanley Luff Bequest Found, 5) Other participating districts | Race: Not reported | Withdrawals: Not reported
| | Gender: Males and females
Townsend, 1990 ^11^ | Design: Prospective Cohort | Sample size: 100 | Exposure: Cancer pts expected to live less than 1 year. | Results: Pts knew diagnosis and prognosis. Most pts admitted for investigation or treatment, but often stayed for respite and symptom control. 63% of pts who died in hospital, would prefer to die at home.
| Quality: Good | Disease: Single disease: Cancer | Outcomes: Place of death, care before death.
| Setting: Hospital (non-ICU) and community | Severity: Advanced | Duration: Pts interviewed at 2 week intervals if expected to live less than 2 months
| Funding: 1) Harrow Health Authority & 2) Rehabilitation Research Fund | Race: Not reported | Withdrawals: 34
| | Gender: Not reported
Danis, 1991 ^12^ | Design: Prospective Cohort | Sample size: 244 | Exposure: Pts. With short life expectancy due to end-stage heart, lung, or liver disease, metastic cancer, or lymphoma. | Results: Majority of pts wanted to receive life-sustaining treatment to prolong life. Chemotherapy and intensive are were the most frequent treatments. CPR and mechanical ventilation were the most frequently withheld. Pts decising life-sustaining treatment to prolong life were no more likely to receive treatments than pts who desired limited treatment.
| Quality: Good | Disease: Mixed Disease | Outcomes: Life-sustaining treatment utilization & cost of hospital care.
| Setting: Hospital (non ICU) | Severity: Advanced | Duration: Followed for 6 months
| Funding: AHRQ - HS06655 | Race: White, Black | Withdrawals: 258
| | Gender: Males and females
Hakim, 1996 ^13^ | Design: Prospective Cohort | Sample size: 8836 | Exposure: Pts enrolled in SUPPORT. | Results: DNR orders written earlier for pts older than 75 years of age, regardless of prognosis. Pt preferences associated with timing of DNR orders.
| Quality: Good | Disease: Mixed Disease | Outcomes: Association between pts resuscitation preferences and frequency and timing of DNR orders.
| Setting: Hospital (ICU & non ICU) | Severity: Advanced | Duration: Third day after study enrollment
| Funding: RWJF (SUPPORT)+C210 | Race: Not reported | Withdrawals: Not reported
| | Gender: Not reported
Junod Perron, 2002 ^14^ | Design: Prospective Cohort | Sample size: 255 | Exposure: Pts who stayed more than 24 hours in hospital, and were provided with a DNR order. | Results: Quality of life was considered in more than 70% of DNR decisions. Physicians underrate their DNR pts. quality of life. Severe depression, social isolation and physical dependence negatively influenced patient's perception of their quality of life.
| Quality: Good | Disease: Predominately one disease: Cancer (Metastatic) Cardiac disease, Other | Outcomes: Agreement between physicians and DNR pts. Perception of quality of life.
| Setting: Hospital (non ICU) | Severity: Advanced | Duration: 5 days following DNR order implementation
| Funding: Not reported | Race: Not reported | Withdrawals: Not reported
| | Gender: Not reported
McParland, 2003 ^15^ | Design: Prospective Cohort | Sample size: 65 | Exposure: Nursing home residents. | Results: Change in cognitive status related to changes in decision. Preferences changed at 12 and 24 months.
| Quality: Good | Disease: Unclear | Outcomes: CPR and hydration and nutrition preferences.
| Setting: Nursing home | Severity: Unclear | Duration: 12 and 24 months
| Funding: American Federation for Aging Research/John A. Harford Foundation Fellowship | Race: Not reported | Withdrawals: 21
| | Gender: Not reported
Azoulay, 2000 ^16^ | Design: Prospective Cohort | Sample size: 102 | Exposure: Representatives of pts visited by at least one person during their ICU stay. | Results: Families poor comprehension related to the age, unemployment, and referral from hematology or oncology ward, admission for acute respiratory failure or coma, and favorable prognosis. Family-related factors were foreign descent, not French speaking, not the spouse, and no healthcare professional in family.
| Quality: Good | Disease: Unclear | Outcomes: Representatives' comprehension of the diagnosis, prognosis, and treatment of the pt.
| Setting: Hospital (ICU) | Severity: Advanced | Duration: 2 days after ICU admission.
| Funding: Not reported | Race: Not reported | Withdrawals: 124
| | Gender: Not reported
Butow, 1997 ^17^ | Design: Prospective Cohort | Sample size: 80 | Exposure: Pts seeing oncologists in outpatient clinic, completed a questionnaire before a directly after one consultation. | Results: Females wanted more detailed information than males. Those whose follow-up visit encompassed a significant change in their condition were more likely to prefer having the doctor make decisions. General information and involvement preferences were relatively stable in the short term despite medical intervention. By the time of their next consultation, pts preferences had shifted considerably.
| Quality: Good | Disease: Predominately one disease: Cancer (Breast, Genitourinary, Colon, Lung, Other) | Outcomes: Differences in general information and involvement preferences before and after consultation.
| Setting: Ambulatory/outpt medical care | Severity: Advanced | Duration: Pts complete questionnaire before their next consultation.
| Funding: Not reported | Race: Not reported | Withdrawals: 38
| | Gender: Not reported
Phillips, 2000 ^18^ | Design: Prospective Cohort | Sample size: 9105 | Exposure: Pts enrolled in SUPPORT. | Results: Decisions to withhold or withdraw ventilatory support or dialysis, or withhold surgery, varied by race. African American pts more likely to prefer life-extending treatments.
| Quality: Good | Disease: Mixed Disease | Outcomes: Timing of decisions to withold or withdraw ventilator support and dialysis, and decisions to withhold surgery.
| Setting: Hospital (ICU & non ICU) | Severity: Advanced | Duration: Between hospital days 3 and 6 after enrollment
| Funding: RWJF (SUPPORT) | Race: Not reported | Withdrawals: Not reported
| | Gender: Females
Teno, 1997 ^19^ | Design: Prospective Cohort | Sample size: 4804 | Exposure: Time of study enrollment in SUPPORT. | Results: ADs in medical records did not guide medical decision-making. Despite specific instructions, care was inconsistent in half of the cases.
| Quality: Good | Disease: Mixed Disease | Outcomes: Relationship between AD in record and hospital utilization.
| Setting: Hospital (ICU & non ICU) | Severity: Advanced | Duration: 6 months follow up or death.
| Funding: RWJF (SUPPORT) | Race: Not reported | Withdrawals: Not reported
| | Gender: Not reported
Teno, 1998 ^20^ | Design: Prospective Cohort | Sample size: 14 | Exposure: Patient receives patient-specific information on prognosis and specially trained nurse to facilitate decision-making. Pt has AD. | Results: Pt had a period of diminished capacity when AD should have been invoked. AD used in 5 of 14 cases. Complex interaction of several factors associated with AD having a limited role.
| Quality: Good | Disease: Mixed Disease | Outcomes: Role of AD in decision-making.
| Setting: Hospital (ICU & non ICU) | Severity: Advanced | Duration: Timeline of communication and decision-making.
| Funding: RWJF (SUPPORT) | Race: Not reported | Withdrawals: Not reported
| | Gender: Not reported
Wenger, 2000 ^21^ | Design: Prospective Cohort | Sample size: 565 | Exposure: Pts enrolled in SUPPORT. | Results: Dialysis withheld associated with older men with a cancer diagnosis.
| Quality: Good | Disease: Single disease: Kidney Disease | Outcomes: Predictors of decisions to withhold or withdraw dialysis.
| Setting: Hospital (non ICU) | Severity: Advanced | Duration: Between 2 and 7 days after study enrollment
| Funding: Not reported (SUPPORT) | Race: White | Withdrawals: Not reported
| | Gender: Males

I = Intervention group, C = Control group, RCT/CCT = Randomized Controlled Trial/Clinical Controlled Trial, ICU = Intensive Care Unit, CPR = Cardiopulmonary Resuscitation, RN = Registered Nurse, DNR = Do Not Resuscitate, outpt = Outpatient, AD = Advance Directive, MD = Physician, ACP = Advance Care Planning, AD/DPA = Advance Directive/Durable Power of Attorney,HRQoL = Health Related Quality of Life, T = Treatment group, DPA = Durable Power of Attorney

## References for Appendix L Evidence Tables

### Reference List for Evidence table 1

1 Bradley E H, Hallemeier A G, Fried T R, et al. Documentation of discussions about prognosis with terminally ill patients. Am J Med. 2001;111(3):218-23. [pmid: 11530033].
2 Burge F, Lawson B, Johnston G. Family physician continuity of care and emergency department use in end-of-life cancer care. Med Care. 2003;41(8):992-1001. [pmid: 12886178].
3 Burge F, Lawson B, Johnston G, et al. Primary care continuity and location of death for those with cancer. J Palliat Med. 2003;6(6):911-8. [pmid: 14733683].
4 Tang S T. Determinants of hospice home care use among terminally ill cancer patients. Nurs Res. 2003;52(4):217-25. [pmid: 12867778].
5 Tang S T, Mccorkle R. Determinants of congruence between the preferred and actual place of death for terminally ill cancer patients. J Palliat Care. 2003;19(4):230-7. [pmid: 14959592].
6 Wennberg J E, Fisher E S, Stukel T A, et al. Use of hospitals, physician visits, and hospice care during last six months of life among cohorts loyal to highly respected hospitals in the United States. BMJ 2004;328(7440):607. Comment in: BMJ. Mar 13. 2004;328(7440):610. PMID: 15016693.
7 Townsend J, Frank A O, Fermont D, et al. Terminal cancer care and patients' preference for place of death: a prospective study. BMJ 1990;301(6749):415–7. Comment in: BMJ. Jun 26. 1993;306(6894):1754. PMID: 8343651.
8 Hutt E, Ecord M, Eilertsen T B, et al. Precipitants of emergency room visits and acute hospitalization in short-stay medicare nursing home residents. J Am Geriatr Soc. 2002;50(2):223-9. [pmid: 12028202].
9 Burns C M, Dixon T, Broom D, et al. Family caregiver knowledge of treatment intent in a longitudinal study of patients with advanced cancer. Support Care Cancer. 2003;11(10):629-37. [pmid: 12898369].
10 Chin M H, Goldman L. Correlates of early hospital readmission or death in patients with congestive heart failure. Am J Cardiol. 1997;79(12):1640-4. [pmid: 9202355].
11 Fried T R, Mor V. Frailty and hospitalization of long-term stay nursing home residents. J Am Geriatr Soc 1997;45(3):265–9. Comment in: J Am Geriatr Soc. Mar. 1997;45(3):378-9. PMID: 9063288.
12 Kane R L, Keckhafer G, Flood S, et al. The effect of Evercare on hospital use. J Am Geriatr Soc. 2003;51(10):1427-34. [pmid: 14511163].
13 Knol H R, Haken L, Kempen G I. Disablement process and the utilization of home care among non-institutionalized elderly people: contrasting results between cross-sectional and panel data. Disabil Rehabil. 2003;25(15):845-55. [pmid: 12851095].
14 Heller R F, Fisher J D, D'Este C A, et al. Death and readmission in the year after hospital admission with cardiovascular disease: the Hunter Area Heart and Stroke Register. Med J Aust. 2000;172(6):261-5. [pmid: 10860090].
15 Holtzman J, Chen Q, Kane R. The effect of HMO status on the outcomes of home-care after hospitalization in a Medicare population. J Am Geriatr Soc. 1998;46(5):629-34. [pmid: 9588380].
16 Nourhashemi F, Andrieu S, Sastres N, et al. Descriptive analysis of emergency hospital admissions of patients with Alzheimer disease. Alzheimer Dis Assoc Disord. 2001;15(1):21-5. [pmid: 11236821].
17 Stewart S, Horowitz J D. Detecting early clinical deterioration in chronic heart failure patients post-acute hospitalisation-a critical component of multidisciplinary, home-based intervention?. Eur J Heart Fail. 2002;4(3):345-51. [pmid: 12034161].
18 Zweig S C, Kruse R L, Binder E F, et al. Effect of do-not-resuscitate orders on hospitalization of nursing home residents evaluated for lower respiratory infections. J Am Geriatr Soc. 2004;52(1):51-8. [pmid: 14687315].

### Reference List for Evidence Table 2

1 Collins C, Stommel M, Wang S, et al. Caregiving transitions: changes in depression among family caregivers of relatives with dementia. Nurs Res. 1994;43(4):220-5. [pmid: 8047426].
2 Emanuel E J, Fairclough D L, Slutsman J, et al. Assistance from family members, friends, paid care givers, and volunteers in the care of terminally ill patients. N Engl J Med. 1999;341(13):956-63. [pmid: 10498492].
3 Grant I, Adler K A, Patterson T L, et al. Health consequences of Alzheimer's caregiving transitions: effects of placement and bereavement. Psychosom Med. 2002;64(3):477-86. [pmid: 12021421].
4 Hays J C, Kasl S V, Jacobs S C. The course of psychological distress following threatened and actual conjugal bereavement. Psychol Med. 1994;24(4):917-27. [pmid: 7892360].
5 Hodgson C, Higginson I, McDonnell M, et al. Family anxiety in advanced cancer: a multicentre prospective study in Ireland. Br J Cancer. 1997;76(9):1211-4. [pmid: 9365171].
6 Martikainen P, Valkonen T. Do education and income buffer the effects of death of spouse on mortality?. Epidemiology. 1998;9(5):530-4. [pmid: 9730032].
7 Schulz R, Beach S R, Lind B, et al. Involvement in caregiving and adjustment to death of a spouse: findings from the caregiver health effects study. JAMA. 2001;285(24):3123-9. [pmid: 11427141].
8 Schulz R, Mendelsohn A B, Haley W E, et al. End-of-life care and the effects of bereavement on family caregivers of persons with dementia. N Engl J Med 2003;349(20):1936–42. Comment in: N Engl J Med. 2003 Nov 13;349(20):1891–2. PMID: 14614164. Comment in: N Engl J Med. Feb 12. 2004;350(7):733-4. ; author reply 733–4. PMID: 14960754.
9 Teno J M, Clarridge B R, Casey V, et al. Family perspectives on end-of-life care at the last place of care. JAMA 2004;291(1):88–93. Comment in: JAMA. Mar 24. 2004;291(12):1445-6. ; author reply 1446. PMID: 15039410.
10 Tilden V P, Tolle S W, Drach L L, et al. Out-of-Hospital Death: Advance Care Planning, Decedent Symptoms, and Caregiver Burden. J Am Geriatr Soc. 2004;52(4):532-9. [pmid: 15066067].
11 Volicer L, Hurley A C, Blasi Z V. Characteristics of dementia end-of-life care across care settings. Am J Hosp Palliat Care. 2003;20(3):191-200. [pmid: 12785040].
12 McCarthy M, Hall J A, Ley M. Communication and choice in dying from heart disease. J R Soc Med. 1997;90(3):128-31. [pmid: 9135608]. [pmcid: 1296175].
13 Evangelista L S, Dracup K, Doering L, et al. Emotional well-being of heart failure patients and their caregivers. J Card Fail. 2002;8(5):300-5. [pmid: 12411980].
14 Covinsky K E, Goldman L, Cook E F, et al. The impact of serious illness on patients' families. SUPPORT Investigators. Study to Understand Prognoses and Preferences for Outcomes and Risks of Treatment. JAMA. 1994;272(23):1839-44. [pmid: 7990218].
15 Brazil K, Bedard M, Willison K, et al. Caregiving and its impact on families of the terminally ill. Aging and Mental Health. 2003;7(5):376-82. [pmid: 12959807].
16 Emanuel E J, Fairclough D L, Slutsman J, et al. Understanding economic and other burdens of terminal illness: the experience of patients and their caregivers. Annals of Internal Medicine. 2000;132(6):451-9. [pmid: 10733444].
17 Markowitz J S, Gutterman E M, Sadik K, et al. Health-related quality of life for daregivers of patients With Alzheimer disease. Alzheimer Disease and Associated Disorders. 2003;17(4):209-214. [pmid: 14657784].
18 Steinhauser K E, Christakis N A, Clipp E C, et al. Factors considered important at the end of life by patients, family, physicians, and other care providers. JAMA. 2000;284(19):2476-82. [pmid: 11074777].

### Reference List for Evidence Table 3

1 Baker R, Wu A W, Teno J M, et al. Family satisfaction with end-of-life care in seriously ill hospitalized adults. J Am Geriatr Soc. 2000;48(5 Suppl):S61-9. [pmid: 10809458].
2 Correa-Velez I, Clavarino A, Barnett A G, et al. Use of complementary and alternative medicine and quality of life: changes at the end of life. Palliat Med. 2003;17(8):695-703. [pmid: 14694921].
3 Curtisa J R, Patrick D L, Caldwell E, et al. The quality of patient-doctor communication about end-of-life care: a study of patients with advanced AIDS and their primary care clinicians. AIDS. 1999;13(9):1123-31. [pmid: 10397544].
4 Fakhoury W, McCarthy M, Addington-Hall J. Determinants of informal caregivers' satisfaction with services for dying cancer patients. Soc Sci Med. 1996;42(5):721-31. [pmid: 8685740].
5 Fakhoury W K, McCarthy M, Addington-Hall J. The effects of the clinical characteristics of dying cancer patients on informal caregivers' satisfaction with palliative care. Palliat Med. 1997;11(2):107-15. [pmid: 9156106].
6 Fisher E S, Wennberg D E, Stukel T A, et al. The implications of regional variations in Medicare spending. Part 2: health outcomes and satisfaction with care. Ann Intern Med 2003;138(4):288–98. Comment in: Ann Intern Med. 2003 Feb 18;138(4):347–8. PMID: 12585834. Comment in: Ann Intern Med. 2003 Feb 18;138(4):348–9. PMID: 12585835. Comment in: Ann Intern Med. Feb 18. 2003;138(4):350-1. PMID: 12585836. Comment in: Ann Intern Med. 2004 Jan.
7 Heyland D K, Rocker G M, O'Callaghan C J, et al. Dying in the ICU: perspectives of family members. Chest 2003;124(1):392–7. Comment in: Chest. Jul. 2003;124(1):11-2. PMID: 12853494.
8 Higginson I J, Costantini M. Communication in end-of-life cancer care: a comparison of team assessments in three European countries. J Clin Oncol. 2002;20(17):3674-82. [pmid: 12202669].
9 Kristjanson L J, Leis A, Koop P M, et al. Family members' care expectations, care perceptions, and satisfaction with advanced cancer care: results of a multi-site pilot study. J Palliat Care. 1997;13(4):5-13. [pmid: 9447806].
10 Larsson B W, Larsson G, Carlson S R. Advanced home care: patients' opinions on quality compared with those of family members. J Clin Nurs. 2004;13(2):226-33. [pmid: 14723675].
11 Malacrida R, Bettelini C M, Degrate A, et al. Reasons for dissatisfaction: a survey of relatives of intensive care patients who died. Crit Care Med 1998;26(7):1187–93. Comment in: Crit Care Med. 1998 Jul;26(7):1150–1. PMID: 9671355. Comment in: Crit Care Med. Jan. 2000;28(1):289-90. PMID: 10667559.
12 Sulmasy D P, McIlvane J M. Patients' ratings of quality and satisfaction with care at the end of life. Arch Intern Med. 2002;162(18):2098-104. [pmid: 12374518].
13 Teno J M, Clarridge B R, Casey V, et al. Family perspectives on end-of-life care at the last place of care. JAMA 2004;291(1):88–93. Comment in: JAMA. Mar 24. 2004;291(12):1445-6. author reply 1446. PMID: 15039410.
14 Tierney R M, Horton S M, Hannan T J, et al. Relationships between symptom relief, quality of life, and satisfaction with hospice care. Palliat Med. 1998;12(5):333-44. [pmid: 9924596].
15 Tolle S W, Tilden V P, Rosenfeld A G, et al. Family reports of barriers to optimal care of the dying. Nurs Res. 2000;49(6):310-7. [pmid: 11093695].
16 Volicer L, Hurley A C, Blasi Z V. Scales for evaluation of End-of-Life Care in Dementia. Alzheimer Dis Assoc Disord. 2001;15(4):194-200. [pmid: 11723370].
17 Zhukovsky D S, Gorowski E, Hausdorff J, et al. Unmet analgesic needs in cancer patients. J Pain Symptom Manage. 1995;10(2):113-9. [pmid: 7537317].
18 Dawson N J. Need satisfaction in terminal care settings. Soc Sci Med. 1991;32(1):83-7. [pmid: 2008626].
19 Jacoby A, Lecouturier J, Bradshaw C, et al. Feasibility of using postal questionnaires to examine carer satisfaction with palliative care: a methodological assessment. South Tyneside MAAG Palliative Care Study Group. Palliat Med. 1999;13(4):285-98. [pmid: 10659098].
20 Kane R L, Homyak P, Bershadsky B, et al. Consumer responses to the Wisconsin Partnership Program for Elderly Persons: a variation on the PACE Model. J Gerontol A Biol Sci Med Sci. 2002;57(4):M250-8. [pmid: 11909892].
21 Steinhauser K E, Christakis N A, Clipp E C, et al. Factors considered important at the end of life by patients, family, physicians, and other care providers. JAMA. 2000;284(19):2476-82. [pmid: 11074777].

### Reference List for Evidence Table 4

1 Desbiens N A, Mueller-Rizner N, Hamel M B, et al. Preference for comfort care does not affect the pain experience of seriously ill patients. The SUPPORT Investigators. Study to Understand Prognoses and Preferences for Outcomes and Risks of Treatment. J Pain Symptom Manage. 1998;16(5):281-9. [pmid: 9846022].
2 Gagnon P, Allard P, Masse B, et al. Delirium in terminal cancer: a prospective study using daily screening, early diagnosis, and continuous monitoring. J Pain Symptom Manage. 2000;19(6):412-26. [pmid: 10908822].
3 Goodwin D M, Higginson I J, Myers K, et al. Effectiveness of palliative day care in improving pain, symptom control, and quality of life. J Pain Symptom Manage 2003;25(3):202–12. Comment in: J Pain Symptom Manage. Oct. 2003;26(4):886-7. author reply 888–9. PMID: 14527753.
4 Lammi U K, Kosunen E, Kellokumpu-Lehtinen P. Palliative cancer care in two health centres and one hospice in Finland. Support Care Cancer. 2001;9(1):25-31. [pmid: 11147139].
5 van der Steen J T, Ooms M E, van der Wal G, et al. Pneumonia: the demented patient's best friend? Discomfort after starting or withholding antibiotic treatment. J Am Geriatr Soc. 2002;50(10):1681-8. [pmid: 12366622].
6 de Wit R, van Dam F, Vielvoye-Kerkmeer A, et al. The treatment of chronic cancer pain in a cancer hospital in The Netherlands. J Pain Symptom Manage. 1999;17(5):333-50. [pmid: 10355212].
7 Friedman M M, Griffin J A. Relationship of physical symptoms and physical functioning to depression in patients with heart failure. Heart Lung. 2001;30(2):98-104. [pmid: 11248712].
8 Fulop G, Strain J J, Stettin G. Congestive heart failure and depression in older adults: clinical course and health services use 6 months after hospitalization. Psychosomatics. 2003;44(5):367-73. [pmid: 12954910].
9 Goldberg R J, Goldberg J. Risperidone for dementia-related disturbed behavior in nursing home residents: a clinical experience. Int Psychogeriatr. 1997;9(1):65-8. [pmid: 9195280].
10 Payne J L, Sheppard J M, Steinberg M, et al. Incidence, prevalence, and outcomes of depression in residents of a long-term care facility with dementia. Int J Geriatr Psychiatry. 2002;17(3):247-53. [pmid: 11921153].
11 Rumsfeld J S, Havranek E, Masoudi F A, et al. Depressive symptoms are the strongest predictors of short-term declines in health status in patients with heart failure. J Am Coll Cardiol. 2003;42(10):1811-7. [pmid: 14642693].
12 Keene J, Hope T, Fairburn C G, et al. Death and dementia. Int J Geriatr Psychiatry 2001;16(10):969–74. Comment in: Int J Geriatr Psychiatry. Nov. 2002;17(11):1078. PMID: 12404661.
13 Jiang W, Alexander J, Christopher E, et al. Relationship of depression to increased risk of mortality and rehospitalization in patients with congestive heart failure. Arch Intern Med 2001;161(15):1849–56. Comment in: Arch Intern Med. 2002 Feb 11;162(3):362. PMID: 11822938. Comment in: Arch Intern Med. Feb 11. 2002;162(3):362-4. PMID: 11822939.
14 Breitbart W, Tremblay A, Gibson C. An open trial of olanzapine for the treatment of delirium in hospitalized cancer patients. Psychosomatics. 2002;43(3):175-82. [pmid: 12075032].

### Reference List for Evidence Table 5

1 Curtisa J R, Patrick D L, Caldwell E, et al. The quality of patient-doctor communication about end-of-life care: a study of patients with advanced AIDS and their primary care clinicians. AIDS. 1999;13(9):1123-31. [pmid: 10397544].
2 Curtis J R, Patrick D L, Caldwell E S, et al. Why don't patients and physicians talk about end-of-life care? Barriers to communication for patients with acquired immunodeficiency syndrome and their primary care clinicians. Arch Intern Med 2000;160(11):1690–6. Comment in: Arch Intern Med. Jun 12. 2000;160(11):1565-6. PMID: 10847247.
3 Golin C E, Wenger N S, Liu H, et al. A prospective study of patient-physician communication about resuscitation. J Am Geriatr Soc. 2000;48(5 Suppl):S52-60. [pmid: 10809457].
4 Higginson I J, Costantini M. Communication in end-of-life cancer care: a comparison of team assessments in three European countries. J Clin Oncol. 2002;20(17):3674-82. [pmid: 12202669].
5 Lockhart L K, Ditto P H, Danks J H, et al. The stability of older adults' judgments of fates better and worse than death. Death Stud. 2001;25(4):299-317. [pmid: 11803982].
6 Rose J H, O'Toole E E, Dawson N V, et al. Generalists and oncologists show similar care practices and outcomes for hospitalized late-stage cancer patients. SUPPORT Investigators. Study to Understand Prognoses and Preferences for Outcomes and Risks for Treatment. Med Care. 2000;38(11):1103-18. [pmid: 11078051].
7 Tierney W M, Dexter P R, Gramelspacher G P, et al. The effect of discussions about advance directives on patients' satisfaction with primary care. J Gen Intern Med 2001;16(1):32–40. Comment in: J Gen Intern Med. Jan. 2001;16(1):68-9. PMID: 11251753.
8 Weeks J C, Cook E F, O'Day S J, et al. Relationship between cancer patients' predictions of prognosis and their treatment preferences. JAMA 1998;279(21):1709–14. Comment in: JAMA. 1998 Jun 3;279(21):1746–8. PMID: 9624031. Comment in: JAMA. 1998 Oct 28;280(16):1403–4. PMID: 9800998. Comment in: JAMA. 1998 Oct 28;280(16):1403; author reply 1404. PMID: 9800997. Erratum in: JAMA. Jan 12. 2000;283(2):203.
9 Wenger N S, Phillips R S, Teno J M, et al. Physician understanding of patient resuscitation preferences: insights and clinical implications. J Am Geriatr Soc. 2000;48(5 Suppl):S44-51. [pmid: 10809456].
10 McCarthy M, Hall J A, Ley M. Communication and choice in dying from heart disease. J R Soc Med. 1997;90(3):128-31. [pmid: 9135608]. [pmcid: 1296175].
11 Townsend J, Frank A O, Fermont D, et al. Terminal cancer care and patients' preference for place of death: a prospective study. BMJ 1990;301(6749):415–7. Comment in: BMJ. Jun 26. 1993;306(6894):1754. PMID: 8343651.
12 Danis M, Southerland L I, Garrett J M, et al. A prospective study of advance directives for life-sustaining care. N Engl J Med 1991;324(13):882–8. Comment in: N Engl J Med. Oct 24. 1991;325(17):1254-6. PMID: 1922218.
13 Hakim R B, Teno J M, Harrell F E Jr, et al. Factors associated with do-not-resuscitate orders: patients' preferences, prognoses, and physicians' judgments. SUPPORT Investigators. Study to Understand Prognoses and Preferences for Outcomes and Risks of Treatment. Ann Intern Med. 1996;125(4):284-93. [pmid: 8678391].
14 Junod Perron N, Morabia A, de Torrente A. Quality of life of Do-Not-Resuscitate (DNR) patients: how good are physicians in assessing DNR patients' quality of life?. Swiss Med Wkly. 2002;132(3940):562-5. [pmid: 12571762].
15 McParland E, Likourezos A, Chichin E, et al. Stability of preferences regarding life-sustaining treatment: a two-year prospective study of nursing home residents. Mt Sinai J Med. 2003;70(2):85-92. [pmid: 12634900].
16 Azoulay E, Chevret S, Leleu G, et al. Half the families of intensive care unit patients experience inadequate communication with physicians. Critical Care Medicine. 2000;28(8):3044-9. [pmid: 10966293].
17 Butow P N, Maclean M, Dunn S M, et al. The dynamics of change: cancer patients' preferences for information, involvement and support. Annals of Oncology. 1997;8(9):857-63. [pmid: 9358935].
18 Phillips R S, Hamel M B, Teno J M, et al. Patient race and decisions to withhold or withdraw life-sustaining treatments for seriously ill hospitalized adults. SUPPORT Investigators. Study to Understand Prognoses and Preferences for Outcomes and Risks of Treatments. American Journal of Medicine. 2000;108(1):14-9. [pmid: 11059436].
19 Teno J M, Licks S, Lynn J, et al. Do advance directives provide instructions that direct care? SUPPORT Investigators. Study to Understand Prognoses and Preferences for Outcomes and Risks of Treatment. Journal of the American Geriatrics Society. 1997;45(4):508-12. [pmid: 9100722].
20 Teno J M, Stevens M, Spernak S, et al. Role of written advance directives in decision making: insights from qualitative and quantitative data. Journal of General Internal Medicine. 1998;13(7):439-46. [pmid: 9686709]. [pmcid: 1496979].
21 Wenger N S, Lynn J, Oye R K, et al. Withholding versus withdrawing life-sustaining treatment: patient factors and documentation associated with dialysis decisions. Journal of the American Geriatrics Society. 2000;48(5 Suppl):S75-83. [pmid: 10809460].