# Appendix J. Bibliography of Excluded Articles

Aaronson N K, Ahmedzai S, Bergman B, Bullinger M, Cull A, Duez N J, Filiberti A, Flechtner H, Fleishman S B, de Haes J C, et al. The European Organization for Research and Treatment of Cancer QLQ-C30: a quality-of-life instrument for use in international clinical trials in oncology. J Natl Cancer Inst. 93;85(5):365-76. [Rec#: 50857] article not received prior to report production.
Adam S J. Palliative care for patients with a failed liver transplant. Intensive Crit Care Nurs. 2000;16(6):396-402. [Rec#: 9044] Recoded: exclude for design. [pmid: 11091471].
Alexander P. An investigation of inpatient referrals to a clinical psychologist in a hospice. Eur J Cancer Care (Engl). 2004;13(1):36-44. [Rec#: 118] Recoded: outcome unrelated to pts/family/non-prof. [pmid: 14961774].
American Pain Society Quality of Care Committee. Quality improvement guidelines for the treatment of acute pain and cancer pain. A. JAMA. 95;274(23):1874-80. [Rec#: 50185] Recoded: exclude for design.
Angeles-Llerenas A, Alvarez del Rio A, Salazar-Martinez E, Kraus-Weissman A, Zamora-Munoz S, Hernandez-Avila M, Lazcano-Ponce E. Perceptions of nurses with regard to doctor-patient communication. Br J Nurs. 2003-2004;12(22):1312-21. [Rec#: 198] article not received prior to report production.
Annunziata M A, Talamini R, Tumolo S, Rossi C, Monfardini S. Physicians and death: comments and behaviour of 605 doctors in the north-east of Italy. Support Care Cancer 96;4(5):334–40. Comment on: Support Care Cancer. Sep. 1996;4(5):325-6. PMID: 8883224. [Rec#: 205] article not received prior to report production.
Axelsson B, Christensen S B. Evaluation of a hospital-based palliative support service with particular regard to financial outcome measures. Palliat Med. 98;12(1):41-9. [Rec#: 275] article not received prior to report production.
Axelsson B, Sjoden P O. Quality of life of cancer patients and their spouses in palliative home care. Palliat Med. 98;12(1):29-39. [Rec#: 279] article not received prior to report production. [pmid: 9616457].
Balentine J, Gaeta T, Rao N, Brandon B. Emergency department do-not-attempt-resuscitation orders: next-of-kin response to the emergency physician. Acad Emerg Med 96;3(1):54–7. Comment in: Acad Emerg Med. Jan. 1997;4(1):83-4. PMID: 9110020. [Rec#: 40170] article not received prior to report production.
Bass D M, Bowman K. The transition from caregiving to bereavement: the relationship of care-related strain and adjustment to death. Gerontologist. 90;30(1):35-42. [Rec#: 412] article not received prior to report production. [pmid: 2311960].
Becker L J, Yeargin K, Rea T D, Owens M, Eisenberg M S. Resuscitation of residents with do not resuscitate orders in long-term care facilities. Prehosp Emerg Care. 2003;7(3):303-6. [Rec#: 454] article not received prior to report production. [pmid: 12879377].
Bentley A, Boyd K. Use of clinical pictures in the management of nausea and vomiting: a prospective audit. Palliat Med. 2001;15(3):247-53. [Rec#: 494] article not received prior to report production. [pmid: 11407196].
Blenkharn A, Faughnan S, Morgan A. Developing a pain assessment tool for use by nurses in an adult intensive care unit. Intensive Crit Care Nurs. 2002;18(6):332-41. [Rec#: 40316] Recoded: no outcomes specified. [pmid: 12526871].
Bock K R, Teres D, Rapoport J. Economic implications of the timing of do-not-resuscitate orders for ICU patients. New Horiz. 97;5(1):51-5. [Rec#: 9626] article not received prior to report production. [pmid: 9017678].
Borasio G D, Shaw P J, Hardiman O, Ludolph A C, Sales Luis M L, Silani V. European ALS Study Group. Standards of palliative care for patients with amyotrophic lateral sclerosis: results of a European survey. Amyotroph Lateral Scler Other Motor Neuron Disord. 2001;2(3):159-64. [Rec#: 9667] article not received prior to report production. [pmid: 11771773].
Borneman T, Chu D Z, Wagman L, Ferrell B, Juarez G, McCahill L E, Uman G. Concerns of family caregivers of patients with cancer facing palliative surgery for advanced malignancies. Oncol Nurs Forum. 2003;30(6):997-1005. [Rec#: 676] article not received prior to report production. [pmid: 14603357].
Boyd K J, Kelly M. Oral morphine as symptomatic treatment of dyspnoea in patients with advanced cancer. Palliat Med. 97;11(4):277-81. [Rec#: 731] article not received prior to report production. [pmid: 9373578].
Boyd K J. Short terminal admissions to a hospice. Palliat Med. 93;7(4):289-94. [Rec#: 729] article not received prior to report production. [pmid: 8261195].
Bozzetti F, Amadori D, Bruera E, Cozzaglio L, Corli O, Filiberti A, Rapin C H, Neuenschwander H, Aoun M, Ricci S B, De Conno F, Doci R, Garrone M, Gentilini M, Lery N, Mantell M, Sheldon-Collins R, Trompino G. Guidelines on artificial nutrition versus hydration in terminal cancer patients. European Association for Palliative Care. Nutrition. 96;12(3):163-7. [Rec#: 9716] Recoded: no outcomes specified.
Brock D B, Foley D J, Salive M E. Hospital and nursing home use in the last three months of life. J Aging Health. 96;8(3):307-19. [Rec#: 810] article not received prior to report production. [pmid: 10165977].
Bruera E, Belzile M, Watanabe S, Fainsinger R L. Volume of hydration in terminal cancer patients. Support Care Cancer. 96;4(2):147-50. [Rec#: 865] article not received prior to report production. [pmid: 8673352].
Bruera E, Brenneis C, Michaud M, MacMillan K, Hanson J, MacDonald R N. Patient-controlled subcutaneous hydromorphone versus continuous subcutaneous infusion for the treatment of cancer pain. Journal of the National Cancer Institute. 88;80(14):1152-4. [Rec#: 50253] Recoded: data older than 1990.
Bruera E, Carraro S, Roca E, Barugel M, Chacon R. Double-blind evaluation of the effects of mazindol on pain, depression, anxiety, appetite, and activity in terminal cancer patients. Cancer Treatment Reports. 86;70(2):295-8. [Rec#: 50258] Recoded: data older than 1990.
Bruera E, Chadwick S, Brenneis C, Hanson J, MacDonald R N. Methylphenidate associated with narcotics for the treatment of cancer pain. Cancer Treatment Reports. 87;71(1):67-70. [Rec#: 50261] Recoded: data older than 1990. [pmid: 3791269].
Bruera E, Fainsinger R, MacEachern T, Hanson J. The use of methylphenidate in patients with incident cancer pain receiving regular opiates. A preliminary report. Pain. 92;50(1):75-7. [Rec#: 50263] Recoded: exclude for design. [pmid: 1381072].
Bruera E, Roca E, Cedaro L, Carraro S, Chacon R. Action of oral methylprednisolone in terminal cancer patients: a prospective randomized double-blind study. Cancer Treatment Reports. 85;69(78):751-4. [Rec#: 50295] Recoded: data older than 1990.
Bucher J A, Trostle G B, Moore M. Family reports of cancer pain, pain relief, and prescription access. Cancer Pract. 99;7(2):71-7. [Rec#: 899] article not received prior to report production. [pmid: 10352064].
Butler J V, Pooviah P K, Cunningham D, Hasan M. Improving decision-making and documentation relating to do not attempt resuscitation orders. Resuscitation. 2003;57(2):139-44. [Rec#: 40494] Recoded: outcome unrelated to pts/family/non-prof. [pmid: 12745181].
Butters E, Higginson I, George R, Smits A, McCarthy M. Assessing the symptoms, anxiety and practical needs of HIV/AIDS patients receiving palliative care. Qual Life Res. 92;1(1):47-51. [Rec#: 950] article not received prior to report production.
Calam B, Andrew R. CPR or DNR? End-of-life decision making on a family practice teaching ward. Can Fam Physician. 2000;46:340-6. [Rec#: 975] article not received prior to report production. [pmid: 10690490]. [pmcid: 1987695].
Castle N G, Mor V. Advance care planning in nursing homes: pre- and post-Patient Self-Determination Act. Health Serv Res. 98;33(1):101-24. [Rec#: 40551] article not received prior to report production. [pmid: 9566180].
Castle N G, Mor V, Banaszak-Holl J. Special care hospice units in nursing homes. Hosp J. 97;12(3):59-69. [Rec#: 10112] Recoded: outcome unrelated to pts/family/non-prof. [pmid: 9256688].
Centeno-Cortes C, Nunez-Olarte J M. Questioning diagnosis disclosure in terminal cancer patients: a prospective study evaluating patients' responses. Palliat Med. 94;8(1):39-44. [Rec#: 10138] article not received prior to report production.
Chan A, Woodruff R K. Comparison of palliative care needs of English- and non-English-speaking patients. J Palliat Care. 99;15(1):26-30. [Rec#: 1148] article not received prior to report production. [pmid: 10333661].
Chaplin J. Pressure sore risk assessment in palliative care. J Tissue Viability. 2000;10(1):27-31. [Rec#: 10161] article not received prior to report production. [pmid: 10839093].
Christakis N A, Iwashyna T J, Zhang J X. Care after the onset of serious illness: a novel claims-based dataset exploiting substantial cross-set linkages to study end-of-life care. J Palliat Med. 2002;5(4):515-29. [Rec#: 10222] Recoded: outcome unrelated to pts/family/non-prof. [pmid: 12243676].
Clayton J, Fardell B, Hutton-Potts J, Webb D, Chye R. Parenteral antibiotics in a palliative care unit: prospective analysis of current practice. Palliat Med. 2003;17(1):44-8. [Rec#: 1329] Recoded: about chemo/surg/stents/laser/radiation. [pmid: 12597465].
Cobb J L, Glantz M J, Nicholas P K, Martin E W, Paul-Simon A, Cole B F, Corless I B. Delirium in patients with cancer at the end of life. Cancer Pract. 2000;8(4):172-7. [Rec#: 1354] article not received prior to report production. [pmid: 11898256].
Cohen S R, Boston P, Mount B M, Porterfield P. Changes in quality of life following admission to palliative care units. Palliat Med. 2001;15(5):363-71. [Rec#: 1382] article not received prior to report production. [pmid: 11591087].
Cohen S R, Mount B M, Bruera E, Provost M, Rowe J, Tong K. Validity of the McGill Quality of Life Questionnaire in the palliative care setting: a multi-centre Canadian study demonstrating the importance of the existential domain. Palliat Med. 97;11(1):3-20. [Rec#: 10315] article not received prior to report production.
Cole B E. The psychiatric management of end-of-life pain and associated psychiatric comorbidity. Curr Pain Headache Rep. 2003;7(2):89-97. [Rec#: 10320] Recoded: useful only for background. [pmid: 12628050].
Cook A M, Finlay I G, Edwards A G, Hood K, Higginson I J, Goodwin D M, Normand C E, Douglas H R. Efficiency of searching the grey literature in palliative care. J Pain Symptom Manage. 2001;22(3):797-801. [Rec#: 10373] article not received prior to report production. [pmid: 11532593].
Costantini M, Higginson I J, Boni L, Orengo M A, Garrone E, Henriquet F, Bruzzi P. Effect of a palliative home care team on hospital admissions among patients with advanced cancer. Palliat Med. 2003;17(4):315-21. [Rec#: 1478] Recoded: outcome unrelated to pts/family/non-prof. [pmid: 12822847].
Covinsky K E, Landefeld C S, Teno J, Connors A F Jr, Dawson N, Youngner S, Desbiens N, Lynn J, Fulkerson W, Reding D, Oye R, Phillips R S. Is economic hardship on the families of the seriously ill associated with patient and surrogate care preferences? SUPPORT Investigators. Arch Intern Med. 96;156(15):1737-41. [Rec#: 1502] article not received prior to report production.
Cowley A J, Skene A M. Treatment of severe heart failure: quantity or quality of life? A trial of enoximone. Enoximone Investigators. Br Heart J 94;72(3):226–30. Comment in: Br Heart J. Jun. 1995;73(6):584. PMID: 7626364. [Rec#: 31102] Recoded: not about end of life care.
Crane R A. Intermittent subcutaneous infusion of opioids in hospice home care: an effective, economical, manageable option. Am J Hosp Palliat Care. 94;11(1):8-12. [Rec#: 10483] article not received prior to report production.
Dangler L A, O'Donnell J, Gingrich C, Bope E T. What do family members expect from the family physician of a deceased loved one? Fam Med 96;28(10):694–7. Comment in: Fam Med. Nov-Dec. 1996;28(10):692-3. PMID: 8937868. [Rec#: 10568] article not received prior to report production.
Davison B J, Degner L F. Promoting patient decision making in life-and-death situations. Semin Oncol Nurs. 98;14(2):129-36. [Rec#: 10634] article not received prior to report production. [pmid: 9580936].
DeCourtney C A, Jones K, Merriman M P, Heavener N, Branch P K. Establishing a culturally sensitive palliative care program in rural Alaska Native American communities. J Palliat Med. 2003;6(3):501-10. [Rec#: 10682] Recoded: no outcomes specified. [pmid: 14509499].
Dellasega C, Zerbe T M. Caregivers of frail rural older adults. Effects of an advanced practice nursing intervention. J Gerontol Nurs. 2002;28(10):40-9. [Rec#: 40850] article not received prior to report production. [pmid: 12382459].
Detmar S B, Muller M J, Schornagel J H, Wever L D, Aaronson N K. Role of health-related quality of life in palliative chemotherapy treatment decisions. J Clin Oncol. 2002;20(4):1056-62. [Rec#: 1795] Recoded: exclude for design. [pmid: 11844830].
Devlen J, Maguire P, Phillips P, Crowther D. Psychological problems associated with diagnosis and treatment of lymphomas. II: Prospective study. British Medical Journal Clinical Research Ed. 87;295(6604):955-7. [Rec#: 50381] article not received prior to report production.
Devlen J, Maguire P, Phillips P, Crowther D, Chambers H. Psychological problems associated with diagnosis and treatment of lymphomas. I: Retrospective study. British Medical Journal Clinical Research Ed. 87;295(6604):953-4. [Rec#: 50382] article not received prior to report production.
Donnelly S. Folklore associated with dying in the west of Ireland. Palliat Med. 99;13(1):57-62. [Rec#: 10796] Recoded: exclude for design. [pmid: 10320877].
Dooneief G, Marder K, Tang M X, Stern Y. The Clinical Dementia Rating scale: community-based validation of “profound” and “terminal” stages. Neurology. 96;46(6):1746-9. [Rec#: 1902] Recoded: not about end of life care. [pmid: 8649584].
Dunn S M, Patterson P U, Butow P N, Smartt H H, McCarthy W H, Tattersall M H. Cancer by another name: a randomized trial of the effects of euphemism and uncertainty in communicating with cancer patients. Journal of Clinical Oncology. 93;11(5):989-96. [Rec#: 50393] Recoded: not about end of life care.
Edmonds P, Karlsen S, Khan S, Addington-Hall J. A comparison of the palliative care needs of patients dying from chronic respiratory diseases and lung cancer. Palliative Medicine. 2001;15(4):287-95. [Rec#: 50395] article not received prior to report production. [pmid: 12054146].
Ejaz F K. The influence of religious and personal values on nursing home residents' attitudes toward life-sustaining treatments. Soc Work Health Care. 2000;32(2):23-39. [Rec#: 2052] article not received prior to report production. [pmid: 11286291].
Ellershaw J E, Kinder C, Aldridge J, Allison M, Smith J C. Care of the dying: is pain control compromised or enhanced by continuation of the fentanyl transdermal patch in the dying phase? J Pain Symptom Manage 2002;24(4):398–403. Comment in: J Pain Symptom Manage. Jul. 2003;26(1):589-90. author reply 590. PMID: 12850638. [Rec#: 2074] article not received prior to report production.
Emanuel E J, Young-Xu Y, Levinsky N G, Gazelle G, Saynina O, Ash A S. Chemotherapy use among Medicare beneficiaries at the end of life. Ann Intern Med. 2003;138(8):639-43. [Rec#: 2094] article not received prior to report production. [pmid: 12693886].
Erdek M A, Pronovost P J. Improving assessment and treatment of pain in the critically ill. Int J Qual Health Care. 2004;16(1):59-64. [Rec#: 41009] Recoded: outcome unrelated to pts/family/non-prof. [pmid: 15020561].
Ernst D S, MacDonald R N, Paterson A H, Jensen J, Brasher P, Bruera E. A double-blind, crossover trial of intravenous clodronate in metastatic bone pain. Journal of Pain & Symptom Management. 92;7(1):4-11. [Rec#: 50401] article not received prior to report production.
Esnaola N F, Cantor S B, Johnson M L, Mirza A N, Miller A R, Curley S A, Crane C H, Cleeland C S, Janjan N A, Skibber J M. Pain and quality of life after treatment in patients with locally recurrent rectal cancer. J Clin Oncol. 2002;20(21):4361-7. [Rec#: 2137] Recoded: about chemo/surg/stents/laser/radiation. [pmid: 12409336].
Evans W K, Will B P, Berthelot J M, Wolfson M C. Estimating the cost of lung cancer diagnosis and treatment in Canada: the POHEM model. Can J Oncol. 95;5(4):408-19. [Rec#: 11062] article not received prior to report production. [pmid: 8770457].
Eve A, Smith A M. Survey of hospice and palliative care inpatient units in the UK and Ireland, 1993. Palliat Med. 96;10(1):13-21. [Rec#: 11065] article not received prior to report production. [pmid: 8821184].
Fakhoury W K, McCarthy M. Can the experience of caring at home affect carers' retrospective evaluation of community care services?. Scand J Caring Sci. 98;12(3):179-85. [Rec#: 2191] article not received prior to report production.
Fantoni M, Ricci F, Del Borgo C, Bevilacqua N, Izzi I, Damiano F, Marasca G. Symptom profile in terminally ill AIDS patients. AIDS Patient Care STDS. 96;10(3):171-3. [Rec#: 11100] article not received prior to report production. [pmid: 11361618].
Farran C J, Miller B H, Kaufman J E, Donner E, Fogg L. Finding meaning through caregiving: development of an instrument for family caregivers of persons with Alzheimer's disease. J Clin Psychol. 99;55(9):1107-25. [Rec#: 31551] Recoded: not about end of life care.
Femia E E, Zarit S H, Johansson B. The disablement process in very late life: a study of the oldest-old in Sweden. J Gerontol B Psychol Sci Soc Sci. 2001;56(1):P12-23. [Rec#: 41048] article not received prior to report production. [pmid: 11192333].
Fontaine K, Rositani R. Cost, quality, and satisfaction with hospice after-hours care. Hosp J. 2000;15(1):1-13. [Rec#: 11288] article not received prior to report production. [pmid: 11033656].
Foti M E. “Do It Your Way”: a demonstration project on end-of-life care for persons with serious mental illness. J Palliat Med. 2003;6(4):661-9. [Rec#: 2386] Recoded: outcome unrelated to pts/family/non-prof. [pmid: 14516513].
Franic D M, Pathak D S. Effect of including (versus excluding) fates worse than death on utility measurement. Int J Technol Assess Health Care. 2003;19(2):347-61. [Rec#: 2408] Recoded: not about end of life care. [pmid: 12862192].
Fulton C. The prevalence and detection of psychiatric morbidity in patients with metastatic breast cancer. Eur J Cancer Care (Engl). 98;7(4):232-9. [Rec#: 31764] article not received prior to report production. [pmid: 9919110].
Gamble E R, McDonald P J, Lichstein P R. Knowledge, attitudes, and behavior of elderly persons regarding living wills. Arch Intern Med. 91;151(2):277-80. [Rec#: 2531] article not received prior to report production. [pmid: 1992955].
Ganzini L, Johnston W S, Silveira M J. The final month of life in patients with ALS. Neurology. 2002;59(3):428-31. [Rec#: 11441] article not received prior to report production. [pmid: 12177378].
Gauthier D M, Froman R D. Preferences for care near the end of life: scale development and validation. Res Nurs Health. 2001;24(4):298-306. [Rec#: 2568] article not received prior to report production. [pmid: 11746060].
Gelber R D, Goldhirsch A, Cole B F. Evaluation of effectiveness: Q-TWiST. The International Breast Cancer Study Group. Cancer Treat Rev. 93;19(Suppl A):73-84. [Rec#: 2586] Recoded: about chemo/surg/stents/laser/radiation. [pmid: 7679323].
Gessert C E, Calkins D R. Rural-urban differences in end-of-life care: the use of feeding tubes. J Rural Health. 2001;17(1):16-24. [Rec#: 2609] article not received prior to report production. [pmid: 11354718].
Gessert C E, Curry N M, Robinson A. Ethnicity and end-of-life care: the use of feeding tubes. Ethn Dis. 2001;11(1):97-106. [Rec#: 11501] article not received prior to report production. [pmid: 11289258].
Gilbert M, Counsell C M, Guin P, O'Neill R, Briggs S. Determining the relationship between end-of-life decisions expressed in advance directives and resuscitation efforts during cardiopulmonary resuscitation. Outcomes Manag Nurs Pract. 2001;5(2):87-92. [Rec#: 2638] article not received prior to report production. [pmid: 11898333].
Ginsburg M L, Quirt C, Ginsburg A D, MacKillop W J. Psychiatric illness and psychosocial concerns of patients with newly diagnosed lung cancer. CMAJ 95;152(5):701–8. Comment in: CMAJ. Jun 15. 1995;152(12):1961-3. PMID: 7780903. [Rec#: 31910] article not received prior to report production.
Glare P, Walsh D, Groh E, Nelson K A. The efficacy and side effects of continuous infusion intravenous morphine (CIVM) for pain and symptoms due to advanced cancer. Am J Hosp Palliat Care. 2002;19(5):343-50. [Rec#: 2666] article not received prior to report production. [pmid: 12269781].
Goldberg L R, Piette J D, Walsh M N, Frank T A, Jaski B E, Smith A L, Rodriguez R, Mancini D M, Hopton L A, Orav E J, Loh E. WHARF Investigators. Randomized trial of a daily electronic home monitoring system in patients with advanced heart failure: the Weight Monitoring in Heart Failure (WHARF) trial. Am Heart J. 2003;146(4):705-12. [Rec#: 31947] Recoded: not about end of life care. [pmid: 14564327].
Goodman M D, Tarnoff M, Slotman G J. Effect of advance directives on the management of elderly critically ill patients. Crit Care Med. 98;26(4):701-4. [Rec#: 41266] article not received prior to report production. [pmid: 9559607].
Goodyer L I, Miskelly F, Milligan P. Does encouraging good compliance improve patients' clinical condition in heart failure? Br J Clin Pract 95;49(4):173–6. Comment in: Br J Clin Pract. Jul-Aug. 1995;49(4):171. PMID: 7547152. [Rec#: 31978] article not received prior to report production.
Grady A, Travers E. Hospice at home 2: evaluating a crisis intervention service. Int J Palliat Nurs. 2003;9(8):326-35. [Rec#: 2766] article not received prior to report production. [pmid: 12968118].
Grande G E, Todd C J, Barclay S I. Support needs in the last year of life: patient and carer dilemmas. Palliat Med. 97;11(3):202-8. [Rec#: 2778] article not received prior to report production. [pmid: 9205653].
Greisinger A J, Lorimor R J, Aday L A, Winn R J, Baile W F. Terminally ill cancer patients. Their most important concerns. Cancer Pract. 97;5(3):147-54. [Rec#: 11708] article not received prior to report production. [pmid: 9171550].
Grey A. The spiritual component of palliative care. Palliat Med. 94;8(3):215-21. [Rec#: 11711] Recoded: useful only for background. [pmid: 7524969].
Griffith C H 3rd, Wilson J F, Emmett K R, Ramsbottom-Lucier M, Rich E C. Knowledge and experience with Alzheimer's disease. Relationship to resuscitation preference. Arch Fam Med. 95;4(9):780-4. [Rec#: 32062] article not received prior to report production.
Grigioni F, Carigi S, Grandi S, Potena L, Coccolo F, Bacchi-Reggiani L, Magnani G, Tossani E, Musuraca A C, Magelli C, Branzi A. Distance between patients' subjective perceptions and objectively evaluated disease severity in chronic heart failure. Psychother Psychosom. 2003;72(3):166-70. [Rec#: 32067] article not received prior to report production. [pmid: 12707484].
Grocott P, Cowley S. The palliative management of fungating malignant wounds--generalising from multiple-case study data using a system of reasoning. Int J Nurs Stud. 2001;38(5):533-45. [Rec#: 11722] Recoded: exclude for design. [pmid: 11524100].
Grond S, Zech D, Schug S A, Lynch J, Lehmann K A. Validation of World Health Organization guidelines for cancer pain relief during the last days and hours of life. J Pain Symptom Manage. 91;6(7):411-22. [Rec#: 2838] article not received prior to report production.
Gutgsell T, Walsh D, Zhukovsky D S, Gonzales F, Lagman R. A prospective study of the pathophysiology and clinical characteristics of pain in a palliative medicine population. Am J Hosp Palliat Care. 2003;20(2):140-8. [Rec#: 2878] article not received prior to report production. [pmid: 12693647].
Haggmark C, Bachner M, Theorell T. A follow-up of psychological state in relatives of cancer patients one year after the patient's death. Effects of an activation programme. Acta Oncol. 91;30(6):677-84. [Rec#: 2911] Recoded: data older than 1990.
Haley W E, LaMonde L A, Han B, Narramore S, Schonwetter R. Family caregiving in hospice: effects on psychological and health functioning among spousal caregivers of hospice patients with lung cancer or dementia. Hosp J. 2001;15(4):1-18. [Rec#: 2938] article not received prior to report production. [pmid: 11876341].
Hamel M B, Teno J M, Goldman L, Lynn J, Davis R B, Galanos A N, Desbiens N, Connors A F Jr, Wenger N, Phillips R S. Patient age and decisions to withhold life-sustaining treatments from seriously ill, hospitalized adults. SUPPORT Investigators. Study to Understand Prognoses and Preferences for Outcomes and Risks of Treatment. Annals of Internal Medicine. 99;130(2):116-25. [Rec#: 50477] article not received prior to report production.
Hanrahan P, Raymond M, McGowan E, Luchins D J. Criteria for enrolling dementia patients in hospice: a replication. Am J Hosp Palliat Care. 99;16(1):395-400. [Rec#: 2983] article not received prior to report production. [pmid: 10085797].
Hanson L C, Danis M. Use of life-sustaining care for the elderly. J Am Geriatr Soc. 91;39(8):772-7. [Rec#: 2990] article not received prior to report production. [pmid: 2071808].
Harrison J, Maguire P. Predictors of psychiatric morbidity in cancer patients. British Journal of Psychiatry. 94;165(5):593-8. [Rec#: 50484] Recoded: exclude for design. [pmid: 7866674].
Hawryluck L A, Harvey W R, Lemieux-Charles L, Singer P A. Consensus guidelines on analgesia and sedation in dying intensive care unit patients. BMC Med Ethics. 2002;3(1):3. [Rec#: 3070] Recoded: outcome unrelated to pts/family/non-prof.
Haxby J V, Raffaele K, Gillette J, Schapiro M B, Rapoport S I. Individual trajectories of cognitive decline in patients with dementia of the Alzheimer type. J Clin Exp Neuropsychol. 92;14(4):575-92. [Rec#: 32227] Recoded: primarily prognosis or trajectories.
Hays J C, Galanos A N, Palmer T A, McQuoid D R, Flint E P. Preference for place of death in a continuing care retirement community. Gerontologist. 2001;41(1):123-8. [Rec#: 3082] article not received prior to report production. [pmid: 11220809].
Hebert R, Dubois M F, Wolfson C, Chambers L, Cohen C. Factors associated with long-term institutionalization of older people with dementia: data from the Canadian Study of Health and Aging. J Gerontol A Biol Sci Med Sci. 2001;56(11):M693-9. [Rec#: 32242] article not received prior to report production. [pmid: 11682577].
Hedestig O, Sandman P O, Widmark A. Living with untreated localized prostate cancer: a qualitative analysis of patient narratives. Cancer Nurs 2003;26(1):55–60. Comment in: Evid Based Nurs. Oct. 2003;6(4):125. PMID: 14577408. [Rec#: 3101] Recoded: not about end of life care.
Hermsen M A, ten Have H A. Moral problems in palliative care practice: a qualitative study. Med Health Care Philos. 2003;6(3):263-72. [Rec#: 12032] Recoded: no outcomes specified. [pmid: 14620463].
Heyse-Moore L, Beynon T, Ross V. Does spirometry predict dyspnoea in advanced cancer?. Palliat Med. 2000;14(3):189-95. [Rec#: 12054] article not received prior to report production. [pmid: 10858826].
Hickman S E, Tilden V P, Tolle S W. Family reports of dying patients' distress: the adaptation of a research tool to assess global symptom distress in the last week of life. J Pain Symptom Manage. 2001;22(1):565-74. [Rec#: 3189] article not received prior to report production. [pmid: 11516598].
Hicks F, Corcoran G. Should hospices offer respite admissions to patients with motor neurone disease?. Palliat Med. 93;7(2):145-50. [Rec#: 3192] Recoded: exclude for design. [pmid: 7505172].
Higginson I J, Astin P, Dolan S. Where do cancer patients die? Ten-year trends in the place of death of cancer patients in England. Palliat Med. 98;12(5):353-63. [Rec#: 3200] article not received prior to report production. [pmid: 9924598].
Higginson I J, Wade A M, McCarthy M. Effectiveness of two palliative support teams. J Public Health Med. 92;14(1):50-6. [Rec#: 3204] article not received prior to report production. [pmid: 1376133].
Higginson I J, McCarthy M. A comparison of two measures of quality of life: their sensitivity and validity for patients with advanced cancer. Palliative Medicine. 94;8(4):282-90. [Rec#: 50491] article not received prior to report production.
High D M. Why are elderly people not using advance directives?. J Aging Health. 93;5(4):497-515. [Rec#: 3205] article not received prior to report production. [pmid: 10129468].
Hilden H M, Louhiala P, Honkasalo M L, Palo J. Finnish nurses' views on end-of-life discussions and a comparison with physicians' views. Nurs Ethics. 2004;11(2):165-78. [Rec#: 3207] article not received prior to report production. [pmid: 15030024].
Hinton J. The progress of awareness and acceptance of dying assessed in cancer patients and their caring relatives. Palliat Med. 99;13(1):19-35. [Rec#: 3238] article not received prior to report production. [pmid: 10320873].
Holley J L, Stackiewicz L, Dacko C, Rault R. Factors influencing dialysis patients' completion of advance directives. Am J Kidney Dis. 97;30(3):356-60. [Rec#: 3292] article not received prior to report production. [pmid: 9292563].
Holmes C, Lovestone S. Long-term cognitive and functional decline in late onset Alzheimer's disease: therapeutic implications. Age Ageing. 2003;32(2):200-4. [Rec#: 32389] Recoded: not about end of life care. [pmid: 12615565].
Hopkinson J B. A study of the perceptions of hospice day care patients: my phenomenological methodology. Int J Nurs Stud. 99;36(3):203-7. [Rec#: 3327] Recoded: no outcomes specified. [pmid: 10404289].
Houts R M, Smucker W D, Jacobson J A, Ditto P H, Danks J H. Predicting elderly outpatients' life-sustaining treatment preferences over time: the majority rules. Med Decis Making. 2002;22(1):39-52. [Rec#: 3364] Recoded: exclude for design. [pmid: 11833664].
Hudson P L, Aranda S, Kristjanson L J. Meeting the supportive needs of family caregivers in palliative care: challenges for health professionals. J Palliat Med. 2004;7(1):19-25. [Rec#: 3392] Recoded: exclude for design. [pmid: 15008126].
Inman L. Advance directives. Why community-based older adults do not discuss their wishes. J Gerontol Nurs. 2002;28(9):40-6. [Rec#: 3475] article not received prior to report production. [pmid: 12240520].
Ita D, Keorney M, O'Slorain L. Psychiatric disorder in a palliative care unit. Palliat Med. 2003;17(2):212-8. [Rec#: 3499] article not received prior to report production. [pmid: 12701854].
John R, Hennessy C H, Dyeson T B, Garrett M D. Toward the conceptualization and measurement of caregiver burden among Pueblo Indian family caregivers. Gerontologist. 2001;41(2):210-9. [Rec#: 41670] article not received prior to report production. [pmid: 11327487].
Johnston G, Abraham C. The WHO objectives for palliative care: to what extent are we achieving them?. Palliat Med. 95;9(2):123-37. [Rec#: 12456] Recoded: exclude for design. [pmid: 7541683].
Johnston SC and Johnson SC. Advance directives: from the perspective of the patient and the physician. J R Soc Med 96;89(10):568–70. Erratum in: J R Soc Med 1997 Feb 90(2):120. Johnson SC[corrected to Johnston SC]. [Rec#: 12461] article not received prior to report production
Kalra L, Evans A, Perez I, Knapp M, Donaldson N, Swift C G. Alternative strategies for stroke care: a prospective randomised controlled trial. Lancet 2000;356(9233):894–9. Comment in: Lancet. 2000 Sep 9;356(9233):869–70. PMID: 11036886. Comment in: Lancet. 2001 Jan 13;357(9250):146–7. PMID: 11197428. Comment in: Lancet. Jan 13. 2001;357(9250):146. author reply 147. PMID: 11197429. [Rec#: 3712] Recoded: not about end of life care.
Kane R L, Homyak P, Bershadsky B. Consumer reactions to the Wisconsin Partnership Program and its parent, the Program for All-Inclusive Care of the Elderly (PACE). Gerontologist. 2002;42(3):314-20. [Rec#: 41718] article not received prior to report production. [pmid: 12040133].
Karlsen S, Addington-Hall J. How do cancer patients who die at home differ from those who die elsewhere? Palliat Med 98;12(4):279–86. Comment in: Palliat Med. Mar. 1999;13(2):169-70. PMID: 10474703. [Rec#: 3736] article not received prior to report production.
Kasser T, Sheldon K M. Of wealth and death: materialism, mortality salience, and consumption behavior. Psychol Sci. 2000;11(4):348-51. [Rec#: 3747] Recoded: not about end of life care. [pmid: 11273398].
Kaunonen M, Aalto P, Tarkka M T, Paunonen M. Oncology ward nurses' perspectives of family grief and a supportive telephone call after the death of a significant other. Cancer Nurs. 2000;23(4):314-24. [Rec#: 12573] Recoded: exclude for design. [pmid: 10939180].
Kavic S M, Atweh N, Possenti P P, Ivy M E. The role of advance directives and family in end-of-life decisions in critical care units. Conn Med. 2003;67(9):531-4. [Rec#: 3774] article not received prior to report production. [pmid: 14619340].
Kayser-Jones J. Malnutrition, dehydration, and starvation in the midst of plenty: the political impact of qualitative inquiry. Qual Health Res. 2002;12(10):1391-405. [Rec#: 3787] Recoded: no outcomes specified. [pmid: 12474910].
Kellar N, Martinez J, Finis N, Bolger A, von Gunten C F. Characterization of an acute inpatient hospice palliative care unit in a U.S. teaching hospital. J Nurs Adm. 96;26(3):16-20. [Rec#: 3806] article not received prior to report production.
Kelleher P, Cox S, McKeogh M. HIV infection: the spectrum of symptoms and disease in male and female patients attending a London hospice. Palliat Med. 97;11(2):152-8. [Rec#: 3808] article not received prior to report production.
Kelly B, Raphael B, Statham D, Ross M, Eastwood H, McLean S, O'Loughlin B, Brittain K. A comparison of the psychosocial aspects of AIDS and cancer-related bereavement. Int J Psychiatry Med. 96;26(1):35-49. [Rec#: 3820] article not received prior to report production.
Kennedy C, Cheston S E. Spiritual distress at life's end: finding meaning in the maelstrom. J Pastoral Care Counsel. 2003;57(2):131-41. [Rec#: 3841] Recoded: useful only for background. [pmid: 12875121].
Kish Wallace S, Martin C G, Shaw A D, Price K J. Influence of an advance directive on the initiation of life support technology in critically ill cancer patients. Crit Care Med 2001;29(12):2294–8. Comment in: Crit Care Med. Dec. 2001;29(12):2391-2. PMID: 11801850. [Rec#: 41781] Recoded: exclude for design.
Kissane D W, Bloch S, Onghena P, McKenzie D P, Snyder R D, Dowe D L. The Melbourne Family Grief Study, II: Psychosocial morbidity and grief in bereaved families. Am J Psychiatry. 96;153(5):659-66. [Rec#: 3932] article not received prior to report production.
Knobel H, Loge J H, Brenne E, Fayers P, Hjermstad M J, Kaasa S. The validity of EORTC QLQ-C30 fatigue scale in advanced cancer patients and cancer survivors. Palliat Med. 2003;17(8):664-72. [Rec#: 3970] article not received prior to report production. [pmid: 14694917].
Koenig H G, Larson D B, Larson S S. Religion and coping with serious medical illness. Annals of Pharmacotherapy. 2001;35(3):352-9. [Rec#: 50525] Recoded: exclude for design. [pmid: 11261534].
Koffman J S, Higginson I J. Fit to care? A comparison of informal caregivers of first-generation Black Caribbeans and White dependants with advanced progressive disease in the UK. Health Soc Care Community. 2003;11(6):528-36. [Rec#: 3989] article not received prior to report production. [pmid: 14629584].
Komaromy C, Sidell M, Katz J T. The quality of terminal care in residential and nursing homes. Int J Palliat Nurs. 2000;6(4):192-200. [Rec#: 4005] article not received prior to report production. [pmid: 11143646].
Kovach C R, Stearns S A. DSCUs: a study of behavior before and after residence. J Gerontol Nurs. 94;20(12):33-9. [Rec#: 50053] Recoded: exclude for design. [pmid: 7852710].
Kress J P, Rubin A, Pohlman A S, Hall J B. Outcomes of critically ill patients denied consideration for liver transplantation. Am J Respir Crit Care Med. 2000;162(2 Pt 1):418-23. [Rec#: 41849] Recoded: primarily prognosis or trajectories. [pmid: 10934063].
Kristjanson L J, Cousins K, White K, Andrews L, Lewin G, Tinnelly C, Asphar D, Greene R. Evaluation of a night respite community palliative care service. Int J Palliat Nurs. 2004;10(2):84-90. [Rec#: 4062] article not received prior to report production. [pmid: 15039612].
Krout R E. The effects of single-session music therapy interventions on the observed and self-reported levels of pain control, physical comfort, and relaxation of hospice patients. Am J Hosp Palliat Care. 2001;18(6):383-90. [Rec#: 4074] article not received prior to report production. [pmid: 11712719].
Kuin A, Courtens A M, Deliens L, Vernooij-Dassen M J, van Zuylen L, van der Linden B, van der Wal G. Palliative care consultation in The Netherlands: a nationwide evaluation study. J Pain Symptom Manage. 2004;27(1):53-60. [Rec#: 4092] Recoded: outcome unrelated to pts/family/non-prof. [pmid: 14711469].
Kurtz M E, Kurtz J C, Given C W, Given B. Predictors of postbereavement depressive symptomatology among family caregivers of cancer patients. Support Care Cancer. 97;5(1):53-60. [Rec#: 4113] article not received prior to report production.
Kyriacou C K, Nidetz A. Performance-based palliative care in the nursing home: closing the gap between “knowing” and “practicing”. J Palliat Med. 2002;5(5):757-8. [Rec#: 12852] Recoded: outcome unrelated to pts/family/non-prof. [pmid: 12572981].
Lamont E B, Christakis N A. Prognostic disclosure to patients with cancer near the end of life. Ann Intern Med 2001;134(12):1096–105. Comment in: Ann Intern Med. 2001 Jun 19;134(12):1142–3. PMID: 11412055. Comment in: Ann Intern Med. 2002 Sep 3;137(5 Part 1):368; author reply 368–9. PMID: 12204026. Comment in: Ann Intern Med. Sep 3. 2002;137(5 Part 1):368. author reply 368–9. P. [Rec#: 12886] article not received prior to report production.
Landi F, Tua E, Onder G, Carrara B, Sgadari A, Rinaldi C, Gambassi G, Lattanzio F, Bernabei R. SILVERNET-HC Study Group of Bergamo. Minimum data set for home care: a valid instrument to assess frail older people living in the community. Med Care. 2000;38(12):1184-90. [Rec#: 41893] Recoded: not about end of life care. [pmid: 11186297].
Lawton M P, Moss M, Glicksman A. The quality of the last year of life of older persons. Milbank Q. 90;68(1):1-28. [Rec#: 4252] article not received prior to report production. [pmid: 2215425].
Layde P M, Beam C A, Broste S K, Connors A F Jr, Desbiens N, Lynn J, Phillips R S, Reding D, Teno J, Vidaillet H. Surrogates' predictions of seriously ill patients' resuscitation preferences. Archives of Family Medicine. 95;4(6):518-23. [Rec#: 50541] article not received prior to report production.
Levin J R, Wenger N S, Ouslander J G, Zellman G, Schnelle J F, Buchanan J L, Hirsch S H, Reuben D B. Life-sustaining treatment decisions for nursing home residents: who discusses, who decides and what is decided?. J Am Geriatr Soc. 99;47(1):82-7. [Rec#: 41975] article not received prior to report production.
Lipman A G. Symptom-related research from the agency for healthcare research and quality. J Pain Palliat Care Pharmacother. 2003;17(1):39-45. [Rec#: 13117] Recoded: useful only for background. [pmid: 14640339].
Lloyd-Williams M, Friedman T, Rudd N. A survey of antidepressant prescribing in the terminally ill. Palliat Med. 99;13(3):243-8. [Rec#: 13141] article not received prior to report production. [pmid: 10474711].
Lloyd-Williams M. Screening for depression in palliative care patients: a review. Eur J Cancer Care (Engl). 2001;10(1):31-5. [Rec#: 13136] article not received prior to report production. [pmid: 11827265].
Lord B, Pockett R. Perceptions of social work intervention with bereaved clients: some implications for hospital social work practice. Soc Work Health Care. 98;27(1):51-66. [Rec#: 13181] article not received prior to report production.
Mansfield D R, Gollogly N C, Kaye D M, Richardson M, Bergin P, Naughton M T. Controlled trial of continuous positive airway pressure in obstructive sleep apnea and heart failure. Am J Respir Crit Care Med 2004;169(3):361–6. Comment in: Am J Respir Crit Care Med. Feb 1. 2004;169(3):329-31. PMID: 14739130. [Rec#: 33472] Recoded: not about end of life care.
Martens K H, Mellor S D. A study of the relationship between home care services and hospital readmission of patients with congestive heart failure. Home Healthc Nurse. 97;15(2):123-9. [Rec#: 50070] article not received prior to report production.
Martensson J, Dracup K, Fridlund B. Decisive situations influencing spouses' support of patients with heart failure: a critical incident technique analysis. Heart Lung. 2001;30(5):341-50. [Rec#: 33506] Recoded: exclude for design. [pmid: 11604976].
Maschmeyer G, Bertschat F L, Moesta K T, Hausler E, Held T K, Nolte M, Osterziel K J, Papstein V, Peters M, Reich G, Schmutzler M, Sezer O, Stula M, Wauer H, Wortz T, Wischnewsky M, Hohenberger P. Outcome analysis of 189 consecutive cancer patients referred to the intensive care unit as emergencies during a 2-year period. Eur J Cancer. 2003;39(6):783-92. [Rec#: 42164] Recoded: primarily prognosis or trajectories. [pmid: 12651204].
McGrath P. Spiritual pain: a comparison of findings from survivors and hospice patients. Am J Hosp Palliat Care. 2003;20(1):23-33. [Rec#: 4978] article not received prior to report production. [pmid: 12568434].
McKinley S, Coote K, Stein-Parbury J. Development and testing of a Faces Scale for the assessment of anxiety in critically ill patients. J Adv Nurs. 2003;41(1):73-9. [Rec#: 42212] Recoded: not about end of life care. [pmid: 12519290].
McMillan S C, Small B J. Symptom distress and quality of life in patients with cancer newly admitted to hospice home care. Oncol Nurs Forum. 2002;29(10):1421-8. [Rec#: 5021] article not received prior to report production. [pmid: 12432413].
McMillan S C, Weitzner M. How problematic are various aspects of quality of life in patients with cancer at the end of life?. Oncol Nurs Forum. 2000;27(5):817-23. [Rec#: 5023] article not received prior to report production. [pmid: 10868392].
McMillan S C. Quality of life of primary caregivers of hospice patients with cancer. Cancer Pract 96;4(4):191–8. Comment in: Cancer Pract. Jul-Aug. 1996;4(4):174. PMID: 8900756. [Rec#: 5016] article not received prior to report production.
McShane R, Keene J, Gedling K, Fairburn C, Jacoby R, Hope T. Do neuroleptic drugs hasten cognitive decline in dementia? Prospective study with necropsy follow up. BMJ 97;314(7076):266–70. Comment in: BMJ. 1997 May 10;314(7091):1411; author reply 1412. PMID: 9161321. Comment in: BMJ. 1997 May 10;314(7091):1411; author reply 1412. PMID: 9161322. Comment in: BMJ. May 10. 1997;314(7091):1412. PMID: 9161323. [Rec#: 33661] article not received prior to report production.
McWhinney I R, Bass M J, Orr V. Factors associated with location of death (home or hospital) of patients referred to a palliative care team. CMAJ 95;152(3):361–7. Comment in: CMAJ. Feb 1. 1995;152(3):337-40. PMID: 7828097. [Rec#: 5040] article not received prior to report production.
Mendyka B E. The dying patient in the intensive care unit: assisting the family in crisis. AACN Clin Issues Crit Care Nurs. 93;4(3):550-7. [Rec#: 5075] Recoded: exclude for design. [pmid: 8136228].
Merrouche Y, Freyer G, Saltel P, Rebattu P. Quality of final care for terminal cancer patients in a comprehensive cancer centre from the point of view of patients' families. Support Care Cancer 96;4(3):163–8. Comment in: Support Care Cancer. May. 1996;4(3):157. PMID: 8739645. [Rec#: 5113] article not received prior to report production.
Meunier-Cartal J, Souberbielle J C, Boureau F. Morphine and the “lytic cocktail” for terminally ill patients in a French general hospital: evidence for an inverse relationship. J Pain Symptom Manage. 95;10(4):267-73. [Rec#: 5119] Recoded: outcome unrelated to pts/family/non-prof.
Meyer W, Balck F. Resuscitation decision index: a new approach to decision-making in prehospital CPR. Resuscitation 2001;48(3):255–63. Comment in: Resuscitation. Jul. 2001;50(1):127. PMID: 11724005. [Rec#: 5126] Recoded: not about end of life care.
Meyers J L, Gray L N. The relationships between family primary caregiver characteristics and satisfaction with hospice care, quality of life, and burden. Oncol Nurs Forum. 2001;28(1):73-82. [Rec#: 5128] article not received prior to report production. [pmid: 11198900].
Meyers R M, Lurie N, Breitenbucher R B, Waring C J. Do-not-resuscitate orders in an extended-care study group. J Am Geriatr Soc. 90;38(9):1011-5. [Rec#: 42275] article not received prior to report production. [pmid: 2212435].
Mezey M, Kluger M, Maislin G, Mittelman M. Life-sustaining treatment decisions by spouses of patients with Alzheimer's disease. J Am Geriatr Soc. 96;44(2):144-50. [Rec#: 42276] article not received prior to report production. [pmid: 8576503].
Mills M, Davies H T, Macrae W A. Care of dying patients in hospital. BMJ 94;309(6954):583–6. Comment in: BMJ. 1994 Dec 10;309(6968):1579. PMID: 7819906. Comment in: BMJ. 1994 Dec 10;309(6968):1579. PMID: 7529607. Comment in: BMJ. 1994 Oct 15;309(6960):1017. PMID: 7524877. Comment in: BMJ. Oct 15. 1994;309(6960):1017. PMID: 7524878. Comment . [Rec#: 5192] Recoded: data older than 1990.
Mizuno E, Hosak T, Ogihara R, Higano H, Mano Y. Effectiveness of a stress management program for family caregivers of the elderly at home. J Med Dent Sci. 99;46(4):145-53. [Rec#: 42306] article not received prior to report production.
Molloy D W, Guyatt G H, Alemayehu E, McIlroy W, Willan A, Eisemann M, Abraham G, Basile J, Penington G, McMurdo M E, et al. Factors affecting physicians' decisions on caring for an incompetent elderly patient: an international study. CMAJ. 91;145(8):947-52. [Rec#: 5260] article not received prior to report production.
Montazeri A, Gillis C R, McEwen J. Tak Tent. Studies conducted in a cancer support group. Support Care Cancer. 97;5(2):118-25. [Rec#: 5269] Recoded: useful only for background. [pmid: 9069611].
Mor V, Masterson-Allen S. A comparison of hospice vs conventional care of the terminally ill cancer patient. Oncology (Huntingt). 90;4(7):85-91. discussion 94, 96. [Rec#: 13841] article not received prior to report production.
Morgan AE, Lindley CM, and Berry JI. Assessment of pain and patterns of analgesic use in hospice patients. Am J Hosp Palliat Care 94;11(1):13–9, 22–5. [Rec#: 5303] article not received prior to report production
Morita T, Hirai K, Sakaguchi Y, Tsuneto S, Shima Y. Family-perceived distress from delirium-related symptoms of terminally ill cancer patients. Psychosomatics. 2004;45(2):107-13. [Rec#: 42341] article not received prior to report production. [pmid: 15016923].
Morita T, Tsunoda J, Inoue S, Chihara S. Perceptions and decision-making on rehydration of terminally ill cancer patients and family members. Am J Hosp Palliat Care. 99;16(3):509-16. [Rec#: 5340] article not received prior to report production.
Moss A H, Hozayen O, King K, Holley J L, Schmidt R J. Attitudes of patients toward cardiopulmonary resuscitation in the dialysis unit. Am J Kidney Dis 2001;38(4):847–52. Comment in: Am J Kidney Dis. Oct. 2001;38(4):884-6. PMID: 11576896. [Rec#: 42352] article not received prior to report production.
Moss A H, Stocking C B, Sachs G A, Siegler M. Variation in the attitudes of dialysis unit medical directors toward decisions to withhold and withdraw dialysis. Journal of the American Society of Nephrology. 93;4(2):229-34. [Rec#: 50622] article not received prior to report production.
Murberg T A, Bru E, Svebak S, Tveteras R, Aarsland T. Depressed mood and subjective health symptoms as predictors of mortality in patients with congestive heart failure: a two-years follow-up study. Int J Psychiatry Med. 99;29(3):311-26. [Rec#: 33918] article not received prior to report production.
Nelson J E, Meier D E, Oei E J, Nierman D M, Senzel R S, Manfredi P L, Davis S M, Morrison R S. Self-reported symptom experience of critically ill cancer patients receiving intensive care. Crit Care Med 2001;29(2):277–82. Comment in: Crit Care Med. Feb. 2001;29(2):449-50. PMID: 11246333. [Rec#: 5515] article not received prior to report production.
Neumann C M, Hanson J, Kuehn N, Bruera E. Temporal distribution of deaths in cancer patients admitted to a palliative care unit. J Palliat Care. 99;15(3):10-3. [Rec#: 5532] article not received prior to report production. [pmid: 10540792].
Ni H, Nauman D J, Hershberger R E. Managed care and outcomes of hospitalization among elderly patients with congestive heart failure. Arch Intern Med. 98;158(11):1231-6. [Rec#: 34027] Recoded: not about end of life care. [pmid: 9625402].
Nolen-Hoeksema S, Larson J, Bishop M. Predictors of family members' satisfaction with hospice. Hosp J. 2000;15(2):29-48. [Rec#: 5590] article not received prior to report production. [pmid: 11271158].
O'Connell L J. Changing the culture of dying. A new awakening of spirituality in America heightens sensitivity to needs of dying persons. Health Prog. 96;77(6):16-20. [Rec#: 14115] article not received prior to report production.
Osoba D, Zee B, Pater J, Warr D, Kaizer L, Latreille J. Psychometric properties and responsiveness of the EORTC quality of Life Questionnaire (QLQ-C30) in patients with breast, ovarian and lung cancer. Qual Life Res. 94;3(5):353-64. [Rec#: 34184] article not received prior to report production.
Owen A, Croucher L. Effect of an exercise programme for elderly patients with heart failure. Eur J Heart Fail. 2000;2(1):65-70. [Rec#: 34210] Recoded: not about end of life care. [pmid: 10742705].
Patrick D L, Engelberg R A, Curtis J R. Evaluating the quality of dying and death. J Pain Symptom Manage. 2001;22(3):717-26. [Rec#: 14330] Recoded: no outcomes specified. [pmid: 11532585].
Pereira J, Lawlor P, Vigano A, Dorgan M, Bruera E. Equianalgesic dose ratios for opioids. a critical review and proposals for long-term dosing. Journal of Pain & Symptom Management. 2001;22(2):672-87. [Rec#: 50665] article not received prior to report production. [pmid: 11495714].
Philbin E F, Rocco T A, Lindenmuth N W, Ulrich K, McCall M, Jenkins P L. The results of a randomized trial of a quality improvement intervention in the care of patients with heart failure. The MISCHF Study Investigators. Am J Med 2000;109(6):443–9. Comment in: Am J Med. Oct 15. 2000;109(6):501-3. PMID: 11042244. [Rec#: 34368] Recoded: not about end of life care.
Pietersma P, Follett-Bick S, Wilkinson B, Guebert N, Fisher K, Pereira J. A bedside food cart as an alternate food service for acute and palliative oncological patients. Support Care Cancer. 2003;11(9):611-4. [Rec#: 14452] article not received prior to report production. [pmid: 12883966].
Pritchard R S, Fisher E S, Teno J M, Sharp S M, Reding D J, Knaus W A, Wennberg J E, Lynn J. Influence of patient preferences and local health system characteristics on the place of death. SUPPORT Investigators. Study to Understand Prognoses and Preferences for Risks and Outcomes of Treatment. J Am Geriatr Soc 98;46(10):1242–50. Comment in: J Am Geriatr Soc. Oct. 1998;46(10):1320-1. PMID: 9777921. [Rec#: 6155] article not received prior to report production.
Proulx K, Jacelon C. Dying with dignity: the good patient versus the good death. Am J Hosp Palliat Care. 2004;21(2):116-20. [Rec#: 6167] Recoded: exclude for design. [pmid: 15055511].
Radbruch L, Nauck F, Fuchs M, Neuwohner K, Schulenberg D, Lindena G. Working Group on the Core Documentation for Palliative Care Units in Germany. What is palliative care in Germany? Results from a representative survey. J Pain Symptom Manage. 2002;23(6):471-83. [Rec#: 14626] Recoded: outcome unrelated to pts/family/non-prof. [pmid: 12067771].
Rector T S, Tschumperlin L K, Kubo S H, Bank A J, Francis G S, McDonald K M, Keeler C A, Silver M A. Use of the Living With Heart Failure questionnaire to ascertain patients' perspectives on improvement in quality of life versus risk of drug-induced death. J Card Fail. 95;1(3):201-6. [Rec#: 34623] article not received prior to report production.
Rich M W, Beckham V, Wittenberg C, Leven C L, Freedland K E, Carney R M. A multidisciplinary intervention to prevent the readmission of elderly patients with congestive heart failure. N Engl J Med 95;333(18):1190–5. Comment in: ACP J Club. 1996 Mar-Apr;124(2):31. Comment in: N Engl J Med. Nov 2. 1995;333(18):1213-4. PMID: 7565979. [Rec#: 34663] Recoded: not about end of life care.
Rinck G C, van den Bos G A, Kleijnen J, de Haes H J, Schade E, Veenhof C H. Methodologic issues in effectiveness research on palliative cancer care: a systematic review. J Clin Oncol. 97;15(4):1697-707. [Rec#: 14768] Recoded: topic unclear.
Rosenfeld K, Rasmussen J. Palliative care management: a Veterans Administration demonstration project. J Palliat Med. 2003;6(5):831-9. [Rec#: 14858] Recoded: no outcomes specified. [pmid: 14622470].
Roth K, Lynn J, Zhong Z, Borum M, Dawson N V. Dying with end stage liver disease with cirrhosis: insights from SUPPORT. Study to Understand Prognoses and Preferences for Outcomes and Risks of Treatment. J Am Geriatr Soc. 2000;48(5 Suppl):S122-30. [Rec#: 6542] article not received prior to report production. [pmid: 10809465].
Sambamoorthi U, Walkup J, McSpiritt E, Warner L, Castle N, Crystal S. Racial differences in end-of-life care for patients with AIDS. AIDS Public Policy J. 2000;15(3–4):136-48. [Rec#: 6662] article not received prior to report production. [pmid: 12189713].
Sarna L. Correlates of symptom distress in women with lung cancer. Cancer Pract. 93;1(1):21-8. [Rec#: 34892] article not received prior to report production. [pmid: 8324526].
Sarna L. Effectiveness of structured nursing assessment of symptom distress in advanced lung cancer. Oncol Nurs Forum. 98;25(6):1041-8. [Rec#: 34893] article not received prior to report production. [pmid: 9679262].
Schofield P, Ball D, Smith J G, Borland R, O'Brien P, Davis S, Olver I, Ryan G, Joseph D. Optimism and survival in lung carcinoma patients. Cancer. 2004;100(6):1276-82. [Rec#: 34984] Recoded: not about end of life care. [pmid: 15022297].
Schrader S L, Horner A, Eidsness L, Young S, Wright C, Robinson M. A team approach in palliative care: enhancing outcomes. S D J Med. 2002;55(7):269-78. [Rec#: 6805] article not received prior to report production. [pmid: 12148413].
Schuit K W, Sleijfer D T, Meijler W J, Otter R, Schakenraad J, van den Bergh F C, Meyboom-de Jong B. Symptoms and functional status of patients with disseminated cancer visiting outpatient departments. J Pain Symptom Manage. 98;16(5):290-7. [Rec#: 6813] article not received prior to report production.
Seale C, Kelly M. A comparison of hospice and hospital care for people who die: views of the surviving spouse. Palliat Med. 97;11(2):93-100. [Rec#: 6877] article not received prior to report production. [pmid: 9156104].
Seale C, Kelly M. A comparison of hospice and hospital care for the spouses of people who die. Palliat Med. 97;11(2):101-6. [Rec#: 6878] article not received prior to report production. [pmid: 9156105].
Shorr A F, Niven A S, Katz D E, Parker J M, Eliasson A H. Regulatory and educational initiatives fail to promote discussions regarding end-of-life care. J Pain Symptom Manage 2000;19(3):168–73. Comment in: J Pain Symptom Manage. Mar. 2000;19(3):165-7. PMID: 10760620. [Rec#: 7037] Recoded: outcome unrelated to pts/family/non-prof.
Sloane P D, Zimmerman S, Hanson L, Mitchell C M, Riedel-Leo C, Custis-Buie V. End-of-life care in assisted living and related residential care settings: comparison with nursing homes. J Am Geriatr Soc. 2003;51(11):1587-94. [Rec#: 7143] article not received prior to report production. [pmid: 14687388].
Smith E M, Gomm S A, Dickens C M. Assessing the independent contribution to quality of life from anxiety and depression in patients with advanced cancer. Palliat Med. 2003;17(6):509-13. [Rec#: 7166] article not received prior to report production. [pmid: 14526884].
Smucker W D, Ditto P H, Moore K A, Druley J A, Danks J H, Townsend A. Elderly outpatients respond favorably to a physician-initiated advance directive discussion. J Am Board Fam Pract. 93;6(5):473-82. [Rec#: 7190] article not received prior to report production.
Stalfelt A M, Brodin H, Pettersson S, Eklof A. The final phase in acute myeloid leukaemia (AML): a study of cause of death, place of death and type of care during the last week of life. Leuk Res 2001;25(8):673–80. Comment in: Leuk Res. Aug. 2001;25(8):681-4. PMID: 11397473. [Rec#: 7295] article not received prior to report production.
Stanek E J, Oates M B, McGhan W F, Denofrio D, Loh E. Preferences for treatment outcomes in patients with heart failure: symptoms versus survival. J Card Fail. 2000;6(3):225-32. [Rec#: 7297] article not received prior to report production. [pmid: 10997749].
Steele L L, Mills B, Long M R, Hagopian G A. Patient and caregiver satisfaction with end-of-life care: does high satisfaction mean high quality of care?. Am J Hosp Palliat Care. 2002;19(1):19-27. [Rec#: 7318] article not received prior to report production. [pmid: 12171422].
Stockelberg D, Lehtola P, Noren I. Palliative treatment at home for patients with haematological disorders. Support Care Cancer. 97;5(6):506-8. [Rec#: 7381] article not received prior to report production. [pmid: 9406366].
Stockler M R, Osoba D, Goodwin P, Corey P, Tannock I F. Responsiveness to change in health-related quality of life in a randomized clinical trial: a comparison of the Prostate Cancer Specific Quality of Life Instrument (PROSQOLI) with analogous scales from the EORTC QLQ-C30 and a trial specific module. European Organization for Research and Treatment of Cancer. J Clin Epidemiol. 98;51(2):137-45. [Rec#: 7383] Recoded: about chemo/surg/stents/laser/radiation.
Stuart B, Coulson N E. Use of outpatient drugs as death approaches. Health Care Financ Rev. 94;15(3):63-82. [Rec#: 7421] article not received prior to report production. [pmid: 10137798].
Surgeons Palliative Care Workgroup. Office of Promoting Excellence in End-of-Life Care: Surgeon's Palliative Care Workgroup report from the field. J Am Coll Surg. 2003;197(4):661-86. [Rec#: 15653] Recoded: useful only for background. [pmid: 14562800].
Suri D N, Egleston B L, Brody J A, Rudberg M A. Nursing home resident use of care directives. J Gerontol A Biol Sci Med Sci. 99;54(5):M225-9. [Rec#: 7463] article not received prior to report production. [pmid: 10362004].
Swanwick M, Haworth M, Lennard R F. The prevalence of episodic pain in cancer: a survey of hospice patients on admission. Palliat Med. 2001;15(1):9-18. [Rec#: 7476] article not received prior to report production. [pmid: 11212475].
Syrett E, Taylor J. Non-pharmacological management of breathlessness: a collaborative nurse--physiotherapist approach. Int J Palliat Nurs. 2003;9(4):150-6. [Rec#: 15684] article not received prior to report production. [pmid: 12734451].
Tamburini M, Rosso S, Gamba A, Mencaglia E, De Conno F, Ventafridda V. A therapy impact questionnaire for quality-of-life assessment in advanced cancer research. Ann Oncol. 92;3(7):565-70. [Rec#: 50887] article not received prior to report production.
Tanaka K, Akechi T, Okuyama T, Nishiwaki Y, Uchitomi Y. Prevalence and screening of dyspnea interfering with daily life activities in ambulatory patients with advanced lung cancer. J Pain Symptom Manage. 2002;23(6):484-9. [Rec#: 35495] Recoded: non-Western location. [pmid: 12067772].
Tang S T, McCorkle R. Appropriate time frames for data collection in quality of life research among cancer patients at the end of life. Qual Life Res. 2002;11(2):145-55. [Rec#: 15730] article not received prior to report production. [pmid: 12018738].
Tarzian A J, Hoffmann D E. Barriers to managing pain in the nursing home: findings from a statewide survey. J Am Med Dir Assoc. 2004;5(2):82-8. [Rec#: 7557] article not received prior to report production. [pmid: 14984618].
Tattersall M H, Gattellari M, Voigt K, Butow P N. When the treatment goal is not cure: are patients informed adequately?. Support Care Cancer. 2002;10(4):314-21. [Rec#: 7561] article not received prior to report production. [pmid: 12029431].
Taylor E J. Spiritual needs of patients with cancer and family caregivers. Cancer Nursing. 2003;26(4):260-6. [Rec#: 50767] Recoded: exclude for design. [pmid: 12886116].
Thomas J, Retsas A. Transacting self-preservation: a grounded theory of the spiritual dimensions of people with terminal cancer. Int J Nurs Stud. 99;36(3):191-201. [Rec#: 7618] Recoded: exclude for design. [pmid: 10404288].
Tiernan E, Casey P, O'Boyle C, Birkbeck G, Mangan M, O'Siorain L, Kearney M. Relations between desire for early death, depressive symptoms and antidepressant prescribing in terminally ill patients with cancer. J R Soc Med 2002;95(8):386–90. Comment in: J R Soc Med. Oct. 2002;95(10):526. PMID: 12356985. [Rec#: 7660] article not received prior to report production.
Tishelman C, Degner L F, Mueller B. Measuring symptom distress in patients with lung cancer. A pilot study of experienced intensity and importance of symptoms. Cancer Nurs 2000;23(2):82–90. Erratum in: Cancer Nurs. Jun;23. 2000;(3):163. [Rec#: 35608] Recoded: exclude for design.
Todero C M, LaFramboise L M, Zimmerman L M. Symptom status and quality-of-life outcomes of home-based disease management program for heart failure patients. Outcomes Manag. 2002;6(4):161-8. [Rec#: 35613] Recoded: not about end of life care. [pmid: 12385167].
Tolle S W, Rosenfeld A G, Tilden V P, Park Y. Oregon's low in-hospital death rates: what determines where people die and satisfaction with decisions on place of death?. Ann Intern Med. 99;130(8):681-5. [Rec#: 15876] Recoded: no outcomes specified.
Tong K L, Porterfield P, Mills I. Vancouver General Hospital Palliative Care Unit utilization review. J Palliat Care. 93;9(1):32-6. [Rec#: 7697] Recoded: outcome unrelated to pts/family/non-prof. [pmid: 8492235].
Torelli G F, Campos A C, Meguid M M. Use of TPN in terminally ill cancer patients. Nutrition. 99;15(9):665-7. [Rec#: 7700] Recoded: not about end of life care. [pmid: 10467610].
Tornatore J B, Grant L A. Family caregiver satisfaction with the nursing home after placement of a relative with dementia. J Gerontol B Psychol Sci Soc Sci. 2004;59(2):S80-8. [Rec#: 43389] article not received prior to report production. [pmid: 15014095].
Trippoli S, Vaiani M, Lucioni C, Messori A. Quality of life and utility in patients with non-small cell lung cancer. Quality-of-life Study Group of the Master 2 Project in Pharmacoeconomics. Pharmacoeconomics. 2001;19(8):855-63. [Rec#: 35667] article not received prior to report production. [pmid: 11596837].
Tsevat J, Cook E F, Green M L, Matchar D B, Dawson N V, Broste S K, Wu A W, Phillips R S, Oye R K, Goldman L. Health values of the seriously ill. SUPPORT investigators. Ann Intern Med 95;122(7):514–20. Comment in: Ann Intern Med. Jan 15. 1996;124(2):279. PMID: 8534018. [Rec#: 43412] article not received prior to report production.
van der Riet P, Mackey S. Therapeutic massage: an education program for rural and remote workers in the palliative care field. Aust J Rural Health. 99;7(3):186-90. [Rec#: 16027] Recoded: outcome unrelated to pts/family/non-prof.
Ventafridda V, De Conno F, Ripamonti C, Gamba A, Tamburini M. Quality-of-life assessment during a palliative care programme. Ann Oncol 90;1(6):415–20. Comment in: Ann Oncol. 1990 Nov;1(6):396–8. PMID: 1707296. Comment in: Ann Oncol. Oct. 1991;2(9):693-4. PMID: 1720657. [Rec#: 7879] article not received prior to report production.
Vetter P, Steiner O, Kraus S, Moises H, Kropp P, Moller W D, Koller O. Factors affecting the utilization of homecare supports by caregiving relatives of Alzheimer patients. Dement Geriatr Cogn Disord. 98;9(2):111-6. [Rec#: 35841] article not received prior to report production.
Volicer L, Hurley A C. Management of behavioral symptoms in progressive degenerative dementias. J Gerontol A Biol Sci Med Sci. 2003;58(9):M837-45. [Rec#: 35868] Recoded: no outcomes specified. [pmid: 14528041].
Wall E, Rodriguez G, Saultz J. A retrospective study of patient care needs on admission to an inpatient hospice facility. J Am Board Fam Pract. 93;6(3):233-8. [Rec#: 7991] article not received prior to report production. [pmid: 8503293].
Walsh D, Nelson K A. Communication of a cancer diagnosis: patients' perceptions of when they were first told they had cancer. Am J Hosp Palliat Care. 2003;20(1):52-6. [Rec#: 8000] article not received prior to report production. [pmid: 12568437].
Ward S E, Gordon D B. Patient satisfaction and pain severity as outcomes in pain management: a longitudinal view of one setting's experience. J Pain Symptom Manage. 96;11(4):242-51. [Rec#: 16192] Recoded: not about end of life care.
Weitzner M A, McMillan S C. The Caregiver Quality of Life Index-Cancer (CQOLC) Scale: revalidation in a home hospice setting. J Palliat Care. 99;15(2):13-20. [Rec#: 8116] article not received prior to report production. [pmid: 10425873].
Westlake C, Dracup K. Role of spirituality in adjustment of patients with advanced heart failure. Prog Cardiovasc Nurs. 2001;16(3):119-25. [Rec#: 35983] article not received prior to report production. [pmid: 11464434].
White P H, Kuhlenschmidt H L, Vancura B G, Navari R M. Antimicrobial use in patients with advanced cancer receiving hospice care. J Pain Symptom Manage. 2003;25(5):438-43. [Rec#: 8175] article not received prior to report production. [pmid: 12727041].
Wielenga R P, Erdman R A, Huisveld I A, Bol E, Dunselman P H, Baselier M R, Mosterd W L. Effect of exercise training on quality of life in patients with chronic heart failure. J Psychosom Res. 98;45(5):459-64. [Rec#: 36014] Recoded: not about end of life care.
Wilson H, Butler L J, Repetto G, Love J. Providing care to patients with pancreatic cancer: a retrospective chart review. Can Oncol Nurs J. 2000;10(4):134-8. [Rec#: 8237] article not received prior to report production. [pmid: 11894319].
Wittkowski J. The construction of the multidimensional orientation toward dying and death inventory (MODDI-F). Death Stud. 2001;25(6):479-95. [Rec#: 8278] article not received prior to report production. [pmid: 11811202].
Wood M M, Ashby M A, Somogyi A A, Fleming B G. Neuropsychological and pharmacokinetic assessment of hospice inpatients receiving morphine. J Pain Symptom Manage. 98;16(2):112-20. [Rec#: 8301] Recoded: exclude for design. [pmid: 9737102].
Woods S, Beaver K, Luker K. Users' views on palliative care services: ethical implications. Nurs Ethics. 2000;7(4):314-26. [Rec#: 16448] article not received prior to report production. [pmid: 11221408].
Workman RH Jr, Orengo CA, Bakey AA, Molinari VA, and Kunik ME. The use of risperidone for psychosis and agitation in demented patients with Parkinson's disease. J Neuropsychiatry Clin Neurosci 97;9(4):594–7. Comment in: J Neuropsychiatry Clin Neurosci. 1998 Fall;10(4):473–5. PMID: 9813797. [Rec#: 36103] Recoded: exclude for design
Worley K, Henderson S. Speaking of difficult choices: the creation of a drama and dialogue group on end-of-life choices. Gerontologist. 95;35(3):412-4. [Rec#: 8319] Recoded: no outcomes specified. [pmid: 7622094].
Yoshioka H. Rehabilitation for the terminal cancer patient. Am J Phys Med Rehabil. 94;73(3):199-206. [Rec#: 8385] article not received prior to report production. [pmid: 7515247].
Zeppetella G, O'Doherty CA, Collins S. Prevalence and characteristics of breakthrough pain in cancer patients admitted to a hospice. J Pain Symptom Manage 2000;20(2):87–92. Erratum in: J Pain Symptom Manage 2001 Mar;21(3):265. [Rec#: 8425] article not received prior to report production
Zeppetella G. Sublingual fentanyl citrate for cancer-related breakthrough pain: a pilot study. Palliat Med. 2001;15(4):323-8. [Rec#: 8424] Recoded: exclude for design. [pmid: 12054149].