# Appendixes

Appendix A. The Scope of the “End of Life”

Appendix B. Search Strategies

Appendix C. Health Canada Reports

Appendix D

Appendix E. Intervention Studies Evidence Tables

Appendix F. TEP and Peer Reviewers

Appendix G. Cambridge Ballot

Appendix H

Appendix I. Bibliography of Excluded Abstracts

Appendix J. Bibliography of Excluded Articles

Appendix K. REVIEWER COMMENTS

Appendix L. Observational Studies Evidence Tables

Appendix M. Included Studies