# Supplemental Evidence Tables

Supplemental Evidence Table B4. Treatment Results of Studies with Drug vs. Drug Comparisons^1^ Academic (Scales used for test scores may vary across studies)

Author(s) & Year of Publication | Arm | Interventions | Tests Used | Test Scores | | Test Scores | | Statistical Significance ^2^ (p<0.05 rated as significant)
Author(s) & Year of Publication | Arm | Interventions | Tests Used | Arm 1 Mean ± SD | Arm 2 Mean ±SD | Arm 3 Mean ±SD | Arm 4 Mean ±SD | Statistical Significance ^2^ (p<0.05 rated as significant)
Same drug comparisons
Arnold 1976 | 1 2 3 | Placebo DEX L-Amph | Social Competence: Conners parent Achievement Tests: David's Hyperkinetic Rating Scale (parent) David's Hyperkinetic Rating Scale (teacher) | 32.13 ±10.5 4.45 ±1.61 4.67 ± 1.6 | 28.0 ±11.2 3.9 ±1.72 4.2 ±1.81 | 48.9 ±14.9 3.79 ±1.18 3.93 ±1.33 | 27.07 ±17.3 4.48 ±1.24 4.66 ±1.32 | NR NR MPH, DEX > Placebo,Caffeine; Placebo vs. Caffeine = NS; MPH vs. DEX = NS
Whitehouse 1980 | 1 2 | MPH MPH-SR | Social Competence: Unspecified parent report Unspecified teacher report Achievement Tests: Unspecified parent report | 4 ^3^ 7 ^3^ 6 ^3^ | 4 ^3^ 8 ^3^ 7 ^3^ | | | NS NS NS
Stimulant vs. stimulant comparisons
Arnold 1978 | 1 2 3 4 | Placebo MPH DEX Caffeine | Social Competence: Problem behavior checklist -- parent Achievement Tests: David's Hyperkinetic Rating Scale (parent) David's Hyperkinetic Rating Scale (teacher) | 63.24 ±16.6 4.34 ±1.11 4.62 ±1.29 | 51.24 ±14.8 3.69 ±1.28 3.83 ±1.28 | 28.52 ±10.1 4.16 ±1.42 4.3 ±1.66 | | NR NR NR
Conners 1980 | 1 2 3 | Placebo MPH Pemoline | Social Competence: Conners parent Conners teacher Achievement Tests: WISC | 0.11 ±0.17 0.9 ±0.63 97.65 ±0.53 | 0.08 ±0.19 0.71 ±0.74 104.2 ±0.51 | 0.06 ±0.15 0.41 ±0.46 101.22 ±0.62 | | NS NS MPH, Pemoline > Placebo; MPH vs. Pemoline = NS
Conners 1972 | 1 2 3 | Placebo DEX Pemoline | Social Competence: Conners parent Conners teacher Achievement Tests: WISC Grades: Report only | 1.7 ^3^ 2.2 ^3^ 3.52 ^3^ 34.8% | 0.9 ^3^ 2.6 ^3^ 7.58 ^3^ 76.2% | 0.5 ^3^ 2.5 ^3^ 4.76 ^3^ 63.6% | | DEX, Pemoline > Placebo; DEX vs. Pemoline = NS NS NS NR
Efron 1997 | 1 2 | MPH DEX | Grades: Conners parent | 68.79 ±15.1 | 69.16 ±15.7 | | | NS
Stimulant vs. tricyclic antidepressants
Werry 1980 | 1 2 3 | Placebo MPH Imipramine | Social Competence: Conners parent Achievement Tests: Conners parent | 0.04 ^3^ 0.43 ^3^ | 0.04 ^3^ 0.55 ^3^ | 0.03 ^3^ 0.38 ^3^ | | NS NS

1 Studies in this group with no data with outcomes of interest given are: Borcherding 1989; Castellanos 1997; Elia 1991; Fitzpatrick 1992; Gross 1976; Kauffman 1981; Matochik 1994; Pelham 1990; Pelham 1987; Quinn 1975; Rapport 1993; Spring 1976; Srinivas 1992; Stephens 1984; Winsberg 1974.

2 > = better than; NS-not significant; NR-statistical significance not reported.

3 SD not given.

Supplemental Evidence Table B5. Treatment Results of Studies with Drug vs. Drug Comparisons^1^ Psychological Conduct/Oppositional (Scales used for test scores may vary across studies)

Author(s) & Year of Publication | Arm | Interventions | Tests Used | Test Scores | | Test Scores | | | Statistical Significance ^2^ (p<0.05 rated as significant)
Author(s) & Year of Publication | Arm | Interventions | Tests Used | Arm 1 Mean ± SD | Arm 2 Mean ±SD | Arm 3 Mean ± SD | Arm 4 Mean ± SD | Arm 5 Mean ± SD | Statistical Significance ^2^ (p<0.05 rated as significant)
Same drug comparisons
Arnold 1978 | 1 2 3 4 | Placebo MPH DEX Caffeine | CD: Conners teacher | 35.28 ±13.7 | 27.76 ±12.3 | 25.03 ±9.8 | 35.41 ±12.7 | | NR
Fitzpatrick 1992 | 1 2 3 4 | Placebo MPH-SR 0.67 mg/kg MPH 0.56 mg/kg MPH-SR 0.67 mg/kg + MPH 0.38 mg/kg | Agressiveness: TOTS Unspecified teacher report | 1.15 ±0.61 0.7 ±0.72 | 0.68 ±0.53 0.31 ±0.5 | 0.56 ±0.37 0.24 ±0.32 | 0.6 ±0.39 0.26 ±0.31 | | MPH, MPH-ST, MPH+MPH-SR > Placebo MPH, MPH-SR, MPH + MPH-SR = NS
Whitehouse 1980 | 1 2 | MPH MPH-SR | CD: Unspecified parent report Unspecified teacher report | 12 ^3^ 17 ^3^ | 11 ^3^ 22 ^3^ | | | | MPH-SR > MPH MPH > MPH-SR
Stimulant vs. stimulant comparisons
Arnold 1976 | 1 2 3 | Placebo DEX L-Amph | Aggressiveness: Conners parent Conners teacher | 58.77 ±18.3 32.83 ±12.9 | 49.55 ±19.4 24.93 ±10.7 | 51.16 ±17.4 25.57 ±10.7 | | | DEX, L-Amph > Placebo DEX, L-Amph > Placebo
Conners 1980 | 1 2 3 | Placebo MPH Pemoline | CD: Conners parent Conners teacher | 1.0 ±0.53 0.71 ±0.48 | 0.64 ±0.36 0.68 ±0.55 | 0.77 ±0.46 0.53 ±0.48 | | | NS NS
Conners 1972 | 1 2 3 | Placebo DEX Pemoline | ODD: Conners teacher CD: Conners parent | 12.2 ^3^ 16.7 ^3^ | 4.9 ^3^ 12.3 ^3^ | 9.7 ^3^ 12.6 ^3^ | | | DEX, Pemoline > Placebo; DEX vs. Pemoline = NS DEX, Pemoline > Placebo; DEX vs. Pemoline = NS
Efron 1997 | 1 2 | MPH DEX | CD: Conners parent Conners teacher | 60.66 ±14.9 55.16 ±12 | 62.39 ±16.8 58.39 ±13.7 | | | | NS MPH > DEX
Elia 1991 | 1 2 3 | Placebo MPH DEX | CD: Conners parent Conners teacher Behavior disturbances: Children's Psychiatric Rating Scale | 0.95 ^3^ 0.5 ^3^ 15% | 0.7 ^3^ 0.5 ^3^ 50% | 0.55 ^3^ 0.1 ^3^ 44% | | | NS MPH, DEX > Placebo; MPH vs. DEX = NS
Pelham 1990 | 1 2 3 4 5 | Placebo MPH 20 mg MPH-SR 20 mg DEX-SR 10 mg Pemoline | CD: Report only | 0.73 ±1.29 | 0.25 ±0.25 | 0.18 ±0.27 | 0.21 ±0.36 | 0.18 ±0.23 | MPH-SR, DEX-SR, Pemoline > Placebo; MPH vs. Placebo = NS Drug vs. Drug Not Reported
Pelham 1987 | 1 2 3 | Placebo MPH 20 mg MPH-SR 20 mg | CD: Report only | 0.7 ±0.69 | 0.3 ±0.29 | 0.4 ±0.22 | | | MPH, MPH-SR > Placebo; MPH vs. MPH-SR = NS
Stimulant vs. tricyclic antidepressants
Quinn 1975 | 1 2 | MPH Imipramine | CD: Conners parent Conners teacher | 6.47 ±4.34 7.34 ±7.17 | 7.61 ±4.03 5.61 ±6.02 | | | | MPH vs Imipramine = NS MPH vs Imipramine = NS
Werry 1980 | 1 2 3 | Placebo MPH Imipramine | CD: Conners parent Conners teacher | 1.0 ^3^ 1.68 ^3^ | 1.04 ^3^ 1.54 ^3^ | 0.78 ^3^ 1.5 ^3^ | | | Imipramine > MPH, Placebo; MPH vs Placebo = NS NS

1 Studies in this group with no data with outcomes of interest given are: Borcherding 1989; Castellanos 1997; Gross 1976; Kauffman 1981; Matochik 1994; Rapport 1993; Srinivas 1992; Spring 1976; Stephens 1984; Winsberg 1974.

2 > = better than; NS-not significant; NR-statistical significance not reported.

3 SD not given.

Supplemental Evidence Table B6. Treatment Results of Studies with Drug vs. Nondrug Comparisons^1^Psychological - "Internalizing" (Scales used for Test Scores may vary across studies)

Author(s) & Year of Publication | Arm | Interventions | Tests Used | Test Scores | | Test scores | | | Statistical significance ^2^ (p < 0.05 rated as significant)
Author(s) & Year of Publication | Arm | Interventions | Tests Used | Arm 1 Mean ± SD | Arm 2 Mean ±SD | Arm 3 Mean ± SD | Arm 4 Mean ± SD | Arm 5 Mean ± SD | Statistical significance ^2^ (p < 0.05 rated as significant)
Same drug comparisons
Arnold 1976 | 1 2 3 | Placebo DEX L-Amph | Anxiety: Conners teacher | 11.3 ±3.72 | 11.3 ±4.24 | 11.7 ± 4.21 | | | NS
Fitzpatrick 1992 | 1 2 3 4 | Placebo MPH-SR 0.67 mg/kg MPH 0.56 mg/kg MPH-SR 0.67 mg/kg + MPH 0.38 mg/kg | Crying: STESS Sadness: STESS | 31.6% ^4^ 5.3% ^4^ | 21% ^4^ 0% ^4^ | 15.8% 10.5% | 26.3% 0.0% | | NS NS
Whitehouse 1980 | 1 2 | MPH MPH-SR | Anxiety: Unspecified parent report Unspecified teacher report | 9 ^3^ 11 ^3^ | 11 ^3^ 9 ^3^ | | | | NS NS
Stimulant vs. stimulant comparisons
Arnold 1978 | 1 2 3 4 | Placebo MPH DEX Caffeine | Depression: Problem Behaviour Checklist - Parent Anxiety: Conners teacher | 16.66 ±5.48 12.17 ±4.72 | 15.03 ±4.59 11.21 ±4.31 | 14.38 ± 5.28 11.17 ± 3.87 | 16.24 ± 6.15 13.14 ± 5.11 | | NR NR
Conners 1980 | 1 2 3 | Placebo MPH Pemoline | Depression: Report Only Anxiety: Conners parent Conners teacher Crying: Report Only | 4% ^4^ 0.61 ±0.63 0.58 ±0.40 25% ^4^ | 4% ^4^ 0.49 ±0.39 0.71 ±0.40 50% ^4^ | 0% 0.41 ± 0.32 0.56 ± 0.36 25% | | | NR NS NS NR
Conners 1972 | 1 2 3 | Placebo DEX Pemoline | Anxiety: Conners parent Conners teacher | 7.9 ^3^ 6.7 ^3^ | 6.5 ^3^ 6.5 ^3^ | 5.6 ^3^ 5.9 ^3^ | | | NS NS
Efron 1997 | 1 2 | MPH DEX | Anxiety: Conners parent Report only Global mood: Conners parent Sadness: Report only | 47.77 ±9.59 61% ^4^ 53.86 ±15.3 56% ^4^ | 48.67 ±10.1 68% ^4^ 55.94 ±16.0 59% ^4^ | | | | MPH > DEX NR NS NR
Elia 1991 | 1 2 3 | Placebo MPH DEX | Sadness: STESS | 48% ^4^ | 68% ^4^ | 62% | | | MPH, DEX > Placebo, MPH vs. DEX = NS
Stimulant vs. tricyclic antidepressants
Quinn 1975 | 1 2 | MPH Imipramine | Anxiety: Conners parent | 3.6 ±3.31 | 3.46 ±2.6 | | | | NS
Werry 1980 | 1 2 3 | Placebo MPH Imipramine | Self-esteem: Report only Anxiety: Conners parent Conners teacher | 59.44 0.33 ^3^ 1.58 ^3^ | 61.38 0.40 ^3^ 1.66 ^3^ | 61.56 0.31 ^3^ 1.60 ^3^ | | | NS NS NS

1 Studies in this group with no data with outcomes of interest given are: Borcherding 1989, Castellanos 1997, Gross 1976, Kauffman 1981, Matochik 1994, Pelham 1987, Rapport 1993, Spring 1976, Srinivas 1992, Stephens 1984, Winsberg 1974.

2 > = better than; NS-not significant; NR-statistical significance not reported.

3 SD not given.

4 Results given as % score, not as mean value.

Supplemental Evidence Table B7. Treatment Results of Studies with Drug vs. Drug Comparisons^1^ Core/Global symptoms (Scales used for test scores may vary across studies)

Author(s) & Year of Publication | Arm | Interventions | Tests Used | Test Scores | | Test scores | | | Statistical significance ^2^ (p < 0.05 rated as significant)
Author(s) & Year of Publication | Arm | Interventions | Tests Used | Arm 1 Mean ± SD | Arm 2 Mean ±SD | Arm 3 Mean ± SD | Arm 4 Mean ± SD | Arm 5 Mean ± SD | Statistical significance ^2^ (p < 0.05 rated as significant)
Same drug comparisons
Arnold 1976 | 1 2 3 | Placebo DEX L-Amphetamine | Global Symptoms: Conners parent Conners teacher David's Hyperkinetic Rating Scale (parent) David's Hyperkinetic Rating Scale (teacher) Core Symptoms: Conners parent Conners teacher David's Hyperkinetic Rating Scale (parent) David's Hyperkinetic Rating Scale (teacher) Doctor's Target Symptoms Scale | 2.06 ^3^ 2.22 ^3^ 4.63 ^3^ 4.47 ^3^ 166.81 ± 43.5 86.77 ± 23.1 32.42 ± 5.58 31.3 ± 6.3 4.89 ± 1.22 | 1.83 ^3^ 1.85 ^3^ 3.93 ^3^ 3.62 ^3^ 148.32 ± 47.3 72.27 ± 20.4 27.52 ± 8.56 25.37 ± 8.25 3.11 ± 1.52 | 1.89 ^3^ 1.89 ^3^ 4.27 ^3^ 3.84 ^3^ 153.42 ±41.4 73.57 ± 21 29.87 ± 6.25 26.87 ± 7.85 3.42 ± 1.34 | | | DEX, L-Amphetamine > Placebo; DEX vs. L-Amphetamine = NS DEX, L-Amphetamine > Placebo; DEX vs. L-Amphetamine = NS DEX, L-Amphetamine > Placebo; DEX > L-Amphetamine DEX, L-Amphetamine> Placebo; DEX vs. L-Amphetamine = NS NR NR NR NR DEX, L-Amphetamine > Placebo; DEX vs. L-Amphetamine = NS
Fitzpatrick 1992 | 1 2 3 4 | Placebo MPH-SR 0.67 mg/kg MPH 0.56 mg/kg MPH-SR 0.67 mg/kg + MPH 0.38 mg/kg | Conners parent Conners teacher | 1.75 ±0.67 1.36 ±0.8 | 0.98 ±0.72 0.77 ±0.63 | 0.96 ± 0.5 0.73 ± 0.65 | 0.81 ± 0.46 0.58 ± 0.4 | | MPH-SR, MPH, MPH + MPH-SR > Placebo; MPH-SR vs. MPH vs. MPH + MPH-SR = NS MPH-SR, MPH, MPH + MPH-SR > Placebo; MPH-SR vs. MPH vs. MPH + MPH-SR = NS
Pelham 1987 | 1 2 3 | Placebo MPH 20 mg MPH-SR 20 mg | Report only BPC -- teacher Conners teacher | 48.1 ±4.7 114.2 ±39.1 4.6 ±3.75 | 83.2 ±17.2 106.4 ±27.8 1.9 ±2 | 81.8 ± 23.7 105.9 ± 23.7 3.4 ± 4.87 | | | NS NS NS
Whitehouse 1980 | 1 2 | MPH MPH-SR | Patient Report Report only Unspecified parent report Unspecified teacher report | 22 ^3^ 20 ^3^ 144 ^3^ 68 ^3^ | 23 ^3^ 21 ^3^ 150 ^3^ 73 ^3^ | | | | NS NS NS MPH > MPH-SR
Stimulant vs. stimulant comparisons
Arnold 1978 | 1 2 3 4 | Placebo MPH DEX Caffeine | Conners teacher David's Hyperkinetic Rating Scale (parent) David's Hyperkinetic Rating scale (teacher) Doctor's Target Symptoms Scale Problem Behavior Checklist Report only (efficacious) | 90.1 ± 20.5 29.97 ± 4.58 29.07 ± 5.2 5 ± 1.09 179.97 ± 38.2 NA | 73.55 ± 2.4 25.41 ± 5.19 23.14 ± 7.08 3.38 ± 1.36 152.28 ± 34.8 73% ^4^ | 70.26 ± 8.3 25.31 ± 5.57 22.38 ± 7.2 3.13 ± 1.47 146.97± 36.6 66% ^4^ | 90 ± 21.8 28.93 ± .49 28.48 ±6.52 4.6 ± 1.47 167.31± 4.5 14% ^4^ | | MPH, DEX > Placebo; MPH, DEX > Caffeine; Caffeine vs. Placebo = NS; MPH vs. DEX = NS MPH, DEX > Placebo; MPH, DEX > Caffeine; Caffeine vs. Placebo = NS; MPH vs. DEX = NS MPH, DEX > Placebo; MPH, DEX > Caffeine; Caffeine vs. Placebo = NS; MPH vs. DEX = NS MPH, DEX > Placebo; MPH, DEX > Caffeine; Caffeine vs. Placebo = NS; MPH vs. DEX = NS MPH, DEX, Caffeine > Placebo; MPH, DEX > Caffeine; MPH vs. DEX = NS NR
Conners 1980 | 1 2 3 | Placebo MPH Pemoline | Report only | 34% ^4^ | 90% ^4^ | 88% ^4^ | | | Pemoline, MPH > Placebo; Pemoline vs. MPH = NS
Conners 1972 | 1 2 3 | Placebo DEX Pemoline | Global Symptoms: Conners teacher (counselor report) Conners teachers (teacher) Core Symptoms: Conners parent Conners teacher | 29.6% ^4^ 30.4% ^4^ 16 ^3^ 16 ^3^ | 99.3% ^4^ 77.3% ^4^ 10 ^3^ 9 ^3^ | 77.8% ^4^ 63.6% ^4^ 12 ^3^ 11 ^3^ | | | NR NR DEX, Pemoline > Placebo; DEX vs. Pemoline = NS DEX, Pemoline > Placebo; DEX vs. Pemoline = NS
Efron 1997 | 1 2 | MPH DEX | Conners parent Conners teacher | 64.28 ± 13.5 56.14 ± 10.2 | 64.89 ± 13.7 58.76 ± 10.6 | | | | NR NR
Elia 1991 | 1 2 3 | Placebo MPH DEX | Clinical Global Impressions Global Assessment Scale | 4.1 ^3^ 47 ^3^ | 2.6 ^3^ 53 ^3^ | 2.4 ^3^ 52 ^3^ | | | DEX, MPH > Placebo; DEX vs. MPH = NS DEX, MPH > Placebo; DEX vs. MPH = NS
Matochik 1994 | 1 2 | MPH DEX | Clinical Global Impressions Conners child Conners teacher | 2.1 ± 1 5 ± 3.2 5.7 ± 4.5 | 1.9 ± 0.9 4.6 ± 4.8 8.3 = 5.6 | | | | NR NR NR
Pelham 1990 | 1 2 3 4 5 | Placebo MPH 20 mg MPH-SR 20 mg DEX-SR 10 mg Pemoline | Report only Conners teacher (counselor report) Conners teacher (teacher report) | 51 ±23 6.3 ±4.8 3.8 ±4.6 | 63 ±24 4.8 ±3.2 2.3 ±2 | 64 ± 22 5 ± 3.6 2.3 ± 2.1 | 67 ± 27 4.5 ± 3 1.7 ±1.4 | 71 ± 27 5.1 ± 3.5 1.5 ± 1.5 | MPH-SR, DEX-SR, Pemoline > Placebo; MPH vs. Placebo = NS MPH, MPH-SR, DEX-SR > Placebo; Pemoline vs. Placebo = NS DEX-SR, Pemoline > Placebo; MPH, MPH-SR vs. Placebo = NS (Drug vs. Drug for all tests, not reported)
Stimulant vs. tricyclic antidepressants
Werry 1980 | 1 2 3 | Placebo MPH Imipramine | Clinical Global Impressions | 4.04 ^3^ | 3.52 ^3^ | 2.78 ^3^ | | | Imipramine > MPH; Imipramine > Placebo

1 Studies in this group with no data with outcomes of interest given are: Borcherding 1989; Castellanos 1997; Gross 1976; Kauffman 1981; Quinn 1975; Rapport 1993; Spring 1976; Srinivas 1992; Stephens 1984; Winsberg 1974.

2 > = better than; NS-not significant; NR-statistical significance not reported.

3 SD not given.

4 Results given as % score, not as mean value.

Supplemental Evidence Table B8. Treatment Results of Studies with Drug vs. Drug Comparisons^1^Inattention-Hyperactivity-Impulsivity (Scales used for test scores may vary across studies)

Author(s) & Year of Publication | Arm | Interventions | Tests Used | Test Scores | | Test Scores | | Statistical Significance ^2^ (p<0.05 rated as significant)
Author(s) & Year of Publication | Arm | Interventions | Tests Used | Arm 1 Mean ± SD | Arm 2 Mean ± SD | Arm 3 Mean ± SD | Arm 4 Mean ± SD | Statistical Significance ^2^ (p<0.05 rated as significant)
Same drug comparisons
Arnold 1978 | 1 2 3 4 | Placebo MPH DEX Caffeine | Inattention: Conners teacher David's Hyperkinetic Rating Scale (parent) David's Hyperkinetic Rating Scale (teacher) Problem Behavior Checklist - parent Hyperactivity: Conners teacher David's Hyperkinetic Rating Scale (parent) David's Hyperkinetic Rating Scale (teacher) Problem Behavior Checklist -- parent Impulsivity: David's Hyperkinetic Rating Scale (parent) David's Hyperkinetic Rating Scale (teacher) | 14. 62 ± 3.51 5.1 ± 0.86 5.07 ± 1.0 14.66 ± 3.98 22.52 ± 5.23 5.21 ± 0.82 5.03 ± 1.15 23.69 ± 5.87 4.97 ± 0.98 5.1 ± 1.01 | 12.1 ± 3.53 3.9 ± 1.01 3.97 ± 1.18 11.83 ± 3.79 16.83 ± 5.5 4.31 ± 1.23 3.83 ± 1.49 18.21 ± 5.61 4.1 ± 1.21 3.97 ± 1.28 | 12.03 ± 3.94 4.21 ± 0.94 3.79 ± 1.35 11.38 ± 3.39 16.17 ± 4.64 4.28 ± 1.07 3.9 ± 1.54 17.21 ± 5.45 4.17 ± 1.04 3.9 ± 1.42 | 14.24 ± 4.06 4.69 ± 0.93 5.07 ± 1.16 13.55 ± 4.95 21.66 ± 5.88 5.0 ± 0.89 4.93 ± 1.39 20.38 ± 6.34 4.83 ± 0.85 4.97 ± 1.15 | NR NR NR NR NR NR NR NR NR NR
Fitzpatrick 1992 | 1 2 3 4 | Placebo MPH-SR 0.67 mg/kg MPH 0.56 mg/kg MPH-SR 0.67 mg/kg + MPH 0.38 mg/kg | Inattention: Conners parent Conners teacher TOTS Unspecified teacher report Hyperactivity: TOTS Unspecified teacher report | 1.9 ± 0.63 1.65 ± 039 0.36 ± 0.41 0.67 ± 0.62 0.7 ± 0.48 0.36 ± 0.69 | 0.98 ± 0.61 0.92 ± 0.68 0.72 ± 0.38 0.88 ± 0.62 0.22 ± 0.5 -0.12 ± 0.51 | 1.01 ± 0.46 0.87 ± 0.63 0.81 ± 0.41 1.01 ± 0.57 0.2 ± 0.31 -0.16 ± 0.44 | 0.79 ± 0.48 0.7 ± 0.56 0.91 ± 0344 1.05 ± 0.52 0.18 ± 0.49 -0.29 ± 0.56 | "Dose group" > Placebo "Dose group" > Placebo "Dose group" > Placebo "Dose group" > Placebo "Dose group" > Placebo "Dose group" > Placebo
Whitehouse 1980 | 1 2 | MPH MPH-SR | Inattention: Unspecified teacher report Hyperactivity: Unspecified parent report Unspecified teacher report | 13 ^3^ 15 ^3^ 15 ^3^ | 13 ^3^ 15 ^3^ 17 ^3^ | | | NS NS NS
Stimulant vs. stimulant comparisons
Arnold 1976 | 1 2 3 | Placebo DEX L-Amph | Inattention: Conners parent Conners teacher David's Hyperkinetic Rating Scale (parent) David's Hyperkinetic Rating Scale (teacher) Hyperactivity: Conners parent Conners teacher David's Hyperkinetic Rating Scale (parent) David's Hyperkinetic Rating Scale (teacher) Impulsivity: David's Hyperkinetic Rating Scale (parent) David's Hyperkinetic Rating Scale (teacher) | 14.65 ± 4.79 15.33 ± 3.83 4.52 ± 1.29 4.73 ± 1.55 20.81 ± 6.83 21.27 ± 5.63 4.58 ± 1.26 4.9 ± 1.3 4.87 ± 1.02 4.6 ± 1.3 | 11.9 ± 5.09 13.4 ± 4.26 3.84 ± 1.53 3.83 ± 1.62 16.68 ± 6.59 16.8 ± 5.54 3.97 ± 1.4 3.7 ± 1.49 4.06 ± 1.46 3.77 ± 1.41 | 12.19 ± 4.4 13.53 ± 4.46 4.13 ± 1.34 4.33 ± 1.45 18.39 ± 6.03 17.2 ± 5.76 4.32 ± 1.17 3.77 ± 1.45 4.39 ± 1.26 3.87 ± 1.41 | | NR NR NR NR NR NR NR NR NR NR
Conners 1980 | 1 2 3 | Placebo MPH Pemoline | Inattention: Conners teacher Hyperactivity: Conners parent Conners teacher Impulsivity: Conners parent | 1.25 ± 0.73 0.75 ± 0.36 1.45 ± 0.63 1.31 ± 0.57 | 1.2 ± 0.73 0.46 ± 0.23 1.28 ± 0.67 0.69 ± 0.52 | 1.07 ± 0.42 0.41 ± 0.16 1.04 ± 0.52 0.7 ± 0.33 | | MPH, Pemoline vs. Placebo = NS NS NS MPH, Pemoline > Placebo; MPH vs. Pemoline = NS
Stimulant vs. stimulant comparisons (cont.)
Conners 1972 | 1 2 3 | Placebo DEX Pemoline | Inattention: Conners teacher Hyperactivity: Conners parent Conners teacher Impulsivity: Conners parent | 9.8 ^3^ 13.4 ^3^ 13.3 ^3^ 19.1 ^3^ | 6.4 ^3^ 10.6 ^3^ 6.2 ^3^ 11 ^3^ | 7.7 ^3^ 10 ^3^ 9.8 ^3^ 13.2 ^3^ | | DEX, Pemoline > Placebo; DEX vs. Pemoline = NS DEX > Placebo; DEX, Placebo vs. Pemoline = NS DEX, Pemoline > Placebo; DEX vs. Pemoline = NS DEX, Pemoline > Placebo; DEX vs. Pemoline = NS
Efron 1997 | 1 2 | MPH DEX | Inattention: Conners teacher Hyperactivity: Conners teacher Impulsivity: Conners parent | 54.09 ± 7.61 52.2 ± 11.0 57.39 ± 10.5 | 55.69 ± 8.9 58.88 ± 11.1 57.33 ± 11.2 | | | MPH > DEX MPH > DEX NS
Elia 1991 | 1 2 3 | Placebo MPH DEX | Hyperactivity: Conners parent Conners teacher | 1.7 ^3^ 1.4 ^3^ | 1 ^3^ 0.4 ^3^ | 0.8 ^3^ 0.5 ^3^ | | MPH, DEX > Placebo; MPH vs. DEX = NS MPH, DEX > Placebo; MPH vs. DEX = NS
Matochik 1994 | 1 2 | MPH DEX | Inattention: STESS | 0.4 ± 0.6 | 0.6 ± 0.9 | | | NR
Stimulant vs. tricyclic antidepressants
Quinn 1975 | 1 2 | MPH Imipramine | Hyperactivity: Conners parent Conners teacher | 6.69 ± 3.59 8.3 ± 4.66 | 6.76 ± 3.74 8.07 ± 5.12 | | | Imipramine vs. MPH = NS Imipramine vs. MPH = NS
Werry 1980 | 1 2 3 | Placebo MPH Imipramine | Inattention: Conners teacher Hyperactivity: Conners parent Conners teacher | 2.14 ^3^ 1.17 ^3^ 2.56 ^3^ | 1.95 ^3^ 1.29 ^3^ 2.22 ^3^ | 2.02 ^3^ 1.04 ^3^ 2.34 ^3^ | | NS Imipramine > MPH NS

1 Studies in this group with no data with outcomes of interest given are: Borcherding 1989 ; Castellanos 1997 ; Gross 1976 ; Kauffman 1981 ; Pelham 1987 ; Pelham 1990 ; Rapport 1993 ; Spring 1976 ; Srinivas 1992 ; Stephens 1984 ; Winsberg 1974.

2 > = better than; NS-not significant; NR-statistical significance not reported.

3 SD not given.

Supplemental Evidence Table C4. Treatment Results of Studies with Drug vs. Nondrug Comparisons^1^ Academic (Scales used for test scores may vary across studies)

Author(s) & Year of Publication | Arm | Interventions | Tests Used | Test Scores | | Test Scores | | Statistical Significance ^2^ (p<0.05 rated as significant)
Author(s) & Year of Publication | Arm | Interventions | Tests Used | Arm 1 Mean ± SD | Arm 2 Mean ±SD | Arm 3 Mean ±SD | Arm 4 Mean ±SD | Statistical Significance ^2^ (p<0.05 rated as significant)
Brown 1985 | 1 2 3 | MPH MPH + CBT CBT | Reading: DETROIT 13 DETROIT 16 DETROIT 6 WRAT Arithmetic: WRAT | 51.5 ± 10.4 11.5 ± 4.6 37.4 ± 8.2 65.4 ± 15.2 27.0 ± 7.8 | 51.4 ± 6.7 13.0 ± 4.8 41.8 ± 12.1 59.8 ± 15.1 26.4 ± 5.3 | 59.4 ± 9.9 14.1 ± 2.0 44.0 ± 4.3 62.5 ± 10.2 29.4 ± 7.6 | | NR NR NR NR NR
Firestone 1986 | 1 2 3 | Placebo + PT MPH MPH + PT | Verbal: Gates-McGintie reading test | 3.23 ± 2.47 | 3.34 ± 2.23 | 3.44 ± 1.65 | | Placebo + PT, MPH, MPH + PT = NS
Klein 1997 | 1 2 3 | Placebo + CBT MPH MPH + CBT | Social Competence: Conners teachers Conners parent Reading: WRAT Arithmetic: WRAT Spelling: WRAT Achievement: WISC | 0.8 ± 0.6 0.3 ± 0.6 3.73 ± 1.8 3.12 ± 1.0 3.1 ± 1.2 102.9 ± 14.1 | 0.5 ± 0.6 0.2 ± 0.3 3.9 ± 1.9 3.3 ± 1.1 3.3 ± 1.6 108.0 ± 13.5 | 0.5 ± 0.6 0.2 ± 0.3 3.9 ± 1.9 3.3 ± 1.1 3.3 ± 1.6 104.7 ± 13.7 | | MPH + CBT, MPH> Placebo + CBT; MPH vs. MPH + CBT = NS NS NS NS NS NS
MTA Coop Study Group 1999 | 1 2 3 4 | Medication (MedMgt) Psychosocial (Beh) Combined Med +Psychosocial (Comb) Assessment & Referral (CC) | Reading Weschler Arithmetic: Weschler Spelling: Weschler Social Competence: Social Skills Rating System -- Teacher Social Skills Rating System -- Parent | 97.9 ± 14.1 99.7 ± 13.0 96.0 ± 14.8 1.15 ± 0.32 1.17 ± 0.26 | 96.2 ± 14.9 100.3 ± 13.7 93.7 ± 13.9 1.06 ± 0.32 1.15 ± 0.24 | 99.4 ± 15.2 100.3 ± 16.4 97.0 ± 14.4 1.19 ± 0.30 1.22 ± 0.27 | 95.5 ± 14.3 98.6 ± 14.1 93.7 ± 13.1 1.05 ± 0.31 1.15 ± 0.25 | Comb > CC; Comb ~ MedMgt (NS) NS NS Comb, MedMgt,> CC; Comb ~ MedMgt NS

1 Studies in this group with no data with outcomes of interest given are: Arnold 1989; Conrad 1971.

2 > = better than; NS-not significant; NR-statistical significance not reported.

Supplemental Evidence Table C5. Treatment Results of Studies with Drug vs. Nondrug Comparisons^1^Psychological Conduct/Oppositional (Scales used for test scores may vary across studies)

Author(s) & Year of Publication | Arm | Interventions | Tests Used | Test Scores | | Test Scores | | Statistical Significance ^2^ (p<0.05 rated as significant)
Author(s) & Year of Publication | Arm | Interventions | Tests Used | Arm 1 Mean ± SD | Arm 2 Mean ±SD | Arm 3 Mean ±SD | Arm 4 Mean ±SD | Statistical Significance ^2^ (p<0.05 rated as significant)
Firestone 1986 | 1 2 3 | Placebo + PT MPH MPH + PT | CD: Peterson Quay Behavior Problem Checklist | 8.33 ± 4.14 | 5.75 ± 3.53 | 5.4 ± 3.67 | | MPH, MPH + PT > Placebo + PT; MPH vs MPH + PT = NS
Klein 1997 | 1 2 3 | Placebo + CBT MPH MPH + CBT | CD: Conners teacher Conners parent | 0.8 ± 0.7 0.9 ± 0.5 | 0.3 ± 0.5 0.8 ± 0.6 | 0.1 ± 0.3 0.6 ± 0.3 | | MPH + CBT, MPH > Placebo + CBT; MPH vs MPH + CBT = NS (Teacher) MPH + CBT > Placebo + CBT (Parent) MPH + CBT, MPH > Placebo + CBT; MPH vs MPH + CBT = NS
MTA Coop Study Group 1999 | 1 2 3 4 | Medication (MedMgt) Psychosocial (Beh) Combined Med + Psychosocial (Comb) Assessment & Referral (CC) | ODD: SNAP -- parent SNAP -- teacher Abikoff Classroom | 0.94 ± 0.74 0.65 ± 0.68 0.004 ± 0.011 | 1.05 ± 0.74 0.97 ± 0.80 0.010 ± 0.018 | 0.76 ± 0.64 0 61 ± 0.68 0.007 ± 0.015 | 1.11 ± 0.67 1.0± 0.84 0.006 ± 0.014 | Comb > Beh, CC; MedMgt ~ Beh; MedMgt, Beh ~ CC MedMgt ~ Beh; Comb ~ MedMgt, Beh; Comb, MedMgt > CC; Beh ~ CC NS

1 Studies in this group with no data with outcomes of interest given are: Arnold 1989; Brown 1985; Conrad 1971.

2 > = better than; NS-not significant; NR-statistical significance not reported.

Supplemental Evidence Table C6. Treatment Results of Studies with Drug vs. Nondrug Comparisons^1^Psychological - "Internalizing" (Scales used for Test Scores may vary across studies)

Author(s) & Year of Publication | Arm | Interventions | Tests Used | Test Scores | Test Scores | | | Statistical Significance ^2^ (p<0.05 rated as significant)
Author(s) & Year of Publication | Arm | Interventions | Tests Used | Arm 1 Mean ± SD | Arm 2 Mean ± SD | Arm 3 Mean ± SD | Arm 4 Mean ± SD | Statistical Significance ^2^ (p<0.05 rated as significant)
Klein 1997 | 1 2 3 | Placebo + CBT MPH MPH + CBT | Anxiety: Conners parent Conners teacher | 0.5 ± 0.4 0.3 ± 0.4 | 0.5 ± 0.4 0.4 ± 0.4 | 0.4 ± 0.6 0.5 ± 0.3 | | NS NS
MTA Coop Study Group 1999 | 1 2 3 4 | Medication (MedMgt) Psychosocial (Beh Combined Med + Psychosocial (Comb Assessment & Referral (CC) | Anxiety: Multidimensional Anxiety Scale for Children (MASC) Social Skills Rating System (SSRS): Parent Social Skills Rating System (SSRS): Teacher | 2.22 ± 0.47 0.67 ± 0.39 0.63 ± 0.47 | 2.27 ± 0.49 0.77 ± 0.40 0.58 ± 0.40 | 2.33 ± 0.47 0.67 ± 0.37 0.68 ± 0.44 | 2.27 ± 0.45 0.82 ± 0.43 0.69 ± 0.44 | NS Comb > Beh, CC; MedMgt ~ Beh, CC; Comb ~ CC NS

1 Studies in this group with no data with outcomes of interest given are: Arnold 1989; Brown 1985; Conrad 1971; Firestone 1986.

2 > = better than; NS-not significant; NR-statistical significance not reported.

Supplemental Evidence Table C7. Treatment Results of Studies with Drug vs. Nondrug Comparisons^1^Core/Global Symptoms (Scales used for test scores may vary across studies)

Author(s) & Year of Publication | Arm | Interventions | Tests Used | Test Scores | | Test Scores | | Statistical Significance ^2^ (p<0.05 rated as significant)
Author(s) & Year of Publication | Arm | Interventions | Tests Used | Arm 1 Mean ± SD | Arm 2 Mean ± SD | Arm 3 Mean ± SD | Arm 4 Mean ±SD | Statistical Significance ^2^ (p<0.05 rated as significant)
Arnold 1989 | 1 2 3 | Placebo DEX Efamol | Conners teacher Physician.s Global Rating Scale | 1.59 ± 0.39 3.78 ^3^ | 1.11 ± 0.57 2.67 ^3^ | 1.39 ± 0.58 3.17 | | DEX > Placebo, Placebo, DEX vs. Efamol = NS DEX > Placebo, Placebo, DEX vs. Efamol = NS
Brown 1985 | 1 2 3 | MPH MPH + CBT CBT | Conners parent Conners teacher | 7.4 ± 5.8 15 ± 3.1 | 7.5 ± 2.6 15.1 ± 4.6 | 13.1 ± 4.1 15.7 ± 2.9 | | NR NR
Firestone 1986 | 1 2 3 | Placebo + PT MPH MPH + PT | Unspecified Reaction Performance | 0.82 ± 0.23 | 0.67 ± 0.24 | 0.68 ± 0.23 | | MPH, MPH + PT > Placebo + PT; MPH vs. MPH + PT = NS
Klein 1997 | 1 2 3 | Placebo + CBT MPH MPH + CBT | Conners teacher | 2.1 ± 0.9 | 1.2 ± 1.0 | 0.9 ± 0.8 | | CBT + MPH > MPH (p<.02) teacher CGI BT vs. MTP = NS
MTA Coop Study Group 1999 | 1 2 3 4 | Medication (MedMgt) Psychosocial (Beh) Combined Med + Psychosocial (Comb) Assessment & Referral (CC) | Global symptoms: Abikoff Classroom | 0.16 ± 0.15 | 0.29 ± 0.26 | 0.21 ± 0.20 | 0.18 ± 0.15 | NS

1 Studies in this group with no data with outcomes of interest given are: Conrad 1971.

2 > = better than; NS-not significant; NR-statistical significance not reported.

3 SD not given.

Supplemental Evidence Table C8. Treatment Results of Studies with Drug vs. Nondrug Comparisons^1^Inattention-Hyperactivity-Impulsivity (Scales used for test scores may vary across studies)

Author(s) & Year of Publication | Arm | Interventions | Tests Used | Test Scores | | Test Scores | | Statistical Significance ^2^ (p<0.05 rated as significant)
Author(s) & Year of Publication | Arm | Interventions | Tests Used | Arm 1 Mean ± SD | Arm 2 Mean ± SD | Arm 3 Mean ± SD | Arm 4 Mean ± SD | Statistical Significance ^2^ (p<0.05 rated as significant)
Arnold 1989 | 1 2 3 | Placebo DEX Efamol | Hyperactivity: Conners teacher | 2.1 ± 0.47 | 1.39 ± 0.78 | 1.81 ± 0.67 | | DEX > Placebo, Efamol; Efamol > Placebo
Brown 1985 | 1 2 3 | MPH MPH + CBT CBT | Inattention: CCT CEFT Teacher rating scale of attention WISC Impulsivity: Children's rating scale of impulsivity MFFT Teacher rating scale of impulsivity Listening: Durrell analysis of listening comprehension | 10.9 ^3^ 14.3 ± 5.0 48.2 ± 10.4 69.5 ± 11.5 67.9 ± 4.2 4.4 ± 4.1 61.7 ± 3.2 33.6 ± 5.6 | 7.4 ^3^ 16.6 ± 6.1 46.6 ± 7.5 72.8 ± 21.5 67.4 ± 5.8 4.7 ± 2.7 61.6 ± 8.1 30.2 ± 5.9 | 16.8 ^3^ 22.0 ± 4.5 51.4 ± 9.1 70.6 ± 11.9 71.8 ± 12.5 6.8 ± 3.3 61.2 ± 9.0 32.4 ± 7.9 | | NR NR NR NR NR NR NR NR
Firestone 1986 | 1 2 3 | Placebo + PT MPH MPH + PT | Hyperactivity: Conners teacher | 1.37 ± 0.57 | 0.91 ± 0.58 | 0.89 ± 0.49 | | MPH, MPH + PT > Placebo + PT; MPH vs. MPH + PT = NS
Klein 1997 | 1 2 3 | Placebo + CBT MPH MPH + CBT | Inattention: Conners teacher Hyperactivity: Conners teacher Conners parent CPRS Impulsivity: Conners parent | 1.2 ± 0.6 1.5 ± 0.6 0.8 ± 0.4 2.6 ± 0.6 0.8 ± 0.7 | 0.9 ± 0.5 1.1 ± 0.4 0.7 ± 0.5 1.7 ± 1.1 0.7 ± 0.8 | 0.7 ± 0.5 0.8 ± 0.4 0.6 ± 0.3 1.5 ± 1.3 0.5 ± 0.5 | | BT vs BT + M p<.001 BT vs MTP p<.01; BT vs BT + M p<.001 NS BT vs MTP p<.05; BT vs BT + M p<.02 NS
MTA Coop Study Group 1999 | 1 2 3 4 | Medication (MedMgt) Psychosocial (Beh) Combined Med + Psychosocial (Comb) Assessment & Referral (CC) | Inattention: SNAP -- parent SNAP -- teacher Hyperactivity: SNAP -- parent SNAP -- teacher | 1.12 ± 0.7 1.11 ± 0.77 0.91 ± 0.65 0.82 ± 0.69 | 1.40 ± 0.7 1.47 ± 0.8 1.24 ± 0.72 1.10 ± 0.77 | 1.02 ± 0.66 1.12 ± 0.75 0.85 ± 0.63 0.75 ± 0.71 | 1.49 ± 0.67 1.48 ± 0.82 1.35 ± 0.72 1.25 ± 0.84 | MedMgt, Comb > Beh, CC; Comb ~ MedMgt; Beh ~ CC MedMgt, Comb > Beh, CC; Comb ~ MedMgt; Beh ~ CC MedMgt, Comb > Beh, CC; Comb ~ MedMgt; Beh ~ CC Comb, MedMgt > CC; MedMgt, Comb ~ Beh; Beh ~ CC

1 Studies in this group with no data with outcomes of interest given are: Conrad 1971.

2 > = better than; NS-not significant; NR-statistical significance not reported.

3 SD not given.

Supplemental Evidence Table D4. Treatment Results of Studies with Combination Treatments^1^ Academic(Scales used for test scores may vary across studies)

Author(s) & Year of Publication | Arm | Interventions | Tests Used | Test Scores | | Test Scores | | Statistical Significance ^2^ (p>0.05 rated as significant)
Author(s) & Year of Publication | Arm | Interventions | Tests Used | Arm 1 Mean ± SD | Arm 2 Mean ± SD | Arm 3 Mean ± SD | Arm 4 Mean ± SD | Statistical Significance ^2^ (p>0.05 rated as significant)
Stimulant vs. a combination of two or more drugs
Gittelman-Klein 1976 | 1 2 3 | MPH THIOR MPH + THIOR | Social Competence: Conners parent Reading: Unspecified teacher report Arithmetic: Unspecified teacher report | 0.83 ^3^ 43% ^4^ 46% ^4^ | 0.87 ^3^ 19% ^4^ 15% ^4^ | 0.87 ^3^ 39% ^4^ 33% ^4^ | | NS NS MPH, MPH + THIOR> THIOR
Stimulant vs. stimulant plus nondrug intervention
Brown 1985 | 1 2 3 | MPH MPH + CBT CBT | Reading: DETROIT 13 DETROIT 16 DETROIT 6 WRAT Arithmetic: WRAT | 51.5 ± 10.4 11.5 ± 4.6 37.4 ± 8.2 65.4 ± 15.2 27.0 ± 7.8 | 51.4 ± 6.7 13.0 ±4.8 41.8 ± 12.1 59.8 ± 15.1 26.4 ± 5.3 | 59.4 ± 9.9 14.1 ± 2.0 44.0 ± 4.3 62.5 ± 10.2 29.4 ± 7.6 | | NR NR NR NR NR
Firestone 1986 | 1 2 3 | Placebo + PT MPH MPH + PT | Verbal: Gates-McGintie reading test | 3.23 ± 2.47 | 3.34 ± 2.23 | 3.44± 1.65 | | Placebo + PT, MPH, MPH + PT = NS
Klein 1997 | 1 2 3 | Placebo + CBT MPH MPH + CBT | Social Competence: Conners teachers Conners parent Reading: WRAT Arithmetic: WRAT Spelling: WRAT Achievement:: WISC | 0.8 ±0.6 0.3 ±0.6 3.73 ± 1.8 3.12 ± 1.0 3.1 ± 1.2 102.9 ± 14.1 | 0.5 ± 0.6 0.2 ± 0.3 3.9 ± 1.9 3.3 ± 1.1 3.3 ± 1.6 108.0 ± 13.5 | 0.5 ± 0.6 0.2 ± 0.3 3.9 ± 1.9 3.3 ± 1.1 3.3 ± 1.6 104.7 ± 13.7 | | MPH + CBT, MPH> Placebo + CBT; MPH vs. MPH + CBT = NS NS NS NS NS NS
MTA Coop Study Group 1999 | 1 2 3 4 | Medication (MedMgt) Psychosocial (Beh) Combined Med+ Psychosocial (Comb) Assessment & Referral (CC) | Reading Weschler Arithmetic: Weschler Spelling: Weschler Social Competence: Social Skills Rating System -- Teacher Social Skills Rating System -- Parent | 97.9 ± 14.1 99.7 ± 13.0 96.0 ± 14.8 1.15 ± 0.32 1.17 ± 0.26 | 96.2 ± 14.9 100.3 ± 13.7 93.7 ± 13.9 1.06 ± 0.32 1.15 ± 0.24 | 99.4 ± 15.2 100.3 ± 16.4 97.0 ± 14.4 1.19 ± 0.30 1.22 ± 0.27 | 95.5 ± 14.3 98.6 ± 14.1 93.7 ± 13.1 1.05 ± 0.31 1.15 ± 0.25 | Comb > CC;Comb ~ MedMgt (NS) NS NS Comb, MedMgt,> CC;Comb ~ MedMgt NS
Nondrug vs. stimulant plus nondrug intervention
Brown 1986 | 1 2 3 4 | Placebo + AC Placebo + CBT MPH + AC MPH + CBT | Social Competence: ACTRS Reading: DETROIT 13 DETROIT16 DETROIT6 WRAT Arithmetic: WRAT Spelling: WRAT | 24.5 ± 5.7 50.63 ± 15.13 12.88 ± 4.8 40.75 ± 6.96 47.75 ± 10.19 24.75 ± 5.6 30.0 ± 8.3 | 19.3 ± 3.7 53.4 ±19.3 13.73 ± 6.0 43.4± 9.43 59.2 ± 16.54 29.4 ± 5.8 36.1 ± 8.6 | 23.63 ± 2.3 46.63 ± 8.2 13.63 ± 1.7 40.25 ± 6.6 61.88 ± 13.25 35.0 ± 9.5 40.13 ± 7.3 | 21.11 ± 2.8 57.78 ± 16.36 42.33 ± 9.1 11.33 ± 5.5 56.56 ± 20.02 28.33 ± 5.6 37.89 ± 12.0 | NS NS NS NS NS NS NS
Brown 1985 | 1 2 3 | MPH MPH + CBT CBT | Reading: DETROIT 13 DETROIT 16 DETROIT 6 WRAT Arithmetic: WRAT | 51.5 ± 10.4 11.5 ± 4.6 37.4 ± 8.2 65.4 ± 15.2 27.0 ± 7.8 | 51.4 ± 6.7 13.0 ±4.8 41.8 ± 12.1 59.8 ± 15.1 26.4 ± 5.3 | 59.4 ± 9.9 14.1 ± 2.0 44.0 ± 4.3 62.5 ± 10.2 29.4 ± 7.6 | | NR NR NR NR NR
Firestone 1986 | 1 2 3 | Placebo + PT MPH MPH + PT | Verbal: Gates-McGintie reading test | 3.23 ± 2.47 | 3.34 ± 2.23 | 3.44± 1.65 | | Placebo + PT, MPH, MPH + PT = NS
Klein 1997 | 1 2 3 | Placebo + CBT MPH MPH + CBT | Social Competence: Conners teachers Conners parent Reading: WRAT Arithmetic: WRAT Spelling: WRAT Achievement: WISC | 0.8 ± 0.6 0.3 ± 0.6 3.73 ± 1.8 3.12 ± 1.0 3.1 ± 1.2 102.9 ± 14.1 | 0.5 ± 0.6 0.2 ± 0.3 3.9 ± 1.9 3.3 ± 1.1 3.3 ± 1.6 108.0 ± 13.5 | 0.5 ± 0.6 0.2 ± 0.3 3.9 ± 1.9 3.3 ± 1.1 3.3 ± 1.6 104.7 ± 13.7 | | MPH + CBT, MPH> Placebo + CBT; MPH vs. MPH + CBT = NS NS NS NS NS NS
Hinshaw 1984 | 1 2 3 4 | Placebo + CT Placebo + AC MPH + CT MPH + AT | Social Competence: Report Only | 22.5 ^3^ | 18.5 ^3^ | 26.2 ^3^ | 24.0 ^3^ | Placebo + CT, MPH + CT, MPH + AC > Placebo + AC; Placebo + CT, MPH + CT, MPH + AC = NS
MTA Coop Study Group 1999 | 1 2 3 4 | Medication (MedMgt) Psychosocial (Beh) Combined Med + Psychosocial (Comb) Assessment & Referral (CC) | Reading Weschler Arithmetic: Weschler Spelling: Weschler Social Competence: Social Skills Rating System -- Teacher Social Skills Rating System -- Parent | 97.10 ± 14.1 99.8 ± 13.0 98.0 ± 14.8 1.16 ± 0.32 1.17 ± 0.26 | 96.2 ± 14.9 100.3 ± 13.7 93.7 ± 13.9 1.06 ± 0.32 1.15 ± 0.24 | 99.4 ± 15.2 100.4 ± 16.4 99.0 ± 14.4 1.20 ± 0.30 1.23 ± 0.27 | 95.6 ± 14.3 98.7 ± 14.1 93.8 ± 13.1 1.06 ± 0.31 1.15±0.25 | Comb > CC;Comb ~ MedMgt (NS) NS NS Comb, MedMgt,> CC;Comb ~ MedMgt NS

1 Studies in this group with no data with outcomes of interest given are: Borden 1989; Brown 1988; Carlson 1992; Christensen 1975; Conrad 1971; Garfinkel 1981; Hinshaw 1989; Levy 1996; Long 1993; Pelham 1993; Rapport 1993; Schechter 1985; Solanto 1997.

2 > = better than;NS-not significant;NR-statistical significance not reported.

3 SD not given.

4 Results given as % of score, not as mean value.

Supplemental Evidence Table D5. Treatment Results of Studies with Combination Treatments^1^ Psychological Conduct/Oppositional (Scales used for test scores may vary across studies)

Author(s) & Year of Publication | Arm | Interventions | Tests Used | Test Scores | | | Test Scores | | | Statistical Significance ^2^ (p < 0.05 rated as significant)
Author(s) & Year of Publication | Arm | Interventions | Tests Used | Arm 1 Mean ± SD | Arm 2 Mean ± SD | Arm 3 Mean ± SD | Arm 4 Mean ± SD | Arm 5 Mean ± SD | Arm 6 Mean ± SD | Statistical Significance ^2^ (p < 0.05 rated as significant)
Stimulant vs. a combination of two or more drugs
Garfinkel 1981 | 1 2 3 4 5 6 | Placebo Placebo + MPH Caffeine 158.6 mg Caffeine 158.6 mg + MPH Caffeine 308.6 mg Caffeine 308.6 mg + MPH | Aggressiveness: Conners teacher | -0.17 ^3^ | 0.43 ^3^ | 0.38 ^3^ | 0.61 ^3^ | 0.08 ^3^ | 0.28 ^3^ | MPH > Placebo, Caffeine(308.6 mg); MPH vs. MPH + Caffeine (308.6) = NS; Mph + Caffeine (158.6) > Placebo, Placebo + MPH, Caffeine (158.6), Caffeine (308.6),Caffeine 308.6) + MPH
Gittelman-Klein 1976 | 1 2 3 | MPH THIOR MPH + THIOR | CD: Conners parent Conners teacher | 1.17 ^3^ 0.32 ^3^ | 1.93 ^3^ 0.77 ^3^ | 1.85 ^3^ 0.34 ^3^ | | | | NS MPH, MPH + THIOR > THIOR
Stimulant vs. stimulant plus nondrug intervention
Firestone 1986 | 1 2 3 | Placebo + PT MPH MPH + PT | CD: Peterson QuayBehavior Problem Checklist | 8.33 ± 4.14 | 5.75 ± 3.53 | 5.4 ± 3.67 | | | | MPH, MPH + PT > Placebo + PT; MPH vs. MPH + PT = NS
Klein 1997 | 1 2 3 | Placebo + CBT MPH MPH + CBT | CD: Conners teacher Conners parent | 0.8 ± 0.7 0.9 ± 0.5 | 0.3 ± 0.5 0.8 ± 0.6 | 0.1 ± 0.3 0.6 ± 0.3 | | | | MPH + CBT, MPH > Placebo + CBT; MPH vs MPH + CBT = NS MPH + CBT > Placebo + CBT MPH + CBT, MPH > Placebo + CBT; MPH vs MPH + CBT = NS
Long 1993 | 1 2 | MPH MPH + PT manual | ODD: Eyberg Intensity Eyberg Problem Behavior disturbances: BPR-T | 159.63 ± 42.66 20.25 ± 10.89 53.58 ± 10.58 | 120.08 ± 0.34 11.67 ± 8.78 67.33 ± 15.21 | | | | | MPH + PT manual > MPH NS MPH + PT manual > MPH
MTA Coop Study Group 1999 | 1 2 3 4 | Medication (MedMgt) Psychosocial (Beh) Combined Med + Psychosocial (Comb) Assessment & Referral (CC) | ODD: SNAP -- parent SNAP -- teacher Abikoff Classroom | 0.94 ± 0.74 0.65 ± 0.68 0.004 ± 0.011 | 1.05 ± 0.74 0.97 ± 0.80 0.010 ± 0.018 | 0.76 ± 0.64 0.61 ± 0.68 0.007 ± 0.015 | 1.11 ± 0.67 1.0 ± 0.84 0.006 ± 0.014 | | | Comb > Beh, CC; MedMgt ~ Beh; MedMgt, Beh ~ CC MedMgt ~ Beh; Comb ~ MedMgt, Beh; Comb, MedMgt > CC; Beh ~ CC NS
Nondrug vs. stimulant plus nondrug intervention
Brown 1986 | 1 2 3 4 | Placebo + AC Placebo + CBT MPH + AC MPH + CBT | ODD: ACTRS | 15.38 ± 6.65 | 20.9 ± 3.7 | 11.75 ± 4.98 | 11.33 ± 3.97 | | | NS
Firestone 1986 | 1 2 3 | Placebo + PT MPH MPH + PT | CD: Peterson Quay Behavior Problem Checklist | 8.33 ± 4.14 | 5.75 ± 3.53 | 5.4 ± 3.67 | | | | MPH, MPH + PT > Placebo + PT; MPH vs. MPH + PT = NS
Klein 1997 | 1 2 3 | Placebo + CBT MPH MPH + CBT | CD: Conners teacher Conners parent | 0.8 ± 0.7 0.9 ± 0.5 | 0.3 ± 0.5 0.8 ± 0.6 | 0.1 ± 0.3 0.6 ± 0.3 | | | | MPH + CBT, MPH > Placebo + CBT; MPH vs MPH + CBT = NS MPH + CBT > Placebo + CBT MPH + CBT, MPH > Placebo + CBT; MPH vs MPH + CBT = NS
MTA Coop Study Group 1999 | 1 2 3 4 | Medication (MedMgt) Psychosocial (Beh) Combined Med + Psychosocial (Comb) Assessment & Referral (CC) | ODD: SNAP -- parent SNAP -- teacher Abikoff Classroom | 0.95 ± 0.74 0.66 ± 0.68 0.004 ± 0.011 | 1.06 ± 0.74 0.98 ± 0.80 0.010 ± 0.018 | 0.77 ± 0.64 0.62 ± 0.68 0.007 ± 0.015 | 1.11 ± 0.67 1.0 ± 0.84 0.006 ± 0.014 | | | Comb > Beh, CC; MedMgt ~ Beh; MedMgt, Beh ~ CC MedMgt ~ Beh; Comb ~ MedMgt, Beh; Comb, MedMgt > CC; Beh ~ CC NS

1 Studies in this group with no data with outcomes of interest given are: Borden 1989; Brown 1985; Brown 1988; Carlson 1992; Christensen 1975; Conrad 1971; Hinshaw 1984; Hinshaw 1989; Levy 1996; Pelham 1993; Rapport 1993; Schechter 1985; Solanto 1997.

2 > = better than;NS-not significant;NR-statistical significance not reported.

3 SD not given.

Supplemental Evidence Table D6. Treatment Results of Studies with Combination Treatments^1^ Psychological - "Internalizing"(Scales used for Test Scores may vary across studies)

Author(s) & Year of Publication | Arm | Interventions | Tests Used | Test Scores | Test Scores | | | Statistical Significance ^2^ (p<0.05 rated as significant)
Arm 1 Mean ± SD | Arm 2 Mean ± SD | Arm 3 Mean ± SD | Arm 4 Mean ± SD
Gittelman-Klein 1976 | 1 2 3 | MPH THIOR MPH + THIOR | Anxiety: Conners parent Conners teacher | 1.54 ^3^ 0.49 ^3^ | 0.4 ± 0.4 0.4 ± 0.4 | 0.5 ± 0.4 0.4 ± 0.4 | | NS NS
Klein 1997 | 1 2 3 | Placebo + CBT MPH MPH + CBT | Anxiety: Conners parent Conners teacher | 0.5 ± 0.4 0.3 ± 0.4 | 1.64 ^3^ 0.55 ^3^ | 1.62 ^3^ 0.46 ^3^ | | NS NS
MTA Coop Study Group 1999 | 1 2 3 4 | Medication (MedMgt) Psychosocial (Beh Combined Med + Psychosocial (Comb Assessment & Referral (CC) | Anxiety: Multidimensional Anxiety Scale for Children (MASC) Social Skills Rating System (SSRS): Parent Social Skills Rating System (SSRS): Teacher | 2.22 ± 0.47 0.67 ± 0.39 0.63 ± 0.47 | 2.77 ± 0.49 0.77 ± 0.40 0.58 ± 0.40 | 2.33 ± 0.47 0.67 ± 0.37 0.68 ± 0.44 | 2.27 ± 0.45 0.82 ± 0.43 0.69 ± 0.44 | NS Comb > Beh, CC; MedMgt ~ Beh, CC; Comb ~ CC NS

1 Studies in this group with no data with outcomes of interest given are: Borden 1989; Brown 1985; Brown 1986; Brown 1988; Carlson 1992; Christensen 1975; Conrad 1971; Firestone 1986; Garfinkel 1981; Hinshaw 1984; Hinshaw 1989; Levy 1996; Long 1993; Pelham 1993; Rapport 1993; Schechter 1985; Solanto 1997.

2 > = better than; NS-not significant; NR-statistical significance not reported.

3 SD not given.

Supplemental Evidence Table D7. Treatment Results of Studies with Combinations of Treatments^1^ Core/Global Symptoms(Scales used for test scores may vary across studies)

Author(s) & Year of Publication | Arm | Interventions | Tests Used | Test Scores | | | Test Scores | | | Statistical Significance ^2^ (p<0.05 rated as significant)
Author(s) & Year of Publication | Arm | Interventions | Tests Used | Arm 1 Mean ± SD | Arm 2 Mean ± SD | Arm 3 Mean ± SD | Arm 4 Mean ± SD | Arm 5 Mean ± SD | Arm 6 Mean ± SD | Statistical Significance ^2^ (p<0.05 rated as significant)
Stimulant vs. a combination of two or more drugs
Garfinkel 1981 | 1 2 3 4 5 6 | Placebo Placebo + MPH Caffeine 158.6 mg Caffeine 158.6 mg + MPH Caffeine 308.6 mg Caffeine 308.6 mg + MPH | Conners teacher | 0.11 ^3^ | 0.65 ^3^ | 0.6 ^3^ | 1 ^3^ | 0.2 ^3^ | 0.4 ^3^ | MPH > Placebo, Caffeine(308.6 mg); MPH vs. MPH + Caffeine (308.6) = NS; Mph + Caffeine (158.6) > Placebo, Placebo + MPH, Caffeine (158.6), Caffeine (308.6), Caffeine 308.6) + MPH
Gittelman-Klein 1976 | 1 2 3 | MPH THIOR MPH + THIOR | Unspecified parent report Unspecified teacher report | 66% ^4^ 71% ^4^ | 42% ^4^ 30% ^4^ | 74% ^4^ 70% ^4^ | | | | MPH, MPH + THIOR > THIOR MPH, MPH + THIOR > THIOR
Schechter 1985 | 1 2 3 4 | DEX 10 mg DEX 3.2 mg DEX 3.2 mg + Caffeine Caffeine | Conners parent CPT | 18.9 ± 3.3 778.8 ± 96.7 | 19.2 ± 2.3 752.1 ± 68.2 | 19 ± 3 763.6 ± 85.4 | 16.8 ± 3.7 771.8 ± 102.9 | | | NR NR
Stimulant vs. stimulant plus nondrug intervention
Brown 1985 | 1 2 3 | MPH MPH + CBT CBT | Conners parent Conners teacher | 7.4 ± 5.8 15 ± 3.1 | 7.5 ± 2.6 15.1 ± 4.6 | 13.1 ± 4.1 15.7 ± 2.9 | | | | NR NR
Firestone 1986 | 1 2 3 | Placebo + PT MPH MPH + PT | Unspecified Reaction Performance | 0.82 ± 0.23 | 0.67 ± 0.24 | 0.68 ± 0.23 | | | | MPH, MPH + PT > Placebo + PT; MPH vs. MPH + PT = NS
Klein 1997 | 1 2 3 | Placebo + CBT MPH MPH + CBT | Conners teacher | 2.1± 0.9 | 1.2± 1.0 | 0.21± 0.20 | | | | Placebo + CBT vs. MPH vs. MPH + CBT = NS MPH + CBT > Placebo + CBT; MPH vs. Placebo + CBT, MPH + CBT = NS MPH + CBT > Placebo + CBT; MPH vs. MPH + CBT, Placebo + CBT = NS
Long 1993 | 1 2 | MPH MPH + PT manual | HSQ intensity HSQ Problem | 54.89 ± 23.0 10.33 ± 3.67 | 29.15 ± 18.8 7.62 ± 3.75 | | | | | MPH + PT manual > MPH NS
MTA Coop Study Group 1999 | 1 2 3 4 | Medication (MedMgt) Psychosocial (Beh) Combined Med + Psychosocial (Comb) Assessment & Referral (CC) | Global symptoms: Abikoff Classroom | 0.16 ± 0.15 | 0.29 ± 0.26 | 0.21 ± 0.20 | 0.18 ± 0.15 | | | NS
Nondrug vs. stimulant plus nondrug intervention
Brown 1985 | 1 2 3 | MPH MPH + CBT CBT | Conners parent Conners teacher | 7.4 ± 5.8 15 ± 3.1 | 7.5 ± 2.6 15.1 ± 4.6 | 13.1 ± 4.1 15.7 ± 2.9 | | | | NR NR
Brown 1986 | 1 2 3 4 | Placebo + AC Placebo + CBT MPH + AC MPH + CBT | Conners parent Conners teacher | 17.25 ± 7.5 13.63 ± 6.26 | 21.1 ± 5.65 16.5 ± 5.38 | 15.88 ± 6.36 9.88 ± 3.18 | 13.78 ±8.14 12.56 ±4.07 | | | NS NS
Firestone 1986 | 1 2 3 | Placebo + PT MPH MPH + PT | Unspecified Reaction Performance | 0.82 ± 0.23 | 0.67 ± 0.24 | 0.68 ± 0.23 | | | | MPH, MPH + PT > Placebo + PT; MPH vs. MPH + PT = NS
Klein 1997 | 1 2 3 | Placebo + CBT MPH MPH + CBT | Conners teacher | 2.1± 0.9 | 1.2± 1.0 | 0.21± 0.20 | | | | Placebo + CBT vs. MPH vs. MPH + CBT = NS MPH + CBT > Placebo + CBT; MPH vs. Placebo + CBT, MPH + CBT = NS MPH + CBT > Placebo + CBT; MPH vs. MPH + CBT, Placebo + CBT = NS
MTA Coop Study Group 1999 | 1 2 3 4 | Medication (MedMgt) Psychosocial (Beh) Combined Med + Psychosocial (Comb) Assessment & Referral (CC) | Global symptoms: Abikoff Classroom | 0.16± 0.15 | 0.29± 0.26 | 0.21± 0.20 | 0.19 ± 0.15 | | | NS

1 Studies in this group with no data with outcomes of interest given are: Borden 1989; Brown 1988; Carlson 1992; Christensen 1975; Conrad 1971; Hinshaw 1989; Hinshaw 1984; Levy 1996; Pelham 1993; Rapport 1993; Solanto 1997.

2 > = better than; NS-not significant; NR-statistical significance not reported.

3 SD not given.

4 Results given % score, not as mean value.

Supplemental Evidence Table D8. Treatment Results of Studies with Combination Treatments^1^ Inattention-Hyperactivity-Impulsivity(Scales used for test scores may vary across studies)

Author(s) & Year of Publication | Arm | Interventions | Tests Used | Test Scores | | | Test Scores | | | Statistical Significance ^2^ (p<0.05 rated as significant)
Author(s) & Year of Publication | Arm | Interventions | Tests Used | Arm 1 Mean ± SD | Arm 2 Mean ± SD | Arm 3 Mean ± SD | Arm 4 Mean ± SD | Arm 5 Mean ± SD | Arm 6 Mean ± SD | Statistical Significance ^2^ (p<0.05 rated as significant)
Stimulant vs. a combination of two or more drugs
Garfinkel 1981 | 1 2 3 4 5 6 | Placebo Placebo + MPH Caffeine 158.6 mg Caffeine 158.6 mg + MPH Caffeine 308.6 mg Caffeine 308.6 mg + MPH | Inattention: Conners tacher Hyperactivity: Conners teacher | 0.3 ^3^ 0.16 ^3^ | 0.65 ^3^ 0.73 ^3^ | 0.79 ^3^ 0.58 ^3^ | 1.05 ^3^ 1.21 ^3^ | 0.25 ^3^ 0.29 ^3^ | 0.45 ^3^ 0.6 ^3^ | MPH > Placebo, Caffeine(308.6 mg); MPH vs. MPH + Caffeine (308.6) = NS; Mph + Caffeine (158.6) > Placebo, Placebo + MPH, Caffeine (158.6), Caffeine (308.6),Caffeine 308.6) + MPH. MPH > Placebo, Caffeine(308.6 mg); MPH vs. MPH + Caffeine (308.6) = NS; Mph + Caffeine (158.6) > Placebo, Placebo + MPH, Caffeine (158.6), Caffeine (308.6),Caffeine 308.6) + MPH.
Gittelman-Klein 1976 | 1 2 3 | MPH THIOR MPH + THIOR | Inattention: Conners teacher Hyperactivity: Conners parent Conners teacher Impulsivity: Conners parent | 1.02 ^3^ 1.53 ^3^ 1.07 ^3^ 1.64 ^3^ | 1.63 ^3^ 1.67 ^3^ 1.83 ^3^ 1.85 ^3^ | 1.14 ^3^ 1.6 ^3^ 1.05 ^3^ 1.78 ^3^ | | | | MPH + THIOR, MPH > THIOR NS MPH + THIOR, MPH > THIOR NS
Stimulant vs. stimulant plus nondrug intervention
Brown 1985 | 1 2 3 | MPH MPH + CBT CBT | Inattention: CCT CEFT Teacher rating scale of attention WISC Impulsivity: Children's rating scale of impulsivity MFFT Teacher rating scale of impulsivity Listening: Durrell analysis of listening comprehension | 10.9 ^3^ 14.3 ± 5.0 48.2 ± 10.4 69.5 ± 11.5 67.9 ± 4.2 4.4 ± 4.1 61.7 ± 3.2 33.6 ± 5.6 | 7.4 ^3^ 16.6 ± 6.1 46.6 ± 7.5 72.8 ± 21.5 67.4 ± 5.8 4.7 ± 2.7 61.6 ± 8.1 30.2 ± 5.9 | 16.8 ^3^ 22.0 ± 4.5 51.4 ± 9.1 70.6 ± 11.9 71.8 ± 12.5 6.8 ± 3.3 61.2 ± 9.0 32.4 ± 7.9 | | | | NR NR NR NR NR NR NR NR
Firestone 1986 | 1 2 3 | Placebo + PT MPH MPH + PT | Hyperactivity: Conners teacher | 1.37 ± 0.57 | 0.91 ± 0.58 | 0.89 ± 0.49 | | | | MPH, MPH + PT > Placebo + PT; MPH vs. MPH + PT = NS
Klein 1997 | 1 2 3 | Placebo + CBT MPH MPH + CBT | Inattention: Conners teacher Hyperactivity: Conners teacher Conners parent CPRS Impulsivity: Conners parent | 1.2 ± 0.6 1.5 ± 0.6 0.8 ± 0.4 2.6 ± 1.6 0.8 ± 0.7 | 0.9 ± 0.5 1.1 ± 0.4 0.7 ± 0.5 1.7 ± 1.1 0.7 ± 0.8 | 0.7 ± 0.5 0.8 ± 0.3 0.6 ± 0.3 1.5 ± 1.3 0.5 ± 0.5 | | | | BT vs BT + M p<.001 BT vs MTPp<.01; BT vs BT + Mp<.001 NS BT vs MTPp<.05; BT vs BT + Mp<.02 NS
Long 1993 | 1 2 | MPH MPH + PT manual | Hyperactivity: Conners parent | 19.56 ± 8.31 | 14.69 ± 5.28 | | | | | NS
MTA Coop Study Group 1999 | 1 2 3 4 | Medication (MedMgt) Psychosocial (Beh) Combined Med + Psychosocial (Comb) Assessment & Referral (CC) | Inattention: SNAP -- parent SNAP -- teacher Hyperactivity: SNAP -- parent SNAP -- teacher | 1.12 ± 0.7 1.11 ± 0.77 0.91 ± 0.65 0.82 ± 0.69 | 1.40 ± 0.7 1.47 ± 0.8 1.24 ± 0.72 1.10 ± 0.77 | 1.02 ± 0.66 1.12 ± 0.75 0.85 ± 0.63 0.75 ± 0.71 | 1.48 ± 0.67 1.47 ± 0.82 1.35 ± 0.72 1.25 ± 0.84 | | | MedMgt, Comb > Beh, CC; Comb ~ MedMgt; Beh ~ CC MedMgt, Comb > Beh, CC; Comb ~ MedMgt; Beh ~ CC MedMgt, Comb > Beh, CC; Comb ~ MedMgt; Beh ~ CC Comb, MedMgt > CC; MedMgt, Comb ~ Beh;Beh ~ CC
Brown 1986 | 1 2 3 4 | Placebo + AC Placebo + CBT MPH + AC MPH + CBT | Inattention: ACTRS CCT CEFT Teacher rating scale of attention WISC Hyperactivity: ACTRS Impulsivity: MFFT Teacher rating scale of impulsivity Listening: Durrell analysis of listening comprehension Self-Control: Hymphries self-control -- teachers | 19.5 ± 5.47 33.0 ± 23.4 17.0 ± 6.05 48.0 ± 8.23 55.38 ± 13.35 17.5 ± 4.41 27.88 ± 14.3 3.21 ± 0.52 19.0 ± 6.5 45.25 ± 10.85 | 15.9 ± 6.01 25.4 ± 16.48 15.7 ± 6.22 51.6 ± 7.93 53.6 ± 10.79 19.6 ± 2.63 23.3 ± 11.15 3.47 ± 0.18 25.5 ± 11.65 35.9 ± 8.01 | 22.0 ± 2.45 29.25 ± 26.15 15.88 ± 4.91 45.38 ± 3.2 52.0 ± 9.7 14.25 ± 5.6 21.5 ± 8.99 3.28 ± 0.49 33.0 ± 9.0 48.38 ± 4.17 | 16.33 ±5.57 34.11 ±23.44 17.22 ±5.76 47.0 ±6.08 57.33 ±8.6 14.33 ±4.66 25.22 ±13.53 3.3 ±0.7 24.44 ±15.56 42.78 ±12.83 | | | NS NS NS NS NS NS NS NS NS NS
Brown 1985 | 1 2 3 | MPH MPH + CBT CBT | Inattention: CCT CEFT Teacher rating scale of attention WISC Impulsivity: Children's rating scale of impulsivity MFFT Teacher rating scale of impulsivity Listening: Durrell analysis of listening comprehension | 10.9 ^3^ 14.3 ± 5.0 48.2 ± 10.4 69.5 ± 11.5 67.9 ± 4.2 4.4 ± 4.1 61.7 ± 3.2 33.6 ± 5.6 | 7.4 ^3^ 16.6 ± 6.1 46.6 ± 7.5 72.8 ± 21.5 67.4 ± 5.8 4.7 ± 2.7 61.6 ± 8.1 30.2 ± 5.9 | 16.8 ^3^ 22.0 ± 4.5 51.4 ± 9.1 70.6 ± 11.9 71.8 ± 12.5 6.8 ± 3.3 61.2 ± 9.0 32.4 ± 7.9 | | | | NR NR NR NR NR NR NR NR
Firestone 1986 | 1 2 3 | Placebo + PT MPH MPH + PT | Studies evaluating MPH vs. other interventions | 1.37 ± 0.57 | 0.91 ± 0.58 | 0.89 ± 0.49 | | | | MPH, MPH + PT > Placebo + PT; MPH vs. MPH + PT = NS
Hinshaw 1989 | 1 2 | Placebo + CBT MPH + CBT | Self-Control: Report only | 3.08 ± 1.62 | 4.33 ± 1.15 | | | | | BT vs BT + M p<.001 BT vs MTP p<.01; BT vs BT + M p<.001 NS BT vs MTP p<.05; BT vs BT + M p<.02 NS
Klein 1997 | 1 2 3 | Placebo + CBT MPH MPH + CBT | Inattention: Conners teacher Hyperactivity: Conners teacher Conners parent CPRS Impulsivity: Conners parent | 1.2 ± 0.6 1.5 ± 0.6 0.8 ± 0.4 2.6 ± 1.6 0.8 ± 0.7 | 0.9 ± 0.5 1.1 ± 0.4 0.7 ± 0.5 1.71 ± 1.1 0.7 ± 0.8 | 0.7 ± 0.5 0.8 ± 0.4 0.6 ± 0.3 1.5 ± 1.3 0.5 ± 0.5 | | | | MPH + CBT > Placebo + CBT
Solanto 1997 | 1 2 3 4 | Placebo + AC Placebo + BC/Mod MPH + AC MPH + BC/Mod | Inattention: CPT CPT (D' discrimination scale) ^2^ | 0.59 ± 0.2 2.03 ± 0.85 | 0.67 ± 0.2 2.46 ± 0.94 | 0.76 ± 0.18 2.66 ± 0.8 | 0.73 ± 0.19 2.63 ± 0.97 | | | Placebo + BC/Mod vs. Placebo + AC, MPH + AC, MPH + BC/Mod = NS; MPH + AC vs. MPH + BC/Mod = NS; MPH + AC, MPH + BC/Mod > Placebo + AC Placebo + BC/Mod, MPH + AC, MPH + BC/Mod = NS; Placebo + BC/Mod, MPH + AC, MPH + BC/Mod > Placebo + AC

1 Studies in this group with no data with outcomes of interest given are: Borden 1989; Brown 1988; Carlson 1992; Christensen 1975; Conrad 1971; Hinshaw 1984; Levy 1996; Pelham 1993; Rapport 1993; Schechter 1985.

2 > = better than; NS-not significant; NR -- statistical significance not reported; D' discriminatin scale = D prime (D') scores.

3 SD not given.

Supplemental Evidence Table E4. Treatment Results of Studies with Comparisons of Tricyclic Antidepressants and Placebo^1^ Academic (Scales used for test scores may vary across studies)

Author(s) & Year of Publication | Arm | Interventions | Tests Used | Test Scores | | | Statistical Significance ^2^ (p<0.05 rated as significant)
Author(s) & Year of Publication | Arm | Interventions | Tests Used | Arm 1 Mean ± SD | Arm 2 Mean ± SD | Arm 3 Mean ± SD | Statistical Significance ^2^ (p<0.05 rated as significant)
Werry 1980 | 1 2 3 | Placebo MPH Imipramine | Social Competence: Conners parent Achievement Tests: Conners parent | 0.04 ^3^ 0.04 ^3^ | 0.43 ^3^ 0.55 ^3^ | 0.03 ^3^ 0.38 ^3^ | NS NS

1 Studies in this group with no data with outcomes of interest given are: Biederman 1989a,b; Donnelly 1986; Gualtieri 1988; Gualtieri 1991; Rapport 1993; Singer 1995; Wilens 1996; Winsberg 1980.

2 > = better than; NS-not significant; NR-statistical significance not reported.

3 SD not given.

Supplemental Evidence Table E5. Treatment Results of Studies Comparing Tricyclic Antidepressants and Placebo^1^ Psychological Conduct/Oppositional (Scales used for test scores may vary across studies)

Author(s) & Year of Publication | Arm | Interventions | Tests Used | Test Scores | Test Scores | | Statistical Significance ^2^ (p<0.05 rated as significant)
Author(s) & Year of Publication | Arm | Interventions | Tests Used | Arm 1 Mean ± SD | Arm 2 Mean ± SD | | Arm 3 Mean ± SD
Werry 1980 | 1 2 3 | Placebo MPH Imipramine | CD: Conners parent Conners teacher | 1.0 ^3^ 1.68 ^3^ | 1.04 ^3^ 1.54 ^3^ | 0.78 ^3^ 1.5 ^3^ | Imipramine > MPH, Placebo; MPH vs. Placebo = NS NS
Winsberg 1980 | 1 2 | Placebo Imipramine | Aggressiveness: Conners parent Conners teacher | 2.29 ± 0.63 2.46 ± 0.74 | 1.98 ± 0.62 2.36 ± 0.71 | | NS NS

1 Studies in this group with no data with outcomes of interest given are: Biederman 1989a,b; Donnelly 1986; Gualtieri 1991; Gualtieri 1988; Rapport 1993; Singer 1995; Wilens 1996.

2 > = better than; NS-not significant; NR-statistical significance not reported.

3 SD not given.

Supplemental Evidence Table E6.Treatment Results of Studies Comparing Tricyclic Antidepressants and Placebo^1^ Psychological - "Internalizing" (Scales used for Test Scores may vary across studies)

Author(s) & Year of Publication | Arm | Interventions | Tests Used | Test Scores | Test Scores | | Statistical Significance ^2^ (p<0.05 rated as significant)
Author(s) & Year of Publication | Arm | Interventions | Tests Used | Arm 1 Mean ± SD | Arm 2 Mean ± SD | Arm 3 Mean ± SD | Statistical Significance ^2^ (p<0.05 rated as significant)
Biederman 1989a,b | 1 2 | Placebo Desipramine | Depression: Children's Depression Inventory | 18.74 ^3^ | 11.24 ^3^ | | Desipramine > Placebo
Werry 1980 | 1 2 3 | Placebo MPH Imipramine | Self-esteem: Report only Anxiety: Conners parent Conners teacher | 59.44 0.33 ^3^ 1.58 ^3^ | 61.38 0.4 ^3^ 1.66 ^3^ | 61.56 0.31 ^3^ 1.6 ^3^ | NS NS NS

1 Studies in this group with no data with outcomes of interest given are: Donnelly 1986; Gualtieri 1988; Gualtieri 1991; Rapport 1993; Singer 1995; Wilens 1996; Winsberg 1980.

2 > = better than; NS-not significant; NR-statistical significance not reported.

3 SD not given.

Supplemental Evidence Table E7. Treatment Results of Studies with Tricyclic Antidepressants vs. Placebo^1^ Core/Global Symptoms (Scales used for test scores may vary across studies)

Author(s) & Year of Publication | Arm | Interventions | Tests Used | Test Scores | | Test Scores | | Statistical Significance ^2^ (p<0.05 rated as significant)
Author(s) & Year of Publication | Arm | Interventions | Tests Used | Arm 1 Mean ± SD | Arm 2 Mean ± SD | Arm 3 Mean ± SD | Arm 4 Mean ± SD | Statistical Significance ^2^ (p<0.05 rated as significant)
Studies evaluating desipramine
Biederman 1989a,b | 1 2 | Placebo Desipramine | Clinical global impressions Conners parent Conners teacher | 4.61 ^3^ , 10% ^4^ 20.2 ^3^ 15.12 ^3^ | 3.44 ^3^ , 68% ^4^ 12.62 ^3^ 11.77 ^3^ | | | Desipramine > Placebo Desipramine > Placebo Desipramine > Placebo
Donnelly 1986 | 2 | Placebo Desipramine | Conners teacher | 10.25 ± 3.75 | 5.82 ± 2.68 | | | Desipramine > Placebo
Gualtieri 1991 | 1 2 3 4 | Placebo Desipramine low Desipramine medium Desipramine high | Conners parent Conners teacher | 3.27 ± 0.29 11.23 ± 1.09 | 2.36 ± 0.29 8.14 ± 1.17 | 1.55 ± 0.29 6.22 ± 1.14 | 2.82 ± 0.29 8.39 ± 1.12 | "Dose group" > Placebo NS
Wilens 1996 | 1 2 | Placebo Desipramine | ADHD rating scale Clinical global impressions | 26 ^3^ 4.8 ^3^ | 12 ^3^ 3 ^3^ , 68% ^4^ | | | Desipramine > Placebo Desipramine > Placebo
Studies evaluating imipramine
Werry 1980 | 1 2 3 | Placebo MPH Imipramine | Clinical global impressions | 4.04 ^3^ | 3.52 ^3^ | 2.78 ^3^ | | Imipramine > MPH; Imipramine > Placebo

1 Studies in this group with no data with outcomes of interest given are: Gualtieri 1988; Rapport 1993; Singer 1995; Winsberg 1980.

2 > = better than; NS-not significant; NR-statistical significance not reported.

3 SD not given.

4 Results given as % score, not as mean value.

Supplemental Evidence Table E8. Treatment Results of Studies with Tricyclic Antidepressants vs. Placebo^1^ Inattention-Hyperactivity-Impulsivity (Scales used for test scores may vary across studies)

Author(s) & Year of Publication | Arm | Interventions | Tests Used | Test Scores | | Test Scores | | Statistical Significance ^2^ (p<0.05 rated as significant)
Author(s) & Year of Publication | Arm | Interventions | Tests Used | Arm 1 Mean ± SD | Arm 2 Mean ± SD | Arm 3 Mean ± SD | Arm 4 Mean ± SD | Statistical Significance ^2^ (p<0.05 rated as significant)
Studies evaluating desipramine
Donnelly 1986 | 1 2 | Placebo Desipramine | Hyperactivity: Unspecified reaction performance | 192.67 ± 92.9 | 131.67 ± 61.1 | | | NS
Singer 1995 | 1 2 3 | Placebo Desipramine Clonidine | Hyperactivity: Unspecified parent report | 64.4 ± 0.6 | 32.8 ± 1.3 | 51.6 ± 2.2 | | Desipramine > Clonidine
Wilens 1996 | 1 2 | Placebo Desipramine | Inattention: ADHD Rating Scale Hyperactivity: ADHD Rating Scale Impulsivity: ADHD Rating Scale | 2.11 ± 0.5 1.41 ± 0.8 1.64 ± 0.7 | 1.07 ± 0.6 0.62 ± 0.6 0.66 ± 0.5 | | | Desipramine > Placebo Desipramine > Placebo Desipramine > Placebo
Studies evaluating imipramine
Gualtieri 1988 | 1 2 3 4 | Placebo Imipramine 1 mg/kg Imipramine 2 mg/kg Imipramine 3 mg/kg | Inattention: CGI -- global improvement | 167.7 ± 1.74 | 172.3 ± 1.85 | 170.7 ± 1.78 | 188.7 ± 1.78 | "Dose group" > Placebo
Werry 1980 | 1 2 3 | Placebo MPH Imipramine | Inattention: Conners teacher Hyperactivity: Conners parent Conners teacher | 2.14 ^3^ 1.17 ^3^ 2.56 ^3^ | 1.95 ^3^ 1.29 ^3^ 2.22 ^3^ | 2.02 ^3^ 1.04 ^3^ 2.34 ^3^ | | NS Imipramine > MPH NS
Winsberg 1980 | 1 2 | Placebo Imipramine | Inattention: Conners parent Conners teacher Hyperactivity: Conners parent Conners teacher Werry-Weis Activity Scale | 2.19 ± 0.79 2.52 ± 0.57 2.51 ± 0.64 2.78 ± 0.5 14.86 ± 9.19 | 1.88 ± 0.71 2.42 ± 0.39 2.19 ± 0.84 2.72 ± 0.58 12.14 ± 6.99 | | | Imipramine > Placebo NS NS NS NS

1 Studies in this group with no data with outcomes of interest given are: Biederman 1989a,b; Gualtieri 1991; Rapport 1993.

2 > = better than; NS-not significant; NR-statistical significance not reported.

3 SD not given.

Supplemental Evidence Table F4. Treatment Results of Studies with Long-term Treatments^1^ Academic (Scales used for test scores may vary across studies)

Author(s) & Year of Publication | Arm | Interventions | Tests Used | Test Scores | | Test Scores | | Statistical Significance ^2^ (P<0.05 rated as significant)
Author(s) & Year of Publication | Arm | Interventions | Tests Used | Arm 1 Mean ± SD | Arm 2 Mean ± SD | Arm 3 Mean ± SD | Arm 4 Mean ± SD | Statistical Significance ^2^ (P<0.05 rated as significant)
Studies evaluating MPH vs. placebo
Brown 1986 | 1 2 3 4 | Placebo + AC Placebo + CBT MPH + AC MPH + CBT | Social Competence: ACTeRS Reading: DETROIT 13 DETROIT16 DETROIT6 WRAT Arithmetic: WRAT Spelling: WRAT | 24.5 ± 5.7 50.63 ± 15.13 12.88 ± 4.8 40.75 ± 6.96 47.75 ± 10.19 24.75 ± 5.6 30.0 ± 8.3 | 19.3 ± 3.7 53.4 ± 19.3 13.7 ± 6.0 43.4 ± 9.43 59.2 ± 17.0 29.4 ± 5.8 36.1 ± 8.6 | 23.63 ± 2.3 46.63 ± 8.2 13.63 ± 1.7 40.25 ± 6.6 61.88 ± 13.0 35.0 ± 9.5 40.13 ± 7.3 | 21.11 ± 2.8 57.78 ± 16.0 42.33 ± 9.1 11.33 ± 5.5 56.56 ± 20.0 28.33 ± 5.6 37.89 ± 12.0 | NS NS NS NS NS NS NS
Firestone 1986 | 1 2 3 | Placebo + PT MPH MPH + PT | Verbal: Gates-McGintie reading test | 3.23 ± 2.47 | 3.34 ± 2.23 | 3.44 ± 1.65 | | NS
Kupietz 1988 | 1 2 3 4 | Placebo MPH 0.3 mg/kg MPH 0.5 mg/kg MPH 0.7 mg/kg | Achievement Tests: PAL Short-term memory task | 2.6 ± 2.3 8.7 ± 1.5 | 2.8 ± 2.0 8.5 ± 2.0 | 1.8 ± 1.2 8.4 ± 2.1 | 1.0 ± 0.5 9.1 ± 1.4 | NS NS
Studies evaluating MPH vs. other interventions
Brown 1986 | 1 2 3 4 | Placebo + AC Placebo + CBT MPH + AC MPH + CBT | Social Competence: ACTeRS Reading: DETROIT 13 DETROIT16 DETROIT6 WRAT Arithmetic: WRAT Spelling: WRAT | 24.5 ± 5.7 50.63 ± 15.13 12.88 ± 4.8 40.75 ± 6.96 47.75 ± 10.19 24.75 ± 5.6 30.0 ± 8.3 | 19.3 ± 3.7 53.4 ± 19.3 13.7 ± 6.0 43.4 ± 9.43 59.2 ± 17.0 29.4 ± 5.8 36.1 ± 8.6 | 23.63 ± 2.3 46.63 ± 8.2 13.63 ± 1.7 40.25 ± 6.6 61.88 ± 13.0 35.0 ± 9.5 40.13 ± 7.3 | 21.11 ± 2.8 57.78 ± 16.0 42.33 ± 9.1 11.33 ± 5.5 56.56 ± 20.0 28.33 ± 5.6 37.89 ± 12.0 | NS NS NS NS NS NS NS
Brown 1985 | 1 2 3 | MPH MPH + CBT CBT | Reading: DETROIT 13 DETROIT 16 DETROIT 6 WRAT Arithmetic: WRAT | 51.5 ± 10.4 11.5 ± 4.6 37.4 ± 8.2 65.4 ± 15.2 27.0 ± 7.8 | 51.4 ± 6.7 13.0 ± 4.8 41.8 ± 12.1 59.8 ± 15.1 26.4 ± 5.3 | 59.4 ± 9.9 14.1 ± 2.0 44.0 ± 4.3 62.5 ± 10.2 29.4 ± 7.6 | | NR NR NR NR NR
Studies evaluating MPH vs. other interventions (continued)
Firestone 1986 | 1 2 3 | Placebo + PT MPH MPH + PT | Verbal: Gates McGinty reading test | 3.23 ± 2.47 | 3.34 ±2.23 | 3.44 ± 1.65 | | NS
Gittelman-Klein 1976 | 1 2 3 | MPH THIOR MPH + THIOR | Social Competence: Conners parent Reading: Unspecified teacher report Arithmetic: Unspecified teacher report | 0.83 ^3^ 43% ^4^ 46% ^4^ | 0.87 ^3^ 19% ^4^ 15% ^4^ | 0.87 ^3^ 39% ^4^ 33% ^4^ | | NS NS MPH, MPH + THIOR> THIOR
Studies evaluating other interventions
Gillberg 1997 | 1 2 | Placebo Amphetamine | Achievement Tests: WISC | 50% ^4^ | 82% ^4^ | | | NS
Linden 1996 | 1 2 | Nothing Biofeed | Achievement Tests: KBIT | 100.0 | 110.4 | | | Biofeedback > Nothing
MTA Coop Study Group 1999 | 1 2 3 4 | Medication (MedMgt) Psychosocial (Beh) Combined Med + Psychosocial (Comb) Assessment & Referral (CC) | Reading Weschler Arithmetic: Weschler Spelling: Weschler Social Competence: Social Skills Rating System -- Teacher Social Skills Rating System -- Parent | 97.9 ± 14.1 99.7 ± 13.0 96.0 ± 14.8 1.15 ± 0.32 1.17 ± 0.26 | 96.2 ± 14.9 100.3 ± 13.7 93.7 ± 13.9 1.06 ± 0.32 1.15 ± 0.24 | 99.4 ± 15.2 100.3 ± 16.4 97.0 ± 14.4 1.19 ± 0.30 1.22 ± 0.27 | 95.5 ± 14.3 98.6 ± 14.1 93.7 ± 13.1 1.05 ± 0.31 1.15 ± 0.25 | Comb > CC; Comb ~ MedMgt (NS) NS NS Comb, MedMgt,> CC; Comb ~ MedMgt NS

1 Studies in this group with no data with outcomes of interest given are: Brown 1988; Conrad 1971; Fehlings 1991; Greenhill 1973; Quinn 1975; Schachar 1997.

2 > = better than; NS-not significant; NR-statistical significance not reported.

3 SD not given.

4 Results given as % score, not as mean value.

Supplemental Evidence Table F5. Social Competence Effects of Long-term Treatments^1^(Scales used for test scores may vary across studies)

Author(s) & Year of Publication | Arm | Interventions | Tests Used | Test Scores | | Test Scores | | Statistical Significance ^2^ (p<0.05 rated as significant)
Author(s) & Year of Publication | Arm | Interventions | Tests Used | Arm 1 Mean ± SD | Arm 2 Mean ± SD | Arm 3 Mean ± SD | Arm 4 Mean ± SD | Statistical Significance ^2^ (p<0.05 rated as significant)
Brown 1986 | 1 2 3 4 | Placebo + CT Placebo + CBT MPH + CT MPH + CBT | ODD: ACTeRS | 15.38 ± 6.7 | 20.9 ± 3.7 | 11.75 ± 5.0 | 11.33 ± 4.0 | NS
Firestone 1986 | 1 2 3 | Placebo + PT MPH MPH + PT | CD: Peterson Quay Behavior Problem Checklist | 8.33 ± 4.1 | 5.75 ± 3.5 | 5.4 ± 3.7 | | MPH, MPH + PT > Placebo + PT; MPH vs. MPH + PT = NS
Gillberg 1997 | 1 2 | Placebo DEX | CD: Conners parent Conners teacher | 4.3 ^3^ 12 ^3^ | 3.4 ^3^ 12 ^3^ | 1.85 ^3^ 0.34 ^3^ | | NS MPH, MPH + THIOR > THIOR
Gittelman-Klein 1976 | 1 2 3 | MPH THIOR MPH + THIOR | CD: Conners parent Conners teacher | 1.7 ^3^ 0.32 ^3^ | 1.93 ^3^ 0.77 ^3^ | | | DEX > Placebo DEX > Placebo
Kupietz 1988 | 1 2 3 4 | Placebo MPH 0.3 mg/kg MPH 0.5 mg/kg MPH 0.7 mg/kg | Aggressiveness: Conners teacher | 2.41 ± 0.8 | 2.02 ± 0.6 | 1.8 ± 0.5 | 1.7 ± 0.5 | "Dose group" > Placebo
Linden 1996 | 1 2 | Nothing Biofeedback | ODD: Conners parent | 7.45 ^3^ | 3 ^3^ | | | NS
MTA Coop Study Group 1999 | 1 2 3 4 | Medication (MedMgt) Psychosocial (Beh) Combined Med + Psychosocial (Comb) Assessment & Referral (CC) | ODD: SNAP -- parent SNAP -- teacher Abikoff Classroom | 0.94 ± 0.74 0.65 ± 0.68 0.004 ± 0.011 | 1.05 ± 0.74 0.97± 0.80 0.010 ± 0.018 | 0.76 ± 0.64 0.61 ± 0.68 0.007 ± 0.015 | 1.11 ± 0.67 1.0 ± 0.84 0.006 ± 0.014 | Comb > Beh, CC; MedMgt ~ Beh; MedMgt, Beh ~ CC MedMgt ~ Beh; Comb ~ MedMgt, Beh; Comb, MedMgt > CC; Beh ~ CC NS
Quinn 1975 | 1 2 | MPH Imipramine | CD: Conners parent Conners teacher | 6.47 ± 4.3 7.34 ± 7.2 | 7.61 ± 4.0 5.61 ± 6.0 | | | NS NS
Schachar 1997 | 1 2 | Placebo MPH | ODD: Telephone Interview Probe -- parent Telephone Interview Probe -- teacher Behavior disturbances: Unspecified parent report Unspecified teacher report Aggressiveness: Conners parent Conners teacher | 1.1 ± 1.6 1.0 ± 1.1 0.5 ± 1.0 0.9 ± 1.2 1.2 ± 0.6 0.7 ± 0.8 | 1.3 ± 1 0.4 ± 0.6 1.5 ± 1.6 0.6 ± 1.1 1.3 ± 0.9 0.4 ± 0.6 | | | NS MPH > Placebo NS NS NS MPH > Placebo

1 Studies in this group with no data with outcomes of interest given are: Brown 1985; Brown 1988; Conrad 1971; Fehlings 1991; Greenhill 1973.

2 > = better than; NS-not significant; NR-statistical significance not reported.

3 SD not given.

Supplemental Evidence Table F6. Treatment Results of Studies with Long-term Treatments^1^ Psychological - "Internalizing" (Scales used for Test Scores may vary across studies)

Author(s) & Year of Publication | Arm | Interventions | Tests Used | Test Scores | Test Scores | | | Statistical Significance ^2^ (p<0.05 rated as significant)
Author(s) & Year of Publication | Arm | Interventions | Tests Used | Arm 1 Mean ± SD | Arm 2 Mean ± SD | Arm 3 Mean ± SD | Arm 4 Mean ± SD | Statistical Significance ^2^ (p<0.05 rated as significant)
Fehlings 1991 | 1 2 | ST CBT | Self-esteem: Piers Harris Scale | 60 ± 9.3 | 65.8 ± 13 | | | CBT > ST
Gillberg 1997 | 1 2 | Placebo Amphetamine | Anxiety: Conners teacher Report only | 3.3 ^3^ 44% | 3.6 ^3^ 28% | | | NS NS
Gittelman-Klein 1976 | 1 2 3 | MPH THIOR MPH + THIOR | Anxiety: Conners parent Conners teacher | 1.54 ^3^ 0.49 ^3^ | 1.64 ^3^ 0.55 ^3^ | 1.62 ^3^ 0.46 ^3^ | | NS0.46 ^3^ NS
MTA Coop Study Group 1999 | 1 2 3 4 | Medication (MedMgt) Psychosocial (Beh Combined Med + Psychosocial (Comb Assessment & Referral (CC) | Anxiety: Multidimensional Anxiety Scale for Children (MASC) Social Skills Rating System (SSRS): Parent Social Skills Rating System (SSRS): Teacher | 2.22 ± 0.47 0.67 ± 0.39 0.63 ± 0.47 | 2.77 ± 0.49 0.77 ± 0.40 0.58 ± 0.40 | 2.33 ± 0.47 0.67 ± 0.37 0.68 ± 0.44 | 2.27 ± 0.45 0.82 ± 0.43 0.69 ± 0.44 | NS Comb > Beh, CC; MedMgt ~ Beh, CC; Comb ~ CC NS
Quinn 1975 | 1 2 | MPH Imipramine | Anxiety: Conners parent | 3.6 ± 3.3 | 3.46 ± 2.6 | | | NS

1 Studies in this group with no data with outcomes of interest given are: Brown 1985; Brown 1986; Brown 1988; Conrad 1971; Firestone 1986; Greenhill 1973; Kupietz 1988; Linden 1996; Schachar 1997.

2 > = better than; NS-not significant; NR-statistical significance not reported.

3 SD not given.

Supplemental Evidence Table F7. Treatment results of studies with long-term comparisons^1^Core/Global Symptoms (Scales used for test scores may vary across studies)

Author(s) & Year of Publication | Arm | Interventions | Tests Used | Test Scores | | Test Scores | | Statistical Significance ^2^ (p< 0.05 rated as significant)
Author(s) & Year of Publication | Arm | Interventions | Tests Used | Arm 1 Mean ± SD | Arm 2 Mean ± SD | Arm 3 Mean ± SD | Arm 4 Mean ± SD | Statistical Significance ^2^ (p< 0.05 rated as significant)
Studies evaluating MPH vs. placebo
Brown 1986 | 1 2 3 4 | Placebo + AC Placebo + CBT MPH + AC MPH + CBT | Conners parent Conners teacher | 17.25 ± 7.5 13.63 ± 6.26 | 21.1 ± 5.65 16.5 ± 5.38 | 15.88 ± 6.36 9.88 ± 3.18 | 13.78 ± 8.14 12.56 ± 4.07 | NS NS
Firestone 1986 | 1 2 3 | Placebo + PT MPH MPH + PT | Unspecified reaction performance | 0.82 ± 0.23 | 0.67 ± 0.24 | 0.68 ± 0.23 | | NS
Kupietz 1988 | 1 2 3 4 | Placebo MPH 0.3 mg/kg MPH 0.5 mg/kg MPH 0.7 mg/kg | Conners parent | 2.5 ± 0.6 | 2.36 ± 0.7 | 2.41 ± 0.8 | 1.83 ± 0.6 | "Dose group" > Placebo
Schachar 1997 | 1 2 | Placebo MPH | Telephone interview probe -- parent Telephone interview probe -- teacher | 0.9 ± 0.9 1.3 ± 1.1 | 1.2 ± 1.1 0.8 ± 0.7 | | | NS MPH > Placebo
Studies evaluating MPH vs. other interventions
Brown 1986 | 1 2 3 4 | Placebo + AC Placebo + CBT MPH + AC MPH + CBT | Conners parent Conners teacher | 17.25 ± 7.5 13.63 ± 6.26 | 21.1 ± 5.65 16.5 ± 5.38 | 15.88 ± 6.36 9.88 ± 3.18 | 13.78 ± 8.14 12.56 ± 4.07 | NS NS
Brown 1985 | 1 2 3 | MPH MPH + CBT CBT | Conners parent Conners teacher | 7.4 ± 5.8 15 ± 3.1 | 7.5 ± 2.6 15.1 ± 4.6 | 13.1 ± 4.1 15.7 ± 2.9 | | NR NR
Firestone 1986 | 1 2 3 | Placebo + PT MPH MPH + PT | Unspecified reaction performance | 0.82 ± 0.23 | 0.67 ± 0.24 | 0.68 ± 0.23 | | NS
Gittelman-Klein 1976 | 1 2 3 | MPH THIOR MPH + THIOR | Unspecified parent report Unspecified teacher report | 66% ^4^ 71% ^4^ | 42% ^4^ 30% ^4^ | 74% ^4^ 70% ^4^ | | MPH, MPH + THIOR > THIOR MPH, MPH + THIOR > THIOR
Studies evaluating other interventions
Gillberg 1997 | 1 2 | Placebo Amphetamine | Global symptoms: Conners parent Conners teacher Core symptoms: Conners parent | 17 ^3^ 42 ^3^ 8.5 ^3^ | 12 ^3^ 40 ^3^ 6 ^3^ | | | Amphetamine > Placebo Amphetamine > Placebo Amphetamine > Placebo
MTA Coop Study Group 1999 | 1 2 3 4 | Medication (MedMgt) Psychosocial (Beh) Combined Med + Psychosocial (Comb) Assessment & Referral (CC) | Global symptoms: Abikoff classroom | 0.16 ± 0.15 | 0.29 ± 0.26 | 0.21 ± 0.20 | 0.18 ± 0.15 | NS

1 Studies in this group with no data with outcomes of interest given are: Brown 1988; Conrad 1971; Fehlings 1991; Greenhill 1973; Linden 1996; Quinn 1975.

2 > = better than; NS-not significant; NR-statistical significance not reported.

3 SD not given.

4 Results given as % score, not as mean value.

Supplemental Evidence Table F8. Treatment Results of Studies with Long-term Treatments ^1^Inattention-Hyperactivity-Impulsivity (Scales used for test scores may vary across studies)

Author(s) & Year of Publication | Arm | Interventions | Tests Used | Test Scores | | Test Scores | | Statistical Significance ^2^ (p<0.05 rated as significant)
Author(s) & Year of Publication | Arm | Interventions | Tests Used | Arm 1 Mean ± SD | Arm 2 Mean ± SD | Arm 3 Mean ± SD | Arm 4 Mean ± SD | Statistical Significance ^2^ (p<0.05 rated as significant)
Studies evaluating MPH vs. placebo
Brown 1986 | 1 2 3 4 | Placebo + AC Placebo + CBT MPH + AC MPH + CBT | Inattention: ACTeRS CCT CEFT Teacher rating scale of attention WISC Hyperactivity: ACTeRS Impulsivity: MFFT Teacher rating scale of impulsivity Listening: Durrell analysis of listening comprehension Self-Control: Humphries self-control -- teachers | 19.5 ± 5.47 33.0 ± 23.4 17.0 ± 6.05 48.0 ± 8.23 55.38 ± 13.35 17.5 ± 4.41 27.88 ± 14.3 3.21 ± 0.52 19.0 ± 6.5 45.25 ± 10.85 | 15.9 ± 6.01 25.4 ± 16.48 15.7 ± 6.22 51.6 ± 7.93 53.6 ± 10.79 19.6 ± 2.63 23.3 ± 11.15 3.47 ± 0.18 25.5 ± 11.65 35.9 ± 8.01 | 22.0 ± 2.45 29.25 ± 26.15 15.88 ± 4.91 45.38 ± 3.2 52.0 ± 9.7 14.25 ± 5.6 21.5 ± 8.99 3.28 ± 0.49 33.0 ± 9.0 48.38 ± 4.17 | 16.33 ± 5.57 34.11 ± 23.44 17.22 ± 5.76 47.0 ± 6.08 57.33 ± 8.6 14.33 ± 4.66 25.22 ± 13.53 3.3 ± 0.7 24.44 ± 15.56 42.78 ± 12.83 | NS NS NS NS NS NS NS NS NS NS
Firestone 1986 | 1 2 3 | Placebo + PT MPH MPH + PT | Hyperactivity: Conners teacher | 1.37 ± 0.57 | 0.91 ± 0.58 | 0.89 ± 0.49 | | NS
Kupietz 1988 | 1 2 3 4 | Placebo MPH 0.3 mg/kg MPH 0.5 mg/kg MPH 0.7 mg/kg | Inattention: Conners teacher Hyperactivity: Conners teacher | 2.54 ± 0.91 2.6 ± 0.69 | 2.15 ± 0.76 2.02 ± 0.53 | 2.06 ± 0.49 1.79 ± 0.43 | 1.6 ± 0.42 1.84 ± 0.64 | MPH 0.7 mg > Placebo; MPH 0.3 vs. MPH 0.5 vs. Placebo = NS MPH 0.5 mg > Placebo; MPH 0.3 vs. MPH 0.7 vs. Placebo = NS
Schachar 1997 | 1 2 | Placebo MPH | Inattention: Telephone interview probe: parent Telephone interview probe: teacher Hyperactivity: Conners parent Conners teacher | 1.2 ± 0.9 1.7 ± 1.0 1.3 ± 0.7 1.7 ± 0.7 | 1.5 ± 1.1 1.0 ± 0.8 1.2 ± 0.7 0.9 ± 0.7 | | | NS MPH > Placebo NS MPH > Placebo
Studies evaluating MPH vs. other interventions
Brown 1986 | 1 2 3 4 | Placebo + AC Placebo + CBT MPH + AC MPH + CBT | Inattention: ACTeRS CCT CEFT Teacher rating scale of attention WISC Hyperactivity: ACTRS Impulsivity: MFFT Teacher rating sale of impulsivity Listening: Durrell analysis of listening comprehension Self-Control: Humphries self-control -- teachers | 19.5 ± 5.47 33.0 ± 23.4 17.0 ± 6.05 48.0 ± 8.23 55.38 ± 13.35 17.5 ± 4.41 27.88 ± 14.3 3.21 ± 0.52 19.0 ± 6.5 45.25 ± 10.85 | 15.9 ± 6.01 25.4 ± 16.48 15.7 ± 6.22 51.6 ± 7.93 53.6 ± 10.79 19.6 ± 2.63 23.3 ± 11.15 3.47 ± 0.18 25.5 ± 11.65 35.9 ± 8.01 | 22.0 ± 2.45 29.25 ± 26.15 15.88 ± 4.91 45.38 ± 3.2 52.0 ± 9.7 14.25 ± 5.6 21.5 ± 8.99 3.28 ± 0.49 33.0 ± 9.0 48.38 ± 4.17 | 16.33 ± 5.57 34.11 ± 23.44 17.22 ± 5.76 47.0 ± 6.08 57.33 ± 8.6 14.33 ± 4.66 25.22 ± 13.53 3.3 ± 0.7 24.44 ± 15.56 42.78 ± 12.83 | NS NS NS NS NS NS NS NS NS NS
Studies evaluating MPH vs. other interventions
Brown 1985 | 1 2 3 | MPH MPH + CBT CBT | Inattention: CCT EFT Teacher rating scale of attention WISC Impulsivity: Children's self-rating of impulsivity MFFT Teacher rating scale of impulsivity Listening: Durrell analysis of listening comprehension | 10.9 ^3^ 14.3 ± 5.0 48.2 ± 10.4 69.5 ± 11.5 67.9 ± 4.2 4.4 ± 4.1 61.7 ± 3.2 33.6 ± 5.6 | 7.4 ^3^ 61.6 ± 6.1 46.6 ± 7.5 72.8 ± 21.5 67.4 ± 5.8 4.7 ± 2.7 61.6 ± 8.1 30.2 ± 5.9 | 16.8 ^3^ 22.0 ± 4.5 51.4 ± 9.1 70.6 ± 11.9 71.8 ± 12.5 6.8 ± 3.3 61.2 ± 9.0 32.4 ± 7.9 | | NR NR NR NR NR NR NR NR
Firestone 1986 | 1 2 3 | Placebo + PT MPH MPH + PT | Hyperactivity: Conners teacher | 1.37 ± 0.57 | 0.91 ± 0.58 | 0.89 ± 0.49 | | NS
Gittelman-Klein 1976 | 1 2 3 | MPH THIOR MPH + THIOR | Inattention: Conners teacher Hyperactivity: Conners parent Conners teacher Impulsivity: Conners parent | 1.02 ^3^ 1.53 ^3^ 1.07 ^3^ 1.64 ^3^ | 1.63 ^3^ 1.67 ^3^ 1.83 ^3^ 1.85 ^3^ | 1.14 ^3^ 1.6 ^3^ 1.05 ^3^ 1.78 ^3^ | | MPH + THIOR, MPH > THIOR NS MPH + THIOR, MPH > THIOR NS
MTA Coop Study Group 1999 | 1 2 3 4 | Medication (MedMgt) Psychosocial (Beh) Combined Med + Psychosocial (Comb) Assessment & Referral (CC) | Inattention: SNAP -- parent SNAP -- teacher Hyperactivity: SNAP -- parent SNAP -- teacher | 1.12 ± 0.7 1.11 ± 0.77 0.91 ± 0.65 0.82 ± 0.69 | 1.40 ± 0.7 1.47 ± 0.8 1.24 ± 0.72 1.10 ± 0.77 | 1.02 ± 0.66 1.11 ± 0.75 0.85 ± 0.63 0.75 ± 0.71 | 1.47 ± 0.67 1.48 ± 0.82 1.35 ± 0.72 1.25 ± 0.84 | MedMgt, Comb > Beh, CC; Comb ~ MedMgt; Beh ~ CC MedMgt, Comb > Beh, CC; Comb ~ MedMgt; Beh ~ CC MedMgt, Comb > Beh, CC; Comb ~ MedMgt; Beh ~ CC Comb, MedMgt > CC; MedMgt, Comb ~ Beh; Beh ~ CC
Quinn 1975 | 1 2 | MPH Imipramine | Hyperactiivty: Conners parent Conners teacher | 6.69 ± 3.59 8.3 ± 4.66 | 6.76 ± 3.74 8.07 ± 5.12 | | | NS NS
Studies evaluating other interventions
Fehlings 1991 | 1 2 | ST CBT | Inattention: Behavioral problem checklist -- attention BPC -- teacher Hyperactivity: Werry-Weis Activity Scale Impulsivity: MFFT SCRS -- teacher Self-control rating scale - parent | 17.7 ± 8.3 17.7 ± 4.9 37.2 ± 19.3 10.3 ± 8.5 159.4 ± 24.2 161.9 ± 31.4 | 13.9 ± 6.7 13.5 ± 4.7 26.2 ± 8.7 12.5 ± 8.5 152.2 ± 21.0 154.1 ± 23.3 | | | NS NS CBT > ST NS NS NS
Gillberg 1997 | 1 2 | Placebo DEX | Inattention: Conners parent Conners teacher Hyperactivity: Conners teacher | 3.5 ^3^ 8.7 ^3^ 11 ^3^ | 2.6 ^3^ 7.0 ^3^ 8.0 ^3^ | | | DEX > Placebo DEX > Placebo
Linden 1996 | 1 2 | Nothing Biofeedback | Inattention: Conners parent SNAP Hyperactivity: Conners parent | 12.44 ^3^ 100.0 ^3^ 9.0 ^3^ | 8.11 ^3^ 110.6 ^3^ 4.77 ^3^ | | | Biofeedback > Placebo Biofeedback > Placebo NS

1 Studies in this group with no data with outcomes of interest given are: Brown 1988; Conrad 1971; Greenhill 1973.

2 > = better than; NS-not significant; NR-statistical significance not reported; CEFT-Children Embedded Figures Test.

3 SD not given.

Supplemental Evidence Table G5. Treatment Results of Studies in Adults^1^Psychological Conduct/Oppositional (Scales used for test scores may vary across studies)

Author(s) & Year of Publication | Arm | Interventions | Tests Used | Test Scores | | Statistical Significance ^2^ (p<0.05 rated as significant)
Author(s) & Year of Publication | Arm | Interventions | Tests Used | Arm 1 Mean ± SD | Arm 2 Mean ± SD | Statistical Significance ^2^ (p<0.05 rated as significant)
Wender 1985 | 1 2 | Placebo MPH | CD: Physician's Target Symptom Ratings | 1.67 ± 0.6 | 1.42 ± 1.0 | NS

1 Studies in this group with no data with outcomes of interest given are: Conners 1996; Deveaugh-Geiss 1980; Ernst 1996; Evans 1994; Matochik 1994; Mattes 1984; Reimherr 1984; Spencer 1995; Wender 1981; Wilens 1996; Wood 1985.

2 > = better than; NS-not significant; NR-statistical significance not reported.

3 SD not given.

Supplemental Evidence Table G6. Treatment Results of Studies in Adults^1^Psychological - "Internalizing" (Scales used for Test Scores may vary across studies)

Author(s) & Year of Publication | Arm | Interventions | Tests Used | Test Scores | Test Scores | | Statistical Significance ^2^ (p< 0.05 rated as significant)
Author(s) & Year of Publication | Arm | Interventions | Tests Used | Arm 1 Mean ± SD | Arm 2 Mean ± SD | Arm 3 Mean ± SD | Statistical Significance ^2^ (p< 0.05 rated as significant)
Ernst 1996 | 1 2 3 | Placebo Selegiline 20 mg Selegiline 60 mg | Depression: Beck's Depression Inventory Brief Psychiatric Rating Scale Hamilton Psychiatric Rating Scale for Depression | 1.8 ± 2.1 25 ± 3.8 4.3 ± 1.6 | 5.3 ± 4.4 29.3 ± 7 6.9 ± 3.8 | 3.2 ± 3.6 26.8 ± 4.7 5.8 ± 4.5 | All NS All NS All NS
Spencer 1995 | 1 2 | Placebo MPH | Anxiety: Report only | NA | 22% ^3^ | | NR
Wender 1985 | 1 2 | Placebo MPH | Depression: Beck's Depression Inventory Profile of Mood States Anxiety: Profile of Mood States Sadness: Report only | 9.23 ± 8.9 50.5 ± 13 55.71 ± 9.2 2.1 ± 1.2 | 8.94 ± 9.2 43.88 ± 10 49.06 ± 12 1.81 ± 0.9 | | NS MPH > Placebo MPH > Placebo NS

1 Studies in this group with no data with outcomes of interest given are: Conners 1996; Deveaugh-Geiss 1980; Evans 1994; Mattes 1984; Matochik 1994; Reimherr 1984; Wender 1981; Wilens 1996; Wood 1985.

2 > = better than; NS-not significant; NR-statistical significance not reported.

3 Results given as %, not as mean value.

Supplemental Evidence Table G7. Treatment Results of Studies in Adults^1^Core/Global Symptoms (Scales used for test scores may vary across studies)

Author(s) & Year of Publication | Arm | Interventions | Tests Used | Test Scores | | Test Scores | Statistical Significance ^2^ (p< 0.05 rated as significant)
Author(s) & Year of Publication | Arm | Interventions | Tests Used | Arm 1 Mean ± SD | Arm 2 Mean ± SD | Arm 3 Mean ± SD | Statistical Significance ^2^ (p< 0.05 rated as significant)
Studies evaluating MPH vs. placebo
Spencer 1995 | 1 2 | Placebo MPH | ADHD rating scale Clinical global impressions | 29 ^3^ 5 ^3^ , 4% ^4^ | 13 ^3^ 3.3 ^3^ , 78% ^4^ | | MPH > Placebo MPH > Placebo
Wender 1985 | 1 2 | Placebo MPH | Global assessment scale Physicians' global rating scale Report only | 61.26 ± 8.0 0.16 ± 6.2, 11% ^4^ 4.31 ± 1.3 | 69.17 ± 9.7, 57% ^4^ 1.4 ± 1.6, 32% ^4^ 4.97 ± 1.8 | | MPH > Placebo MPH > Placebo NS
Studies evaluating DEX
Matochik 1994 | 1 2 | MPH DEX | Clinical global impressions Conners parent Conners teacher | 2.1 ± 1 5 ± 3.2 5.7 ± 4.5 | 1.9 ± 0.9 4.6 ± 4.8 8.3 = 5.6 | | NR NR NR
Other interventions
Ernst 1996 | 1 2 3 | Placebo Selegiline 20 mg Selegiline 60 mg | CGI -- global improvement CGI -- severity of disease Conners child -- by self Conners teacher -- by spouse Global assessment scale | 3.7 ± 1 3.7 ± 1 9 ± 2.4 8.8 ± 5.2 68.3 ± 9.2 | 3.6 ± 1.1 3.6 ± 1.1 9.6 ± 3.5 8.1 ± 4.5 69.6 ± 5.1 | 3.1 ± 1.5 3.6 ± 0.7 8.5 ± 6.1 11.3 ± 6.5 68.1 ± 6.8 | NS NS NS NS NR
Wender 1981 | 1 2 | Placebo Pemoline | Physicians global assessment of change | | 1.23 ^3^ , 50% ^4^ | | Pemoline > Placebo
Wilens 1996 | 1 2 | Placebo Desipramine | ADHD rating scale Clinical global impressions | 26 ^3^ 4.8 ^3^ | 12 ^3^ 3 ^3^ , 68% ^4^ | | Desipramine > Placebo Desipramine > Placebo
Wood 1985 | 1 2 | Placebo Phenylalanine | Physicians' global rating scale | 0.2 ^3^ , 15% ^4^ | 1.2 ^3^ , 46% ^4^ | | NS

1 Studies in this group with no data with outcomes of interest given are: Conners 1996; Deveaugh-Geiss 1980; Evans 1994; Mattes 1984; Reimherr 1984.

2 > = better than; NS-not significant; NR-statistical significance not reported.

3 SD not given.

4 Results given as % score, not as mean value.

Supplemental Evidence Table G8. Treatment results of studies in adults^1^Inattention-Hyperactivity-Impulsivity (Scales used for test scores may vary across studies)

Author(s) & Year of Publication | Arm | Interventions | Tests Used | Test Scores | | Statistical Significance ^2^ (p< 0.05 rated as significant)
Author(s) & Year of Publication | Arm | Interventions | Tests Used | Arm 1 Mean ± SD | Arm 2 Mean ± SD | Statistical Significance ^2^ (p< 0.05 rated as significant)
Studies evaluating MPH vs. placebo
Spencer 1995 | 1 2 | Placebo MPH | Inattention: ADHD Rating Scale Hyperactivity: ADHD Rating Scale Impulsivity: ADHD Rating Scale | 2.28 ^3^ 1.88 ± 0.04 1.99 ± 0.04 | 1.89 ± 0.02 1.84 ± 0.04 0.91 ± 0.02 | MPH > Placebo MPH > Placebo MPH > Placebo
Wender 1985 | 1 2 | Placebo MPH | Inattention: Physician's Target Symptom Ratings Hyperactivity: Physician's Target Symptom Ratings | 3.35 ± 1.0 3.29 ± 1.0 | 2.27 ± 1.0 2.33 ± 1.1 | MPH > Placebo MPH > Placebo
Studies evaluating DEX
Matochik 1994 | 1 2 | MPH DEX | Inattention: STESS | 0.4 ± 0.6 | 0.6 ± 0.9 | NR
Other interventions
Wender 1981 | 1 2 | Placebo Pemoline | Inattention: Unclear/Not Reported Hyperactivity: Unclear/Not Reported Impulsivity: Unclear/Not Reported | 3.66 ± 0.5 3.22 ± 0.7 3.56 ± 0.5 | 2.88 ± 1.1 2.24 ± 1.3 2.35 ± 0.8 | Pemoline > Placebo Pemoline > Placebo Pemoline > Placebo
Wilens 1996 | 1 2 | Placebo Desipramine | Inattention: ADHD Rating Scale Hyperactivity: ADHD Rating Scale Impulsivity: ADHD Rating Scale | 2.11 ± 0.5 1.41 ± 0.8 1.64 ± 0.7 | 1.07 ± 0.6 0.62 ± 0.6 0.66 ± 0.5 | Desipramine > Placebo Desipramine > Placebo Desipramine > Placebo

1 Studies in this group with no data with outcomes of interest given are: Conners 1996; Deveaugh-Geiss 1980; Ernst 1996; Evans 1994; Mattes 1984; Reimherr 1984; Wood 1985.

2 > = better than; NS-not significant; NR-statistical significance not reported.

3 SD not given.