# Evidence Tables

Evidence Tables A: General Characteristics of All Studies

Evidence Table A1. Where Study Was First Identified

MEDLINE | 65
CINAHL | 0
HEALTHStar | 0
PsychINFO | 3
EMBASE | 7
Other source: Reference list, personal file, special release | 3

Evidence Table A2. Type of Study

RCT parallel | 29
RCT crossover | 48
Non-RCT | 1

Evidence Table A3. Funding Source (multiple answers possible)

Industry | 23
Government agency | 47
Consumer organization | 2
Charity | 5
Professional organization | 2
Not reported | 22

Evidence Table A4. Publication Year

1971-75 | 7
1976--80 | 11
1981--85 | 11
1986--90 | 17
1991--95 | 19
1996--99 | 13

Evidence Table A5. Country of Publication

USA | 66
Canada | 6
Sweden | 1
Australia | 2
New Zealand | 1
Norway | 1
Netherlands | 1

Evidence Table A6. Number of Authors

1 | 3
2 | 8
3 | 19
4 | 19
5 | 10
6 or more | 19

Evidence Table A7. Areas Covered (multiple areas possible)

Drug vs drug | 22
Drug vs nondrug | 6
Long-term therapy | 15
Combination therapy | 20
Adult ADHD | 12
Adverse effects | 29

Evidence Table A8. Background of First Author (multiple backgrounds possible)

Psychology | 16
Psychiatry | 41
Pediatrics | 30
Pharmacology | 6
Neurology | 4
Not reported | 9

Evidence Table A9. Number of Research Centers

1 | 76
2 | 0
3 | 0
4 | 1
6 | 1

Evidence Table A10. (Study Duration)

< 4 weeks | 15
5-8 weeks | 25
9-12 weeks | 17
13-16 weeks | 5
17-20 weeks | 2
21-28 weeks | 2
> 52 weeks | 5
Unclear | 5
Not reported | 2

Evidence Table A11. Ethnic Groups

Ethnic groups mentioned
Yes | 24
No | 54
Groups mentioned (more than one group possible)
White | 23
Afro-American | 14
Asian | 2
Hispanic | 7
Other | 2

Evidence Table A12. Treatment Setting (more than one setting possible)

Home | 17
School | 10
Community | 2
Hospital inpatient | 5
Hospital outpatient | 19
Mental health outpatient | 47
Pediatric clinic | 1
Not reported | 1

Evidence Table A13. Is the Analysis Grouped by Treatment Setting?

Yes | 0
No | 2
Not applicable | 76

Evidence Table A14. Are the Inclusion Criteria Reported?

Yes | 58
No | 19
Unclear | 2

Evidence Table A15. Are the Exclusion Criteria Reported?

Yes | 39
No | 38
Unclear | 1

Evidence Table A16. Is the Primary Outcome Stated?

Yes | 17
No | 61

Evidence Table A17. Age of Subjects (more than one age group possible)

<5 years | 2
5 to 12 years | 64
13 to 18 years | 19
>18 years | 12
Not reported | 2

Evidence Table A18. Gender of Subjects (more than one gender choice possible)

Male | 75
Female | 51
Not reported | 1

Evidence Table A19. IQ Considered

Is IQ considered?
Yes | 62
No | 14
Not reported | 2
Is IQ one of the exclusion criteria?
Yes | 31
No | 40
Not reported | 7
IQ cutoff used
< 70 | 7
71--80 | 15
> 80 | 8
Unclear | 1

Evidence Table A20. Diagnostic Model Used

MBD | 6
Hyperkinetic syndrome | 2
ADD (DSM I-III) | 28
ADHD (DSM-IIIR and -IV) | 29
Teacher diagnosis | 1
Individual method | 6
Not reported | 6

Evidence Table A21. Comorbid Disorders of Subjects (more than one choice possible)

ODD | 24
CD | 24
Tourette's syndrome | 5
Anxiety disorder | 17
Depressive disorder | 6
Learning disorder | 11
Mental retardation/low IQ | 3
Autistic | 1
None | 43

Evidence Table A22. Who Made the Diagnosis? (more than one choice possible)

Clinician | 71
Parent | 10
Teacher | 13
Not reported | 6

Evidence Table A23. Sample Origin (more than one choice possible)

Hospital inpatient | 4
Hospital outpatient | 14
Mental health outpatient | 38
Community | 13
School | 19
Home | 2
Community physicians | 13
Pediatric clinic outpatient | 1
Not reported | 10

Evidence Table A24. Family Characteristics

Are family characteristics mentioned?
Yes | 32
No | 46
Which family characteristics are mentioned (more than one choice possible)
Family history of ADHD | 12
Family structure | 5
Socioeconomic status | 24
Maternal education | 4
Paternal education | 3
Income | 4
Family functioning | 4
Maternal depression | 4
Paternal depression | 4
Ethno-cultural background | 5

Evidence Table A25. Number of Treatment Arms

2 | 28
3 | 26
4 | 20
5 | 1
6 | 3

Evidence Table A26. Monitoring of Treatments

Was there fidelity and monitoring of treatment?
Yes | 25
No | 53
Which methods were used? (more than one choice possible)
Trained therapists | 19
Treatment manual | 4
Self-monitoring and administration of treatment | 11

Evidence Table A27. Was Compliance With Treatment Measured?

Yes | 33
No | 45

Evidence Table A28. Scores and Tests

Are baseline test scores given?
Yes | 54
No | 24
Which tests were reported on?
Abikoff Classroom Observation | 1
ACTeRS | 1
ADHD rating scale | 1
Beck's depression inventory | 3
Behavior problem checklist - attention | 1
BPC | 1
Brief psychiatric rating scale | 1
CBCL | 2
CGI | 3
Children's Depression Inventory | 1
Conners | 37
Corrected grade placement (CGP) | 1
CPT | 5
Family history of disorders | 2
Global assessment scale | 5
Hamilton anxiety scale | 1
Hamilton psychiatric rating -- depression | 4
Hollingshead SES | 1
Home activity scale | 1
Kaufman brief intelligence (KBIT) | 1
KIDDIE-SADS | 1
MFFT | 1
Peak interval timing procedure | 1
Physicians global rating scale | 2
Piers Harris scale self-esteem | 1
Profile of mood state (POMS) | 1
Reaction performance | 1
Reading grade level | 1
Revised children's manifest anxiety | 1
SCL 90 | 1
SCRS | 1
Self-control rating scale | 1
SNAP | 2
STESS | 2
STROOP | 1
Structured clinical interview DSM-III-R | 1
Telephone interview probe (TIP) | 1
TOTS | 2
WAIS-R | 3
Wender-Utah rating | 1
Werry | 2
Weschler | 22
WRAT | 3
Unclear/not reported | 1

Evidence Table A29. Treatment Described

Is randomization reported?
Yes | 77
No | 1
Is randomization described?
Yes | 3
No | 74
Is randomization appropriate?
Yes | 2
No | 1
Is double blinding reported?
Yes | 67
No | 10
Is double blinding described?
Yes | 57
No | 10
Is double blinding appropriate?
Yes | 8
No | 49
Are withdrawals reported in terms of number and reasons per arm?
Yes | 10
No | 68

Evidence Table A30. Is the Intended Allocation to Treatment Group Concealed From the Investigator?

Yes | 4
No | 69
Not reported | 5

Evidence Table A31. Industry Association

Is an association with industry reported?
Yes | 27
No | 51
Which companies are mentioned?
Abbott | 2
Autogenics Systems | 1
Ciba Geigy | 16
Efamol Ltd | 1
General Foods Ltd | 1
JB Roerig Division Pfizer Inc | 1
Merrell-Dow Pharmaceutical | 1
National Corporation of Swedish Pharmacies | 1
Smith Kline & French | 1
Somerset | 1
Tutag Pharmaceutical Division | 1

Evidence Table A32. Overall Frequencies of Interventions

Intervention | Frequency
Amphetamine | 1
Attention control/child training | 4
Behavior modification | 5
Bibliotherapy-protocol | 1
Buproprion | 1
Caffeine | 3
Child training | 4
Chlorpromazine | 1
Clonidine | 1
Cognitive behavioral therapy | 6
Desipramine | 5
Dexamphetamine | 18
EEG biofeedback | 1
Efamol | 1
Haloperidol | 1
Hydroxyzine | 1
Imipramine | 6
L-amphetamine | 1
Lithium carbonate | 1
Lethylphenidate | 56
Nicotine | 1
Nothing (e.g., wait lists) | 3
Parent training | 1
Pemoline | 5
Phenylalanine | 1
Pindolol | 1
Placebo | 64
Racemic amphetamine | 1
Secobarbitol | 1
Selegiline | 1
Supportive therapy | 1
Thioridazine | 1

Evidence Table A33. Overall Outcomes

Outcomes | Frequency
Abdominal pain | 21
Achievement pests | 9
Aggressiveness | 2
Anorexia | 6
Anxiety | 22
Arithmetic | 3
Behavior disturbances | 5
CD | 15
Core symptoms | 20
Crying | 7
Decreased appetite | 17
Depression | 8
Disturbed sleep | 3
Emotional | 1
Fatigue/tiredness | 10
Global mood | 1
Global side effects | 4
Global symptoms | 21
Grades | 2
Growth | 1
Headache | 20
Height | 4
Hyperactivity | 30
Impulsivity | 12
Inattention | 29
Increased appetite | 6
Interaction with family | 1
Interaction with friends | 6
Irritability | 14
Listening | 2
Motor Tics | 8
Nausea | 11
Nightmares | 8
ODD | 7
Reading | 5
Performance | 4
Sadness | 10
Self-control | 2
Self-esteem | 2
Sleep disorder -- insomnia | 22
Sleep disorder -- sleep | 12
Social competence | 11
Somatic effects | 3
Spelling | 1
Verbal | 3
Weight | 7
Weight gain | 1
Weight loss | 1

Evidence Table A34. Overall Frequencies of Tests

Tests | Frequency
ACTeRS | 1
ADHD Rating Scale | 2
Beck Depression Inventory | 3
Behavior Problem Checklist | 1
Brief Psychiatric Rating Scale | 1
CGI - Global Improvement | 1
CGI - Severity of Illness | 1
Child Psychological Rating | 1
Children's Checking Task | 2
Children's Depression Inventory | 1
Clinical Global Improvement | 8
Conners Child/Self | 2
Conners Parent Rating Scale | 22
Conners Teacher/Spouse | 37
CPT | 4
DETROIT13 | 3
DETROIT16 | 3
DETROIT6 | 3
DTS | 2
Durrell Anal. Reading | 2
EFT | 2
Gates McGinty Test | 1
Global Assessment Scale | 3
HAM-A | 1
Hamilton Psychiatric Rating - Depression | 2
How I Feel | 1
Humphries Self-Control - Teacher | 1
KBIT | 1
MFFT | 3
Other Clinician Report | 1
Other Parent Report | 8
Other Teacher Report | 12
Peterson Quay Checklist | 1
PGS | 3
Physician Global Assessment of Change | 1
Piers Harris Scale | 1
POMS | 1
PTSR | 1
Report Only | 32
SNAP | 1
STESS | 5
STM Task | 1
Unspecified Reaction Performance | 2
Werry Weiss Activity Scale | 2
Weschler | 7
WRAT | 3
Unclear/Not Reported | 1

Evidence Table B1. Key Characteristics of Studies With Drug vs. Drug Comparisons

Author & Year of Publication | Type | Patients Randomized | Diagnosis Model | Interventions | Duration per Intervention (weeks) | Clinically Relevant Elements (of 20) ^1^ | Quality Assessment Total Score (of 5) | Outcomes of Interest Measured ^2^ | Outcome Results^3,4,5^
Same drug comparisons
Arnold 1976 | Crossover | 31 | MBD | DEX L-amph Placebo | 4 | 11 | 3 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity Academic Conduct/Oppositional Disorders Depression | NS; except one parent report of DEX > L-Amphetamine NR NR NR NS
Fitzpatrick 1992 | Crossover | 19 ^6^ | ADD (DSM-I-III) | MPH-low MPH-med MPH-high-SR Placebo | 2 | 13 | 2 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity Conduct/Oppositional Disorders Depression | NS NR NS NS
Pelham 1987 | Crossover | 13 ^6^ | ADD (DSM-I-III) | MPH-reg MPH-SR Placebo | 5 | 11 | 2 | Core/Global Symptoms Conduct/Oppositional Disorders | NS NS
Srinivas 1992 | Crossover | 9 | Other | l-MPH d-MPH dl-MPH Placebo | Unclear | 9 | 2 | Inattention/Hyperactivity/Impulsivity | Data not presented in a manner compatible with extraction
Whitehouse 1980 | Parallel | 34 | MBD | MPH-reg MPH-SR | 2 | 13 | 2 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity Academic Conduct/Oppositional Disorders Depression | NS; except one teacher report of MPH > MPH-SR NS NS MPH-SR > MPH for parent; MPH > MPH-SR for teacher NS
Stimulant vs. stimulant comparisons
Arnold 1978 | Crossover | 29 ^6^ | MBD | MPH DEX Caffeine Placebo | 3 | 10 | 2 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity Academic Conduct/Oppositional Disorders Depression | MPH vs DEX = NS NR MPH vs DEX = NS NR NR
Borcherding 1989 | Crossover | 18 ^6^ | ADD (DSM-I-III) | MPH DEX Placebo | 3 | 12 | 2 | Inattention/Hyperactivity/Impulsivity | Data not presented in a manner compatible with extraction
Castellanos 1997 | Crossover | 22 | ADHD (DSM-IIIR/IV) | MPH DEX Placebo | 3 | 18 | 2 | Adverse effects | Data not presented in a manner compatible with extraction
Conners 1972 | Parallel | 84 | MBD | DEX Pemoline Placebo | 8 | 15 | 1 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity Academic Conduct/Oppositional Disorders Depression | NS NS NS NS NS
Conners 1980 | Parallel | 60 | MBD | MPH Pemoline Placebo | 8 | 17 | 3 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity Academic Conduct/Oppositional Disorders Depression | NS NS NS NS NS
Efron 1997 | Crossover | 125 | Other | MPH DEX | 2 | 11 | 2 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity Academic Conduct/Oppositional Disorders Depression | NR MPH > DEX; except for parent report of impulsivity = NS NS MPH > DEX for teacher; NS for parent MPH > DEX and NS
Stimulant vs. stimulant comparisons
Elia 1991 | Crossover | 48 ^6^ | ADD DSM I-III | MPH DEX Placebo | 3 | 13 | 2 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity Conduct/Oppositional Disorders Depression | NS NS NS NS
Gross 1976 | Crossover | 50 | MBD | MPH DEX R-Amph Placebo | 1 | 7 | 2 | Inattention/Hyperactivity/Impulsivity | Data not presented in a manner compatible with extraction
Kauffman 1981 | Crossover | 12 ^6^ | Other | MPH DEX Placebo | 6 | 13 | 3 | Adverse effects | Data not presented in a manner compatible with extraction
Matochik 1994 | Parallel | 37 ^6^ | ADHD DSM-IIIR/IV | MPH DEX | Unclear | 11 | 1 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity | NR NR
Pelham 1990 | Crossover | 22 ^6^ | ADHD DSM-IIIR/IV | MPH-reg MPH-SR DEX-SR Pemoline Placebo | 1 | 11 | 2 | Core/Global Symptoms Conduct/Oppositional Disorders | NR NR
Stephens 1984 | Crossover | 36 | ADD DSM-I-III | MPH Pemoline Placebo | 1 | 9 | 2 | Academic | Data not presented in a manner compatible with extraction
Winsberg 1974 | Crossover | 20 | Other | MPH DEX Placebo | 1 | 12 | 2 | Inattention/Hyperactivity/Impulsivity Adverse effects | Data not presented in a manner compatible with extraction
Stimulant vs. tricyclic antidepressants
Quinn 1975 | Parallel | 75 | Other | MPH Imipramine | 52 | 7 | 2 | Inattention/Hyperactivity/Impulsivity Academic Conduct/Oppositional Disorders Depression | NS NR NS NS
Rapport 1993 | Crossover | 16 | ADHD (DSM-IIIR/IV) | MPH Desipramine MPH + Desipramine Placebo | 1 | 17 | 3 | Adverse effects | Data not presented in a manner compatible with extraction
Spring 1976 | Parallel | 58 | Other | MPH+Placebo Placebo+ MPH Imipramine + Placebo Placebo + Imipramine | 3 | 13 | 3 | Inattention/Hyperactivity/Impulsivity | Data not presented in a manner compatible with extraction
Werry 1980 | Crossover | 30 | Other | MPH Imipramine Placebo | 4 | 12 | 2 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity Academic Conduct/Oppositional Disorders Depression | Imipramine > MPH NS; except one parent report of Imipramine > MPH NS Imipramine > MPH for parent; NS for teacher NS

1 These are clinically relevant elements extracted from the studies that are not supported by empirical methodological research. Refer to Evidence Table B3, for details of the 20 elements.

2 Data on adverse effects are included in the Adverse Effects Table only (Evidence Tables H1a-H1h).

3 Results are based on various reports, not all of which give usable data or outcomes. Specific outcomes in each category are given in Evidence Tables B2, B3, and Supplemental Evidence Tables B4--B8.

4 Results given are for drug-to-drug comparisons, NOT baseline/placebo comparisons.

5 Outcomes regarded, a priori, as not of interest by expert panel are not included in this table but are discussed in the text if clinically significant.

6 Number of randomized subjects not reported; number of subjects analyzed is given in table.

Abbreviations used: AC-attention control; ADD-attention-deficit disorder; ADHD-attention-deficit/hyperactivity disorder; BC/Mod-behavioral contingencies/modification; BDI-Beck's depression inventory; CBT-cognitive behavioral therapy; CDRS-Children's Depression Rating Scale; CT-child training; Des-desipramine; DEX-dextroamphetamine; DSM-Diagnostic and Statistical Manual of Mental Disorders; L-amph-l-amphetamine; MBD-minimal brain dysfunction; MPH or MPH-reg-methylphenidate; MPH-SR-sustained-release methylphenidate; POMS-Profile of mood states; PT-parent training; SSERS-Stimulant Side Effects Rating Scale; ST-supportive therapy; STESS-Subject's Treatment Emergent Symptom Scale; THIOR-thioridazine; > = better than; NS-not significant; NR-statistical significance not reported.

Evidence Table B2. Total Number of Characteristics Checked for Drug vs. Drug Comparisons^1^

Author | # Subjects Eligible (Q14) ^2^ | # Subjects Randomized (Q15) ^2^ | # Subjects Analyzed (Q17) ^2^ | Ethnic Groups Considered (Q18) ^2^ | Treatment Setting (Q19) ^2^ | Inclusion Criteria Reported (Q21) ^2^ | Exclusion Criteria Reported (Q22) ^2^ | Primary Outcome Stated (Q23) ^2^ | Age Categories of Subjects (Q24) ^2^ | Gender of Subjects (Q25) ^2^ | IQ Considered in election of Subjects (Q26) ^2^ | Diagnosis Model Used (Q28) ^2^ | Comorbid Disorders Considered (Q29a) ^2^ | Comorbid Disorders in Population (Q29b) ^2^ | Who Diagnosed Subjects (Q30) ^2^ | Sample Origin (Q31) ^2^ | Family Characteristics Mentioned (Q32) ^2^ | Fidelity & Monitoring of Treatment (Q34) ^2^ | Compliance With Treatment Measured (Q35) ^2^ | Baseline Test Scores Presented (Q36) ^2^ | Total Count (20) ^2^
Same drug comparisons
Arnold 1976 | 1 | 1 | 1 | 0 | 1 | 1 | 0 | 0 | 1 | 1 | 0 | 1 | 0 | 0 | 1 | 1 | 0 | 0 | 0 | 1 | 11
Fitzpatrick 1992 | 0 | 0 | 1 | 0 | 1 | 0 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 13
Pelham 1987 | 0 | 0 | 1 | 0 | 1 | 0 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 0 | 1 | 11
Srinivas 1992 | 1 | 1 | 1 | 0 | 1 | 0 | 0 | 0 | 1 | 1 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 1 | 1 | 0 | 9
Whitehouse 1980 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 0 | 0 | 0 | 0 | 1 | 13
Stimulant vs. stimulant comparisons
Arnold 1978 | 1 | 0 | 1 | 0 | 1 | 1 | 0 | 0 | 1 | 1 | 0 | 1 | 0 | 0 | 1 | 1 | 0 | 0 | 0 | 1 | 10
Borcherding 1989 | 0 | 0 | 1 | 0 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 0 | 0 | 12
Castellanos 1997 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 0 | 1 | 18
Conners 1972 | 0 | 1 | 1 | 1 | 1 | 0 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 1 | 15
Conners 1980 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 0 | 1 | 1 | 17
Efron 1997 | 0 | 1 | 0 | 0 | 1 | 1 | 0 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 0 | 0 | 0 | 1 | 11
Elia 1991 | 0 | 0 | 1 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 0 | 1 | 13
Gross 1976 | 0 | 1 | 1 | 0 | 1 | 0 | 0 | 0 | 1 | 1 | 0 | 1 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 7
Kauffman 1981 | 0 | 0 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 0 | 0 | 1 | 0 | 13
Matochik 1994 | 0 | 0 | 1 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 0 | 0 | 1 | 0 | 1 | 0 | 0 | 1 | 11
Pelham 1990 | 0 | 0 | 1 | 0 | 1 | 0 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 0 | 1 | 11
Stephens 1984 | 0 | 1 | 1 | 0 | 1 | 0 | 0 | 1 | 1 | 1 | 0 | 1 | 0 | 0 | 1 | 1 | 0 | 0 | 0 | 0 | 9
Winsberg 1974 | 0 | 1 | 1 | 0 | 1 | 1 | 0 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 0 | 1 | 0 | 0 | 12
Stimulant vs. tricyclic antidepressants
Quinn 1975 | 0 | 1 | 1 | 0 | 1 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 1 | 1 | 0 | 0 | 0 | 0 | 0 | 1 | 7
Rapport 1993 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 17
Spring 1976 | 0 | 1 | 1 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 0 | 13
Werry 1980 | 0 | 1 | 1 | 0 | 1 | 1 | 0 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 0 | 0 | 1 | 0 | 12

1 0 = absent; 1 = present

2 Q numbers given in brackets are the question number from the data extraction form (Appendix E).

Evidence Table B3. Description of Characteristics Checked for Drug vs. Drug Comparisons

Author | # Subjects Eligible (Q14) ^1^ | # Subjects Randomized (Q15) ^1^ | # Subjects Analyzed (Q17) ^1^ | Ethnic Groups Considered (Q18) ^1^ | Treatment Setting(Q19) ^1^ | Inclusion Criteria Reported (Q21) ^1^ | Exclusion Criteria Reported Q22) ^1^ | Primary Outcome Stated (Q23) ^1^ | Age Categories of Subjects (Q24) ^1^ | Gender of Subjects(Q25) ^1^ | IQ Considered in Selection Of Subjects (Q26) ^1^ | Diagnosis Model Used (Q28) ^1^ | Comorbid Disorders Considered (Q29a) ^1^ | Comorbid Disorders in Population (Q29b) ^1^ | Who Diagnosed Subjects (Q30) ^1^ | Sample Origin(Q31) ^1^ | Family Characteristics Mentioned (Q32) ^1^ | Fidelity & Monitoring of Treatment Mentioned (Q34) ^1^ | Compliance With Treatment Measured (Q35) ^1^ | Baseline Test Scores Presented (Q36) ^1^ | Total Count (20) ^1^
Same drug comparisons
Arnold 1976 | 31 | 31 | 31 | No | MHOP | Yes | No | No | <5 yr 5-12 yr | Male Female | No | MBD | No | NM | Clin | MHOP | No | No | No | Yes | 11
Fitzpatrick 1992 | NR | NR | 19 | No | MHOP Home | No | No | No | 5-12 yr | Male Female | Yes NM | ADD | Yes | ODD CD | Clin Teach | PC | Yes | No | Yes | Yes | 13
Pelham 1987 | NR | NR | 13 | No | MHOP Home | No | No | No | 5-12 yr | Male | Yes NM | ADD | Yes | ODD CD, LD | Clin | MHOP | No | No | No | Yes | 11
Srinivas 1992 | 9 | 9 | 9 | No | HoOP | No | No | No | 5-12 yr | Male | NR | NR | No | NM | NR | HoOP | No | Yes | Yes | No | 9
Whitehouse 1980 | NR | 34 | 30 | WhiteAfro | MHOP | Yes | Yes | No | 5-12 yr | Male Female | No | MBD | Yes | NP | Clin | NR | No | No | No | Yes | 13
Stimulant vs. stimulant comparisons
Arnold 1978 | 31 | NR | 29 | No | MHOP Home | Yes | No | No | 5-12 yr | Male Female | No | MBD | No | NM | Clin | MHOP | No | No | No | Yes | 10
Borcherding 1989 | NR | NR | 18 | No | MHOP | Yes | No | Yes | 5-12 yr | Male | Yes >80 | ADD | Yes | ODD CD,AD | Clin Teach | PCOP School | No | No | No | No | 12
Castellanos 1997 | 38 | 22 | 20 | White Afro Asian Hispanic | MHOP | Yes | Yes | Yes | 5-12 yr | Male | Yes >75 | ADHD | Yes | ODD CD Touret | Clin | PC/MHOP Comm School | No | Yes | No | Yes | 18
Conners 1972 | NR | 84 | 81 | White Afro | HoOP | No | Yes | No | 5-12 yr | Male Female | Yes NM | MBD | Yes | NP | Clin | PC/MHOP Com School | Yes | No | No | Yes | 15
Conners 1980 | 60 | 60 | 60 | White Afro | MHOP Home | Yes | Yes | No | 5-12 yr | Male Female | Yes >80 | MBD | Yes | NP | Clin | NR | Yes | No | Yes | Yes | 17
Efron 1997 | NR | 125 | NR | No | MHOP | Yes | No | No | 5-12 yr | Male Female | Yes NM | ADHD | Yes | NP | Clin | PC/MHOP Comm Home School | No | No | No | Yes | 11
Elia 1991 | NR | NR | 48 | No | MHOP | Yes | Yes | No | 5-12 yr | Male | Yes >80 | ADD | Yes | ODD CD, AD | Clin | PCOP School | No | No | No | Yes | 13
Gross 1976 | NR | 50 | 48 | No | MHOP | No | No | No | <5 yr 5-18 yr | Male Female | No | MBD | No | NM | Clin | NR | No | No | No | No | 7
Kauffman 1981 | NR | NR | 12 | White | PCOP | Yes | No | Yes | 5-12 yr | Male | Yes NM | InMe | Yes | NP | Clin | MHOP CommPhy | No | No | Yes | No | 13
Matochik 1994 | NR | NR | 37 | No | MHOP | Yes | Yes | No | >18 yr | Male Female | Yes NM | ADHD | No | NM | Clin | Unclear | Yes | No | No | Yes | 11
Pelham 1990 | NR | NR | 22 | No | MHOP | No | No | No | 5-12 yr 13-18 yr | Male | Yes NM | ADHD | Yes | ODD CD, LD | Clin | MHOP | No | No | No | Yes | 11
Stephens 1984 | NR | 36 | 36 | No | MHOP | No | No | Yes | 5-12 yr | Male Female | No | ADD | No | NM | Clin | MHOP PCOP | No | No | No | No | 9
Winsberg 1974 | NR | 20 | 18 | No | HoIP | Yes | No | No | 5-12 yr | Male Female | Yes NM | InMe | Yes | NP | Clin | HoOP HoIP | No | Yes | No | No | 12
Stimulant vs. tricyclic antidepressants
Quinn 1975 | NR | 75 | 36 | No | Com | No | No | No | NR | Male | NR | NR | Yes | NP | NR | NR | No | No | No | Yes | 7
Rapport 1993 | 20 | 16 | 16 | WhiteAfro | HoIP | Yes | No | No | 5-12 yr | Male | Yes >80 | ADHD | Yes | ODD CD, AD DD, LD | Clin | HoIP | Yes | Yes | Yes | No | 17
Spring 1976 | NR | 58 | 47 | No | MHOP | Yes | Yes | No | 5-12 yr | Male Female | Yes NM | InMe | Yes | NP | Clin Parent Teach | PCOP | Yes | No | No | No | 13
Werry 1980 | NR | 30 | 30 | No | HoOP Home | Yes | No | No | 5-12 yr | Male Female | Yes NM | InMe | Yes | NP | Clin | HoOP School | No | No | Yes | No | 12

1 Q numbers given in brackets are the question number from the data extraction form (Appendix E).

Abbreviations: AD-anxiety disorder; ADHD-attention-deficit/hyperactivity disorder (DSM-IIIR-IV); ADD-attention-deficit disorder (DSM-I-III); CD-conduct disorder; Clin-clinician; Com-community; CommPhy-community physicians; DD-depressive disorder; HoIP-hospital inpatient; HoOP-hospital outpatient; HySy-hyperkinetic syndrome; InMe-individual method; LD-learning disorder; MBD-minimal brain dysfunction; MHOP-mental health clinic outpatient; MRIQ-mental retardation/low IQ; NM-none mentioned; NP-none present; NR-not reported; ODD-oppositional defiant disorder; PC-pediatric clinic; PCOP-pediatric clinic outpatient; Teach-teacher; TeDi-teacher diagnosis; Touret-Tourette's syndrome; ADHD-ADHD Activity Scale.

Evidence Table C1. Key Characteristics of Studies with Drug vs. Nondrug Comparisons

Author &Year of Publication | Type | Patients Randomized | Diagnosis Model | Interventions | Duration per Intervention (weeks) | Clinically Relevant Elements (of 20) ^1^ | Quality Assessment Total Score (of 5) | Outcomes of Interest Measured ^2^ | Outcome Results ^3,^ ^4,^ ^5^
Arnold 1989 | Crossover | 18 ^6^ | ADD DSM-I-III | DEX Efamol Placebo | 4 | 10 | 3 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity | NS DEX > Efamol
Brown 1985 | Parallel | 30 | ADD DSM-I-III | MPH MPH + CBT CBT | 12 | 15 | 1 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity Academic | NR NR NR
Conrad 1971 | Parallel | 81 | Other | DEX DEX + CT Placebo Placebo + CT | Not reported | 12 | 2 | Academic | Data not presented in a manner compatible with extraction
Firestone 1986 | Parallel | 73 ^6^ | ADD DSM-I-III | MPH MPH + PT Placebo + PT | 12 | 16 | 2 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity Academic Conduct/Oppositional Disorders | MPH, MPH + PT>Placebo + PT; MPH vs MPH + PT = NS MPH, MPH + PT>Placebo + PT; MPH vs MPH + PT = NS Placebo + PT, MPH, MPH + PT = NS MPH, MPH + PT > Placebo + PT; MPH vs MPH + PT = NS
Klein 1997 | Parallel | 89 | Other | MPH MPH + CBT Placebo + CBT | 8 | 13 | 1 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity Academic Conduct/Oppositional Disorders Depression | NS; except MPH + CBT > CBT MPH+CBT, MPH > Placebo+CBT; MPH vs MPH+CBT = NS MPH+CBT, MPH > Placebo+CBT; MPH vs MPH+CBT = NS MPH+CBT, MPH > Placebo+CBT; MPH vs MPH+CBT = NS NS
MTA Coop Group 1999 | Parallel | 579 | ADHD DSM-IIIR/IV | Medication (MedMgt) Psychosocial (Beh) Combined Med + Psychosocial (Comb) Assessment + Referral (CC) | varies up to 112 weeks | 20 | 3 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity Academic Conduct/Oppositional Disorders Social | MedMgt > Beh; Comb~MedMgt; Comb, MedMgt > Beh, CC Comb > Beh, CC (reading only) Comb > Beh, CC; MedMgt ~ Beh, Comb MedMgt, Beh, Comb > CC; MedMgt ~ Beh, Comb

1 These are clinically relevant elements extracted from the studies that are not supported by empirical methodological research. Refer to Evidence Table C3 for details of the 20 elements.

2 Data on adverse effects are included in the Adverse Effects Table only (Evidence Tables H1a--H1h).

3 Results are based on various reports, not all of which give usable data or outcomes. Specific outcomes in each category are given in Evidence Tables C2, C3, and Supplemental Evidence Tables C4--C8.

4 Results given are for drug-to-drug comparisons, NOT baseline/placebo comparisons.

5 Outcomes regarded, a priori, as not of interest by expert panel are not included in this table but are discussed in the text if clinically significant.

6 Number of randomized subjects not reported; number of subjects analyzed is given in table.

Abbreviations used: AC-attention control; ADD-attention-deficit disorder; ADHD-attention-deficit/hyperactivity disorder; BC/Mod-behavioral contingencies/modification; BDI-Beck's depression inventory; CBT-cognitive behavioral therapy; CDRS-Children's Depression Rating Scale; CT-child training; Des-desipramine; DEX-dextroamphetamine; DSM-Diagnostic and Statistical Manual of Mental Disorders; L-amph-l-amphetamine; MBD-minimal brain dysfunction; MPH or MPH-reg-methylphenidate; MPH-SR-sustained-release methylphenidate; POMS-Profile of mood states; PT-parent training; SSERS-Stimulant Side Effects Rating Scale; ST-supportive therapy; STESS-Subject's Treatment Emergent Symptom Scale; THIOR-thioridazine; > = better than; NS-not significant; NR-statistical significance not reported; ~ about the same as.

Evidence Table C2. Total Number of Characteristics Checked for Drug vs. Nondrug Comparisons^1^

Author | # Subjects Eligible (Q14) ^2^ | # Subjects Randomized (Q15) ^2^ | # Subjects Analyzed (Q17) ^2^ | Ethnic Groups Considered (Q18) ^2^ | Treatment Setting (Q19) ^2^ | Inclusion Criteria Reported (Q21) ^2^ | Exclusion Criteria Reported (Q22) ^2^ | Primary Outcome Stated (Q23) ^2^ | Age Categories of Subjects (Q24) ^2^ | Gender of Subjects (Q25) | IQ Considered In Selection of Subjects (Q26) ^2^ | Diagnosis Model Used (Q28) ^2^ | Comorbid Disorders Considered (Q29a) ^2^ | Comorbid Disorders in Population (Q29b) ^2^ | Who Diagnosed Subjects (Q30) ^2^ | Sample Origin (Q31) ^2^ | Family Characteristics Mentioned (Q32) ^2^ | Fidelity & Monitoring of Treatment Mentioned (Q34) ^2^ | Compliance With Treatment Measured (Q35) ^2^ | Baseline Test Scores Presented (Q36) ^2^ | Total Count (20) ^2^
Arnold 1989 | 0 | 0 | 1 | 0 | 0 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 0 | 0 | 0 | 1 | 10
Brown 1985 | 0 | 1 | 1 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 0 | 1 | 15
Conrad 1971 | 1 | 1 | 1 | 0 | 1 | 1 | 0 | 0 | 1 | 0 | 1 | 0 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 0 | 12
Firestone 1986 | 1 | 0 | 1 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 16
Klein 1997 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 0 | 1 | 1 | 1 | 0 | 0 | 0 | 0 | 0 | 1 | 13
MTA Coop Group 1999 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 20

1 0 = absent; 1 = present

2 Q numbers given in brackets are the question number from the data extraction form (Appendix E).

Evidence Table C3. Description of Characteristics Checked for Drug vs. Nondrug Comparisons

Author | # Subjects Eligible (Q14) ^1^ | # Subjects Randomized (Q15) ^1^ | # Subjects Analyzed (Q17) ^1^ | Ethnic Groups Considered (Q18) ^1^ | Treatment Setting (Q19) ^1^ | Inclusion Criteria Reported (Q21) ^1^ | Exclusion Criteria Reported (Q22) ^1^ | Primary Outcome Stated (Q23) ^1^ | Age Categories of Subjects (Q24) ^1^ | Gender of Subjects (Q25) | IQ Considered In Selection of Subjects (Q26) ^1^ | Diagnosis Model Used (Q28) ^1^ | Comorbid Disorders Considered (Q29a) ^1^ | Comorbid Disorders in Population (Q29b) ^1^ | Who Diagnosed Subjects (Q30) ^1^ | Sample Origin (Q31) ^1^ | Family Characteristics Mentioned (Q32) ^1^ | Fidelity & Monitoring of Treatment Mentioned (Q34) ^1^ | Compliance with Treatment Measured (Q35) ^1^ | Baseline Test Scores Presented (Q36) ^1^ | Total Count (20) ^1^
Arnold 1989 | NR | NR | 18 | No | NR | Yes | No | Yes | 5-12 | Male | Yes NM | ADD | Yes | NP | NR | NR | No | No | No | Yes | 10
Brown 1985 | NR | 30 | 30 | No | MHOP Home | Yes | Yes | No | 5-12 | Male | Yes NM | ADD | Yes | NP | Clin Parent Teach | PCOP School | No | Yes | No | Yes | 15
Conrad 1971 | 262 | 81 | 68 | No | MHOP Home | Yes | No | No | 5-12 | NR | Yes NM | TeDi | No | NM | Teach | School | Yes | Yes | Yes | No | 12
Firestone 1986 | 134 | NR | 73 | No | HoOP | Yes | Yes | No | 5-12 | Male Female | Yes >85 | ADD | Yes | CD | Clin | MHOP PCOP | Yes | Yes | No | Yes | 16
Klein 1997 | NR | 89 | 86 | White Afro Hispanic Asian | Home School | Yes | Yes | No | 5-12 | Male Female | Yes >85 | InMe | Yes | NP | Clin Parent Teach | NR | No | No | No | Yes | 13
MTA Coop Group 1999 | 609 | 579 | 559 | White Afro Hispanic | Home School Comm | Yes | Yes | Yes | 5-12 | Male Female | Yes >80 | ADHD | Yes | ODD, CD, Touret Depress Anxiety | Clin Parent | MHOP Comm School | Yes | Yes | Yes | Yes | 20

1 Q numbers given in brackets are the question number from the data extraction form (Appendix E).

Abbreviations: AD-anxiety disorder; ADHD-attention-deficit/hyperactivity disorder (DSM-IIIR-IV); ADD-attention-deficit disorder (DSM-I-III); Clin-clinician; Com-community; CoPh-community physicians; DD-depressive disorder; HoIP-hospital inpatient; HoOP-hospital outpatient; HySy-hyperkinetic syndrome; InMe-individual method; LD-learning disorder; MBD-minimal brain dysfunction; MHOP-mental health clinic outpatient; MRIQ-mental retardation/low IQ; NM-none mentioned; NP-none present; NR-not reported; PC-pediatric clinic; PCOP-pediatric clinic outpatient; Teach-teacher; TeDi-teacher diagnosis; Touret-Tourette's syndrome; ADHD-ADHD Activity Scale.

Evidence Table D1. Key Characteristics of Studies with Combination Therapy

Author & Year of Publication | Type | Patients Randomized | Diagnosis Model | Interventions | Duration per Intervention (weeks) | Clinically Relevant Elements (of 20) ^1^ | Quality Assessment Total Score (of 5) | Outcomes of Interest Measured ^2^ | Outcome Results ^3,^ ^4,^ ^5^
Stimulant vs. a combination of two or more drugs
Garfinkel 1981 | Crossover | 6 | ADD DSM-I-III | Caffeine - low Caffeine - high Caffeine - low + MPH Caffeine - high + MPH Placebo Placebo + MPH | 3 | 15 | 2 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity Conduct/Oppositional Disorders | MPH vs MPH + caffeine (high) = NS; MPH + Caffeine (low) > Placebo, Placebo + MPH, Caffeine (low), Caffeine (high), Caffeine (high) + MPH MPH vs MPH + caffeine (high) = NS; MPH + Caffeine (low) > Placebo, Placebo + MPH, Caffeine (low), Caffeine (high), Caffeine (high) + MPH MPH vs MPH + caffeine (high) = NS; MPH + Caffeine (low) > Placebo, Placebo + MPH, Caffeine (low), Caffeine (high), Caffeine (high) + MPH
Gittelman-Klein 1976 | Parallel | 166 | ADD DSM-I-III | MPH THIOR MPH + THIOR | 12 | 16 | 3 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity Academic Conduct/Oppositional Disorders Depression | MPH ± THIOR > THIOR NS for parents; MPH ± THIOR > THIOR for teachers NS for parents; MPH ± THIOR > THIOR for teachers NS for parents; MPH ± THIOR > THIOR for teachers NS
Levy 1996 | Crossover | 10** | ADD DSM-I-III | MPH + Haloperidol Placebo + Haloperidol Placebo + MPH Placebo | NR | 13 | 2 | Reaction times | Data not presented in a manner compatible with extraction
Rapport 1993 | Crossover | 16 | ADHD DSM-IIIR/IV | MPH MPH+ Desipramine Desipramine Placebo | NR | 17 | 3 | Adverse effects | Data not presented in a manner compatible with extraction
Schechter 1985 | Crossover | 10 | Hyperkinetic syndrome | DEX-low DEX-high DEX + Caffeine Caffeine | 2 | 13 | 2 | Core/Global Symptoms | NR
Stimulant vs. stimulant plus nondrug intervention
Brown 1985 | Parallel | 30 | ADD DSM-1-III | MPH MPH + CBT CBT | 12 | 15 | 1 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity Academic | NS NS NS
Conrad 1971 | Parallel | 81 | Other | DEX DEX + CT Placebo Placebo + CT | NR | 12 | 2 | Academic | NS
Firestone 1986 | Parallel | 73 ^6^ | ADD DSM-I-III | MPH MPH + PT PT | 12 | 16 | 2 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity Academic Conduct/Oppositional Disorders | MPH, MPH + PT>Placebo + PT; MPH vs MPH + PT = NS MPH, MPH + PT>Placebo + PT; MPH vs MPH + PT = NS Placebo + PT, MPH, MPH + PT = NS MPH, MPH + PT > Placebo + PT; MPH vs MPH + PT = NS
Klein 1997 | Parallel | 89 | Other | MPH MPH + CBT Placebo + CBT | 8 | 13 | 1 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity Academic Conduct/Oppositional Disorders Depression | NS; except MPH + CBT > CBT MPH + CBT, MPH > Placebo + CBT; MPH vs MPH + CBT = NS MPH + CBT, MPH > Placebo + CBT; MPH vs MPH + CBT = NS MPH + CBT, MPH > Placebo + CBT; MPH vs MPH + CBT = NS NS
Long 1993 | Parallel | 32 | ADHD DSM-IIIR/IV | MPH MPH + Bibliotherapy-protocol | 8 | 10 | 1 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity Conduct/Oppositional Disorders | MPH + PT manual > MPH NS MPH + PT manual > MPH
MTA Coop Group 1999 | Parallel | 579 | ADHD DSM-IIIR/IV | Medication (MedMgt) Psychosocial (Beh) Combined Med + Psychosocial (Comb) Assessment + Referral (CC) | Varies up to 112 weeks | 20 | 3 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity Academic Conduct/Oppositional Disorders Social | MedMgt > Beh; Comb~MedMgt; Comb, MedMgt > Beh,CC Comb > Beh, CC (reading only) Comb > Beh, CC; MedMgt ~ Beh, Comb MedMgt, Beh, Comb > CC; MedMgt ~ Beh, Comb
Nondrug vs. stimulant plus nondrug intervention
Borden 1989 | Parallel | 30 | ADD DSM-I-III | MPH + CBT Placebo + CBT CBT | 12 | 17 | 2 | Inattention/Hyperactivity/Impulsivity Academic | Data not presented in a manner compatible with extraction
Brown 1985 | Parallel | 30 | ADD DSM-I-III | MPH MPH + CBT CBT | 12 | 15 | 1 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity Academic | NR NR NR
Brown 1986 | Parallel | 40 | ADD DSM-I-III | MPH + AC MPH + CBT Placebo + AC Placebo + CBT | 12 | 14 | 3 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity Academic Conduct/Oppositional Disorders | NS NS NS NS
Brown 1988 | Parallel | 71 | ADD DSM-I-III | MPH + CT MPH + AC Placebo + CT Placebo + AC | 12 | 15 | 2 | Inattention/Hyperactivity/Impulsivity | Data not presented in a manner compatible with extraction
Carlson 1992 | Crossover | 24 | ADHD (DSM-IIIR/IV) | MPH + AC MPH + BC/Mod MPH + AC MPH + BC/Mod Placebo + AC Placebo + BC/Mod | Unclear | 15 | 1 | Academic | Data not presented in a manner compatible with extraction
Christensen 1975 | Crossover | 16 | Other | MPH + BC/Mod Placebo + BC/Mod | 4 | 12 | 4 | Academic Conduct/Oppositional Disorders | Data not presented in a manner compatible with extraction
Conrad 1971 | Parallel | 81 | Other | DEX DEX + CT Placebo Placebo + CT | NR | 12 | 2 | Academic | Data not presented in a manner compatible with extraction
Firestone 1986 | Parallel | 73 ^6^ | ADD DSM-I-III | MPH MPH + PT PT | 12 | 16 | 2 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity Academic Conduct/Oppositional Disorders | MPH, MPH + PT>Placebo + PT; MPH vs MPH + PT = NS MPH, MPH + PT>Placebo + PT; MPH vs MPH + PT = NS Placebo + PT, MPH, MPH + PT = NS MPH, MPH + PT > Placebo + PT; MPH vs MPH + PT = NS
Klein 1997 | Parallel | 89 | Other | MPH MPH + CBT Placebo + CBT | 8 | 13 | 1 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity Academic Conduct/Oppositional Disorders Depression | NS; except MPH + CBT > CBT MPH+CBT, MPH > Placebo+CBT; MPH vs MPH+CBT = NS MPH+CBT, MPH > Placebo+CBT; MPH vs MPH+CBT = NS MPH+CBT, MPH > Placebo+CBT; MPH vs MPH+CBT = NS NS
Nondrug vs. stimulant plus nondrug intervention (cont.)
Hinshaw 1989 | Crossover | 24 | ADHD DSM-IIIR/IV | MPH + CBT Placebo + CBT | Unclear | 15 | 2 | Inattention/Hyperactivity/Impulsivity | MPH+CBT > Placebo + CBT
Hinshaw 1984 | Crossover | 24 | ADHD DSM-IIIR/IV | MPH + CT MPH + AC Placebo + CT Placebo + AC | 5 (drug) 1 (therapy) | 18 | 2 | Academic | NS except for CT, MPH + CT, MPH + AC > AC
MTA Coop Group 1999 | Parallel | 579 | ADHD DSM-IIIR/IV | Medication (MedMgt) Psychosocial (Beh) Combined Med + Psychosocial (Comb) Assessment + Referral (CC) | varies up to 112 weeks | 20 | 3 | Inattention/Hyperactivity/Impulsivity | Effect of BC/Mod added to MPH was not significant for any of the dependent measures
Pelham 1993 | Crossover | 31 | ADHD DSM-IIIR/IV | Placebo BC/Mod Low MPH + BC/Mod Low MPH High MPH + BC/Mod High MPH | Unclear | 15 | 1 | Inattention/Hyperactivity/Impulsivity | NS except for MPH + AC, MPH + BC/Mod > AC
Solanto 1997 | Crossover | 22 | ADHD DSM-IIIR/IV | MPH + AC MPH + BC/Mod Placebo + AC Placebo+ BC/Mod | 1 | 17 | 3 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity Academic Conduct/Oppositional Disorders Social | MedMgt > Beh; Comb~MedMgt; Comb, MedMgt > Beh, CC Comb > Beh, CC (reading only) Comb > Beh, CC; MedMgt ~ Beh, Comb MedMgt, Beh, Comb > CC; MedMgt ~ Beh, Comb

1 These are clinically relevant elements extracted from the studies that are not supported by empirical methodological research. Refer to Evidence Table D3 for details of the 20 elements.

2 Data on adverse effects are included in the Adverse Effects Table only (Evidence Tables H1a--H1h).

3 Results are based on various reports, not all of which give usable data or outcomes. Specific outcomes in each category are given in Evidence Tables D2, D3, and Supplemental Evidence Tables D4--D8.

4 Results given are for drug-to-drug comparisons, NOT baseline/placebo comparisons.

5 Outcomes regarded, a priori, as not of interest by expert panel are not included in this table but are discussed in the text if clinically significant

6 Number of randomized subjects not reported; number of subjects analyzed is given in table.

Abbreviations used: AC-attention control; ADD-attention-deficit disorder; ADHD-attention-deficit/hyperactivity disorder; BC/Mod-behavioral contingencies/modification; BDI-Beck's depression inventory; CBT-cognitive behavioral therapy; CDRS-Children's Depression Rating Scale; CT-child training; Des-desipramine; DEX-dextroamphetamine; DSM-Diagnostic and Statistical Manual of Mental Disorders; L-amph-l-amphetamine; MBD-minimal brain dysfunction; MPH or MPH-reg-methylphenidate; MPH-SR-sustained-release methylphenidate; POMS-Profile of mood states; PT-parent training; SSERS-Stimulant Side Effects Rating Scale; ST-supportive therapy; STESS-Subject's Treatment Emergent Symptom Scale; THIOR-thioridazine; > = better than; NS-not significant; NR-statistical significance not reported.

Evidence Table D2. Total Number of Characteristics Checked for Combination Therapy Comparisons^1^

Author | # Subjects Eligible (Q14) ^2^ | # Subjects Randomized (Q15) ^2^ | # Subjects Analyzed (Q17) ^2^ | Ethnic Groups Considered (Q18) ^2^ | Treatment Setting (Q19) ^2^ | Inclusion Criteria Reported (Q21) ^2^ | Exclusion Criteria Reported (Q22) ^2^ | Primary Outcome Stated (Q23) ^2^ | Age Categories of Subjects (Q24) ^2^ | Gender of Subjects (Q25) ^2^ | IQ Considered In Selection of Subjects (Q26) ^2^ | Diagnosis Model Used (Q28) ^2^ | Comorbid Disorders Considered (Q29a) ^2^ | Comorbid Disorders in Population (Q29b) ^2^ | Who Diagnosed Subjects (Q30) ^2^ | Sample Origin (Q31) ^2^ | Family Characteristics Mentioned (Q32) ^2^ | Fidelity & Monitoring of Treatment Mentioned (Q34) ^2^ | Compliance with Treatment Measured (Q35) ^2^ | Baseline Test Scores Presented (Q36) ^2^ | Total Count (20) ^2^
Stimulant vs. a combination of two or more drugs
Garfinkel 1981 | 0 | 1 | 1 | 0 | 1 | 1 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 15
Gittelman-Klein 1976 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 1 | 16
Levy 1996 | 0 | 0 | 1 | 0 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 0 | 13
Rapport 1993 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 17
Schechter 1985 | 0 | 1 | 1 | 0 | 1 | 0 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 0 | 1 | 1 | 1 | 13
Stimulant vs. stimulant plus nondrug intervention
Brown 1985 | 0 | 1 | 1 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 0 | 1 | 15
Conrad 1971 | 1 | 1 | 1 | 0 | 1 | 1 | 0 | 0 | 1 | 0 | 1 | 0 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 0 | 12
Firestone 1986 | 1 | 0 | 1 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 16
Klein 1997 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 0 | 0 | 0 | 0 | 1 | 13
Long 1993 | 0 | 1 | 0 | 0 | 1 | 1 | 0 | 0 | 1 | 1 | 0 | 1 | 0 | 0 | 1 | 1 | 1 | 1 | 0 | 0 | 10
MTA Coop Group 1999 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 20
Nondrug vs. stimulant plus nondrug intervention
Borden 1989 | 0 | 1 | 1 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 17
Brown 1985 | 0 | 1 | 1 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 0 | 1 | 15
Brown 1986 | 0 | 1 | 1 | 0 | 1 | 0 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 14
Brown 1988 | 0 | 1 | 0 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 15
Carlson 1992 | 0 | 1 | 1 | 0 | 1 | 0 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 15
Christensen 1975 | 0 | 1 | 1 | 0 | 1 | 0 | 0 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 0 | 1 | 0 | 1 | 1 | 1 | 12
Conrad 1971 | 1 | 1 | 1 | 0 | 1 | 1 | 0 | 0 | 1 | 0 | 1 | 0 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 0 | 12
Firestone 1986 | 1 | 0 | 1 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 16
Klein 1997 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 0 | 0 | 0 | 0 | 1 | 13
Hinshaw 1984 | 1 | 1 | 0 | 0 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 0 | 15
Hinshaw 1989 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 18
MTA Coop Group 1999 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 20
Pelham 1993 | 0 | 1 | 1 | 1 | 1 | 0 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 16
Solanto 1997 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 1 | 17

1 0 = absent; 1 = present

2 Q numbers given in brackets are the question number from the data extraction form (Appendix E)

Evidence Table D3. Description of Characteristics Checked for Combination Therapy Comparisons

Author | # Subjects Eligible (Q14) ^1^ | # Subjects Randomized (Q15) ^1^ | # Subjects Analyzed (Q17) ^1^ | Ethnic Groups Considered (Q18) ^1^ | Treatment Setting (Q19) ^1^ | Inclusion Criteria Reported (Q21) ^1^ | Exclusion Criteria Reported (Q22) ^1^ | Primary Outcome Stated (Q23) ^1^ | Age Categories of Subjects (Q24) ^1^ | Gender of Subjects (Q25) ^1^ | IQ Considered in Selection of Subjects (Q26) ^1^ | Diagnosis Model Used (Q28) ^1^ | Comorbid Disorders Considered (Q29A) ^1^ | Comorbid Disorders in Population (Q29B) ^1^ | Who Diagnosed Subjects (Q30) ^1^ | Sample Origin (Q31) ^1^ | Family Characteristics Mentioned (Q32) ^1^ | Fidelity & Monitoring of Treatment Mentioned (Q34) ^1^ | Compliance with Treatment Measured (Q35) ^1^ | Baseline Test Scores Presented (Q36) ^1^ | Total Count (20) ^1^
Stimulant vs. a combination of two or more drugs
Garfinkel 1981 | NR | 6 | 6 | No | MHOP | Yes | No | No | 5-12 yr | Male | Yes >90 | ADD | Yes | NP | Clin | MHOP | No | Yes | Yes | Yes | 15
Gittelman-Klein 1976 | 166 | 166 | 155 | White Afro | MHOP Home | Yes | No | No | 5-12 yr | Male Female | Yes >85 | ADD | Yes | NP | Clin Parent Teach | MHOP PCOP Home School | Yes | No | No | Yes | 16
Levy 1996 | NR | NR | 10 | No | HoOP | yes | No | Yes | 5-12 yr | Male | Yes NM | ADD | Yes | ODD | Clin | HoOP | Yes | No | No | No | 13
Rapport 1993 | 20 | 16 | 16 | White Afro | HoIP | Yes | No | No | 5-12 yr | Male | Yes >80 | ADHD | Yes | ODD CD, AD DD, LD | Clin | HoIP | Yes | Yes | Yes | No | 17
Schechter 1985 | NR | 10 | 10 | No | HoOP Home | No | No | No | 5-12 yr | Male | Yes >85 | HySy | Yes | NP | NR | HoOP | No | Yes | Yes | Yes | 13
Stimulant vs. stimulant plus nondrug intervention
Brown 1985 | NR | 30 | 30 | No | MHOP Home | Yes | Yes | No | 5-12 yr | Male | Yes NM | ADD | Yes | NP | Clin Parent Teach | PCOP School | No | Yes | No | Yes | 15
Conrad 1971 | 262 | 81 | 68 | No | MHOP Home | Yes | No | No | 5-12 yr | NR | Yes NM | TeDi | No | NM | Teach | School | Yes | Yes | Yes | No | 12
Firestone 1986 | 134 | NR | 73 | No | HoOP | Yes | Yes | No | 5-12 yr | Male Female | Yes >85 | ADD | Yes | CD | Clin | MHOP PCOP | Yes | Yes | No | Yes | 16
Klein 1997 | NR | 89 | 86 | White Afro Hispanic Asian | Home School | Yes | Yes | No | 5-12 yr | Male Female | Yes >85 | InMe | Yes | NP | Clin Parent Teach | NR | No | No | No | Yes | 13
Long 1993 | NR | 32 | NR | No | MHOP | Yes | No | No | 5-12 yr | Male Female | No | ADHD | No | NM | Clin | MHOP | Yes | Yes | No | No | 10
MTA Coop Group 1999 | 609 | 579 | 559 | White Afro Hispanic | Home School Comm | Yes | Yes | Yes | 5-12 yr | Male Female | Yes >80 | ADHD | Yes | ODD, CD, AD, Depress Touret | Clin Parent | MHOP Comm School | Yes | Yes | Yes | Yes | 20
Nondrug vs. stimulant plus nondrug intervention
Borden 1989 | NR | 30 | 23 | No | MHOP | Yes | Yes | No | 5-12 yr | Male Female | Yes >80 | ADD | Yes | NP | Clin | PCOP | Yes | Yes | Yes | Yes | 17
Brown 1985 | NR | 30 | 30 | No | MHOP Home | Yes | Yes | No | 5-12 yr | Male | Yes NM | ADD | Yes | NP | Clin Parent Teach | PCOP School | No | Yes | No | Yes | 15
Brown 1986 | NR | 40 | 35 | No | MHOP | No | No | No | 5-12 yr 13-18 yr | Male Female | Yes NM | ADD | Yes | CD | Clin | PCOP School | No | Yes | Yes | Yes | 14
Brown 1988 | NR | 71 | NR | No | HoOP Home | Yes | Yes | No | 5-12 yr 13-18 yr | Male Female | Yes NM | ADD | Yes | NP | Clin Parent Teach | NR | Yes | Yes | Yes | Yes | 15
Carlson 1992 | NR | 24 | 24 | No | School | No | Yes | No | 5-12 yr | Male | Yes NM | ADHD | Yes | ODD CD, LD | Clin | MHOP | No | Yes | Yes | Yes | 15
Christensen 1975 | NR | 16 | 13 | No | School | No | No | No | 5-12 yr 13-18 yr | Male Female | Yes <70 | NR | Yes | MRIQ | Unclear | School | No | Yes | Yes | Yes | 12
Conrad 1971 | 262 | 81 | 68 | No | MHOP Home | Yes | No | No | 5-12 yr | NR | Yes NM | TeDi | No | NM | Teach | School | Yes | Yes | Yes | No | 12
Firestone 1986 | 134 | NR | 73 | No | HoOP | Yes | Yes | No | 5-12 yr | Male Female | Yes NM | ADD | Yes | CD | Clin | MHOP PCOP | Yes | Yes | No | Yes | 16
Hinshaw 1984 | 24 | 24 | Unclear | No | School | Yes | No | Yes | 5-12 yr 13-18 yr | Male Female | Yes >85 | InMe | Yes | NP | Clin Parent Teach | NR | No | No | No | Yes | 13
Hinshaw 1989 | NR | 24 | 24 | White Afro Hispanic | MHOP Home School | Yes | Yes | No | 5-12 yr | Male | Yes NM | ADHD | Yes | NP | Clin | MHOP PCOP Comm School | On | Yes | Yes | No | 15
Klein 1997 | NR | 89 | 86 | White Afro Hispanic Asian | Home School | Yes | Yes | No | 5-12 yr | Male | Yes NM | ADHD | Yes | ODD CD,LD | Clin | MHOP PCOP | Yes | Yes | Yes | Yes | 18
MTA Coop Group 1999 | 609 | 579 | 559 | White Afro Hispanic | Home School Comm | Yes | Yes | Yes | 5-12 yr | Male Female | Yes >80 | ADHD | Yes | ODD, CD, AD, Depress Touret | Clin Parent | MHOP Comm School | Yes | Yes | Yes | Yes | 20
Pelham 1993 | NR | 31 | 31 | White Afro | MHOP School | No | Yes | No | 5-12 yr | Male | Yes NM | ADHD | Yes | ODD CD, LD | Clin | MHOP | No | Yes | Yes | Yes | 15
Solanto 1997 | 22 | 22 | 22 | White Hispanic East Indian | HoOP | Yes | No | Yes | 5-12 yr | Male Female | Yes >80 | ADHD | Yes | ODD AD | Clin | HoOP PCOP | Yes | No | No | Yes | 17

1 Q numbers given in brackets are the question number from the data extraction form (Appendix E).

Abbreviations: AD- anxiety disorder; ADHD- attention-deficit/hyperactivity disorder (DSM-IIIR-IV); ADD- attention-deficit disorder (DSM-I-III); Clin- clinician; Com- community; CoPh- community physicians; DD- depressive disorder; HoIP- hospital inpatient; HoOP- hospital outpatient; HySy- hyperkinetic syndrome; InMe- individual method; LD- learning disorder.

MBD- minimal brain dysfunction; MHOP- mental health clinic outpatient; MRIQ- mental retardation/low IQ; NM- none mentioned; NP- none present; NR- not reported; PC- pediatric clinic; PCOP- pediatric clinic outpatient; Teach- teacher; TeDi- teacher diagnosis; Touret- Tourette's; ADHD- ADHD Activity Scale.

Evidence Table E1. Key Characteristics of Studies Comparing Tricyclic Antidepressants vs. Placebo

Author & Year of Publication | Type | Patients Randomized | Diagnosis Model | Interventions | Duration per Intervention (weeks) | Clinically Relevant Elements (of 20) ^1^ | Quality Assessment Total Score (of 5) | Outcomes of Interest Measured ^2^ | Outcome Results ^3,^ ^4,^ ^5^
Studies evaluating desipramine
Biederman 1989a+b | Parallel | 73 | ADD DSM-I-III | Placebo Desipramine | 6 | 16 | 4 | Core/Global Symptoms Depression | Desipramine > Placebo Desipramine > Placebo
Donnelly 1986 | Parallel | 29 | ADD DSM-I-III | Placebo Desipramine | 2 | 13 | 2 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity | Desipramine > Placebo NS
Gualtieri 1991 | Crossover | 12 | ADD DSM-I-III | Placebo Desipramine-L Desipramine-M Desipramine-H | 1 | 14 | 2 | Core/Global Symptoms | Desipramine-M > Placebo for parent; NS for teacher
Rapport 1993 | Crossover | 16 | ADHD DSM-IIIR/IV | MPH Desipramine MPH + Desipramine Placebo | 1 | 17 | 3 | Adverse effects | Data not presented in a manner compatible with extraction
Singer 1995 | Crossover | 37 | ADHD DSM-IIIR/IV | Placebo Desipramine Clonidine | 6 | 12 | 3 | Inattention/Hyperactivity/Impulsivity | Desipramine > Clonidine
Wilens 1996 | Parallel | 43 | ADHD DSM-IIIR/IV | Desipramine Placebo | 6 | 15 | 2 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity | Desipramine > Placebo Desipramine > Placebo
Studies evaluating imipramine
Gualtieri 1988 | Crossover | 9 ^6^ | ADD (DSM-I-III) | Placebo Imipramine 1 mg Imipramine 2 mg Imipramine 5 mg | 1 | 11 | 2 | Inattention/Hyperactivity/ Impulsivity | Imipramine > Placebo
Werry 1980 | Crossover | 30 | Other | MPH Imipramine Placebo | 4 | 12 | 2 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity Academic Conduct/Oppositional Disorders Depression | Imipramine > MPH, Placebo NS for teachers; Imipramine > MPH for parents NS NS for teachers; Imipramine > MPH, Placebo for parents NS
Winsberg 1980 | Crossover | 11 | ADD (DSM-I-III) | Placebo Imipramine | 2 | 15 | 3 | Inattention/Hyperactivity/Impulsivity Conduct/Oppositional Disorders | NS; except Imipramine > Placebo for parent report of inattention NS

1 These are clinically relevant elements extracted from the studies that are not supported by empirical methodological research. Refer to Evidence Table E3 for details of the 20 elements.

2 Data on adverse effects are included in the Adverse Effects Table only (Evidence Tables H1a--H1h).

3 Results are based on various reports, not all of which give usable data or outcomes. Specific outcomes in each category are given in Evidence Tables E2, E3, and Supplemental Evidence Tables E4--E8.

4 Results given are for drug-to-drug comparisons, NOT baseline/placebo comparisons.

5 Outcomes regarded, a priori, as not of interest by expert panel are not included in this table but are discussed in the text if clinically significant.

6 Number of randomized subjects not reported; number of subjects analyzed is given in table.

Abbreviations used: AC-attention control; ADD-attention-deficit disorder; ADHD-attention-deficit/hyperactivity disorder; BC/Mod-behavioral contingencies/modification; BDI-Beck's depression inventory; CBT-cognitive behavioral therapy; CDRS-Children's Depression Rating Scale; CT-child training; Des-desipramine; DEX-dextroamphetamine; DSM-Diagnostic and Statistical Manual of Mental Disorders; L-amph-l-amphetamine; MBD-minimal brain dysfunction; MPH or MPH-reg-methylphenidate; MPH-SR-sustained-release methylphenidate; POMS-Profile of mood states; PT-parent training; SSERS-Stimulant Side Effects Rating Scale; ST-supportive therapy; STESS-Subject's Treatment Emergent Symptom Scale; THIOR-thioridazine; > = better than; NS-not significant; NR-statistical significance not reported; ~ about the same as.

Evidence Table E2. Total Number of Characteristics Checked for Studies Evaluating Tricyclic Antidepressants vs. Placebo^1^

Author | # Subjects Eligible (Q14) ^2^ | # Subjects Randomized (Q15) ^2^ | # Subjects Analyzed (Q17) ^2^ | Ethnic Groups Considered (Q18) ^2^ | Treatment Setting (Q19) ^2^ | Inclusion Criteria Reported (Q21) ^2^ | Exclusion Criteria Reported (Q22) ^2^ | Primary Outcome Stated (Q23) ^2^ | Age Categories of Subjects (Q24) ^2^ | Gender Of Subjects (Q25) ^2^ | IQ Considered In Selection of Subjects (Q26) ^2^ | Diagnosis Model Used (Q28) ^2^ | Comorbid Disorders Considered (Q29a) ^2^ | Comorbid Disorders in Population (Q29b) ^2^ | Who Diagnosed Subjects (Q30) ^2^ | Sample Origin (Q31) ^2^ | Family Characteristics Mentioned (Q32) ^2^ | Fidelity & Monitoring of Treatment (Q34) ^2^ | Compliance With Treatment Measured (Q35) ^2^ | Baseline Test Scores Presented (Q36) ^2^ | Total Count (20) ^2^
Studies evaluating desipramine
Biederman 1989 a+b | 0 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 16
Donnelly 1986 | 0 | 1 | 1 | 0 | 1 | 1 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 0 | 1 | 13
Gualtieri 1991 | 0 | 1 | 1 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 1 | 0 | 14
Rapport 1993 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 17
Singer 1995 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 0 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 0 | 0 | 12
Wilens 1996 | 0 | 1 | 1 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 1 | 15
Studies evaluating imipramine
Gualtieri 1988 | 0 | 0 | 1 | 0 | 1 | 1 | 0 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 0 | 1 | 11
Werry 1980 | 0 | 1 | 1 | 0 | 1 | 1 | 0 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 0 | 0 | 1 | 0 | 12
Winsberg 1980 | 0 | 1 | 1 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 1 | 15

1 0 = absent; 1 = present

2 Q numbers given in brackets are the question number from the data extraction form (Appendix E).

Evidence Table E3. Description of Characteristics Checked for Studies Evaluating Tricyclic Antidepressants vs. Placebo

Author | # Subjects Eligible (Q14) ^1^ | # Subjects Randomized (Q15) ^1^ | # Subjects Analyzed (Q17) ^1^ | Ethnic Groups Considered (Q18) ^1^ | Treatment Setting (Q19) ^1^ | Inclusion Criteria Reported (Q21) ^1^ | Exclusion Criteria Reported (Q22) ^1^ | Primary Outcome Stated (Q23) ^1^ | Age Categories Of Subjects (Q24) ^1^ | Gender of Subjects (Q25) ^1^ | IQ Considered In Selection of Subjects (Q26) ^1^ | Diagnosis Model Used (Q28) ^1^ | Comorbid Disorders Considered (Q29a) ^1^ | Comorbid Disorders in Population (Q29b) ^1^ | Who Diagnosed Subjects (Q30) ^1^ | Sample Origin (Q31) ^1^ | Family Characteristics Mentioned (Q32) ^1^ | Fidelity & Monitoring of Treatment Mentioned (Q34) ^1^ | Compliance With Treatment Measured (Q35) ^1^ | Baseline Test Scores Presented (Q36) ^1^ | Total Count (20) ^1^
Studies evaluating desipramine
Biederman 1989a, 1989b | NR | 73 | 62 | White | MHOP | Yes | No | No | 5-12 yr 13-18 yr | Male Female | Yes > 70 | ADD | Yes | ODD CD, AD DD, LD | Clin Parent Teach | MHOP | Yes | No | Yes | Yes | 16
Donnelly 1986 | NR | 29 | 29 | No | MHOP | Yes | No | No | 5-12 yr | Male | Yes NM | ADD | Yes | ODD CD, LD | Clin Parent Teach | School | No | No | No | Yes | 13
Gualtieri 1991 | NR | 12 | 12 | No | HoIP | Yes | Yes | No | 5-12 yr | Male Female | Yes > 70 | ADD | Yes | NP | Clin | HoIP | No | No | Yes | No | 14
Rapport 1993 | 20 | 16 | 16 | White Afro | HoIP | Yes | No | No | 5-12 yr | Male | Yes > 80 | ADHD | Yes | ODD CD, AD DD, LD | Clin | HoIP | Yes | Yes | Yes | No | 17
Singer 1995 | 37 | 37 | 34 | White Afro | HoOP | No | No | No | 5-12 yr 13-18 yr | Male Female | No | ADHD | Yes | Touret | Clin | HoOP | No | No | No | No | 12
Wilens 1996 | NR | 43 | 41 | No | HoOP | Yes | Yes | No | >18 yr | Male Female | Yes > 75 | ADHD | Yes | CD, AD DD | Clin | HoOP | Yes | No | No | Yes | 15
Studies evaluating imipramine
Gualtieri 1988 | NR | NR | 9 | No | HoIP | Yes | No | No | NR | Male Female | Yes NM | ADD | Yes | NP | Clin | HoIP | No | No | No | Yes | 11
Werry 1980 | NR | 30 | 30 | No | HoOP Home | Yes | No | No | 5-12 yr | Male Female | Yes NM | InMe | Yes | NP | Clin | HoOP School | No | No | Yes | No | 12
Winsberg 1980 | NR | 11 | 10 | No | MHOP | Yes | Yes | No | 5-12 yr | Male Female | Yes NM | ADD | Yes | NP | Clin Teach | MHOP School | Yes | No | No | Yes | 15

1 Q numbers given in brackets are the question number from the data extraction form (Appendix E).

Abbreviations: AD-anxiety disorder; ADHD-attention-deficit/hyperactivity disorder (DSM-IIIR-IV); ADD-attention-deficit disorder (DSM-I-III); Clin-clinician; Comm-community; CommPh-community physicians; DD-depressive disorder; HoIP-hospital inpatient; HoOP-hospital outpatient; HySy-hyperkinetic syndrome; InMe-individual method; LD-learning disorder; MBD-minimal brain dysfunction; MHOP-mental health clinic outpatient; MRIQ-mental retardation/low IQ; NM-none mentioned; NP-none present; NR-not reported; PC-pediatric clinic; PCOP-pediatric clinic outpatient; Teach-teacher; TeDi-teacher diagnosis; Touret-Tourette's syndrome; ADHD-ADHD Activity Scale.

Evidence Table F1. Key Characteristics of Studies With Long-term Therapy

Author & Year of Publication | Type | Patients Randomized | Diagnosis Model | Interventions | Duration per Intervention (weeks) | Clinically Relevant Elements (of 20) ^1^ | Quality Assessment Total Score (of 5) | Outcomes of Interest Measured ^2^ | Outcome Results ^3,^ ^4,^ ^5^
Studies evaluating MPH vs. placebo
Brown 1986 | Parallel | 40 | ADD DSM-I-III | MPH + CT MPH + CBT Placebo + CT Placebo + CBT | 12 | 14 | 3 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity Academic Conduct/Oppositional Disorders | NS NS NS NS
Brown 1988 | Parallel | 71 | ADD DSM-I-III | MPH + CT MPH + AC Placebo + CT Placebo + AC | 12 | 15 | 2 | Inattention/Hyperactivity/Impulsivity | Data not presented in a manner compatible with extraction
Firestone 1986 | Parallel | 73 ^6^ | ADD DSM-I-III | MPH MPH + PT Placebo + PT | 12 | 16 | 2 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity Academic Conduct/Oppositional Disorders Depression | No statistical evidence of long-term difference among the three groups in any of the outcomes measured.
Kupietz 1988 | Parallel | 58 | ADD DSM-I-III | MPH-low MPH-med MPH-high Placebo | 28 | 16 | 3 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity Academic Conduct/Oppositional Disorders | MPH > Placebo MPH 0.7 > Placebo; MPH 0.3, 0.5 vs Placebo = NS NS MPH > Placebo
Schachar 1997 | Parallel | 91 | ADHD DSM-IIIR/IV | MPH Placebo | 16 | 17 | 4 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity Conduct/Oppositional Disorders | NS for parent; MPH > Placebo MPH > Placebo for teachers; NS for parents NS; except MPH > Placebo ODD and aggressiveness teachers
Studies evaluating MPH vs. other interventions
Brown 1985 | Parallel | 30 | ADD DSM-I-III | MPH MPH + CBT CBT | 12 | 15 | 1 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity Academic | NR NR NR
Gittelman-Klein 1976 | Parallel | 166 | ADD DSM-I-III | MPH THIOR MPH + THIOR | 12 | 16 | 3 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity Academic Conduct/Oppositional Disorders Depression | MPH, MPH + THIOR > THIOR MPH, MPH + THIOR > THIOR teachers; NS parents NS; except MPH, MPH + THIOR > THIOR arithmetic MPH ± THIOR > THIOR teachers; NS parents NS
MTA Coop Group 1999 | Parallel | 579 | ADHD DSM-IIIR/IV | Medication (MedMgt) Psychosocial (Beh) Combined Med + Psychosocial (Comb) Assessment + Referral (CC) | 60 | 20 | 2 | Inattention/Hyperactivity/Impulsivity Conduct/Oppositional Disorders Depression | NS NS NS
Quinn 1975 | Parallel | 75 | Other | MPH Imipramine | 52 | 7 | 3 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity Academic Conduct/Oppositional Disorders Social | MedMgt > Beh; Comb~MedMgt; Comb, MedMgt > Beh,CC Comb > Beh, CC (reading only) Comb > Beh, CC; MedMgt ~ Beh, Comb MedMgt, Beh, Comb > CC; MedMgt ~ Beh, Comb
Studies evaluating DEX
Conrad 1971 | Parallel | 81 | Other | DEX DEX + CT Placebo Placebo + CT | Approx. 20 | 12 | 2 | Academic | Data not presented in a manner compatible with extraction
Gillberg 1997 | Parallel | 62 | ADHD DSM-IIIR/IV | DEX Placebo | 52 | 15 | 2 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity Academic Conduct/Oppositional Disorders Depression | DEX > Placebo DEX > Placebo NS DEX > Placebo NS
Greenhill 1973 | Crossover | 9 | Other | DEX Lithium carbonate Placebo | 12 | 12 | 2 | Adverse effects | Data not presented in a manner compatible with extraction
Studies evaluating other interventions
Fehlings 1991 | Parallel | 26 | ADHD DSM-IIIR/IV | Supportive therapy CBT | 16 | 16 | 2 | Inattention/Hyperactivity/Impulsivity Depression | NS; except CBT > ST for hyperactivity CBT > ST
Linden 1996 | Parallel | 18 | ADHD DSM-IIIR/IV | EEG-Biofeedback Nothing | 26 | 14 | 1 | Inattention/Hyperactivity/Impulsivity Academic Conduct/Oppositional Disorders | Biofeedback > Nothing for inattention NS for hyperactivity Biofeedback > Nothing NS

1 These are clinically relevant elements extracted from the studies that are not supported by empirical methodological research. Refer to Evidence Table F3 for details of the 20 elements.

2 Data on adverse effects are included in the Adverse Effects Table only (Evidence Tables H1a-H1h).

3 Results are based on various reports, not all of which give usable data or outcomes. Specific outcomes in each category are given in Evidence Tables F2, F3, and Supplemental Evidence Tables F4--F8.

4 Results given are for drug-to-drug comparisons, NOT baseline/placebo comparisons.

5 Outcomes regarded, a priori, as not of interest by expert panel are not included in this table but are discussed in the text if clinically significant.

6 Number of randomized subjects not reported; number of subjects analyzed is given in table.

Abbreviations used: AC-attention control; ADD-attention-deficit disorder; ADHD-attention-deficit/hyperactivity disorder; BC/Mod-behavioral contingencies/modification; BDI-Beck's depression inventory; CBT-cognitive behavioral therapy; CDRS-Children's Depression Rating Scale; CT-child training; Des-desipramine; DEX-dextroamphetamine; DSM-Diagnostic and Statistical Manual of Mental Disorders; L-amph-l-amphetamine; MBD-minimal brain dysfunction; MPH or MPH-reg-methylphenidate; MPH-SR-sustained-release methylphenidate; POMS-Profile of mood states; PT-parent training; SSERS-Stimulant Side Effects Rating Scale; ST-supportive therapy; STESS-Subject's Treatment Emergent Symptom Scale; THIOR-thioridazine; > = better than; NS-not significant; NR-statistical significance not reported; ~ about the same as.

Evidence Table F2. Total Number of Characteristics Checked for Studies Evaluating Long-term Therapy^1^

Author | # Subjects Eligible (Q14) ^2^ | # Subjects Randomized (Q15) ^2^ | # Subjects Analyzed (Q17) ^2^ | Ethnic Groups Considered (Q18) ^2^ | Treatment Setting (Q19) ^2^ | Inclusion Criteria Reported (Q21) ^2^ | Exclusion Criteria Reported (Q22) ^2^ | Primary Outcome Stated (Q23) ^2^ | Age Categories of Subjects (Q24) ^2^ | Gender Of Subjects (Q25) ^2^ | IQ Considered in Selection of Subjects (Q26) ^2^ | Diagnosis Model Used (Q28) ^2^ | Comorbid Disorders Considered (Q29A) ^2^ | Comorbid Disorders in Population (Q29B) ^2^ | Who Diagnosed Subjects (Q30) ^2^ | Sample Origin (Q31) ^2^ | Family Characteristics Mentioned (Q32) ^2^ | Fidelity & Monitoring of Treatment (Q34) ^2^ | Compliance with Treatment Measured (Q35) ^2^ | Baseline Test Scores Presented (Q36) ^2^ | Total Count (20) ^2^
Studies evaluating MPH vs. placebo
Brown 1986 | 0 | 1 | 1 | 0 | 1 | 0 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 14
Brown 1988 | 0 | 1 | 0 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 15
Firestone 1986 | 1 | 0 | 1 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 16
Kupietz 1988 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 1 | 1 | 16
Schachar 1997 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 17
Studies evaluating MPH vs. other interventions
Brown 1985 | 0 | 1 | 1 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 0 | 1 | 15
Gittelman-Klein 1976 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 1 | 16
MTA Coop Group 1999 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 1 | 1 | 0 | 0 | 0 | 0 | 0 | 1 | 7
Quinn 1975 | 0 | 1 | 1 | 0 | 1 | 0 | 0 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 20
Studies evaluating DEX
Conrad 1971 | 1 | 1 | 1 | 0 | 1 | 1 | 0 | 0 | 1 | 0 | 1 | 0 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 0 | 12
Gillberg 1997 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 0 | 1 | 15
Greenhill 1973 | 0 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 0 | 0 | 1 | 1 | 0 | 0 | 12
Studies evaluating other interventions
Fehlings 1991 | 0 | 1 | 1 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 16
Linden 1996 | 0 | 1 | 1 | 0 | 1 | 0 | 1 | 0 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 14

1 0 = absent; 1 = present

2 Q numbers given in brackets are the question number from the data extraction form (Appendix E).

Evidence Table F3. Description of Characteristics Checked for Studies Evaluating Long-term Therapy

Author | # Subjects Eligible (Q14) ^1^ | # Subjects Randomized (Q15) ^1^ | # Subjects Analyzed (Q17) ^1^ | Ethnic Groups Considered (Q18) ^1^ | Treatment Setting (Q19) ^1^ | Inclusion Criteria Reported (Q21) ^1^ | Exclusion Criteria Reported (Q22) ^1^ | Primary Outcome Stated (Q23) ^1^ | Age Categories of Subjects (Q24) ^1^ | Gender of Subjects (Q25) ^1^ | IQ Considered in Selection Of Subjects (Q26) ^1^ | Diagnosis Model Used (Q28) ^1^ | Comorbid Disorders Considered (Q29a) ^1^ | Comorbid Disorders in Population (Q29b) ^1^ | Who Diagnosed Subjects (Q30) ^1^ | Sample Origin (Q31) ^1^ | Family Characteristics Mentioned (Q32) ^1^ | Fidelity & Monitoring of Treatment Mentioned (Q34) ^1^ | Compliance with Treatment Measured (Q35) ^1^ | Baseline Test Scores Presented (Q36) ^1^ | Total Count (20) ^1^
Studies evaluating MPH vs. placebo
Brown 1986 | NR | 40 | 35 | No | MHOP | No | No | No | 5-12 yr 13-18 yr | Male Female | Yes NM | ADD | Yes | CD | Clin | PCOP School | No | Yes | Yes | Yes | 14
Brown 1988 | NR | 71 | NR | No | HoOP Home | Yes | Yes | No | 5-12 yr 13-18 yr | Male Female | Yes NM | ADD | Yes | NP | Clin Parent Teach | NR | Yes | Yes | Yes | Yes | 15
Firestone 1986 | 134 | NR | 73 | No | HoOP | Yes | Yes | No | 5-12 yr | Male Female | Yes > 85 | ADD | Yes | CD | Clin | MHOP PCOP | Yes | Yes | Np | Yes | 16
Kupietz 1988 | 58 | 58 | 47 | No | MHOP | Yes | Yes | No | 5-12 yr 13-18 yr | Male Female | Yes > 80 | ADD | Yes | NP | Clin Teach | HoOP Com School | No | No | Yes | Yes | 16
Schachar 1997 | 105 | 91 | 66 | No | HoOP | Yes | Yes | No | 5-12 yr | Male Female | Yes > 80 | ADHD | Yes | ODD CD, AD | Clin | HoOP | No | Yes | Yes | Yes | 17
Studies evaluating MPH vs. other interventions
Brown 1985 | NR | 30 | 30 | No | MHOP Home | Yes | Yes | No | 5-12 yr | Male | Yes NM | ADD | Yes | NP | Clin Parent Teach | PCOP School | No | Yes | No | Yes | 15
Gittelman-Klein 1976 | 166 | 166 | 155 | White Afro | MHOP Home | Yes | No | No | 5-12 yr | Male Female | Yes > 85 | ADD | Yes | NP | Clin Parent | MHOP PCOP Home School | Yes | No | No | Yes | 16
MTA Coop Group 1999 | 609 | 579 | 559 | white afro hispanic | Home School Comm | Yes | Yes | Yes | 5-12 yr | Male | NR | NR | Yes | NP | NR | NR | No | No | No | Yes | 7
Quinn 1975 | NR | 75 | 36 | No | Comm | No | No | No | NR | Male Female | Yes >80 | ADHD | Yes | ODD, CD Touret, DD, AD | Clin Parent | MHOP Comm School | Yes | Yes | Yes | Yes | 20
Studies evaluating DEX
Conrad 1971 | 262 | 81 | 68 | No | MHOP Home | Yes | No | No | 5-12 yr | NR | Yes NM | TeDi | No | NM | Teach | School | Yes | Yes | Yes | No | 12
Gillberg 1997 | 72 | 62 | 32 | No | MHOP | Yes | Yes | No | 5-12 yr | Male Female | Yes > 50 | ADHD | Yes | ODD CD, AD Touret MRIQ Autism | Clin | MHOP | No | No | No | Yes | 15
Greenhill 1973 | NR | 9 | 9 | White | HoOP HoIP Home School | Yes | No | No | 5-12 yr 13-18 yr | Male Female | Yes NM | NR | Yes | NP | NR | NR | Yes | Yes | No | No | 12
Studies evaluating other interventions
Fehlings 1991 | NR | 26 | 25 | No | HoOP | Yes | Yes | No | 5-12 yr 13-18 yr | Male | Yes > 85 | ADHD | Yes | NP | Clin | PCOP School | No | Yes | Yes | Yes | 16
Linden 1996 | NR | 18 | 18 | No | MHOP | No | Yes | No | 5-12 yr 13-18 yr | NR | Yes NM | ADHD | Yes | ODD LD | Clin | Com | No | Yes | Yes | Yes | 14

1 Q numbers given in brackets are the question number from the data extraction form (Appendix E).

Abbreviations: AD- anxiety disorder; ADHD- attention-deficit/hyperactivity disorder (DSM-IIIR-IV); ADD- attention-deficit disorder (DSM-I-III); Clin- clinician; Com- community; CoPh- community physicians; DD- depressive disorder; HoIP- hospital inpatient; HoOP- hospital outpatient; HySy- hyperkinetic syndrome; InMe- individual method; LD- learning disorder; MBD- minimal brain dysfunction; MHOP- mental health clinic outpatient; MRIQ- mental retardation/low IQ; NM- none mentioned; NP- none present; NR- not reported; PC- pediatric clinic; PCOP- pediatric clinic outpatient; Teach- teacher; TeDi- teacher diagnosis; Touret- Tourette's syndrome; ADHD- ADHD Activity Scale.

Evidence Table G1. Key Characteristics of Studies in Adults

Author & Year of Publication | Type | Patients Randomized | Diagnosis Model | Interventions | Duration per Intervention (weeks) | Clinically Relevant Elements (of 20) ^1^ | Quality Assessment Total Score (of 5) | Outcomes of Interest Measured ^2^ | Outcome Results ^3,^ ^4,^ ^5^
Studies evaluating MPH vs. placebo
Evans 1994 | Crossover | 1 | ADHD (DSM-IIIR/IV) | MPH Placebo | 1 | 14 | 2 | Adverse effects | Data not presented in a manner compatible with extraction
Mattes 1984 | Crossover | 66 | ADD (DSM-I-III) | MPH Placebo | 3 | 14 | 2 | Core/Global Symptoms | Data not presented in a manner compatible with extraction
Reimherr 1984 | Crossover | 36 | ADD (DSM-I-III) | MPH Placebo | 2 | 12 | 2 | Core/Global Symptoms | Data not presented in a manner compatible with extraction
Spencer 1995 | Crossover | 25 | ADHD (DSM-IIIR/IV) | MPH Placebo | 3 | 19 | 3 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity Depression | MPH > Placebo MPH > Placebo NR
Wender 1985 | Crossover | 37 ^6^ | ADD (DSM-I-III) | MPH Placebo | 2 | 15 | 2 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity Conduct/Oppositional Disorders Depression | MPH > Placebo; except report of NS MPH > Placebo NS NS for BDI and sadness report; MPH > Placebo for POMS depression & anxiety
Studies evaluating DEX
Deveaugh-Geiss 1980 | Crossover | 1 | Hyperkinetic Syndrome | DEX-low DEX-high Secobarbitol Placebo | Unclear | 12 | 2 | Core/Global Symptoms | Data not presented in a manner compatible with extraction
Matochik 1994 | Parallel | 37 ^6^ | ADHD (DSM-IIIR/IV) | MPH DEX | Unclear | 11 | 1 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity | NR NR
Other interventions
Conners 1996 | Crossover | 18 | ADHD (DSM-IIIR/IV) | Nicotine Placebo | 1 | 14 | 2 | Depression | Data not presented in a manner compatible with extraction
Ernst 1996 | Parallel | 24** | ADHD (DSM-IIIR/IV) | Selegiline-low Selegiline-high Placebo | 6 | 15 | 2 | Core/Global Symptoms Depression | NS NS
Wender 1981 | Parallel | 60 | ADD (DSM-I-III) | Pemoline Placebo | 6 | 17 | 2 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity | Pemoline > Placebo Pemoline > Placebo
Wilens 1996 | Parallel | 43 | ADHD (DSM-IIIR/IV) | Desipramine Placebo | 6 | 15 | 2 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity | Desipramine > Placebo Desipramine > Placebo
Wood 1985 | Crossover | 16 | ADD (DSM-I-III) | Phenylalanine Placebo | Unclear | 14 | 2 | Core/Global Symptoms | NS

1 These are clinically relevant elements extracted from the studies that are not supported by empirical methodological research. Refer to Evidence Table G3 for details of the 20 elements.

2 Data on adverse effects are included in the Adverse Effects Table only (Evidence Tables H1a-H1h).

3 Results are based on various reports, not all of which give usable data or outcomes. Specific outcomes in each category are given in Evidence Tables G2, G3, and Supplemental Evidence Tables G5 --G8.

4 Results given are for drug-to-drug comparisons, NOT baseline/placebo comparisons.

5 Outcomes regarded, a priori, as not of interest by expert panel are not included in this table but are discussed in the text if clinically significant.

6 Number of randomized subjects not reported; number of subjects analyzed is given in table.

Abbreviations used: AC-attention control; ADD-attention-deficit disorder; ADHD-attention-deficit/hyperactivity disorder; BC/Mod-behavioral contingencies/modification; BDI-Beck's depression inventory; CBT-cognitive behavioral therapy; CDRS-Children's Depression Rating Scale; CT-child training; Des-desipramine; DEX-dextroamphetamine; DSM-Diagnostic and Statistical Manual of Mental Disorders; L-amph-l-amphetamine; MBD-minimal brain dysfunction; MPH or MPH-reg-methylphenidate; MPH-SR-sustained-release methylphenidate; POMS-Profile of mood states; PT-parent training; SSERS-Stimulant Side Effects Rating Scale; ST-supportive therapy; STESS-Subject's Treatment Emergent Symptom Scale; THIOR-thioridazine; > = better than; NS-not significant; NR-statistical significance not reported.

Evidence Table G2. Total Number of Characteristics Checked for Studies in Adults^1^

Author | # Subjects Eligible (Q14) ^2^ | # Subjects Randomized (Q15) ^2^ | # Subjects Analyzed (Q17) ^2^ | Ethnic Groups Considered (Q18) ^2^ | Treatment Setting (Q19) ^2^ | Inclusion Criteria Reported (Q21) ^2^ | Exclusion Criteria Reported (Q22) ^2^ | Primary Outcome Stated (Q23) ^2^ | Age Categories of Subjects (Q24) ^2^ | Gender of Subjects (Q25) ^2^ | IQ Considered in Selection Of Subjects (Q26) ^2^ | Diagnosis Model Used (Q28) ^2^ | Comorbid Disorders Considered (Q29a) ^2^ | Comorbid Disorders in Population (Q29b) ^2^ | Who Diagnosed Subjects (Q30) ^2^ | Sample Origin (Q31) ^2^ | Family Characteristics Mentioned (Q32) ^2^ | Fidelity & Monitoring of Treatment (Q34) ^2^ | Compliance with Treatment Measured (Q35) ^2^ | Baseline Test Scores Presented (Q36) ^2^ | Total Count (20) ^2^
Studies evaluating MPH vs. placebo
Evans 1994 | 1 | 1 | 1 | 0 | 1 | 0 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 14
Mattes 1984 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 0 | 0 | 14
Reimherr 1984 | 0 | 1 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 0 | 0 | 12
Spencer 1995 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 19
Wender 1985 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 1 | 15
Studies evaluating DEX
Deveaugh-Geiss 1980 | 1 | 1 | 1 | 0 | 1 | 0 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 0 | 0 | 12
Matochik 1994 | 0 | 0 | 1 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 0 | 0 | 1 | 0 | 1 | 0 | 0 | 1 | 11
Other interventions
Conners 1996 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 0 | 1 | 14
Ernst 1996 | 1 | 0 | 1 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 15
Wender 1981 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 1 | 17
Wilens 1996 | 0 | 1 | 1 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 1 | 15
Wood 1985 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 0 | 0 | 14

1 0= absent; 1 = present

2 Q numbers given in brackets are the question number from the data extraction form (Appendix E).

Evidence Table G3. Description of Characteristics Checked for Studies in Adults

Author | # Subjects Eligible (Q14) ^1^ | # Subjects Randomized (Q15) ^1^ | # Subjects Analyzed (Q!7) ^1^ | Ethnic Groups Considered (Q18) ^1^ | Treatment Setting (Q19) ^1^ | Inclusion Criteria reported (Q21) ^1^ | Exclusion Criteria Reported (Q22) ^1^ | Primary Outcome Stated (Q23) ^1^ | Age Categories of Subjects (Q24) ^1^ | Gender of Subjects (Q25) | IQ Considered in Selection of Subjects (Q26) ^1^ | Diagnosis Model Used (Q28) ^1^ | Comorbid Disorders Considered (Q29A) ^1^ | Comorbid Disorders in Population (Q29B) ^1^ | Who Diagnosed Subjects (Q30) ^1^ | Sample Origin (Q31) ^1^ | Family Characteristics Mentioned (Q32) ^1^ | Fidelity & Monitoring of Treatment Mentioned (Q34) ^1^ | Compliance with Treatment Measured (Q35) ^1^ | Baseline Test Scores Presented (Q36) ^1^ | Total Count (20) ^1^
Studies evaluating MPH vs. placebo
Evans 1994 | 1 | 1 | 1 | No | MHOP | Unclear | Unclear | Yes | >18 yr | Female | No | ADHD | Yes | NP | Clin | HoOP MHOP | Yes | Yes | No | No | 14
Mattes 1984 | 116 | 66 | 61 | No | MHOP | Yes | Yes | No | >18 yr | Male Female | Yes NM | ADD | Yes | AD | Clin | MHOP Com | No | No | No | No | 14
Reimherr 1984 | NR | 36 | NR | No | HoOP | Yes | Yes | Yes | >18 yr | Male Female | No | ADD | Yes | AD, DD | Clin | MHOP Com | No | No | No | No | 12
Spencer 1995 | 25 | 25 | 23 | White | HoOP | Yes | Yes | Yes | >18 yr | Male Female | Yes >75 | ADHD | Yes | AD, CD DD | Clin | HoOP | Yes | No | Yes | Yes | 19
Wender 1985 | NR | NR | 37 | White | MHOP | Yes | Yes | No | >18 yr | Male Female | Yes >90 | ADD | Yes | AD | Clin | MHOP PCOP Com | Yes | No | No | Yes | 15
Studies evaluating DEX
Deveaugh-Ggeiss 1980 | 1 | 1 | 1 | No | HoOP | Unclear | No | No | >18 yr | Male | Yes 80 | HySy | Yes | NP | Clin | HoOP | No | No | No | No | 12
Matochik 1994 | NR | NR | 37 | No | MHOP | Yes | Yes | No | >18 yr | Male Female | Yes NM | ADHD | No | NM | Clin | Unclear | Yes | No | No | Yes | 11
Other interventions
Conners 1996 | 22 | 18 | 17 | No | HoOP | Yes | Yes | No | >18 yr | Male Female | No | ADHD | Yes | NP | Clin | PCOP Com | No | No | No | Yes | 14
Ernst 1996 | 44 | unclear | 24 | No | MHOP | Yes | Yes | No | >18 yr | Male Female | No | ADHD | Yes | NP | Clin | Com | Yes | No | Yes | Yes | 15
Wender 1981 | 60 | 60 | 26 | White | MHOP | Yes | Yes | No | >18 yr | Male Female | Yes >90 | ADD | Yes | AD | Clin | HoOP MHOP PCOP | Yes | No | No | Yes | 17
Wilens 1996 | NR | 43 | 41 | No | HoOP | Yes | Yes | No | >18 yr | Male Female | Yes >75 | ADHD | Yes | CD, AD DD | Clin | HoOP | Yes | No | No | Yes | 15
Wood 1985 | 19 | 16 | 13 | No | MHOP | Yes | Yes | No | >18 yr | Male Female | Yes >90 | ADD | Yes | NP | Clin | MHOP | No | No | No | No | 14

1 Q numbers given in brackets are the question number from the data extraction form (Appendix E).

Abbreviations: AD- anxiety disorder; ADHD- attention-deficit/hyperactivity disorder (DSM-IIIR-IV); ADD- attention-deficit disorder (DSM-I-III); Clin- clinician; Com- community; CoPh- community physicians; DD- depressive disorder; HoIP- hospital inpatient; HoOP- hospital outpatient; HySy- hyperkinetic syndrome; InMe- individual method; LD- learning disorder; MBD- minimal brain dysfunction; MHOP- mental health clinic outpatient; MRIQ- mental retardation/low IQ; NM- none mentioned; NP- none present; NR- not reported; PC- pediatric clinic; PCOP- pediatric clinic outpatient; Teach- teacher; TeDi- teacher diagnosis; Touret- Tourette's; ADHD- ADHD Activity Scale.

Evidence Table H1a. Key Characteristics of Studies with Adverse Effects Focusing on Sleep Disorders

Author & Year of Publication | Type | Number of Patients Randomized | Interventions | Duration per Intervention (weeks) | Clinically Relevant Elements (of 20) ^1^ | Quality Assessment Total Score (of 5) | Comments | Sleep Disorders Outcome Results ^2,^ ^3^ (x > y : adverse effects are significantly worse in x than y either in terms of frequency or intensity)
Studies evaluating only MPH and placebo
Ahmann 1993 | Crossover | 206 ^4^ | MPH-low MPH-high Placebo | 1, 2 | 13 | 2 | - Increase in insomnia with MPH therapy; - No significant dose effect | MPH 0.9, 1.5 > Placebo; MPH 0.9 vs. MPH 1.5 = NS
Barkley 1990 | Crossover | 83 ^4^ | MPH-low MPH-high Placebo | Unclear | 14 | 2 | - Insomnia measured as "severe" in 7% placebo, 18% MPH.03, and MPH.05 by parents; in 2% placebo, 0% MPH.03 and 2% MPH.05 by teachers; - Information alsocollected on nightmares; - Mean severity ratings: no significant differences between groups | MPH 0.3, 0.5 > Placebo; MPH 0.3 vs. MPH 0.5 = NS for parent; NS for teacher
Fine 1993 | Parallel | 24 ^4^ | MPH-low MPH-high Placebo | Unclear | 8 | 2 | - Information collected on trouble sleeping and nightmares; - No significant drug or dose effect reported; - High correlation between symptoms on parents ACRS and side effects questionnaire | NS
Fitzpatrick 1992 | Crossover | 19 ^4^ | MPH-low MPH-med MPH high-SR Placebo | 2 | 13 | 2 | - Information collected from parents using the STESS; - Sleep problems generally increased with MPH | MPH + MPH-SR > Placebo
Handen 1991 | Crossover | 27 | MPH-low MPH-high Placebo | 2 | 14 | 2 | - Side effects listed in the Physician's Desk Reference (presence or absence of symptom) based upon ratings of teachers | NS
Klorman 1990 | Crossover | 48 | MPH Placebo | 3 | 17 | 2 | - Information collected from parents in weekly telephone conversation | NS
Klorman 1987 | Crossover | 19 | MPH Placebo | 3 | 16 | 2 | - Frequency dichotomized as present or absent; - Information collected on sleep problem and sleepiness | NS
Spencer 1995 | Crossover | 25 | MPH Placebo | 3 | 19 | 3 | - Reported as insomnia; - 2 subjects had dose lowered because of side effects; - Subjective adverse effects more pronounced with active medication | NR
Stein 1996 | Crossover | 25 | MPH-titrate MPH-low MPH-high Placebo | 1 | 17 | 3 | - Reported as nightmares on SSERS parent interview; - Rated as severe in 12% at baseline, 4% on each of placebo, titration, and MPH-high; 0% MPH-low | NS
Wender 1985 | Crossover | 37 ^4^ | MPH Placebo | 2 | 15 | 2 | - Information collected from patients' subjective experience measuring on a 5-point scale, absent to very much | NS
Studies evaluating MPH and DEX with or without placebo
Arnold 1978 | Crossover | 29 ^4^ | MPH DEX Caffeine Placebo | 3 | 10 | 2 | - Reported as "awake at night"; - Reported by parents on a 4-point checklist -- "not at all" to "very much" | NS
Castellanos 1997 | Crossover | 22 | MPH DEX Placebo | 3 | 18 | 2 | - Reported as "insomnia"; - Effect remitted with change of medication or decreasing dose | NR
Elia 1991 | Crossover | 48 ^4^ | MPH DEX Placebo | 3 | 13 | 2 | - STESS data presented as mild, moderate, severe; - No significant difference between drugs or drug order | MPH, DEX > Placebo; MPH vs. DEX = NR
Gillberg 1997 | Parallel | 62 | DEX Placebo | 52 | 15 | 2 | - Information collected at physical examination; - "Early awakenings" and "disturbed sleep" occurred less frequently with DEX than at baseline | NS
Studies evaluating MPH and DEX with or without placebo (cont.)
Matochik 1994 | Parallel | 37 ^4^ | MPH DEX | Unclear | 11 | 1 | - Only pre-post comparisons available | NR
Pelham 1990 | Crossover | 22 ^4^ | MPH-reg MPH-SR DEX-SR Pemoline Placebo | 1 | 11 | 2 | - Reported as disturbed sleep, nightmares and sleep disorder; - Considerably more difficulty falling asleep was reported for all long-acting drugs than for placebo or MPH reg; - Pemoline had this effect in twice as many children | NR
Winsberg 1974 | Crossover | 20 | MPH DEX Placebo | 1 | 12 | 2 | - Reported as nightmares; - Side effects were rated by a nurse with a 33-item checklist as severe, moderate, mild or absent | NR
Studies evaluating MPH and drugs other than DEX
Barrickman 1995 | Crossover | 18 | MPH Bupropion | 6 | 16 | 2 | - Adverse effects were always transient and primarily reported during first 2 weeks of treatment; - No statistical analysis presented | NR
Buitelaar 1996 | Crossover | 32 | MPH Pindolol Placebo | 4 | 19 | 4 | - Reported as nightmares; - Measured by parents after 2 and 4 weeks (SSERS) on a 3-point scale | NS
Conners 1980 | Parallel | 60 | MPH Pemoline Placebo | 8 | 17 | 3 | - Reported as nightmares; - Several methods of recording side effects were used; - Little difference in parent-reported side effects among 3 treatment groups | NR
Gittelman-Klein 1976 | Parallel | 166 | MPH THIOR MPH+THIOR | 12 | 16 | 3 | - Reported as insomnia, trouble sleeping and sleepiness; - Presented information as mild or moderate, dichotomized from a 7-point scale | NR
Rapport 1993 | Crossover | 16 | MPH MPH + Desipramine Desipramine Placebo | NR | 17 | 3 | Sleep disturbance not found to differ significantly across medications | NR for STESS; NS for CDRS
Studies evaluating drugs other than MPH
Arnold 1976 | Crossover | 31 | DEX L-Amph Placebo | 4 | 11 | 3 | - Reported as awake at night; - Side effects are conspicuously undramatic | NS
Greenberg 1972 | Parallel | 61 ^4^ | DEX Hydroxyzine Chlorpromazine Placebo | 8 | 12 | 2 | - Children receiving chlorpromazine report sleepiness more often than any of the other children; - Intensity of all side effects improved with decreased dosage | NR at p=0.05 level

1 These are clinically relevant elements extracted from the studies that are not supported by empirical methodological research. Refer to Evidence Table H3 for the details of the 20 elements.

2 Results are based on various reports, not all of which give usable data or outcomes. For more details, see Evidence Tables H2, H3, and Supplemental Evidence Table H4.

3 Results given are for drug-to-drug/nondrug/placebo comparisons, NOT baseline comparisons.

4 Number of randomized subjects not reported; number of subjects analyzed is given in table.

Abbreviations used: AC-attention control; ADD-attention-deficit disorder; ADHD-attention-deficit/hyperactivity disorder; BC/Mod-behavioral contingencies/modification; BDI-Beck's depression inventory; CBT-cognitive behavioral therapy; CDRS-Children's Depression Rating Scale; CT-child training; DEX-dextroamphetamine; DSM-Diagnostic and Statistical Manual of Mental Disorders; L-amph-l-amphetamine; MBD-minimal brain dysfunction; MPH or MPH-reg-methylphenidate; MPH-SR-sustained-release methylphenidate; POMS-Profile of mood states; PT-parent training; SSERS-Stimulant Side Effects Rating Scale; ST-supportive therapy; STESS-Subject's Treatment Emergent Symptom Scale; THIOR-thioridazine; NS-not significant; NR-statistical significance not reported.

Evidence Table H1b. Key Characteristics of Studies with Adverse Effects Focusing on Headaches

Author & Year of Publication | Type | Number of Patients Randomized | Interventions | Duration per Intervention (weeks) | Clinically Relevant Elements (of 20) ^1^ | Quality Assessment Total Score (of 5) | Comments | Headaches: Outcome Results ^2,^ ^3^ (x > y : adverse effects are significantly worse in x than y either in terms of frequency or intensity)
Studies evaluating only MPH and placebo
Ahmann 1993 | Crossover | 206 ^4^ | MPH-low MPH-high Placebo | 1, 2 | 13 | 2 | - One child reported severe headaches and could not complete the protocol; - No significant dose effect | MPH 1.5 > Placebo; Placebo, MPH 1.5 vs. MPH 0.9 = NS
Barkley 1990 | Crossover | 80 ^4^ | MPH-low MPH-high Placebo | Unclear | 14 | 2 | - Low dose and high dose showed significant increase relative to placebo but no significant dose effect was apparent Rated as severe: 0% placebo, 1% MPH 0.3, 4% MPH 0.5 (parent); 0% placebo, 2% MPH 0.3, 0% MPH 0.5 (teacher) | MPH 0.3, 0.5 > Placebo; MPH 0.3 vs. MPH 0.5 = NS for parent; NS for teacher
Fine 1993 | Parallel | 24 ^4^ | MPH-low MPH-high Placebo | Unclear | 8 | 2 | - No statistically significant drug or dose effect reported | NS
Fitzpatrick 1992 | Crossover | 73 ^4^ | MPH-low MPH-med MPH high-SR Placebo | 2 | 13 | 2 | - Information collected from parents using STESS; - No statistically significant difference reported | NS
Handen 1991 | Crossover | 27 | MPH-low MPH-high Placebo | 2 | 14 | 2 | - Side effects listed in Physician's Desk Reference (presence or absence of symptom) based upon ratings of teachers | NS
Klorman 1990 | Crossover | 48 | MPH Placebo | 3 | 17 | 2 | - Information collected from parents in weekly telephone conversation | NS
Klorman 1987 | Crossover | 19 | MPH Placebo | 3 | 16 | 2 | - Frequency dichotomized as present or absent | NS
Stein 1996 | Crossover | 25 | MPH-titrate MPH-low MPH-high Placebo | 1 | 17 | 3 | - Collected on SSERS parent rating; - Rated as severe in 4% titration, 4% MPH 0.9, 0% baseline, placebo and MPH 0.6 | MPH 0.6 vs. MPH 0.9 = NS; Placebo vs. MPH 0.6, 0.9, titration = NS
Studies evaluating MPH and DEX with or without placebo
Arnold 1978 | Crossover | 29 ^4^ | MPH DEX Caffeine Placebo | 3 | 10 | 2 | - Reported by parents on a 4-point checklist: not at all to very much | NS
Gillberg 1997 | Parallel | 62 | DEX Placebo | 52 | 15 | 2 | - Information collected at physical examination | NS
Matochik 1994 | Parallel | 37 ^4^ | MPH DEX | Unclear | 11 | 1 | - Only pre-post comparisons available | NR
Pelham 1990 | Crossover | 22 ^4^ | MPH-reg MPH-SR DEX Pemoline Placebo | 1 | 11 | 2 | - No clear differences between drugs | NR
Studies evaluating MPH and drug other than DEX
Barrickman 1995 | Crossover | 18 | MPH Bupropion | 6 | 16 | 2 | - Adverse effects were always transient and primarily reported during first 2 weeks of treatment; - No statistical analysis presented | NR
Buitelaar 1996 | Crossover | 32 | MPH Pindolol Placebo | 4 | 19 | 4 | - Measured by parents after 2 and 4 weeks (SSERS) on a 3-point scale | NS
Conners 1980 | Parallel | 60 | MPH Pemoline Placebo | 8 | 17 | 3 | - Several methods of recording side effects were used; - Little difference in parent reported side effects among 3 treatment group | NR
Gittelman-Klein 1976 | Parallel | 166 | MPH THIOR MPH+THIOR | 12 | 16 | 3 | - Presented information as mild or moderate dichotomized from a 7-point scale | NR
Rapport 1993 | Crossover | 16 | MPH MPH + Desipramine Desipramine Placebo | NR | 17 | 3 | - Somatic factor on the IGRS; subjects were significantly worse on the combination MPH and desipramine when compared with MPH alone | NR statistically as an individual condition
Studies evaluating drugs other than MPH
Arnold 1976 | Crossover | 31 | DEX L-Amph Placebo | 4 | 11 | 3 | - Potential side effects were conspicuously undramatic as rated on the parents' checklist | NS
Greenberg 1972 | Parallel | 61 ^4^ | DEX Hydroxyzine Chlorpromazine Placebo | 8 | 12 | 2 | - Intensity of side effects improved with decreased dosage | NR at p=0.05 level

1 These are clinically relevant elements extracted from the studies that are not supported by empirical methodological research. Refer to Evidence Table H3 for the details of the 20 elements.

2 Results are based on various reports, not all of which give usable data or outcomes. For more details, see Evidence Tables H2, H3, and Supplemental Evidence Table H4.

3 Results given are for drug-to-drug/nondrug/placebo comparisons, NOT baseline comparisons.

4 Number of randomized subjects not reported; number of subjects analyzed is given in table.

Abbreviations used: AC-attention control; ADD-attention-deficit disorder; ADHD-attention-deficit/hyperactivity disorder; BC/Mod-behavioral contingencies/modification; BDI-Beck's depression inventory; CBT-cognitive behavioral therapy; CDRS-Children's Depression Rating Scale; CT-child training; DEX-dextroamphetamine; DSM-Diagnostic and Statistical Manual of Mental Disorders; IGRS-Inpatient Global Rating Scale; L-amph-l-amphetamine; MBD-minimal brain dysfunction; MPH or MPH-reg-methylphenidate; MPH-SR-sustained-release methylphenidate; POMS-Profile of mood states; PT-parent training; SSERS-Stimulant Side Effects Rating Scale; ST-supportive therapy; STESS-Subject's Treatment Emergent Symptom Scale; THIOR-thioridazine; NS-not significant; NR-statistical significance not reported.

Evidence Table H1c. Key Characteristics of Studies with Adverse Effects Focusing on Motor Tics

Author & Year of Publication | Type | Number of Patients Randomized | Interventions | Duration per Intervention (weeks) | Clinically Relevant Elements (of 20) ^1^ | Quality Assessment Total Score (of 5) | Comments | Motor Tics: Outcome Results^2,3^ (x > y : adverse effects are significantly worse in x than y either in terms of frequency or intensity)
Studies evaluating only MPH and placebo
Barkley 1990 | Crossover | 83 ^4^ | MPH-low MPH-high Placebo | Unclear | 14 | 2 | - No drug or dose effect reached statistical significance; - Score of 7 or higher on 10-point scale considered severe | Severe tics: 11% Placebo, 8% MPH-low; 4% MPH-high (teacher); 4% placebo, 7% MPH-low, 5% MPH-high (parent)
Gadow 1995 | Crossover | 34 ^4^ | MPH-low MPH-med MPH-high Placebo | 2 | 16 | 2 | - Ratings of motor, vocal and tic severity measured by the clinician; - Ratings of motor tic frequency and tic severity improved with MPH treatment | NS; except placebo > MPH for teacher
Schachar 1997 | Parallel | 91 | MPH Placebo | 16 | 17 | 4 | - Motor and vocal tics measured on 10-point scale; - Clinically significant if change >1SD or move from absent/mild to moderate or severe | NS
Stein 1996 | Crossover | 25 | MPH-titrate MPH-low MPH-high Placebo | 1 | 17 | 3 | - SSERS completed by parents (10-point scale); - Side effects (%present/%severe): Placebo 20/8; titration 16/4; MPH-low 8/0; MPH-high 12/4 | MPH-low vs. MPH-high = NS; Placebo vs. MPH-low, MPH-high, titration = NR
Studies evaluating MPH and DEX
Castellanos 1997 | Crossover | 22 | MPH DEX Placebo | 3 | 18 | 2 | - Tic severity significantly greater during the 2^nd^ and 3^rd^ weeks of DEX and during 2^nd^ week of MPH (NS at week 3 for MPH) | DEX > placebo MPH vs. Placebo, DEX = NS
Gillberg 1997 | Parallel | 62 | Dex Placebo | 52 | 15 | 2 | - Information collected at physical examination; - 18 children reported tics during the course of this study; 0 showed an increase in tic frequency or severity | NS
Studies evaluating MPH and drugs other than DEX
Buitelaar 1996 | Crossover | 32 | MPH Pindolol Placebo | 4 | 19 | 4 | - Measured by parents after 2 and 4 weeks (SSERS) on a 3-point scale; - Measured no distress, distress, considerable distress | NS

1 These are clinically relevant elements extracted from the studies that are not supported by empirical methodological research. Refer to Evidence Table H3 for the details of the 20 elements.

2 Results are based on various reports, not all of which give usable data or outcomes. For more details, see Evidence Tables H2, H3, and Supplemental Evidence Table H4.

3 Results given are for drug-to-drug/nondrug/placebo comparisons, NOT baseline comparisons.

4 Number of randomized subjects not reported; number of subjects analyzed is given in table.

Abbreviations used: AC-attention control; ADD-attention-deficit disorder; ADHD-attention-deficit/hyperactivity disorder; BC/Mod-behavioral contingencies/modification; BDI-Beck's depression inventory; CBT-cognitive behavioral therapy; CDRS-Children's Depression Rating Scale; CT-child training; DEX-dextroamphetamine; DSM-Diagnostic and Statistical Manual of Mental Disorders; L-amph-l-amphetamine; MBD-minimal brain dysfunction; MPH or MPH-reg-methylphenidate; MPH-SR-sustained-release methylphenidate; POMS-Profile of mood states; PT-parent training; SD-standard deviation; SSERS-Stimulant Side Effects Rating Scale; ST-supportive therapy; STESS-Subject's Treatment Emergent Symptom Scale; THIOR-thioridazine; NS-not significant; NR-statistical significance not reported.

Evidence Table H1d. Key Characteristics of Studies with Adverse Effects Focusing on Decreased Appetite

Author & Year of Publication | Type | Number of Patients Randomized | Interventions | Duration per Intervention (weeks) | Clinically Relevant Elements (of 20) ^1^ | Quality Assessment Total Score (of 5) | Comment | Decreased Appetite/Anorexia: Outcome Results^2,3^ (x > y: adverse effects are significantly worse in x than y either in terms of frequency or intensity)
Studies evaluating only MPH and placebo
Ahmann 1993 | Crossover | 206 ^4^ | MPH-low MPH-high Placebo | 1, 2 | 13 | 2 | A significant dose effect is apparent for decreased appetite; - 2 children removed from protocol for "severe" appetite side effects | MPH-low, MPH-high > Placebo; MPH-low vs MPH-high = NS
Barkley 1990 | Crossover | 80 ^4^ | MPH-low MPH-high Placebo | Unclear | 14 | 2 | - Significant drug and dose effect in parent rating; - Decreased appetite measured as "severe" in 1% placebo, 7% MPH-low; 13% MPH-high (parents), 2% placebo, 2% MPH-low, 6% MPH-high (teachers) | MPH-low, MPH-high > Placebo; MPH-low > MPH-high (parent rating)
Fine 1993 | Parallel | 24 ^4^ | MPH-low MPH-high Placebo | Unclear | 8 | 2 | - Mean severity rating by parents between active drug and placebo. No report of dose effect | MPH doses > Placebo
Fitzpatrick 1992 | Crossover | 73 ^4^ | MPH-low MPH-med MPH high-SR Placebo | 2 | 13 | 2 | - Information collected from parents using STESS; - No significant difference | NS
Handen 1991 | Crossover | 27 | MPH-low MPH-high Placebo | 2 | 14 | 2 | - Side effects listed in the Physician's Desk Reference (presence or absence of symptom) based upon ratings of teachers | NS
Klorman 1987 | Crossover | 19 | MPH Placebo | 3 | 16 | 2 | - Frequency dichotomized as present or absent; - Information collected on "eat less" | NS
Klorman 1990 | Crossover | 48 | MPH Placebo | 3 | 17 | 2 | - Weekly telephone conversation with parents; - Patients and parents report statistically significant appetite loss; - Weight loss not significantly correlated with reported appetite loss | MPH > Placebo
Spencer 1995 | Crossover | 25 | MPH Placebo | 3 | 19 | 3 | - Subjective adverse effects more pronounced with active medication | NS
Stein 1996 | Crossover | 25 | MPH-titrate MPH-low MPH-high Placebo | 1 | 17 | 3 | - Measured on the SSERS parent interview rated as severe in 12% titration, 4% MPH-low, 16% MPH-high | MPH-high, MPH titration > Placebo; MPH-low vs. MPH-high = NS
Studies evaluating MPH and DEX with or without placebo
Arnold 1978 | Crossover | 29 ^4^ | MPH DEX Caffeine Placebo | 3 | 10 | 2 | - Recorded as poor appetite; - Reported by parents on a 4-point checklist, "not at all" to "very much" | MPH, DEX > Placebo; DEX > Caffeine; MPH vs. Caffeine, DEX = NR
Castellanos 1997 | Crossover | 22 | MPH DEX Placebo | 3 | 18 | 2 | - Recorded as "marked appetite suppression with transient weight loss" | NR
Elia 1991 | Crossover | 48 ^4^ | MPH DEX Placebo | 3 | 13 | 2 | - STESS data presented in terms of level of severity: mild, moderate, severe; - No significant difference between drugs or drug order | MPH, DEX > Placebo; MPH vs. DEX = NR
Studies evaluating MPH and DEX with or without placebo (cont.)
Gillberg 1997 | Parallel | 62 | DEX Placebo | 52 | 15 | 2 | - Recorded as "poor appetite"; - Information collected at physical examination at 6 months | Amphetamine > Placebo
Pelham 1990 | Crossover | 22 ^4^ | MPH-reg MPH-SR DEX-SR Pemoline Placebo | 1 | 11 | 2 | - All medication caused a loss of appetite relative to placebo; - Long acting forms more than standard MPH | NR
Winsberg 1974 | Crossover | 20 | MPH DEX Placebo | 1 | 12 | 2 | - Reported as "anorexia"; - Side effects were monitored with a 33-item nurse-rated checklist as severe, moderate, mild, or absent | NR
Studies evaluating MPH and drug other than DEX
Barrickman 1995 | Crossover | 18 | MPH Bupropion | 6 | 16 | 2 | - Reported as "anorexia"; - Adverse effects were always transient and primarily reported during first 2 weeks of treatment; - No statistical analysis presented | NR
Buitelaar 1996 | Crossover | 32 | MPH Pindolol Placebo | 4 | 19 | 4 | - Reported as "anorexia"; - Measured by parents after 2 and 4 weeks (SSERS) on a 3-point scale; - Measured no distress, distress, considerable distress | NS
Conners 1980 | Parallel | 60 | MPH Pemoline Placebo | 8 | 17 | 3 | - Reported as "anorexia "; - Several methods of recording side effects used; - Little difference in parent-reported side effects among 3 treatment groups | NR NR
Gittelman-Klein 1976 | Parallel | 166 | MPH THIOR MPH+THIOR | 12 | 16 | 3 | - Reported as "appetite decreasing"; - Presented information as mild or moderate, dichotomized from a 7-point scale | NR
Quinn 1975 | Parallel | 75 | MPH Imipramine | 52 | 7 | 2 | - Reported as "anorexia" | NR
Rapport 1993 | Crossover | 16 | MPH MPH + Desipramine Desipramine Placebo | NR | 17 | 3 | - Appetite disturbance" on CDRS showed significant medication condition differences | NS
Studies evaluating drugs other than MPH
Arnold 1976 | Crossover | 31 | DEX L-Amphetamine Placebo | 4 | 11 | 3 | - Side effects are conspicuously undramatic; - Data collected as "poor appetite" | L-Amphetamine, DEX > Placebo
Greenberg 1972 | Parallel | 60 ^4^ | DEX Hydroxyzine Chlorpromazine Placebo | 8 | 12 | 2 | - DEX group complained of decreased appetite more than hydroxyzine and placebo-treated children; - Intensity of side effects improved with decreased dosage | NR at p=0.05 level

1 These are clinically relevant elements extracted from the studies that are not supported by empirical methodological research. Refer to Evidence Table H3 for the details of the 20 elements.

2 Results are based on various reports, not all of which give usable data or outcomes. For more details, see Evidence Tables H2, H3, and Supplemental Evidence Table H4.

3 Results given are for drug-to-drug/nondrug/placebo comparisons, NOT baseline comparisons.

4 Number of randomized subjects not reported; number of subjects analyzed is given in table.

Abbreviations used: AC-attention control; ADD-attention-deficit disorder; ADHD-attention-deficit/hyperactivity disorder; BC/Mod-behavioral contingencies/modification; BDI-Beck's depression inventory; CBT-cognitive behavioral therapy; CDRS-Children's Depression Rating Scale; CT-child training; DEX-dextroamphetamine; DSM-Diagnostic and Statistical Manual of Mental Disorders; L-amph-l-amphetamine; MBD-minimal brain dysfunction; MPH or MPH-reg-methylphenidate; MPH-SR-sustained-release methylphenidate; POMS-Profile of mood states; PT-parent training; SSERS-Stimulant Side Effects Rating Scale; ST-supportive therapy; STESS-Subject's Treatment Emergent Symptom Scale; THIOR-thioridazine; NS-not significant; NR-statistical significance not reported.

Evidence Table H1e. Key Characteristics of Studies with Adverse Effects Focusing on Abdominal Pain

Author & Year of Publication | Type | Number of Patients Randomized | Interventions | Duration per Intervention (weeks) | Quality Assessment Total Score (of 5) | Clinically Relevant Elements (of 20) ^1^ | Comments | Abdominal pain: Outcome Results^2,3^ (x > y: adverse effects are significantly worse in x than y either in terms of frequency or intensity
Studies evaluating only MPH and placebo
Ahmann 1993 | Crossover | 206 ^4^ | MPH-low MPH-high Placebo | 1, 2 | 2 | 13 | - Prevalence of stomach ache increased with MPH therapy but with no apparent dose effect; - One child withdrawn from study due to "severe" stomach aches | MPH-low, MPH-high > Placebo; MPH-low vs. MPH-high = NS
Barkley 1990 | Crossover | 83 ^4^ | MPH-low MPH-high Placebo | Unclear | 2 | 14 | - Significant drug and dose effect; - "Severe" stomach aches reported by parents in 0% placebo, 1% MPH-low , 6% MPH-high; by teachers in 0% placebo, 2% MPH-low, 2% MPH-high | MPH-low, MPH-high > Placebo; MPH-high > MPH-low for parent; NS for teacher
Fine 1993 | Parallel | 24 ^4^ | MPH-low MPH-high Placebo | Unclear | 2 | 8 | - No significant drug or dose effect reported | NS
Fitzpatrick 1992 | Crossover | 19 ^4^ | MPH-low MPH-med MPH high-SR Placebo | 2 | 2 | 13 | - Information collected from parents using STESS; - No significant difference | NS
Handen 1991 | Crossover | 27 | MPH-low MPH-high Placebo | 2 | 2 | 14 | - Side effects listed in the Physicians' Desk Reference (presence or absence of symptoms) based upon ratings of teachers | NS
Klorman 1990 | Crossover | 48 | MPH Placebo | 3 | 2 | 17 | - Information collected from parents in weekly telephone conversations | NS
Klorman 1987 | Crossover | 19 | MPH Placebo | 3 | 2 | 16 | - Frequency dichotomized as presence or absence | NS
Stein 1996 | Crossover | 25 | MPH-titrate MPH-low MPH-high Placebo | 1 | 3 | 17 | - Rated as "severe" in 8% on titration, 4% on MPH-low, 4% on MPH-high, 0% at baseline or on placebo; - SSERS rating by parents | MPH-low vs. MPH-high = NS; Placebo vs. MPH-low, MPH-high, titration = NS
Studies evaluating MPH and DEX with or without placebo
Arnold 1978 | Crossover | 29 ^4^ | MPH DEX Caffeine Placebo | 3 | 2 | 10 | - Reported by parents on a 4-point checklist "not at all" to "very much"; - Data collected as "tummy aches" | NS
Gillberg 1997 | Parallel | 62 | DEX Placebo | 52 | 2 | 15 | - Info collected at physical exam; - Occasionally or often in 32% on at least 1 assessment but no difference between baseline or treatment groups | NS
Pelham 1990 | Crossover | 22 ^4^ | MPH-reg MPH-SR DEX-SR Pemoline Placebo | 1 | 2 | 11 | - No clear difference between drugs | NR
Winsberg 1974 | Crossover | 20 | MPH DEX Placebo | 1 | 2 | 12 | - Side effects were monitored with a 33-item side-effects checklist rated by a nurse as "severe," "moderate," "mild," or "absent" | NR
Studies evaluating MPH and drugs other than DEX
Barrickman 1995 | Crossover | 18 | MPH Bupropion | 6 | 2 | 16 | - Adverse effects were always transient and primarily reported during first 2 weeks of treatment; - No statistical analysis presented | NR
Buitelaar 1996 | Crossover | 32 | MPH Pindolol Placebo | 4 | 4 | 19 | - Measured by parents after 2 and 4 weeks on a 3-point scale (SSERS) | NS
Conners 1980 | Parallel | 60 | MPH Pemoline Placebo | 8 | 3 | 17 | - Several methods of recording side effects were used; - Little difference in parent-reported side effects among 3 treatment groups | NR
Gittelman-Klein 1976 | Parallel | 166 | MPH THIOR MPH+THIOR | 12 | 3 | 16 | - Presented information as mild or moderate dichotomized from a 7-point scale | NR
Rapport 1993 | Crossover | 16 | MPH MPH + Desipramine Desipramine Placebo | NR | 3 | 17 | - "Stomach ache" data presented as >3 on the STESS | NR
Studies evaluating drugs other than MPH
Arnold 1976 | Crossover | 31 | DEX L-Amph Placebo | 4 | 3 | 11 | - Data collected as "tummy aches"; - "Side effects are conspicuously undramatic" | NS
Greenberg 1972 | Parallel | 61 ^4^ | DEX Hydroxyzine Chlorpromazine Placebo | 8 | 2 | 12 | - Children receiving DEX complained of stomach aches more often than those receiving hydroxyzine and placebo; - Intensity of all side effects improved with decreased dosage | NR at p=0.05 level

1 These are clinically relevant elements extracted from the studies that are not supported by empirical methodological research. Refer to Evidence Table H3 for the details of the 20 elements.

2 Results are based on various reports, not all of which give usable data or outcomes. For more details, see Evidence Tables H2, H3, and Supplemental Evidence Table H4.

3 Results given are for drug-to-drug/nondrug/placebo comparisons, NOT baseline comparisons.

4 Number of randomized subjects not reported; number of subjects analyzed is given in table.

Abbreviations used: AC-attention control; ADD-attention-deficit disorder; ADHD-attention-deficit/hyperactivity disorder; BC/Mod-behavioral contingencies/modification; BDI-Beck's depression inventory; CBT-cognitive behavioral therapy; CDRS-Children's Depression Rating Scale; CT-child training; DEX-dextroamphetamine; DSM-Diagnostic and Statistical Manual of Mental Disorders; L-amph-l-amphetamine; MBD-minimal brain dysfunction; MPH or MPH-reg-methylphenidate; MPH-SR-sustained-release methylphenidate; POMS-Profile of mood states; PT-parent training; SSERS-Stimulant Side Effects Rating Scale; ST-supportive therapy; STESS-Subject's Treatment Emergent Symptom Scale; THIOR-thioridazine; NS-not significant; NR-statistical significance not reported.

Evidence Table H1f. Key Characteristics of Studies with Adverse Effects Focusing on Irritability

Author & Year of Publication | Type | Number of Patients Randomized | Interventions | Duration per Intervention (weeks) | Clinically Relevant Elements (of 20) ^1^ | Quality Assessment Total Score (of 5) | Comments | Irritability: Outcome Results ^2,^ ^3^ (x > y: adverse effects are significantly worse in x than y either in terms of frequency or intensity)
Studies evaluating only MPH and placebo
Ahmann 1993 | Crossover | 206 ^4^ | MPH-low MPH-high Placebo | 1, 2 | 13 | 2 | - Decrease in irritability during Ritalin weeks of trial | MPH-low vs. Placebo, MPH-high = NS
Barkley 1990 | Crossover | 80 ^4^ | MPH-low MPH-high Placebo | Unclear | 14 | 2 | - Neither drug nor dose effect reached statistical significance; - Irritability measured as "severe" in 18% on placebo, 15% MPH-low, 13% MPH-high (parent ratings); 9% Placebo; 7% MPH-low, 2% MPH-high (teacher ratings) | NS
Fine 1993 | Parallel | 24 ^4^ | MPH-low MPH-high Placebo | Unclear | 8 | 2 | - No significant drug or dose effect reported; - High correlation between variables on parent ACRS and side effect questionnaire | NS
Handen 1991 | Crossover | 27 | MPH-low MPH-high Placebo | 2 | 14 | 2 | - Side effects listed in the Physician's Desk Reference (presence or absence of symptom) based upon ratings of teachers | MPH-high > Placebo; Placebo vs. MPH-low = NS; MPH-low vs. MPH-high = NR
Klorman 1987 | Crossover | 19 | MPH Placebo | 3 | 16 | 2 | - Frequency of symptoms dichotomized as present or absent | NS
Stein 1996 | Crossover | 25 | MPH-titrate MPH-low MPH-high Placebo | 1 | 17 | 3 | - Reported as severe in 28% at baseline; 21% on Placebo; 12% titration; 17% MPH-low; 16% MPH-high; (SSERS) parent rating | MPH-low vs. MPH-high = NS; Placebo vs. MPH-low, MPH-high, titration = NR
Studies evaluating MPH and DEX
Arnold 1978 | Crossover | 29 ^4^ | MPH DEX Caffeine Placebo | 3 | 10 | 2 | - Reported by parents on a 4-point checklist -- "not at all" to "very much" | NS
Pelham 1990 | Crossover | 22 ^4^ | MPH-reg MPH-SR DEX-SR Pemoline Placebo | 1 | 11 | 2 | No clear difference between drugs | NR
Studies evaluating MPH and drugs other than DEX
Barrickman 1995 | Crossover | 18 | MPH Bupropion | 6 | 16 | 2 | - Adverse effects were always transient and primarily reported during first 2 weeks of treatment; - No statistical analysis presented | NR
Buitelaar 1996 | Crossover | 32 | MPH Pindolol Placebo | 4 | 19 | 4 | - Measured by parents after 2 and 4 weeks (SSERS); - Measured no distress, distress, considerable distress | NS
Conners 1980 | Parallel | 60 | MPH Pemoline Placebo | 8 | 17 | 3 | - Several methods of recording side effects were used; - Little difference in parent-reported side effects among 3 treatment groups | NR
Studies evaluating drugs other than MPH
Arnold 1976 | Crossover | 31 | DEX L-Amph Placebo | 4 | 11 | 3 | - "Side effects are conspicuously undramatic" for both parents and teachers on David's Hyperkinetic Rating scale | NS
Greenberg 1972 | Parallel | 60 ^4^ | DEX Hydroxyzine Chlorpromazine Placebo | 8 | 12 | 2 | - Intensity of all side effects improved with decreased dosage | NR at p=0.05 level

1 These are clinically relevant elements extracted from the studies that are not supported by empirical methodological research. Refer to Evidence Table H3 for the details of the 20 elements.

2 Results are based on various reports, not all of which give usable data or outcomes. For more details, see Evidence Tables H2, H3, and Supplemental Evidence Table H4.

3 Results given are for drug-to-drug/nondrug/placebo comparisons, NOT baseline comparisons.

4 Number of randomized subjects not reported; number of subjects analyzed is given in table.

Abbreviations used: AC-attention control; ADD-attention-deficit disorder; ADHD-attention-deficit/hyperactivity disorder; BC/Mod-behavioral contingencies/modification; BDI-Beck's depression inventory; CBT-cognitive behavioral therapy; CDRS-Children's Depression Rating Scale; CT-child training; DEX-dextroamphetamine; DSM-Diagnostic and Statistical Manual of Mental Disorders; L-amph-l-amphetamine; MBD-minimal brain dysfunction; MPH or MPH-reg-methylphenidate; MPH-SR-sustained-release methylphenidate; POMS-Profile of mood states; PT-parent training; SSERS-Stimulant Side Effects Rating Scale; ST-supportive therapy; STESS-Subject's Treatment Emergent Symptom Scale; THIOR-thioridazine; NS-not significant; NR-statistical significance not reported.

Evidence Table H1g. Key Characteristics of Studies with Adverse Effects Focusing on Nausea

Author & Year of Publication | Type | Number of Patients Randomized | Interventions | Duration per Intervention (weeks) | Clinically Relevant Elements (of 20) ^1^ | Quality Assessment Total Score (of 5) | Comments | Nausea: Outcome Results ^2,^ ^3^ (x > y : adverse effects are significantly worse in x than y either in terms of frequency or intensity)
Studies evaluating only MPH and placebo
Fitzpatrick 1992 | Crossover | 73 ^4^ | MPH-low MPH-med MPH high-SR Placebo | 2 | 13 | 2 | - Information collected from parents using STESS; - No significant difference | NS
Klorman 1990 | Crossover | 48 | MPH Placebo | 3 | 17 | 2 | - Information collected from parents in weekly telephone conversation | NS
Klorman 1987 | Crossover | 19 | MPH Placebo | 3 | 16 | 2 | - Frequency of symptom dichotomized as present or absent | NS
Studies evaluating MPH and DEX
Gillberg 1997 | Parallel | 62 | DEX Placebo | 52 | 15 | 2 | - Information collected at physical exam | NS
Pelham 1990 | Crossover | 22 ^4^ | MPH-reg MPH-SR DEX-SR Pemoline Placebo | 1 | 11 | 2 | - No clear difference between drugs | NR
Winsberg 1974 | Crossover | 20 | MPH DEX Placebo | 1 | 12 | 2 | - Side effects were monitored with a 33-item checklist as severe, moderate, mild, or absent rated by a nurse | NR
Studies evaluating MPH and drugs other than DEX
Barrickman 1995 | Crossover | 18 | MPH Bupropion | 6 | 16 | 2 | - Adverse effects were always transient and primarily reported during first 2 weeks of treatment; - No statistical analysis presented | NR
Buitelaar 1996 | Crossover | 32 | MPH Pindolol Placebo | 4 | 19 | 4 | - Measured by parents after 2 and 4 weeks (SSERS); - Measured no distress, distress, considerable distress | NS
Conners 1980 | Parallel | 60 | MPH Pemoline Placebo | 8 | 17 | 3 | - Several methods of recording side effects were used; - Little difference in parent-reported side effects among 3 treatment groups | NR
Gittelman-Klein 1976 | Parallel | 166 | MPH THIOR MPH+THIOR | 12 | 16 | 3 | - Presented information as mild or moderate, dichotomized from a 7-point scale | NR
Rapport 1993 | Crossover | 16 | MPH MPH + Desipramine Desipramine Placebo | NR | 17 | 3 | - Considered a positive endorsement if scored > 3 on the STESS | NR

1 These are clinically relevant elements extracted from the studies that are not supported by empirical methodological research. Refer to Evidence Table H3 for the details of the 20 elements.

2 Results are based on various reports, not all of which give usable data or outcomes. For more details, see Evidence Tables H2, H3, and Supplemental Evidence Table H4.

3 Results given are for drug-to-drug/nondrug/placebo comparisons, NOT baseline comparisons.

4 Number of randomized subjects not reported; number of subjects analyzed is given in table.

Abbreviations used: AC-attention control; ADD-attention-deficit disorder; ADHD-attention-deficit/hyperactivity disorder; BC/Mod-behavioral contingencies/modification; BDI-Beck's depression inventory; CBT-cognitive behavioral therapy; CDRS-Children's Depression Rating Scale; CT-child training; DEX-dextroamphetamine; DSM-Diagnostic and Statistical Manual of Mental Disorders; L-amph-l-amphetamine; MBD-minimal brain dysfunction; MPH or MPH-reg-methylphenidate; MPH-SR-sustained-release methylphenidate; POMS-Profile of mood states; PT-parent training; SSERS-Stimulant Side Effects Rating Scale; ST-supportive therapy; STESS-Subject's Treatment Emergent Symptom Scale; THIOR-thioridazine; NS-not significant; NR-statistical significance not reported.

Evidence Table H1h. Key Characteristics of Studies with Adverse Effects Focusing on Fatigue/Tiredness

Author & Year of Publication | Type | Number of Patients Randomized | Interventions | Duration per Intervention (weeks) | Clinically Relevant Elements (of 20)^1^ | Quality Assessment Total Score (of 5) | Comments | Fatigue/Tiredness: Outcome Results ^2,^ ^3^ (x > y: adverse effects are significantly worse in x than y either in terms of frequency or severity)
Studies evaluating only MPH and placebo
Barkley 1990 | Crossover | 80 ^4^ | MPH-low MPH-high Placebo | Unclear | 14 | 2 | - Reported as drowsiness, not statistically significant in drug or dose effect by parent or teacher; - Reported as "severe" by parent in 1% of placebo, 2% of MPH-low, 1% MPH-high; and by teacher in 4% placebo, 4% MPH-low, 2% MPH-high | NS
Klorman 1987 | Crossover | 19 | MPH Placebo | 3 | 17 | 2 | - Frequency dichotomized as present or absent | NS
Stein 1996 | Crossover | 25 | MPH-titrate MPH-low MPH-high Placebo | 1 | 17 | 3 | - SSERS parent rated "severe" in 8% at baseline, 8% on placebo, 4% on titration, 4% on high, 0% on low | MPH low vs. high = NS; Placebo vs. MPH 0.6, 0.9, titration = NR
Wender 1985 | Crossover | 37 ^4^ | MPH Placebo | 2 | 15 | 2 | - Data collected from patient's subjective experience ranking 1=absent, 5=very much | NS
Studies evaluating MPH and DEX
Matochik 1994 | Parallel | 37 ^4^ | MPH DEX | Unclear | 11 | 1 | - Only pre -- postcomparisons available | NR
Pelham 1990 | Crossover | 22 ^4^ | MPH-reg MPH-SR DEX-SR Pemoline Placebo | 1 | 11 | 2 | - No clear difference between drugs | NR
Winsberg 1974 | Crossover | 20 | MPH DEX Placebo | 1 | 12 | 2 | - Side effects were monitored with a 33-item side- effects checklist rated as "severe," "moderate," "mild," or "absent" by a nurse | NR
Studies evaluating MPH and drugs other than DEX
Barrickman 1995 | Crossover | 18 | MPH Bupropion | 6 | 16 | 2 | - Adverse effects were always transient and primarily reported during first 2 weeks of treatment; - No statistical analysis presented | NR
Buitelaar 1996 | Crossover | 32 | MPH Pindolol Placebo | 4 | 19 | 2 | - Measured by parents after 2 and 4 weeks (SSERS) on a 3-point scale | NS
Rapport 1993 | Crossover | 16 | MPH MPH + Desipramine Desipramine Placebo | NR | 17 | 3 | - Data presented as a positive endorsement of >3 on the STESS | NR

1 These are clinically relevant elements extracted from the studies that are not supported by empirical methodological research. Refer to Evidence Table H3 for the details of the 20 elements.

2 Results are based on various reports, not all of which give usable data or outcomes. For more details, see Evidence Tables H2, H3, and Supplemental Evidence Table H4.

3 Results given are for drug-to-drug/nondrug/placebo comparisons, NOT baseline comparisons.

4 Number of randomized subjects not reported; number of subjects analyzed is given in table.

Abbreviations used: AC-attention control; ADD-attention-deficit disorder; ADHD-attention-deficit/hyperactivity disorder; BC/Mod-behavioral contingencies/modification; BDI-Beck's depression inventory; CBT-cognitive behavioral therapy; CDRS-Children's Depression Rating Scale; CT-child training; DEX-dextroamphetamine; DSM-Diagnostic and Statistical Manual of Mental Disorders; L-amph-l-amphetamine; MBD-minimal brain dysfunction; MPH or MPH-reg-methylphenidate; MPH-SR-sustained-release methylphenidate; POMS-Profile of mood states; PT-parent training; SSERS-Stimulant Side Effects Rating Scale; ST-supportive therapy; STESS-Subject's Treatment Emergent Symptom Scale; THIOR-thioridazine; NS-not significant; NR-statistical significance not reported.

Evidence Table H2. Total Number of Characteristics Checked for Studies with Adverse Effects^1^

Author | # Subjects Eligible (Q14) ^2^ | # Subjects Randomized (Q15) ^2^ | # Subjects Analyzed (Q17) ^2^ | Ethnic Groups Considered (Q18) ^2^ | Treatment Setting (Q19) ^2^ | Inclusion Criteria Reported (Q21) ^2^ | Exclusion Criteria Reported (Q22) ^2^ | Primary Outcome Stated (Q23) ^2^ | Age Categories of Subjects (Q24) ^2^ | Gender of Subjects (Q25) ^2^ | IQ Considered in Selection Of Subjects (Q26) ^2^ | Diagnosis Model Used (Q28) ^2^ | Comorbid Disorders Considered (Q29a) ^2^ | Comorbid Disorders in Population (Q29b) ^2^ | Who Diagnosed Subjects (Q30) ^2^ | Sample Origin (Q31) ^2^ | Family Characteristics Mentioned (Q32) ^2^ | Fidelity & Monitoring of Treatment Mentioned (Q34) ^2^ | Compliance with Treatment Measured (Q35) ^2^ | Baseline Test Scores Presented (Q36) ^2^ | Total Count (20) ^2^
Studies evaluating only MPH and placebo
Ahmann 1993 | 1 | 0 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 0 | 0 | 13
Barkley 1990 | 0 | 0 | 1 | 0 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 14
Fine 1993 | 0 | 0 | 1 | 0 | 1 | 0 | 0 | 1 | 1 | 1 | 0 | 1 | 0 | 0 | 1 | 1 | 0 | 0 | 0 | 0 | 8
Fitzpatrick 1992 | 0 | 0 | 1 | 0 | 1 | 0 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 13
Gadow 1995 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 16
Gittelman-Klein 1988 | 0 | 1 | 1 | 0 | 1 | 0 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 0 | 1 | 12
Handen 1991 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 0 | 1 | 0 | 14
Klorman 1987 | 0 | 1 | 1 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 16
Klorman 1990 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 17
Schachar 1997 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 17
Spencer 1995 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 19
Stein 1996 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 17
Wender 1985 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 1 | 15
Studies evaluating MPH and DEX with or without placebo
Arnold 1978 | 1 | 0 | 1 | 0 | 1 | 1 | 0 | 0 | 1 | 1 | 0 | 1 | 0 | 0 | 1 | 1 | 0 | 0 | 0 | 1 | 10
Castellanos 1997 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 0 | 1 | 18
Elia 1991 | 0 | 0 | 1 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 0 | 1 | 13
Gillberg 1997 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 0 | 1 | 15
Matochik 1994 | 0 | 0 | 1 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 0 | 0 | 1 | 0 | 1 | 0 | 0 | 1 | 11
Pelham 1990 | 0 | 0 | 1 | 0 | 1 | 0 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 0 | 1 | 11
Winsberg 1974 | 0 | 1 | 1 | 0 | 1 | 1 | 0 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 0 | 1 | 0 | 0 | 12
Studies evaluating MPH and drugs other than DEX
Barrickman 1995 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 1 | 16
Buitelaar 1996 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 19
Conners 1980 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 0 | 1 | 1 | 17
Gittelman-Klein 1976 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 1 | 16
Quinn 1975 | 0 | 1 | 1 | 0 | 1 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 1 | 1 | 0 | 0 | 0 | 0 | 0 | 1 | 7
Rapport 1993 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 17
Studies evaluating drugs other than MPH
Arnold 1976 | 1 | 1 | 1 | 0 | 1 | 1 | 0 | 0 | 1 | 1 | 0 | 1 | 0 | 0 | 1 | 1 | 0 | 0 | 0 | 1 | 11
Greenberg 1972 | 0 | 0 | 1 | 1 | 1 | 0 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 0 | 1 | 12

1 0 = absent; 1 = present

2 Q numbers given in brackets are the question number from the data extraction form (Appendix E).

Evidence Table H3. Total Number of Characteristics Checked for Studies with Adverse Effects

Author | # Subjects Eligible (Q14) ^1^ | # Subjects Randomized (Q15) ^1^ | # Subjects Analyzed (Q17) ^1^ | Ethnic Groups Considered (Q18) ^1^ | Treatment Setting (Q19) ^1^ | Inclusion Criteria Reported (Q21) ^1^ | Exclusion Criteria Reported (Q22) ^1^ | Primary Outcome Stated (Q23) ^1^ | Age Categories of Subjects (Q24) ^1^ | Gender of Subjects (Q25) ^1^ | IQ Considered In Selection of Subjects (Q26) ^1^ | Diagnosis Model Used (Q28) ^1^ | Comorbid Disorders Considered (Q29a) ^1^ | Comorbid Disorders in Population (Q29b) ^1^ | Who Diagnosed Subjects (Q30) ^1^ | Sample Origin (Q31) ^1^ | Family Characteristics Mentioned (Q32) ^1^ | Fidelity & Monitoring of Treatment Mentioned (Q34) ^1^ | Compliance with Treatment Measured (Q35) ^1^ | Baseline Test Scores Presented (Q36) ^1^ | Total Count (20) ^1^
Studies evaluating only MPH and placebo
Ahmann 1993 | 234 | NR | 206 | No | MHOP | Yes | Yes | Yes | 5-12 yr 13-18 yr | Male Female | No | ADHD | Yes | NP | Clin | MHOP | No | No | No | No | 13
Barkley 1990 | NR | NR | 83 | No | MHOP | Yes | No | Yes | 5-12 yr 13-18 yr | Male Female | Yes >80 | NR | Yes | NP | Clin | MHOP | Yes | No | Yes | Yes | 14
Fine 1993 | NR | NR | 24 | No | MHOP | No | No | Yes | 5-12 yr | Male Female | No | ADHD | No | NM | Clin | MHOP PCOP School | No | No | No | No | 8
Fitzpatrick 1992 | NR | NR | 19 | No | MHOP Home | No | No | No | 5-12 yr | Male Female | Yes NM | ADD | Yes | ODD CD | Clin Teach | PCOP | Yes | No | Yes | Yes | 13
Gadow 1995 | NR | NR | 34 | White, Afro Hispanic Asian | MHOP | Yes | Yes | No | 5-12 yr | Male | Yes >70 | ADHD | Yes | ODD CD, AD Touret | Clin Parent Teach | MHOP | Yes | No | Yes | Yes | 16
Gittelman-Klein 1988 | NR | 62 | 34 | No | MHOP | No | No | No | 5-12 yr | Male Female | Yes NM | ADD | Yes | NP | Clin | MHOP | No | No | No | Yes | 12
Handen 1991 | NR | 27 | 27 | White, Afro | MHOP | Yes | Yes | No | 5-12 yr | Male Female | Yes <80 | ADHD | Yes | MRIQ | Clin | NR | No | No | Yes | No | 14
Klorman 1987 | NR | 19 | 19 | No | MHOP Home | Yes | Yes | No | 5-12 yr 13-18 yr | Male Female | Yes >74 | ADD | Yes | NP | Clin | MHOP | Yes | No | Yes | Yes | 16
Klorman 1990 | NR | 48 | 48 | White | MHOP Home School | Yes | Yes | No | 5-12 yr 13-18 yr | Male Female | Yes >80 | ADD | Yes | ODD CD, AD | Clin | MHOP | Yes | No | Yes | Yes | 17
Schachar 1997 | 105 | 91 | 66 | No | HoOP | Yes | Yes | No | 5-12 yr | Male Female | Yes >80 | ADHD | Yes | ODD CD, AD | Clin | HoOP | No | Yes | Yes | Yes | 17
Spencer 1995 | 25 | 25 | 23 | White | HoOP | Yes | Yes | Yes | >18 yr | Male Female | Yes >75 | ADHD | Yes | CD, AD DD | Clin | HoOP | Yes | No | Yes | Yes | 19
Stein 1996 | NR | 25 | 25 | White Hispanic | HoOP | Yes | Yes | No | 5-12 yr | Male | Yes NM | ADHD | Yes | ODD CD | Clin | MHOP PCOP Com | Yes | No | Yes | Yes | 17
Wender 1985 | NR | NR | 37 | White | MHOP | Yes | Yes | No | >18 yr | Male Female | Yes >90 | ADD | Yes | AD | Clin | MHOP PCOP Com | Yes | No | No | Yes | 15
Studies evaluating MPH and DEX with or without placebo
Arnold 1978 | 31 | NR | 29 | No | MHOP Home | Yes | No | No | 5-12 yr | Male Female | No | MBD | No | NM | Clin | MHOP | No | No | No | Yes | 10
Castellanos 1997 | 38 | 22 | 20 | White, Afro Hispanic Asian | MHOP | Yes | Yes | Yes | 5-12 yr | Male | Yes >75 | ADHD | Yes | ODD CD Touret | Clin | MHOP PCOP Com School | No | Yes | No | Yes | 18
Elia 1991 | NR | NR | 48 | No | MHOP | Yes | Yes | No | 5-12 yr | Male | Yes >80 | ADD | Yes | ODD CD, AD | Clin | PCOP School | No | No | No | Yes | 13
Gillberg 1997 | 72 | 62 | 32 | No | MHOP | Yes | Yes | No | 5-12 yr | Male Female | Yes NM | ADHD | Yes | ODD CD, AD Touret MRIQ Autism | Clin | MHOP | No | No | No | Yes | 15
Matochik 1994 | NR | NR | 37 | No | MHOP | Yes | Yes | No | >18 yr | Male Female | Yes NM | ADHD | No | NM | Clin | Unclear | Yes | No | No | Yes | 11
Pelham 1990 | NR | NR | 22 | No | MHOP | No | No | No | 5-12 yr 13-18 yr | Male | Yes NM | ADHD | Yes | ODD CD, LD | Clin | MHOP | No | No | No | Yes | 11
Winsberg 1974 | NR | 20 | 18 | No | HoIP | Yes | No | No | 5-12 yr | Male Female | Yes NM | InMe | Yes | NP0 | Clin | HoIP HoOP | No | Yes | No | No | 12
Studies evaluating MPH and drugs other than DEX
Barrickman 1995 | NR | 18 | 15 | White | MHOP | Yes | Yes | No | 5-12 yr 13-18 yr | Male Female | Yes | ADHD | Yes | ODD CD, LD | Clin | MHOP | Yes | No | No | Yes | 16
Buitelaar 1996 | 55 | 32 | 32 | No | MHOP | Yes | Yes | Yes | 5-12 yr 13-18 yr | Male Female | Yes | ADHD | Yes | ODD CD, AD | Clin Parent | MHOP | Yes | Yes | Yes | Yes | 19
Conners 1980 | 60 | 60 | 60 | White Afro | MHOP Home | Yes | Yes | No | 5-12 yr | Male Female | Yes | MBD | Yes | NP | Clin | NR | Yes | No | Yes | Yes | 17
Gittelman-Klein 1976 | 166 | 166 | 155 | White Afro | MHOP Home | Yes | No | No | 5-12 yr | Male Female | Yes | ADD | Yes | NP | Clin Parent Teach | MHOP PCOP Home School | Yes | No | No | Yes | 16
Quinn 1975 | NR | 75 | 36 | No | Com | No | No | No | NR | Male | NR | NR | Yes | NP | NR | NR | No | No | No | Yes | 7
Rapport 1993 | 20 | 16 | 16 | White Afro | HoIP | Yes | No | No | 5-12 yr | Male | Yes | ADHD | Yes | ODD CD, AD DD, LD | Clin | HoIP | Yes | Yes | Yes | No | 17
Studies valuating drugs other than MPH
Arnold 1976 | 31 | 31 | 31 | No | MHOP | Yes | No | No | <5 yr 5-12 yr | Male Female | No | MBD | No | NM | Clin | MHOP | No | No | No | Yes | 11
Greenberg 1972 | NR | NR | 61 | Afro | HoOP | No | No | No | 5-12 yr | Male | Yes | HySy | Yes | NP | Clin | PCOP School | No | No | No | Yes | 12

1 Q numbers given in brackets are the question number from the data extraction form (Appendix E).

Abbreviations: AD-anxiety disorder; ADHD-attention-deficit/Hyperactivity disorder (DSM-IIIR-IV); ADD-attention deficit disorder (DSM-I-III); Clin-clinician; Com-community; CoPh-community physicians; DD-depressive disorder; HoIP-hospital inpatient; HoOP-hospital outpatient; HySy-hyperkinetic syndrome; InMe-individual method; LD- learning disorder; MBD-minimal brain dysfunction; MHOP-mental health clinic outpatient; MRIQ-mental retardation/low IQ; NM-none mentioned; NP-none present; NR-not reported; PC-pediatric clinic; PCOP-pediatric clinic outpatient; Teach-teacher; TeDi-teacher diagnosis; Touret-Tourette's; ADHD-ADHD Activity Scale.

Evidence Table I1. Key Characteristics of Studies with Stimulant vs. Placebo Comparisons

Author & Year of Publication | Type | Patients Randomized | Diagnosis Model | Interventions | Duration per Intervention (weeks) | Clinically Relevant Elements (of 20) ^1^ | Quality Assessment Total Score (of 5) | Outcomes of Interest Measured ^2^ | Outcome Results^3,4,5^
Ahmann 1993 | Crossover | NR | ADHD DSM-IIIR/IV | MPH-low MPH-high Placebo | 1 | 13 | 2 | Data on adverse effects only | No significant dose effect for adverse effects
Arnold 1976 | Crossover | 31 | MBD | DEX L-amph Placebo | 4 | 11 | 3 | Core/Global Symptoms Depression | NS; one parent report of DEX > L-Amphetamine NS
Arnold 1978 | Crossover | 29 ^6^ | MBD | MPH DEX Caffeine Placebo | 3 | 10 | 2 | Core/Global Symptoms Academic | MPH vs. DEX = NS MPH vs. DEX = NS
Arnold 1989 | Crossover | 18 ^6^ | ADD DSM-I-III | DEX Efamol Placebo | 4 | 10 | 3 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity | NS DEX > Efamol
Barkley 1990 | Crossover | 80 ^6^ | Other | MPH-low MPH-high Placebo | Unclear | 14 | 2 | Data on adverse effects only | Details available in Tables H1a through H1h
Borcherding 1989 | Crossover | 18 ^6^ | ADD DSM-I-III | MPH DEX Placebo | 3 | 12 | 2 | Inattention/Hyperactivity/Impulsivity | Data not presented in a manner compatible with extraction
Brown 1986 | Parallel | 40 | ADD DSM-I-III | MPH + AC MPH + CBT Placebo + AC Placebo + CBT | 12 | 14 | 3 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity Academic Conduct/Oppositional Disorders | NS NS NS NS
Buitelaar 1996 | Crossover | 32 | ADHD DSM-IIIR/IV | MPH Pindolol Placebo | 4 | 19 | 4 | Data on adverse effects available | Details available in Tables H1a through H1h
Carlson 1992 | Crossover | 24 | ADHD DSM- IIIR/IV | MPH + AC MPH + BC/Mod MPH + AC MPH + BC/Mod Placebo + AC Placebo+ BC/Mod | Unclear | 15 | 1 | Academic | Data not presented in a manner compatible with extraction
Castellanos 1997 | Crossover | 22 | ADHD DSM-IIIR/IV | MPH DEX Placebo | 3 | 18 | 2 | Data on adverse effects only | Details available in Tables H1a through H1h
Christensen 1975 | Crossover | 16 | Other | MPH + BC/Mod Placebo + BC/Mod | 4 | 12 | 4 | Academic Conduct/Oppositional Disorders | Data not presented in a manner compatible with extraction
Conners 1972 | Parallel | 84 | MBD | DEX Pemoline Placebo | 8 | 15 | 1 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity Academic Conduct/Oppositional Disorders Depression | NS NS NS NS NS
Conners 1980 | Parallel | 60 | MBD | MPH Pemoline Placebo | 8 | 17 | 3 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity Academic Conduct/Oppositional Disorders Depression | NS NS NS NS NS
Conners 1996 | Crossover | 18 | ADHD DSM-IIIR/IV | Nicotine Placebo | 1 | 14 | 2 | Depression | Data not presented in a manner compatible with extraction
Deveaugh-Geiss 1980 | Crossover | 1 | Hyperkinetic Syndrome | DEX-low DEX-high Secobarbitol Placebo | Unclear | 12 | 2 | Core/Global Symptoms | Data not presented in a manner compatible with extraction
Elia 1991 | Crossover | 48 ^6^ | ADD DSM-I-III | MPH DEX Placebo | 3 | 13 | 2 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity Conduct/Oppositional Disorders Depression | NS NS NS NS
Evans 1994 | Crossover | 1 | ADHD DSM-IIIR/IV | MPH Placebo | 1 | 14 | 2 | Data on adverse effects only | Details available in Tables H1a through H1h
Fine 1993 | Parallel | 24 ^6^ | Not Reported | MPH-low MPH-high Placebo | Unclear | 8 | 2 | Data on adverse effects available | Details available in Tables H1a through H1h
Fitzpatrick 1992 | Crossover | 19 ^6^ | ADD DSM-I-III | MPH-low MPH-med MPH-high-SR Placebo | 2 | 13 | 2 | Core/Global Symptoms Conduct/Oppositional Disorders Depression | NS NS NS
Gadow 1995 | Crossover | 34 ^6^ | ADHD DSM- IIIR/IV | MPH-low MPH-med MPH-high Placebo | 2 | 16 | 2 | Core/Global Symptoms | MPH > Placebo
Garfinkel 1981 | Crossover | 6 | ADD DSM-I-III | Caffeine - low Caffeine - high Caffeine - low + MPH Caffeine - high + MPH Placebo Placebo + MPH | 1,2,3 | 15 | 2 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity Conduct/Oppositional Disorders | MPH vs. MPH + caffeine (308.6mg) = NS; MPH + Caffeine (158.6) > Placebo, Placebo + MPH, Caffeine (158.6), Caffeine (308.6), Caffeine (308.6) + MPH; MPH vs. MPH + caffeine (308.6mg) = NS; MPH + Caffeine (158.6) > Placebo, Placebo + MPH, Caffeine (158.6), Caffeine (308.6), Caffeine (308.6) + MPH; MPH vs. MPH + caffeine (308.6mg) = NS; MPH + Caffeine (158.6) > Placebo, Placebo + MPH, Caffeine (158.6), Caffeine (308.6), Caffeine (308.6) + MPH
Gillberg 1997 | Parallel | 62 | ADHD DSM-IIIR/IV | DEX Placebo | 52 | 15 | 2 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity Academic Conduct/Oppositional Disorders Depression | DEX > Placebo DEX > Placebo NS DEX > Placebo NS
Greenberg 1972 | Parallel | 60 ^6^ | Hyperkinetic Syndrome | DEX Hydroxyzine Chlorpromazine Placebo | 8 | 12 | 2 | Data on adverse effects only | Details available in Tables H1a through H1h
Greenhill 1973 | Crossover | 9 | Other | DEX Lithium carbonate Placebo | 12 | 12 | 2 | Data on adverse effects only | Details available in Tables H1a through H1h
Gross 1976 | Crossover | 50 | MBD | MPH DEX R-Amph Placebo | 1 | 7 | 2 | Inattention/Hyperactivity/Impulsivity | Data not presented in a manner compatible with extraction
Handen 1991 | Crossover | 27 | ADHD DSM-IIIR/IV | MPH-low MPH-high Placebo | 2 | 14 | 2 | Data on adverse effects only | Details available in Tables H1a through H1h
Hinshaw 1984 | Crossover | 24 | ADHD DSM-IIIR/IV | MPH + CT MPH + AC Placebo + CT Placebo + AC | 1,5 | 18 | 2 | Academic | NS except for CT, MPH + CT, MPH + AC > AC
Kauffman 1981 | Crossover | 12 ^6^ | Other | MPH DEX Placebo | 6 | 13 | 3 | Data on adverse effects only | Details available in Tables H1a through H1h
Klorman 1987 | Crossover | 19 | ADD DSM-I-III | MPH Placebo | 3 | 17 | 2 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity | MPH > Placebo MPH > Placebo
Klorman 1990 | Crossover | 48 | ADD DSM-I-III | MPH Placebo | 3 | 17 | 2 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity | MPH > Placebo MPH > Placebo
Kupietz 1988 | Parallel | 58 | ADD DSM-I-III | MPH-low MPH-med MPH-high Placebo | 28 | 16 | 3 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity Academic Conduct/Oppositional Disorders | MPH > Placebo MPH 0.7 > Placebo; MPH 0.3, 0.5 vs. Placebo = NS MPH > Placebo
Mattes 1984 | Crossover | 66 | ADD DSM I-III | MPH Placebo | 3 | 14 | 2 | Core/Global Symptoms | Data not presented in a manner compatible with extraction
Pelham 1987 | Crossover | 13 ^6^ | ADD DSM-I-III | MPH-reg MPH-SR Placebo | 5 | 11 | 2 | Core/Global Symptoms Conduct/Oppositional Disorders | NS NS
Pelham 1990 | Crossover | 22 ^6^ | ADHD DSM-IIIR/IV | MPH-reg MPH-SR DEX-SR Pemoline Placebo | 1 | 11 | 2 | Core/Global Symptoms Conduct/Oppositional Disorders Depression | NR NR NS
Pelham 1993 | Crossover | 31 | ADHD DSM-IIIR/IV | Placebo BC/Mod Low MPH + BC/Mod Low MPH High MPH + BC/Mod High MPH | Unclear | 15 | 3 | Inattention/Hyperactivity/Impulsivity | Effect of BC/Mod added to MPH was not significant for any of the dependent measures
Rapport 1993 | Crossover | 16 | ADHD DSM-IIIR/IV | MPH Desipramine MPH + Desipramine Placebo | 1 | 17 | 3 | Data on adverse effects only | Details available in Tables H1a through H1h
Reimherr 1984 | Crossover | 36 | ADD DSM-I-III | MPH Placebo | 2 | 12 | 2 | Core/Global Symptoms | Data not presented in a manner compatible with extraction
Schachar 1997 | Parallel | 91 | ADHD DSM- IIIR/IV | MPH Placebo | 16 | 17 | 4 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity Conduct/Oppositional Disorders | NS for parent; MPH > Placebo MPH > Placebo for teachers; NS for parents NS; except MPH > Placebo ODD and aggressiveness teachers
Spencer 1995 | Crossover | 25 | ADHD DSM-IIIR/IV | MPH Placebo | 3 | 19 | 3 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity Depression | MPH > Placebo MPH > Placebo NR
Spring 1976 | Parallel | 58 | Other | MPH+Placebo Placebo+ MPH Imipramine + Placebo Placebo + Imipramine | 3 | 13 | 3 | Inattention/Hyperactivity/Impulsivity | Data not presented in a manner compatible with extraction
Srinivas 1992 | Crossover | 9 | Other | l-MPH d-MPH dl-MPH Placebo | Unclear | 9 | 2 | Inattention/Hyperactivity/Impulsivity | Data not presented in a manner compatible with extraction
Stein 1996 | Crossover | 25 | ADHD DSM-IIIR/IV | MPH-titrate MPH-low MPH-high Placebo | 1 | 17 | 3 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity | MPH high > Placebo MPH high > Placebo, MPH low
Stephens 1984 | Crossover | 36 | ADD DSM-I-III | MPH Pemoline Placebo | 1 | 9 | 2 | Academic | Data not presented in a manner compatible with extraction
Wender 1981 | Parallel | 60 | ADD DSM-I-III | Pemoline Placebo | 6 | 17 | 2 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity | Pemoline > Placebo Pemoline > Placebo
Wender 1985 | Crossover | 37 ^6^ | ADD DSM I-III | MPH Placebo | 2 | 15 | 2 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity Conduct/Oppositional Disorders Depression | MPH > Placebo; except report of NS MPH > Placebo NS NS for BDI and sadness report; MPH > Placebo for POMS depression & anxiety
Werry 1980 | Crossover | 30 | Other | MPH Imipramine Placebo | 4 | 12 | 2 | Core/Global Symptoms Inattention/Hyperactivity/Impulsivity Academic Conduct/Oppositional Disorders Depression | Imipramine > MPH parent report of Imipramine > MPH NS Imipramine > MPH for parent; NS for teacher NS
Winsberg 1974 | Crossover | 20 | Other | MPH DEX Placebo | 1 | 12 | 2 | Inattention/Hyperactivity/Impulsivity | Data not presented in a manner compatible with extraction

1 These are clinically relevant elements extracted from the studies that are not supported by empirical methodological research.

2 Data on adverse effects are included in the Adverse Effects Table only (Evidence Tables H1a-H1h).

3 Results are based on various reports, not all of which give usable data or outcomes. Specific outcomes in each category are given in Evidence Tables B4--B6.

4 Results given are for drug-to-drug comparisons, NOT baseline/placebo comparisons.

5 Outcomes regarded, a priori, as not of interest by expert panel are not included in this table but are discussed in the text if clinically significant.

6 Number of randomized subjects not reported; number of subjects analyzed is given in table.

Abbreviations used: AC-attention control; ADD-attention-deficit disorder; ADHD-attention-deficit/hyperactivity disorder; BC/Mod-behavioral contingencies/modification; BDI-Beck's depression inventory; CBT-cognitive behavioral therapy; CDRS-Children's Depression Rating Scale; CT-child training; Des-desipramine; DEX-dextroamphetamine; DSM-Diagnostic and Statistical Manual of Mental Disorders; L-amph-l-amphetamine; MBD-minimal brain dysfunction; MPH or MPH-reg-methylphenidate; MPH-SR-sustained-release methylphenidate; POMS-Profile of mood states; PT-parent training; SSERS-Stimulant Side Effects Rating Scale; ST-supportive therapy; STESS-Subject.s Treatment Emergent Symptom Scale; THIOR-thioridazine; > = better than; NS-not significant; NR-statistical significance not reported.

Evidence Table I2. Total Number of Characteristics Checked for Studies Involving MPH vs. Placebo^1^

Author | # Subjects Eligible (Q14) ^2^ | # Subjects Randomized (Q15) ^2^ | # Subjects Analyzed (Q!7) ^2^ | Ethnic Groups Considered (Q18) ^2^ | Treatment Setting (Q19) ^2^ | Inclusion Criteria Reported (Q21) ^2^ | Exclusion Criteria Reported (Q22) ^2^ | Primary Outcome Stated (Q23) ^2^ | Age Categories of Subjects (Q24) ^2^ | Gender of Subjects (Q25) ^2^ | IQ Considered in Selection Of Subjects (Q26) ^2^ | Diagnosis Model Used (Q28) ^2^ | Comorbid Disorders Considered (Q29a) ^2^ | Comorbid Disorders In Population (Q29b) ^2^ | Who Diagnosed Subjects (Q30) ^2^ | Sample Origin (Q31) ^2^ | Family Characteristics Mentioned (Q32) ^2^ | Fidelity & Monitoring of Treatment (Q34) ^2^ | Compliance with Treatment Measured (Q35) ^2^ | Baseline Test Scores Presented (Q36) ^2^ | Total Count (20) ^2^
Ahmann 1993 | 1 | 0 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 0 | 0 | 13
Arnold 1976 | 1 | 1 | 1 | 0 | 1 | 1 | 0 | 0 | 1 | 1 | 0 | 1 | 0 | 0 | 1 | 1 | 0 | 0 | 0 | 1 | 11
Arnold 1978 | 1 | 0 | 1 | 0 | 1 | 1 | 0 | 0 | 1 | 1 | 0 | 1 | 0 | 0 | 1 | 1 | 0 | 0 | 0 | 1 | 10
Arnold 1989 | 0 | 0 | 1 | 0 | 0 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 0 | 0 | 0 | 1 | 10
Barkley 1990 | 0 | 0 | 1 | 0 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 14
Barrickman 1995 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 1 | 16
Borcherding 1989 | 0 | 0 | 1 | 0 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 0 | 0 | 12
Brown 1986 | 0 | 1 | 1 | 0 | 1 | 0 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 14
Buitelaar 1996 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 19
Carlson 1992 | 0 | 1 | 1 | 0 | 1 | 0 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 15
Castellanos 1997 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 0 | 1 | 18
Christensen 1975 | 0 | 1 | 1 | 0 | 1 | 0 | 0 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 0 | 1 | 0 | 1 | 1 | 1 | 12
Conners 1972 | 0 | 1 | 1 | 1 | 1 | 0 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 1 | 15
Conners 1980 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 0 | 1 | 1 | 17
Conners 1996 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 0 | 1 | 14
Deveaugh-Geiss 1980 | 1 | 1 | 1 | 0 | 1 | 0 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 0 | 0 | 12
Elia 1991 | 0 | 0 | 1 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 0 | 1 | 13
Ernst 1996 | 1 | 0 | 1 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 15
Evans 1994 | 1 | 1 | 1 | 0 | 1 | 0 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 14
Fine 1993 | 0 | 0 | 1 | 0 | 1 | 0 | 0 | 1 | 1 | 1 | 0 | 1 | 0 | 0 | 1 | 1 | 0 | 0 | 0 | 0 | 8
Fitzpatrick 1992 | 0 | 0 | 1 | 0 | 1 | 0 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 13
Gadow 1995 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 16
Garfinkel 1981 | 0 | 1 | 1 | 0 | 1 | 1 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 15
Gillberg 1997 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 0 | 1 | 15
Greenberg 1972 | 0 | 0 | 1 | 1 | 1 | 0 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 0 | 1 | 12
Greenhill 1973 | 0 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 0 | 0 | 1 | 1 | 0 | 0 | 12
Gross 1976 | 0 | 1 | 1 | 0 | 1 | 0 | 0 | 0 | 1 | 1 | 0 | 1 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 7
Handen 1991 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 0 | 1 | 0 | 14
Hinshaw 1984 | 1 | 1 | 0 | 0 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 0 | 15
Kauffman 1981 | 0 | 0 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 0 | 0 | 1 | 0 | 13
Klorman 1987 | 0 | 1 | 1 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 16
Klorman 1990 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 17
Kupietz 1988 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 1 | 1 | 16
Mattes 1984 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 0 | 0 | 14
Pelham 1987 | 0 | 0 | 1 | 0 | 1 | 0 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 0 | 1 | 11
Pelham 1990 | 0 | 0 | 1 | 0 | 1 | 0 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 0 | 1 | 11
Pelham 1993 | 0 | 1 | 1 | 1 | 1 | 0 | 1 | 0 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 15
Rapport 1993 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 17
Reimherr 1984 | 0 | 1 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 0 | 0 | 12
Schachar 1997 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 17
Spencer 1995 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 19
Spring 1976 | 0 | 1 | 1 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 0 | 13
Srinivas 1992 | 1 | 1 | 1 | 0 | 1 | 0 | 0 | 0 | 1 | 1 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 1 | 1 | 0 | 9
Stein 1996 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 17
Stephens 1984 | 0 | 1 | 1 | 0 | 1 | 0 | 0 | 1 | 1 | 1 | 0 | 1 | 0 | 0 | 1 | 1 | 0 | 0 | 0 | 0 | 9
Wender 1981 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 1 | 17
Wender 1985 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 1 | 15
Werry 1980 | 0 | 1 | 1 | 0 | 1 | 1 | 0 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 0 | 0 | 1 | 0 | 12
Winsberg 1974 | 0 | 1 | 1 | 0 | 1 | 1 | 0 | 0 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 0 | 1 | 0 | 0 | 12

1 0 = absent; 1 = present

2 Q numbers given in brackets are the question number from the data extraction form (Appendix E).

Evidence Table I3. Description of Characteristics Checked for Studies Involving MPH vs. Placebo

Author | # Subjects Eligible (Q14) ^1^ | # Subjects Randomized (Q15) ^1^ | # Subjects Analyzed (Q!7) ^1^ | Ethnic Groups Considered (Q18) ^1^ | Treatment Setting (Q19) ^1^ | Inclusion Criteria Reported (Q21) ^1^ | Exclusion Criteria Reported (Q22) ^1^ | Primary Outcome Stated (Q23) ^1^ | Age Categories of Subjects (Q24) ^1^ | Gender of Subjects (Q25) ^1^ | IQ Considered in Selection Of Subjects (Q26) ^1^ | Diagnosis Model Used (Q28) ^1^ | Comorbid Disorders Considered (Q29a) ^1^ | Comorbid Disorders in Population (Q29b) ^1^ | Who Diagnosed Subjects (Q30) ^1^ | Sample Origin (Q31) ^1^ | Family Characteristics Mentioned (Q32) ^1^ | Fidelity & Monitoring of Treatment Mentioned (Q34) ^1^ | Compliance with Treatment Measured (Q35) ^1^ | Baseline Test Scores Presented (Q36) ^1^ | Total Count (20) ^1^
Ahmann 1993 | 234 | NR | 206 | No | MHOP | Yes | Yes | Yes | 5-12 yr 13-18 yr | Male Female | No | ADHD | Yes | NP | Clin | MHOP | No | No | No | No | 13
Arnold 1976 | 31 | 31 | 31 | No | MHOP | Yes | No | No | <5 yr 5-12 yr | Male Female | No | MBD | No | NM | Clin | MHOP | No | No | No | Yes | 11
Arnold 1978 | 31 | NR | 29 | No | MHOP Home | Yes | No | No | 5-12 yr | Male Female | No | MBD | No | NM | Clin | MHOP | No | No | No | Yes | 10
Arnold 1989 | NR | NR | 18 | No | NR | Yes | No | Yes | 5-12 yr | Male | Yes NM | ADD | Yes | NP | NR | NR | No | No | No | Yes | 10
Barkley 1990 | NR | NR | 83 | No | MHOP | Yes | No | Yes | 5-12 yr 13-18 yr | Male Female | Yes> 80 | NR | Yes | NP | Clin | MHOP | Yes | No | Yes | Yes | 14
Barrickman 1995 | NR | 18 | 15 | White | MHOP | Yes | Yes | No | 5-12 yr 13-18 yr | Male Female | Yes >70 | ADHD | Yes | ODD CD, LD | Clin | MHOP | Yes | No | No | Yes | 16
Borcherding 1989 | NR | NR | 18 | No | MHOP | Yes | No | Yes | 5-12 yr | Male | Yes >80 | ADD | Yes | ODD CD, AD | Clin Teach | PCOP School | No | No | No | No | 12
Brown 1986 | NR | 40 | 35 | No | MHOP | No | No | No | 5-12 yr 13-18 yr | Male Female | Yes NM | ADD | Yes | CD | Clin | PCOP School | No | Yes | Yes | Yes | 14
Buitelaar 1996 | 55 | 32 | 32 | No | MHOP | Yes | Yes | Yes | 5-12 yr 13-18 yr | Male Female | Yes NM | ADHD | Yes | ODD CD, AD | Clin Parent | MHOP | Yes | Yes | Yes | Yes | 19
Carlson 1992 | NR | 24 | 24 | No | School | No | Yes | No | 5-12 yr | Male | Yes NM | ADHD | Yes | ODD CD, LD | Clin | MHOP | No | Yes | Yes | Yes | 15
Castellanos 1997 | 38 | 22 | 20 | White Afro Hispanic Asian | MHOP | Yes | Yes | Yes | 5-12 yr | Male | Yes >75 | ADHD | Yes | ODD CD Touret | Clin | MHOP Com School PCOP | No | Yes | No | Yes | 18
Christensen 1975 | NR | 16 | 13 | No | School | No | No | No | 5-12 yr 13-18 yr | Male Female | Yes <70 | NR | Yes | MRIQ | Unclear | School | No | Yes | Yes | Yes | 12
Conners 1972 | NR | 84 | 81 | White Afro | HoOP | No | Yes | No | 5-12 yr | Male Female | Yes >80 | MBD | Yes | NP | Clin | MHOP PCOP Com School | Yes | No | No | Yes | 15
Conners 1980 | 60 | 60 | 60 | White Afro | MHOP Home | Yes | Yes | No | 5-12 yr | Male Female | Yes >80 | MBD | Yes | NP | Clin | NR | Yes | No | Yes | Yes | 17
Conners 1996 | 22 | 18 | 17 | No | HoOP | Yes | Yes | No | >18 yr | Male Female | No | ADHD | Yes | NP | Clin | PCOP Com | No | No | No | Yes | 14
Deveaugh-Geiss1980 | 1 | 1 | 1 | No | HoOP | Unclear | No | No | >18 yr | Male | Yes 80 | HySy | Yes | NP | Clin | HoOP | No | No | No | No | 12
Elia 1991 | NR | NR | 48 | No | MHOP | Yes | Yes | No | 5-12 yr | Male | Yes> 80 | ADD | Yes | ODD CD, AD | Clin | PCOP School | No | No | No | Yes | 13
Ernst 1996 | 44 | Unclear | 24 | No | MHOP | Yes | Yes | No | >18 yr | Male Female | No | ADHD | Yes | NP | Clin | Com | Yes | No | Yes | Yes | 15
Evans 1994 | 1 | 1 | 1 | No | MHOP | Unclear | Unclear | Yes | >18 yr | Female | No | ADHD | Yes | NP | Clin | HoOP MHOP | Yes | Yes | No | No | 14
Fine 1993 | NR | NR | 24 | No | MHOP | No | No | Yes | 5-12 yr | Male Female | No | ADHD | No | NM | Clin | MHOP PCOP School | No | No | No | No | 8
Fitzpatrick 1992 | NR | NR | 19 | No | MHOP Home | No | No | No | 5-12 yr | Male Female | Yes NM | ADD | Yes | ODD CD | Clin Teach | PC | Yes | No | Yes | Yes | 13
Gadow 1995 | NR | NR | 34 | White Afro Hispanic Asian | MHOP | Yes | Yes | No | 5-12 yr | Male | Yes >70 | ADHD | Yes | ODD CD, AD Tourette | Clin Parent Teach | MHOP | Yes | No | Yes | Yes | 16
Garfinkel 1981 | NR | 6 | 6 | No | MHOP | Yes | No | No | 5-12 yr | Male | Yes >90 | ADD | Yes | NP | Clin | MHOP | No | Yes | Yes | Yes | 15
Gillberg 1997 | 72 | 62 | 32 | No | MHOP | Yes | Yes | No | 5-12 yr | Male Female | Yes> 50 | ADHD | Yes | ODD CD, AD Tourette MRIQ Autism | Clin | MHOP | No | No | No | Yes | 15
Greenberg 1972 | NR | NR | 61 | Afro | HoOP | No | No | No | 5-12 yr | Male | Yes NM | HySy | Yes | NP | Clin | PCOP School | No | No | No | Yes | 12
Greenhill 1973 | NR | 9 | 9 | White | HoOP HoIP Home School | Yes | No | No | 5-12 yr 13-18 yr | Male Female | Yes NM | NR | Yes | NP | NR | NR | Yes | Yes | No | No | 12
Gross 1976 | NR | 50 | 48 | No | MHOP | No | No | No | <5 yr 5-12 yr 13-18 yr | Male Female | No | MBD | No | NM | Clin | NR | No | No | No | No | 7
Handen 1991 | NR | 27 | 27 | White Afro | MHOP | Yes | Yes | No | 5-12 yr | Male Female | Yes <80 | ADHD | Yes | MRIQ | Clin | NR | No | No | Yes | No | 14
Hinshaw 1984 | 24 | 24 | Unclear | No | School | Yes | No | Yes | 5-12 yr 13-18 yr | Male | Yes NM | ADHD | Yes | NP | Clin | MHOP PCOP Com School | On | Yes | Yes | No | 15
Kauffman 1981 | NR | NR | 12 | White | PCOP | Yes | No | Yes | 5-12 yr | Male | Yes NM | InMe | Yes | NP | Clin | MHOP CoPh | No | No | Yes | No | 13
Klorman 1987 | NR | 19 | 19 | No | MHOP Home | Yes | Yes | No | 5-12 yr 13-18 yr | Male Female | Yes >74 | ADD | Yes | NP | Clin | MHOP | Yes | No | Yes | Yes | 16
Klorman 1990 | NR | 48 | 48 | White | MHOP Home School | Yes | Yes | No | 5-12 yr 13-18 yr | Male Female | Yes >80 | ADD | Yes | ODD CD AD | Clin | MHOP | Yes | No | Yes | Yes | 17
Kupietz 1988 | 58 | 58 | 47 | No | MHOP | Yes | Yes | No | 5-12 yr 13-18 yr | Male Female | Yes >80 | ADD | Yes | NP | Clin Teach | HoOP Com School | No | No | Yes | Yes | 16
Mattes 1984 | 116 | 66 | 61 | No | MHOP | Yes | Yes | No | >18 yr | Male Female | Yes NM | ADD | Yes | AD | Clin | MHOP Com | No | No | No | No | 14
Pelham 1987 | NR | NR | 13 | No | MHOP Home | No | No | No | 5-12 yr | Male | Yes NM | ADD | Yes | ODD CD, LD | Clin | MHOP | No | No | No | Yes | 11
Pelham 1990 | NR | NR | 22 | No | MHOP | No | No | No | 5-12 yr 13-18 yr | Male | Yes NM | ADHD | Yes | ODD CD, LD | Clin | MHOP | No | No | No | Yes | 11
Pelham 1993 | NR | 31 | 31 | White Afro | MHOP School | No | Yes | No | 5-12 yr | Male | Yes NM | ADHD | Yes | ODD CD, LD | Clin | MHOP | No | Yes | Yes | Yes | 15
Rapport 1993 | 20 | 16 | 16 | White Afro | HoIP | Yes | No | No | 5-12 yr | Male | Yes >80 | ADHD | Yes | ODD CD, AD DD, LD | Clin | HoIP | Yes | Yes | Yes | No | 17
Reimherr 1984 | NR | 36 | NR | No | HoOP | Yes | Yes | Yes | >18 yr | Male Female | No | ADD | Yes | AD, DD | Clin | MHOP Com | No | No | No | No | 12
Schachar 1997 | 105 | 91 | 66 | No | HoOP | Yes | Yes | No | 5-12 yr | Male Female | Yes >80 | ADHD | Yes | ODD CD,AD | Clin | HoOP | No | Yes | Yes | Yes | 17
Spencer 1995 | 25 | 25 | 23 | White | HoOP | Yes | Yes | Yes | >18 yr | Male Female | Yes >75 | ADHD | Yes | AD,CD DD | Clin | HoOP | Yes | No | Yes | Yes | 19
Spring 1976 | NR | 58 | 47 | No | MHOP | Yes | Yes | No | 5-12 yr | Male Female | Yes NM | InMe | Yes | NP | Clin Parent Teach | PCOP | Yes | No | No | No | 13
Srinivas 1992 | 9 | 9 | 9 | No | HoOP | No | No | No | 5-12 yr | Male | NR | NR | No | NM | NR | HoOP | No | Yes | Yes | No | 9
Stein 1996 | NR | 25 | 25 | White Hispanic | HoOP | Yes | Yes | No | 5-12 yr | Male | Yes NM | ADHD | Yes | ODD CD | Clin | MHOP PCOP Com | Yes | No | Yes | Yes | 17
Stephens 1984 | NR | 36 | 36 | No | MHOP | No | No | Yes | 5-12 yr | Male Female | No | ADD | No | NM | Clin | MHOP PCOP | No | No | No | No | 9
Wender 1981 | 60 | 60 | 26 | White | MHOP | Yes | Yes | No | >18 yr | Male Female | Yes >90 | ADD | Yes | AD | Clin | HoOP MHOP PCOP | Yes | No | No | Yes | 17
Wender 1985 | NR | NR | 37 | White | MHOP | Yes | Yes | No | >18 yr | Male Female | Yes >90 | ADD | Yes | AD | Clin | MHOP PCOP Com | Yes | No | No | Yes | 15
Werry 1980 | NR | 30 | 30 | No | HoOP Home | Yes | No | No | 5-12 yr | Male Female | Yes NM | InMe | Yes | NP | Clin | HoOP School | No | No | Yes | No | 12
Winsberg 1974 | NR | 20 | 18 | No | HoIP | Yes | No | No | 5-12 yr | Male Female | Yes NM | InMe | Yes | NP | Clin | HoOP HoIP | No | Yes | No | No | 12

1 Q numbers given in brackets are the question number from the data extraction form (Appendix E).

Abbreviations: AD-anxiety disorder; ADHD-attention-deficit/hyperactivity disorder (DSM-IIIR-IV); ADD-attention deficit disorder (DSM-I-III); Clin-clinician; Com-community; CoPh-community physicians; DD-depressive disorder; HoIP-hospital inpatient; HoOP-hospital outpatient; HySy-hyperkinetic syndrome; InMe-individual method; LD-learning disorder; MBD-minimal brain dysfunction; MHOP-mental health clinic outpatient; MRIQ-mental retardation/low IQ; NM-none mentioned; NP-none present; NR-not reported; PC-pediatric clinic; PCOP-pediatric clinic outpatient; Teach-teacher; TeDi-teacher diagnosis; Touret-Tourette's; ADHD-ADHD Activity Scale.