# Bibliography

Aarskog D, Fevang FO, Klove H, Stoa KF, Thorsen T. The effect of the stimulant drugs, dextroamphetamine and methylphenidate, on secretion of growth hormone in hyperactive children. J Pediatr. 1977;90(1):136-9. [pmid: 318680].
Abikoff H, Gittelman R. Hyperactive children treated with stimulants. Is cognitive training a useful adjunct?. Arch Gen Psychiatry. 1985;42(10):953-61. [pmid: 2864027].
Abramowitz AJ, Eckstrand D, O'Leary SG, Dulcan MK. ADHD children's responses to stimulant medication and two intensities of a behavioral intervention. Behav Modif. 1992;16(2):193-203. [pmid: 1580893].
Adler LA, Resnick S, Kunz M, Devinsky O. Open-label trial of venlafaxine in adults with attention deficit disorder. Psychopharmacol Bull. 1995;31(4):785-8. [pmid: 8851654].
Ahmann PA, Waltonen SJ, Olson KA, Theye FW, Van Erem AJ, LaPlant RJ. Placebo-controlled evaluation of Ritalin side effects. Pediatrics. 1993 Jun;91(6):1101-6. [pmcid: 375534].
Ajibola O, Clement PW. Differential effects of methylphenidate and self-reinforcement on attention-deficit hyperactivity disorder. Behav Modif. 1995;19(2):211-33. [pmid: 7726818].
Alessandri SM, Schramm K. Effects of dextroamphetamine on the cognitive and social play of a preschooler with ADHD. J Am Acad Child Adolesc Psychiatry. 1991;30(5):768-72. [pmid: 1938792].
Alexandris A, Lundell FW. Effect of thioridazine, amphetamine and placebo on the hyperkinetic syndrome and cognitive area in mentally deficient children. Can Med Assoc J. 1968;98(2):92-6. [pmid: 4864657].
Alston CY, Romney DM. A comparison of medicated and nonmedicated attention-deficit disordered hyperactive boys. Acta Paedopsychiatr. 1992;55(2):65-70. [pmid: 1585804].
Aman MG, Turbott SH. Prediction of clinical response in children taking methylphenidate. J Autism Dev Disord. 1991;21(2):211-28. [pmid: 1864828].
Aman MG, Werry JS. The effects of methylphenidate and haloperidol on the heart rate and blood pressure of hyperactive children with special reference to time of action. Psychopharmacologia. 1975;43(2):163-8. [pmid: 1103207].
Aman MG, Mitchell EA, Turbott SH. The effects of essential fatty acid supplementation by Efamol in hyperactive children. J Abnorm Child Psychol. 1987;15(1):75-90. [pmid: 3553274].
Aman MG, Kern RA, McGhee DE, Arnold LE. Fenfluramine and methylphenidate in children with mental retardation and ADHD: Clinical and side effects. J Am Acad Child Adolesc Psychiatry. 1993;32(4):851-9. [pmid: 8340309].
Aman MG, Kern RA, McGhee DE, Arnold LE. Fenfluramine and methylphenidate in children with mental retardation and attention deficit hyperactivity disorder: Laboratory effects. J Autism Dev Disord. 1993;23(3):491-506. [pmid: 8226583].
Aman MG, Marks RE, Turbott SH, Wilsher CP, Merry SN. Clinical effects of methylphenidate and thioridazine in intellectually subaverage children. J Am Acad Child Adolesc Psychiatry. 1991;30(2):246-56. [pmid: 2016229].
Aman MG, Pejeau C, Osborne P, Rojahn J, Handen B. Four-year follow-up of children with low intelligence and ADHD. Res Dev Disabil. 1996;17(6):417-32. [pmid: 8946568].
Dulcan M. Practice parameters for the assessment and treatment of children, adolescents and adults with attention-deficit/hyperactivity disorder. American Academy of Child and Adolescent Psychiatry. J Am Acad Child Adolesc Psychiatry. 1997a;36(Suppl 10):85S-121S.
Dulcan MK, Benson RS. AACAP Official Action .Summary of Practice Parameters for the assessment and treatment of children, adolescents and adults with ADHD. J Am Acad Child Adolesc Psychiatry. 1997b;36:1311-1317. [pmid: 9291734].
American Psychiatric Association. Diagnostic and statistical manual of mental disorders. 4^th^ed.. Washington, D.C.: American Psychiatric Association; 1994.
Anastopoulos AD, Guevremont DC, Shelton TL, DuPaul GJ. Parenting stress among families of children with attention deficit hyperactivity disorder. J Abnorm Child Psychol. 1992;20(5):503-20. [pmid: 1487593].
Anderson EE, Clement PW, Oettinger LJ. Methylphenidate compared with behavioral self-control in attention deficit disorder: preliminary report. J Dev Behav Pediatr. 1981;2(4):137-41. [pmid: 7320203].
Anonymous. Clonidine for treatment of attention-deficit/hyperactivity disorder. Med Lett Drugs Ther. 1996;38(989):109-10. [pmid: 8957471].
Anonymous. Pharmacotherapy facilitates management of psychiatric disorders in children and adolescents. Drugs Ther Perspect. 1996;8(7):9-12.
Anonymous. [Drug therapy in attention deficit disorders with hyperactivity in children] (Ger). Geneesmiddelen Bull. 1996;30(2):16-20.
Anonymous. Methylphenidate. Prescrire Int. 1997;6(31):126-30.
Arnold LE. Some nontraditional (unconventional and/or innovative) psychosocial treatments for children and adolescents: Critique and proposed screening principles. J Abnorm Child Psychol. 1995;23(1):125-40. [pmid: 7759671].
Arnold LE, Abikoff HB, Cantwell DP, Conners CK, Elliott G, Greenhill LL, Hecthman L, Hinshaw SP, Hoza B, Jensen PS, Kraemer HC, March JS, Newcorn JH, Pelham WE, Richters JE, Schiller E, Severe JB, Swanson JM, Vereen D, Wells KC, for the MTA. National Institute of Mental Health Collaborative Multimodal Treatment Study of Children With ADHD (the MTA): Design Challenges and Choices. Arch Gen Psychiatry. 1997;54:865-870. [pmid: 9294378].
Arnold LE, Christopher J, Huestis R, Smeltzer DJ. Methylphenidate vs dextroamphetamine vs caffeine in minimal brain dysfunction: Controlled comparison by placebo washout design with Bayes' analysis. Arch Gen Psychiatry. 1978 Apr;35(4):463-73.
Arnold LE, Clark DL, Sachs LA, Jakim S, Smithies C. Vestibular and visual rotational stimulation as treatment for attention deficit and hyperactivity. Am J Occup Ther. 1985;39(2):84-91. [pmid: 3872075].
Arnold LE, Huestis RD, Smeltzer DJ, Scheib J, Wemmer D, Colner G. Levoamphetamine vs dextroamphetamine in minimal brain dysfunction. Replication, time response, and differential effect by diagnostic group and family rating. Arch Gen Psychiatry. 1976 Mar;33(3):292-301.
Arnold LE, Huestis RD, Wemmer D, Smeltzer DJ. Differential effect of amphetamine optical isomers on Bender Gestalt performance of the minimally brain dysfunctioned. J Learn Disabil. 1978;11(3):127-32. [pmid: 353207].
Arnold LE, Kirilcuk V, Corson SA, Corson EO. Levoamphetamine and dextroamphetamine: Differential effect on aggression and hyperkinesis in children and dogs. Am J Psychiatry. 1973;130(2):165-70. [pmid: 4568123].
Arnold LE, Kleykamp D, Votolato NA, Taylor WA, Kontras SB, Tobin K. Gamma-linolenic acid for attention-deficit hyperactivity disorder: Placebo-controlled comparison to d-amphetamine. Biol Psychiatry. 1989;25:222-8. [pmid: 2539203].
Arnold LE, Wender PH, McCloskey K, Snyder SH Levamphetamine and dextroamphetamine: Comparative efficacy in the hyperkinetic syndrome. Assessment by target symptoms Arch Gen Psychiatry 1972 27(6) 816 22View this and related citations using 4564954
Arzumanian AM, Stupa MV. [Therapeutic principles in hyperkinetic syndromes]. (Rus). Zh Nevropatol Psikhiatr. 1994;94(5):32-5. [pmcid: 204872].
Baker BA. ADHD-RT and low-dose lithium: A review article and pilot study. J Neurol Orthop Med Surg. 1995;16(1):19-27.
Ballard JE, Boileau RA, Sleator EK, Massey BH, Sprague RL. Cardiovascular responses of hyperactive children to methylphenidate. JAMA. 1976;236(25):2870-4. [pmid: 792490].
Balthazor MJ, Wagner RK, Pelham WE. The specificity of the effects of stimulant medication on classroom learning-related measures of cognitive processing for attention deficit disorder children. J Abnorm Child Psychol. 1991;19(1):35-52. [pmid: 2030246].
Barber MA, Milich R, Welsh R. Effects of reinforcement schedule and task difficulty on the performance of attention deficit hyperactivity disordered and control boys. J Clin Child Psychol. 1996;25(1):66-76.
Barkley RA. Hyperactive girls and boys: stimulant drug effects on mother-child interactions [published erratum appears in J Child Psychol Psychiatry 1993 Mar;34(3):437]. J Child Psychol Psychiatry. 1989;30(3):379-90. [pmid: 2663900].
Barkley, RA. Attention-deficit/hyperactivity disorder. In: Mash EJ and Barkley RA, editors. Child psychopathology. New York: Guildford; 1996. p. 63-112.
Barkley RA, Cunningham CE. The effects of methylphenidate on the mother-child interactions of hyperactive children. Arch Gen Psychiatry. 1979;36(2):201-8. [pmid: 369470].
Barkley RA, DuPaul GJ, McMurray MB. Attention deficit disorder with and without hyperactivity: Clinical response to three dose levels of methylphenidate. Pediatrics. 1991;87(4):519-31. [pmid: 2011430].
Barkley RA, Anastopoulos AD, Guevremont DC, Fletcher KE. Adolescents with attention deficit hyperactivity disorder: Mother-adolescent interactions, family beliefs and conflicts, and maternal psychopathology. J Abnorm Child Psychol. 1992;20(3):263-88. [pmid: 1619134].
Barkley RA, Guevremont DC, Anastopoulos AD, Fletcher KE. A comparison of three family therapy programs for treating family conflicts in adolescents with attention-deficit hyperactivity disorder. J Consult Clin Psychol. 1992;60(3):450-62. [pmid: 1619099].
Barkley RA, Karlsson J, Pollard S, Murphy JV. Developmental changes in the mother-child interactions of hyperactive boys: Effects of two dose levels of Ritalin. J Child Psychol Psychiatry. 1985;26(5):705-15. [pmid: 3900116].
Barkley RA, Koplowitz S, Anderson T, McMurray MB. Sense of time in children with ADHD: Effects of duration, distraction, and stimulant medication. J Int Neuropsychol Soc. 1997;3(4):359-69. [pmid: 9260445].
Barkley RA, McMurray MB, Edelbrock CS, Robbins K. The response of aggressive and nonaggressive ADHD children to two doses of methylphenidate. J Am Acad Child Adolesc Psychiatry. 1989;28(6):873-81. [pmid: 2808257].
Barkley RA, McMurray MB, Edelbrock CS, Robbins K. Side effects of methylphenidate in children with attention deficit hyperactivity disorder: A systemic, placebo-controlled evaluation. Pediatrics. 1990;Aug;86(2):184-92.
Barrickman LL, Perry PJ, Allen AJ, Kuperman S, Arndt SV, Herrmann KJ, Schumacher E. Bupropion versus methylphenidate in the treatment of attention-deficit hyperactivity disorder. J Am Acad Child Adolesc Psychiatry. 1995 May;34(5):649-57.
Beal D, Gillis JS. Methylphenidate hydrochloride and judgmental behavior in hyperkinetic children. Curr Ther Res Clin Exp. 1979;26(6):931-9.
Becker DF, Doane JA, Wexler BE. Effects of emotion on perceptual asymmetry in adolescent inpatients with attention-deficit hyperactivity disorder. J Am Acad Child Adolesc Psychiatry. 1993;32(2):318-21. [pmid: 8444760].
Begg C, Cho M, Eastwood S, Horton R, Moher D, Olkin I, Pitkin R, Rennie D, Schulz KF, Simel D, Stroup DF. Improving the quality of reporting of randomized controlled trials. The CONSORT statement. JAMA. 1996;276(8):637-9. [pmid: 8773637].
Berlin JA. Does blinding of readers affect the results of meta-analyses? University of Pennsylvania meta-analysis blinding study group. Lancet. 1997;350(9072):185-6. [pmid: 9250191].
Berman BM, Ezzo J, Hadhazy VA, Jadad AR, Lao L, Singh B. Penetrating the methodological issues in randomized controlled trials of acupuncture and chronic pain: A systematic review. Forthcoming.
Bero LA, Rennie D. Influences on the quality of published drug trials. Int J Technol Assess Health Care. 1996;12:209-37. [pmid: 8707496].
Biederman J, Faraone SV, Keenan K. Further evidence for family-genetic risk factors in attention deficit hyperactivity disorder. Arch Gen Psychiatry. 1992;49:728-38. [pmid: 1514878].
Biederman J, Baldessarini RJ, Wright V, Knee D, Harmatz JS, Goldblatt A. A double-blind placebo controlled study of desipramine in the treatment ADD: II. Serum drug levels and cardiovascular findings. J Am Acad Child Adolesc Psychiatry. 1989a Nov;28(6):903-11.
Biederman J, Baldessarini RJ, Wright V, Knee D, Harmatz JS. A double-blind placebo controlled study of desipramine in the treatment of ADD: I. Efficacy. J Am Acad Child Adolesc Psychiatry. 1989b Sep;28(5):777-84.
Biederman J, Baldessarini RJ, Wright V, Keenan K, Faraone S. A double-blind placebo controlled study of desipramine in the treatment of ADD: III. Lack of impact of comorbidity and family history factors on clinical response. J Am Acad Child Adolesc Psychiatry. 1993 Jan;32(1):199-204.
Biederman J, Milberger S, Faraone S, Kiely K, Guite J, Mick E, Ablon S, Warburton R, Reed E. Family-environment risk factors for attention-deficit hyperactivity disorder. Arch Gen Psychiatry. 1995;52:464-70. [pmid: 7771916].
Birmaher B, Greenhill LL, Cooper TB, Fried J, Maminski B. Sustained release methylphenidate: Pharmacokinetic studies in ADDH males. J Am Acad Child Adolesc Psychiatry. 1989;28(5):768-72. [pmid: 2793805].
Bloomquist ML, August GJ, Ostrander R. Effects of a school-based cognitive-behavioral intervention for ADHD children. J Abnorm Child Psychol. 1991;19(5):591-605. [pmid: 1770187].
Bond WS. Recognition and treatment of attention deficit disorder. [Review] [66 refs]. Clin Pharm. 1987;6(8):617-24. [pmid: 2891464].
Borcherding BG, Keysor CS, Cooper TB, Rapoport JL. Differential effects of methylphenidate and dextroamphetamine on the motor activity level of hyperactive children. Neuropsychopharmacology. 1989 Dec;2(4):255-63.
Borden, KA, Brown, RT. Attributional outcomes: The subtle messages of treatments for attention deficit disorder. Cognitive Ther Res. 1989 Apr;13(2):147-60.
Bowen J, Fenton T, Rappaport L Stimulant medication and attention deficit-hyperactivity disorder. The child's perspective Am J Dis Child 1991 145(3) 291 5View this and related citations using 2003477
Brown CS, Wells BG, Cold JA, Froemming JH, Self TH, Jabbour JT. Possible influence of carbamazepine on plasma imipramine concentrations in children with attention deficit hyperactivity disorder [see comments]. J Clin Psychopharmacol. 1990;10(5):359-62. [pmid: 2258453].
Brown RT. Impulsivity and psychoeducational intervention in hyperactive children. J Learn Disabil. 1980;13(5):249-54. [pmid: 7391686].
Brown RT, Sexson SB. Effects of methylphenidate on cardiovascular responses in attention deficit hyperactivity disordered adolescents. J Adolesc Health Care. 1989;10(3):179-83. [pmid: 2715089].
Brown RT, Sleator EK. Methylphenidate in hyperkinetic children: Differences in dose effects on impulsive behavior. Pediatrics. 1979;64(4):408-11. [pmid: 492804].
Brown RT, Wynne ME, Medenis R. Methylphenidate and cognitive therapy: A comparison of treatment approaches with hyperactive boys. J Abnorm Child Psychol. 1985 Mar;13(1):69-87.
Brown RT, Wynne ME, Slimmer LW. Attention deficit disorder and the effect of methylphenidate on attention, behavioral, and cardiovascular functioning. J Clin Psychiatry. 1984;45(11):473-6. [pmid: 6386794].
Brown RT, Borden KA, Wynne ME, Schleser R, Clingerman SR. Methylphenidate and cognitive therapy with ADD children: A methodological reconsideration. J Abnorm Child Psychol. 1986 Dec;14(4):481-97.
Brown RT, Borden KA, Wynne ME, Spunt AL. Patterns of compliance in a treatment program for children with attention deficit disorder. J Compliance Health Care. 1988;3(1):23-39.
Brown RT, Jaffe SL, Silverstein J, Magee H. Methylphenidate and hospitalized adolescents with conduct disorder: Dose effects on classroom behavior, academic performance, and impulsivity. J Youth Adolesc. 1991;20(5):501-18.
Brown RT, Wynne ME, Borden KA, Clingerman SR, Geniesse R, Spunt AL. Methylphenidate and cognitive therapy in children with attention deficit disorder: A double-blind trial. J Dev Behav Pediatr. 1986;7(3):163-74. [pmid: 3522630].
Buhrmester D, Whalen CK, Henker B, MacDonald V, Hinshaw SP. Prosocial behavior in hyperactive boys: Effects of stimulant medication and comparison with normal boys. J Abnorm Child Psychol. 1992;20(1):103-21. [pmid: 1548391].
Buitelaar JK, van der Gaag RJ, Swaab-Barneveld H, Kuiper M. Prediction of clinical response to methylphenidate in children with attention-deficit hyperactivity disorder. J Am Acad Child Adolesc Psychiatry. 1995;34(8):1025-32. [pmid: 7665441].
Buitelaar JK, van der Gaag RJ, Swaab-Barneveld H, Kuiper M. Pindolol and methylphenidate in children with attention-deficit hyperactivity disorder. Clinical efficacy and side-effects. J Child Psychol Psychiatry. 1996 Jul;37(5):587-95.
Butter HJ, Lapierre YD. The effect of methylphenidate on sensory perception and integration in hyperactive children. Int Pharmacopsychiatry. 1974;9(4):235-44. [pmid: 4616915].
Butter HJ, Lapierre YD. The effect of methylphenidate on cardiovascular sensory differentiation on the hyperkinetic syndrome. Int J Clin Pharmacol Biopharm. 1975;11(4):309-14. [pmid: 1099022].
Butter HJ, Lapierre YD. The effect of methylphenidate on sensory perception in varying degrees of hyperkinetic behaviour. Dis Nervous Syst. 1975;36(6):286-8.
Butter HJ, Lapierre Y, Firestone P, Blank A. A comparative study of the efficacy of ACTH4-9 analog, methylphenidate, and placebo on attention deficit disorder with hyperkinesis. J Clin Psychopharmacol. 1983;3(4):226-30. [pmid: 6309918].
Butter HJ, Lapierre Y, Firestone P, Blank, A. Efficacy of ACTH 4-9 analog, methylphenidate, and placebo on attention deficit disorder with hyperkinesis. Prog Neuropsychopharmacol Biol Psychiatry. 1984;8(4-6):661-4. [pmid: 6099589].
Cadoret RJ, Stewart MA. An adoption study of attention deficity/hyperactivity/aggression and their relationship to adult antisocial personality. Compr Psychiatry. 1991;32:73-82. [pmid: 2001624].
Campbell L, Malone MA, Kershner JR, Roberts W, Humphries T, Logan WJ. Methylphenidate slows right hemisphere processing in children with attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 1996;6(4):229-39. [pmid: 9231316].
Campbell NB, Tamburrino MB, Evans CL, Franco KN. Fluoxetine for ADHD in a young child. J Am Acad Child Adolesc Psychiatry. 1995;34(10):1259-60. [pmid: 7592260].
Carlson CL, Pelham WEJ, Swanson JM, Wagner JL. A divided attention analysis of the effects of methylphenidate on the arithmetic performance of children with attention-deficit hyperactivity disorder. J Child Psychol Psychiatry. 1991;32(3):463-71. [pmid: 2061366].
Carlson CL, Pelham WEJ, Milich R, Dixon J. Single and combined effects of methylphenidate and behavior therapy on the classroom performance of children with attention-deficit hyperactivity disorder. J Abnorm Child Psychol. 1992;20(2):213-32. [pmid: 1593027].
Carlson CL, Pelham WE, Jr, Milich R, Hoza B. ADHD boys' performance and attributions following success and failure: Drug effects and individual differences. Cognitive Ther Res. 1993;17(3):269-87.
Carlson GA, Rapport MD, Kelly KL, Pataki CS. Methylphenidate and desipramine in hospitalized children with comorbid behavior and mood disorders: Separate and combined effects on behavior and mood. J Child Adolesc Psychopharmacol. 1995;5(3):191-204.
Carter CM, Urbanowicz M, Hemsley R, Mantilla L, Strobel S, Graham PJ, Taylor E. Effects of a few food diet in attention deficit disorder. Arch Dis Child. 1993;69(5):564-8. [pmid: 8257176].
Casat CD, Pleasants DZ, Schroeder DH, Parler DW. Bupropion in children with attention deficit disorder. Psychopharmacol Bull. 1989;25(2):198-201. [pmid: 2513592].
Castellanos FX, Giedd JN, Elia J, Marsh WL, Ritchie GF, Hamburger SD, Rapoport JL. Controlled stimulant treatment of ADHD and comorbid Tourette's syndrome: Effects of stimulant and dose. J Am Acad Child Adolesc Psychiatry. 1997 May;36(5):589-96.
Cavanagh R, Clifford JS, Gregory WL. The use of bromocriptine for the treatment of attention deficit disorder in two chemically dependent patients. J Psychoactive Drugs. 1989;21(2):217-20. [pmid: 2668485].
Chabot RJ, Merkin H, Wood LM, Davenport TL, Serfontein G. Sensitivity and specificity of QEEG in children with attention deficit or specific developmental learning disorders. Clin Electroencephalogr. 1996;27(1):26-34. [pmid: 8719499].
Chappell PB, Riddle MA, Scahill L, Lynch KA, Schultz R, Arnsten A, Leckman JF, Cohen DJ. Guanfacine treatment of comorbid attention-deficit hyperactivity disorder and Tourette's syndrome: Preliminary clinical experience. J Am Acad Child Adolesc Psychiatry. 1995;34(9):1140-6. [pmid: 7559307].
Charles L, Schain R. A four-year follow-up study of the effects of methylphenidate on the behavior and academic achievement of hyperactive children. J Abnorm Child Psychol. 1981;9(4):495-505. [pmid: 7328229].
Cho MK, Bero LA. The quality of drug studies published in symposium proceedings. Ann Intern Med. 1996;124:485-9. [pmid: 8602706].
Christensen DE. Effects of combining methylphenidate and a classroom token system in modifying hyperactive behavior. Am J Ment Defic. 1975 Nov;80(3):266-76. [pmid: 1103623].
Claghorn J, Neblett C, Sutter E, Farrell G, Kraft I. The effect of drugs on hyperactivity in children with some observations of changes in mineral metabolism. J Nerv Ment Dis. 1971;153(2):118-25. [pmid: 4941954].
Clay TH, Gualtieri CT, Evans RW, Gullion CM. Clinical and neuropsychological effects of the novel antidepressant bupropion. Psychopharmacol Bull. 1988;24(1):143-8. [pmid: 3133717].
Cohen ML, Kelly PC, Atkinson AW. Parent, teacher, child. A trilateral approach to attention deficit disorder. Am J Dis Child. 1989;143(10):1229-33. [pmid: 2801667].
Cohen NJ, Douglas VI, Morgenstern G. The effect of methylphenidate on attentive behavior and autonomic activity in hyperactive children. Psychopharmacologia. 1971;22(3):282-94. [pmid: 4943560].
Cohen NJ, Sullivan J, Minde K, Novak C, Helwig C. Evaluation of the relative effectiveness of methylphenidate and cognitive behavior modification in the treatment of kindergarten-aged hyperactive children. J Abnorm Child Psychol. 1981;9(1):43-54. [pmid: 7217537].
Cohen P, Cohen J, Kasen S, Velez CN, Hartmark C, Johnson J, Rojas M, Brook J, Streuning EL. An epidemiological study of disorders in late childhood and adolescence. I. Age- and gender-specific prevalence. J Child Psychol Psychiatry. 1993;34:851-67. [pmid: 8408371].
Cohn LM, Caliendo GC. Guanfacine use in children with attention deficit hyperactivity disorder. Ann Pharmacother. 1997;31(7-8):918-9. [pmid: 9220058].
Coleman M, Steinberg G, Tippett J, Bhagavan HN, Coursin DB, Gross M, Lewis C, DeVeau L. A preliminary study of the effect of pyridoxine administration in a subgroup of hyperkinetic children: A double-blind crossover comparison with methylphenidate. Biol Psychiatry. 1979;14(5):741-51. [pmid: 497303].
Collier SJ. Effects of parent training on children's attention deficit disorder: A comparative outcome study. Diss Abstr Int. 1990;50(8-B).
Conners CK, Taylor E. Pemoline, methylphenidate, and placebo in children with minimal brain dysfunction. Arch Gen Psychiatry. 1980 Aug;37(8):922-30.
Conners CK, Casat CD, Gualtieri CT, Weller E, Reader M, Reiss A, Weller RA, Khayrallah M, Ascher, J. Bupropion hydrochloride in attention deficit disorder with hyperactivity. J Am Acad Child Adolesc Psychiatry. 1996;35(10):1314-21. [pmid: 8885585].
Conners CK, Levin ED, Sparrow E, Hinton SC, Erhardt D, Meck WH, Rose JE, March J. Nicotine and attention in adult attention deficit hyperactivity disorder (ADHD). Psychopharmacol Bull. 1996;32(1):67-73. [pmid: 8927677].
Conners CK, Taylor E, Meo G, Kurtz MA, Fournier M. Magnesium pemoline and dextroamphetamine: A controlled study in children with minimal brain dysfunction. Psychopharmacologia. 1972;26(4):321-36. [pmid: 4508756].
Conrad WG, Dworkin ES, Shai A, Tobiessen JE. Effects of amphetamine therapy and prescriptive tutoring on the behavior and achievement of lower class hyperactive children. J Learn Disabil. 1971;4:509-17.
Coons HW, Klorman R, Borgstedt AD. Effects of methylphenidate on adolescents with a childhood history of attention deficit disorder: II. Information processing [published erratum appears in J Am Acad Child Adolesc Psychiatry 1987 Sep; 26(5): 820]. J Am Acad Child Adolesc Psychiatry. 1987;26(3):368-74. [pmid: 3298202].
Cotton MF, Rothberg AD. Methylphenidate v. placebo-a randomised double-blind crossover study in children with the attention deficit disorder. S Afr Med J. 1988;74(6):268-71. [pmid: 3047886].
Cowart VS. ADD: Not limited to children? [news]. JAMA. 1982;248(3).
Cunningham CE, Bremner R, Secord-Gilbert M. Increasing the availability, accessibility, and cost efficacy of services for families of ADHD children: A school-based systems-oriented parenting course. Can J School Psychol. 1993;9(1):1-15.
Cunningham CE, Bremner R, Boyle M. Large group community-based parenting programs for families of preschoolers at risk for disruptive behaviour disorders: Utilization, cost effectiveness, and outcome. J Child Psychol Psychiatry. 1995;36(7):1141-59. [pmid: 8847377].
Cunningham CE, Siegel LS, Offord DR. A developmental dose-response analysis of the effects of methylphenidate on the peer interactions of attention deficit disordered boys. J Child Psychol Psychiatry. 1985;26(6):955-71. [pmid: 4066819].
Cunningham CE, Siegel LS, Offord DR. A dose-response analysis of the effects of methylphenidate on the peer interactions and simulated classroom performance of ADD children with and without conduct problems. J Child Psychol Psychiatry. 1991;32(3):439-52. [pmid: 2061364].
Dalby JT, Kinsbourne M, Swanson JM. Self-paced learning in children with attention deficit disorder with hyperactivity. J Abnorm Child Psychol. 1989;17(3):269-75. [pmid: 2666475].
David OJ, Hoffman SP, Clark J, Grad G, Sverd J. The relationship of hyperactivity to moderately elevated lead levels. Arch Environ Health. 1983;38(6):341-6. [pmid: 6667034].
de Sonneville LM, Njiokiktjien C, Bos H. Methylphenidate and information processing. Part 1: Differentiation between responders and nonresponders; Part 2: Efficacy in responders. J Clin Exp Neuropsychol. 1994;16(6):877-97. [pmid: 7890822].
de Sonneville LM, Njiokiktjien C, Hilhorst RC. Methylphenidate-induced changes in ADDH information processors. J Child Psychol Psychiatry. 1991;32(2):285-95. [pmid: 2033109].
Denkowski KM, Denkowski GC Is group progressive relaxation training as effective with hyperactive children as individual EMG biofeedback treatment? Biofeedback Self Regul 1984 9(3) 353 64View this and related citations using 6395905
Denkowski KM, Denkowski GC, Omizo MM The effects of EMG-assisted relaxation training on the academic performance, locus of control, and self-esteem of hyperactive boys Biofeedback Self Regul 1983 8(3) 363 75View this and related citations using 6367832
DeVeaugh-Geiss J, Joseph A. Paradoxical response to amphetamine in a hyperkinetic adult. Psychosomatics. 1980;21(3):247-52. [pmid: 7367570].
Diderichsen J, Ruud E. [Hyperkinetic behavior syndrome. An interdisciplinary study of the basis for rational medical treatment]. (Nor). Tidsskr Nor Laegeforen. 1988;108(6):481-3, 465. [pmid: 3281323].
DiTraglia J. Methylphenidate protocol: Feasibility in a pediatric practice [see comments]. Clin Pediatr. 1991;30(12):656-60.
Donnelly M, Rapoport JL, Ismond DR. Fenfluramine treatment of childhood attention deficit disorder with hyperactivity: A preliminary report. Psychopharmacol Bull. 1986;22(1):152-4. [pmid: 3523573].
Donnelly M, Rapoport JL, Potter WZ, Oliver J, Keysor CS, Murphy DL. Fenfluramine and dextroamphetamine treatment of childhood hyperactivity. Clinical and biochemical findings. Arch Gen Psychiatry. 1989;46(3):205-12. [pmid: 2645848].
Donnelly M, Zametkin AJ, Rapoport JL, Ismond DR, Weingartner H, Lane E, Oliver J, Linnoila M, Potter WZ. Treatment of childhood hyperactivity with desipramine: Plasma drug concentration, cardiovascular effects, plasma and urinary catecholamine levels, and clinical response. Clin Pharmacol Ther. 1986;Jan;39(1):72-81.
Douglas VI, Barr RG, Amin K, O'Neill ME, Britton BG. Dosage effects and individual responsivity to methylphenidate in attention deficit disorder. J Child Psychol Psychiatry. 1988;29(4):453-75. [pmid: 3063718].
Douglas VI, Barr RG, Desilets J, Sherman E. Do high doses of stimulants impair flexible thinking in attention-deficit hyperactivity disorder?. J Am Acad Child Adolesc Psychiatry. 1995;34(7):877-85. [pmid: 7649958].
Douglas VI, Barr RG, O'Neill ME, Britton BG. Short term effects of methylphenidate on the cognitive, learning and academic performance of children with attention deficit disorder in the laboratory and the classroom. J Child Psychol Psychiatry. 1986;27(2):191-211. [pmid: 3514644].
Drtilkowa I, Misurec J, Nahunek K. The paradox effect of psychostimulants in the treatment of the child hyperkinetic syndrome. Act Nerv Super. 1990;32(4):302-3.
Dubey DR, O'Leary SG, Kaufman KF. Training parents of hyperactive children in child management: A comparative outcome study. J Abnorm Child Psychol. 1983;11(2):229-45. [pmid: 6619436].
Dumbrell S, Woodhill JM, Mackie L, Leelarthaepin B. Is the Australian version of the Feingold diet safe?. Med J Aust. 1978;2(12):548, 569-70. [pmid: 364258].
Dunson RM, Hughes JN, Jackson TW. Effect of behavioral consultation on student and teacher behavior. J School Psychol. 1994;32(3):247-66.
DuPaul GJ, Eckert TL. The effects of school-based interventions for attention deficit hyperactivity disorder: A meta-analysis. School Psychol Rev. 1997;26(1):5-27.
DuPaul GJ, Rapport MD. Does methylphenidate normalize the classroom performance of children with attention deficit disorder?. J Am Acad Child Adolesc Psychiatry. 1993;32(1):190-8. [pmid: 8428871].
DuPaul GJ, Barkley RA, McMurray MB. Response of children with ADHD to methylphenidate: Interaction with internalizing symptoms. J Am Acad Child Adolesc Psychiatry. 1994;33(6):894-903. [pmid: 8083147].
DuPaul GJ, Rapport MD, Vyse SA. ADDH and methylphenidate responders: Effects on behavior controlled by complex reinforcement schedules. Int Clin Psychopharmacol. 1988;3(4):349-61. [pmid: 3235820].
Dykman RA, Ackerman PT, McCray DS. Effects of methylphenidate on selective and sustained attention in hyperactive, reading-disabled, and presumably attention-disordered boys. J Nerv Ment Dis. 1980;168(12):745-52. [pmid: 7452214].
Dykman RA, McGrew J, Ackerman PT. A double-blind clinical study of pemoline in MBD children: Comments on the psychological test results. In: Conners CK, editor. Clinical use of stimulant drugs in children. Excerpta Medica (Amsterdam). 1974;(1972):125-9.
Efron D, Jarman F, Barker M. Methylphenidate versus dexamphetamine in children with attention deficit hyperactivity disorder: A double-blind, crossover trial. Paediatrics. 1997;100(6).
Egger J, Carter CM, Graham PJ, Gumley D, Soothill JF. Controlled trial of oligoantigenic treatment in the hyperkinetic syndrome. Lancet. 1985;1(8428):540-5. [pmid: 2857900].
Eich WF, Thim EB, Crowder JE. Effect of the Feingold Kaiser Permanente diet in minimal brain dysfunction. J Med Assoc Ala. 1979;49(4):16-8, 20.
Eisenberg J, Asnis GM, van Praag HM, Vela RM. Effect of tyrosine on attention deficit disorder with hyperactivity. J Clin Psychiatry. 1988;49(5):193-5. [pmid: 3284877].
Elia J, Ambrosini, PJ, Rapoport JL. Treatment of attention-deficit/hyperactivity disorder. N Engl J Med. 1999 Mar;340(10):780-88.
Elia J, Borcherding BG, Rapoport JL, Keysor CS. Methylphenidate and dextroamphetamine treatments of hyperactivity: Are there true nonresponders?. Psychiatry Res. 1991 Feb;36(2):141-55.
Elia J, Welsh PA, Gullotta CS, Rapoport JL. Classroom academic performance: Improvement with both methylphenidate and dextroamphetamine in ADHD boys. J Child Psychol Psychiatry. 1993;34(5):785-804. [pmid: 8340445].
Ernst M, Liebenauer LL, Jons PH, Tebeka D, Cohen RM, Zametkin AJ. Selegiline in adults with attention deficit hyperactivity disorder: Clinical efficacy and safety. Psychopharmacol Bull. 1996;32(3):327-34. [pmid: 8961775].
Ernst M, Liebenauer LL, Tebeka D, Jons PH, Eisenhofer G, Murphy DL, Zametkin AJ. Selegiline in ADHD adults: Plasma monoamines and monoamine metabolites. Neuropsychopharmacology. 1997 Apr;16(4):276-84. (Same study as Ernst, Liebenauer, Jons et al., 1996).
Ernst M, Zametkin AJ, Matochik JA, Liebenauer L, Fitzgerald GA, Cohen RM. Effects of intravenous dextroamphetamine on brain metabolism in adults with attention-deficit hyperactivity disorder (ADHD). Preliminary findings. Psychopharmacol Bull. 1994;30(2):219-25.
Evans RW, Gualtieri CT, Amara I. Methylphenidate and memory: Dissociated effects in hyperactive children. Psychopharmacology. 1986;90(2):211-6. [pmid: 3097701].
Evans SW, Pelham WE. Psychostimulant effects on academic and behavioral measures for ADHD junior high school students in a lecture format classroom. J Abnorm Child Psychol. 1991;19(5):537-52. [pmid: 1770184].
Evans SW, Vallano G, Pelham W. Treatment of parenting behavior with a psychostimulant: A case study of an adult with attention-deficit hyperactivity disorder. J Child Adolesc Psychopharmacol. 1994;4(1):63-9.
Everett J, Thomas J, Cote F, Levesque J, Michaud D. Cognitive effects of psychostimulant medication in hyperactive children. Child Psychiatry Hum Dev. 1991;22(2):79-87. [pmid: 1686856].
Fehlings DL, Roberts W, Humphries T, Dawe G. Attention deficit hyperactivity disorder: Does cognitive behavioral therapy improve home behavior?. J Dev Behav Pediatrics. 1991 Aug;12(4):223-8.
Feigin A, Kurlan R, McDermott MP, Beach J, Dimitsopulos T, Brower CA, Chapieski L, Trinidad K, Como P, Jankovic J. A controlled trial of deprenyl in children with Tourette's syndrome and attention deficit hyperactivity disorder. Neurology. 1996;46(4):965-8. [pmid: 8780073].
Feinberg I, Hibi S, Braun M, Cavness C, Westerman G, Small A. Sleep amphetamine effects in MBDS and normal subjects. Arch Gen Psychiatry. 1974;31(5):723-31. [pmid: 4374157].
Feldman H, Crumrine P, Handen BL, Alvin R, Teodori J. Methylphenidate in children with seizures and attention-deficit disorder. Am J Dis Children. 1989;143(9):1081-6. [pmid: 2672786].
Fenichel RR. Combining methylphenidate and clonidine: The role of post-marketing surveillance. J Child Adolesc Psychopharmacol. 1995;5(3):155-6.
Fiedler NL, Ullman DG. The effects of stimulant drugs on curiosity behaviors of hyperactive boys. J Abnorm Child Psychol. 1983;11(2):193-206. [pmid: 6619433].
Findling RL. Open-label treatment of comorbid depression and attentional disorders with co-administration of serotonin reuptake inhibitors and psychostimulants in children, adolescents, and adults: A case series. J Child Adolesc Psychopharmacol. 1996;6(3):165-75. [pmid: 9231310].
Findling RL, Schwartz MA, Flannery DJ, Manos MJ. Venlafaxine in adults with attention-deficit/hyperactivity disorder: An open clinical trial [see comments]. J Clin Psychiatry. 1996;57(5):184-9. [pmid: 8626348].
Fine S, Johnston C. Drug and placebo side effects in methylphenidate-placebo trial for attention deficit hyperactivity disorder. Child Psychiatry Hum Dev. 1993;4(1):25-30.
Firestone P, Douglas V. The effects of reward and punishment on reaction times and autonomic activity in hyperactive and normal children. J Abnorm Child Psychol. 1975;3(3):201-16. [pmid: 1214031].
Firestone P, Crowe D, Goodman JT, McGrath P. Vicissitudes of follow-up studies: Differential effects of parent training and stimulant medication with hyperactives. Am J Orthopsychiatry. 1986 Apr;56(2):184-94.
Firestone P, Davey J, Goodman JT, Peters S. The effects of caffeine and methylphenidate on hyperactive children. J Am Acad Child Psychiatry. 1978;17(3):445-56. [pmid: 690354].
Firestone P, Kelly MJ, Goodman JT, Davey J. Differential effects of parent training and stimulant medication with hyperactives: A progress report. J Am Acad Child Psychiatry. 1981;20(1):135-47. [pmid: 7217546].
Fitzpatrick PA, Klorman R, Brumaghim JT, Borgstedt AD. Effects of sustained-release and standard preparations of methylphenidate on attention deficit disorder. J Am Acad Child Adolesc Psychiatry. 1992;31:226-34. [pmid: 1564023].
Forness SR, Cantwell DP, Swanson JM, Hanna GL, Youpa D. Differential effects of stimulant medication on reading performance of boys with hyperactivity with and without conduct disorder. J Learn Disabil. 1991;24(5):304-10. [pmid: 2045727].
Forness SR, Swanson JM, Cantwell DP, Youpa D, Hanna GL. Stimulant medication and reading performance: Follow-up on sustained dose in ADHD boys with and without conduct disorders. J Learn Disabil. 1992;25(2):115-23. [pmid: 1583417].
Frank Y. Visual event related potentials after methylphenidate and sodium valproate in children with attention deficit hyperactivity disorder. Clin Electroencephalogr. 1993;24(1):19-24. [pmid: 8420693].
Frankel F, Myatt R, Cantwell DP, Feinberg DT. Parent-assisted transfer of children's social skills training: Effects on children with and without attention-deficit hyperactivity disorder. J Am Acad Child Adolesc Psychiatry. 1997;36(8):1056-64. [pmid: 9256585].
Freibergs V, Douglas VI, Weiss G. The effect of chlorpromazine on concept learning in hyperactive children under two conditions of reinforcement. Psychopharmacologia. 1968;13(4):299-310. [pmid: 4881014].
Freiman JA, Chalmers TC, Smith H, Kuebler R. The importance of beta, the type II error and sample size in the design and interpretation of the randomized control trial. Survey of 71 "negative" trials. N Engl J Med. 1978 Sep;299(13):690-4.
Friedman R, Dale EP, Wagner JH. A long-term comparison of two treatment regimens for minimal brain dysfunction. Drug therapy versus combined therapy. Clin Pediatr. 1973;12(11):666-71.
Funk JB, Chessare JB, Weaver MT, Exley AR. Attention deficit hyperactivity disorder, creativity, and the effects of methylphenidate. Pediatrics. 1993;91(4):816-9. [pmcid: 375534]. [pmid: 8464673].
Gadow KD, Nolan EE, Sverd J. Methylphenidate in hyperactive boys with comorbid tic disorder: II. Short-term behavioral effects in school settings. J Am Acad Child Adolesc Psychiatry. 1992 May;31(3):462-71. (Same study as Gadow, Sverd, Sprafkin et al., 1995).
Gadow KD, Nolan EE, Sverd J, Sprafkin J, Paolicelli L. Methylphenidate in aggressive-hyperactive boys: I. Effects on peer aggression in public school settings. J Am Acad Child Adolesc Psychiatry. 1990;29(5):710-8. [pmid: 2228923].
Gadow KD, Nolan E, Sprafkin J, Sverd J. School observations of children with attention-deficit hyperactivity disorder and comorbid tic disorder: Effects of methylphenidate treatment. J Dev Behav Pediatr. 1995 Jun;16(3):167-76. (Same study as Gadow, Sverd, Sprafkin et al., 1995).
Gadow KD, Sverd J, Sprafkin J, Nolan EE, Ezor SN. Efficacy of methylphenidate for attention-deficit hyperactivity disorder in children with tic disorder [published erratum appears in Arch Gen Psychiatry 1995 Oct;52(10):836]. Arch Gen Psychiatry. 1995 Jun;52(6):444-55.
Garfinkel BD, Webster CD, Sloman L. Individual responses to methylphenidate and caffeine in children with minimal brain dysfunction. Can Med Assoc J. 1975;113(8):729-32. [pmid: 803184].
Garfinkel BD, Webster CD, Sloman L. Methylphenidate and caffeine in the treatment of children with minimal brain dysfunction. Am J Psychiatry. 1975;132(7):723-8. [pmid: 1094842].
Garfinkel BD, Webster CD, Sloman L. Responses to methylphenidate and varied doses of caffeine in children with attention deficit disorder. Can J Psychiatry. 1981 Oct;26(6):395-401.
Garfinkel BD, Brown WA, Klee SH, Braden W. Neuroendocrine and cognitive responses to amphetamine in adolescents with a history of attention deficit disorder. J Am Acad Child Psychiatry. 1986;25(4):503-8. [pmid: 3745731].
Gascon GG, Johnson R, Burd L. Central auditory processing and attention deficit disorders. J Child Neurol. 1986;1(1):27-33. [pmid: 3598105].
Gastfriend DR, Biederman J, Jellinek MS. Desipramine in the treatment of adolescents with attention deficit disorder. Am J Psychiatry. 1984;141(7):906-8. [pmid: 6375400].
Gauthier M. Stimulant medications in adults with attention deficit disorder. [Review] [52 refs]. Can J Psychiatry. 1984;29(5):435-40. [pmid: 6148139].
Ghose K. l-Tryptophan in hyperactive child syndrome associated with epilepsy: A controlled study. Neuropsychobiology. 1983;10(2-3):111-4. [pmid: 6425713].
Gillberg IC, Gillberg C. Children with deficits in attention, motor control and perception (DAMP): Need for specialist treatment. Acta Paediatr Scan. 1988;77(3):450-1.
Gittelman-Klein R, Klein DF, Abikoff H, Katz S, Gloisten AC, Kates W. Relative efficacy of methylphenidate and behavior modification in hyperkinetic children: An interim report. J Abnorm Child Psychol. 1976;4(4):361-79. [pmid: 1002948].
Gittelman-Klein R, Klein DF, Katz S, Saraf K, Pollack E. Comparative effects of methylphenidate and thioridazine in hyperkinetic children. I. Clinical results. Arch Gen Psychiatry. 1976 Oct;33(10):1217-31.
Gittelman Klein R, Landa B, Mattes, JA, Klein, DF. Methylphenidate and Growth in Hyperactive Children. Arch Gen Psychiatry. 1988;45:1127-30. [pmid: 3058088].
Goldman LS, Genel M, Bezman RJ, Slanetz PJ. Diagnosis and treatment of attention-deficit/hyperactivity disorder in children and adolescents. JAMA. 1998;279(14):1100-7. [pmid: 9546570].
Golinko BE. Side effects of dexedrine in hyperactive children: operationalization and quantification in a short-term trial. Prog Neuropsychopharmacol Biol Psychiatry. 1982;6(2):175-83. [pmid: 7202238].
Gomez R, Sanson AV. Effects of experimenter and mother presence on the attentional performance and activity of hyperactive boys. J Abnorm Child Psychol. 1994;22(5):517-29. [pmid: 7822626].
Gordon M, DiNiro D, Mettelman BB. Effect upon outcome of nuances in selection criteria for ADHD/hyperactivity. Psychol Rep. 1988;62(2):539-44. [pmid: 3406269].
Greenberg LM, Yellin AM. Blood pressure and pulse changes in hyperactive children treated with imipramine and methylphenidate. Am J Psychiatry. 1975;132(12):1325-6. [pmid: 1106218].
Greenberg LM, Deem MA, McMahon S. Effects of dextroamphetamine, chlorpromazine, and hydroxyzine on behavior and performance in hyperactive children. Am J Psychiatry. 1972 Nov;129(5):532-9.
Greenhill LL, Abikoff HB, Arnold LE, Cantwell DP, Conners CK, Elliott G, Hechtman L, Hinshaw SP, Hoza B, Jensen PS, March JS, Newcorn J, Pelham WE, Severe JB, Swanson JS, Vitiello B, Wells K. Medication treatment strategies in the MTA Study: Relevance to clinicians and researchers. J Am Acad Child Adolesc Psychiatry. 1996;34(10):1304-1313.
Greenhill LL, Rieder RO, Wender PH, Buchsbaum M, Zhan TP. Lithium carbonate in the treatment of hyperactive children. Arch Gen Psychiatry. 1973 May;28(5):636-40.
Grizenko N. Outcome of multimodal day treatment for children with severe behavior problems: A five-year follow-up. J Am Acad Child Adolesc Psychiatry. 1997;36(7):989-97. [pmid: 9204678].
Gross MD. Imipramine in the treatment of minimal brain dysfunction in children. Psychosomatics. 1973;14(5):283-5. [pmid: 4794958].
Gross MD. Caffeine in the treatment of children with minimal brain dysfunction or hyperkinetic syndrome. Psychosomatics. 1975;16(1):26-7. [pmid: 1101283].
Gross MD A comparison of dextro-amphetamine and racemic-amphetamine in the treatment of the hyperkinetic syndrome or minimal brain dysfunction Dis Nerv Syst 1976 Jan 37(1) 14 6View this and related citations using 1106966
Gross MD. Effect of sucrose on hyperkinetic children. Pediatrics. 1984;74(5):876-8. [pmid: 6387615].
Gross MD. Origin of stimulant use for treatment of attention deficit disorder [7]. Am J Psychiatry. 1995;152(2):298-9. [pmid: 7840374].
Gross-Tsur V, Manor O, vanderMeere J, Joseph A, Shalev RS. Epilepsy and attention deficit hyperactivity disorder: is methylphenidate safe and effective?. J Pediatr. 1997;130(4):670-4. [pmid: 9432523].
Gualtieri CT, Evans RW. Motor performance in hyperactive children treated with imipramine. Percept Mot Skills. 1988 Jun;66(3):763-9.
Gualtieri CT, Keenan PA, Chandler M. Clinical and neuropsychological effects of desipramine in children with attention deficit hyperactivity disorder. J Clin Psychopharmacol. 1991 Jun;11(3):155-9.
Guerreiro MM, Montenegro MA, Piva RT, Moura-Ribeiro MV. [Attention deficit disorder: treatment with methylphenidate]. (Por). Arq Neuropsiquiatr. 1996;54(1):25-9. [pmid: 8736140].
Gunning WB, Ferdinand RF, De Vrijer JC, Minderaa RB. The application of clonidine in child and adolescent psychiatry. Tijdschr Psychiatr. 1990;32(7):462-72.
Hall CW, Kataria S. Effects of two treatment techniques on delay and vigilance tasks with attention deficit hyperactive disorder (ADHD) children. J Psychol. 1992;126(1):17-25. [pmid: 1602426].
Halliday R, Callaway E, Rosenthal JH. The visual ERP predicts clinical response to methylphenidate in hyperactive children. Psychophysiology. 1984;21(1):114-21. [pmid: 6366860].
Halliday R, Rosenthal JH, Naylor H, Callaway E. Averaged evoked potential predictors of clinical improvement in hyperactive children treated with methylphenidate: An initial study and replication. Psychophysiology. 1976;13(5):429-40. [pmid: 972966].
Halperin JM, Gittelman R, Katz S, Struve FA. Relationship between stimulant effect, electroencephalogram, and clinical neurological findings in hyperactive children. J Am Acad Child Psychiatry. 1986;25(6):820-5. [pmid: 3540074].
Handen BL, Janosky J, McAuliffe S. Long-term follow-up of children with mental retardation/borderline intellectual functioning and ADHD. J Abnorm Child Psychol. 1997;25(4):287-95. [pmid: 9304445].
Handen BL, Breaux AM, Gosling A, Ploof DL, Feldman H. Efficacy of methylphenidate among mentally retarded children with attention deficit hyperactivity disorder [see comments]. Pediatrics. 1990;86(6):922-30. [pmid: 2135682].
Handen BL, Feldman H, Gosling A, Breaux AM, McAuliffe S. Adverse side effects of methylphenidate among mentally retarded children with ADHD. J Am Acad Child Adolesc Psychiatry. 1991 Mar;30(2):241-5.
Handen BL, Janosky J, McAuliffe S, Breaux AM, Feldman H. Prediction of response to methylphenidate among children with ADHD and mental retardation. J Am Acad Child Adolesc Psychiatry. 1994;33(8):1185-93. [pmid: 7982869].
Harley JP, Matthews CG, Eichman P. Synthetic food colors and hyperactivity in children: A double-blind challenge experiment. Pediatrics. 1978;62(6):975-83. [pmid: 366539].
Harley JP, Ray RS, Tomasi L, Eichman PL, Matthews CG, Chun R, Cleeland CS, Traisman E. Hyperkinesis and food additives: Testing the Feingold hypothesis. Pediatrics. 1978;61(6):818-28. [pmcid: 449715]. [pmid: 353681].
Hart EL, Lahey BB, Loeber R, Applegate B, Frick PJ. Developmental change in attention-deficit hyperactivity disorder in boys: A four-year longitudinal study. J Abnorm Child Psychol. 1995;23(6):729-49. [pmid: 8609310].
Harvey DH, Marsh RW. The effects of de-caffeinated coffee versus whole coffee on hyperactive children. Dev Med Child Neurol. 1978;20(1):81-6. [pmid: 346427].
Haslam RH. Is there a role for megavitamin therapy in the treatment of attention deficit hyperactivity disorder?. Adv Neurol. 1992;58:303-10. [pmid: 1414636].
Haslam RH, Dalby JT, Rademaker AW. Effects of megavitamin therapy on children with attention deficit disorders. Pediatrics. 1984;74(1):103-11. [pmid: 6234505].
Hazell PL, McDowell MJ, Walton JM. Management of children prescribed psychostimulant medication for attention deficit hyperactivity disorder in the Hunter region of NSW. Med J Aust. 1996;165(9):477-80. [pmid: 8937367].
Hechtman L, Weiss G, Perlman T. Young adult outcome of hyperactive children who received long-term stimulant treatment. J Am Acad Child Psychiatry. 1984;23(3):261-9. [pmid: 6736490].
Hedges D, Reimherr FW, Rogers A, Strong R, Wender PH. An open trial of venlafaxine in adult patients with attention deficit hyperactivity disorder. Psychopharmacol Bull. 1995;31(4):779-83. [pmid: 8851653].
Heiligenstein E, Anders J. Pemoline in adult attention deficit hyperactivity disorder: Predictors of nonresponse. J Am Coll Health. 1997;45(5):225-9. [pmid: 9069682].
Henker B, Whalen CK, Collins BE. Double-blind and triple-blind assessments of medication and placebo responses in hyperactive children. J Abnorm Child Psychol. 1979;7(1):1-13. [pmid: 374446].
Hicks RE, Mayo JPJ, Clayton CJ. Differential psychopharmacology of methylphenidate and the neuropsychology of childhood hyperactivity. Int J Neurosci. 1989;45(1-2):7-32. [pmid: 2654045].
Hinshaw SP, Buhrmester D, Heller T. Anger control in response to verbal provocation: Effects of stimulant medication for boys with ADHD. J Abnorm Child Psychol. 1989 Aug;17(4):393-407.
Hinshaw SP, Heller T, McHale JP. Covert antisocial behavior in boys with attention-deficit hyperactivity disorder: External validation and effects of methylphenidate. J Consult Clin Psychol. 1992;60(2):274-81. [pmid: 1592958].
Hinshaw SP, Henker B, Whalen CK. Cognitive-behavioral and pharmacologic interventions for hyperactive boys: Comparative and combined effects. J Consult Clin Psychol. 1984 Oct;52(5):739-49.
Hinshaw SP, Henker B, Whalen CK, Erhardt D, Dunnington REJ. Aggressive, prosocial, and nonsocial behavior in hyperactive boys: Dose effects of methylphenidate in naturalistic settings. J Consult Clin Psychol. 1989;57(5):636-43. [pmid: 2794184].
Hinshaw SP, March JS, Abikoff H, Arnold LE, Cantwell DP, Conners CK, Elliott GR, Halperin J, Greenhill LL, Hechtman LT, Hoza B, Jensen PS, Newcorn JH, McBurnett K, Pelham WE, Richters JE, Severe JB, Schiller E, Swanson J, Vereen D, Wells K, Wigal T. Comprehensive assessment of childhood attention-deficit hperactivity disorder in the context of a multisite, multimodal clinical trial. J Attention Disord. 1997;1(4):217-34.
Hoffman SP, Engelhardt DM, Margolis RA, Polizos P, Waizer J, Rosenfeld R. Response to methylphenidate in low socioeconomic hyperactive children. Arch Gen Psychiatry. 1974;30(3):354-9. [pmid: 4813138].
Horn WF, Ialongo NS, Pascoe JM, Greenberg G, Packard T, Lopez M, Wagner A, Puttler L. Additive effects of psychostimulants, parent training, and self-control therapy with ADHD children. J Am Acad Child Adolesc Psychiatry. 1991;30(2):233-40. [pmid: 2016227].
Horn WF, Ialongo N, Popovich S, Peradotto D. Behavioral parent training and cognitive-behavioral self-control therapy with ADD-H children: Comparative and combined effects. J Clin Child Psychol. 1987;16(1):57-68.
Horrigan JP, Barnhill LJ. Guanfacine for treatment of attention-deficit hyperactivity disorder in boys. J Child Adolesc Psychopharmacol. 1995;5(3):215-23.
Horwitz DL. Conspectus: Food colorings and hyperkinetic children. Compr Ther. 1980;6(11):3-4.
Hoza B, Pelham WE Jr, Sams SE, Carlson C. An examination of the "dosage" effects of both behavior therapy and methylphenidate on the classroom performance of two ADHD children. Behav Modif. 1992;16(2):164-92. [pmid: 1580892].
http://www.healthy.net/library/books/ullman/chap3.htm.
Hubbard JA, Newcomb AF. Initial dyadic peer interaction of attention deficit-hyperactivity disorder and normal boys. J Abnorm Child Psychol. 1991;19(2):179-95. [pmid: 2056162].
Hunt RD. Treatment effects of oral and transdermal clonidine in relation to methylphenidate: An open pilot study in ADD-H. Psychopharmacol Bull. 1987;23(1):111-4. [pmid: 3602304].
Hunt RD, Arnsten AFT, Asbell MD. An open trial of guanfacine in the treatment of attention-deficit hyperactivity disorder. J Am Acad Child Adolesc Psychiatry. 1995;34(1):50-4. [pmid: 7860456].
Hunt RD, Minderaa RB, Cohen DJ. Clonidine benefits children with attention deficit disorder and hyperactivity: Report of a double-blind placebo-crossover therapeutic trial. J Am Acad Child Psychiatry. 1985;24(5):617-29. [pmid: 3900182].
Hunt RD, Minderaa RB, Cohen DJ. The therapeutic effect of clonidine in attention deficit disorder with hyperactivity: A comparison with placebo and methylphenidate. Psychopharmacol Bull. 1986;22(1):229-36. [pmid: 3523578].
Ioannidis JPA, Cappelleri JC, Lau J. Issues in comparisons between meta-analyses and large trials. JAMA. 1998;279:1089-93. [pmid: 9546568].
Iaboni F, Douglas VI, Baker AG. Effects of reward and response costs on inhibition in ADHD children. J Abnorm Psychol. 1995;104(1):232-40. [pmid: 7897047].
Ialongo NS, Horn WF, Pascoe JM, Greenberg G, Packard T, Lopez M, Wagner A, Puttler L. The effects of a multimodal intervention with attention-deficit hyperactivity disorder children: A 9-month follow-up. J Am Acad Child Adolesc Psychiatry. 1993;32(1):182-9. [pmid: 8428870].
Jadad AR, Rennie D. The randomized controlled trial gets a middle-aged checkup. (Editorial). JAMA. 1998;279(4):319-20. [pmid: 9450719].
Jadad AR, Moore RA, Carroll D, Jenkinson C, Reynolds DJM, Gavaghan DJ, McQuay HJ. Assessing the quality of reports of randomized clinical trials: Is blinding necessary?. Controlled Clin Trials. 1996;17:1-12. [pmid: 8721797].
Jensen P, Martin D, Cantwell D. Comorbidity in ADHD: Implications for research, practice, and DSM-V. J Am Acad Child Adolesc Psychiatry. 1997;36(8):1065-79. [pmid: 9256586].
Johnson CR, Handen BL, Lubetsky MJ, Sacco KA. Efficacy of methylphenidate and behavioral intervention on classroom behavior in children with ADHD and mental retardation. Behav Modif. 1994;18(4):470-87. [pmid: 7980374].
Jonkman LM, Kemner C, Verbaten MN, Koelega HS, Camfferman G, Gaag RJ, Buitelaar JK, van Engeland H. Effects of methylphenidate on event-related potentials and performance of attention-deficit hyperactivity disorder children in auditory and visual selective attention tasks. Biol Psychiatry. 1997;41(6):690-702. [pmid: 9066993].
Juchems R, Wertz U. [Central hemodynamics of the hyperkinetic syndrome under blockade with beta receptors]. (Ger). Munchener Med Wochenschrift. 1969;111(49):2567-71.
Kahn KS, Daya S, Jadad AR. The importance of quality of primary studies in producing unbiased systematic reviews. Arch Intern Med. 1996 Mar 25;156:661-6.
Kaplan BJ, McNicol J, Conte RA, Moghadam HK Dietary replacement in preschool-aged hyperactive boys Pediatrics 1989 83(1) 7 17View this and related citations using 2909977
Kaplan SL, Busner J, Kupietz S, Wassermann E, Segal B. Effects of methylphenidate on adolescents with aggressive conduct disorder and ADDH: A preliminary report. J Am Acad Child Adolesc Psychiatry. 1990;29(5):719-23. [pmid: 2228924].
Kauffman RE, Smith-Wright D, Reese CA, Simpson R, Jones F. Medication compliance in hyperactive children. Pediatr Pharmacol. 1981;1(3):231-7.
Kavale K. The efficacy of stimulant drug treatment for hyperactivity: A meta-analysis. J Learn Disabil. 1982;15(5):280-9. [pmid: 6123539].
Kavale KA, Forness SR. Hyperactivity and diet treatment: A meta-analysis of the Feingold hypothesis. J Learn Disabil. 1983 Jun-Jul;16(6):324-30.
Keith RW, Engineer P. Effects of methylphenidate on the auditory processing abilities of children with attention deficit-hyperactivity disorder. J Learn Disabil. 1991;24(10):630-6. [pmid: 1783870].
Kelly KL, Rapport MD, DuPaul GJ. Attention deficit disorder and methylphenidate: A multi-step analysis of dose-response effects on children's cardiovascular functioning. Int Clin Psychopharmacol. 1988;3(2):167-81. [pmid: 3294285].
Kelly PC, Cohen ML, Walker WO, Caskey OL, Atkinson AW. Self-esteem in children medically managed for attention deficit disorder [see comments]. Pediatrics. 1989;83(2):211-7. [pmid: 2913551].
Kendall PC, Finch AJJ. A cognitive-behavioral treatment for impulsivity: A group comparison study. J Consult Clin Psychol. 1978;46(1):110-8. [pmid: 342557].
Kendall PC, Panichelli MSM. Cognitive-behavioral treatments. J Abnorm Child Psychol. 1995;23(1):107-24. [pmid: 7759669].
Kent JD, Blader JC, Koplewicz HS, Abikoff H, Foley CA. Effects of late-afternoon methylphenidate administration on behavior and sleep in attention-deficit hyperactivity disorder [see comments]. Pediatrics. 1995;96(2 Pt 1):320-5. [pmcid: 169185]. [pmid: 7630692].
Kessler S. Drug therapy in attention-deficit hyperactivity disorder. South Med J. 1996;89(1):33-8. [pmid: 8545689].
Kewley GD. Personal paper: Attention deficit hyperactivity disorder is underdiagnosed and undertreated in Britain. BMJ. 1998;316:1594-6. [pmid: 9596603]. [pmcid: 1113204].
Klein RG. Clinical efficacy of methylphenidate in children and adolescents. [Review] [44 refs]. Encephale. 1993;19(2):89-93. [pmid: 8275902].
Klein RG, Abikoff H. Behavior therapy and methylphenidate in the treatment of children with ADHD. J Attention Dis. 1997;2(2):89-114. (Same study as Gittelman-Klein, Klein, Abikoff et al., 1976).
Klein RG, Mannuzza S. Hyperactive boys almost grown up. III. Methylphenidate effects on ultimate height. Arch Gen Psychiatry. 1988;45(12):1131-4. [pmid: 3058089].
Klein RG, Abikoff H, Klass E, Ganeles D, Seese LM, Pollack S. Clinical efficacy of methylphenidate in conduct disorder with and without attention deficit hyperactivity disorder. Arch Gen Psychiatry. 1997;54:1073-80. [pmid: 9400342].
Klein RG, Landa B, Mattes JA, Klein DF. Methylphenidate and growth in hyperactive children. A controlled withdrawal study. Arch Gen Psychiatry. 1988 Dec;45(12):1127-30. (Same study as Gittelman-Klein, Klein, Katz et al., 1976).
Coons HW, Klorman R, Borgstedt AD. Effects of methylphenidate on adolescents with a childhood history of attention deficit disorder: I. Clinical findings [published erratum appears in J Am Acad Child Adolesc Psychiatry 1987 Sep; 26(5): 820]. J Am Acad Child Adolesc Psychiatry. 1987;26(3):363-7. [pmid: 3298201].
Klorman R, Brumaghim JT, Salzman LF, Strauss J, Borgstedt AD, McBride MC, Loeb, S. Effects of methylphenidate on attention-deficit hyperactivity disorder with and without aggressive/noncompliant features. J Abnorm Psychol. 1988;97(4):413-22. [pmid: 3060506].
Klorman R, Brumaghim JT, Fitzpatrick PA, Borgstedt AD. Clinical effects of a controlled trial of methylphenidate on adolescents with attention deficit disorder. J Am Acad Child Adolesc Psychiatry. 1990;Sep;29(5):702-9.
Klorman R, Brumaghim JT, Fitzpatrick PA, Borgstedt AD. Methylphenidate speeds evaluation processes of attention deficit disorder adolescents during a continuous performance test. J Abnorm Child Psychol. 1991;19(3):263-83. [pmid: 1865045].
Klorman R, Brumaghim JT, Fitzpatrick PA, Borgstedt AD. Methylphenidate reduces abnormities of stimulus classification in adolescents with attention deficit disorder. J Abnorm Psychol. 1992;101(1):130-8. [pmid: 1537959].
Klorman R, Brumaghim JT, Fitzpatrick PA, Borgstedt AD, Strauss J. Clinical and cognitive effects of methylphenidate on children with attention deficit disorder as a function of aggression/oppositionality and age. J Abnorm Psychol. 1994;103(2):206-21. [pmid: 8040490].
Klorman R, Brumaghim JT, Salzman LF, Strauss J, Borgstedt AD, McBride MC, Loeb, S. Comparative effects of methylphenidate on attention-deficit hyperactivity disorder with and without aggressive/noncompliant features. Psychopharmacol Bull. 1989;25(1):109-13. [pmid: 2772109].
Klorman R, Brumaghim JT, Salzman LF, Strauss J, Borgstedt AD, McBride MC, Loeb, S. Effects of methylphenidate on processing negativities in patients with attention-deficit hyperactivity disorder. Psychophysiology. 1990;27(3):328-37. [pmid: 2236435].
Klorman R, Coons HW, Brumaghim JT, Borgstedt AD, Fitzpatrick P. Stimulant treatment for adolescents with attention deficit disorder. Psychopharmacol Bull. 1988;24(1):88-92. [pmid: 2898797].
Knights RM, Viets CA. Effects of pemoline on hyperactive boys. Pharmacol Biochem Behav. 1975;3(6):1107-14. [pmid: 772696].
Knoelker U, Nissen G. Double-blind study nomifensine vs. imipramine in children with hyperkinetic syndrome. Arzneimittelforschung. 1980;30(8).
Kolko DJ, Loar LL, Sturnick D. Inpatient social-cognitive skills training groups with conduct disordered and attention deficit disordered children. J Child Psychol Psychiatry. 1990;31(5):737-48. [pmid: 2398118].
Krusch DA, Klorman R, Brumaghim JT, Fitzpatrick PA, Borgstedt AD, Strauss J. Methylphenidate slows reactions of children with attention deficit disorder during and after an error. J Abnorm Child Psychol. 1996;24(5):633-50. [pmid: 8956088].
Kupietz SS, Winsberg BG, Richardson E, Maitinsky S. Effects of methylphenidate dosage in hyperactive reading-disabled children: I. Behavior and cognitive performance effects. J Am Acad Child Adolesc Psychiatry. 1988 Jan;27(1):70-7.
Kutcher SP. Assessing and treating attention deficit disorder in adolescents. The clinical application of a single-case research design. Br J Psychiatry. 1986;149:710-5. [pmid: 3539250].
Langer DH, Rapoport JL, Brown GL, Ebert MH, Bunney WEJ. Behavioral effects of carbidopa/levodopa in hyperactive boys. J Am Acad Child Psychiatry. 1982;21(1):10-8. [pmid: 7047618].
Laumann A, Poustka F. Differential diagnosis and treatment outcome in the hyperkinetic syndrome. Z Kinder Jugendpsychiatr. 1991;19(4):231-9. [pmid: 1812672].
Lauth GW, Naumann K, Roggenkamper A, Heine A. [Behavior medicine indications and evaluation of cognitive-behavioral therapy with attention-deficit/hyperkinetic children]. (Ger). Z Kinder Jugenpsychiatr. 1996;24(3):164-75.
Lawrence JD, Lawrence DB, Carson DS. Optimizing ADHD therapy with sustained-release methylphenidate. Am Fam Physician. 1997;55(5):1705-9. [pmid: 9105199].
Lerer RJ, Lerer MP. The effects of methylphenidate on the soft neurological signs of hyperactive children. Pediatrics. 1976;57(4):521-5. [pmid: 772581].
Lerer RJ, Artner J, Lerer MP. Handwriting deficits in children with minimal brain dysfunction: effects of methylphenidate (Ritalin) and placebo. J Learn Disabil. 1979;12(7):450-5. [pmid: 521686].
Lesnik OM, Van-Der VH, Hoencamp E, et al. Stimulus-governance and the hyperkinetic syndrome. J Abnorm Child Psychol. 1978;6(3):407-12. [pmid: 701653].
Levin ED, Conners CK, Sparrow E, Hinton SC, Erhardt D, Meck WH, Rose JE, March J. Nicotine effects on adults with attention-deficit/hyperactivity disorder. Psychopharmacology. 1996;123(1):55-63. [pmid: 8741955].
Levine M, Walter S, Lee H, Haines T, Holbrook A, Moyer V. Users' guide to the medical literature IV: How to use an article about harm. JAMA. 1994;271(20):1615-9. [pmid: 8182815].
Levy F, Hobbes G. Does haloperidol block methylphenidate? Motivation or attention?. Psychopharmacology. 1996 Jul;126(1):70-4.
Levy F, Dumbrell S, Hobbes G, Ryan M, Wilton N, Woodhill JM. Hyperkinesis and diet: A double-blind crossover trial with a tartrazine challenge. Med J Aust. 1978;1(2):61-4. [pmid: 349320].
Lewis JA, Young R. Deanol and methylphenidate in minimal brain dysfunction. Clin Pharmacol Ther. 1975;17(5):534-40. [pmid: 1092513].
Lie N. Follow-ups of children with attention deficit hyperactivity disorder (ADHD). Acta Psychiatr Scand Suppl. 1992;368:1-40. [pmid: 1642137].
Linden M, Habib T, Radojevic V. A controlled study of the effects of EEG biofeedback on cognition and behavior of children with attention deficit disorder and learning disabilities. Biofeedback Self Regul. 1996 Mar;21(1):35-49.
Long N, Rickert VI, Ashcraft EW. Bibliotherapy as an adjunct to stimulant medication in the treatment of attention-deficit hyperactivity disorder. J Pediatr Health Care. 1993 Mar;7(2):82-8.
Losier BJ, McGrath PJ, Klein RM. Error patterns on the continuous performance test in nonmedicated and medicated samples of children with and without ADHD: A meta-analytic review. J Child Psychol Psychiatry. 1996;Nov;37(8):971-87.
Lubar JF, Swartwood MO, Swartwood JN, O'Donnell PH. Evaluation of the effectiveness of EEG neurofeedback training for ADHD in a clinical setting as measured by changes in T.O.V.A. scores, behavioral ratings, and WISC-R performance. Biofeedback Self Regul. 1995;20(1):83-99. [pmid: 7786929].
Lucas B, Sells CJ. Nutrient intake and stimulant drugs in hyperactive children. J Am Diet Assoc. 1977;70(4):373-7. [pmid: 321504].
Lupandin VM, Lando LI, Gromova EA, Kamenskaia VM, Zykov MB. [Role of biogenic amines in the pathogenesis of intellectual disorders in children with minimal psychoorganic syndromes]. (Rus). Zh Nevropatol Psikhiatr. 1978;78(10):1538-44. [pmid: 716733].
Malone MA, Swanson JM. Effects of methylphenidate on impulsive responding in children with attention-deficit hyperactivity disorder. J Child Neurol. 1993;8(2):157-63. [pmid: 8505479].
Malone MA, Kershner JR, Siegel L. The effects of methylphenidate on levels of processing and laterality in children with attention deficit disorder. J Abnorm Child Psychol. 1988;16(4):379-95. [pmid: 3221029].
Malone MA, Couitis J, Kershner JR, Logan WJ. Right hemisphere dysfunction and methylphenidate effects in children with attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 1994;4(4):245-53.
Matier K, Halperin JM, Sharma V, Newcorn JH, Sathaye N. Methylphenidate response in aggressive and nonaggressive ADHD children: Distinctions on laboratory measures of symptoms. J Am Acad Child Adolesc Psychiatry. 1992;31(2):219-25. [pmid: 1564022].
Matochik JA, Liebenauer LL, King C, Szymanski HV, Cohen RM, Zametkin AJ. Cerebral glucose metabolism in adults with attention deficit hyperactivity disorder after chronic stimulant treatment. Am J Psychiatry. 1994;151(5):658-64. [pmid: 8166305].
Matochik JA, Nordahl TE, Gross M, Semple WE, King AC, Cohen RM, Zametkin AJ. Effects of acute stimulant medication on cerebral metabolism in adults with hyperactivity. Neuropsychopharmacology. 1993;8(4):377-86. [pmid: 8512624].
Mattes JA, Gittelman R. Effects of artificial food colorings in children with hyperactive symptoms. A critical review and results of a controlled study. Arch Gen Psychiatry. 1981;38(6):714-8. [pmid: 7247635].
Mattes JA, Gittelman R. Growth of hyperactive children on maintenance regimen of methylphenidate. Arch Gen Psychiatry. 1983;40(3):317-21. [pmid: 6830410].
Mattes JA, Boswell L, Oliver H. Methylphenidate effects on symptoms of attention deficit disorder in adults. Arch Gen Psychiatry. 1984 Nov;41(11):1059-63.
Mayes SD, Crites DL, Bixler EO, Humphrey FJ, Mattison RE. Methylphenidate and ADHD: Influence of age, IQ and neurodevelopmental status. Dev Med Child Neurol. 1994;36(12):1099-107. [pmid: 7525394].
McBride MC. An individual double-blind crossover trial for assessing methylphenidate response in children with attention deficit disorder [see comments]. J Pediatr. 1988;113(1 Pt 1):137-45. [pmid: 3290413].
McIntyre HB, Firemark HM, Cho AK, Bodner L, Gomez M. Computer analyzed EEG in amphetamine-responsive hyperactive children. Psychiatry Res. 1981;4(2):189-97. [pmid: 6939009].
McManis DI, McCarthy M, Koval R. Effects of a stimulant drug on extraversion level in hyperactive children. Percept Mot Skills. 1978;46(1):88-90. [pmid: 643501].
McNutt B, Ballard JE, Boileau R. The effects of long-term stimulant medication on growth and body composition of hyperactive children. Psychopharmacol Bull. 1976;12(2):13-5.
McNutt BA, Boileau RA, Cohen MN. The effects of long-term stimulant medication on the growth and body composition of hyperactive children [proceedings]. Psychopharmacol Bull. 1977;13(2):36-8.
Milich R, Carlson CL, Pelham WEJ, Licht BG. Effects of methylphenidate on the persistence of ADHD boys following failure experiences. J Abnorm Child Psychol. 1991;19(5):519-36. [pmid: 1770183].
Milich R, Licht BG, Murphy DA, Pelham WE. Attention-deficit hyperactivity disordered boys' evaluations of and attributions for task performance on medication versus placebo. J Abnorm Psychol. 1989;98(3):280-4. [pmid: 2671083].
Miller A, Lee SK, Raina P, Klassen A, Zupancic J, Olsen L. A review of therapies for attention-deficit/hyperactivity disorder. Ottawa: Canadian Coordinating Office for Health Technology Assessment (CCOHTA); 1998. RFP #ADHD-1196 http://www.ccohta.ca/main-e.html.
Millichap JG, Johnson FH. Methylphenidate in hyperkinetic behavior: Relation of response to degree of activity and brain damage. In: Conners CK, editor. Clinical use of stimulant drugs in children. Excerpta Medica (Amsterdam). 1974;(1972):130-40.
Mino Y, Ohara H. Methylphenidate and interpersonal relationships of children with attention deficit hyperactivity disorder. Jpn J Psychiatry Neurol. 1991;45(1):45-51. [pmid: 1753489].
Moher D, Dulberg CS, Wells GA. Statistical power, sample size, and their reporting in randomized controlled trials. JAMA. 1994 Jul;272(2):122-4.
Moher D, Jadad AR, Klassen TP. Guides for reading and interpreting systematic reviews: III. How did the authors synthesize the data and make their conclusions?. Arch Pediatr Adolesc Med. 1998 Sep;152(9):915-20.
Moher D, Pham B, Jones A, Cook D, Jadad A, Moher M, Tugwell P, Klassen T. Does quality of reports of randomised trials affect estimates of intervention efficacy reported in meta-analyses?. Lancet. 1998;352:609-13. [pmid: 9746022].
Morkrid L, Qiao ZG, Reichelt KL. Effect of methylphenidate on skin conductance in hyperactive children and its relationship to urinary peptides. J Oslo City Hosp. 1987;37(4):35-40. [pmid: 3598760].
MTA Cooperative Group. 14-month randomized clinical trial of treatment strategies for attention deficit hyperactivity disorder. Multimodal treatment Study of Children with ADHD. Arch Gen Psychiatry. 1999;56(12):1073-86. [pmid: 10591283].
Murphy DA, Pelham WE, Lang AR. Aggression in boys with attention deficit-hyperactivity disorder: Methylphenidate effects on naturalistically observed aggression, response to provocation, and social information processing. J Abnorm Child Psychol. 1992;20(5):451-66. [pmid: 1487590].
Musten LM, Firestone P, Pisterman S, Bennett S, Mercer J. Effects of methylphenidate on preschool children with ADHD: Cognitive and behavioral functions. J Am Acad Child Adolesc Psychiatry. 1997;36(10):1407-15. [pmid: 9334554].
Nemzer ED, Arnold LE, Votolato NA, McConnell H. Amino acid supplementation as therapy for attention deficit disorder. J Am Acad Child Psychiatry. 1986;25(4):509-13. [pmid: 3528266].
Niebuhr VN, Smith LR. The school nurse's role in attention deficit hyperactivity disorder. J School Health. 1993;63(2):112-5. [pmid: 8479160].
Nigg JT, Swanson JM, Hinshaw SP. Covert visual spatial attention in boys with attention deficit hyperactivity disorder: Lateral effects, methylphenidate response and results for parents. Neuropsychologia. 1997;35(2):165-76. [pmid: 9025120].
NIH Consensus Statement Online. Diagnosis and treatment of attention deficit hyperactivity disorder. 1998 Nov 16-18;16(2) http://odp.od.nih.gov/consensus/110/110_intor.htm.
Nolan EE, Gadow KD. Children with ADHD and tic disorder and their classmates: Behavioral normalization with methylphenidate. J Am Acad Child Adolesc Psychiatry. 1997;36(5):597-604. [pmid: 9136493].
Northup J, Jones K, Broussard C, DiGiovanni G, Herring M, Fusilier I, Hanchey A. A preliminary analysis of interactive effects between common classroom contingencies and methylphenidate. J Appl Behav Anal. 1997;30(1):121-5. [pmid: 9157096].
Olvera RL, Pliszka SR, Luh J, Tatum R. An open trial of venlafaxine in the treatment of attention-deficit/hyperactivity disorder in children and adolescents. J Child Adolesc Psychopharmacol. 1996;6(4):241-50. [pmid: 9231317].
Orford E. Commentary: Diagnosis needs tightening. BMJ. 1998;316:1594-6. [pmid: 9596603]. [pmcid: 1113204].
Ortiz deAleman MY, Castanon deMartinez V. [Evaluation of different treatment in minimal brain damage]. (Spa). Neurologia-Neurocirugia-Psiquiatria. 1977;18(1):39-51.
O'Toole K, Abramowitz A, Morris R, Dulcan M. Effects of methylphenidate on attention and nonverbal learning in children with attention-deficit hyperactivity disorder. J Am Acad Child Adolesc Psychiatry. 1997;36(4):531-8. [pmid: 9100428].
Ottenbacher KJ, Cooper HM. Drug treatment of hyperactivity in children. Dev Med Child Neurol. 1983;25(3):358-66. [pmid: 6347775].
Ottinger DR, Halpin B, Miller M, et al. Evaluating drug effectiveness in an office setting for children with attention deficit disorders. Clin Pediatr (Hagerstown). 1985;24(5):245-51. [pmcid: 358331].
Oxman AD, Guyatt GH. Validation of an index of the quality of review articles. J Clin Epidemiol. 1991;44:1271-8. [pmid: 1834807].
Page JG, Bernstein JE, Janicki RS, Michelli FA. A multi-clinic trial of pemoline in childhood hyperkinesis. In: Conners CK, editor. Clinical use of stimulant drugs in children. Excerpta Medica (Amsterdam). )1974;(1972):198-224.
Palmer S, Rapoport JL, Quinn PO. Food additives and hyperactivity. Clin Pediatr. 1975;14(10):956-9.
Parraga HC, Kelly DP, Parraga MI, Cochran MK. Combined psychostimulant and tricyclic antidepressant treatment of Tourette's syndrome and comorbid disorders in children. J Child Adolesc Psychopharmacol. 1994;4(2):113-22.
Pataki CS, Carlson GA, Kelly KL, Rapport MD, Biancaniello TM. Side effects of methylphenidate and desipramine alone and in combination in children. J Am Acad Child Adolesc Psychiatry. 1993;32(5):1065-72. (Same study as Rapport, Carlson, Kelly et al., 1993). [pmid: 8407753].
Payton JB, Burkhart JE, Hersen M, Helsel WJ. Treatment of ADDH in mentally retarded children: A preliminary study. J Am Acad Child Adolesc Psychiatry. 1989;28(5):761-7. [pmid: 2676965].
Pelham WE, Bender ME, Caddell J, Booth S, Moorer SH. Methylphenidate and children with attention deficit disorder. Dose effects on classroom academic and social behavior. Arch Gen Psychiatry. 1985;42(10):948-52. [pmid: 3899046].
Pelham WEJ, Carlson C, Sams SE, Vallano G, Dixon MJ, Hoza B. Separate and combined effects of methylphenidate and behavior modification on boys with attention deficit-hyperactivity disorder in the classroom. J Consult Clin Psychol. 1993;61(3):506-15. [pmid: 8326053].
Pelham WEJ, Greenslade KE, Vodde-Hamilton M, Murphy DA, Greenstein JJ, Gnagy EM, Guthrie KJ, Hoover MD, Dahl RE. Relative efficacy of long-acting stimulants on children with attention deficit-hyperactivity disorder: A comparison of standard methylphenidate, sustained-release methylphenidate, sustained-release dextroamphetamine, and pemoline. Pediatrics. 1990 Aug;86(2):226-37.
Pelham WE, Hoza B, Kipp HL, Gnagy EM, Trane ST. Effects of methylphenidate and expectancy of ADHD children's performance, self-evaluations, persistence, and attributions on a cognitive task. Exp Clin Psychopharmacol. 1997;5(1):3-13. [pmid: 9234034].
Pelham WEJ, McBurnett K, Harper GW, Milich R, Murphy DA, Clinton J, Thiele C. Methylphenidate and baseball playing in ADHD children: Who's on first?. J Consult Clin Psychol. 1990;58(1):130-3. [pmid: 2319047].
Pelham WE, Murphy DA, Vannatta K, Milich R, Licht BG, Gnagy EM, Greenslade KE, Greiner AR, Vodde-Hamilton M. Methylphenidate and attributions in boys with attention-deficit hyperactivity disorder. J Consult Clin Psychol. 1992;60(2):282-92. [pmid: 1592959].
Pelham WEJ, Sturges J, Hoza J, Schmidt C, Bijlsma JJ, Milich R, Moorer S. Sustained release and standard methylphenidate effects on cognitive and social behavior in children with attention deficit disorder. Pediatrics. 1987 Oct;80(4):491-501. [pmcid: 138812].
Pelham WEJ, Swanson JM, Furman MB, Schwindt H. Pemoline effects on children with ADHD: A time-response by dose-response analysis on classroom measures. J Am Acad Child Adolesc Psychiatry. 1995;34(11):1504-13. [pmid: 8543519].
Pelham WEJ, Walker JL, Sturges J, Hoza J. Comparative effects of methylphenidate on ADD girls and ADD boys. J Am Acad Child Adolesc Psychiatry. 1989;28(5):773-6. [pmid: 2676966].
Pfiffner LJ, McBurnett K. Social skills training with parent generalization: Treatment effects for children with attention deficit disorder. J Consult Clin Psychol. 1997;65(5):749-57. [pmid: 9337494].
Pisterman S, Firestone P, McGrath P, Goodman JT, Webster I, Mallory R, Goffin B. The role of parent training in treatment of preschoolers with ADDH. Am J Orthopsychiatry. 1992;62(3):397-408. [pmid: 1497105].
Pisterman S, McGrath P, Firestone P, Goodman JT, Webster I, Mallory R. Outcome of parent-mediated treatment of preschoolers with attention deficit disorder with hyperactivity. J Consult Clin Psychol. 1989;57(5):628-35. [pmid: 2794183].
Pliszka SR. Tricyclic antidepressants in the treatment of children with attention deficit disorder. J Am Acad Child Adolesc Psychiatry. 1987;26(2):127-32. [pmid: 3584008].
Pliszka SR. Effect of anxiety on cognition, behavior, and stimulant response in ADHD. J Am Acad Child Adolesc Psychiatry. 1989;28(6):882-7. [pmid: 2808258].
Pliszka SR. Comorbidity of attention-deficit hyperactivity disorder and overanxious disorder. J Am Acad Child Adolesc Psychiatry. 1992;31:197-203. [pmid: 1564019].
Pliszka SR, Hatch JP, Borcherding SH, Rogeness GA. Classical conditioning in children with attention deficit hyperactivity disorder (ADHD) and anxiety disorders: A test of Quay's model. J Abnorm Child Psychol. 1993;21(4):411-23. [pmid: 8408987].
Porrino LJ, Rapoport JL, Behar D, Ismond DR, Bunney WEJ. A naturalistic assessment of the motor activity of hyperactive boys. II. Stimulant drug effects. Arch Gen Psychiatry. 1983;40(6):688-93. [pmid: 6847336].
Prince JB, Wilens TE, Biederman J, Spencer TJ, Wozniak JR. Clonidine for sleep disturbances associated with attention-deficit hyperactivity disorder: A systematic chart review of 62 cases. J Am Acad Child Adolesc Psychiatry. 1996;35(5):599-605. [pmid: 8935206].
Quinn PO, Rapoport JL. One-year follow-up of hyperactive boys treated with imipramine or methylphenidate. Am J Psychiatry. 1975 Mar;132(3):241-5.
Rapoport JL, Buchsbaum MS, Weingartner H, Zahn TP, Ludlow C, Mikkelsen EJ. Dextroamphetamine. Its cognitive and behavioral effects in normal and hyperactive boys and normal men. Arch Gen Psychiatry. 1980;37(8):933-43. [pmid: 7406657].
Rapoport JL, Quinn PO, Bradbard G, Riddle KD, Brooks E. Imipramine and methylphenidate treatments of hyperactive boys. A double-blind comparison. Arch Gen Psychiatry. 1974;30(6):789-93. [pmid: 4598851].
Rapoport JL, Lott IT, Alexander DF, Abramson AU. Urinary noradrenaline and playroom behaviour in hyperactive boys. Lancet. 1970;2(683).
Rapport MD, DuPaul GJ. Methylphenidate: Rate-dependent effects on hyperactivity. Psychopharmacol Bull. 1986;22(1):223-8. [pmid: 3523577].
Rapport MD, DuPaul GJ. Hyperactivity and methylphenidate: Rate-dependent effects on attention. Int Clin Psychopharmacol. 1986;1(1):45-52. [pmid: 3549871].
Rapport MD, Denney C. Titrating methylphenidate in children with attention-deficit/hyperactivity disorder: Is body mass predictive of clinical response?. J Am Acad Child Adolesc Psychiatry. 1997;36(4):523-30. [pmid: 9100427].
Rapport MD, DuPaul GJ, Smith, NF. Rate-dependency and hyperactivity: Methylphenidate effects on operant responding. Pharmacol Biochem Behav. 1985;23(1):77-83. [pmid: 4034622].
Rapport MD, Carlson GA, Kelly KL, Pataki C. Methylphenidate and desipramine in hospitalized children: I. Separate and combined effects on cognitive function. J Am Acad Child Adolesc Psychiatry. 1993;Mar;32(2):333-42.
Rapport MD, Denney C, DuPaul GJ, Gardner MJ. Attention deficit disorder and methylphenidate: Normalization rates, clinical effectiveness, and response prediction in 76 children. J Am Acad Child Adolesc Psychiatry. 1994;33(6):882-93. [pmid: 8083146].
Rapport MD, DuPaul GJ, Stoner G, Birmingham BK, Masse G. Attention deficit disorder with hyperactivity: Differential effects of methylphenidate on impulsivity. Pediatrics. 1985;76(6):938-43. [pmid: 4069863].
Rapport MD, DuPaul GJ, Stoner G, Jones TJ. Comparing classroom and clinic measures of attention deficit disorder: Differential, idiosyncratic, and dose-response effects of methylphenidate. J Consult Clin Psychol. 1986;54(3):334-41. [pmid: 3522683].
Rapport MD, Jones JT, DuPaul GJ, Kelly KL. Attention deficit disorder and methylphenidate: Group and single-subject analyses of dose effects on attention in clinic and classroom settings. J Clin Child Psychol. 1987;16(4):329-38.
Rapport MD, Loo S, Isaacs P, Goya S, Denney C, Scanlan S. Methylphenidate and attentional training. Comparative effects on behavior and neurocognitive performance in twin girls with attention-deficit/hyperactivity disorder. Behav Modif. 1996;20(4):428-30. [pmid: 8875814].
Rapport MD, Quinn SO, DuPaul GJ, Quinn EP, Kelly KL. Attention deficit disorder with hyperactivity and methylphenidate: The effects of dose and mastery level on children's learning performance. J Abnorm Child Psychol. 1989;17(6):669-89. [pmid: 2607058].
Rapport MD, Stoner G, DuPaul GJ, Birmingham BK, Tucker S. Methylphenidate in hyperactive children: Differential effects of dose on academic, learning, and social behavior. J Abnorm Child Psychol. 1985;13(2):227-43. [pmid: 3891813].
Reimherr FW, Wood DR, Wender PH. An open clinical trial of l-dopa and carbidopa in adults with minimal brain dysfunction. Am J Psychiatry. 1980;137(1):73-5. [pmid: 6986093].
Reimherr FW, Wender PH, Ebert MH, Wood DR. Cerebrospinal fluid homovanillic acid and 5-hydroxy-indoleacetic acid in adults with attention deficit disorder, residual type. Psychiatry Res. 1984 Jan;11(1):71-8.
Reimherr FW, Wender PH, Wood DR, Ward M. An open trial of L-tyrosine in the treatment of attention deficit disorder, residual type. Am J Psychiatry. 1987;144(8):1071-3. [pmid: 3300376].
Richardson E, Kupietz SS, Winsberg BG, Maitinsky S, Mendell N. Effects of methylphenidate dosage in hyperactive reading-disabled children: II. Reading achievement. J Am Acad Child Adolesc Psychiatry. 1988;27(1):78-87. [pmid: 3343210].
Richters JE, Arnold IE, Jensen PS, Abikoff H, Conners CK, Greenhill LL, Hechtman L, Hinshaw SP, Pelham WE, Swanson JM. NIMH Collaborative Multisite Multimodal Treatment Study of children with ADHD: I. Background and rationale. J Am Acad Child Adolesc Psychiatry. 1995 Aug;34(8):987-1000.
Rie HE, Rie ED, Stewart S, Ambuel JP. Effects of methylphenidate on underachieving children. J Consult Clin Psychol. 1976;44(2):250-60. [pmid: 767375].
Riggs PD, Thompson LL, Mikulich SK, Whitmore EA, Crowley TJ. An open trial of pemoline in drug-dependent delinquents with attention-deficit hyperactivity disorder. J Am Acad Child Adolesc Psychiatry. 1996;35(8):1018-24. [pmid: 8755798].
Rose TL. The functional relationship between artificial food colors and hyperactivity. J Appl Behav Anal. 1978;11(4):439-46. [pmid: 365851].
Rossel E. [Attention in hyperkinetic children: A signal detection analysis of the effect of methylphenidate]. (Ger]. Z Kinder Jugenpsychiatr. 1987;15(1):6-17. [pmid: 3554818].
Rowe KS. Synthetic food colourings and#147;hyperactivity": A double-blind crossover study. Aust Paediatr J. 1988;24(2):143-7. [pmid: 3395307].
Rumain B. Efficacy of behavior management versus methylphenidate in a hyperactive child: The role of dynamics. Am J Orthopsychiatry. 1988;58(3):466-9. [pmid: 3407738].
Sackett DL, Richardson WS, Rosenberg W, Haynes RB. Evidence-based medicine: How to practice and teach EBM. New York: Churchill Livingstone; 1997.
Safer DJ, Allen RP. Absence and tolerance to the behavioral effects of methylphenidate in hyperactive and inattentive children. J Pediatr. 1989;115(6):1003-8. [pmid: 2585214].
Safer D, Krager JM. Hyperactivity and inattentiveness. School assessment of stimulant treatment. Clin Pediatr. 1989;28(5):216-21.
Safer D, Allen R, Barr E. Depression of growth in hyperactive children on stimulant drugs. N Eng J Med. 1972;287(5):217-20.
Saletu B, Saletu M, Simeon J, Viamontes G, Itil TM. Comparative symptomatological and evoked potential studies with d-amphetamine, thioridazine, and placebo in hyperkinetic children. Biol Psychiatry. 1975;10(3):253-75. [pmid: 1095081].
Sallee FR, Stiller RL, Perel JM. Pharmacodynamics of pemoline in attention deficit disorder with hyperactivity. J Am Acad Child Adolesc Psychiatry. 1992;31(2):244-51. [pmid: 1564025].
Sangal JM, Sangal RB, Persky B. Prolonged P300 latency in attention deficit hyperactivity disorder predicts poor response to imipramine. Clin Electroencephalogr. 1996;27(3):191-201. [pmid: 9465283].
Satterfield JH, Satterfield BT, Cantwell DP. Three-year multimodality treatment study of 100 hyperactive boys. J Pediatr. 1981;98(4):650-61. [pmid: 7205499].
Satterfield JH, Lesser LI, Saul RE, Cantwell DP. EEG aspects in the diagnosis and treatment of minimal brain dysfunction. Ann NY Acad Sci. 1973;205:274-82. [pmid: 4511281].
Schachar R, Tannock R. Childhood hyperactivity and psychostimulants: A review of extended treatment studies. J Child Adolesc Psychopharmacol. 1993;3(2):81-97. [pmid: 19630640].
Schachar RJ, Tannock R, Cunningham C, Corkum PV. Behavioral, situational, and temporal effects of treatment of ADHD with methylphenidate. J Am Acad Child Adolesc Psychiatry. 1997 Jun;36(6):754-63.
Schain RJ, Reynard CL. Observations on effects of a central stimulant drug (methylphenidate) in children with hyperactive behavior. Pediatrics. 1975;55(5):709-16. [pmid: 1093108].
Schaub JS. Hyposensitisation in children with food-induced hyperkinetic syndrome [news]. Eur J Pediatr. 1992;151(11):864-5. [pmid: 1468466].
Schechter MD, Timmons GD. Objectively measured hyperactivity-II. Caffeine and amphetamine effects. J Clin Pharmacology. 1985 May;25(4):276-80.
Schell RM, Pelham WE, Bender ME, Andree JA. The concurrent assessment of behavioral and psychostimulant interventions: A controlled case study. Behav Assess. 1986;8(4):373-84.
Schleifer M, Weiss G, Cohen N, Elman M, Cvejic H, Kruger E. Hyperactivity in preschoolers and the effect of methylphenidate. Am J Orthopsychiatry. 1975;45(1):38-50. [pmid: 1089359].
Schmidt MH, Mocks P, Lay B, Eisert HG, Fojkar R, Fritz SD, Marcus A, Musaeus B. Does oligoantigenic diet influence hyperactive/conduct-disordered children-A controlled trial. Eur Child Adolesc Psychiatry. 1997;6(2):88-95. [pmid: 9257090].
Schroeder JS, Mullin AV, Elliott GR, Steiner H, Nichols M, Gordon A, Paulos M. Cardiovascular effects of desipramine in children [see comments]. J Am Acad Child Adolesc Psychiatry. 1989;28(3):376-9. [pmid: 2661525].
Schulte-Korne G, Deimel W, Gutenbrunner C, Hennighausen K, Blank R, Rieger C, Remschmidt H. [Effect of an oligo-antigen diet on the behavior of hyperkinetic children]. (Ger). Z Kinder Jugenpsychiatr. 1996;24(3):176-83.
Schultz FR, Hayford JT, Wolraich ML, Hintz RL, Thompson RG. Methylphenidate treatment of hyperactive children: Effects on the hypothalamic-pituitary-somatomedin axis. Pediatrics. 1982;70(6):987-92. [pmcid: 65040]. [pmid: 7145556].
Schulz KF, Chalmers I, Hayes RJ, Altman DG. Empirical evidence of bias: Dimensions of methodological quality associated with estimates of treatment effects in controlled trials. JAMA. 1995;273(5):408-12. [pmid: 7823387].
Schvehla TJ, Mandoki MW, Sumner GS. Clonidine therapy for comorbid attention deficit hyperactivity disorder and conduct disorder: Preliminary findings in a children's inpatient unit. South Med J. 1994;87(7):692-5. [pmid: 8023201].
Schweitzer JB, Sulzer-Azaroff B. Self-control in boys with attention deficit hyperactivity disorder: Effects of added stimulation and time. J Child Psychol Psychiatry. 1995;36(4):671-86. [pmid: 7650090].
Sebrechts MM, Shaywitz SE, Shaywitz BA, Jatlow P, Anderson GM, Cohen DJ. Components of attention, methylphenidate dosage, and blood levels in children with attention deficit disorder. Pediatrics. 1986;77(2):222-8. [pmcid: 116575]. [pmid: 3945535].
Sever Y, Ashkenazi A, Tyano S, Weizman A. Iron treatment in children with attention deficit hyperactivity disorder. A preliminary report. Neuropsychobiology. 1997;35(4):178-80.
Shafto F, Sulzbacher S. Comparing treatment tactics with a hyperactive preschool child: Stimulant medication and programmed teacher intervention. J Appl Behav Anal. 1977;10(1):13-20. [pmid: 845097].
Shaywitz BA, Sullivan CM, Anderson GM, Gillespie SM, Sullivan B, Shaywitz SE. Aspartame, behavior, and cognitive function in children with attention deficit disorder [see comments]. Pediatrics. 1994;93(1):70-5. [pmid: 7505423].
Shaywitz BA, Shaywitz SE, Sebrechts MM, Anderson GM, Cohen DJ, Jatlow P, Young JG. Growth hormone and prolactin response to methylphenidate in children with attention deficit disorder. Life Sci. 1990;46(9):625-33. [pmid: 2308471].
Shekim WO, Bylund DB, Hodges K, Glaser R, Ray-Prenger C, Oetting G. Platelet alpha 2-adrenergic receptor binding and the effects of d-amphetamine in boys with attention deficit hyperactivity disorder. Neuropsychobiology. 1994;29(3):120-4. [pmid: 8022532].
Shekim WO, Davis LG, Bylund DB, et al. Platelet MAO in children with attention deficit disorder and hyperactivity: A pilot study. Am J Psychiatry. 1982;139(7):936-8. [pmid: 7091414].
Shekim WO, Masterson A, Cantwell DP, Hanna GL, McCracken JT. Nomifensine maleate in adult attention deficit disorder. J Nerv Ment Dis. 1989;177(5):296-9. [pmid: 2651559].
Shevell M, Schreiber R. Pemoline-associated hepatic failure: A critical analysis of the literature. Pediatr Neurol. 1997 Jan;16(1):14-6.
Silva RR, Munoz DM, Alpert M. Carbamazepine use in children and adolescents with features of attention-deficit hyperactivity disorder: A meta-analysis. J Am Acad Child Adolesc Psychiatry. 1996 Mar;35(3):352-8.
Silverstein JM, Allison DB. The comparative efficacy of antecedent exercise and methylphenidate: A single-case randomized trial. Child Care Health Dev. 1994;20(1):47-60. [pmid: 8149503].
Simeon JG, Ferguson HB, Van Wyck FJ. Bupropion effects in attention deficit and conduct disorders. Can J Psychiatry. 1986;31(6):581-5. [pmid: 3093046].
Simerzin VV. [Obsidan treatment of neuroendocrine disorders and hyperkinetic syndrome in patients with macrofocal myocardial infarction]. (Rus). Klin Med. 1989;67(1):84-7.
Singer HS, Brown J, Quaskey S, Rosenberg LA, Mellits ED, Denckla MB. The treatment of attention-deficit hyperactivity disorder in Tourette's syndrome: A double-blind placebo-controlled study with clonidine and desipramine. Pediatrics. 1995 Jan;95(1):74-81. [pmcid: 161813].
Sleator EK, von Neumann A, Sprague RL. Hyperactive children. A continuous long-term placebo-controlled follow-up. JAMA. 1974;229(3):316-7. [pmid: 4600587].
Solanto MV. Behavioral effects of low-dose methylphenidate in childhood attention deficit disorder: Implications for a mechanism of stimulant drug action. J Am Acad Child Psychiatry. 1986;25(1):96-101. [pmid: 3950273].
Solanto MV. The effects of reinforcement and response-cost on a delayed response task in children with attention deficit hyperactivity disorder: A research note. J Child Psychol Psychiatry. 1990;31(5):803-8. [pmid: 2398122].
Solanto MV, Wender EH. Does methylphenidate constrict cognitive functioning? [published erratum appears in J Am Acad Child Adolesc Psychiatry 1990 Jan; 29(1): 156]. J Am Acad Child Adolesc Psychiatry. 1989;28(6):897-902. [pmid: 2808260].
Solanto MV, Wender EH, Bartell SS. Effects of methylphenidate and behavioral contingencies on sustained attention in attention-deficit hyperactivity disorder: A test of the reward dysfunction hypothesis. J Child Adolesc Psychoparmacol. 1997;7(2):123-36.
Spencer T, Biederman J, Wright V, Danon M. Growth deficits in children treated with desipramine: A controlled study [see comments]. J Am Acad Child Adolesc Psychiatry. 1992;31(2):235-43. [pmid: 1564024].
Spencer T, Biederman J, Wilens T, Harding M, O'Donnell D, Griffin S. Pharmacotherapy of attention-deficit hyperactivity disorder across the life cycle. J Am Acad Child Adolesc Psychiatry. 1996 Apr;35(4):409-32.
Spencer TJ, Biederman J, Harding M, O'Donnell D, Faraone SV, Wilens TE. Growth deficits in ADHD children revisited: Evidence for disorder-associated growth delays?. J Am Acad Child Adolesc Psychiatry. 1996;35(11):1460-9. [pmid: 8936912].
Spencer T, Wilens T, Biederman J, Faraone SV, Ablon JS, Lapey K. A double-blind, crossover comparison of methylphenidate and placebo in adults with childhood-onset attention-deficit hyperactivity disorder. Arch Gen Psychiatry. 1995 Jun;52(6):434-43.
Spiga R, Pearson DA, Broitman M, Santos CW. Effects of methylphenidate on cooperative responding in children with attention deficit-hyperactivity disorder. Exp Clin Psychopharmacol. 1996;4(4):451-8.
Sprafkin J, Gadow KD. Double-blind versus open evaluations of stimulant drug response in children with attention-deficit hyperactivity disorder. J Child Adolesc Psychopharmacol. 1996;6(4):215-28. [pmid: 9231315].
Spring C, Yellin AM, Greenberg L. Effects of imipramine and methylphenidate on perceptual-motor performance of hyperactive children. Percept Mot Skills. 1976 Oct;42(43):459-70.
Srinivas NR, Hubbard JW, Quinn D, Midha KK. Enantioselective pharmacokinetics and pharmacodynamics of dl-threo-methylphenidate in children with attention deficit hyperactivity disorder. Clin Pharmacol Ther. 1992 Nov;52(5):561-8.
Stein MA, Blondis TA, Schnitzler ER, O'Brien T, Fishkin J, Blackwell B, Szumowski E, Roizen NJ. Methylphenidate dosing: Twice daily versus three times daily. Pediatrics. 1996 Oct;98(4 Pt 1):748-56.
Stein MA, Krasowski M, Leventhal BL, Phillips W, Bender BG. Behavioral and cognitive effects of methylxanthines. A meta-analysis of theophylline and caffeine. Arch Pediatr Adolesc Med. 1996 Mar;150(3):284-8.
Steingard R, Biederman J, Spencer T, Wilens T, Gonzalez A. Comparison of clonidine response in the treatment of attention-deficit hyperactivity disorder with and without comorbid tic disorders. J Am Acad Child Adolesc Psychiatry. 1993;32(2):350-3. [pmid: 8444764].
Steinhausen HC. The hyperkinetic syndrome: Multidimensional diagnosis, assessment of treatment effectiveness and course of outpatient treatment. Z Kinder Jugend Psychiatr. 1980;8(3):269-87.
Stephens RS, Pelham WE, Skinner R. State-dependent and main effects of methylphenidate and pemoline on paired-associate learning and spelling in hyperactive children. J Consult Clin Psychol. 1984;52(1):104-13. [pmid: 6699239].
Stoner G, Carey SP, Ikeda MJ, Shinn MR. The utility of curriculum-based measurement for evaluating the effects of methylphenidate on academic performance. J Appl Behav Anal. 1994;27(1):101-13. [pmid: 8188554].
Strayhorn JM, Weidman CS. Reduction of attention deficit and internalizing symptoms in preschoolers through parent-child interaction training [published erratum appears in J Am Acad Child Adolesc Psychiatry 1990 Mar;29(2):314]. J Am Acad Child Adolesc Psychiatry. 1989;28(6):888-96. [pmid: 2808259].
Strayhorn JM, Weidman CS. Follow-up one year after parent-child interaction training: Effects on behavior of preschool children. J Am Acad Child Adolesc Psychiatry. 1991;30(1):138-43. [pmid: 2005049].
Suffin SC, Emory WH. Neurometric subgroups in attentional and affective disorders and their association with pharmacotherapeutic outcome. Clin Electroencephalogr. 1995;26(2):76-83. [pmid: 7781194].
Sunohara GA, Voros JG, Malone MA, Taylor MJ. Effects of methylphenidate in children with attention deficit hyperactivity disorder: A comparison of event-related potentials between medication responders and non-responders. Int J Psychophysiol. 1997;27(1):9-14. [pmid: 9161888].
Sverd J, Gadow KD, Paolicelli LM. Methylphenidate treatment of attention-deficit hyperactivity disorder in boys with Tourette's syndrome. J Am Acad Child Adolesc Psychiatry. 1989;28(4):574-9. [pmid: 2768152].
Swanson J, Kinsbourne M, Roberts W, Zucker K. Time-response analysis of the effect of stimulant medication on the learning ability of children referred for hyperactivity. Pediatrics. 1978;61(1):21-9. [pmcid: 449715]. [pmid: 400817].
Swanson JM, McBurnett K, Wigal T, Pfiffner LJ, Lerner MA, Williams L, Christian DL, Tamm L, Willcutt E, Crowley K, Clevenger W, Khouzam N, Woo C, Crinella FM. Effect of stimulant medication on children with attention deficit disorder: A "review of reviews.". Except Child. 1993;60(2):154-62.
Swanson JM, Sandman CA, Deutsch C, Baren M. Methylphenidate hydrochloride given with or before breakfast: I. Behavioral, cognitive, and electrophysiologic effects. Pediatrics. 1983;72(1):49-55. [pmcid: 155650]. [pmid: 6866591].
Sykes DH, Douglas VI, Morgenstern G. The effect of methylphenidate (ritalin) on sustained attention in hyperactive children. Psychopharmacologia. 1972;25(3):262-74. [pmid: 4557941].
Sykes DH, Douglas VI, Weiss G, Minde KK. Attention in hyperactive children and the effect of methylphenidate (ritalin). J Child Psychol Psychiatry. 1971;12(2):129-39. [pmid: 4935554].
Syrigou-Papavasiliou A, Lycaki H, LeWitt PA, Verma NP, Spivak D, Chayasirisobhon S. Dose-response effects of chronic methylphenidate administration on late event-related potentials in attention deficit disorder. Clin Electroencephalogr. 1988;19(3):129-33. [pmid: 3416497].
Szatmari P, Offord DR, Boyle MH. Ontario Child Health Study: Prevalence of attention deficit disorder with hyperactivity. J Child Psychol Psychiatry. 1989;30:219-30. [pmid: 2708462].
Tannock R, Schachar R. Methylphenidate and cognitive perseveration in hyperactive children. J Child Psychol Psychiatry. 1992;33(7):1217-28. [pmid: 1400703].
Tannock R, Ickowicz A, Schachar R. Differential effects of methylphenidate on working memory in ADHD children with and without comorbid anxiety. J Am Acad Child Adolesc Psychiatry. 1995;34(7):886-96. [pmid: 7649959].
Tannock R, Schachar R, Logan G. Methylphenidate and cognitive flexibility: Dissociated dose effects in hyperactive children. J Abnorm Child Psychol. 1995;23(2):235-66. [pmid: 7642836].
Tannock R, Fine J, Heintz T, Schachar RJ. A linguistic approach detects stimulant effects in two children with attention-deficit hyperactivity disorder. J Child Adolesc Psychopharmacol. 1995;5(3):177-89.
Tannock R, Schachar RJ, Carr RP, Logan GD. Dose-response effects of methylphenidate on academic performance and overt behavior in hyperactive children. Pediatrics. 1989;84(4):648-57. [pmid: 2780127].
Tannock R, Schachar RJ, Carr RP, Chajczyk D, Logan GD. Effects of methylphenidate on inhibitory control in hyperactive children [published erratum appears in J Abnorm Child Psychol 1990 Feb;18(1):119]. J Abnorm Child Psychol. 1989;17(5):473-91. [pmid: 2681316].
Tao KT. Hyperactivity and attention deficit disorder syndromes in China. J Am Acad Child Adolesc Psychiatry. 1992;31(6):1165-6. [pmid: 1429422].
Taylor E, Hemsley R. Treating hyperkinetic disorders in childhood. BMJ. 1995;310:1617-8. [pmid: 7795435].
Taylor MJ, Voros JG, Logan WJ, Malone MA. Changes in event-related potentials with stimulant medication in children with attention deficit hyperactivity disorder. Biol Psychol. 1993;36(3):139-56. [pmid: 8260563].
Tellechea N, Guardiola A, Barros HT, Hibig A. Efficacy of imipramine in children with attention deficit hyperactivity disorder. Int Pediatr. 1991;6(4):343-6.
Thurber S, Walker CE. Medication and hyperactivity: A meta-analysis. J Gen Psychol. 1983 Jan;108(1st half):79-86.
Thurston LP. Comparison of the effects of parent training and of ritalin in treating hyperactive children. Int J Ment Health. 1979;8(1):121-8.
Tirosh E, Elhasid R, Kamah SC, Cohen A. Predictive value of placebo methylphenidate. Pediatr Neurol. 1993;9(2):131-33. [pmid: 8499043].
Tirosh E, Sadeh A, Munvez R, Lavie P Effects of methylphenidate on sleep in children with attention-deficient hyperactivity disorder. An activity monitor study Am J Dis Child 1993 147(12) 1313 5View this and related citations using 8249952
Tiwary CM, Rosenbloom AL, Robertson MF, Parker JC. Effects of thyrotropin-releasing hormone in minimal brain dysfunction. Pediatrics. 1975;56(1):119-21. [pmcid: 449715]. [pmid: 808786].
Tomkins CP, Soldin SJ, Macleod SM, Rochefort JG, Swanson JM. Analysis of pemoline in serum by high performance liquid chromatography: Clinical application to optimize treatment of hyperactive children. Ther Drug Monit. 1980;2(3):255-60. [pmid: 7222180].
Toren P, Eldar S, Sela BA, Wolmer L, Weitz R, Inbar D, Koren S, Reiss A, Weizman R, Laor N. Zinc deficiency in attention-deficit hyperactivity disorder. Biol Psychiatry. 1996;40(12):1308-10. [pmid: 8959299].
Toren P, Silbergeld A, Eldar S, Laor N, Wolmer L, Koren S, Weitz R, Inbar D, Reiss A, Eshet R, Weizman R. Lack of effect of methylphenidate on serum growth hormone (GH):GH- binding protein, and insulin-like growth factor I. Clin Neuropharmacol. 1997;20(3):264-9. [pmid: 9197950].
Trommer BL, Hoeppner JA, Zecker SG. The go-no go test in attention deficit disorder is sensitive to methylphenidate. J Child Neurol. 1991;6(Suppl):S128-S131. [pmid: 2002211].
Trott GE, Menzel M, Friese HJ, Nissen G. [Effectiveness and tolerance of the selective MAO-A inhibitor moclobemide in children with hyperkinetic syndrome]. (Ger). Z Kinder Jugenpsychiatr. 1991;19(4):248-53. [pmid: 1812674].
Ullmann RK, Sleator EK. Responders, nonresponders, and placebo responders among children with attention deficit disorder. Importance of a blinded placebo evaluation. Clin Pediatr. 1986;25(12):594-9.
Urman R, Ickowicz A, Fulford P, Tannock R. An exaggerated cardiovascular response to methylphenidate in ADHD children with anxiety. J Child Adolesc Psychopharmacol. 1995;5(1):29-37.
Valentine J, Zubrick S, Sly, P. National trends in the use of stimulant medication for attention deficit hyperactivity disorder. J Paediatr Child Health. 1996;32(3):223-7. [pmid: 8827539].
Varley CK. Effects of methylphenidate in adolescents with attention deficit disorder. J Am Acad Child Psychiatry. 1983;22(4):351-4. [pmid: 6875130].
Varley CK, Trupin EW. Double-blind assessment of stimulant medication for attention deficit disorder: A model for clinical application. Am J Orthopsychiatry. 1983;53(3):542-47. [pmid: 6349375].
Verbaten MN, Overtoom CC, Koelega HS, Swaab-Barneveld H, van der Gaag RJ, Buitelaar J, van Engeland H. Methylphenidate influences on both early and late ERP waves of ADHD children in a continuous performance test. J Abnorm Child Psychol. 1994;22(5):561-78. [pmid: 7822629].
Vitiello B, Hill JL, Elia J, Cunningham E, McLeer SV, Behar D. P.r.n. medications in child psychiatric patients: A pilot placebo-controlled study. J Clin Psychiatry. 1991;52(12):499-501. [pmid: 1752851].
Vyborova L, Nahunek K, Drtilkova I, Misurec J, Slama B. A controlled study of lisurid in hyperactive children. Activitas Nervosa Superior. 1978;20(1):86-7. [pmid: 345719].
Vyborova L, Nahunek K, Drtilkova I, Balastikova B. Oxyprothepin and clorotepin compared in the hyperkinetic syndrome. Activitas Nervosa Superior. 1989;31(1):45-6. [pmid: 2571227].
Vyborova L, Nahunek K, Misurec J, et al. Comparison of amphetaminil and methylphenidate in the treatment of hyperkinetic syndrome in children. Activitas Nervosa Superior. 1984;26(1).
Vyse SA, Rapport MD. The effects of methylphenidate on learning in children with ADDH: The stimulus equivalence paradigm. J Consult Clin Psychol. 1989;57(3):425-35. [pmid: 2661612].
Waizer J, Hoffman SP, Polizos P, Engelhardt DM. Outpatient treatment of hyperactive school children with imipramine. Am J Psychiatry. 1974;131(5):587-91. [pmid: 4594559].
Waldrop RD. Selection of patients for management of attention deficit hyperactivity disorder in a private practice setting. Clin Pediatr. 1994;33(2):83-7.
Wallace AE, Kofoed LL. Statistical analysis of single case studies in the clinical setting: The example of methylphenidate trials in children with attention-deficit hyperactivity disorder. J Child Adolesc Psychopharmacol. 1994;4(3):141-50.
Wallander JL, Schroeder SR, Michelli JA, Gualtieri CT. Classroom social interactions of attention deficit disorder with hyperactivity children as a function of stimulant medication. J Pediatric Psychol. 1987;12(1):61-76.
Walters A, Singh N, Beale IL. Effects of lorazepam on hyperactivity in retarded children. N Z Med J. 1977;86(600):473-5. [pmid: 24194].
Weinberg WA, Brumback RA. The myth of attention-deficit-hyperactivity disorder: Symptoms resulting from multiple causes. J Child Neurology. 1992;7:431-45.
Weiss G, Kruger E, Danielson U, Elman M. Effect of long-term treatment of hyperactive children with methylphenidate. Can Med Assoc J. 1975;112(2):159-65. [pmid: 803405].
Weiss G, Minde K, Douglas V, Werry J, Sykes D. Comparison of the effects of chlorpromazine, dextroamphetamine and methylphenidate on the behaviour and intellectual functioning of hyperactive children. Can Med Assoc J. 1971;104(1):20-5. [pmid: 5540117].
Weiss G, Werry J, Minde K, Douglas V, Sykes D. Studies on the hyperactive child. V. The effects of dextroamphetamine and chlorpromazine on behaviour and intellectual functioning. J Child Psychol Psychiatry. 1968;9(3):145-56. [pmid: 4893343].
Weiss RE, Stein MA, Refetoff S. Behavioral effects of liothyronine (L-T3) in children with attention deficit hyperactivity disorder in the presence and absence of resistance to thyroid hormone. Thyroid. 1997;7(3):389-93. [pmid: 9226208].
Weizman A, Weitz R, Szekely GA, et al. Combination of neuroleptic and stimulant treatment in attention deficit disorder with hyperactivity. J Am Acad Child Psychiatry. 1984;23(3):295-8. [pmid: 6145738].
Wender EH, Solanto MV. Effects of sugar on aggressive and inattentive behavior in children with attention deficit disorder with hyperactivity and normal children. Pediatrics. 1991;88(5):960-6. [pmid: 1945637].
Wender PH, Reimherr FW. Bupropion treatment of attention-deficit hyperactivity disorder in adults. Am J Psychiatry. 1990;147(8):1018-20. [pmid: 2115746].
Wender PH, Reimherr FW, Wood DR. Attention deficit disorder ("minimal brain dysfunction") in adults. A replication study of diagnosis and drug treatment. Arch Gen Psychiatry. 1981 Apr;38(4):449-56.
Wender PH, Wood DR, Reimherr FW, Ward M. An open trial of pargyline in the treatment of attention deficit disorder, residual type. Psychiatry Res. 1983;9(4):329-36. [pmid: 6359210].
Wender PH, Reimherr FW, Wood D, Ward M. A controlled study of methylphenidate in the treatment of attention deficit disorder, residual type, in adults. Am J Psychiatry. 1985 May;142(5):547-52.
Werry JS, Aman MG. Methylphenidate and haloperidol in children. Effects on attention, memory, and activity. Arch Gen Psychiatry. 1975;32(6):790-5. [pmid: 1093506].
Werry JS, Aman MG, Diamond E. Imipramine and methylphenidate in hyperactive children. J Child Psychol Psychiatry. 1980 Jan;21(1):27-35.
Werry JS, Aman MG, Lampen E. Haloperidol and methylphenidate in hyperactive children. Acta Paedopsychiatr. 1976;42(1):26-40. [pmid: 775883].
Werry JS, Biederman J, Thisted R, Greenhill L, Ryan N. Resolved: Cardiac arrhythmias make desipramine an unacceptable choice in children. J Am Acad Child Adolesc Psychiatry. 1995;34(9):1239-48. [pmid: 7559320].
West SA, Strakowski SM, Sax KW, Minnery KL, McElroy SL, Keck Jr. The comorbidity of attention-deficit hyperactivity disorder in adolescent mania: Potential diagnostic and treatment implications. Psychopharmacol Bull. 1995;31(2):347-51. [pmid: 7491390].
Whalen CK, Henker B, Granger DA. Social judgment processes in hyperactive boys: Effects of methylphenidate and comparisons with normal peers. J Abnorm Child Psychol. 1990;18(3):297-316. [pmid: 2198308].
Whalen CK, Henker B, Buhrmester D, Hinshaw SP, Huber A, Laski K. Does stimulant medication improve the peer status of hyperactive children?. J Consult Clin Psychol. 1989;57(4):545-9. [pmid: 2768616].
Whalen CK, Henker B, Collins BE, McAuliffe S, Vaux A. Peer interaction in a structured communication task: Comparisons of normal and hyperactive boys and of methylphenidate (Ritalin) and placebo effects. Child Dev. 1979;50(2):388-401. [pmid: 487880].
Whalen CK, Henker B, Hinshaw SP, Heller T, Huber-Dressler A. Messages of medication: Effects of actual versus informed medication status on hyperactive boys' expectancies and self-evaluations. J Consult Clin Psychol. 1991;59(4):602-6. [pmid: 1918565].
Whalen CK, Henker B, Swanson JM, Granger D, Kliewer W, Spencer J. Natural social behaviors in hyperactive children: Dose effects of methylphenidate. J Consult Clin Psychol. 1987;55(2):187-93. [pmid: 3571671].
Whitehead PL, Clark LD. Effect of lithium carbonate, placebo, and thioridazine on hyperactive children. Am J Psychiatry. 1970;127(6):824-5. [pmid: 5482878].
Whitehouse D, Shah U, Palmer FB. Comparison of sustained-release and standard methylphenidate in the treatment of minimal brain dysfunction. J Clin Psychiatry. 1980 Aug;41(8):282-5.
Wilens TE, Biederman J. The stimulants. Psychiatr Clin North Am. 1992;15(1):191-222. [pmid: 1347939].
Wilens TE, Biederman J, Baldessarini RJ, McDermott SP, Puopolo PR, Flood JG. Fluoxetine inhibits desipramine metabolism [2]. Arch Gen Psychiatry. 1992;49(9).
Wilens TE, Biederman J, Abrantes AM, Spencer TJ. A naturalistic assessment of protriptyline for attention-deficit hyperactivity disorder. J Am Acad Child Adolesc Psychiatry. 1996;35(11):1485-90. [pmid: 8936915].
Wilens TE, Biederman J, Geist DE, Steingard R, Spencer T. Nortriptyline in the treatment of ADHD: A chart review of 58 cases. J Am Acad Child Adolesc Psychiatry. 1993;32(2):343-9. [pmid: 8444763].
Wilens TE, Biederman J, Prince J, Spencer TJ, Faraone SV, Warburton R, Schleifer D, Harding M, Linehan C, Geller D. Six-week, double-blind, placebo-controlled study of desipramine for adult attention deficit hyperactivity disorder. Am J Psychiatry. 1996;153(9):1147-53. [pmid: 8780417].
Wilens TE, Biederman J, Spencer TJ, Prince J. Pharmacotherapy of adult attention deficit/hyperactivity disorder: A review. J Clin Psychopharmacol. 1995;15(4):270-9. [pmid: 7593710].
Wilkison PC, Kircher JC, McMahon WM, Sloane HN. Effects of methylphenidate on reward strength in boys with attention-deficit hyperactivity disorder. J Am Acad Child Adolesc Psychiatry. 1995;34(7):897-901. [pmid: 7649960].
Williams JI, Cram DM, Tausig FT, Webster E. Relative effects of drugs and diet on hyperactive behaviors: An experimental study. Pediatrics. 1978;61(6):811-7. [pmcid: 449715]. [pmid: 353680].
Winsberg BG, Javitt DC, Silipo GS, Doneshka P. Mismatch negativity in hyperactive children: Effects of methylphenidate. Psychopharmacol Bull. 1993;29(2):229-33. [pmid: 8290670].
Winsberg BG, Kupietz SS, Yepes LE, Goldstein S. Ineffectiveness of imipramine in children who fail to respond to methylphenidate. J Autism Dev Disord. 1980 Jun;10(2):129-37.
Winsberg BG, Press M, Bialer I, Kupietz S. Dextroamphetamine and methylphenidate in the treatment of hyperactive-aggressive children. Pediatrics. 1974 Feb;53(2):236-41. [pmcid: 126268].
Wolraich, ML. Stimulant drug therapy in hyperactive children: Research and clinical implications. Pediatrics. 1977;60(4):512-8. [pmcid: 343283]. [pmid: 333368].
Wolraich M. Assessing response to methylphenidate for attention deficit disorder [letter; comment]. J Pediatr. 1989;114(5):902-3. [pmid: 2715907].
Wolraich M, Drummond T, Salomon MK, O'Brien ML, Sivage C. Effects of methylphenidate alone and in combination with behavior modification procedures on the behavior and academic performance of hyperactive children. J Abnorm Child Psychol. 1978;6(1):149-61. [pmid: 632455].
Wolraich ML, Hannah JN, Pinnock TY, Baumgaertel A, Brown J. Comparison of diagnostic criteria for attention-deficit hyperactivity disorder in a county-wide sample. J Am Acad Child Adolesc Psychiatry. 1996;35:319-24. [pmid: 8714320].
Wolraich ML, Lindgren S, Stromquist A, Milich R, Davis C, Watson D. Stimulant medication use by primary care physicians in the treatment of attention deficit hyperactivity disorder. Pediatrics. 1990;86(1):95-101. [pmid: 2359688].
Wolraich M, Milich R, Stumbo P, Schultz F. Effects of sucrose ingestion on the behavior of hyperactive boys. J Pediatr. 1985;106(4):675-82. [pmid: 3981325].
Wood DR, Reimherr FW, Wender PH. Amino acid precursors for the treatment of attention deficit disorder, residual type. Psychopharmacol Bull. 1985;21(1):146-9. [pmid: 3885291].
Wood DR, Reimherr FW, Wender PH. Treatment of attention deficit disorder with dl-phenylalanine. Psychiatry Res. 1985 Sep;16(1):21-6.
Wood DR, Reimherr FW, Wender PH, Johnson GE. Diagnosis and treatment of minimal brain dysfunction in adults: A preliminary report. Arch Gen Psychiatry. 1976;33(12):1453-60. [pmid: 793563].
Wulbert M, Dries R. The relative efficacy of methylphenidate (ritalin) and behavior-modification techniques in the treatment of a hyperactive child. J Appl Behav Anal. 1977;10(1):21-31. [pmid: 321410].
Yates A, Gray F, Beutler LE, Sherman DE, Segerstrom EM. Effect of negative air ionization on hyperactive and autistic children. Am J Phys Med. 1987;66(5):264-8. [pmid: 3434628].
Yellin AM, Greenberg LM. Attention-deficit disorder. Monitored data-based assessment and treatment. Minn Med. 1981;64(8):487-90. [pmid: 7290045].
Yellin AM, Hopwood JH, Greenberg LM. Adults and adolescents with attention deficit disorder: Clinical and behavioral responses to psychostimulants. J Clin Psychopharmacol. 1982;2(2):133-6. [pmid: 7076878].
Young ES, Perros P, Price GW, Sadler T. Acute challenge ERP as a prognostic of stimulant therapy outcome in attention-deficit hyperactivity disorder. Biol Psychiatry. 1995;37(1):25-33. [pmid: 7893855].
Zahn TP, Rapoport JL, Thompson CL. Autonomic and behavioral effects of dextroamphetamine and placebo in normal and hyperactive prepubertal boys. J Abnorm Child Psychol. 1980;8(2):145-60. [pmid: 6995513].
Zametkin AJ, Karoum F, Rapoport JL. Treatment of hyperactive children with d-phenylalanine. Am J Psychiatry. 1987;144(6):792-4. [pmid: 3296793].
Zametkin AJ, Brown GL, Karoum F, Rapoport JL, Langer DH, Chuang LW, Wyatt RJ. Urinary phenethylamine response to d-amphetamine in 12 boys with attention deficit disorder. Am J Psychiatry. 1984;141(9):1055-8. [pmid: 6380319].
Zametkin AJ, Karoum F, Linnoila M, Rapoport JL, Brown GL, Chuang LW, Wyatt RJ. Stimulants, urinary catecholamines, and indoleamines in hyperactivity. A comparison of methylphenidate and dextroamphetamine. Arch Gen Psychiatry. 1985;42(3):251-5. [pmid: 2579615].
Zametkin A, Rapoport JL, Murphy DL, Linnoila M, Ismond D. Treatment of hyperactive children with monoamine oxidase inhibitors. I. Clinical efficacy. Arch Gen Psychiatry. 1985;42(10):962-6. [pmid: 3899047].
Zametkin A, Rapoport JL, Murphy DL, Linnoila M, Karoum F, Potter WZ, Ismond D. Treatment of hyperactive children with monoamine oxidase inhibitors. II. Plasma and urinary monoamine findings after treatment. Arch Gen Psychiatry. 1985;42(10):969-73. [pmid: 2412521].
Zametkin AJ, Reeves JC, Webster L, Werry JS. Promethazine treatment of children with attention deficit disorder with hyperactivity-ineffective and unpleasant. J Am Acad Child Psychiatry. 1986;25(6):854-6. [pmid: 3540075].
Zeiner P. Body growth and cardiovascular function after extended treatment (1. 75 years) with methylphenidate in boys with attention-deficit hyperactivity disorder. J Child Adolesc Psychopharmacol. 1995;5(2):129-38.
Zentall SS, Falkenberg SD, Smith LB. Effects of color stimulation and information on the copying performance of attention-problem adolescents. J Abnorm Child Psychol. 1985;13(4):501-11. [pmid: 4078182].
Zhang H, Huang J. [Preliminary study of traditional Chinese medicine treatment of minimal brain dysfunction: Analysis of 100 cases]. (Chi). Chin J Mod Dev Tradit Med. 1990;10(5):278-9.
Zito JM, Safer DJ, dosReis S, Magder LS, Riddle MA. Methylphenidate patterns among medicaid youths. Psychopharmacol Bull. 1997;33(1):143-7. [pmid: 9133766].