# Acknowledgments

This report was funded by the Agency for Healthcare Research and Quality (AHRQ) and developed with the help of many dedicated contributors. We are especially grateful for the input received from our partner organizations, the American Academy of Pediatrics (AAP) and the American Psychiatric Association. The members of the AAP Subcommittee on ADHD were especially helpful during the formulation of the research questions and the development of the data extraction forms. The support and commitment from our contacts at AHRQ were invaluable: Dr. David Atkins, the AHRQ Task Order Officer; Jacqueline Besteman; Al Deal; and the late Therese Dick, the AHRQ Contract Officer for this Task Order. It was with great sadness that we learned of Therese's untimely passing in the fall of 1998.

Thanks go to the San Franciso Cochrane Center for coordinating the peer review process, to the peer reviewers, and to Dr. Patricia Huston for her development of a coherent and constructive synthesis of the peer review commentaries. Several people provided us with information that was otherwise unavailable to us, including Drs. G. DuPaul, P. Jensen, and J. Swanson and members of the MTA Cooperative Group and the Canadian Coordinating Office for Health Technology Assessment (CCOHTA) research team. Special thanks to our colleagues at McMaster University for their enthusiasm, vision, and continued support.