# Conclusions and Implications for Future Research

## Overall Conclusions

The main overall conclusions from studies included in the Task Order are the following:

- Extensive research has been done on the treatment of ADHD for more than 25 years. However, few studies compare different pharmacological interventions head to head or with nonpharmacological treatments or evaluate the efficacy of antidepressants or combination therapies, the implications of long-term therapy, the treatment of ADHD in adults, or the adverse effects associated with the most frequently prescribed medications.
- The field would benefit from empirical methodological research evidence indicating the added value of nonrandomized within-subject and single-subject research designs for direct head-to-head comparisons between psychosocial interventions and other treatments.
- The reports of the studies available have numerous deficiencies that limit the assessment of their validity, relevance, precision, and, therefore, their clinical application. It was surprising, for instance, to find that most studies did not describe clearly important information such as the presence of comorbid disorders, the characteristics of the patients' families, the fidelity of treatments, compliance with treatment, or baseline measurement of outcomes of interest. Little information is available on the treatment of adult patients who belong to minority ethnic groups. In addition, the reporting of other important aspects of the studies was deficient.
- Most of the studies available had small sample sizes and did not provide information on the primary outcome of interest to the researchers. Therefore, it was unclear on most occasions whether statistically nonsignificant results reflected a true lack of difference among interventions or false-negative results from underpowered studies. Research during the past 20 years on this issue in other areas indicates that the latter is the most plausible situation in most cases (Freiman, Chalmers, Smith et al., 1978; Moher, Dulberg, and Wells, 1994).
- One of the most important challenges faced by researchers interested in ADHD and its treatment is to select a core set of uniform outcome measures to be used across studies in addition to those preferred by individual research groups. Standardized methods to obtain and report each of the outcomes, and the identification of clinically meaningful changes in the outcomes in response to treatment, would facilitate the interpretation of individual studies and the synthesis of data across studies.
- More research is needed to understand the relative value of the different aspects of a study. For instance, it is unclear whether having information on family characteristics is more or less important than having information on comorbid disorders. More efforts should be made to understand the implications that different diagnostic models for ADHD and comorbid disorders could have on the outcomes of treatment. This area provides a fertile ground of research on these clinically and methodologically important issues. Any future research efforts may also benefit from more communication among clinicians, providers, and consumers.
- Most reports lacked description of basic generic methodological aspects that increase their likelihood of bias. For instance, 97 percent of the articles did not describe the method of randomization, 95 percent did not provide information on concealment of allocation, and 87 percent did not describe the number of, or reasons for, withdrawals and dropouts in each of the groups. It is important to acknowledge that the studies may have included most of the elements in their protocols throughout the execution of the study but did not describe them in their report. Journal editors and peer reviewers should recognize the importance of these elements and encourage authors to include them in their reports. Most of the current problems that were encountered could be easily corrected if journal editors adopted evidence-based reporting recommendations such as the Consolidation of the Standards of Reporting Trials (CONSORT) statement (Begg, Cho, Eastwood et al., 1996) and kept track of new methodological developments that could increase the validity and applicability of research. The CONSORT statement was produced and published by an international group of clinical epidemiologists, biostatisticians, and journal editors in 1996. Its aim is to improve the standards of written reports of RCTs and to ensure that readers find all the information they require in the reports to interpret the trial results with confidence. This statement includes a checklist of 21 items and a flow diagram that authors can use to provide necessary information on the progress of patients through a study. The statement has already been adopted by over 70 major biomedical journals (Jadad and Rennie, 1998).
- The approach used in this review for the assessment of the quality of the studies by no means represents the only or most appropriate way to assess trial quality. However, the authors of this Task Order report included the only validated tool available that also appears to produce robust and valid results in an increasing number of empirical methodological studies. In addition, the scale was not used in isolation. Instead, it was complemented with separate assessments of other components for which empirical evidence of a direct relationship with bias exists. In addition, separate assessments of 20 other components were added to provide readers with a much wider and more clinically relevant picture. Any future decision on the assessment of trial validity should be made in the light of new empirical methodological evidence.
- The large number and heterogeneity of outcome measures and tests used in the studies limited efforts to compare and synthesize data across the studies included in this report.
- Researchers often use modified versions of the same tests (e.g., Conners) across studies but provide little information on their modified versions. The field would benefit by the selection of a core set of validated and clinically relevant outcomes to be measured in all the studies in addition to any other outcomes of interest to the specific groups of researchers. Few studies have been supported financially by sources other than governments or pharmaceutical companies. A great opportunity exists for consumer groups to support more research activities, given the number of important questions that remain unanswered and the implications of the results of research on the public.
- Future research efforts in the areas reviewed in this Task Order report will require collaboration and commitment among different groups of stakeholders. The MTA study funded by NIMH is an example of this type of collaboration.

The following is a description of the main implications for clinical practice and future research efforts from each of the seven categories of interest.

### Drug vs. Drug Comparisons

The small group of studies comparing different chemical structures and formulations of the same stimulants suggests that the different compounds are more effective than placebo but very similar to each other.

In agreement with the AMA and AACAP reports, it seems that few, if any, differences occur among MPH, DEX, and pemoline. In addition, the studies comparing stimulants with tricyclic antidepressants had many limitations and presented conflicting results. More rigorous studies are clearly needed to establish the relative effectiveness of stimulants and tricyclic antidepressants.

Studies are also required to compare the effects of stimulants with clonidine, buproprion, or selective serotonin-reuptake inhibitors.

### Drug vs. Nondrug Studies

The studies available indicate consistently that stimulants (particularly MPH) may be more effective than nonpharmacological interventions when compared head to head. The use of nondrug interventions as adjunct to treatment with stimulant awaits more definitive studies.

### Combination Therapies

Evidence is lacking that supports the superiority of combination therapy over stimulant alone or superiority of combination therapy over nondrug interventions alone. Thus, more definitive studies are needed to determine the added value of nondrug interventions when patients are already receiving stimulants, as well as the value of adding stimulants when nondrug interventions fail to achieve the desired outcomes. These studies, however, will require complex designs, substantial amounts of resources, and efficient collaboration among research groups. The MTA study is an example of this type of study and represents an important contribution to knowledge in this area.

### Tricyclic Antidepressants vs. Placebo

The studies on desipramine, regardless of their heterogeneous designs, small sample sizes, and variable quality, suggest that desipramine is more effective than placebo. The studies evaluating imipramine show inconsistent results. Given that this group of drugs may be considered by clinicians as the second line of treatment after stimulants, more rigorous research is needed to establish their role in the treatment of ADHD.

### Long-Term Therapy

Despite the fact that most patients diagnosed with ADHD receive treatment for long periods of time, the research efforts made to date are of little value to guide most clinical decisions. More studies are needed in this area because of the persistence of the disorder (NIH Consensus Statement Online, 1998). Practically all the evidence available concentrates on school-age children. Even in this age group, few data are available on adverse effects, on academic achievement, or on situation-specific outcomes (e.g., at home and at school). This is compounded by frequent crossover from one treatment arm to another within studies with parallel design, high attrition rates, and poor description of the reasons for discontinuation of treatments.

When adverse drug reactions do occur, they are usually related to dose and there is no evidence that concludes long-term effects of therapeutic use of psychostimulants are harmful. Long-term therapy studies supply evidence that MPH reduces behavioral disturbance in ADHD children as long as it is taken. Lithium does not appear to be an effective alternative in subjects who do not respond to stimulants. The MTA confirmed the findings of previous studies demonstrating short-term benefits do continue during longer term treatment (MTA Cooperative Group, 1999). There is no information on the long-term outcomes of medication-treated ADHD individuals in terms of educational and occupational achievements, involvement with law enforcement agencies or other areas of social functioning (NIH Consensus Statement Online, 1998).

### Treatment of ADHD in Adults

The studies available in this category are few, and most have incomplete reports and small sample sizes and are of short duration. Given the dearth of research evidence in this area, more studies are needed to establish the effectiveness and adverse effects of different interventions for the treatment of ADHD in adults. In the meantime, clinicians should be aware that the few studies evaluating MPH compared with placebo show contradictory results, that antidepressants may be effective in adults, and that the studies available do not support the use of pemoline, nicotine, or phenylalanine. Studies were not found that evaluated the effectiveness of nonpharmacological interventions for adults with diagnosis of ADHD.

### Adverse Effects

The findings in this report agree with those in the AMA report in relation to the evidence available on adverse effects. Many of the side effects associated with stimulant use appear to be relatively "mild, short lived and responsive to dosing or timing adjustments" (Goldman, Genel, Bezman et al., 1998). However, data are inadequate on the long-term effects and severity of the adverse effects of most interventions. Timing is an additional element that should be taken into account in future studies (e.g., the effects of stimulants administered during puberty and/or concomitant growth spurts). It appears from the available commentaries in many of the studies that desirable changes in behavior brought about by stimulant medication far outweigh reported side effects. Although this may be true, no attempts have been made to evaluate the tradeoff explicitly (i.e., examine the differential utility) between behavioral changes and side effects. The risks and benefits of treatment with psychostimulants must also be measured (NIH Consensus Statement Online, 1998). However, this is only worth doing if the perspectives of all interested parties (parents, teachers, and patients ) are included in the exercise.

In addition, it is important to highlight the following issues/concerns:

- No comparative studies were identified with data on addiction in relation to the treatment of ADHD with stimulants, liver toxicity resulting from pemoline administration, or major arrhythmia resulting from administration of tricyclic antidepressants.
- Reports of adverse effects almost always come from parents and/or teachers. One study (of adolescents) showed some important differences between parents and adolescents in the side-effects profile reported by each group. Data need to be collected from children on adverse side effects in order to make an intelligible assessment of their importance from the patients' perspective.
- A better understanding of the distinctions between "adverse effects" and concomitant characteristics of ADHD is needed. A number of reports discuss the high prevalence of "side effects" reported on placebo. Many of these may be associated problem behaviors. Including such behaviors distorts the context for evaluating the importance of side effects.
- Few girls and women have been studied. It is possible that effectiveness and adverse effects vary by sex. This issue needs to be examined or at least discussed.
- RCTs are limited to evaluate adverse effects, particularly rare ones or those that appear during long-term therapy. Only one comparative non-RCT with adequate data was found, and it also provided limited information. More observational studies are required (particularly case-control or cohort studies) to gain a better understanding of adverse effects associated with different treatments for ADHD. Knowledge of adverse effects may also improve through more creative use of existing drug databases.

## Limitations of This Evidence Report

The findings and conclusions of this evidence report are based on the information that was available in the published reports of the studies included. Additional information obtained directly from the authors could have overcome many of the reporting limitations described above. Contact with authors could have also led to reduction in the likelihood of publication bias through the identification of unpublished studies. The budget and time lines available, however, were insufficient to allow this.

The interpretability of these data included in most of the tables of this evidence report is limited. These data were obtained by the authors of the studies with many different instruments that were poorly described in most reports.

Another limitation of this report is that it does not include quantitative estimates of the relative effects of the interventions evaluated. However, meta-analysis was deemed inappropriate given the amount, heterogeneity, and quality of the data available. As mentioned above, the use of meta-analysis to synthesize this type of data has been associated with a greater chance of obtaining imprecise and potentially misleading results (Ioannidis, Cappelleri, and Lau, 1998). It is unclear, however, whether the problems found in this data set are greater or smaller than those in other areas. It is important, however, to recognize that qualitative systematic reviews can introduce other problems such as biased narrative description of the characteristics and findings of the studies included. By including detailed evidence tables in this report, it is hoped that readers will be able to replicate the findings, when appropriate.

It could also be argued that another limitation of this report is that it did not include a separate section for studies comparing the short-term effects of stimulants with placebo. This decision was motivated by the need to make efficient use of the resources available while ensuring the maximum added value from the Task Order report. Given the consistency of the findings of the individual studies included in this review, the three published systematic reviews, and the most recent unpublished review, as well as the limitations of the studies available, it is the belief of the authors that the decision to focus attention on the other seven categories resulted in the most efficient use of the resources available.

It could be argued that systematic reviews of behavioral interventions could benefit substantially by the inclusion of nonrandom within-subject and single-subject research designs. However, we regarded these study designs as too vulnerable to bias and of limited value for direct head-to-head comparisons between psychosocial therapies and interventions.

In many instances, it was concluded that there was a lack of evidence on the effectiveness of clinically important interventions. It is important to recognize that this is different from the lack of effectiveness of the same interventions.

## Closing Remarks

This report represents a collective effort by representatives of different groups of stakeholders, including government agencies (AHRQ), professional organizations (AAP and APA), consumer groups (Children and Adults with Attention-Deficit Disorders [CHADD]), clinicians, and researchers with content and methodological expertise. Emphasis was placed on ensuring the relevance of the research questions, on building on existing knowledge, and on supporting future clinical practice guideline development or research efforts.

The report includes seven systematic reviews that incorporated state-of-the-art methodology and data that are ready for incorporation into evidence-based clinical practice guidelines or performance measures.

This report would best be used as a tool to guide future research priorities and as a platform from which to develop programs, guidelines, and policies rather than as a guideline for clinical practice. Our hope is that this report will be used to stimulate discussion, advance knowledge, and provide constructive challenge in an area of public concern: ADHD.