# Introduction

Attention-deficit/hyperactivity disorder (ADHD) is one of the most common psychiatric disorders diagnosed in children and adolescents (American Academy of Child and Adolescent Psychiatry, 1997a; Goldman, Genel, Bezman et al., 1998), estimated to affect 3 to 5 percent of school age children (NIH Consensus Statement Online, 1998). The American Psychiatric Association (APA) has proposed a series of diagnostic criteria for ADHD (Appendix A), identifying as the essential feature "a persistent pattern of inattention and/or hyperactivity-impulsivity that is more frequent and severe than is typically observed in individuals at a comparable level of development" (American Psychiatric Association, 1994). Over the years, different terms have been used to describe children with "distractability, impulsivity and usually also overactivity," including minimal brain dysfunction/damage (MBD), hyperkinetic reaction, and hyperkinesis (American Academy of Child and Adolescent Psychiatry, 1997a). ADHD is not a unitary entity. Subtypes of ADHD can be constructed based on differences in phenomenology, comorbidity, and etiology. These different subtypes may differ in etiology, natural history, and response to treatment. The prominence of particular core "symptoms" (they are really signs) of ADHD-inattentiveness, hyperactivity, and impulsiveness-is the basis for the primary distinction among ADHD subtypes. The Diagnostic and Statistical Manual of Mental Disorders IV (DSM-IV) distinguishes among a primarily inattentive subtype, a hyperactive-impulsive subtype, and a combined subtype (American Psychiatric Association, 1994). Inattentive ADHD children may be lethargic, shy, and prone to daydream and have a higher incidence of learning disabilities. Hyperactive-impulsive ADHD subjects may be more disruptive and aggressive.

Prevailing opinions regarding the validity of ADHD vary from those who do not believe it exists and regard it as a myth (http://www.healthy.net/library/books/ullman/chap3.htm;">http://www.healthy.net/library/books/ullman/chap3.htm; Weinberg and Brumback, 1992) to those who believe that underlying genetic and physiological evidence supports its existence (Kewley, 1998). Several features of ADHD contribute to the controversy: (1) it is a clinical diagnosis for which no laboratory or radiological confirmatory tests or specific physical features exist; (2) diagnostic criteria have changed frequently; (3) there is no curative treatment, so patients require long-term therapies; (4) therapy often includes stimulant drugs that are thought to have abuse or diversion potential; and (5) substantial differences in the rate of diagnosis and treatment occur across countries, particularly in the United Kingdom, Australia, Canada, and the United States (American Academy of Child and Adolescent Psychiatry, 1997b; Goldman, Genel, Bezman et al., 1998; Kewley, 1998; NIH Consensus Statement Online, 1998; Orford, 1998).

Prevalence estimates of ADHD vary according to the methods of ascertainment, diagnostic criteria, informants, and population sampled (American Academy of Child and Adolescent Psychiatry, 1997a; Elia, Ambrosini, and Rapoport, 1999; Goldman, Genel, Bezman et al., 1998). According to the DSM-IV, the prevalence of ADHD among school-age children is 3 to 5 percent (American Psychiatric Association, 1994). However, prevalence studies using the two previous versions of the DSM (DSM-III and DSM-III-R) in the United States, Canada, United Kingdom, Germany, and New Zealand have shown rates that vary from 1.7 to 16.1 percent (Goldman, Genel, Bezman et al., 1998). ADHD has been identified as the most common cause of referrals to child and adolescent psychiatric health services (American Psychiatric Association, 1994). Consistently, the disorder is diagnosed more frequently in males than in females (American Academy of Child and Adolescent Psychiatry, 1997a; American Psychiatric Association, 1994). Even in children rated by teachers as meeting criteria for any subtype of ADHD, fewer girls than boys receive an ADHD diagnosis (Wolraich, Hannah, Pinnock et al., 1996).

Although it was previously thought that ADHD remitted before or during adolescence, it is now estimated that more than 70 percent of hyperactive children continue to meet criteria for ADHD as adolescents and up to 65 percent as adults (Barkley, 1996; Goldman, Genel, Bezman et al., 1998).

Problems with the diagnosis and treatment of ADHD can also arise because of the presence of comorbidity, in the form of anxiety disorders, communication disorders, mood disorders, conduct disorders (CDs), oppositional defiant disorder (ODD), learning disorders, Tourette's syndrome, and subnormal intelligence (American Psychiatric Association, 1994; Goldman, Genel, Bezman et al., 1998; Orford, 1998). In fact, it has been estimated that as many as 65 percent of children with ADHD have at least one comorbid disorder (Goldman, Genel, Bezman et al., 1998). ADHD with comorbid oppositional defiant and/or conduct disorder is the most prevalent comorbidity. Children with ADHD and comorbid ODD/CD are more likely to be males, live in families with higher rates of psychosocial adversity, and have a poorer prognosis characterized by antisocial behavior, substance use disorder, and poor scholastic success. ADHD with ODD/CD may represent a genetic subtype (Biederman, Faraone, and Keenan, 1992; Cadoret and Stewart, 1991). However, the evidence for differential response to medication of ADHD with and without comorbid ODD/CD is not strong (Barkley, McMurray, Edelbrock et al., 1989). Children with comorbid CD may be less likely to comply with treatment regimens. Similarly, their families may be less adherent to treatment.

Comorbid internalizing disorders such as anxiety or depressive disorders are also common (reviewed in Jensen, Martin, and Cantwell, 1997). Few differences in clinical or demographic features have been found between ADHD with and without comorbid anxiety: ADHD in patients with anxiety is associated with more psychosocial risk factors (Biederman, Milberger, Faraone et al., 1995) and possibly with less impulsivity (Pliszka, 1992). This combination does not appear to be a distinct genetic subtype of ADHD (Biederman, Faraone, and Keenan, 1992). However, evidence shows that children with a diagnosis of ADHD with comorbid anxiety may respond less well to stimulants and better to antidepressants (Jensen, Martin, and Cantwell, 1997).

The presence of ADHD has been associated with some individual and family features. Patients have impaired academic achievement and may be rejected by peers, and their family relationships are often characterized by resentment and antagonism (American Psychiatric Association, 1994). Increased levels of parental frustration, marital discord, and divorce occur in families who have children with ADHD (NIH Consensus Statement Online, 1998). Individuals with ADHD also tend to consume a disproportionate share of resources and attention from educators, the health care system, social service agencies, and the legal system. (NIH Consensus Statement Online, 1998).

Many different treatment modalities have been proposed for patients with ADHD, including, among others, pharmacological agents (e.g., stimulants, antidepressants), cognitive/behavioral techniques, dietary interventions, and combinations of any of the above. However, given the present debate around the existence of ADHD, the variation in estimates of prevalence, and the frequency with which comorbid disorders are identified, it is not surprising to find wide variation and controversy around its treatment. This variability in treatments in North America led to the development of practice parameters by the American Academy of Child and Adolescent Psychiatry (AACAP) (American Academy of Child and Adolescent Psychiatry, 1997b) and has motivated the American Academy of Pediatrics (AAP) to develop clinical practice guidelines. The APA is currently contemplating how to use the available information, including this report, in the development of quality improvement projects.

## Commissioning of This Report

Since 1997, the Agency for Healthcare Research and Quality (AHRQ) has been supporting initiatives that could facilitate the production of clinical practice guidelines and quality improvement tools and inform consensus conferences. One of these efforts is a joint initiative involving the AAP and Technical Resources International, Inc., to gather and analyze evidence on the prevalence and diagnostic screening of ADHD.

In June 1997, the U.S. Department of Health and Human Services announced the start of a new program through which the AHRQ would award contracts to institutions in the United States and Canada to serve as Evidence-based Practice Centers (EPCs). The mission of these EPCs, of which McMaster University is one, is to review all the relevant scientific literature on health care topics assigned to them by AHRQ. The main task of the EPCs is to produce "evidence reports" that will serve as the scientific foundation for public and private sector organizations to develop tools and strategies for improving the quality of the health care services. The first set of topics was nominated by a group of public and private sector organizations in response to a solicitation published by AHRQ in November 1996. On August 21, 1997, the McMaster University EPC (MU-EPC) was invited to submit a proposal for the development of an evidence report on the treatment of ADHD. This topic had been nominated by the AAP and the APA. Dr. David Atkins was identified by AHRQ as the Task Order Officer (TOO) for this Task Order.

The MU-EPC was notified on September 30, 1997, that it was successful in its bid to undertake the development of an evidence report on the treatment of ADHD, which is described in this document. The objectives of this Task Order were to conduct a comprehensive systematic review of the literature on the treatment of ADHD and to support guideline development initiatives by the nominating organizations, while building on existing work and focusing on answerable, clinically relevant questions.

## Concurrent Work

During the period in which this Task Order was in development, two professional organizations, the American Medical Association (AMA) and AACAP produced important reports on the treatment of ADHD (American Academy of Child and Adolescent Psychiatry, 1997a; Goldman, Genel, Bezman et al., 1998).

The report by the AMA was produced by the Council of Scientific Affairs. It had some elements of a systematic review, as it included a clear description of the research questions and provided a description of the search strategy used to identify the relevant literature. The report, however, did not describe the inclusion or exclusion criteria for articles, the methods to assess the validity of the information, or the strategies used for data synthesis. The report by the AMA addressed six questions to inform current professional and public concern about ADHD. Two of the questions relate to issues addressed by this Task Order:

- What constitutes optimal treatment for ADHD, and how do stimulants fit into it?
- What are the adverse consequences of using stimulants, and, in particular, what is known about the risks of abuse and diversion?

The report by the AACAP was produced by the Work Group on Quality Issues and approved by the AACAP Council in February 1997. It also included a description of the search strategy used to identify literature on the assessment and treatment of children, adolescents, and adults with ADHD. The report did not present the issues of interest as questions but was structured following clear sections by topics of interest. As in the AMA report, no description of the inclusion and exclusion criteria, the criteria to assess the validity of the information, or the strategies used to synthesize the information was included. Because reports were published in peer-reviewed journals, it is possible that the information was not provided because of space limitations.

The National Institutes of Health (NIH) held a consensus planning conference on ADHD in November 1998. The NIH has also funded a long-term, collaborative Multimodal Treatment Study of Children with ADHD (the MTA Collaborative Group study) to address issues emphasized by the Institute of Medicine study Research on Children and Adolescents with Mental, Behavioral, and Developmental Disorders, the National Institute of Mental Health (NIMH) National Plan for Research on Child and Adolescent Mental Disorders, the Healthy People 2000, and Healthy Children 2000. This study examined long-term (14 months with a 24-month followup) effectiveness of medication for treatment of ADHD vs. behavioral treatment vs. both and compared state-of-the-art treatment with routine community care. In a parallel-groups design, 576 children (age 7 to 9 years) with ADHD were thoroughly assessed and randomized to 4 conditions: (1) medication alone, (2) psychosocial treatment alone, (3) the combination of both, or (4) community comparison (Richters, Arnold, Jensen et al., 1995). The results of this study became available to us in early 1999 and have been incorporated into this report.

The research team for this report was also aware that a systematic review that included placebo-controlled studies evaluating the effect of stimulants had been commissioned by the Canadian Coordinating Office for Health Technology Assessment (CCOHTA) to a group of researchers at the University of British Columbia in Canada. Relevant results from that effort have also been incorporated into this Task Order Report.