# Appendix H: Reference List of All Included Articles by Categories

## Drug vs. Drug studies RCTs only (n=22)

Arnold LE, Christopher J, Huestis R, Smeltzer DJ. Methylphenidate vs dextroamphetamine vs caffeine in minimal brain dysfunction: controlled comparison by placebo washout design with Bayes' analysis. Arch Gen Psychiatry. 1978 Apr;35(4):463-73. Source Database: Medline.
Arnold LE, Huestis RD, Smeltzer DJ, Scheib J, Wemmer D, Colner G. Levoamphetamine vs dextroamphetamine in minimal brain dysfunction. Replication, time response, and differential effect by diagnostic group and family rating. Arch Gen Psychiatry. 1976 Mar;33(3):292-301. Source Database: Medline.
Borcherding BG, Keysor CS, Cooper TB, Rapoport JL. Differential effects of methylphenidate and dextroamphetamine on the motor activity level of hyperactive children. Neuropsychopharmacology. 1989 Dec;2(4):255-63. Source Database: Medline.
Castellanos FX, Giedd JN, Elia J, Marsh WL, Ritchie GF, Hamburger SD, Rapoport JL. Controlled stimulant treatment of ADHD and comorbid Tourette's syndrome: Effects of stimulant and dose. J Am Acad Child Adolesc Psychiatry. 1997 May;36(5):589-96. Source Database: Medline.
Conners CK, Taylor E. Pemoline, methylphenidate, and placebo in children with minimal brain dysfunction. Arch Gen Psychiatry. 1980 Aug;37(8):922-30. Source Database: Medline.
Conners CK, Taylor E, Meo G, Kurtz MA, Fournier M. Magnesium pemoline and dextroamphetamine: A controlled study in children with minimal brain dysfunction. Psychopharmacologia. 1972;26(4):321-36. Source Database: Medline. [pmid: 4508756].
Efron D, Jarman F, Barker M. Methylphenidate versus Dexamphetamine in children with Attention Deficit Hyperactivity Disorder: A double-blind, crossover trial. Paediatrics. 1997;100(6). Source Database: Consultant.
Elia J, Borcherding BG, Rapoport JL, Keysor CS. Methylphenidate and dextroamphetamine treatments of hyperactivity: Are there true nonresponders?. Psychiatry Res. 1991 Feb;36(2):141-55. Source Database: Medline.
Fitzpatrick PA, Klorman R, Brumaghim JT, Borgstedt AD. Effects of sustained-release and standard preparations of methylphenidate on attention deficit disorder. J Am Acad Child Adolesc Psychiatry. 1992;31(2):226-34. Source Database: Medline. [pmid: 1564023].
Gross MD. A comparison of dextro-amphetamine and racemic-amphetamine in the treatment of the hyperkinetic syndrome or minimal brain dysfunction. Dis Nerv Syst. 1976 Jan;37(1):14-6. Source Database: Medline. [pmid: 1106966].
Kauffman RE, Smith-Wright D, Reese CA, Simpson R, Jones F. Medication compliance in hyperactive children. Pediatr Pharmacol. 1981;1(3):231-7. Source Database: Medline.
Matochik JA, Liebenauer LL, King C, Szymanski HV, Cohen RM, Zametkin AJ. Cerebral glucose metabolism in adults with attention deficit hyperactivity disorder after chronic stimulant treatment. Am J Psychiatry. 1994;151(5):658-64. Source Database: Embase. [pmid: 8166305].
Pelham WE J, Greenslade KE, Vodde-Hamilton M, Murphy DA, Greenstein JJ, Gnagy EM, Guthrie KJ, Hoover MD, Dahl RE. Relative efficacy of long-acting stimulants on children with attention deficit-hyperactivity disorder: A comparison of standard methylphenidate, sustained-release methylphenidate, sustained-release dextroamphetamine, and pemoline. Pediatrics. 1990 Aug;86(2):226-37. Source Database: Medline.
Pelham WE J, Sturges J, Hoza J, Schmidt C, Bijlsma JJ, Milich R, Moorer S. Sustained release and standard methylphenidate effects on cognitive and social behavior in children with attention deficit disorder. Pediatrics. 1987 Oct;80(4):491-501. Source Database: Medline. [pmcid: 138812].
Quinn PO, Rapoport JL. One-year follow-up of hyperactive boys treated with imipramine or methylphenidate. Am J Psychiatry. 1975 Mar;132(3):241-5. Source Database: Medline.
Rapport MD, Carlson GA, Kelly KL, Pataki C. Methylphenidate and desipramine in hospitalized children: I. Separate and combined effects on cognitive function. J Am Acad Child Adolesc Psychiatry. 1993 Mar;32(2):333-42. Source Database: Medline.
Spring C, Yellin AM, Greenberg L. Effects of imipramine and methylphenidate on perceptual-motor performance of hyperactive children. Percept Mot Skills. 1976 Oct;42(43):459-70. Source Database: Medline.
Srinivas NR, Hubbard JW, Quinn D, Midha KK. Enantioselective pharmacokinetics and pharmacodynamics of dl-threo-methylphenidate in children with attention deficit hyperactivity disorder. Clinical Pharmacology & Therapeutics. 1992 Nov;52(5):561-8. Source Database: Medline.
Stephens RS, Pelham WE, Skinner R. State-dependent and main effects of methylphenidate and pemoline on paired-associate learning and spelling in hyperactive children. J Consult Clin Psychol. 1984;52(1):104-13. Source Database: Embase. [pmid: 6699239].
Werry JS, Aman MG, Diamond E. Imipramine and methylphenidate in hyperactive children. J Child Psychol Psychiatry. 1980 Jan;21(1):27-35. Source Database: Medline.
Whitehouse D, Shah U, Palmer FB. Comparison of sustained-release and standard methylphenidate in the treatment of minimal brain dysfunction. J Clin Psychiatry. 1980 Aug;41(8):282-5. Source Database: Medline.
Winsberg BG, Press M, Bialer I, Kupietz S. Dextroamphetamine and methylphenidate in the treatment of hyperactive-aggressive children. Pediatrics. 1974 Feb;53(2):236-41. Source Database: Medline. [pmcid: 126268].

## Drug vs. Non-Drug studies RCTs only (n=12)

Arnold LE, Kleykamp D, Votolato NA, Taylor WA, Kontras SB, Tobin K. Gamma-linolenic acid for attention-deficit hyperactivity disorder: Placebo-controlled comparison to D-amphetamine. Biol Psychiatry. 1989;25(2):222-8. Source Database: Medline. [pmid: 2539203].
Arnold LE, Abikoff HB, Cantwell DP, Conners CK, Elliott G, Greenhill LL, Hechtman L, Hinshaw SP, Hoza B, Jensen PS, Kraemer HC, March JS, Newcorn JH, Pelham WE, Richters JE, Schiller E, Severe JB, Swanson JM, Vereen D, Wells KC, for the MTA. National Institute of Mental Health Collaborative Multimodal Treatment Study of Children With ADHD (the MTA): Design challenges and choices. Arch Gen Psychiatry. 1997;54(9):865-70. (same study as MTA Cooperative Study Group, 1999). Source Database: Medline. [pmid: 9294378].
Brown RT, Wynne ME, Medenis R. Methylphenidate and cognitive therapy: a comparison of treatment approaches with hyperactive boys. J Abnorm Child Psychol. 1985 Mar;13(1):69-87. Source Database: Medline.
Conrad WG, Dworkin ES, Shai A, Tobiessen JE. Effects of amphetamine tharapy and prescriptive tutoring on the behavior and achievement of lower class hyperactive children. J Learn Disabil. 1971;4:509-17. Source Databse: reference list Schachar review article.
Firestone P, Crowe D, Goodman JT, McGrath P. Vicissitudes of follow-up studies: differential effects of parent training and stimulant medication with hyperactives. Am J Orthopsychiatry. 1986 Apr;56(2):184-94. Source Database: Medline.
Firestone P, Kelly MJ, Goodman JT, Davey J. Differential effects of parent training and stimulant medication with hyperactives: A progress report. J Am Acad Child Psychiatry. 1981;20(1):135-47. Source Database: Medline. [pmid: 7217546].
Gittelman-Klein R, Klein DF, Abikoff H, Katz S, Gloisten AC, Kates W. Relative efficacy of methylphenidate and behavior modification in hyperkinetic children: an interim report. J Abnorm Child Psychol. 1976;4(4):361-79. (Same study as Klein and Abikoff, 1997). Source Database: Medline. [pmid: 1002948].
Greenhill LL, Abikoff HB, Arnold LE, Cantwell DP, Conners CK, Elliott G, Hechtman L, Hinshaw SP, Hoza B, Jensen PS, March JS, Newcorn J, Pelham WE, Severe JB, Swanson JS, Vitiello B, Wells K. Medication treatment strategies in the MTA study: Relevance to clinicians and researchers. J Am Acad Child Adolesc Psychiatry. 1996;34(10):1304-13. (same study as MTA Cooperative Group, 1999). Source Database: Medline.
Hinshaw SP, March JS, Abikoff H, Arnold LE, Cantwell DP, Conners CK, Elliott GR, Halperin J, Greenhill LL, Hechtman LT, Hoza B, Jensen PS, Newcorn JH, McBurnett K, Pelham WE, Richters JE, Severe JB, Schiller E, Swanson J, Vereen D, Wells K, Wigal T. Comprehensive assessment of childhood Attention-Deficit Hyperactivity Disorder in the context of a multisite, multimodal clinical trial. J Attention Dis. 1997;1(4):217-34. (same study as MTA Cooperative Group, 1999). Source Database: Medline.
Klein RG, Abikoff H. Behavior therapy and methylphenidate in the treatment of children with ADHD. J Attention Dis. 1997;2(2):89-114. Source Database: Medline.
MTA Cooperative Group. 14-month randomized clinical trial of treatment strategies for attention deficit hyperactivity disorder. Multimodal Treatment Study of Children with ADHD. Arch Gen Psychiatry. 1999 Dec;56(12):1073-86.
Richters JE, Arnold IE, Jensen PS, Abikoff H, Conners CK, Greenhill LL, Hechtman L, Hinshaw SP, Pelham WE, Swanson JM. NIMH Collaborative Multisite Multimodal Treatment Study of children with ADHD: I. Background and rationale. J Am Acad Child Adolesc Psychiatry. 1995 Aug;34(8):987-1000. (same study as MTA Cooperative Group, 1999). Source Database: Medline.

## Combination Therapy Papers RCTs only (n=26)

Arnold LE, Abikoff HB, Cantwell DP, Conners CK, Elliott G, Greenhill LL, Hechtman L, Hinshaw SP, Hoza B, Jensen PS, Kraemer HC, March JS, Newcorn JH, Pelham WE, Richters JE, Schiller E, Severe JB, Swanson JM, Vereen D, Wells KC, for the MTA. National Institute of Mental Health Collaborative Multimodal Treatment Study of Children With ADHD (the MTA): Design challenges and choices. Arch Gen Psychiatry. 1997;54(9):865-70. (same study as MTA Cooperative Study Group, 1999). Source Database: Medline. [pmid: 9294378].
Borden, KA, Brown, RT. Attributional outcomes: The subtle messages of treatments for attention deficit disorder. Cognitive Ther Res. 1989 Apr;13(2):147-60. Source Database: PsycINFO.
Brown RT, Borden KA, Wynne ME, Schleser R, Clingerman SR. Methylphenidate and cognitive therapy with ADD children: A methodological reconsideration. J Abnorm Child Psychol. 1986 Dec;14(4):481-97. Source Database: Medline.
Brown RT, Borden KA, Wynne ME, Spunt AL. Patterns of compliance in a treatment program for children with attention deficit disorder. J Compliance Health Care. 1988;3(1):23-39. Source Database: PsycINFO.
Brown RT, Wynne ME, Medenis R. Methylphenidate and cognitive therapy: A comparison of treatment approaches with hyperactive boys. J Abnorm Child Psychol. 1985 Mar;13(1):69-87. Source Database: Medline.
Carlson CL, Pelham-WE J, Milich R, Dixon J. Single and combined effects of methylphenidate and behavior therapy on the classroom performance of children with attention-deficit hyperactivity disorder. J Abnorm Child Psychol. 1992;20(2):213-32. Source Database: Embase. [pmid: 1593027].
Christensen DE. Effects of combining methylphenidate and a classroom token system in modifying hyperactive behavior. Am J Ment Defic. 1975 Nov;80(3):266-76. Source Database: Medline. [pmid: 1103623].
Conrad WG, Dworkin ES, Shai A, Tobiessen JE. Effects of amphetamine tharapy and prescriptive tutoring on the behavior and achievement of lower class hyperactive children. J Learn Disabil. 1971;4:509-17. Source Database: reference list Schachar review article.
Firestone P, Crowe D, Goodman JT, McGrath P. Vicissitudes of follow-up studies: differential effects of parent training and stimulant medication with hyperactives. Am J Orthopsychiatry. 1986 Apr;56(2):184-94. Source Database: Medline.
Firestone P, Kelly MJ, Goodman JT, Davey J. Differential effects of parent training and stimulant medication with hyperactives: A progress report. J Am Acad Child Psychiatry. 1981;20(1):135-47. (Same study as Firestone, Crowe, Goodman et al., 1986). Source Database: Medline. [pmid: 7217546].
Garfinkel BD, Webster CD, Sloman L. Responses to methylphenidate and varied doses of caffeine in children with attention deficit disorder. Can J Psychiatry. 1981 Oct;26(6):395-401. Source Database: Medline.
Gittelman-Klein R, Klein DF, Abikoff H, Katz S, Gloisten, AC, Kates W. Relative efficacy of methylphenidate and behavior modification in hyperkinetic children: an interim report. J Abnorm Child Psychol. 1976;4(4):361-79. Source Database: Medline. [pmid: 1002948].
Gittelman-Klein R, Klein DF, Katz S, Saraf K, Pollack E. Comparative effects of methylphenidate and thioridazine in hyperkinetic children. I. Clinical results. Arch Gen Psychiatry. 1976 Oct;33(10):1217-31. Source Database: Medline.
Greenhill LL, Abikoff HB, Arnold LE, Cantwell DP, Conners CK, Elliott G, Hechtman L, Hinshaw SP, Hoza B, Jensen PS, March JS, Newcorn J, Pelham WE, Severe JB, Swanson JS, Vitiello B, Wells K. Medication treatment strategies in the MTA study: Relevance to clinicians and researchers. J Am Acad Child Adolesc Psychiatry. 1996;34(10):1304-13. (same study as MTA Cooperative Group, 1999). Source Database: Medline.
Hinshaw SP, Buhrmester D, Heller T. Anger control in response to verbal provocation: Effects of stimulant medication for boys with ADHD. J Abnorm Child Psychol. 1989 Aug;17(4):393-407. Source Database: Medline.
Hinshaw SP, Henker B, Whalen CK. Cognitive-behavioral and pharmacologic interventions for hyperactive boys: comparative and combined effects. J Consult Clin Psychol. 1984 Oct;52(5):739-49. Source Database: Medline.
Hinshaw SP, March JS, Abikoff H, Arnold LE, Cantwell DP, Conners CK, Elliott GR, Halperin J, Greenhill LL, Hechtman LT, Hoza B, Jensen PS, Newcorn JH, McBurnett K, Pelham WE, Richters JE, Severe JB, Schiller E, Swanson J, Vereen D, Wells K, Wigal T. Comprehensive assessment of childhood Attention-Deficit Hyperactivity Disorder in the context of a multisite, multimodal clinical trial. J Attention Dis. 1997;1(4):217-34. (same study as MTA Cooperative Group, 1999). Source Database: Medline.
Klein RG, Abikoff H. Behavior therapy and methylphenidate in the treatment of children with ADHD. J Attention Dis. 1997;2(2):89-114. (Same study as Gittelman-Klein, Klein, Abikoff et al., 1976). Source Database: Medline.
Levy F, Hobbes G. Does haloperidol block methylphenidate?. Motivation or attention? Psychopharmacology. 1996 Jul;126(1):70-4. Source Database: Medline. [pmcid: 53046].
Long N, Rickert VI, Ashcraft EW. Bibliotherapy as an adjunct to stimulant medication in the treatment of attention-deficit hyperactivity disorder. J Pediatr Health Care. 1993 Mar;7(2):82-8. Source Database: Medline.
MTA Cooperative Group. 14-month randomized clinical trial of treatment strategies for attention deficit hyperactivity disorder. Multimodal Treatment Study of Children with ADHD. Arch Gen Psychiatry. 1999 Dec;56(12):1073-86.
Pataki CS, Carlson GA, Kelly KL, Rapport MD, Biancaniello TM. Side effects of methylphenidate and desipramine alone and in combination in children. J Am Acad Child Adolesc Psychiatry. 1993;32(5):1065-72. (Same study as Rapport, Carlson, Kelly et al., 1993). Source Database: Medline. [pmid: 8407753].
Pelham WE, Carlson C, Sams SE, Vallano G, Dixon MJ, Hoza B. Separate and combined effects of methylphenidate and behavior modificationon boys with attention deficit-hyperactivity disorder in the classroom. J Consult Clin Psychol. 1993;61(3):506-15. Source Database: Embase. [pmid: 8326053].
Rapport MD, Carlson GA, Kelly KL, Pataki C. Methylphenidate and desipramine in hospitalized children: I. Separate and combined effects on cognitive function. J Am Acad Child Adolesc Psychiatry. 1993 Mar;32(2):333-42. Source Database: Medline.
Richters JE, Arnold IE, Jensen PS, Abikoff H, Conners CK, Greenhill LL, Hechtman L, Hinshaw SP, Pelham WE, Swanson JM. NIMH Collaborative Multisite Multimodal Treatment Study of children with ADHD: I. Background and rationale. J Am Acad Child Adolesc Psychiatry. 1995 Aug;34(8):987-1000. (same study as MTA Cooperative Group, 1999). Source Database: Medline.
Schechter MD, Timmons GD. Objectively measured hyperactivity-II. Caffeine and amphetamine effects. J Clin Pharmacol. 1985 May;25(4):276-80. Source Database: Medline.
Solanto MV, Wender EH, Bartell SS. Effects of methylphenidate and behavioral contingencies on sustained attention in attention-deficit hyperactivity disorder: A test of the reward dysfunction hypothesis. J Child Adolesc Psychoparmacol. 1997;7(2):123-36. Source Database: Embase.

## Tricyclic Antidepressants vs. Placebo, n=12

Biederman J, Baldessarini RJ, Wright V, Keenan K, Faraone S. A double-blind placebo controlled study of desipramine in the treatment of ADD: III. Lack of impact of comorbidity and family history factors on clinical response. J Am Acad Child Adolesc Psychiatry. 1993 Jan;32(1):199-204. Source Database: Medline.
Biederman J, Baldessarini RJ, Wright V, Knee D, Harmatz JS, Goldblatt A. A double-blind placebo controlled study of desipramine in the treatment ADD: II. Serum drug levels and cardiovascular findings. J Am Acad Child Adolesc Psychiatry. 1989 Nov;28(6):903-11. Source Database: Medline.
Biederman J, Baldessarini RJ, Wright V, Knee D, Harmatz JS. A double-blind placebo controlled study of desipramine in the treatment of ADD: I. Efficacy. J Am Acad Child Adolesc Psychiatry. 1989 Sep;28(5):777-84. Source Database: Medline.
Conners CK, Taylor E. Pemoline, methylphenidate, and placebo in children with minimal brain dysfunction. Arch Gen Psychiatry. 1980;37(8):922-30. Source Database: Medline. [pmid: 7406656].
Donnelly M, Zametkin AJ, Rapoport JL, Ismond DR, Weingartner H, Lane E, Oliver J, Linnoila M, Potter WZ. Treatment of childhood hyperactivity with desipramine: Plasma drug concentration, cardiovascular effects, plasma and urinary catecholamine levels, and clinical response. Clin Pharmacol Ther. 1986 Jan;39(1):72-81. Source Database: Medline.
Gualtieri CT, Evans RW. Motor performance in hyperactive children treated with imipramine. Percept Mot Skills. 1988 Jun;66(3):763-9. Source Database: Medline.
Gualtieri CT, Keenan PA, Chandler M. Clinical and neuropsychological effects of desipramine in children with attention deficit hyperactivity disorder. J Clin Psychopharmacol. 1991 Jun;11(3):155-9. Source Database: Medline.
Rapport MD, Carlson GA, Kelly KL, Pataki C. Methylphenidate and desipramine in hospitalized children: I. Separate and combined effects on cognitive function. J Am Acad Child Adolesc Psychiatry. 1993;32(2):333-42. Source Database: Medline. [pmid: 8444762].
Singer HS, Brown J, Quaskey S, Rosenberg LA, Mellits ED, Denckla MB. The treatment of attention-deficit hyperactivity disorder in Tourette's syndrome: A double-blind placebo-controlled study with clonidine and desipramine. Pediatrics. 1995 Jan;95(1):74-81. Source Database: Medline. [pmcid: 161813].
Werry JS; Aman MG; Diamond E. Imipramine and methylphenidate in hyperactive children. J Child Psychol Psychiatry. 1980;21(1):27-35. Source Database: Medline. [pmid: 7358801].
Wilens TE, Biederman J, Prince J, Spencer TJ, Faraone SV, Warburton R, Schleifer D, Harding M, Linehan C, Geller D. Six-week, double-blind, placebo-controlled study of desipramine for adult attention deficit hyperactivity disorder. Six-week, double-blind, placebo-controlled study of desipramine for adult attention deficit hyperactivity disorder. Am J Psychiatry. 1996;153(9):1147-53. Source Databse: Medline. [pmid: 8780417].
Winsberg BG, Kupietz SS, Yepes LE, Goldstein S. Ineffectiveness of imipramine in children who fail to respond to methylphenidate. J Autism Dev Disord. 1980 Jun;10(2):129-37. Source Database: Medline.

## Long-Term Therapy Studies (n = 18)

Arnold LE, Abikoff HB, Cantwell DP, Conners CK, Elliott G, Greenhill LL, Hechtman L, Hinshaw SP, Hoza B, Jensen PS, Kraemer HC, March JS, Newcorn JH, Pelham WE, Richters JE, Schiller E, Severe JB, Swanson JM, Vereen D, Wells KC, for the MTA. National Institute of Mental Health Collaborative Multimodal Treatment Study of Children With ADHD (the MTA): Design challenges and choices. Arch Gen Psychiatry. 1997;54(9):865-70. (same study as MTA Cooperative Study Group, 1999). Source Database: Medline. [pmid: 9294378].
Brown RT, Borden KA, Wynne ME, Schleser R, Clingerman SR. Methylphenidate and cognitive therapy with ADD children: A methodological reconsideration. J Abnorm Child Psychol. 1986 Dec;14(4):481-97. Source Database: Medline.
Brown RT, Borden KA, Wynne ME, Spunt AL. Patterns of compliance in a treatment program for children with attention deficit disorder. J Compliance Health Care. 1988;3(1):23-39. Source Database: PsycINFO.
Brown RT, Wynne ME, Medenis R. Methylphenidate and cognitive therapy: A comparison of treatment approaches with hyperactive boys. J Abnorm Child Psychol. 1985 Mar;13(1):69-87. Source Database: Medline.
Conrad WG, Dworkin ES, Shai A, Tobiessen JE. Effects of amphetamine tharapy and prescriptive tutoring on the behavior and achievement of lower class hyperactive children. J Learn Disabil. 1971;4:509-17. Source Database: reference list Schachar review article.
Fehlings DL, Roberts W, Humphries T, Dawe G. Attention deficit hyperactivity disorder: Does cognitive behavioral therapy improve home behavior?. J Dev Behav Pediatrics. 1991 Aug;12(4):223-8. Source Database: Medline.
Firestone P, Crowe D, Goodman JT, McGrath P. Vicissitudes of follow-up studies: Differential effects of parent training and stimulant medication with hyperactives. Am J Orthopsychiatry. 1986 Apr;56(2):184-94. Source Database: Medline.
Gillberg C, Melander H, von Knorring AL, Janols LO, Thernlund G, Hagglof B, Eidevall-Wallin L, Gustafsson P, Kopp S. Long-term stimulant treatment of children with attention-deficit hyperactivity disorder symptoms. A randomized, double-blind, placebo-controlled trial. Arch Gen Psychiatry. 1997 Sep;54(9):857-64. Source Database: Medline.
Gittelman-Klein R, Klein DF, Katz S, Saraf K, Pollack E. Comparative effects of methylphenidate and thioridazine in hyperkinetic children. I. Clinical results. Arch Gen Psychiatry. 1976 Oct;33(10):1217-31. Source Database: Medline.
Greenhill LL, Rieder RO, Wender PH, Buchsbaum M, Zhan TP. Lithium carbonate in the treatment of hyperactive children. Arch Gen Psychiatry. 1973 May;28(5):636-40. Source Database: Medline.
Greenhill LL, Abikoff HB, Arnold LE, Cantwell DP, Conners CK, Elliott G, Hechtman L, Hinshaw SP, Hoza B, Jensen PS, March JS, Newcorn J, Pelham WE, Severe JB, Swanson JS, Vitiello B, Wells K. Medication treatment strategies in the MTA study: Relevance to clinicians and researchers. J Am Acad Child Adolesc Psychiatry. 1996;34(10):1304-13. (same study as MTA Cooperative Group, 1999). Source Database: Medline.
Hinshaw SP, March JS, Abikoff H, Arnold LE, Cantwell DP, Conners CK, Elliott GR, Halperin J, Greenhill LL, Hechtman LT, Hoza B, Jensen PS, Newcorn JH, McBurnett K, Pelham WE, Richters JE, Severe JB, Schiller E, Swanson J, Vereen D, Wells K, Wigal T. Comprehensive assessment of childhood Attention-Deficit Hyperactivity Disorder in the context of a multisite, multimodal clinical trial. J Attention Dis. 1997;1(4):217-34. (same study as MTA Cooperative Group, 1999). Source Database: Medline.
Kupietz SS, Winsberg BG, Richardson E, Maitinsky S. Effects of methylphenidate dosage in hyperactive reading-disabled children: I. Behavior and cognitive performance effects. J Am Acad Child Adolesc Psychiatry. 1988 Jan;27(1):70-7. Source Database: PsycINFO.
Linden M, Habib T, Radojevic V. A controlled study of the effects of EEG biofeedback on cognition and behavior of children with attention deficit disorder and learning disabilities. Biofeedback Self Regul. 1996 Mar;21(1):35-49. Source Database: Medline.
MTA Cooperative Group. 14-month randomized clinical trial of treatment strategies for attention deficit hyperactivity disorder. Multimodal Treatment Study of Children with ADHD. Arch Gen Psychiatry. 1999 Dec;56(12):1073-86.
Quinn PO, Rapoport JL. One-year follow-up of hyperactive boys treated with imipramine or methylphenidate. Am J Psychiatry. 1975 Mar;132(3):241-5. Source Database: Medline.
Richters JE, Arnold IE, Jensen PS, Abikoff H, Conners CK, Greenhill LL, Hechtman L, Hinshaw SP, Pelham WE, Swanson JM. NIMH Collaborative Multisite Multimodal Treatment Study of children with ADHD: I. Background and rationale. J Am Acad Child Adolesc Psychiatry. 1995 Aug;34(8):987-1000. (same study as MTA Cooperative Group, 1999). Source Database: Medline.
Schachar RJ, Tannock R, Cunningham C, Corkum PV. Behavioral, situational, and temporal effects of treatment of ADHD with methylphenidate. J Am Acad Child Adolesc Psychiatry. 1997 Jun;36(6):754-63. Source Database: Medline.

## Adult Studies (n = 13)

Conners CK, Levin ED, Sparrown E, Hinton SC, Erhardt D, Meck WH, Rose JE, March J. Nicotine and attention in adult attention deficit hyperactivity disorder (ADHD). Psychopharmacol Bull. 1996;32(1):67-73. Source Database: Medline. [pmid: 8927677].
DeVeaugh-Geiss J, Joseph A. Paradoxical response to amphetamine in a hyperkinetic adult. Psychosomatics. 1980;21(3):247-52. Source Database: Embase. [pmid: 7367570].
Ernst M, Liebenauer LL, Jons PH, Tebeka D, Cohen RM, Zametkin AJ. Selegiline in adults with attention deficit hyperactivity disorder: Clinical efficacy and safety. Psychopharmacol Bull. 1996;32(3):327-34. Source Database: Medline. [pmid: 8961775].
Ernst M, Liebenauer LL, Tebeka D, Jons PH, Eisenhofer G, Murphy DL, Zametkin A J. Selegiline in ADHD adults: Plasma monoamines and monoamine metabolites. Neuropsychopharmacology. 1997 Apr;16(4):276-84. (Same study as Ernst, Liebenauer, Jons et al., 1996) Source Database: Medline.
Evans SW, Vallano G, Pelham W. Treatment of parenting behavior with a psychostimulant: A case study of an adult with attention-deficit hyperactivity disorder. J Child Adolesc Psychoparmacol. 1994;4(1):63-9. Source Database: Embase.
Matochik JA, Liebenauer LL, King C, Szymanski HV, Cohen RM, Zametkin AJ. Cerebral glucose metabolism in adults with attention deficit hyperactivity disorder after chronic stimulant treatment. Am J Psychiatry. 1994;151(5):658-64. Source Database: Embase. [pmid: 8166305].
Mattes JA, Boswell L, Oliver H. Methylphenidate effects on symptoms of attention deficit disorder in adults. Arch Gen Psychiatry. 1984 Nov;41(11):1059-63. Source Database: Medline.
Reimherr FW, Wender PH, Ebert MH, Wood DR. Cerebrospinal fluid homovanillic acid and 5-hydroxy-indoleacetic acid in adults with attention deficit disorder, residual type. Psychiatry Res. 1984 Jan;11(1):71-8. Source Database: Medline.
Spencer T, Wilens T, Biederman J, Faraone SV, Ablon JS, Lapey K. A double-blind, crossover comparison of methylphenidate and placebo in adults with childhood-onset attention-deficit hyperactivity disorder. Arch Gen Psychiatry. 1995 Jun;52(6):434-43. Source Database: Medline.
Wender PH, Reimherr FW, Wood DR. Attention deficit disorder ('minimal brain dysfunction') in adults. A replication study of diagnosis and drug treatment. Arch Gen Psychiatry. 1981 Apr;38(4):449-56. Source Database: Medline.
Wender PH, Reimherr FW, Wood D, Ward M. A controlled study of methylphenidate in the treatment of attention deficit disorder, residual type, in adults. Am J Psychiatry. 1985 May;142(5):547-52. Source Database: Medline.
Wilens TE, Biederman J, Prince J, Spencer TJ, Faraone SV, Warburton R, Schleifer D, Harding M, Linehan C, Geller D. Six-week, double-blind, placebo-controlled study of desipramine for adult attention deficit hyperactivity disorder. Am J Psychiatry. 1996 Sep;153(9):1147-53. Source Database: Medline.
Wood DR, Reimherr FW, Wender PH. Treatment of attention deficit disorder with DL-phenylalanine. Psychiatry Res. 1985 Sep;16(1):21-6. Source Database: Medline.

## Adverse Effect Studies RCTs ONLY (n = 31)

Ahmann PA, Waltonen SJ, Olson KA, Theye FW, Van Erem AJ, LaPlant RJ. Placebo-controlled evaluation of Ritalin side effects. Pediatrics. 1993 Jun;91(6):1101-6. Source Database: Medline. [pmcid: 375534].
Arnold LE, Christopher J, Huestis R, Smeltzer DJ. Methylphenidate vs dextroamphetamine vs caffeine in minimal brain dysfunction: Controlled comparison by placebo washout design with Bayes' analysis. Arch Gen Psychiatry. 1978 Apr;35(4):463-73. Source Database: Medline.
Arnold LE, Huestis R, Smeltzer,DJ, Scheib J, Wemmer D, Colner G. Levoamphetamine vs dextroamphetamine in minimal brain dysfunction. Replication, time response, and differential effect by diagnostic group and family rating. Arch Gen Psychiatry. 1976;33(3):292-301. Source Database: Medline. [pmid: 769721].
Barkley RA, McMurray M B, Edelbrock CS, Robbins K. Side effects of methylphenidate in children with attention deficit hyperactivity disorder: A systemic, placebo-controlled evaluation. Pediatrics. 1990 Aug;86(2):184-92. Source Database: Medline.
Barrickman LL, Perry PJ, Allen AJ, Kuperman S, Arndt SV, Herrmann KJ, Schumacher, E. Bupropion versus methylphenidate in the treatment of attention-deficit hyperactivity disorder. J Am Acad Child Adolesc Psychiatry. 1995 May;34(5):649-57. Source Database: Medline.
Buitelaar JK, van der Gaag RJ, Swaab-Barneveld H, Kuiper M. Pindolol and methylphenidate in children with attention-deficit hyperactivity disorder. Clinical efficacy and side-effects. J Child Psychol Psychiatry. 1996 Jul;37(5):587-95. Source Database: Medline.
Castellanos FX, Giedd JN, Elia J, Marsh WL, Ritchie GF, Hamburger SD, Rapoport JL. Controlled stimulant treatment of ADHD and comorbid Tourette's syndrome: Effects of stimulant and dose. J Am Acad Child Adolesc Psychiatry. 1997 May;36(5):589-96. Source Database: Medline.
Conners CK, Taylor E. Pemoline, methylphenidate, and placebo in children with minimal brain dysfunction. Arch Gen Psychiatry. 1980 Aug;37(8):922-30. Source Database: Medline.
Elia J, Borcherding BG, Rapoport JL, Keysor CS. Methylphenidate and dextroamphetamine treatments of hyperactivity: Are there true nonresponders?. Psychiatry Res. 1991 Feb;36(2):141-55. Source Database: Medline.
Fine S, Johnston C. Drug and placebo side effects in methylphenidate-placebo trial for attention deficit hyperactivity disorder. Child Psychiatry Hum Dev. 1993;4(1):25-30. Source Database: Medline.
Fitzpatrick PA, Klorman R, Brumaghim JT, Borgstedt AD. Effects of sustained-release and standard preparations of methylphenidate on attention deficit disorder. J Am Acad Child Adolesc Psychiatry. 1992 Mar;31(2):226-34. Source Database: Medline.
Gadow KD, Nolan EE, Sverd J. Methylphenidate in hyperactive boys with comorbid tic disorder: II. Short-term behavioral effects in school settings. J Am Acad Child Adolesc Psychiatry. 1992 May;31(3):462-71. (Same study as Gadow, Sverd, Sprafkin et al., 1995). Source Database: Medline.
Gadow KD, Nolan E, Sprafkin J, Sverd J. School observations of children with attention-deficit hyperactivity disorder and comorbid tic disorder: Effects of methylphenidate treatment. J Dev Behav Pediatr. 1995 Jun;16(3):167-76. (Same study as Gadow, Sverd, Sprafkin et al., 1995). Source Database: Medline.
Gadow KD, Sverd J, Sprafkin J, Nolan EE, Ezor SN. Efficacy of methylphenidate for attention-deficit hyperactivity disorder in children with tic disorder [published erratum appears in Arch Gen Psychiatry 1995 Oct;52(10):836]. Arch Gen Psychiatry. 1995 Jun;52(6):444-55. Source Database: Medline.
Gillberg C, Melander H, von Knorring AL, Janols LO, Thernlund G, Hagglof B, Eidevall-Wallin L, Gustafsson P, Kopp S. Long-term stimulant treatment of children with attention-deficit hyperactivity disorder symptoms. A randomized, double-blind, placebo-controlled trial. Arch Gen Psychiatry. 1997 Sep;54(9):857-64. Source Database: Medline.
Gittelman-Klein R, Klein DF, Katz S, Saraf K, Pollack E. Comparative effects of methylphenidate and thioridazine in hyperkinetic children. I. Clinical results. Arch Gen Psychiatry. 1976 Oct;33(10):1217-31. Source Database: Medline.
Gittleman-Klein RG, Landa B, Mattes JA, Klein DF. Methylphenidate and growth in hyperactive children. A controlled withdrawal study. Arch Gen Psychiatry. 1988 Dec;45(12):1127-30. (Same study as Gittleman-Klein, Klein, Katz et al., 1976). Source Database: Medline.
Greenberg LM, Deem MA, McMahon S. Effects of dextroamphetamine, chlorpromazine, and hydroxyzine on behavior and performance in hyperactive children. Am J Psychiatry. 1972 Nov;129(5):532-9. Source Database: Medline.
Handen BL, Feldman H, Gosling A, Breaux AM, McAuliffe S. Adverse side effects of methylphenidate among mentally retarded children with ADHD. J Am Acad Child Adolesc Psychiatry. 1991 Mar;30(2):241-5. Source Database: Medline.
Klorman R, Brumaghim JT, Fitzpatrick PA, Borgstedt AD. Clinical effects of a controlled trial of methylphenidate on adolescents with attention deficit disorder. J Am Acad Child Adolesc Psychiatry. 1990 Sep;29(5):702-9. Source Database: Medline.
Klorman R, Coons HW, Borgstedt AD. Effects of methylphenidate on adolescents with a childhood history of attention deficit disorder: I. Clinical findings [published erratum appears in J Am Acad Child Adolesc Psychiatry 1987 Sep; 26(5): 820]. J Am Acad Child Adolesc Psychiatry. 26(3). 363. 7. Source Database: Medline.
Matochik JA, Liebenauer LL, King C, Szymanski HV, Cohen RM, Zametkin AJ. Cerebral glucose metabolism in adults with attention deficit hyperactivity disorder after chronic stimulant treatment. Am J Psychiatry. 1994;151(5):658-64. Source Database: Embase. [pmid: 8166305].
Pataki CS, Carlson GA, Kelly KL, Rapport MD, Biancaniello TM. Side effects of methylphenidate and desipramine alone and in combination in children. J Am Acad Child Adolesc Psychiatry. 1993 Sep;32(5):1065-72. (Same study as Rapport, Carlson, Kelly et al., 1993). Source Database: Medline.
Pelham WE J, Greenslade KE, Vodde-Hamilton M, Murphy DA, Greenstein JJ, Gnagy EM, Guthrie KJ, Hoover MD, Dahl RE. Relative efficacy of long-acting stimulants on children with attention deficit-hyperactivity disorder: A comparison of standard methylphenidate, sustained-release methylphenidate, sustained-release dextroamphetamine, and pemoline. Pediatrics. 1990 Aug;86(2):226-37. Source Database: Medline.
Quinn PO, Rapoport JL. One-year follow-up of hyperactive boys treated with imipramine or methylphenidate. Am J Psychiatry. 1975 Mar;132(3):241-5. Source Database: Medline.
Rapport MD, Carlson GA, Kelly KL, Pataki C. Methylphenidate and desipramine in hospitalized children: I. Separate and combined effects on cognitive function. J Am Acad Child Adolesc Psychiatry. 1993;32(2):333-42. Source Database: Medline. [pmid: 8444762].
Schachar RJ, Tannock R, Cunningham C, Corkum PV. Behavioral, situational, and temporal effects of treatment of ADHD with methylphenidate. J Am Acad Child Adolesc Psychiatry. 1997;36(6):754-63. Source Database: Medline. [pmid: 9183129].
Spencer T, Wilens T, Biederman J, Faraone SV, Ablon JS, Lapey K. A double-blind, crossover comparison of methylphenidate and placebo in adults with childhood-onset attention-deficit hyperactivity disorder. Arch Gen Psychiatry. 1995;52:444-55. Source Database: Medline. [pmid: 7771914].
Stein MA, Blondis TA, Schnitzler ER, O'Brien T, Fishkin J, Blackwell B, Szumowski E, Roizen NJ. Methylphenidate dosing: Twice daily versus three times daily. Pediatrics. 1996 Oct;98(4 Pt 1):748-56. Source Database: Medline.
Wender PH, Reimherr FW, Wood D, Ward M. A controlled study of methylphenidate in the treatment of attention deficit disorder, residual type, in adults. Am J Psychiatry. 1985 May;142(5):547-52. Source Database: Medline.
Winsberg BG, Press M, Bialer I, Kupietz S. Dextroamphetamine and methylphenidate in the treatment of hyperactive-aggressive children. Pediatrics. 1974 Feb;53(2):236-41. Source Database: Medline. [pmcid: 126268].
Zeiner P. Body growth and cardiovascular function after extended treatment (1.75 years) with methylphenidate in boys with attention-deficit hyperactivity Disorder. J Child Adolesc Psychoparmacol. 1995;5(2):129-38. Source Database: Embase.