# Appendix D. Computerized Database Library Search Strategy

Database: Medline <1966 -- 28-Nov-97> Set Search

- 001 exp "Behavioral Symptoms (Non MeSH)"/
- 002 hyperactiv:.tw,sh.
- 003 exp Cognition Disorders/
- 004 1 and 2
- 005 2 and 3
- 006 exp attention deficit disorder with hyperactivity/
- 007 attention deficit:.tw,sh.
- 008 6 or 7
- 009 4 or 5
- 010 8 or 9
- 011 minimal brain damage:.tw,sh.
- 012 minimal brain dysfunction:.tw,sh.
- 013 hyperkinetic syndrome:.tw,sh.
- 014 hyperkinetic reaction:.tw,sh.
- 015 impulsivity:.tw,sh.
- 016 inattent:.tw,sh.
- 017 10 or 11 or 12 or 13 or 14 or 15 or 16
- 018 random:.tw,sh,pt.
- 019 clinical trial:.tw,sh,pt.
- 020 comparative:.tw,sh.
- 021 case-control:.tw,sh.
- 022 cohort:.tw,sh.
- 023 18 or 19 or 20 or 21 or 22
- 024 17 and 23
- 025 17 and 18
- 026 17 and 19
- 027 17 and 20
- 028 17 and 21
- 029 17 and 22
- 030 29