# Appendix C. Results of the Systematic Review and Meta-Analyses

[This appendix includes a summary of the main findings and the list of the articles that were included. The full document is available upon request]

## Summary

### Context

--The Agency for Health Care Policy and Research (AHCPR) charged the McMaster Evidence-based Practice Centre (EPC) to conduct a comprehensive systematic review of the literature about the treatment of ADHD, with input from different groups of stakeholders. One of the strategies used to avoid duplication of work included a critical appraisal of existing systematic reviews and meta-analyses.

### Objective

--To identify and appraise published meta-analyses and systematic reviews on the treatment of ADHD and to produce an annotated bibliography.

### Data Sources

--MEDLINE, CINAHL, HealthSTAR, PsycINFO, and EMBASE were searched from their first issue date to September 1998; The Cochrane database (1998 issue 3); selected Internet sites and the files of investigators.

### Study Selection

--Review articles described as systematic reviews or meta-analyses or including methods section were selected independently by three reviewers.

### Data Extraction

--Two reviewers extracted, by consensus, information on the name, number and background of authors; publication year and language; funding, source of studies; years covered; type and number of studies included; language restrictions; methodological quality; and data on the population, interventions, and outcomes evaluated by the reviews.

### Results

--Thirteen reviews, published from 1982 to 1998, were included. Eight included meta-analysis and five a qualitative review. Nonpharmacological treatments were mentioned in six reviews and combination therapies in three. One review focused on the treatment of adults. Forty seven drugs and 20 adverse effects were mentioned. Most reviews had major methodological flaws.

### Conclusions

--Most published systematic reviews and meta-analyses on the treatment of ADHD have limited value to guide clinical, policy, and research decisions. A rigorous systematic review following established methodological criteria is warranted.

## List of appraised systematic reviews and meta-analyses

Goldman LS, Genel M, BezmanRJ, Slanetz PJ. Diagnosis and treatment of attention-deficit/hyperactivity disorder in children and adolescents. JAMA. 1998;279(14):1100-7. [pmid: 9546570].
DuPaul GJ, Eckert TL. The effects of school-based interventions for Attention Deficit hyperactivity disorder: A meta-analysis. School Psychol Rev. 1997;26(1):5-27.
Kavale K. The efficacy of stimulant drug treatment for hyperactivity: A meta-analysis. Learn Disabil. 1982;15(5):280-9.
Kavale KA, Forness SR. Hyperactivity and diet treatment: A meta-analysis of the Feingold hypothesis. Learn Disabil. 1983;16(6):324-30.
Losier BJ, McGrath PJ, Klein RM. Error patterns on the continuous performance test in non-medicated and medicated samples of children with and without ADHD: A meta-analytic review. Child Psychol Psychiatry. 1996;37(8):971-87.
Ottenbacher KJ,Cooper HM. Drug treatment of hyperactivity in children. Dev Med Child Neurol. 1983;25(3):358-66. [pmid: 6347775].
Schachar R, Tannock R. Childhood hyperactivity and psychostimulants: A review of extended treatment studies. Child Adolesc Psychopharmacol. 1993;3(2):81-97.
Shevell M, Schreiber R. Pemoline-associated hepatic failure: A critical analysis of the literature. Pediatr Neurol. 1997;16(1):14-6. [pmid: 9044395].
Silva RR, Munoz DM, Alpert M. Carbamazepine use in children and adolescents with features of attention-deficit hyperactivity disorder: a meta-analysis. Child Adolesc Psychiatry. 1996;35(3):352-8.
Spencer T, Biederman J, Wilens T, Harding M, O'Donnell D, Griffin S. Pharmacotherapy of attention-deficit hyperactivity disorder across the life. Child Adolesc Psychiatry. 1996;35(4):409-32.
Stein MA, Krasowski M, Leventhal BL, Phillips W, Bender BG. Behavioral and cognitive effects of methylxanthines. A meta-analysis of theophylline and caffeine. Arch Pediatr Adolesc Med. 1996;150(3):284-8. [pmid: 8603222].
Thurber S, Walker C.E. Medication and hyperactivity: A meta-analysis. Gen Psychol. 1983;108(1st half):79-86.
Wilens TE, Biederman J, Spencer TJ, Prince J. Pharmacotherapy of adult attention deficit/hyperactivity disorder: A review. Clin Psychopharmacol. 1995;15(4):270-9.