# Appendix B. Members of the Multidisciplinary Research Team: McMaster University Evidence-based Practice Center (MU-EPC)

## Local Research Team

The following individuals were consulted extensively and actively participated in all the steps of this project:

- Alejandro (Alex) R. Jadad, MD DPhil, Professor, Clinical Epidemiology and Biostatistics (CE&B), McMaster University; Co-Director, Canadian Cochrane Centre; and Director of the MU-EPC was the Task Order Leader for this proposal. Dr. Jadad coordinated the design, execution and reporting of the Task Order. Dr. Jadad also led the section on drug vs. drug comparisons.
- Michael Boyle, PhD, Professor and Research Coordinator in the Department of Psychiatry and Behavioural Neurosciences; Associate member of CE&B, McMaster University; and a member of the Centre for Studies of Children at Risk, Hamilton Health Sciences Corporation. Dr. Boyle provided methodological expertise to the project as well as knowledge of the diagnostic and assessment issues pertaining to children suffering from psychiatric disorders.He led the section on adverse effects and the discussion of issues related to sampling.
- Charles (Chuck) Cunningham, PhD, is a Clinical Child Psychologist for the Child and Family Centre, Hamilton Health Sciences Corporation; and Professor, Department of Psychiatry and Behavioural Neurosciences; associate member CE&B, McMaster University. Dr. Cunningham is the Chair ofthe Professional Advisory Board for the organization Children and Adults with Attention-Deficit Disorders (CHADD) in Canada.He has been extensively involved in both clinical and research activities for children suffering from ADHD.Dr. Cunningham synthesized the data on antidepressants vs. placebo and on the treatment of ADHD in adults.
- Marie Kim, MD, is an Assistant Professor in the Departments of Pediatrics at both McMaster University and University of Western Ontario.She is a pediatrician with expertise in neurodevelopmental issues and is currently a graduate student in the McMaster Health Research Methodology program. Dr. Kim led the development of the sections on combination therapy and nondrug vs. drug comparisons.
- Russell Schachar, MD, is a Professor in the Department of Psychiatry at the University of Toronto; the Director of Child Psychiatry Research at the Hospital for Sick Children in Toronto; and Senior Scientist in the Research Institute at the Hospital for Sick Children in Toronto. He has published extensively in the field of pediatric psychiatry, including a systematic review of long-term studies (1996).Dr. Schachar led the section focusing on long-term studies.
- Andrew (Andy) R. Willan, Professor, CE&B, McMaster University, is a biostatistican and has overseen the statistical direction and support for the Task Order.He provided advice on the design of the extraction forms and the programming and implementation of the technology that was used for data extraction, storage, and analysis.
- Stuart MacLeod, MD, is the Director of the Father Sean O'Sullivan Resaerch Center at St. Joseph's Hospital, Hamilton; Professor, CE&B, Medicine and Pediatrics, McMaster University.Dr. MacLeod is a clinical pharmacologist and provided input on the pharmacological issues associated with the treatment of ADHD.
- Deborah Cook, MD, MSc, Associate Professor, CE&B, McMaster University, has significant expertise in systematic reviews and provided methodological input to the design and execution of the review.

## Representatives from Nominating Organizations

- American Academy of Pediatrics (AAP): All members of the AAP Subcommittee on ADHD participated actively in the task order, providing input during the formulation of the research questions, the development of the data extraction forms, and support during the search for systematic reviews on the treatment of ADHD. Members of this Subcommittee include Dr. James Perrin (Co-Chair), Dr. Martin Stein (Co-Chair), Dr. Robert Amler, Dr. Thomas Blondis, Dr. Ronald Brown, Dr. Anthony DeSpirito, Dr. Heidi Feldman, Dr. Theodore Ganiats, Dr. Brian Grabert, Dr. Charles Homer, Dr. Bruce Meyer, Dr. Karen Pierce, Dr. Bennett Shaywitz, Dr. Mark Wolraich, and Ms. Carla Herrerias (coordinator).
- American Psychiatry Association (APA): Dr. Deborah Zarin, Deputy Medical Director, American Psychiatric Association, provided background materials from the APA and acted as the liaison with that organization. She also provided input during the formulation of the research questions, the development of the data extraction forms, and support during the search for systematic reviews on the treatment of ADHD.

## Consumer Representative

- Carmela Vidic is a member of the Hamilton local chapter of CHADD.Ms. Vidic has made presentations to government officials and school boards on the topic of ADHD and is a social worker in her professional life. She is also the mother of three children, one of whom has been diagnosed with ADHD.

## Staff Involved with the Task Order

- Lynda Booker, BA, is a Research Assistant and was the second reviewer/abstractor for the research articles included in this review. Ms. Booker was also involved with the development of search strategies, identification of eligible articles, and the presentation and design of many of the evidence tables. Ms. Booker also coordinated data extraction and synthesis for the review of reviews.
- Mary Gauld, BA, has been the Research Coordinator for the Task Order. Working under the direction of the Task Order Leader, Ms. Gauld coordinated all aspects of the production of the evidence report, including supervision of other staff and ensuring planning and communication structures in keeping with the timelines set for various aspects of the Task Order.Ms. Gauld was also one of two reviewers and abstractors for the research articles included in this review.
- Ritz Kakuma, BA,was the Office Assistant on the Task Order.Ms. Kakuma was primarily responsible for conducting the literature searches and managing the office files, as well as preparing and editing the various reports submitted to AHCPR.
- Ann McKibbon, MLS,is a medical librarian in the Health Information Research Unit.She provided invaluable expertise and advise to the group in searching, reviewing, and abstracting the medical literature.
- Debbie Robinson provided support as accounting clerk, monitoring University financial statements and assisting in the preparation of monthly reports and invoices to AHCPR.
- Anne Snider, MEd, is the Coordinator of the MU-EPC and provided the overall coordination of the monthly reporting and financial management. Ms. Snider also acted as the liaison within the McMaster community, as well as with external bodies such as the AHCPR Contracts Office and subcontractors such as the San Francisco Cochrane Center.
- Elizabeth Wiecek, MD, worked along with Andy Willan, our biostatistician, coordinating the development the database using traditional programming methods (SAS) along with the new technology.Together Drs. Willan and Wieczek developed a plan to use MicroSoft Office Version 8.0, MicroSoft Access program, and the TELEform Designer software for data extraction.