# Appendix J: Acronyms and Abbreviations

AACAP: American Association of Child and Adolescent Psychiatry

AAP: American Academy of Pediatrics

AC: attention control

ACRS: Abbreviated Conners Rating Scale

ACTeRS: ADD-H Comprehensive Teachers' Rating Scale

AD: anxiety disorder

ADD: Attention-Deficit Disorder (DSM-I-III)

ADDES: Attention-Deficit Disorder Evaluation Scale

ADHD: Attention-Deficit/Hyperactivity Disorder (DSM-IIIR-IV)

AHRQ: Agency for Healthcare Research and Quality

AMA: American Medical Association

APA: American Psychiatric Association

Afro: African American

BC/Mod: behavioral contingencies/modification

BDI: Beck's depression inventory

Beh: behavioral treatment

BPC: Behavior Problem Checklist

CAAS: Children's Attention and Adjustment Survey

CAP: Child Attention Profile

CBCL: Child Behavior Check List

CBT: cognitive behavioral therapy

CC: community service providers

CCOHTA: Canadian Coordinating Office for Health Technology Assessment

CCT: Children's Checking Task

CD: conduct disorder

CDRS: Children's Depression Rating Scale

CEFT: Children's Embedded Figures Test

CGI: Clinical Global Improvement

CGP: corrected grade placement

CHADD: Children and Adults with Attention-Deficit Disorders

CLAM: Conners, Loney, and Milich

Clin: clinician

Comb: combined

Com: community

CONSORT: Consolidation of the Standards of Reporting Trials

CommPhy: community physicians

CPRS: Conners Parent Rating Scale

CPT: Continuous Performance Test

CT: child training

DD: depressive disorder

Des: desipramine

DETROIT: Detroit Tests of Learning Aptitude

DEX: dextroamphetamine, dexamphetamine

DSM: Diagnostic and Statistical Manual of Mental Disorders

DTS: Doctor's Target Symptoms Scale

Dx: Diagnosis

EEG: electroencephalogram

EFT: Embedded Figures Test

EPC: Evidence-based Practice Center

HAM-A: Hamilton Anxiety Rating Scale

HoIP: hospital inpatient

HoOP: hospital outpatient

HSQ: Home Situations Questionnaire

HySy: hyperkinetic syndrome

InMe: individual method

IGRS: Inpatient Global Rating Scale

IQ: intelligence quotient

KBIT: Kaufman brief intelligence

KIDDIE-SADS: Schedule for Affective Disorders and Schizophrenia for Children

L-amph: l-amphetamine

LD: learning disorder

MASC: Multidimensional Anxiety Scale for Children

MBD: minimal brain dysfunction/damage

MedMgt: medication management

MFFT: Matching Familiar Figures Test

MHOP: mental health clinic outpatient

MPH or MPH-reg: methylphenidate

MPH-SR: sustained-release methylphenidate

MRIQ: mental retardation/low IQ

MTA: Multimodal Treatment Study of Children with ADHD

MU-EPC: McMaster University Evidence-based Practice Center

NIH: National Institutes of Health

NIMH: National Institute of Mental Health

NM: none mentioned

NP: none present

NR: not reported

NS: not significant

ODD: oppositional defiant disorder

PAL: Paired Associate Learning

PC: pediatric clinic

PCOP: pediatric clinic outpatient

PET: positron emission tomograph

PGS: Physician's Global Rating Scale

POMS: profile of mood states

PT: parent training

PTSR: Physician's Target Symptom Ratings

RBPC: Revised Behavior Problem Checklist

RCT: randomized controlled trial

RSE: reinforced self-evaluation

SCL90: Derogitais Symptom Checklist 90

SCRS: Self Control Rating Scale

SD: standard deviation

SEM: standard error of the mean

SEP: Stimulus Equivalence Paradigm

SNAP: Swanson, Nolan, and Pelham

SSERS: Stimulant Side Effects Rating Scale

SSQ: School Situations Questionnaire

ST: supportive therapy

STESS: Subjective Treatment Emergent Symptom Scale

STM: Short Term Memory Task

STROOP: A test to measure interference in serial verbal reactions

Teach: teacher

TeDi: teacher diagnosis

THIOR: thioridazine

TIP: telephone interview probe

TOO: Task Order Officer

TOTS: Time on Task Scale

Touret: Tourettes's syndrome

TRF: Teacher Report Form

WAIS-R: Weschler Adult Intelligence Scaled-Revised

WISC: Wechsler Intelligence Scale for Children

WRAT: Wide Range Achievement Tests