# Appendixes

Appendix A. DSM-IV Criteria for Attention-Deficit/Hyperactivity Disorder from the American Psychiatric Association

Appendix B. Members of the Multidisciplinary Research Team: McMaster University Evidence-based Practice Center (MU-EPC)

Appendix C. Results of the Systematic Review and Meta-Analyses

Appendix D. Computerized Database Library Search Strategy

Appendix E: Data Extraction Form for ADHD Studies

Appendix F. Quality Assessment Scale

Appendix G: Peer Review Process

Appendix H: Reference List of All Included Articles by Categories

Appendix I: Reference List of Articles Considered but Not Included in This Review

Appendix J: Acronyms and Abbreviations