# Summary Tables

Summary Table 1. Success rates of various techniques used to obtain semen in men with SCI

Summary Table 1. Success rates of various techniques used to obtain semen in men with SCI

Author, Year | Study Design | Number of patients | Technique | Success rates | Quality
Bensman & Kottke, 1966 | Noncomparative case series | 5 | Electrostimulator | Sperm obtained in 3/5 from retrograde ejaculate; no motile sperm in 2/5; in 1/3 with 410K sperm/cm4, 20–30% of the sperm had abnormal forms | 4/19
Brackett et al., 2000 | Case-control | 12 | Vas aspirated to ejaculated sperm | Vas aspirated sperm motility and viability plus or minus standard error of mean were significantly higher than mean ejaculated sperm motility and viability (54.4% +/- 5.0% and 74.1% +/- 5.3% versus 14.1% +/- 2.6% and 26.1% +/- 4.9%, respectively) | 7* (NOS)
Brindley et al., 1986 | Noncomparative case series | 12 | Implanted sperm reservoir | 8 pts (67%) motile spermatozoa were recovered | 6/19
| | | | 2 pregnancies (17%) achieved with subsequent live births (by AIH).
Hirsch et al., 1994 | Case-control | 10 | Testicular biopsy | Spermatogenesis similar between SCI men and controls | 4* (NOS)
Perkash et al., 1985 | Noncomparative case series | 30 | Electrical stimulator | Sperm count in n=18 men >40 million | 7/19
| | | | Total sperm count in 22 pts >20 million
| | | | Normal Sperm morphology: mean 55%, range 40–75%
| | | | Sperm progressive motility <20% in 27 of 35 specimens
| | | | No motile in 10 specimens & less than 10% motile in 13; 10%–20% motile in 4 pts; >30% motile in 5 pts

NOS = Newcastle Ottawa Scale

Summary Table 2. Study examining the impact of freezing sperm

Summary Table 2. Study examining the impact of freezing sperm

Author, Year | Study Design | Number of patients | Fertility Rate | Quality
Padron et al., 1994 | Controlled clinical trial | 9 | Frozen sperm from SCI men retain motility similar to that of normal men | Not applicable (non-RCT)

Summary Table 3. Success rates and complications observed with electroejaculation and/or vibration

Summary Table 3. Success rates and complications observed with electroejaculation and/or vibration

Author/Year | Procedure | Success Ratio* | Complications
Sarkarati et al. (1987) | Vibration | 29/34 | Pain in 4/34 pts.(electroejaculation)
| Electroejaculation | | Minor headache and/or 20 to 40 mm.Hg increase in systolic BP occurred in a few patients (autonomic dysreflexia)
Pryor et al. (1995) | Vibration | 6/6 | Case 1: headaches and spasticity due to ephedrine, switched to imipramine
| Case 1: ephedrine, imipramine, sodium bicarb. | | Case 2: NR (not recorded)
| Case 2: ephedrine and sodium bicarb, imipramine and sodium bicarb | | Case 3: NR
| Case 3: | | Case 4: NR
| Case 4: ephedrine and sodium bicarb | | Case 5: NR
| Case 5: | | Case 6: NR
| Case 6: intra-uterine insemination
Lim et al. (1994) | Electroejaculation | 12/12 | “No incidence of severe hypertension due to autonomic dysreflexia”
| Vibration | | “Post-electroejaculation proctoscopy showed no damage to the rectal mucosa of any patient”
| | | “1 patient had significant problems with recurrent urinary tract infections”
| | | “1 pt complained of severe stomach cramps during electroejaculation”
VerVoort et al. (1988) | Electroejaculation | 7/7 | “All patients complained of headache/blurred vision/sweating/flushing and increased BP with no nifedipine”
| | | “Autonomic hyperreflexia effects reduced during electroejaculation with nifedipine”
Sonksen et al. (1994) | Vibration | 58/66 | “Population I: 4 pts had light headache/no increase in BP;1 pt had glycerine nitrate sublingual”
| Population I - 25 pts.(Vibrator A, no nifedipine) | | “Population II - no discomfort”
| Population II - 41pts.(Vibrator B, nifedipine sublingual prophylactically)
Heruti et al. (2001) | Electroejaculation | 14/14 | Abdominal pain or spasm in 17 stimulations
| | | raised BP in 15 stimulations
| | | 3 cases of increased spasm
| | | 1 case of syncope
| | | occurred in total of 16 patients, no tx needed, no further complications
Brindley (1981) | Electroejaculation | 50/84 | 7 pts experienced intolerable pain - procedure stopped
Halstead et al. (1987) | Electroejaculation | 10/12 | Mild dysreflexia (3pts) disruption of normal bowel program (1 pt)
Rawicki & Hill (1991) | Electroejaculation | 24/38 | Electroejaculation: autonomic hyperreflexia in pts with high lesions; pain in pts with low lesions
| Vibration | | Vibration: autonomic hyperreflexia in pts with high lesions; 1pt with superficial ulcer; 2 pts with superficial trauma to the glans resulting in bruising
| Subcutaneous physostigmine | | Subcutaneous physostigmine: blurring vision (4/5); nausea and vomiting (2/5); marijuana-like highs (2/5)
| 24 pt total
| (3 pt had electroejaculation under general anaesthetic due to pain)
| pts with lesions above C7 treated with labetolol 100mg or nifedipine 10mg

* success of ejaculation

Summary Table 4. Pregnancy and live birth rates for studies that used AF techniques compared with those that did not.

Summary Table 4. Pregnancy and live birth rates for studies that used AF techniques compared with those that did not

Study | N | AF vs non-AF | Pregnancies | Live births
Brackett 1995 | 23 | AF | 11/23 (48%) | 8/23
Brinsden, 1997 | 35 | AF | 18/35 (51%) | 14/35
Dahlberg, 1995 | 35 | AF | 18/35 (51%) | 14/35
Elliot, 2002 | 73 | AF | NR | 45/73
Heruti, 2001 | 33 | AF | 18/33 (55%) | 18/33
Hultling, 1997 | 25 | AF | 16/25 (64%) | 11/25
Nehra, 1996 | 33 | AF | 17/33 (52%) | 17/33
Pryor, 1995 | 6 | AF | 5/6 (83%) | NR
Pryor, 2001 | 11 | AF | 8/11 (73%) | NR
Taylor, 1999 | 19 | AF | 14/19 (74%) | NR
Beretta, 1996 | 6 | non-AF | 3/6 (50%) | NR
Buch, 1993 | 6 | non-AF | NR | 2/6
Chung, 1997 | 27 | non-AF | 7/27 (26%) | 4/27
Halstead, 1987 | 10 | non-AF | 0/11 (0%) | NR
Hultling, 1994 | 12 | non-AF | 6/12 (50%) | 2/10
Leduc, 1992 | 6 | non-AF | 3/6 (50%) | 3/6
Lucas, 1991 | 10 | non-AF | 1/10 (10%) | 1/7
Sonksen, 1997 | 28 | non-AF | 10/28 (36%) | 9/28

NR=not reported

Summary Table 5. Studies examining various interventions for female sexual dysfunction

Summary Table 5. Studies examining various interventions for female sexual dysfunction

Author, Year | Study Design | Number of Patients | Quality Score
Whipple, 1996 | Case-control | 21 (16 SCI/5 controls) | 6* (NOS)
Komisaruk et al., 1997 | Case-control | 21 (16 SCI/5 controls) | 6* (NOS)
Sipski et al., 1995a | Case-control | 21 (13 SCI/8 controls) | 6* (NOS)
Sipski et al., 1995b | Case-control | 35 (25 SCI/10 controls) | 5* (NOS)
Sipski et al., 1996 | Case-control | 20 (10 SCI/10 controls) | 7* (NOS)
Sipski et al., 2001 | Case-control | 89 (68 SCI/21 controls) | 5* (NOS)
Sipski et al., 2000 | RCT | 19 | 2/5 (Jadad)

Summary Table 6. Evidence for the use of vasoactive agents to stimulate erection in men with SCI

Summary Table 6. Evidence for the use of vasoactive agents to stimulate erection in men with SCI

Author, Year | Topical Substance | Response | Quality Assessment
Beretta, 1993 | Transcutaneous Minoxidil | 4/15 had full erections | 8/19
Kim & McVary, 1995 | Topical prostaglandin | 2/9 had clinical erections | 10/19
Kim et al, 1995 | Topical papaverine gel | 3/12 had full erections | Not applicable (non-RCT)
Sonsken, 1992 | Nitroglycerine patch | 5/17 had full erections | 7/19

Summary Table 7. Evidence for the use of intraurethral Alprostadil to stimulate erection in men with SCI

Summary Table 7. Evidence for the use of intraurethral Alprostadil to stimulate erection in men with SCI

Author, Year | N | Results | Quality Assessment
Bodner, 1999 | 15 | 3/15 achieved erections sufficient for intercourse | 8/19
Waldbaum, 1998 | 15 | 4/15 achieved erections sufficient for intercourse | Not applicable (abstract)

Summary Table 8. Case-series evidence for the use of penile implants for erectile dysfunction in men with SCI

Summary Table 8. Case-series evidence for the use of penile implants for erectile dysfunction in men with SCI

Author, Year | N Implants | Complications | Quality Score
Golji, 1979 | 30 | 2 cases infection causing extrusion | 7/19
| | 2 cases wound infections treated conservatively
Green & Sloan, 1986 | 40 | 3 cases extruded rods | 7/19
| | 1 case penile erosion
Gross et al., 1996 | 209 | 14 cases requiring removal of implant | 5/19
| | 21 cases rod perforation
Iwatsubo et al., 1986 | 37 | 2 cases infection causing extrusion | 5/19
| | 1 case severe pain
| | 1 case mechanical failure
Montague, 1994 | 47 | 2 cases infection requiring removal | 6/19
| | 1 case penile erosion requiring removal
| | 2 cases mechanical failure

Summary Table 9. RCT evidence for the use of Viagra® for sexual dysfunction in men with SCI

Summary Table 9. RCT evidence for the use of Viagra® for sexual dysfunction in men with SCI

Author, Year, Location | Number of subjects (N); | Results | Adverse Events | Quality Score
| Number of dropouts (D)
Giuliano et al., 1999 France, U.K., Australia | N=178 | 76% improved erections and a preference for Viagra® vs 4% for placebo | Headache: Viagra®=30, placebo=8 | 3/5 (Jadad)
| D=7 | | Flushing: Viagra®=12, placebo=2
| | | Dyspepsia: Viagra®=5, placebo=0
| | | Visual effects: Viagra®=4, placebo=0
| | | Rhinitis: Viagra®=3, placebo=0
Maytom et al., 1999, UK | N=27 | Erections in clinic >60% at base: Viagra®=65%; placebo=8% | Headache: Viagra®=4, placebo=1 | 3/5 (Jadad)
| D= 0 | Global Efficacy Question (did treatment improve erections?): Viagra®=75%; placebo=7% | Dyspepsia: Viagra®=1, placebo=0
| | | Vomiting: Viagra®=1, placebo=0
| | | Dizziness: Viagra®=1, placebo=0
| | | Rash: Viagra®=2, placebo=3

Summary Table 10. Side effects associated with the use of intracavernous injection or Viagra® for sexual dysfunction in men with SCI

Summary Table 10. Side effects associated with the use of intracavernous injection or Viagra® for sexual dysfunction in men with SCI

Author, Year | Intervention (number of pts) | Side Effects (number of pts)
Anonymous, (1999) | Viagra® (26) | 2 pts with dyspepsia and respiratory disorder
Clontz et al., 1999 (abstract) | Viagra® (12) | visual changes (1) and headache (3)
Derry FA et al., (1998) | Viagra® (27), vibration | headache (4)
| | dyspepsia (1)
| | dizziness (1)
| | anxiety (1)
Giuliano et al., (1999) | Viagra® (178) | headache (30)
| | flushing(12)
| | dyspepsia(5)
| | rhinitis (3)
| | abnormal vision (4)
| | discontinued treatment (6)
Kier et al., 1999 | Viagra® (29) | visual change (3%)
| | headache (17%)
| | dizziness (3%)
| | flushing (3%)
Laschke et al., (abstract, 2002) | Viagra® (69) | headaches and flushing (25%)
Sanchez et al., 2001 | Viagra® (170) | headache (10)
| | flushing (15)
| | GI discomfort (7)
| | nasal congestion (8)
| | visual disturbances (7)
| | restlessness, palpitations, hiccup, dry mouth (9)
| | unbearable abdominal pain (1)
Schmid et al., 2000 | Viagra® (41) | headache(3) or dizziness(2)
| | flushing (2)
| | dyspepsia (1)
| | blurred vision (1)
| | 2 withdrew because of adverse events
Shenot et al., 1999 (abstract) | Viagra® (29) | headache (7%)
| | flushing (7%)
Takeda et al., 2000 (abstract) | Viagra® (36) | headache, facial flush, chest strangled feeling
Beretta et al., 1986 | Papaverine (22) | 7 pts with prolonged erections
Earle et al., 1992 | Papaverine, papaverine & phentolamine, prostaglandin E1 (22) | pain with 2 pts, one using papaverine one using papaverine and phentolamine
Hirsch et al., 1994 | Prostaglandin E1 (14) | 2 pts with subclinical corporal fibrosis
Kapoor et al., 1993 | Papaverine: 101 volunteers, 65 papaplegics, 36 tetraplegics | 3 subcutaneous haematoma, 2 cavernosal fibrosis, 3 prolonged erection, 1 systemic effects
Renganathan et al., 1997 | Transdermal nitroglycerin vs papaverine (28) | 9 pts complications with papaverine: 8 had mild edema, 1 pt with prolonged erection
Sidi et al., 1987 | Papaverine HCl, or combo papaverine/phentolamine mesylate (66) | 4 pts with sustained erections that required irrigation
Tang et al., 1995 | Prostaglandin E1 (15) | 2 pts pain at injection site
Zaslau et al., 1999 | Fixed combo of prostaglandin E1 and papaverine (37) | 2 pts stopped due to pain/ecchymosis at injection site

Summary Table 11. Side effects associated with intracavernous injections

Summary Table 11. Side effects associated with intracavernous injections

Author, Year | N treated | Substance | Side Effects | Quality Score
Beretta et al. 1986 | 22 | Papaverine | 7 had priapism | 5/19
Earle et al. 1992 | 22 | Papaverine, papaverine & phentolamine, prostaglandin E1 | pain with 2 pts, one using papaverine one using papaverine and phentolamine | 7/19
Hirsch et al. 1994 | 27 | Prostaglandin E1 | 2 had penile scarring detectable only on ultrasound after repeated use | 6/19
Kapoor et al. 1993 | 101 | Papaverine | 3 had subcutaneous haematoma | 10/19
| | | 2 had cavernosa fibrosis after 3 years use
| | | 1 had priapism
| | | 1 had a vasovagal reaction requiring dosage reduction
Renganathan et al. 1997 | 28 | Papaverine | 1 had priapism | 0/5 (Jadad)
| | | 8 had local swelling requiring no intervention
Sidi et al. 1987 | 66 | Papaverine or papaverine/phentolamine mixture | 4 had priapism | 13/19
| | | 3 had minor hematomas
| | | 1 had localized site induration requiring discontinuation
Tang et al. 1995 | 15 | Prostaglandin E1 | 2 complained of pain at injection site | 12/19
Zaslau et al. 1999 | 28 | Papaverine and prostaglandin E1 mixture | 2 complained of pain at injection site | 10/19