# List of Excluded Studies

### Fertility

Alici B, Ozkara H, Tunc B, et al. The preferred treatment options by spinal cord-injured male patients; a prospective study. Int J Impot Res. 2002;14(Suppl 4):s61. No measure of fertility reported. [pmid: 11896482].
Amador M J. Contemporary information regarding male infertility following spinal cord injury. SCI Nurs. 1998;15(3):61-5. No measure of fertility reported.
Amador MJ. Guide and resources directory to male fertility following SCI/D. 17th American association of spinal cord injury nurses conference 2000;35-5. No measure of fertility reported.
Amble JS, Lannoye-Amble R. The winding road of infertility: the successful path to parenthood with SCI. 18th American association of spinal cord injury nurses conference 2001;53–4. No measure of fertility reported.
Amelar R D, Dubin L. Sexual function and fertility in paraplegic males. Urology. 1982;20(1):62-5. No measure of fertility reported. [pmid: 7112799].
Andres P. Sexual and genital prognosis in adult paraplegics. Paraplegia. 1972;10(3):218. No measure of fertility reported. [pmid: 4636923].
Atterbury J L, Groome L J. Pregnancy in women with spinal cord injuries. [Review] [52 refs]. Crit Care Nurs Clin North Am. 1998;33(4):603-13. No measure of fertility reported.
Auroux M. [Spermatogenesis, the central nervous system and paraplegia (author's transl)]. [French]. Journal d Urologie et de Nephrologie. 1974;80(78):621-30. No measure of fertility reported. [pmid: 4444064].
Bar-Chama N. Assisted reproductive technologies. J Spinal Cord Med. 2000;23(3):175. No measure of fertility reported.
Barros A, Sousa M, Andrade M J, et al. Birth after electroejaculation coupled to intracytoplasmic sperm injection in a gun-shot spinal cord-injured man. Arch Androl. 1998;41(1):5-9. No measure of fertility reported. [pmid: 9642453].
Beckerman H, Becher J, Lankhorst G J. The effectiveness of vibratory stimulation in anejaculatory men with spinal cord injury. [Review] [29 refs]. Paraplegia. 1993;31(11):689-99. No measure of fertility reported. [pmid: 8295779].
Benevento B T, Sipski M L. Neurogenic bladder, neurogenic bowel, and sexual dysfunction in people with spinal cord injury. [Review] [100 refs]. Phys Ther. 2002;82(6):601-12. No measure of fertility reported. [pmid: 12036401].
Bennett C J, Seager S W, Vasher E A, et al. Sexual dysfunction and electroejaculation in men with spinal cord injury: review. [Review] [63 refs]. Br J Urol. 1988;139(3):453-7. No measure of fertility reported.
Beretta G, Zanollo A, Colpi G M, et al. [Vibration massage in genito-sexual rehabilitation of spinal cord injuries. Our experience]. [Italian]. Minerva Urol Nefrol. 1985;37(2):203-6. No pre and post intervention fertility rate reported. [pmid: 4081959].
Beretta G, Zanollo A, Fanciullacci F, et al. Intracavernous injection of papaverine in paraplegic males. Acta Eur Fertil. 1986;17(4):283-4. No measure of fertility reported. [pmid: 3577592].
Berger S. The role of sexual impotence in the concept of self in male paraplegics. Zh Nevropatol Psikhiatr Im S S Korsakova. No measure of fertility reported.
Biering S, Sonksen J. Sexual function in spinal cord lesioned men. Proc Annu Clin Spinal Cord Inj Conf. 2001;39(9):455-70. No measure of fertility reported.
Biering-Sorensen F, Sonksen J. Sexual function in spinal cord lesioned men. Proc Annu Clin Spinal Cord Inj Conf. 2001;39(9):455-70. No measure of fertility reported.
Bird V G, Brackett N L, Lynne C M, et al. Reflexes and somatic responses as predictors of ejaculation by penile vibratory stimulation in men with spinal cord injury. Proc Annu Clin Spinal Cord Inj Conf. 2001;39(10):514-9. No pre and post intervention fertility rate reported.
Blockmans D, Steeno O. Physostigmine as a treatment for anejaculation with paraplegic men. Andrologia. 1988;20(4):311-3. Not an original report of an intervention trial. [pmid: 3195723].
Bodner D R, Seftel A D. Sildenafil in treatment of erectile dysfunction in SCI patients. J Spinal Cord Med. 2000;23(Suppl 1):46-6. No measure of fertility reported.
Bodner D R, Seftel A, Krueger B. Intraurethral Alprostsdil (MUSE) for treatment of erectile dysfunction in spinal cord injured patients. J Spinal Cord Med. 1998;21(2):186-7. No measure of fertility reported.
Boone T B, Kim E D, Kim Y H, et al. Advances in impotence and fertility technology for neurologically disabled men. Physical Medicine & Rehabilitation: State of the Art Reviews. 1997;11(1):161-76. No measure of fertility reported.
Brackett N L. Penile vibratory stimulation for men with spinal cord injury. Hum Reprod Update. 1999;5(5):551-2. No measure of fertility reported. [pmid: 10582793].
Brackett N L. Semen retrieval by penile vibratory stimulation in men with spinal cord injury. Hum Reprod Update. 1999;5(3):216-22. No measure of fertility reported. [pmid: 10438106].
Brackett N L, Ferrell S M, Aballa T C, et al. An analysis of 653 trials of penile vibratory stimulation in men with spinal cord injury. Br J Urol. 1998;159(6):1931-4. No pre and post intervention fertility rate reported.
Brackett N L, Nash M S, Lynne C M. Male fertility following spinal cord injury: facts and fiction. Phys Ther. 1996;76(11):1221-31. No measure of fertility reported. [pmid: 8911434].
Brindley G S. Sexual and reproductive problems of paraplegic men. Oxf Rev Reprod Biol. 1986;8(214):222. No measure of fertility reported.
Brindley G S. Reflex ejaculation under vibratory stimulation in paraplegic men. Paraplegia. 1981;19(5):299-302. No measure of fertility reported. [pmid: 7279433].
Brown JF. Patient abuse by partners?. J Spinal Cord Med 1998;21(conference proceedings). No measure of fertility reported.
Brown T R. Anejaculation in quadriplegia. [letter; comment.]. Arch Phys Med Rehabil. 1995;76(9):889. No measure of fertility reported. [pmid: 7668965].
Brown T R, Hensleigh H C, Nagel T C, et al. Anejaculation in quadriplegia. Vibratory stimulation for treatment of anejaculation in quadriplegic men. Arch Phys Med Rehabil. 1995;76(9):889. No measure of fertility reported. [pmid: 7668965].
Bustillo M, Rajfer J. Pregnancy following insemination with sperm aspirated directly from vas deferens. Fertil Steril. 1986;46(1):144-6. No measure of fertility reported. [pmid: 3720972].
Byfield G, LaFavor K, Murphy D, et al. Inpatient sexual health needs of individuals with acute spinal cord injury. J Spinal Cord Med. 1999;22(1):13-4. No measure of fertility reported.
Byfield G, Tymus-Brown T, Laud P, et al. Sexual health needs of persons with spinal cord injury six months after discharge. J Spinal Cord Med. 2000;23(Suppl 1):33. No measure of fertility reported.
Chapelle P A. [Pregnancy achieved by ambulatory treatment of an ejaculation in the paraplegic man. Apropos of a case]. [French]. Journal d Urologie. 1983;89(3):165-8. Reported in a language other than English. [pmid: 6688263].
Chapelle P A, Colbeau-Justin P, Durand J, et al. [Ejaculation problems in traumatic paraplegia]. [French]. Sem Hop. 1982;58(2829):1691-7. Reported in a language other than English. [pmid: 6289450].
Chapelle P A, Jondet M, Durand J, et al. Pregnancy of the wife of a complete paraplegic by homologeous insemination after an intrathecal injection of neostigmine. Paraplegia. 1976;14(3):173-7. Not an original report of an intervention trial. [pmid: 1036617].
Chen D, Hartwig D, Jeyendran R S. Azoospermia - a unique challenge in the treatment of infertility in a spinal cord injured man. J Spinal Cord Med. 2000;23(Suppl 1):43. Not an original report of an intervention trial.
Chen D, Ling E A, Jeyendran R S. Semen extenders to salvage ejaculate in a retrograde ejaculate environment: a potential use in spinal cord-injured men. Arch Phys Med Rehabil. 1995;76(5):446-9. No pre and post intervention fertility rate reported. [pmid: 7741615].
Chung P H, Palermo G, Schlegel P N, et al. The use of intracytoplasmic sperm injection with electroejaculates from anejaculatory men. Hum Reprod. 1998;13(7):1854-8. No measure of fertility reported. [pmid: 9740438].
Chung P H, Verkauf B S, Eichberg R D, et al. Electroejaculation and assisted reproductive techniques for anejaculatory infertility. Curr Opin Obstet Gynecol. 1996;87(1):22-6. Not an original report of an intervention trial.
Chung P H, Yeko T R, Mayer J C, et al. Assisted fertility using electroejaculation in men with spinal cord injury--a review of literature. [Review] [56 refs]. Fertil Steril. 1995;64(1):1-9. No measure of fertility reported. [pmid: 7789540].
Clontz D, Kier A, Land D, et al. Effects of sildenafil on spinal cord injury patients suffering from erectile dysfunction. J Spinal Cord Med. 1999;22(1):48-9. No measure of fertility reported.
Courtois F, Mathieu C, Charvier K. Sexual rehabilitation for men with spinal cord injury: Preliminary report on a behavioral strategy. Sex Disabil. 2001;19(2):153-7. No measure of fertility reported.
Craven C B C, Mittmann N, Gordon M, et al. The cost utility of Viagra for treatment of erectile dysfunction in men after SCI. J Spinal Cord Med. 2002;25(Suppl 1):s44-5. No measure of fertility reported.
Craven C B C, Mittmann N, Kaiser A, et al. The “hard truth” an information resource for men with SCI and erectile dysfunction. J Spinal Cord Med. 2002;25(Suppl 1):s44. No measure of fertility reported.
Creasey G H. Restoration of bladder, bowel, and sexual function. Topics in Spinal Cord Injury Rehabilitation. 1999;5(1):21-32. No measure of fertility reported.
Cross L L, Meythaler J M, Tuel S M, et al. Pregnancy, labour and delivery post spinal cord injury. Paraplegia. 1992;30(12):890-902. No fertility intervention reported. [pmid: 1287543].
Denil J, Kuczyk M A, Schultheiss D, et al. Use of assisted reproductive techniques for treatment of ejaculatory disorders. Andrologia. 1996;28(Suppl 143):51. SCI results not reported separately.
Denil J, Ohl D A, McGuire E J, et al. Treatment of anejaculation with electroejaculation. Acta Urol Belg. 1992;60(3):15-25. Not an original report of an intervention trial. [pmid: 1492631].
Donatucci CF, Lue TF. Pathophysiology of sexual dysfunction in males with physical disabilities. Clin Exp Hypertens 291–310. No measure of fertility reported.
Donohue J, Gebhard P. The Kinsey Institute/Indiana University report on sexuality and spinal cord injury. Sex Disabil. 1995;13(1):7-85. No measure of fertility reported.
Drench M E. Impact of altered sexuality and sexual function in spinal cord injury: A review: Sex Disabil 1992;10(1):11–14. No measure of fertility reported.
Ekland M B, Rines B A. Women's experience of sexual adjustment post spinal cord injury. J Spinal Cord Med. 2002;25(Suppl1):s44. No measure of fertility reported.
Ekland M, Griffin S, Copeland J, et al. Exploring male fertility options after spinal cord injury: the role of the nurse clinician. [Review] [7 refs]. SCI Nurs. 1998;15(4):95-8. No measure of fertility reported. [pmid: 10347544].
Elliot S, Szasz G, Zouves C. The combined use of vibrostimulation and in vitro fertilization: successful pregnancy outcome from a retrograde specimen obtained from a spinal cord-injured male. J In Vitro Fert Embryo Transf. 1991;8(6):348-52. No measure of fertility reported. [pmid: 1770277].
Elliott S. Anejaculation, fertility and sex. Can J Hum Sex. 1996;2(3):124-7. No measure of fertility reported.
Elliott S P, Orejuela F, Hirsch I H, et al. Testis biopsy findings in the spinal cord injured patient. Br J Urol. 2000;163(3):792-5. No fertility intervention reported.
Fernandez J B, Barber D B, Able A C, et al. Acute spinal cord injury in pregnancy: cases and literature review. J Spinal Cord Med. 2000;23(3):182. No measure of fertility reported.
Fiedler K, Lochner-Ernst D, Krusmann G, et al. Two pregnancies after in-vitro fertilization with spermatozoa from alloplastic spermatocoeles. Hum Reprod. 1993;8(3):422-4. No measure of fertility reported. [pmid: 8473460].
Fisher T, Byfield G, Tymus T, et al. The profile of sexual health needs of individuals one year after spinal cord injury. J Spinal Cord Med. 2001;24(Suppl 1):s35. No measure of fertility reported. [pmid: 11587433].
Francois M, Maury M, Jouannet P, et al. [Our experience with electro-ejaculation in paraplegics. First pregnancies]. [French]. Journal d Urologie et de Nephrologie. 1979;85(78):513-24. Reported in a language other than English. [pmid: 529373].
Francois N. [Genital sexual and procreation disorders in patients with spinal cord injuries]. [French]. Rev Prat. 1995;45(16):2017-21. Reported in a language other than English. [pmid: 8578112].
Francois N, Maury M. Sexual aspects in paraplegic patients. Paraplegia. 1987;25(3):289-92. No measure of fertility reported. [pmid: 3601441].
Francois N, Jouannet P, Maury M. [Genitosexual function of paraplegics]. [French]. Journal d Urologie. 1983;89(3):159-64. Reported in a language other than English. [pmid: 6875295].
Francois N, Maury M, David G, et al. [Electric stimulation of ejaculation in paraplegia. Possibilities of impregnation using artificial insemination]. [French]. Acta Urol Belg. 1979;47(1):173-86. Reported in a language other than English. [pmid: 312001].
Goddard L R. Sexuality and spinal cord injury. J Neurosci Nurs. 1988;20(4):240-4. No measure of fertility reported. [pmid: 2973501].
Green B G, Killorin E W, Bennett J K, et al. Erectile response following administration of sildenafil citrate (Viagra) in the neuropathic patient:initial results. J Spinal Cord Med. 1999;22(1):48. No measure of fertility reported.
Green B, Killorin E W, Rozas K, et al. Results of elective electroejaculation with freezing and subsequent sperm manipulation versus electroejaculation at ovulation to achieve pregnancy in male factor spinal cord injured males. J Spinal Cord Med. 2000;23(Suppl 1):45. No measure of fertility reported. [pmid: 10752874].
Grundy D, Russell J. ABC of spinal cord injury. Later management and complications--I. Br Med J (Clin Res Ed). 1986;292(6521):677-80. No measure of fertility reported. [pmid: 2418908].
Halstead L S, Seager S W J. Fertility aspects of men with spinal cord injury: results obtained by electroejaculation. Arch Phys Med Rehabil. 1999;80:1119. SCI results not reported separately.
Hazama M, Nakano M, Shinozaki M, et al. [A case of a complete paraplegic fathering a girl following artificial insemination after an intrathecal neostigmine injection]. [Review] [12 refs] [Japanese]. Hinyokika Kiyo - Acta Urologica Japonica. 1988;34(6):1047-50. Reported in a language other than English. [pmid: 3066212].
Higgins G E. Sexual response in spinal cord injured adults: a review of the literature. Arch Sex Behav. 1979;8(2):173-96. No measure of fertility reported. [pmid: 475578].
Hirsch I H, Jeyendran R S, Sedor J, et al. Biochemical analysis of electroejaculates in spinal cord injured men: comparison to normal ejaculates. Br J Urol. 1991;145(1):73-6. No pre and post intervention fertility rate reported.
Hirsch I H, Kulp-Hugues D, Sedor J, et al. Simplified and objective assessment of spermatogenesis in spinal cord injured men by flow cytometry analysis. Paraplegia. 1993;31(12):785-92. No measure of fertility reported. [pmid: 8115171].
Hirsch I H, Seager S W, Sedor J, et al. Electroejaculatory stimulation of a quadriplegic man resulting in pregnancy. Arch Phys Med Rehabil. 1990;71(1):54-7. No measure of fertility reported. [pmid: 2297310].
Hirsch I H, Sedor J, Callahan H J, et al. Systemic sperm autoimmunity in spinal-cord injured men. Arch Androl. 1990;25(1):69-73. No fertility intervention reported. [pmid: 2389995].
Hirsh A V, Mills C, Tan S L, et al. Pregnancy using spermatozoa aspirated from the vas deferens in a patient with ejaculatory failure due to spinal injury. Hum Reprod. 1993;8(1):89-90. No measure of fertility reported. [pmid: 8458935].
Holstein A F, Sauerwein D, Schirren U. [Spermatogenesis in patients with traumatic transverse paralysis]. [German]. Rev Med Interna Neurol Psihiatr Neurochir Dermatovenerol Med Interna. 1985;24(4):208-15. Reported in a language other than English.
Hovatta O, von Smitten K. Sperm aspiration from vas deferens and in-vitro fertilization in cases of non-treatable anejaculation. Hum Reprod. 1993;8(10):1689-91. SCI results not reported separately. [pmid: 8300829].
Hudson BS. Erectile dysfunction options for SCI males. 17th American association of spinal cord injury nurses conference 2000;34. No measure of fertility reported.
Jackson A B. Pregnancy and delivery. for women with disabilities. Sex Disabil. 1996;14(3):211-9. Not an original report of an intervention trial.
Jackson R W. Sexual rehabilitation after cord injury. Paraplegia. 1972;10(1):50-5. No measure of fertility reported. [pmid: 5039328].
Jondet M, Got C L, Chapelle P A, et al. [Full term pregnancy in the wife of a total paraplegic following intrathecal injection of neostigmine and artificial insemination] [letter]. [French]. Nouv Presse Med. 1976;5(35):2325. Reported in a language other than English.
Jouannet P, Francois N, Maury M. [Evaluation of fertility in paraplegic men]. [French]. Journal d Urologie. 1983;89(3):169-71. Reported in a language other than English. [pmid: 6875296].
Keeshin S, Lane G, Kanter S, et al. Medical and psychosocial issues in women with spinal cord injury: a comprehensive survey. Arch Phys Med Rehabil. 1999;80:1119. No measure of fertility reported.
Key BH, Hale AM, Jackson AB. Promoting accessible health care examinations for women with SCI. 15th American association of spinal cord injury nurses conference 1998;43. No measure of fertility reported.
Kier AJ, Kennelly MJ, Holdren RE, et al. Sildenafil effects on spinal cord patients with erectile dysfunction. 16th American association of spinal cord injury nurses conference 1999;32–33. No measure of fertility reported.
Kimura Y. [Sexual function of the paraplegics; with a special reference to erection and ejaculation]. [Japanese]. Nippon Hinyokika Gakkai Zasshi. 1970;61(10):1010-6. Reported in a language other than English. [pmid: 5529303].
Kolon T F, Philips K A, Buch J P. Pentoxifylline enhancement of post-thaw motility in cryopreserved semen of spinal cord-injured men. Int J Fertil Menopausal Stud. 1995;40(3):156-60. No pre and post intervention fertility rate reported. [pmid: 7663542].
Laschke S, Carl S, Staehler G, et al. Efficacy and reproducibility of sildenafil (Viagra) in erectile dysfunction in spinal cord injured men. J Spinal Cord Med. 2002;25(Suppl1):s43. No measure of fertility reported. [pmid: 11939466].
Leduc B E, Poulin O, Parisi D. [Pregnancy by insemination from a quadriplegic donor after stimulation by physostigmine]. [French]. CMAJ (Canadian Medical Association Journal). 1988;139(11):1071-2. Reported in a language other than English.
Leeton J, Yates C, Rawicki B. Successful pregnancy using known donor oocytes fertilized in vitro by spermatozoa obtained by electro-ejaculation from a quadriplegic husband. Hum Reprod. 1991;6(3):384-5. No measure of fertility reported. [pmid: 1955547].
Leriche A, Berard E, Vauzelle J L, et al. Histological and hormonal testicular changes in spinal cord patients. Paraplegia. 1977;15(3):274-9. No measure of fertility reported. [pmid: 593717].
Lewis JH. What's new in the treatment of erectile dysfunction. 15th American association of spinal cord injury nurses conference 1998;21. No measure of fertility reported.
Linsenmeyer T A. Male infertility following spinal cord injury. [Review] [48 refs]. J Am Paraplegia Soc. 1991;14(3):116-21. No measure of fertility reported. [pmid: 1885947].
Linsenmeyer T A. Sexual function and infertility following spinal cord injury. [Review] [52 refs]. Phys Med Rehabil Clin N Am. 2000;11(1):141-56. No measure of fertility reported. [pmid: 10680162].
Linsenmeyer TA. Management of male infertility. Vet J Ed 487–509. No measure of fertility reported.
Linsenmeyer T A. Overview of male infertility following SCI. J Spinal Cord Med. 2000;23(3):174. No measure of fertility reported.
Linsenmeyer T A, Perkash I. Infertility in men with spinal cord injury. [Review] [75 refs]. Arch Phys Med Rehabil. 1991;72(10):747-54. No measure of fertility reported. [pmid: 1929799].
Linsenmeyer T A, Perkash I. Infertility in men with spinal cord injury. Arch Phys Med Rehabil. 1991;72(10):747-54. No measure of fertility reported. [pmid: 1929799].
Linsenmeyer T, Ottenweller J, Anesetti R. Effects of Vitamin E/Selenium on sperm motility following SCI. J Spinal Cord Med. 1998;21(2):164. No measure of fertility reported.
Linsenmeyer T, Wilmot C, Anderson R U. The effects of the electroejaculation procedure on sperm motility. Paraplegia. 1989;27(6):465-9. No pre and post intervention fertility rate reported. [pmid: 2608300].
Loughead RM. Males' perception of changes in their sex role orientation as a function of spinal cord injury. Bull Acad Natl Chir Dent. No measure of fertility reported.
Lynne C M, Aballa T C, Wang T J, et al. Serum and semen prostate specific antigen concentrations are different in young spinal cord injured men compared to normal controls. Br J Urol. 1999;162(1):89-91. No fertility intervention reported.
Macourt D, Engel S, Jones R F, et al. Pregnancy by gamete intrafallopian transfer (GIFT) with sperm aspirated from the vaso-epididymal junction of spinal injured man: case report. Paraplegia. 1991;29(8):550-3. No measure of fertility reported. [pmid: 1775362].
Marina S, Marina F, Alcolea R, et al. Triplet pregnancy achieved through intracytoplasmic sperm injection with spermatozoa obtained by prostatic massage of a paraplegic patient: case report. Hum Reprod. 1999;14(6):1546-8. No measure of fertility reported. [pmid: 10357973].
Martin M M. Fertility in SCI males. SCI Nurs. 1992;9(1):36-8. No measure of fertility reported. [pmid: 1561542].
Mauney MC. Fertility program/electroejaculation-coordination of services. 17th American association of spinal cord injury nurses conference 2000;34–35. No measure of fertility reported.
McBride KE, Rines B. Sexuality and SCI: a roadmap for nurses. 15th American association of spinal cord injury nurses conference 1998;19. No measure of fertility reported.
McKenna K E. Neural circuitry involved in sexual function. [Review] [78 refs]. J Spinal Cord Med. 2001;24(3):148-54. No measure of fertility reported. [pmid: 11585233].
Mendius R A. Female sexuality and spinal cord injury. SCI Nurs. 1989;6(4):68-74. No measure of fertility reported. [pmid: 2631196].
Momose H, Hirao Y, Yamamoto M, et al. Electroejaculation in patients with spinal cord injury: first report of a large-scale experience from Japan. Int J Urol. 1995;2(5):326-9. No pre and post intervention fertility rate reported. [pmid: 8749952].
Monga M, Bernie J, Rajasekaran M. Male infertility and erectile dysfunction in spinal cord injury: a review. Arch Physical Med Rehabil. 1999;80(10):1331-9. No measure of fertility reported.
Murphy DF. Sexual health information sheets. 15th American association of spinal cord injury nurses conference 1998;37–8. No measure of fertility reported.
Nagai S, Kasai T, Ogawa K, et al. Successful treatment of infertility due to anejaculation with in vitro fertilization and embryo transfer: a report of two cases. Tohoku J Exp Med. 1998;184(3):241-6. Not an original report of an intervention trial. [pmid: 9591339].
Otani T, Kai S, Narushima M. Ejaculation obtained by intracavernous papaverine in a cervical spinal cord injury patient resulting in pregnancy and childbirth. Case report. Paraplegia. 1994;32(3):180-1. No measure of fertility reported. [pmid: 8008421].
Otani T, Kondo A, Takita T. A paraplegic fathering a child after an intrathecal injection of neostigmine: case report. Paraplegia. 1986;24(1):32-7. No measure of fertility reported. [pmid: 3754323].
Perkash I, Martin D E, Warner H. Reproductive problems of paraplegics and the present status of electroejaculation. Cent Nerv Syst Trauma. 1986;3(1):13-23. No measure of fertility reported. [pmid: 3488130].
Perkash I, Martin D E, Warner H, et al. Electroejaculation in spinal cord injury patients: simplified new equipment and technique. Br J Urol. 1990;143(2):305-7. No pre and post intervention fertility rate reported.
Piera J B. The establishment of a prognosis for genito-sexual function in the paraplegic and tetraplegic male. Paraplegia. 1973;10(4):271-8. Not an original report of an intervention trial. [pmid: 4696999].
Porter-Gaskins J. In search of baby. Accent on Living. 1996;41(3):50-52. No measure of fertility reported.
Powers J, Meats J, Saylor L, et al. Care of a pregnant spinal cord injured patient. 17th American association of spinal cord injury nurses conference 2000;40. No measure of fertility reported.
Rajasekaran M, Monga M. Cellular and molecular causes of male infertility in spinal cord injury. [Review] [52 refs]. J Androl. 1999;20(3):326-30. No measure of fertility reported. [pmid: 10386809].
Raviv G, Heruti R J, Shaked A, et al. Sexual rehabilitation: clinical experience with sildenafil citrate (Viagra) in spinal cord injured patients. Int J Impot Res. 2000;12(Suppl 5):s1. No measure of fertility reported.
Rawicki H, Lording D W. Assisted fertility in complete paraplegia: case report. Paraplegia. 1988;26(6):401-4. Not an original report of an intervention trial. [pmid: 3226767].
Raymond C A. New use for old method of inducing ejaculation may give hope of fatherhood to some spinal cord-injured men. JAMA. 1987;258(6):743-4. Not an original report of an intervention trial. [pmid: 3612994].
Romeo AJ. Sexual adjustment to spinal-cord injury. No measure of fertility reported.
Rucker B, Szasz G, Carpenter C. Legal, ethical and religious issues related to fertility enhancement of men with spinal cord injuries. Can J Rehabil. 1988;1(4):225-31. No measure of fertility reported.
Rutkowski S B, Geraghty T J, Hagen D L, et al. A comprehensive approach to the management of male infertility following spinal cord injury. Proc Annu Clin Spinal Cord Inj Conf. 1999;37(7):508-14. No measure of fertility reported.
Sadowsky C L. Electrical stimulation in spinal cord injury. NeuroRehabilitation. 2001;16(3):165-9. No measure of fertility reported. [pmid: 11790901].
Schatte E C, Orejuela F J, Lipshultz L I, et al. Treatment of infertility due to anejaculation in the male with electroejaculation and intracytoplasmic sperm injection. Br J Urol. 2000;163(6):1717-20. SCI results not reported separately.
Scheutzow M H, Bockenek W L. Electroejaculation in persons with spinal cord injury: a unique complication and review of the literature. Arch Phys Med Rehabil. 1998;79:1187. No measure of fertility reported.
Seager S W, Halstead L S. Fertility options and success after spinal cord injury. [Review] [32 refs]. Urol Clin North Am. 1993;20(3):543-8. No measure of fertility reported. [pmid: 8351779].
Sedor J F, Hirsch I H. Evaluation of sperm morphology of electroejaculates of spinal cord-injured men by strict criteria. Fertil Steril. 1995;63(5):1125-7. No pre and post intervention fertility rate reported. [pmid: 7720930].
Seftel A D, Bodner D R, Gothe B, et al. Efficacy of sildenafil in spinal cord injured men. J Spinal Cord Med. 2000;23(3):207. No measure of fertility reported.
Shaban S F, Seager S W, Lipshultz L I. Clinical electroejaculation. [Review] [31 refs]. Med Instrum. 1988;22(2):77-81. No measure of fertility reported. [pmid: 3285147].
Shenot P J, Rajan R, Rivas D A. Initial experience with sildenafil (viagra) in spinal cord injured men with erectile dysfunction. J Spinal Cord Med. 1999;22(1):49. No measure of fertility reported.
Siosteen A. Emission dysfunctions and current modes of treatment in neurogenic male infertility. Scand J Urol Nephrol 1988;Supplementum. 110(59):64. No measure of fertility reported.
Sipski ML. Spinal cord injury and sexual function: An educational model. Vet J Ed 149–176. No measure of fertility reported.
Sipski M L, Katz M A, Blight A R. The effects of oral fampridine-SR (sustained-release 4-aminopyridine) on sexual function in subjects with chronic motor-incomplete spinal cord injury. J Spinal Cord Med. 2003;26(Suppl 1):s18. No measure of fertility reported.
Sonksen J, Biering-Sorensen F. Semen quality in the same man before and after spinal cord injury. Case report. Paraplegia. 1994;32(2):117-9. No measure of fertility reported. [pmid: 8015844].
Sonksen J, Biering-Sorensen F. Fertility in men with spinal cord or cauda equina lesions. [Review] [85 refs]. Semin Neurol. 1992;12(2):106-14. No measure of fertility reported. [pmid: 1323870].
Sonksen J O, Biering-Sorensen F, Kristensen J K, et al. [Ejaculation induced by electrostimulation in men with spinal cord injuries]. [Danish]. Ugeskr Laeger. 1993;155(3):176-9. Reported in a language other than English. [pmid: 8421879].
Sonksen J, Ohl D A, Momose H, et al. Treatment of infertility. [see comments.]. [Review] [46 refs]. Proc Annu Clin Spinal Cord Inj Conf. 1999;37(2):89-95. Not an original report of an intervention trial.
Sprouse D O. Electroejaculation for anejaculate males. Urol Nurs. 1994;14(2):57-61. No measure of fertility reported. [pmid: 7709238].
Sprouse D O. Fertility issues and anejaculation. Urol Nurs. 1994;14(2):62-5. No measure of fertility reported. [pmid: 7709239].
Staerman F, Bryckaert P E, Youinou Y, et al. [Pharmacologic stimulation of ejaculation with midodrine hydrochloride (Gutron) for medically assisted reproduction in spinal injury]. [French]. Prog Urol. 2001;11(6):1264-8. Reported in a language other than English. [pmid: 11859662].
Stien R. Spinal cord injured men and infertility. [letter; comment.]. Proc Annu Clin Spinal Cord Inj Conf. 1999;37(7):527. No measure of fertility reported.
Stien R. Sexual dysfunctions in the spinal cord injured. Paraplegia. 1992;30(1):54-7. No measure of fertility reported. [pmid: 1589275].
Szasz G, Carpenter C. Clinical observations in vibratory stimulation of the penis of men with spinal cord injury. Arch Sex Behav. 1989;18(6):461-74. No pre and post intervention fertility rate reported. [pmid: 2604539].
Takeda H, Otani T, Ito Y. Efficacy of sildenafil citrate for ED associated with spinal cord injury. Int J Impot Res. 2000;12(Suppl 2):s19. No measure of fertility reported. [pmid: 10982308].
Tallada M, Ruiz F, Herruzo A, et al. [Intrathecal injection of neostigmine in a paraplegia patient, in order to obtain semen for artifical insemination]. [Spanish]. Actas Urol Esp. 1977;1(6):347-50. Reported in a language other than English. [pmid: 581036].
Tarabulcy E. Sexual function in the normal and in paraplegia. Paraplegia. 1972;10(3):201-8. No measure of fertility reported. [pmid: 4636921].
Tepper MS. Providing comprehensive sexual health care in SCI rehabilitation. 15th American association of spinal cord injury nurses conference 1998;26. No measure of fertility reported.
Thomas A J. Ejaculatory dysfunction. Fertil Steril. 1983;39(4):445-54. No measure of fertility reported. [pmid: 6832399].
Thomas R J, McLeish G, McDonald I A. Electroejaculation of the paraplegic male followed by pregnancy. Med J Aust. 1975;2(21):789. Not an original report of an intervention trial. [pmid: 1207568].
Tollon C, Soulie M, Pontonnier F, et al. [Prevention of sterility in spinal cord injured men]. [French]. Prog Urol. 1997;7(2):203-8. No measure of fertility reported. [pmid: 9264760].
Truss M C, Djamilian M H, Tan H K, et al. Single potential analysis of cavernous electrical activity. Four years' experience in more than 500 patients with erectile dysfunction. Eur Urol. 1993;24:358-65. No measure of fertility reported.
Urey Jon R. Marital adjustment following spinal cord injury: An analysis of recreational, sexual and conflict resolution behaviours. ADM No measure of fertility reported.
Veit N, Mikelonis M. Health Issues of women who have spinal cord impairment. 18th American association of spinal cord injury nurses conference 2001;25. No measure of fertility reported.
Velasco M, Buyo A, Barrera S, et al. Sexual and gynecologic issues in a sample of women with spinal cord injury. J Spinal Cord Med. 2002;25(Suppl 1):s45. No fertility intervention reported.
Ver Voort S M. Infertility in spinal-cord injured male. Urology. 1987;29(2):157-65. No measure of fertility reported. [pmid: 3544454].
Verduyn W H. Spinal cord injured women, pregnancy and delivery. Paraplegia. 1986;24(4):231-40. No measure of fertility reported. [pmid: 3763239].
Villeneuve M J. Sexual function and fertility: the impact of spinal cord injury. CONA Journal. 1989;11(1):12-7. No measure of fertility reported.
Wagenknecht L V. Alloplastic spermatocele: 20 years experience and perspectives. Acta Chir Hung. 1994;34(34):207-9. No measure of fertility reported. [pmid: 7618373].
Walbroehl G S. Impaired spermatogenesis. Am Fam Physician. 1987;36(5):45. No measure of fertility reported. [pmid: 3687663].
Waldbaum J, Chen D, Nussbaum S B, et al. Use of transurethral alprostadil to treat erectile dysfunction in spinal cord injured patients. Arch Phys Med Rehabil. 1998;79:1184. No measure of fertility reported.
Wang Y H, Huang T S, Lien I N. Hormone changes in men with spinal cord injuries. Am J Phys Med Rehabil. 1992;71(6):328-32. No fertility intervention reported. [pmid: 1466870].
Wang Y H, Huang T S, Lin M C, et al. Scrotal temperature in spinal cord injury. Am J Phys Med Rehabil. 1993;72(1):6-9. No measure of fertility reported. [pmid: 8431271].
Weinberg J S. Human Sexuality and spinal cord injury. Crit Care Nurs Clin North Am. 1982;17(3):407-19. No measure of fertility reported.
Winston A, Hirschenfang S, Fine L, et al. Patterns of psychological decompensation in patients with spinal cord syndromes. Dis Nerv Syst. 1969;30(12):824-7. No measure of fertility reported. [pmid: 5369133].
Wolski J K, Kluge P, Koziol K, et al. [Needle testicular biopsy in the diagnosis of male infertility]. [Polish]. Ginekol Pol. 1998;69(6):541-4. Not an original report of an intervention trial. [pmid: 9695380].
Yamamoto M, Momose H, Yamada K. Fathering of a child with the assistance of electroejaculation in conjunction with intracytoplasmic sperm injection: case report. Proc Annu Clin Spinal Cord Inj Conf. 1997;35(3):179-80. No measure of fertility reported.
Yamamoto M, Yamada K, Hirata N, et al. [Electroejaculation and assisted reproductive techniques in the patients with spinal cord injury]. [Japanese]. Nippon Hinyokika Gakkai Zasshi. 1997;88(3):420-6. Reported in a language other than English. [pmid: 9125866].
Yarkony G M. Enhancement of sexual function and fertility in spinal cord-injured males. Am J Phys Med Rehabil. 1990;69(2):81-7. No measure of fertility reported. [pmid: 2184843].
Yarkony G M, Chen D. Sexuality in patients with spinal cord injury. Physical Medicine & Rehabilitation: State of the Art Reviews. 1995;9(2):325-44. No measure of fertility reported.
Zeller F L, Lassalle G, Repetti P, et al. Electromyographical findings in patients with spinal cord injury and erectile dysfunction. Int J Impot Res. 2001;13(Suppl 2):s16. No measure of fertility reported. [pmid: 11313835].

### Sexual Dysfunction

Alici B, Ozkara H, Tunc B, et al. The preferred treatment options by spinal cord-injured male patients;a prospective study. Int J Impot Res. 2002;14(Suppl 4):s61. No measure of sexual dysfunction reported. [pmid: 11896482].
Amador M J. Contemporary information regarding male infertility following spinal cord injury. SCI Nurs. 1998;15(3):61-5. No measure of sexual dysfunction reported.
Amador MJ. Guide and resources directory to male fertility following SCI/D. 17th American association of spinal cord injury nurses conference 2000;35-5. No measure of sexual dysfunction reported.
Amble JS, Lannoye-Amble R. The winding road of infertility: the successful path to parenthood with SCI. 18th American association of spinal cord injury nurses conference 2001;53–4. No measure of sexual dysfunction reported.
Amelar R D, Dubin L. Sexual function and fertility in paraplegic males. Urology. 1982;20(1):62-5. No measure of sexual dysfunction reported. [pmid: 7112799].
Andres P. Sexual and genital prognosis in adult paraplegics. Paraplegia. 1972;10(3):218. No measure of sexual dysfunction reported. [pmid: 4636923].
Auroux M. [Spermatogenesis, the central nervous system and paraplegia (author's transl)]. [French]. Journal d Urologie et de Nephrologie. 1974;80(78):621-30. No measure of sexual dysfunction reported. [pmid: 4444064].
Bar-Chama N. Assisted reproductive technologies. J Spinal Cord Med. 2000;23(3):175. No measure of sexual dysfunction reported.
Beckerman H, Becher J, Lankhorst G J. The effectiveness of vibratory stimulation in anejaculatory men with spinal cord injury. Review article. [Review] [29 refs]. Paraplegia. 1993;31(11):689-99. No measure of sexual dysfunction reported. [pmid: 8295779].
Benevento B T, Sipski M L. Neurogenic bladder, neurogenic bowel, and sexual dysfunction in people with spinal cord injury. [Review] [100 refs]. Phys Ther. 2002;82(6):601-12. No measure of sexual dysfunction reported. [pmid: 12036401].
Bennett C J, Seager S W, Vasher E A, et al. Sexual dysfunction and electroejaculation in men with spinal cord injury: review. [Review] [63 refs]. Br J Urol. 1988;139(3):453-57. No measure of sexual dysfunction reported.
Bensman A, Kottke F J. Induced emission of sperm utilizing electrical stimulation of the seminal vesicles and vas deferens. Arch Phy Med Rehab. 1966;47(7):436-43. No measure of sexual dysfunction reported.
Beretta G, Chelo E, Zanollo A. Reproductive aspects in spinal cord injured males. Paraplegia. 1989;27(2):113-8. No measure of sexual dysfunction reported. [pmid: 2717193].
Beretta G, Zanollo A, Chelo E, et al. Seminal parameters and auto-immunity in paraplegic/quadraplegic men. Acta Eur Fertil. 1987;18(3):203-5. No measure of sexual dysfunction reported. [pmid: 3439407].
Beretta G, Zanollo A, Colpi G M, et al. [Vibration massage in genito-sexual rehabilitation of spinal cord injuries. Our experience]. [Italian]. Minerva Urol Nefrol. 1985;37(2):203-6. Reported in a language other than English. [pmid: 4081959].
Berger S. The role of sexual impotence in the concept of self in male paraplegics. Zh Nevropatol Psikhiatr Im S S Korsakova Concept No sexual dysfunction intervention reported.
Biering S, Sonksen J. Sexual function in spinal cord lesioned men. Proc Annu Clin Spinal Cord Inj Conf. 2001;39(9):455-70. No measure of sexual dysfunction reported.
Biering-Sorensen F, Sonksen J. Penile erection in men with spinal cord or cauda equina lesions. [Review] [76 refs]. Semin Neurol. 1992;12(2):98-105. No measure of sexual dysfunction reported. [pmid: 1502437].
Biering-Sorensen F, Sonksen J. Sexual function in spinal cord lesioned men. Proc Annu Clin Spinal Cord Inj Conf. 2001;39(9):455-70. No measure of sexual dysfunction reported.
Bird V G, Brackett N L, Lynne C M, et al. Reflexes and somatic responses as predictors of ejaculation by penile vibratory stimulation in men with spinal cord injury. Proc Annu Clin Spinal Cord Inj Conf. 2001;39(10):514-19. No sexual dysfunction intervention reported.
Bodner D R, Seftel A D. Sildenafil in treatment of erectile dysfunction in SCI patients. J Spinal Cord Med. 2000;23(Suppl 1):46. No measure of sexual dysfunction reported.
Bodner D R, Lindan R, Leffler E, et al. The application of intracavernous injection of vasoactive medications for erection in men with spinal cord injury. Br J Urol. 1987;138(2):310-11. No measure of sexual dysfunction reported.
Boone T B, Kim E D, Kim Y H, et al. Advances in impotence and fertility technology for neurologically disabled men. Physical Medicine & Rehabilitation: State of the Art Reviews. 1997;11(1):161-76. No measure of sexual dysfunction reported.
Boyce E G, Umland E M. Sildenafil citrate: a therapeutic update. Clin Ther. 2001;23(1):2-23. No measure of sexual dysfunction reported. [pmid: 11219477].
Brackett N L. Semen retrieval by penile vibratory stimulation in men with spinal cord injury. Hum Reprod Update. 1999;5(3):216-22. No measure of sexual dysfunction reported. [pmid: 10438106].
Brackett N L, Abae M, Padron O F, et al. Treatment by assisted conception of severe male factor infertility due to spinal cord injury or other neurologic impairment. Journal of Assisted Reproduction & Genetics. 1995;12(3):210-6. No measure of sexual dysfunction reported. [pmid: 8520188].
Brackett N L, Davi R C, Padron O F, et al. Seminal plasma of spinal cord injured men inhibits sperm motility of normal men. Br J Urol. 1996;155(5):1632-5. No measure of sexual dysfunction reported.
Brackett N L, Ferrell S M, Aballa T C, et al. An analysis of 653 trials of penile vibratory stimulation in men with spinal cord injury. Br J Urol. 1998;159(6):1931-4. No measure of sexual dysfunction reported.
Brackett N L, Lynne C M, Aballa T C, et al. Sperm motility from the vas deferens of spinal cord injured men is higher than from the ejaculate. Br J Urol. 2000;164(3 Pt 1):712-715. No measure of sexual dysfunction reported.
Brackett N L, Lynne C M, Weizman M S, et al. Endocrine profiles and semen quality of spinal cord injured men. Br J Urol. 1994;151(1):114-9. No sexual dysfunction intervention reported.
Brackett N L, Lynne C M, Weizman M S, et al. Scrotal and oral temperatures are not related to semen quality of serum gonadotropin levels in spinal cord-injured men. J Androl. 1994;15(6):614-9. No measure of sexual dysfunction reported. [pmid: 7721665].
Brackett N L, Nash M S, Lynne C M. Male fertility following spinal cord injury: facts and fiction. Phys Ther. 1996;76(11):1221-31. No measure of sexual dysfunction reported. [pmid: 8911434].
Brackett N L, Padron O F, Lynne C M. Semen quality of spinal cord injured men is better when obtained by vibratory stimulation versus electroejaculation. Br J Urol. 1997;157(1):151-7. No measure of sexual dysfunction reported.
Brackett N L, Santa-Cruz C, Lynne C M. Sperm from spinal cord injured men lose motility faster than sperm from normal men: the effect is exacerbated at body compared to room temperature. Br J Urol. 1997;157(6):2150-3. No measure of sexual dysfunction reported.
Brindley G S. Electroejaculation and the fertility of paraplegic men. Sexuality & Disability. 1981;3(3):225-229. No measure of sexual dysfunction reported.
Brindley G S. Electroejaculation: its technique, neurological implications and uses. J Neurol Neurosurg Psych. 1981;44(1):9-18. No measure of sexual dysfunction reported.
Brindley G S. Reflex ejaculation under vibratory stimulation in paraplegic men. Paraplegia. 1981;19(5):299-302. No measure of sexual dysfunction reported. [pmid: 7279433].
Brindley G S. The fertility of men with spinal injuries. Paraplegia. 1984;22(6):337-48. No measure of sexual dysfunction reported. [pmid: 6335235].
Brindley G S. Sexual and reproductive problems of paraplegic men. Oxf Rev Reprod Biol. 1986;8:214-22. No measure of sexual dysfunction reported. [pmid: 3540803].
Brindley G S. The Ferrier lecture, 1986. The actions of parasympathetic and sympathetic nerves in human micturition, erection and seminal emission, and their restoration in paraplegic patients by implanted electrical stimulators. Proc R Soc Lond B Biol Sci. 1988;235(1279):111-20. No measure of sexual dysfunction reported. [pmid: 2907141].
Brindley G S, Scott G I, Hendry W F. Vas cannulation with implanted sperm reservoirs for obstructive azoospermia or ejaculatory failure. Br J Urol. 1986;58(6):721-3. No measure of sexual dysfunction reported. [pmid: 3801834].
Brinsden P R, Avery S M, Marcus S, et al. Transrectal electroejaculation combined with in-vitro fertilization: effective treatment of anejaculatory infertility due to spinal cord injury. Hum Reprod. 1997;12(12):2687-92. No measure of sexual dysfunction reported. [pmid: 9455836].
Brown JF. Patient abuse by partners?. J Spinal Cord Med 1998;21(conference proceedings). No measure of sexual dysfunction reported.
Buch J P, Zorn B H. Evaluation and treatment of infertility in spinal cord injured men through rectal probe electroejaculation. Br J Urol. 1993;149(5 Pt 2):1350-4. No measure of sexual dysfunction reported.
Burks J S. Rehabilitation of multiple sclerosis patients with spinal cord dysfunction compared to spinal cord injury patients. J Neurol Rehabil. 1994;8(1):17-24. No measure of sexual dysfunction reported.
Burns A S, Jackson A B. Gynecologic and reproductive issues in women with spinal cord injury. Phys Med Rehabil Clin N Am. 2001;12(1):183-99. No measure of sexual dysfunction reported. [pmid: 11853036].
Burns A S, Rivas D A, Ditunno J F. The management of neurogenic bladder and sexual dysfunction after spinal cord injury. [Review] [82 refs]. Spine. 2001;26(24 Suppl):S129-36. No measure of sexual dysfunction reported. [pmid: 11805620].
Bustillo M, Rajfer J. Pregnancy following insemination with sperm aspirated directly from vas deferens. Fertil Steril. 1986;46(1):144-6. No measure of sexual dysfunction reported. [pmid: 3720972].
Byfield G, LaFavor K, Murphy D, et al. Inpatient sexual health needs of individuals with acute spinal cord injury. J Spinal Cord Med. 1999;22(1):13-4. No measure of sexual dysfunction reported.
Byfield G, Tymus-Brown T, Laud P, et al. Sexual health needs of persons with spinal cord injury six months after discharge. J Spinal Cord Med. 2000;23(Suppl 1):33. No measure of sexual dysfunction reported.
Chalouhy E, Armache K, Kassardjian Z, et al. [Implantation of the Ultrex type inflatable penile prosthesis. Four years experience]. [French]. Journal Medical Libanais - Lebanese Medical Journal. 1996;44(2):60-2. Reported in a language other than English.
Chapelle P A. [Pregnancy achieved by ambulatory treatment of an ejaculation in the paraplegic man. Apropos of a case]. [French]. J Urol (Paris). 1983;89(3):165-8. No measure of sexual dysfunction reported. [pmid: 6688263].
Chapelle P A, Blanquart F, Puech A J, et al. Treatment of anejaculation in the total paraplegic by subcutaneous injection of Physostigmine. Paraplegia. 1983;21(1):30-6. No measure of sexual dysfunction reported. [pmid: 6835690].
Chapelle P A, Colbeau-Justin P, Durand J, et al. [Ejaculation problems in traumatic paraplegia ]. [French]. Sem Hop. 1982;58(2829):1691-7. No measure of sexual dysfunction reported. [pmid: 6289450].
Chen D, Hartwig D M, Roth E J. Comparison of sperm quantity and quality in antegrade V retrograde ejaculates obtained by vibratory penile stimulation in males with spinal cord injury. Am J Phys Med Rehabil. 1997;78(1):46-55. No measure of sexual dysfunction reported.
Chen D, Hartwig D, Jeyendran R S. Azoospermia - a unique challenge in the treatment of infertility in a spinal cord injured man. J Spinal Cord Med. 2000;23(Suppl 1):43. No measure of sexual dysfunction reported.
Chung P H, Palermo G, Schlegel P N, et al. The use of intracytoplasmic sperm injection with electroejaculates from anejaculatory men. Hum Reprod. 1998;13(7):1854-8. No measure of sexual dysfunction reported. [pmid: 9740438].
Colombel P, Egon G, Isambert J L. [Electrostimulation of anterior sacral nerve roots in spinal cord injury patients (evaluation of the 1st 25 cases)]. [French]. Prog Urol. 1992;2(1):41-9. Reported in a language other than English. [pmid: 1299515].
Courtois F J, Charvier K F, Leriche A, et al. Clinical approach to erectile dysfunction in spinal cord injured men. A review of clinical and experimental data. [Review] [60 refs]. Paraplegia. 1995;33(11):628-35. No measure of sexual dysfunction reported. [pmid: 8584296].
Craven C B C, Mittmann N, Gordon M, et al. The cost utility of Viagra for treatment of erectile dysfunction in men after SCI. J Spinal Cord Med. 2002;25(Suppl1):s44-s45. No measure of sexual dysfunction reported.
Craven C B C, Mittmann N, Kaiser A, et al. The “hard truth” an information resource for men with SCI and erectile dysfunction. J Spinal Cord Med. 2002;25(Suppl1):s44. No measure of sexual dysfunction reported.
Creasey G H. Restoration of bladder, bowel, and sexual function. Topics in Spinal Cord Injury Rehabilitation. 1999;5(1):21-32. No measure of sexual dysfunction reported.
Cross L L, Meythaler J M, Tuel S M, et al. Pregnancy, labor and delivery post spinal cord injury. Paraplegia. 1992;30(12):890-902. No measure of sexual dysfunction reported. [pmid: 1287543].
Dahlberg A, Ruutu M, Hovatta O. Pregnancy results from a vibrator application, electroejaculation, and a vas aspiration programme in spinal-cord injured men. Hum Reprod. 1995;10(9):2305-7. No measure of sexual dysfunction reported. [pmid: 8530657].
de Lamirande E, Leduc B E, Iwasaki A, et al. Increased reactive oxygen species formation in semen of patients with spinal cord injury. Fertil Steril. 1995;63(3):637-42. No measure of sexual dysfunction reported. [pmid: 7851599].
DeKoker B. Sex and the spinal cord. Sci Am. 1996;275(6):30-2. No measure of sexual dysfunction reported. [pmid: 8923761].
Denil J, Kuczyk M A, Schultheiss D, et al. Use of assisted reproductive techniques for treatment of ejaculatory disorders. Andrologia. 1996;28(Suppl 1):43-51. No measure of sexual dysfunction reported. [pmid: 9082877].
Denil J, Ohl D A, McGuire E J, et al. Treatment of anejaculation with electroejaculation. Acta Urol Belg. 1992;60(3):15-25. No measure of sexual dysfunction reported. [pmid: 1492631].
Dollfus P, Jurascheck F, Adli G, et al. Impairment of erection after external sphincter resection. Paraplegia. 1976;13(4):290-293. No measure of sexual dysfunction reported. [pmid: 1264486].
Donohue J, Gebhard P. The Kinsey Institute/Indiana University report on sexuality and spinal cord injury. Sexuality & Disability. 1995;13(1):7-85. No sexual dysfunction intervention reported.
Drench M E. Impact of altered sexuality and sexual function in spinal cord injury: A review. Sex Disabil. 1992;10(1):11-4. No measure of sexual dysfunction reported.
Ekland M B, Rines B A. Women's experience of sexual adjustment post spinal cord injury. J Spinal Cord Med. 2002;25(Suppl1):s44. No measure of sexual dysfunction reported.
Ekland M, Griffin S, Copeland J, et al. Exploring male fertility options after spinal cord injury: the role of the nurse clinician. [Review] [7 refs]. SCI Nurs. 1998;15(4):95-8. No measure of sexual dysfunction reported. [pmid: 10347544].
Elliott S. Anejaculation, fertility and sex. Can J Hum Sex. 1996;2(3):124-7. No measure of sexual dysfunction reported.
Elliott S L, Griffin S, Ekland M, et al. Vibrostimulation - techniques and results. J Spinal Cord Med. 2000;23(3):175. No measure of sexual dysfunction reported.
Elliott S L, Nigro M, Ekland M B, et al. The Vancouver experience: sperm retrieval program. J Spinal Cord Med. 2002;25(Suppl 1):s14. No measure of sexual dysfunction reported.
Fernandez J B, Barber D B, Able A C, et al. Acute spinal cord injury in pregnancy: cases and literature review. J Spinal Cord Med. 2000;23(3):182. No measure of sexual dysfunction reported.
Fisher T, Byfield G, Tymus T, et al. The profile of sexual health needs of individuals one year after spinal cord injury. J Spinal Cord Med. 2001;24(Suppl 1):s35. No measure of sexual dysfunction reported. [pmid: 11587433].
Francois N. [Genital sexual and procreation disorders in patients with spinal cord injuries]. [French]. Rev Prat. 1995;45(16):2017-21. Reported in a language other than English. [pmid: 8578112].
Francois N, Maury M. Sexual aspects in paraplegic patients. Paraplegia. 1987;25(3):289-92. No measure of sexual dysfunction reported. [pmid: 3601441].
Francois N, Jouannet P, Maury M. [Genitosexual function of paraplegics]. [French]. J Urol (Paris). 1983;89(3):159-64. Reported in a language other than English. [pmid: 6875295].
Francois N, Maury M, David G, et al. [Electric stimulation of ejaculation in paraplegia. Possibilities of impregnation using artificial insemination]. [French]. Acta Urol Belg. 1979;47(1):173-86. No measure of sexual dysfunction reported. [pmid: 312001].
Green B G, Killorin E W, Bennett J K, et al. Erectile response following administration of sildenafil citrate (ViagraO) in the neuropathic patient:initial results. J Spinal Cord Med. 1999;22(1):48. Not an original report of an intervention trial with pre and post measures.
Green B, Killorin E W, Rozas K, et al. Results of elective electroejaculation with freezing and subsequent sperm manipulation versus electroejaculation at ovulation to achieve pregnancy in male factor spinal cord injured males. J Spinal Cord Med. 2000;23(Suppl 1):45. No measure of sexual dysfunction reported. [pmid: 10752874].
Grossiord A, Chapelle P A, Lacert P, et al. [The affected medullary segment in paraplegics. Relation to sexual function in men (author's transl)]. [French]. Rev Neurol (Paris). 1978;134(12):729-40. No measure of sexual dysfunction reported. [pmid: 572987].
Grundy D, Russell J. ABC of spinal cord injury. Later management and complications--I. Br Med J (Clin Res Ed). 1986;292(6521):677-80. No measure of sexual dysfunction reported. [pmid: 2418908].
Guldin A. Self-claiming sexuality: Mobility impaired people and American culture. Sex Disabil. 2000;18(4):225-38. No measure of sexual dysfunction reported.
Halstead L S, Seager S W J. Fertility aspects of Men with spinal cord injury: results obtained by electroejaculation. Arch Phys Med Rehabil. 1999;80:1119. No measure of sexual dysfunction reported.
Halstead L S, VerVoort S, Seager S W. Rectal probe electrostimulation in the treatment of anejaculatory spinal cord injured men. Paraplegia. 1987;25(2):120-9. No measure of sexual dysfunction reported. [pmid: 3495772].
Hatzichristou DG. Sildenafil citrate: lessons learned from 3 years of clinical experience. Int J Impot Res 2002;14 Suppl 1(S43):S52. No measure of sexual dysfunction reported.
Hellstrom W J, Stone A R, Deitch A D, et al. The clinical application of aspiration deoxyribonucleic acid flow cytometry to neurologically impaired men entering an electroejaculation program. Br J Urol. 1989;142(2 Pt 1):309-12. No measure of sexual dysfunction reported.
Heruti R J, Katz H, Menashe Y, et al. Treatment of male infertility due to spinal cord injury using rectal probe electroejaculation: the Israeli experience. Proc Annu Clin Spinal Cord Inj Conf. 2001;39(3):168-75. No measure of sexual dysfunction reported.
Higgins G E. Sexual response in spinal cord injured adults: a review of the literature. Arch Sex Behav. 1979;8(2):173-96. No measure of sexual dysfunction reported. [pmid: 475578].
Hirsch I H, Jeyendran R S, Sedor J, et al. Biochemical analysis of electroejaculates in spinal cord injured men: comparison to normal ejaculates. Br J Urol. 1991;145(1):73-6. No measure of sexual dysfunction reported.
Hirsch I H, Kulp-Hugues D, Sedor J, et al. Simplified and objective assessment of spermatogenesis in spinal cord injured men by flow cytometry analysis. Paraplegia. 1993;31(12):785-92. No measure of sexual dysfunction reported. [pmid: 8115171].
Hirsch I H, McCue P, Allen J, et al. Quantitative testicular biopsy in spinal cord injured men: comparison to fertile controls. Br J Urol. 1991;146(2):337-41. No measure of sexual dysfunction reported.
Hirsch I H, Sedor J, Callahan H J, et al. Systemic sperm autoimmunity in spinal-cord injured men. Arch Androl. 1990;25(1):69-73. No measure of sexual dysfunction reported. [pmid: 2389995].
Hirsch I H, Sedor J, Kulp D, et al. Objective assessment of spermatogenesis in men with functional and anatomic obstruction of the genital tract. Int J Androl. 1994;17(1):29-34. No measure of sexual dysfunction reported. [pmid: 8005706].
Hohmann G W. Considerations in management of psychosexual readjustment in the cord injured male. Proc Veterans Adm Spinal Cord Inj Conf. 1971;18:199-204. No measure of sexual dysfunction reported. [pmid: 5161629].
Holstein A F, Sauerwein D, Schirren U. [Spermatogenesis in patients with traumatic transverse paralysis]. [German]. Rev Med Interna Neurol Psihiatr Neurochir Dermatovenerol Med Interna. 1985;24(4):208-15. Reported in a language other than English.
Hovatta O, von Smitten K. Sperm aspiration from vas deferens and in-vitro fertilization in cases of non-treatable anejaculation. Hum Reprod. 1993;8(10):1689-91. No measure of sexual dysfunction reported. [pmid: 8300829].
Howitt HP. Psychological aspects of sexual adjustment in the spinal cord injured. Conn Nurs News line 27 No sexual dysfunction intervention reported.
Hudson BS. Erectile dysfunction options for SCI males. 17th American association of spinal cord injury nurses conference 2000;34. No measure of sexual dysfunction reported.
Hultling C, Levi R, Garoff L, et al. Assisted ejaculation combined with in vitro fertilisation: an effective technique treating male infertility due to spinal cord injury. Paraplegia. 1994;32(7):463-7. No measure of sexual dysfunction reported. [pmid: 7970847].
Hultling C, Rosenlund B, Levi R, et al. Assisted ejaculation and in-vitro fertilization in the treatment of infertile spinal cord-injured men: the role of intracytoplasmic sperm injection. Hum Reprod. 1997;12(3):499-502. No measure of sexual dysfunction reported. [pmid: 9130750].
Iwatsubo E, Iwakawa A, Koga H, et al. [Clinical studies on the management of urogenital dysfunction in patients with spinal cord injury. 1. Noninflatable penile prosthesis for the management of urinary incontinence and sexual disability]. [Japanese]. Nippon Hinyokika Gakkai Zasshi. 1986;77(5):760-5. Reported in a language other than English. [pmid: 3747312].
Jackson R W. Sexual rehabilitation after cord injury. Paraplegia. 1972;10(1):50-5. No measure of sexual dysfunction reported. [pmid: 5039328].
Jouannet P, Francois N, Maury M. [Evaluation of fertility in paraplegic men]. [French]. J Urol (Paris). 1983;89(3):169-71. No measure of sexual dysfunction reported. [pmid: 6875296].
Keeshin S, Lane G, Kanter S, et al. Medical and psychosocial issues in women with spinal cord injury: a comprehensive survey. Arch Phys Med Rehabil. 1999;80:1119. No measure of sexual dysfunction reported.
Key BH, Hale AM, Jackson AB. Promoting accessible health care examinations for women with SCI. 15th American association of spinal cord injury nurses conference 1998;43. No measure of sexual dysfunction reported.
Kimoto Y, Iwatsubo E. Penile prostheses for the management of the neuropathic bladder and sexual dysfunction in spinal cord injury patients: long term follow up. Paraplegia. 1994;32(5):336-9. No measure of sexual dysfunction reported. [pmid: 8058351].
Kimura Y. [Sexual function of the paraplegics; with a special reference to erection and ejaculation]. [Japanese]. Nippon Hinyokika Gakkai Zasshi. 1970;61(10):1010-6. Reported in a language other than English. [pmid: 5529303].
Kolon T F, Philips K A, Buch J P. Pentoxifylline enhancement of post-thaw motility in cryopreserved semen of spinal cord-injured men. Int J Fertil Menopausal Stud. 1995;40(3):156-60. No measure of sexual dysfunction reported. [pmid: 7663542].
Komisaruk B R. The suppression of pain by genital stimulation in females. Annu Rev Sex Res. 1995;VI(151):186. No measure of sexual dysfunction reported.
Kulkarni S, Morgan O S. Pregnancy outcome in paraplegic women. West Indian Med J. 1992;41(3):99-100. No measure of sexual dysfunction reported. [pmid: 1441461].
Langtry H D, Markham A. Sildenafil: a review of its use in erectile dysfunction. Drugs. 1999;57(6):967-89. No measure of sexual dysfunction reported. [pmid: 10400408].
Le Chapelain L, Nguyen Van, Tam Dehail P, et al. Ejaculatory stimulation, quality of semen and reproductive aspects in spinal cord injured men. Proc Annu Clin Spinal Cord Inj Conf. 1998;36(2):132-6. No measure of sexual dysfunction reported.
Lebib B A, Laffont I, Boyer F, et al. Intracavernous injections in the treatment of erectile dysfunction in spinal cord injured patients: experience with 36 patients. [French]. Ann Readapt Med Phys. 2001;44(1):35-40. Reported in a language other than English. [pmid: 11587653].
Leduc B E, Roy D, Poulin O. The use of physostigmine in men with spinal cord injury with ejaculatory dysfunction. Can J Rehabil. 1992;5(4):231-5. No measure of sexual dysfunction reported.
Lewis JH. What's new in the treatment of erectile dysfunction. 15th American association of spinal cord injury nurses conference 1998;21. No measure of sexual dysfunction reported.
Leyson J. Foreword. Sex Disabil. 1995;13(1):5. No measure of sexual dysfunction reported.
Lim T C, Mallidis C, Hill S T, et al. A simple technique to prevent retrograde ejaculation during assisted ejaculation. Paraplegia. 1994;32(3):142-9. No measure of sexual dysfunction reported. [pmid: 8008416].
Lindsey L L, Brown J F. VIAGRA (sildenafil) and spinal cord injury: review and update. SCI Psychosocial Process. 2000;13(1):13-6. No measure of sexual dysfunction reported.
Linsenmeyer T A. Evaluation and treatment of erectile dysfunction following spinal cord injury: a review. [Review] [65 refs]. J Am Paraplegia Soc. 1991;14(2):43-51. No measure of sexual dysfunction reported. [pmid: 2051156].
Linsenmeyer TA. Management of male infertility. Vet J Ed 487–509. No measure of sexual dysfunction reported.
Linsenmeyer T A. Overview of male infertility following SCI. J Spinal Cord Med. 2000;23(3):174. No measure of sexual dysfunction reported.
Linsenmeyer T A, Perkash I. Infertility in men with spinal cord injury. Arch Phys Med Rehabil. 1991;72(10):747-54. No measure of sexual dysfunction reported. [pmid: 1929799].
Linsenmeyer T, Ottenweller J, Anesetti R. Effects of Vitamin E/Selenium on sperm motility following SCI. J Spinal Cord Med. 1998;21(2):164. No measure of sexual dysfunction reported.
Linsenmeyer T, Wilmot C, Anderson R U. The effects of the electroejaculation procedure on sperm motility. Paraplegia. 1989;27(6):465-9. No measure of sexual dysfunction reported. [pmid: 2608300].
Linton SS. Sexual satisfaction following spinal cord injury as a function of locus of control. Acta Radiol line 27 No measure of sexual dysfunction reported.
Loecher-Ernst D, Grosse J, Mandalka B, et al. Semen retrieved and fertility in 229 spinal cord injured males:longterm results of a fertility program in spinal cord injured males. J Spinal Cord Med. 1998;21(2):164. No measure of sexual dysfunction reported.
Loughead R M. Males' perception of changes in their sex role orientation as a function of spinal cord injury. Bull Acad Natl Chir Dent. No sexual dysfunction intervention reported.
Lucas M G, Hargreave T B, Edmond P, et al. Sperm retrieval by electro-ejaculation. Preliminary experience in patients with secondary anejaculation. Br J Urol. 1991;67(2):191-4. No measure of sexual dysfunction reported. [pmid: 2004235].
Mallidis C, Lim T C, Hill S T, et al. Collection of semen from men in acute phase of spinal cord injury. Lancet. 1994;343(8905):1072-3. No measure of sexual dysfunction reported. [pmid: 7909101].
Mauney MC. Fertility program/electroejaculation-coordination of services. 17th American association of spinal cord injury nurses conference 2000;34–5. No measure of sexual dysfunction reported.
May AC. Sex differences related to adjustment to spinal cord injury. Monogr Am Assoc Ment Defic. No measure of sexual dysfunction reported.
McBride K E, Rines B. Sexuality and SCI: a roadmap for nurses. 15th American association of spinal cord injury nurses conference 1998;19. No measure of sexual dysfunction reported.
McKenna K E. Neural circuitry involved in sexual function. [Review] [78 refs]. J Spinal Cord Med. 2001;24(3):148-54. No measure of sexual dysfunction reported. [pmid: 11585233].
Momose H, Hirao Y, Yamamoto M, et al. Electroejaculation in patients with spinal cord injury: first report of a large-scale experience from Japan. Int J Urol. 1995;2(5):326-29. No measure of sexual dysfunction reported. [pmid: 8749952].
Momose H, Natsume O, Yamamoto M, et al. [Intracavernous injection of papaverine hydrochloride for impotence in patients with spinal cord injury]. [Japanese]. Hinyokika Kiyo. 1987;33(7):1065-9. Reported in a language other than English. [pmid: 3687629].
Monga M, Bernie J, Rajasekaran M. Male infertility and erectile dysfunction in spinal cord injury: a review. Archives of Physical Medicine & Rehabilitation. 1999;80(10):1331-9. No measure of sexual dysfunction reported. [pmid: 10527097].
Murphy DF. Sexual health information sheets. 15th American association of spinal cord injury nurses conference 1998;37–8. No measure of sexual dysfunction reported.
Nehra A, Moreland R B. Neurologic erectile dysfunction. Urol Clin North Am. 2001;28(2):289-308. No measure of sexual dysfunction reported. [pmid: 11402582].
Nehra A, Werner M A, Bastuba M, et al. Vibratory stimulation and rectal probe electroejaculation as therapy for patients with spinal cord injury: semen parameters and pregnancy rates. Br J Urol. 1996;155(2):554-9. No measure of sexual dysfunction reported.
Odum L, Sonksen J, Biering-Sorensen F. Seminal somatostatin in men with spinal cord injury. Paraplegia. 1995;33(7):374-6. No measure of sexual dysfunction reported. [pmid: 7478725].
Ohl D A, Bennett C J, McCabe M, et al. Predictors of success in electroejaculation of spinal cord injured men. Br J Urol. 1989;142(6):1483-6. No measure of sexual dysfunction reported.
Ohl D A, Denil J, Fitzgerald-Shelton K, et al. Fertility of spinal cord injured males: effect of genitourinary infection and bladder management on results of electroejaculation. J Am Paraplegia Soc. 1992;15(2):53-9. No measure of sexual dysfunction reported. [pmid: 1583503].
Ohl D A, Sonksen J, Menge A C, et al. Electroejaculation versus vibratory stimulation in spinal cord injured men: sperm quality and patient preference. Br J Urol. 1997;157(6):2147-9. No measure of sexual dysfunction reported.
Padma-Nathan H, Giuliano F. Oral drug therapy for erectile dysfunction. Urol Clin North Am. 2001;28(2):321-34. No measure of sexual dysfunction reported. [pmid: 11402584].
Padron O F, Brackett N L, Weizman M S, et al. Semen of spinal cord injured men freezes reliably. J Androl. 1994;15(3):266-9. No measure of sexual dysfunction reported. [pmid: 7928669].
Park C I, Shin J, Kim D, et al. Ejaculatory induction and semen analysis with vibratory and electrical stimulation in spinal cord injured patients. Arch Phys Med Rehabil. 1999;80:1195. No measure of sexual dysfunction reported.
Peckham P H, Creasey G H. Neural prostheses: clinical applications of functional electrical stimulation in spinal cord injury. Paraplegia. 1992;30(2):96-101. No measure of sexual dysfunction reported. [pmid: 1589297].
Perduta-Fulginiti P S. Sexual functioning of women with complete spinal cord injury: Nursing implications. Sex Disabil. 1993;10(2):115-8. No measure of sexual dysfunction reported.
Perkash I, Martin D E, Warner H. Reproductive problems of paraplegics and the present status of electroejaculation. Cent Nerv Syst Trauma. 1986;3(1):13-23. No measure of sexual dysfunction reported. [pmid: 3488130].
Perkash I, Martin D E, Warner H. Electroejaculation in spinal cord injury patients: simplified new equipment and technique. Br J Urol. 1990;143(2):305-7. No measure of sexual dysfunction reported.
Perkash I, Martin D E, Warner H, et al. Reproductive biology of paraplegics: results of semen collection, testicular biopsy and serum hormone evaluation. Br J Urol. 1985;134(2):284-8. No sexual dysfunction intervention reported.
Phelps J, Albo M, Dunn K, et al. Spinal cord injury and sexuality in married or partnered men: activities, function, needs, and predictors of sexual adjustment. Arch Sex Behav. 2001;30(6):591-602. Not an original report of an intervention trial with pre and post measures. [pmid: 11725457].
Piera J B. The establishment of a prognosis for genito-sexual function in the paraplegic and tetraplegic male. Paraplegia. 1973;10(4):271-8. No measure of sexual dysfunction reported. [pmid: 4696999].
Powers J, Meats J, Saylor L, et al. Care of a pregnant spinal cord injured patient. 17th American association of spinal cord injury nurses conference 2000;40. No measure of sexual dysfunction reported.
Pryor J L, Kuneck P H, Blatz S M, et al. Delayed timing of intrauterine insemination results in a significantly improved pregnancy rate in female partners of quadriplegic men. Fertil Steril. 2001;76(6):1130-5. No measure of sexual dysfunction reported. [pmid: 11730739].
Rajasekaran M, Monga M. Cellular and molecular causes of male infertility in spinal cord injury. [Review] [52 refs]. J Androl. 1999;20(3):326-30. No measure of sexual dysfunction reported. [pmid: 10386809].
Rawicki H B, Hill S. Semen retrieval in spinal cord injured men. Paraplegia. 1991;29(7):443-6. No measure of sexual dysfunction reported. [pmid: 1784510].
Raymond C A. New use for old method of inducing ejaculation may give hope of fatherhood to some spinal cord-injured men. JAMA. 1987;258(6):743-4. No measure of sexual dysfunction reported. [pmid: 3612994].
Rivas DA. Management of erectile dysfunction. Vet J Ed 457–464. No measure of sexual dysfunction reported.
Roberts R. A case study of the experiences of six women who are paraplegic. Farmaco. No sexual dysfunction intervention reported.
Romeo AJ. Sexual adjustment to spinal-cord injury. Microcirculation. No measure of sexual dysfunction reported.
Rossier A B, Fam B A. Indication and results of semirigid penile prostheses in spinal cord injury patients: long-term followup. Br J Urol. 1984;131(1):59-62. No measure of sexual dysfunction reported.
Rucker B, Szasz G, Carpenter C. Legal, ethical and religious issues related to fertility enhancement of men with spinal cord injuries. Can J Rehabil. 1988;1(4):225-31. No measure of sexual dysfunction reported.
Rutkowski S B, Geraghty T J, Hagen D L, et al. A comprehensive approach to the management of male infertility following spinal cord injury. Proc Annu Clin Spinal Cord Inj Conf. 1999;37(7):508-14. No measure of sexual dysfunction reported.
Rutkowski B, Middleton J W, Truman G, et al. The influence of bladder management on fertility in spinal cord injured males. Paraplegia. 1995;33(5):263-6. No measure of sexual dysfunction reported. [pmid: 7630651].
Sadovsky R, Miller T, Moskowitz M, et al. Three-year update of sildenafil citrate (Viagra) efficacy and safety. Int J Clin Pract. 2001;55(2):115-28. No measure of sexual dysfunction reported. [pmid: 11321851].
Sanchez R A, Vidal J, Juregui M L, et al. Efficacy, safety and predictive factors of therapeutic success with sildenafil for erectile dysfunction in patients with different spinal cord injuries. Proc Annu Clin Spinal Cord Inj Conf. 2001;39(12):637-43. No measure of sexual dysfunction reported.
Sarkarati M, Rossier A B, Fam B A. Experience in vibratory and electro-ejaculation techniques in spinal cord injury patients: a preliminary report. Br J Urol. 1987;138(1):59-62. No measure of sexual dysfunction reported.
Schatte E C, Orejuela F J, Lipshultz L I, et al. Treatment of infertility due to anejaculation in the male with electroejaculation and intracytoplasmic sperm injection. Br J Urol. 2000;163(6):1717-20. No measure of sexual dysfunction reported.
Scheutzow M H, Bockenek W L. Electroejaculation in persons with spinal cord injury: a unique complication and review of the literature. Arch Phys Med Rehabil. 1998;79:1187. No measure of sexual dysfunction reported.
Seager S W, Halstead L S. Fertility options and success after spinal cord injury. [Review] [32 refs]. Urol Clin North Am. 1993;20(3):543-8. No measure of sexual dysfunction reported. [pmid: 8351779].
Seager S W J, Halstead L S. Electroejaculation - techniques and results. J Spinal Cord Med. 2000;23(3):174. No measure of sexual dysfunction reported.
Seftel A D. Disturbed sexual function in patients with spinal cord disease. Neurol Clin. 1991;9(3):757-78. No measure of sexual dysfunction reported. [pmid: 1921957].
Seftel A D, Bodner D R, Gothe B, et al. Efficacy of sildenafil in spinal cord injured men. J Spinal Cord Med. 2000;23(3):207. No measure of sexual dysfunction reported.
Shaban S F, Seager S W, Lipshultz L I. Clinical electroejaculation. [Review] [31 refs]. Med Instrum. 1988;22(2):77-81. No measure of sexual dysfunction reported. [pmid: 3285147].
Siosteen A. Emission dysfunctions and current modes of treatment in neurogenic male infertility. Scand J Urol Nephrol 1988;Supplementum. 110(59):64. No measure of sexual dysfunction reported.
Siosteen A, Forssman L, Steen Y, et al. Quality of semen after repeated ejaculation treatment in spinal cord injury men. Paraplegia. 1990;28(2):96-104. No measure of sexual dysfunction reported. [pmid: 2235028].
Siosteen A, Steen Y, Forssman L, et al. Auto-immunity to spermatozoa and quality of semen in men with spinal cord injury. Int J Fertil. 1993;38(2):117-22. No measure of sexual dysfunction reported. [pmid: 8097501].
Sipski M L. Future options for improving sexual satisfaction in persons with spinal cord injuries. The Howard H. Steel Conference on Pediatric Spinal Cord Injury, Rancho Mirage, California, December 3–5, 1999. Topics in Spinal Cord Injury Rehabilitation. 2000;6(148):154. No measure of sexual dysfunction reported.
Sipski M L. Sexual response in women with spinal cord injury: neurologic pathways and recommendations for the use of electrical stimulation. [Review] [21 refs]. J Spinal Cord Med. 2001;24(3):155-8. No measure of sexual dysfunction reported. [pmid: 11585234].
Sipski M L. Central nervous system based neurogenic female sexual dysfunction: Current status and future trends. Arch Sex Behav. 2002;31(5):421-4. No measure of sexual dysfunction reported. [pmid: 12238609].
Sipski ML. Spinal cord injury and sexual function: An educational model. Vet J Ed 149–176. No measure of sexual dysfunction reported.
Sipski M L. A controlled trial of positive feedback to increase sexual arousal in women with spinal cord injuries. NeuroRehabilitation. 2000;15(2):145-53. No measure of sexual dysfunction reported. [pmid: 11455091].
Sipski M L, Behnegar A. Neurogenic female sexual dysfunction: a review. [Review] [53 refs]. Clin Auton Res. 2001;11(5):279-83. No measure of sexual dysfunction reported. [pmid: 11758793].
Sipski M L, Katz M A, Blight A R. The effects of oral fampridine-SR (sustained-release 4-aminopyridine) on sexual function in subjects with chronic motor-incomplete spinal cord injury. J Spinal Cord Med. 2003;26(Suppl 1):s18. No measure of sexual dysfunction reported.
Sonksen J O, Biering-Sorensen F, Kristensen J K, et al. [Ejaculation induced by electrostimulation in men with spinal cord injuries]. [Danish]. Ugeskr Laeger. 1993;155(3):176-9. Reported in a language other than English. [pmid: 8421879].
Sonksen J O, Hansen E F, Biering-Sorensen F. Intracavernous self-injection for treatment of erectile dysfunction inpatients with spinal cord injuries. [Danish]. Ugeskr Laeger. 1990;152(41):3006-9. Reported in a language other than English. [pmid: 2238171].
Sonksen J, Biering-Sorensen F, Kristensen J K. Ejaculation induced by penile vibratory stimulation in men with spinal cord injuries. The importance of the vibratory amplitude. Paraplegia. 1994;32(10):651-60. No measure of sexual dysfunction reported. [pmid: 7831070].
Sonksen J, Sommer P, Biering-Sorensen F. Pregnancy after assisted ejaculation procedures in men with spinal cord injury. Arch Phys Med Rehabil. 1997;78(10):1059-61. No measure of sexual dysfunction reported. [pmid: 9339152].
Sprouse D O. Electroejaculation for anejaculate males. Urol Nurs. 1994;14(2):57-61. No measure of sexual dysfunction reported. [pmid: 7709238].
Sprouse D O. Fertility issues and anejaculation. Urol Nurs. 1994;14(2):62-5. No measure of sexual dysfunction reported. [pmid: 7709239].
Staerman F, Bryckaert P E, Youinou Y, et al. [Pharmacologic stimulation of ejaculation with midodrine hydrochloride (Gutron) for medically assisted reproduction in spinal injury]. [French]. Prog Urol. 2001;11(6):1264-8. No measure of sexual dysfunction reported. [pmid: 11859662].
Stein Mark. The evaluation and treatment of sexual dysfunction in the neurologically impaired patient. J Neurol Rehabil. 1993;7(2):63-71. No measure of sexual dysfunction reported.
Stien R. Sexual dysfunctions in the spinal cord injured. Paraplegia. 1992;30(1):54-7. No measure of sexual dysfunction reported. [pmid: 1589275].
Szasz G, Carpenter C. Clinical observations in vibratory stimulation of the penis of men with spinal cord injury. Arch Sex Behav. 1989;18(6):461-74. No measure of sexual dysfunction reported. [pmid: 2604539].
Tarabulcy E. Sexual function in the normal and in paraplegia. Paraplegia. 1972;10(3):201-8. No measure of sexual dysfunction reported. [pmid: 4636921].
Taylor Z, Molloy D, Hill V, et al. Contribution of the assisted reproductive technologies to fertility in males suffering spinal cord injury. Aust N Z J Obstet Gynaecol. 1999;39(1):84-7. No measure of sexual dysfunction reported. [pmid: 10099757].
Tepper MS. Lived experiences that impede or facilitate sexual pleasure and orgasm in people with spinal cord injury. J Womens Health (Larchmt). No sexual dysfunction intervention reported.
Tepper MS. Providing comprehensive sexual health care in SCI rehabilitation. 15th American association of spinal cord injury nurses conference 1998;26. No measure of sexual dysfunction reported.
Thomas A J. Ejaculatory dysfunction. Fertil Steril. 1983;39(4):445. No measure of sexual dysfunction reported. [pmid: 6832399].
Tollon C, Soulie M, Pontonnier F, et al. [Prevention of sterility in spinal cord injured men]. [French]. Prog Urol. 1997;7(2):203-8. No measure of sexual dysfunction reported. [pmid: 9264760].
Truss M C, Djamilian M H, Tan H K, et al. Single potential analysis of cavernous electrical activity. Four years' experience in more than 500 patients with erectile dysfunction. Eur Urol. 1993;24(3):358-65. No sexual dysfunction intervention reported. [pmid: 8262103].
Urey Jon R. Marital adjustment following spinal cord injury: An analysis of recreational, sexual and conflict resolution behaviors. ADM. No measure of sexual dysfunction reported.
Vaidyanathan S, Soni B M, Krishnan K R. Special precautions to be observed while using alprostadil in patients with spinal cord injury. Proc Annu Clin Spinal Cord Inj Conf. 1997;35(6):402-3. No measure of sexual dysfunction reported.
van der, Linde I. Oral sildenafil (Viagra) on trial. S Afr Med J. 1998;88(10):1290. No measure of sexual dysfunction reported.
Veit N, Mikelonis M. Health Issues of women who have spinal cord impairment. 18th American association of spinal cord injury nurses conference 2001;25-25. No measure of sexual dysfunction reported.
Velasco M, Buyo A, Barrera S. Sexual and gynecologic issues in a sample of women with spinal cord injury. J Spinal Cord Med. 2002;25(Suppl1):s45. No measure of sexual dysfunction reported.
Ver Voort S M. Infertility in spinal-cord injured male. Urology. 1987;29(2):157-65. No measure of sexual dysfunction reported. [pmid: 3544454].
VerVoort S M, Donovan W H, Dykstra D D, et al. Increased current delivery and sperm collection using nifedipine during electroejaculation in men with high spinal cord injuries. Arch Phys Med Rehabil. 1988;69(8):595-7. No measure of sexual dysfunction reported. [pmid: 3408330].
Wagenknecht L V. Alloplastic spermatocele: 20 years experience and perspectives. Acta Chir Hung. 1994;34:207-29. No measure of sexual dysfunction reported. [pmid: 7618373].
Wang Y H, Chiang H S, Wu C H, et al. Electroejaculation in spinal cord injured males. J Formos Med Assoc. 1992;91(4):413-8. No measure of sexual dysfunction reported. [pmid: 1358310].
Wang Y H, Huang T S, Lien I N. Hormone changes in men with spinal cord injuries. Am J Phys Med Rehabil. 1992;71(6):328-32. No sexual dysfunction intervention reported. [pmid: 1466870].
Wang Y H, Huang T S, Lin M C, et al. Scrotal temperature in spinal cord injury. Am J Phys Med Rehabil. 1993;72(1):6-9. No measure of sexual dysfunction reported. [pmid: 8431271].
Warner H, Martin D E, Perkash I, et al. Electrostimulation of erection and ejaculation and collection of semen in spinal cord injured humans. J Rehabil Res Devel. 1986;23(3):21-31. No measure of sexual dysfunction reported. [pmid: 3490567].
Weinberg J S. Human Sexuality and spinal cord injury. Crit Care Nurs Clin North Am. 1982;17(3):407-19. No measure of sexual dysfunction reported.
Whipple B, Komisaruk B R. Brain (PET) responses to vaginal-cervical self-stimulation in women with complete spinal cord injury: preliminary findings. J Sex Marital Ther. 2002;28(1):79-86. No measure of sexual dysfunction reported. [pmid: 11928182].
Willmuth M E. Sexuality after spinal cord injury: A critical review. Clin Psychol Rev. 1987;7(4):389-412. No measure of sexual dysfunction reported.
Wolski J K, Kluge P, Koziol K, et al. [Needle testicular biopsy in the diagnosis of male infertility]. [Polish]. Ginekol Pol. 1998;69(6):541-4. No measure of sexual dysfunction reported. [pmid: 9695380].
Wyndaele J J, de Meyer J M, de Sy W A, et al. Intracavernous injection of vasoactive drugs, an alternative for treating impotence in spinal cord injury patients. Paraplegia. 1986;24(5):271-5. No measure of sexual dysfunction reported. [pmid: 3774363].
Yamamoto M, Yamada K, Hirata N, et al. [Electroejaculation and assisted reproductive techniques in the patients with spinal cord injury]. [Japanese]. Nippon Hinyokika Gakkai Zasshi - Japanese Journal of Urology. 1997;88(3):420-6. Reported in a language other than English.
Yarkony G M. Enhancement of sexual function and fertility in spinal cord-injured males. Am J Phys Med Rehabil. 1990;69(2):81-7. No measure of sexual dysfunction reported. [pmid: 2184843].
Yarkony G M, Chen D. Sexuality in patients with spinal cord injury. Physical Medicine & Rehabilitation: State of the Art Reviews. 1995;9(2):325-44. No measure of sexual dysfunction reported.
Yarkony G M, Chen D, Palmer J, et al. Management of impotence due to spinal cord injury using low dose papaverine. Paraplegia. 1995;33(2):77-9. No measure of sexual dysfunction reported. [pmid: 7753572].
Zeller F L, Lassalle G, Repetti P, et al. Electromyographical findings in patients with spinal cord injury and erectile dysfunction. Int J Impot Res. 2001;13(Suppl 2):s16. No sexual dysfunction intervention reported. [pmid: 11313835].