# References & Included Studies

1 Glickman S, Kamm M A. Bowel dysfunction in spinal-cord-injury patients. Lancet. 1996;347(9016):1651-3. [pmid: 8642958].
2 Ophthalmology Study Design Worksheet #3 Noncomparative (nonrandomized, noncontrolled) Interventional Case Series. 2004.
3 Benevento B T, Sipski M L. Neurogenic bladder, neurogenic bowel, and sexual dysfunction in people with spinal cord injury. Phys Ther. 2002;82(6):601-12. [pmid: 12036401].
4 Burns A S, Rivas D A, Ditunno J F. The management of neurogenic bladder and sexual dysfunction after spinal cord injury. Spine. 2001;26(24 Suppl):S129-S136. [pmid: 11805620].
5 Linsenmeyer T A. Sexual function and infertility following spinal cord injury. Phys Med Rehabil Clin N Am. 2000;11(1):141-56. [pmid: 10680162].
6 Sipski M L, Alexander C J, Rosen R. Sexual arousal and orgasm in women: effects of spinal cord injury. Ann Neurol. 2001;49(1):35-44. [pmid: 11198294].
7 Biering-Sorensen F, Sonksen J. Sexual function in spinal cord lesioned men. Spinal Cord. 2001;39(9):455-70. [pmid: 11571657].
8 Alexander C J, Sipski M L, Findley T W. Sexual activities, desire, and satisfaction in males pre- and post-spinal cord injury. Arch Sex Behav. 1993;22(3):217-28. [pmid: 8494489].
9 Sipski M L, Alexander C J. Sexual activities, response and satisfaction in women pre- and post-spinal cord injury. Arch Phys Med Rehabil. 1993;74(10):1025-9. [pmid: 8215851].
10 Linsenmeyer T A. Male infertility following spinal cord injury. J Am Paraplegia Soc. 1991;14(3):116-21. [pmid: 1885947].
11 Sipski M L. Sexual functioning in the spinal cord injured. Int J Impot Res. 1998;10(Suppl 2):S128-S130. [pmid: 9647975].
12 Smith E M, Bodner D R. Sexual dysfunction after spinal cord injury. Urol Clin North Am. 1993;20(3):535-42. [pmid: 8351778].
13 Nygaard I, Bartscht K D, Cole S. Sexuality and reproduction in spinal cord injured women [Review] [20 refs]. Obstet Gynecol Surv. 1990;45(11):727-32. [pmid: 2234703].
14 Whipple B, Komisaruk B R. Sexuality and women with complete spinal cord injury. Spinal Cord. 1997;35(3):136-8. [pmid: 9076862].
15 Linsenmeyer T A. Evaluation and treatment of erectile dysfunction following spinal cord injury: a review. J Am Paraplegia Soc. 1991;14(2):43-51. [pmid: 2051156].
16 Lloyd L K, Richards J S. Intracavernous pharmacotherapy for management of erectile dysfunction in spinal cord injury. Paraplegia. 1989;27(6):457-64. [pmid: 2608299].
17 Bodner D R, Lindan R, Leffler E, Kursh E D, Resnick M I. The application of intracavernous injection of vasoactive medications for erection in men with spinal cord injury. J Urol. 1987;138(2):310-1. [pmid: 3599245].
18 Burns A S, Jackson A B. Gynecologic and reproductive issues in women with spinal cord injury. Phys Med Rehabil Clin N Am. 2001;12(1):183-99. [pmid: 11853036].
19 Sipski M L. The impact of spinal cord injury on female sexuality, menstruation and pregnancy: a review of the literature. J Am Paraplegia Soc. 1991;14(3):122-6. [pmid: 1885948].
20 Brackett N L, Nash M S, Lynne C M. Male fertility following spinal cord injury: facts and fiction. Phys Ther. 1996;76(11):1221-31. [pmid: 8911434].
21 Sonksen J, Biering-Sorensen F. Fertility in men with spinal cord or cauda equina lesions. Semin Neurol. 1992;12(2):106-14. [pmid: 1323870].
22 Beckerman H, Becher J, Lankhorst G J. The effectiveness of vibratory stimulation in anejaculatory men with spinal cord injury. Review article. Paraplegia. 1993;31(11):689-99. [pmid: 8295779].
23 Chung P H, Yeko T R, Mayer J C, Sanford E J, Maroulis G B. Assisted fertility using electroejaculation in men with spinal cord injury--a review of literature. Fertil Steril. 1995;64(1):1-9. [pmid: 7789540].
24 Kolettis P N, Lambert M C, Hammond K R, Kretzer P A, Steinkampf M P, Lloyd L K. Fertility outcomes after electroejaculation in men with spinal cord injury. Fertil Steril. 2002;78(2):429-31. [pmid: 12137889].
25 Fisher T L, Laud P W, Byfield M G, Brown T T, Hayat M J, Fiedler I G. Sexual health after spinal cord injury: a longitudinal study. Arch Phys Med Rehabil. 2002;83(8):1043-51. [pmid: 12161824].
26 Pervin-Dixon L. Sexuality and the spinal cord injured. J Psychosoc Nurs Ment Health Serv. 1988;26(4):31-4. [pmid: 3373459].
27 Wells GA Shea B O'Connell D Peterson J Welch V Tugwell P. The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. 3rd Symposium on Systematic Reviews: Beyond the Basics, July 2000 in Oxford. 2000.
28 Moher D, Cook D J, Eastwood S, Olkin I, Rennie D, Stroup D F. Improving the quality of reports of meta-analyses of randomised controlled trials: the QUOROM statement Quality of Reporting of Meta-analyses. Lancet. 1999;354(9193):1896-900. [pmid: 10584742].
29 Moher D, Pham B, Jones A, Cook D J, Jadad A R, Moher M, et al. Does quality of reports of randomised trials affect estimates of intervention efficacy reported in meta-analyses?. Lancet. 1998;352(9128):609-13. [pmid: 9746022].
30 Berlin J A. Does blinding of readers affect the results of meta-analyses? University of Pennsylvania Meta-analysis Blinding Study Group. Lancet. 1997;350(9072):185-6. [pmid: 9250191].
31 Egger M, Juni P, Bartlett C, Holenstein F, Sterne J. How important are comprehensive literature searches and the assessment of trial quality in systematic reviews? Empirical study. Health Technol Assess. 2003;7(1):1-76. [pmid: 12583822].
32 Moher D, Cook D J, Jadad A R, Tugwell P, Moher M, Jones A, et al. Assessing the quality of reports of randomised trials: implications for the conduct of meta-analyses. Health Technol Assess. 1999;3(12):i-98. [pmid: 10374081].
33 Jadad A R, Moore R A, Carroll D, Jenkinson C, Reynolds D J, Gavaghan D J, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. 1996;17(1):1-12. [pmid: 8721797].
34 Schulz K F, Chalmers I, Hayes R J, Altman D G. Empirical evidence of bias. Dimensions of methodological quality associated with estimates of treatment effects in controlled trials. JAMA. 1995;273(5):408-12. [pmid: 7823387].
35 Newcombe R G. Improved confidence intervals for the difference between binomial proportions based on paired data. Stat Med. 1998;17(22):2635-50. [pmid: 9839354].
36 Laird N M, Mosteller F. Some statistical methods for combining experimental results. Int J Technol Assess Health Care. 1990;6(1):5-30. [pmid: 2361819].
37 Green B, Killorin E W, Rozas K, Bennett J, Foote J, Hasty L, et al. Results of elective electroejaculation with freezing and subsequent sperm manipulation versus electroejaculation at ovulation to achieve pregnancy in male factor spinal cord injured males. J Spinal Cord Med. 2000;23(Suppl 1):45. [pmid: 10752874].
38 Brindley G S. The fertility of men with spinal injuries. Paraplegia. 1984;22(6):337-48. [pmid: 6335235].
39 Brindley G S. Electroejaculation and the fertility of paraplegic men. Sex Disabil. 1981;3(3):225-9.
40 Brindley G S. Electroejaculation: its technique, neurological implications and uses. J Neurol Neurosurg Psychiatry. 1981;44(1):9-18. [pmid: 6451670].
41 Halstead L S, VerVoort S, Seager S W. Rectal probe electrostimulation in the treatment of anejaculatory spinal cord injured men. Paraplegia. 1987;25(2):120-9. [pmid: 3495772].
42 Sarkarati M, Rossier A B, Fam B A. Experience in vibratory and electro-ejaculation techniques in spinal cord injury patients: a preliminary report. J Urol. 1987;138(1):59-62. [pmid: 3496469].
43 VerVoort S M, Donovan W H, Dykstra D D, Syers P. Increased current delivery and sperm collection using nifedipine during electroejaculation in men with high spinal cord injuries. Arch Phys Med Rehabil. 1988;69(8):595-7. [pmid: 3408330].
44 Lucas M G, Hargreave T B, Edmond P, Creasey G H, McParland M, Seager S W. Sperm retrieval by electro-ejaculation. Preliminary experience in patients with secondary anejaculation. Br J Urol. 1991;67(2):191-4. [pmid: 2004235].
45 Rawicki H B, Hill S. Semen retrieval in spinal cord injured men. Paraplegia. 1991;29(7):443-6. [pmid: 1784510].
46 Mallidis C, Lim T C, Hill S T, Skinner D J, Brown D J, Johnston W I, et al. Collection of semen from men in acute phase of spinal cord injury. Lancet. 1994;343(8905):1072-3. [pmid: 7909101].
47 Lim T C, Mallidis C, Hill S T, Skinner D J, Carter P D, Brown D J, et al. A simple technique to prevent retrograde ejaculation during assisted ejaculation. Paraplegia. 1994;32(3):142-9. [pmid: 8008416].
48 Hultling C, Levi R, Garoff L, Nylund L, Rosenborg L, Sjoblom P, et al. Assisted ejaculation combined with in vitro fertilisation: an effective technique treating male infertility due to spinal cord injury. Paraplegia. 1994;32(7):463-7. [pmid: 7970847].
49 Sonksen J, Biering-Sorensen F, Kristensen J K. Ejaculation induced by penile vibratory stimulation in men with spinal cord injuries. The importance of the vibratory amplitude. Paraplegia. 1994;32(10):651-60. [pmid: 7831070].
50 Pryor J L, LeRoy S C, Nagel T C, Hensleigh H C. Vibratory stimulation for treatment of anejaculation in quadriplegic men. Arch Phys Med Rehabil. 1995;76(1):59-64. [pmid: 7811177].
51 Dahlberg A, Ruutu M, Hovatta O. Pregnancy results from a vibrator application, electroejaculation, and a vas aspiration programme in spinal-cord injured men. Hum Reprod. 1995;10(9):2305-7. [pmid: 8530657].
52 Nehra A, Werner M A, Bastuba M, Title C, Oates R D. Vibratory stimulation and rectal probe electroejaculation as therapy for patients with spinal cord injury: semen parameters and pregnancy rates. J Urol. 1996;155(2):554-9. [pmid: 8558659].
53 Beretta G, Chelo E, Zanollo A. Reproductive aspects in spinal cord injured males. Paraplegia. 1989;27(2):113-8. [pmid: 2717193].
54 Chung P H, Verkauf B S, Mola R, Skinner L, Eichberg R D, Maroulis G B. Correlation between semen parameters of electroejaculates and achieving pregnancy by intrauterine insemination. Fertil Steril. 1997;67(1):129-32. [pmid: 8986697].
55 Sonksen J, Sommer P, Biering-Sorensen F, Ziebe S, Lindhard A, Loft A, et al. Pregnancy after assisted ejaculation procedures in men with spinal cord injury. Arch Phys Med Rehabil. 1997;78(10):1059-61. [pmid: 9339152].
56 Chen D, Hartwig D M, Roth E J. Comparison of sperm quantity and quality in antegrade V retrograde ejaculates obtained by vibratory penile stimulation in males with spinal cord injury. Am J Phys Med Rehabil. 1999;78(1):46-51. [pmid: 9923429].
57 Taylor Z, Molloy D, Hill V, Harrison K. Contribution of the assisted reproductive technologies to fertility in males suffering spinal cord injury. Aust N Z J Obstet Gynaecol. 1999;39(1):84-7. [pmid: 10099757].
58 Pryor J L, Kuneck P H, Blatz S M, Thorp C, Cornwell C E, Carrell D T. Delayed timing of intrauterine insemination results in a significantly improved pregnancy rate in female partners of quadriplegic men. Fertil Steril. 2001;76(6):1130-5. [pmid: 11730739].
59 Heruti R J, Katz H, Menashe Y, Weissenberg R, Raviv G, Madjar I, et al. Treatment of male infertility due to spinal cord injury using rectal probe electroejaculation: the Israeli experience. Spinal Cord. 2001;39(3):168-75. [pmid: 11326328].
60 Ohl D A, Sonksen J, Menge A C, McCabe M, Keller L M. Electroejaculation versus vibratory stimulation in spinal cord injured men: sperm quality and patient preference. J Urol. 1997;157(6):2147-9. [pmid: 9146603].
61 Brackett N L, Padron O F, Lynne C M. Semen quality of spinal cord injured men is better when obtained by vibratory stimulation versus electroejaculation. J Urol. 1997;157(1):151-7. [pmid: 8976239].
62 Park C I, Shin J, Kim D, Cho S. Ejaculatory induction and semen analysis with vibratory and electrical stimulation in spinal cord injured patients. Arch Phys Med Rehabil. 1999;80:1195.
63 Warner H, Martin D E, Perkash I, Speck V, Nathan B. Electrostimulation of erection and ejaculation and collection of semen in spinal cord injured humans. J Rehabil Res Dev. 1986;23(3):21-31. [pmid: 3490567].
64 Martin D E, Warner H, Crenshaw T L, Crenshaw R T, Shapiro C E, Perkash I. Initiation of erection and semen release by rectal probe electrostimulation (RPE). J Urol. 1983;129(3):637-42. [pmid: 6834568].
65 Seager S W J, Halstead L S. Electroejaculation - techniques and results. J Spinal Cord Med. 2000;23(3):174.
66 Loecher-Ernst D, Grosse J, Mandalka B, Kramer G, Stohrer M. Semen retrieved and fertility in 229 spinal cord injured males:longterm results of a fertility program in spinal cord injured males. J Spinal Cord Med. 1998;21(2):164.
67 Elliott S L, Griffin S, Ekland M, Nigro M. Vibrostimulation - techniques and results. J Spinal Cord Med. 2000;23(3):175.
68 Chapelle P A, Blanquart F, Puech A J, Held J P. Treatment of anejaculation in the total paraplegic by subcutaneous injection of Physostigmine. Paraplegia. 1983;21(1):30-6. [pmid: 6835690].
69 Leduc B E, Roy D, Poulin O. The use of physostigmine in men with spinal cord injury with ejaculatory dysfunction. Can J Rehab. 1992;5(4):231-5.
70 Brackett N L, Abae M, Padron O F, Lynne C M. Treatment by assisted conception of severe male factor infertility due to spinal cord injury or other neurologic impairment. J Assist Reprod Genet. 1995;12(3):210-6. [pmid: 8520188].
71 Hultling C, Rosenlund B, Levi R, Fridstrom M, Sjoblom P, Hillensjo T. Assisted ejaculation and in-vitro fertilization in the treatment of infertile spinal cord-injured men: the role of intracytoplasmic sperm injection. Hum Reprod. 1997;12(3):499-502. [pmid: 9130750].
72 Brinsden P R, Avery S M, Marcus S, Macnamee M C. Transrectal electroejaculation combined with in-vitro fertilization: effective treatment of anejaculatory infertility due to spinal cord injury. Hum Reprod. 1997;12(12):2687-92. [pmid: 9455836].
73 Buch J P, Zorn B H. Evaluation and treatment of infertility in spinal cord injured men through rectal probe electroejaculation. J Urol. 1993;149(5 Pt 2):1350-4. [pmid: 8479034].
74 Elliott S L, Nigro M, Ekland M B, Griffin S, Allison G. The Vancouver experience: sperm retrieval program. J Spinal Cord Med. 2002;25(Suppl1):s14.
75 Matthews G J, Gardner T A, Eid J F. In vitro fertilization improves pregnancy rates for sperm obtained by rectal probe ejaculation. J Urol. 1996;155(6):1934-7. [pmid: 8618291].
76 Ohl D A, Denil J, Fitzgerald-Shelton K, McCabe M, McGuire E J, Menge A C, et al. Fertility of spinal cord injured males: effect of genitourinary infection and bladder management on results of electroejaculation. J Am Paraplegia Soc. 1992;15(2):53-9. [pmid: 1583503].
77 Rutkowski S B, Middleton J W, Truman G, Hagen D L, Ryan J P. The influence of bladder management on fertility in spinal cord injured males. Paraplegia. 1995;33(5):263-6. [pmid: 7630651].
78 Ohl D A, Bennett C J, McCabe M, Menge A C, McGuire E J. Predictors of success in electroejaculation of spinal cord injured men. J Urol. 1989;142(6):1483-6. [pmid: 2585621].
79 Wang Y H, Chiang H S, Wu C H, Lien I N. Electroejaculation in spinal cord injured males. J Formos Med Assoc. 1992;91(4):413-8. [pmid: 1358310].
80 Siosteen A, Forssman L, Steen Y, Sullivan L, Wickstrom I. Quality of semen after repeated ejaculation treatment in spinal cord injury men. Paraplegia. 1990;28(2):96-104. [pmid: 2235028].
81 Brackett N L, Lynne C M, Weizman M S, Bloch W E, Padron O F. Scrotal and oral temperatures are not related to semen quality of serum gonadotropin levels in spinal cord-injured men. J Androl. 1994;15(6):614-9. [pmid: 7721665].
82 Brackett N L, Santa-Cruz C, Lynne C M. Sperm from spinal cord injured men lose motility faster than sperm from normal men: the effect is exacerbated at body compared to room temperature. J Urol. 1997;157(6):2150-3. [pmid: 9146604].
83 Beretta G, Zanollo A, Chelo E, Livi C, Scarselli G. Seminal parameters and auto-immunity in paraplegic/quadraplegic men. Acta Eur Fertil. 1987;18(3):203-5. [pmid: 3439407].
84 Bensman A, Kottke F J. Induced emission of sperm utilizing electrical stimulation of the seminal vesicles and vas deferens. Arch Phys Med Rehabil. 1966;47(7):436-43. [pmid: 4952412].
85 Brindley G S, Scott G I, Hendry W F. Vas cannulation with implanted sperm reservoirs for obstructive azoospermia or ejaculatory failure. Br J Urol. 1986;58(6):721-3. [pmid: 3801834].
86 Hirsch I H, Sedor J, Kulp D, McCue P J, Staas W E Jr. Objective assessment of spermatogenesis in men with functional and anatomic obstruction of the genital tract. Int J Androl. 1994;17(1):29-34. [pmid: 8005706].
87 Perkash I, Martin D E, Warner H, Blank M S, Collins D C. Reproductive biology of paraplegics: results of semen collection, testicular biopsy and serum hormone evaluation. J Urol. 1985;134(2):284-8. [pmid: 3927013].
88 Brackett N L, Lynne C M, Aballa T C, Ferrell S M. Sperm motility from the vas deferens of spinal cord injured men is higher than from the ejaculate. J Urol. 2000;164(3 Pt 1):712-5. [pmid: 10953131].
89 Chen D, Hartwig D M, Roth E J. Comparison of sperm quantity and quality in antegrade V retrograde ejaculates obtained by vibratory penile stimulation in males with spinal cord injury. Am J Phys Med Rehabil. 1997;78(1):46-55. [pmid: 9923429].
90 Brackett N L, Davi R C, Padron O F, Lynne C M. Seminal plasma of spinal cord injured men inhibits sperm motility of normal men. J Urol. 1996;155(5):1632-5. [pmid: 8627840].
91 Mallidis C, Lim T C, Hill S T, Skinner D J, Brown D J, Johnston W I, et al. Necrospermia and chronic spinal cord injury. Fertil Steril. 2000;74(2):221-7. [pmid: 10927035].
92 Hellstrom W J, Stone A R, Deitch A D, deVere White R W. The clinical application of aspiration deoxyribonucleic acid flow cytometry to neurologically impaired men entering an electroejaculation program. J Urol. 1989;142(2 Pt 1):309-12. [pmid: 2787410].
93 Monga M, Dunn K, Rajasekaran M. Characterization of ultrastructural and metabolic abnormalities in semen from men with spinal cord injury. J Spinal Cord Med. 2001;24(1):41-6. [pmid: 11587434].
94 de Lamirande E, Leduc B E, Iwasaki A, Hassouna M, Gagnon C. Increased reactive oxygen species formation in semen of patients with spinal cord injury. Fertil Steril. 1995;63(3):637-42. [pmid: 7851599].
95 Hirsch I H, Sedor J, Callahan H J, Staas W E. Antisperm antibodies in seminal plasma of spinal cord-injured men. Urology. 1992;39(3):243-7. [pmid: 1546417].
96 Hirsch I H, McCue P, Allen J, Lee J, Staas W E. Quantitative testicular biopsy in spinal cord injured men: comparison to fertile controls. J Urol. 1991;146(2):337-41. [pmid: 1856929].
97 Odum L, Sonksen J, Biering-Sorensen F. Seminal somatostatin in men with spinal cord injury. Paraplegia. 1995;33(7):374-6. [pmid: 7478725].
98 Hou J W, Chen D, Jeyendran R S. Sperm nuclear maturity in spinal cord-injured men: evaluation by acidic aniline blue stain. Arch Phys Med Rehabil. 1995;76(5):444-5. [pmid: 7537955].
99 Brackett N L, Lynne C M, Weizman M S, Bloch W E, Abae M. Endocrine profiles and semen quality of spinal cord injured men. J Urol. 1994;151(1):114-9. [pmid: 8254785].
100 Sipski M L, Alexander C J, Rosen R C. Physiological parameters associated with psychogenic sexual arousal in women with complete spinal cord injuries. Arch Phys Med Rehabil. 1995;76(9):811-8. [pmid: 7668950].
101 Sipski M L, Alexander C J, Rosen R C. Orgasm in women with spinal cord injuries: a laboratory-based assessment. Arch Phys Med Rehabil. 1995;76(12):1097-102. [pmid: 8540784].
102 Sipski M L, Rosen R C, Alexander C J. Physiological parameters associated with the performance of a distracting task and genital self-stimulation in women with complete spinal cord injuries. Arch Phys Med Rehabil. 1996;77(5):419-24. [pmid: 8629915].
103 Komisaruk B R, Gerdes C A, Whipple B. ‘Complete’ spinal cord injury does not block perceptual responses to genital self-stimulation in women. Arch Neurol. 1997;54(12):1513-20. [pmid: 9400361].
104 Whipple B. Sexual responses to self-stimulation in women with complete spinal cord injury. J Sex Res. 1996;33(3):231-40.
105 Sipski M L, Rosen R C, Alexander C J, Hamer R M. Sildenafil effects on sexual and cardiovascular responses in women with spinal cord injury. Urology. 2000;55(6):812-5. [pmid: 10840082].
106 Beretta G, Saltarelli O, Marzotto M, Zanollo A, Re B. Transcutaneous minoxidil in the treatment of erectile dysfunctions in spinal cord injured men. Acta Eur Fertil. 1993;24(1):27-30. [pmid: 8303971].
107 Kim E D, McVary K T. Topical prostaglandin-E1 for the treatment of erectile dysfunction. [see comments]. J Urol. 1995;153(6):1828-30. [pmid: 7752328].
108 Sonksen J, Biering-Sorensen F. Transcutaneous nitroglycerin in the treatment of erectile dysfunction in spinal cord injured. Paraplegia. 1992;30(8):554-7. [pmid: 1522996].
109 Kim E D, el Rashidy R, McVary K T. Papaverine topical gel for treatment of erectile dysfunction. J Urol. 1995;153(2):361-5. [pmid: 7815584].
110 Costa P, Bressolle F, Sarrazin B, Mosser J, Navratil H, Galtier M. Moxisylyte plasma kinetics in humans after intracavernous administration. Biopharm Drug Dispos. 1992;13(9):671-9. [pmid: 1467454].
111 Costa P, Sarrazin B, Bressolle F, Mottet N, Louis J F, Saudubray F, et al. Is the volume injected a parameter likely to influence the erectile response observed after intracavernous administration of an alpha-blocking agent?. Eur Urol. 1993;24(1):43-7. [pmid: 8365438].
112 Hirsch I H, Smith R L, Chancellor M B, Bagley D H, Carsello J, Staas W E Jr. Use of intracavernous injection of prostaglandin E1 for neuropathic erectile dysfunction. Paraplegia. 1994;32(10):661-4. [pmid: 7831071].
113 Tang S F, Chu N K, Wong M K. Intracavernous injection of prostaglandin E1 in spinal cord injured patients with erectile dysfunction. A preliminary report. Paraplegia. 1995;33(12):731-3. [pmid: 8927414].
114 Earle C M, Keogh E J, Ker J K, Cherry D J, Tulloch A G, Lord D J. The role of intracavernosal vasoactive agents to overcome impotence due to spinal cord injury. Paraplegia. 1992;30(4):273-6. [pmid: 1625897].
115 Zaslau S, Nicolis C, Galea G, Britanico J, Vapnek J M. A simplified pharmacologic erection program for patients with spinal cord injury. J Spinal Cord Med. 1999;22(4):303-7. [pmid: 10751135].
116 Sidi A A, Cameron J S, Dykstra D D, Reinberg Y, Lange P H. Vasoactive intracavernous pharmacotherapy for the treatment of erectile impotence in men with spinal cord injury. J Urol. 1987;138(3):539-42. [pmid: 2442418].
117 Kapoor V K, Chahal A S, Jyoti S P, Mundkur Y J, Kotwal S V, Mehta V K. Intracavernous papaverine for impotence in spinal cord injured patients. Paraplegia. 1993;31(10):675-7. [pmid: 8259331].
118 Golji H. Experience with penile prosthesis in spinal cord injury patients. J Urol. 1979;121(3):288-9. [pmid: 430620].
119 Green B G, Sloan S L. Penile prostheses in spinal cord injured patients: combined psychosexual counselling and surgical regimen. Paraplegia. 1986;24(3):167-72. [pmid: 3748596].
120 Gross A J, Sauerwein D H, Kutzenberger J, Ringert R H. Penile prostheses in paraplegic men. Br J Urol. 1996;78(2):262-4. [pmid: 8813925].
121 Iwatsubo E, Tanaka M, Takahashi K, Akatsu T. Non-inflatable penile prosthesis for the management of urinary incontinence and sexual disability of patients with spinal cord injury. Paraplegia. 1986;24(5):307-10. [pmid: 3774367].
122 Montague D K. Penile prosthesis implantation in men with neurogenic impotence. Sex Disabil. 1994;12(1):94-8.
123 Giuliano F, Hultling C, El Masry W S, Smith M D, Osterloh I H, Orr M, et al. Randomized trial of sildenafil for the treatment of erectile dysfunction in spinal cord injury. Sildenafil Study Group. Ann Neurol. 1999;46(1):15-21. [pmid: 10401776].
124 Maytom M C, Derry F A, Dinsmore W W, Glass C A, Smith M D, Orr M, et al. A two-part pilot study of sildenafil (VIAGRA) in men with erectile dysfunction caused by spinal cord injury. Spinal Cord. 1999;37(2):110-6. [pmid: 10065749].
125 Gans W H, Zaslau S, Wheeler S, Galea G, Vapnek J M. Efficacy and safety of oral sildenafil in men with erectile dysfunction and spinal cord injury. J Spinal Cord Med. 2001;24(1):35-40. [pmid: 11587433].
126 Kier AJ, Kennelly MJ, Holdren RE, Land DG, Hudson BS, Clontz DR. Sildenafil effects on spinal cord patients with erectile dysfunction. 16th American association of spinal cord injury nurses conference 1999;32–3.
127 Takeda H, Otani T, Ito Y. Efficacy of sildenafil citrate for ED associated with spinal cord injury. Int J Impot Res. 2000;12(Sup 2):s19. [pmid: 10982308].
128 Schmid D M, Schurch B, Hauri D. Sildenafil in the treatment of sexual dysfunction in spinal cord-injured male patients. Eur Urol. 2000;38(2):184-93. [pmid: 10895011].
129 Raviv G, Heruti R J, Shaked A, Katz H, Ohry A, Ramon J, et al. Sexual rehabilitation: clinical experience with sildenafil citrate (Viagra) in spinal cord injured patients. Int J Impot Res. 2000;12(Suppl 5):s1.
130 Laschke S, Carl S, Staehler G, Gerner H J. Efficacy and reproducibility of sildenafil (Viagra) in erectile dysfunction in spinal cord injured men. J Spinal Cord Med. 2002;25(Suppl1):s43. [pmid: 11939466].
131 Sanchez R A, Vidal J, Jauregui M L, Barrera M, Recio C, Giner M, et al. Efficacy, safety and predictive factors of therapeutic success with sildenafil for erectile dysfunction in patients with different spinal cord injuries. Spinal Cord. 2001;39(12):637-43. [pmid: 11781860].
132 Courtois F, Mathieu C, Charvier K. Sexual rehabilitation for men with spinal cord injury: Preliminary report on a behavioral strategy. Sex Disabil. 2001;19(2):153-7.
133 Bodner D R, Haas C A, Krueger B, Seftel A D. Intraurethral alprostadil for treatment of erectile dysfunction in patients with spinal cord injury. Urology. 1999;53(1):199-202. [pmid: 9886612].
134 Waldbaum J, Chen D, Nussbaum S B, Hartwig D M. Use of transurethral alprostadil to treat erectile dysfunction in spinal cord injured patients. Arch Phys Med Rehabil. 1998;79:1184.
135 Zasler N D, Katz P G. Synergist erection system in the management of impotence secondary to spinal cord injury. Arch Phys Med Rehabil. 1989;70(9):712-6. [pmid: 2774893].
136 Heller L, Keren O, Aloni R, Davidoff G. An open trial of vacuum penile tumescence: constriction therapy for neurological impotence. Paraplegia. 1992;30(8):550-3. [pmid: 1522995].
137 van der Aa H E, Alleman E, Nene A, Snoek G. Sacral anterior root stimulation for bladder control: clinical results. Arch Physiol Biochem. 1999;107(3):248-56. [pmid: 10650355].
138 Clontz D, Kier A, Land D, Hudson B, Kennelly M. Effects of sildenafil on spinal cord injury patients suffering from erectile dysfunction. J Spinal Cord Med. 1999;22(1):48-9.
139 Derry F A, Dinsmore W W, Fraser M, Gardner B P, Glass C A, Maytom M C, et al. Efficacy and safety of oral sildenafil (Viagra) in men with erectile dysfunction caused by spinal cord injury. Neurology. 1998;51(6):1629-33. [pmid: 9855514].
140 Shenot P J, Rajan R, Rivas D A. Initial experience with sildenafil (viagra) in spinal cord injured men with erectile dysfunction. J Spinal Cord Med. 1999;22(1):49.
141 Sildenafil in men with spinal cord injury. Nurses Drug Alert 1999;23(2): 12.
142 Beretta G, Zanollo A, Fanciullacci F, Catanzaro F. Intracavernous injection of papaverine in paraplegic males. Acta Eur Fertil. 1986;17(4):283-4. [pmid: 3577592].
143 Renganathan R, Suranjan B, Kurien T. Comparison of transdermal nitroglycerin and intracavernous injection of papaverine in the treatment of erectile dysfunction in patients with spinal cord lesions. Spinal Cord. 1997;35(2):99-103. [pmid: 9044517].
144 Potter P J, Hayes K C, Segal J L, Hsieh J T, Brunnemann S R, Delaney G A, et al. Randomized double-blind crossover trial of fampridine-SR (sustained release 4-aminopyridine) in patients with incomplete spinal cord injury. J Neurotrauma. 1998;15(10):837-49. [pmid: 9814639].
145 Jaworski T M, Richards J S, Lloyd L K. Retrospective review of sexual and marital satisfaction of spinal cord injury and diabetic males post penile injection or implant. Urology. 1992;40(2):127-31. [pmid: 1502747].
146 Richards J S. Treatment of erectile dysfunction secondary to spinal cord injury: Sexual and psychosocial impact on couples. Rehabil Psych. 1993;37(3):211-3.
147 Ohl D A, Wolf L J, Menge A C, Christman G M, Hurd W W, Ansbacher R, et al. Electroejaculation and assisted reproductive technologies in the treatment of anejaculatory infertility. Fertil Steril. 2001;76(6):1249-55. [pmid: 11730759].
148 Padron O F, Brackett N L, Weizman M S, Lynne C M. Semen of spinal cord injured men freezes reliably. J Androl. 1994;15(3):266-9. [pmid: 7928669].
149 Whipple B, Komisaruk B R. Brain (PET) responses to vaginal-cervical self-stimulation in women with complete spinal cord injury: preliminary findings. J Sex Marital Ther. 2002;28(1):79-86. [pmid: 11928182].
150 Le Chapelain L, Nguyen V T, Dehail P, Berjon J J, Barat M, Mazaux J M, et al. Ejaculatory stimulation, quality of semen and reproductive aspects in spinal cord injured men. Spinal Cord. 1998;36(2):132-6. [pmid: 9495004].
151 Bodner D R, Seftel A, Krueger B. Intraurethral Alprostsdil (MUSE) for treatment of erectile dysfunction in spinal cord injured patients. J Spinal Cord Med. 1998;21(2):186-7.
152 van der Aa H E, Hermens H, Alleman E, Vorsteveld H. Sacral anterior root stimulation for bladder control in patients with a complete lesion of the spinal cord. Acta Neurochir (Wien). 1995;134(12):88-92. [pmid: 7668136].
153 Giuliano F, Hultling C, El Masry WS, Luchner E, Stien R, Maytom MC, et al. Sildenafil citrate (VIAGRA): a novel oral treatment for erectile dysfunction caused by traumatic spinal cord injury. Int J Clin Pract 1999;Supplement. 102:24–6.
154 Hultling C. Partners' perceptions of the efficacy of sildenafil citrate (VIAGRA) in the treatment of erectile dysfunction. Int J Clin Pract 1999;Supplement. 102:16–8.
155 Hultling C, Giuliano F, Quirk F, Pena B, Mishra A, Smith M D. Quality of life in patients with spinal cord injury receiving Viagra (sildenafil citrate) for the treatment of erectile dysfunction. Spinal Cord. 2000;38(6):363-70. [pmid: 10889565].
156 Chancellor M B, Rivas D A, Panzer D E, Freedman M K, Staas W E Jr. Prospective comparison of topical minoxidil to vacuum constriction device and intracorporeal papaverine injection in treatment of erectile dysfunction due to spinal cord injury. Urology. 1994;43(3):365-9. [pmid: 8134992].
157 Chapelle P A, Roby-Brami A, Yakovleff A, Bussel B. Neurological correlations of ejaculation and testicular size in men with a complete spinal cord section. J Neurol Neurosurg Psychiatry. 1988;51(2):197-202. [pmid: 3346683].