# Acknowledgments

The authors would like to thank several individuals for their support of the present project: Nick Barrowman, who helped with the statistical analysis, Margaret Sampson, who helped with conducting the literature search, and Drs. Isabella Steffensen and Christine Murray for their assistance in the writing and editing of this report.