# Discussion

## Limitations

Much of the literature reviewed consisted of clinic reports in case-series format, describing a center's experience with a variety of treatment techniques. Although these descriptive experiences are valuable, they are often reported in variable formats with different outcome measures, providing little consistency for comparative purposesacross studies. Similarly, the quality of reporting, especially the earlier publications, is less than optimal.

As in all scientific fields, changes in technology tend to influence, and perhaps confound the effectiveness of interventions. We have tried to account for this “evolution” in technology by pooling results from the last decade, excluding early attempts that tended to have smaller numbers of patients, with lower success rates. We do not wish in any way to belittle the groundbreaking research of these earlier pioneers, without whose efforts we would still be counselling our patients to “forget about sex or having children,” as was done only several decades ago. The pioneers encouraged us all to try to do “something,” and our own early clinical experience reflects this; for example, we would inject intrathecal physostigmine into patients in the clinic with a kidney basin nearby to catch their vomit and a test tube to catch their semen—this before we knew that a simple modified vibrator could do the same. We hope this report accurately reflects the rapid evolution of this field, while respecting its history. Despite the somewhat high statistical heterogeneity in the pooled data, clinicians are familiar with discussing ranges of success with their patients, and saying that “this technique has a success rate of 80% to 90%” is not at all uncomfortable to those who deal with biologic uncertainties.

For fertility in males after SCI, one source of heterogeneity was a secular trend in success rates. For this reason, only studies from the last decade were pooled. Nevertheless, in each of the meta-analyses conducted in this evidence report, statistically significant heterogeneity remained. In the presence of statistical heterogeneity, confidence intervals for random effects pooled estimates are broadened to account for differences amongst the studies. However, these results should still be treated with caution, and we discuss other factors that may be contributing to the observed heterogeneity.

## Fertility in Females After SCI

It is often stated, both in review articles and by clinician teachers at the bedside, that although there is an initial acute delay in the return of ovulation cycles in females following SCI, ultimately there is no impact on female fertility by the injury per se. Although this statement may be true, it is unfortunately not supported by studies comparing fertility of women with SCI with an uninjured cohort. There may well be unsuspected effects of SCI on the rate of miscarriages and live births in couples trying to have a child. A prospective, well-organized and well-reported case-series or cohort study, potentially involving multiple centers, could provide valuable natural history information to answer this question.

## Fertility in Males After SCI

In 1960, Bors and Comarr reported that males post-SCI had a fertility rate of less than 10%. Not surprisingly, since male reproduction is most obviously affected, the vast majority of fertility literature focuses on male reproduction post-SCI. In addition to this the vast majority of spinal cord injuries occur in men, most western nations approximately 80 percent of injured persons are male. Initial attempts to help infertile couples conceive a child were used to develop techniques to harvest sperm from the SCI male and inseminate the female partner, either using taught self-insemination or clinic intrauterine insemination. Although successful, these efforts were hampered by the low semen quality often found in SCI males. Later, IVF and ICSI techniques were used to overcome this problem, and now patients can typically expect a stepped approach in a fertility clinic, where couples start with the least invasive approach and progress to the most invasive techniques. Although these techniques improve the chances of a successful live birth by up over 50%, they are extremely expensive and somewhat invasive, with female partners often exposed to hormonal cycle manipulation and SCI males undergoing testicular biopsies and aspirations. Although these risks and expenses mirror those of other infertile couples, we must remember that those living with SCI have additional lifelong equipment and care expenses, as well as reduced employment opportunities, creating financial burdens that may not allow them to consider these options. This financial situation has imposed a new form of limitation on pregnancy success. There is therefore a need for research to improve semen quality in men with SCI so that pregnancy may be attempted at lower cost and less invasiveness in these couples. As a result of this combination of expense and invasiveness, most fertility clinics utilized a stepped approach, going from the most natural and inexpensive and least invasive methodology to the enhanced fertility option in a graduated approach. This may account for some of the heterogeneity in the data, nevertheless we felt that it was worthwhile to pool the fertility data to enable us to compare the results of this type of treatment for SCI males to the fertility treatment for the general population. It is also recognized that in the fertility literature in general, it is likely that this type of heterogeneity will also be present, again influenced by invasiveness as well as by cost.

Despite the fact that fertility clinic data is extremely valuable in understanding this subject area, many of the case-series studies published on fertility were rated low in quality. Since most fertility clinic data is reported in a similar fashion, the Spinal Consortium could improve the quality of future data by publishing guidelines on the reporting of case-series studies and case-control study designs.

Original articles recounting issues of fertility after SCI describe the problem of harvesting semen and the poor quality of the semen as factors inhibiting success. Our review demonstrates that by using vibration for upper motor neuron injuries and electroejaculation for the remaining lower motor neuron injuries, semen can be harvested in 80% to 90% of cases. Furthermore, testicular biopsy or vas deferens aspiration techniques, although expensive and invasive, are usually successful in the remaining patients. Partner pregnancy is achieved usually using a stepped approach, moving from intrauterine insemination to IVF techniques with success rates for achieving a pregnancy of up to 50%. Sperm freezing probably does little to enhance this process unless the sperm is frozen almost immediately after injury, usually a difficult time to make such life decisions.

### Sperm Quality in Males with SCI

There has been much discussion regarding the abnormal sperm found in the ejaculate of males with SCI including: decreased sperm counts,^87^ decreased sperm motility,^82,^ ^87,^ ^94^increased reactive oxygen species formation,^94^ sperm autoimmunity,^83^ necrospermia,^91^ the inhibitive effect of seminal plasma in SCI males,^90^ and the presence of antisperm antibodies.^95^ Methods used to counteract these negative effects include retrieving the semen more proximally through testicular biopsy or aspiration.^85,^ ^88^ Medical factors can also be optimized in order to try to improve sperm quality. Chapelle et al.^157^ studied 135 SCI males at various neurological levels using physostigmine and testicular volume, and found that damage to the T12-L2 region of the cord (T12 metamer) correlated with testicular atrophy and poor ability to ejaculate. Three studies examining the effects of bladder management on sperm quality found that those men managing their bladders with high-pressure reflex voiding had reduced sperm quality, whereas those men using intermittent catheterization had the best sperm parameters.^76–78^ Two studies documented the effect of repeated ejaculation on sperm quality and demonstrated that repeated ejaculation improved sperm quality to a plateau, but that too frequent ejaculation (once per week) decreased sperm quality.^79,^ ^80^ They also indicated that these procedures should be timed monthly with the female partner's cycle. Chen et al. compared the sperm counts in antegrade versus retrograde sperm samples, and found that although there was a non-statistical trend towards better sperm counts in antegrade specimens, retrograde ejaculation occurred more frequently.^56,^ ^89^ Bracket et al. studied the effect of temperature on the semen of SCI males and found that although the semen of SCI males lose motility faster than the sperm of normal males, especially at higher (body as opposed to room) temperatures,^82^ scrotal temperature and gonadotropin levels did not contribute to poor semen quality in SCI males.^81^

Although sperm motility and other aspects of fertility are seldom reported after acute SCI, studies show that in the chronically spinal cord injured individual (>1 year), there is no relationship between duration of injury and sperm quality.^77–79,^ ^87^ However, Mallidus et al.^46^ demonstrated that the sperm motility and viability first improve after the acute patient comes out of spinal shock then rapidly starts to deteriorate, reaching the levels observed in males with chronic SCI by Day 16 after injury.^46^ Padron,^148^ in a case-series study, and Green^37^ in a case report, demonstrated that although sperm from SCI males freezes reliably, there is still a great reduction in sperm motility.

When these data are considered together, one can conclude that there is little to support the practice of freezing the sperm of SCI males after 16 days post-injury, and that even the advantages of early freezing (within the first 2 weeks) is outweighed by the loss of sperm motility during the procedure, since with modern techniques one is virtually certain of obtaining fresh sperm from the SCI male when he is ready to conceive a child in later years.

## Sexual Dysfunction in Females with SCI

The studies done on female sexuality post-SCI, especially the thorough work done by Sipski, present fresh ideas and debunk old myths. Even without genital sensation, females with SCI have both reflex and cognitive pathways available to them to alow pleasurable experiences during sexual activities. Reflex pathways can be enhanced with increased stimulation (i.e. vibration) and cognitive behavioral therapy can enhance cognitive stimulation. Unfortunately, aside from a small RCT pilot with Viagra®, little has been done to study possible interventions along this line. Despite the early hope in the small Viagra® study, a large multicentre Viagra® study that has just been completed and not yet published, failed to reveal any benefit in SCI females with sexual arousal disorder (personal communication).

Cognitive/behavioral therapy is often used in clinical settings to help address female sexuality issues after SCI, yet there are no trials to support its use. These trials could be conducted, and it would be useful to describe protocols to help set practice standards in this important area. Given the complex biosocial issues described by Sipski, it is unlikely that pharmaceutical treatment alone will address the problems.

## Male Sexual Dysfunction

Although attractive conceptually, topical and intraurethral pharmaceutical agents have not had much success in treating individuals with SCI erectile dysfunction. However, penile injections with a variety of medications have proven extrememly successful. It can be noted that careful dosage adjustment is necessary with the papaverine or papaverine/phentolamine combinations. When used alone, prostaglandin E1 has few side effects outside of its cost.

If subjects are reliable and if they have little sensation there seems to be few advantages of Viagra® over intracavernous injections aside from subject and partner preference.

Although other phosphodiesterase inhibitors have come to market since sildanefil, no SCI treatment data for these drugs were available at the time of this review.

Both vacuum pumps and intracavernous injections must be used with caution or not at all in anticoagulated patients because of the risk of hemorrhaging or bruising. Both treatment groups must also be monitored for priapism. Both of these complications appear to be quite rare if patients are first tested and instructed in the clinic before being sent home for self-treatment.

## Research and Clinical Implications

Our review highlights some important issues in terms of how spinal cord clinical research is conducted. Like many other clinical content areas, there is a wide variation in the types of research designs used and measures used to assess similar outcomes. Although different approaches, particularly if they provide similar results, help to provide powerful evidence about the robustness of interventions, such as the use of Viagra®, there are important and often debilitating consequences for such research development. Often, separate groups are so unique that the process of how their arrived at the results are disparate making it difficult to impossible to get a broad holistic view of the evidence base in the field.

To help overcome these problems groups are coming together and proposing more standardization when conducting clinical research. The rheumatology community provides an excellent example through the OMERACT initiative. For example, they have agreed upon standard methodologies and forms to collect specific outcomes. The advantage is that clinical trials conducted by various groups are ‘similar’ in terms of design features and outcomes. As such this information can be combined qualitatively and quantitatively providing the strongest possible evidence base regarding the merits of specific interventions. Such an approach might be beneficial for groups trying to advance this field of research and understanding.

Such actions are also happening for reporting clinical trials. The clinical trials community has moved towards a standard for reporting randomized trials. The CONSORT Statement, a 22-item checklist and flow diagram, is now required by most major medical journals when authors are submitting reports of randomized trials.

Finally, the female SCI literature describes biosocial holistic models of sexuality and, therefore, is ripe for trials involving multidimensional treatment modalities. The male SCI literature seems completely unidimensional (male sexuality + erection) and this focus deprives males from those same treatment options, the danger is that the clinician, when faced with a suffering patient, reaches into their drawer for the drug sample. Research must be driven by patient need—this literature is not.

As a final point, clinicians working in this area are confronted with issues from same sex couples, with absolutely no literature to guide them in this discussion. Well-conducted, qualitative analysis work would provide a great deal of clarity in these matters, but again this literature is absent.

## Conclusions

There were two general themes in this review—sexuality and fertility after SCI. These reviewers often found the division between these two themes to be artificial, and overlap often occurred. Nevertheless, we attempted to discern between the two bodies of literature.

There is a great deal of literature in this area; however, much of the data was found to be repeat data (i.e., nonoriginal), and new data was incompletely reported, resulting in the evidence often being of poor quality. However, given these limitations and those outlined in the Discussion, we would like to answer the questions posed in as straightforward a manner as the evidence allows for:

1. Reproductive health: What is the current fertility rate for men and women after SCI?
  For women, fertility rate is likely unaffected but little is known beyond that. For example, is there a higher pregnancy failure rate, or are there more or less birth deformities?
  - Are fertility rates changed by freezing a new patient's sperm?
    Unless done in the first one or two weeks after SCI, and even if done earlier, this intervention is unlikely to make a significant improvement in SCI fertility rates, and therefore is not widely practiced.
  - Are there better fertility rates using electroejaculation or vibration? Does order of method influence outcome?
    The level of invasiveness is likely more of a factor than either the choice or the order. Vibration should be tried at least on all upper motor neuron injuries first, with electroejaculation reserved for those failures and the lower motor neuron injuries
  - To improve fertility rates, when should invasive techniques such as testicular biopsy or aspiration or ICSI be pursued?
    Testicular biopsy or vas aspirations should be reserved for those patients who cannot achieve sperm harvesting or whose harvested sperm by the above techniques is of very low quality. ICSI can greatly enhance success in those individuals whose sperm quality is insufficient for intrauterine insemination (IUI).
  - Are there pregnancy complications and prospective obstetric management issues for SCI females?
    Yes, but they are not described in the literature except in author opinion pieces and case reports. Comparative case series and cohort studies would add a great deal of information to this area.
2. Male sexuality: How has the availability of Viagra® and other remediation affected sexual function, frequency of activity, and adjustment after SCI?
  Penile injection, Viagra® and vacuum devices can help most problems in SCI males with erectile dysfunction, making the need for penile implants less common. These interventions positively affect sexual activity at least in the short-term. Long-term sexual adjustment has not been examined.
  - Is Viagra® really more benign than intracavernous injections?
    Not really, unless the patient has enough sensation that the injections are uncomfortable or if they find that the paraphernalia affects their sexual activity.
  - How does the morbidity of prostaglandin injections compare to the older (less expensive) papaverine?
    Although the efficacy of these two treatments is similar, priapism and discomfort are reported more frequently with papaverine.
  - What is the morbidity of vacuum tumescence devices?
    There is a paucity of reports regarding the morbidity of these pumps. These devices are not recommended in patients on anticoagulants. Patients must take care to remove the device after sexual activity.
  - What indications, if any, remain for implantable penile prosthetic devices?
    Very few patients will not respond to any of the more benign techniques. Penile implants still possess a significant morbidity risk, and in case-series studies, implants are often described with condom drainage systems.