# Results

## Results of Literature Search

A total of 2,420 bibliographic records were retrieved through database searches (QUOROM flow chart, Appendix C). After duplicate records were removed, 2,082 unique items remained. An additional 46 potentially relevant studies were identified through conference abstracts or were nominated by manufacturers. A total of 2,128 reports were evaluated against the eligibility criteria and after the initial screening for relevance, 1,627 records were excluded. Although the majority of the initial screening was performed in the phase I feasibility study,^37^ the additional studies that were identified when the search was “rerun” at the beginning of this study (n = 98, of which 47 were duplicates) were screened according to phase I criteria. The reasons for exclusion were: not relevant to SCI (n = 530); not relevant to sexuality or reproductive health (n = 410); case report or opinion piece (n = 282); no relevant measure reported (n = 271); not relevant to any of the questions (n = 78); and, report pertaining to adolescent or child only (n = 6). The remaining 501 reports were then retrieved and subjected to a more detailed relevance assessment. Two hundred and forty-five of these reports dealt with issues relating to fertility and 289 of the reports examined sexual dysfunction. After further relevance assessment, 180 of the 246 reports on fertility and 232 of the 289 reports on sexual dysfunction failed to meet the inclusion criteria. The reasons for exclusion are listed in the QUORUM flow chart (Appendix C). In total, 122 reports were deemed relevant for the systematic review—66 of the reports examined fertility and 56 reports examined sexual dysfunction in individuals with SCI. The Evidence Tables are presented in Appendix E. Evidence Tables1 to 3 present the fertility rate evidence from non-comparative case-series studies (Evidence Table 1), case-control studies (Evidence Table 2) and conference proceedings (Evidence Table 3). Evidence Tables 4 to 6 outline the evidence from RCTs (Evidence Table 4), other study designs (Evidence Table 5) and conference proceedings (Evidence Table 6), regarding the use of sildenafil (Viagra®).

## Report and Study Design Characteristics of Included Studies

The 122 studies included 6,668 individuals^1^, ranging in age from 16 years to 81 years, of which 78% of the studies enrolled only men and 6% of studies reporting all female participation. 14% of the included studies reported on the enrollment of couples only or together with single-case male participants.^2^

1 “Couples” were counted as a single case when pertaining to number of participants enrolled.

2 14% of the included studies reported on the enrollment of couples only or together with single-case male participants.

As might be expected, the complete spectrum of SCI severity was represented in the included studies. Eighty-seven studies (71%) reported on the level of lesion; 18 (15%) reported on the American Spinal Injury Association level of injury. With regards to the reporting of severity of injury, inconsistencies were observed between studies. The majority of studies used a non-comparative study design (61%) to address the question under consideration; for example, studies examining ejaculation rates in men with SCI typically did not include a comparator group but reported only on specific outcomes of a particular intervention to improve ejaculation rates. Few RCTs were identified that evaluated the efficacy of male sexual dysfunction, and the majority of these were duplicate publications. The quality of reporting of the 122 included studies was less than optimal. For example, of the 75 non-comparative studies, none reported on all of the quality items that were used to evaluate the reports. The highest number of quality criteria met was 16/19 items, and this was achieved by only one (1%) of the 75 studies.

### Fertility in Females After SCI

There were no studies found that investigated this question.

### Fertility in Males After SCI

We identified 22 non-comparative case series, including 806 men, which addressed ejaculation rates in men with SCI using vibration or electroejaculation.^38–59^ Three other case-series studies directly examined differences between the two techniques.^60–62^ We identified two articles that described the details of electroejaculation techniques and precautions in SCI males; however, these studies did not specifically address any of the questions posed by the consortium.^63,^ ^64^

Several authors reported results of electroejaculation and/or vibration studies using numerical breakdowns that could not be pooled.^24,^ ^65,^ ^66^ Koletis et al. described his clinical results with electroejaculation in some detail, but did not define the ejaculatory outcomes well, or report the incidence of side effects.^24^ Likewise, several abstracts either did not describe results in sufficient detail to abstract the data,^65,^ ^66^ or more complete description of the data was found in other publications.^67^

The use of physostigmine injection for ejaculation is described in two articles involving 57 SCI males.^68,^ ^69^

We identified 18 non-comparative case series, including 398 couples, reporting on pregnancies and/or live births.^41,^ ^44,^ ^48,^ ^50–55,^ ^57–59,^ ^69–74^ One additional case series describing IVF after electroejaculation included SCI patients but did not adequately breakdown the success rates by diagnosis.^75^

Nine studies involving 294 SCI males were designed to look at specific effects of medical and physical factors on SCI male fertility;^56,^ ^76–83^ however, these studies did not specifically address any of the questions posed by the consortium.

Five studies reporting on 69 SCI males described other more invasive techniques used to harvest semen.^84–88^

Finally, a further 12 articles reported on semen examination techniques or on various semen characteristics in SCI males, often to further delineate reasons for infertility and discuss possible treatments.^83,^ ^89–99^ However, these studies did not address specifically any of the questions posed by the consortium. These articles are referred to again in the discussion as they highlight treatment implication.

### Interventions for Female Sexual Dysfunction

We identified seven studies—six case-control studies^6,^ ^100–104^ and one RCT^105^—including 132 females with SCI, that addressed interventions for female sexual dysfunction.

### Male Sexual Dysfunction

We identified four studies, of which three were non-comparative case-series studies^106–108^ and one was a placebo-controlled clinical trial,^109^ that evaluated the use of topical agents (n = 53 patients) for sexual dysfunction in men with SCI. Eight studies, all of which were non-comparative case-series studies, examined intracavernous injections (n = 273).^110–117^ Five case-series studies evaluated penile implants (n = 363).^118–122^ Nine studies, of which two were RCTs^123,^ ^124^ and seven were case-series studies,^125–131^ evaluated Viagra® (n = 627). The remaining studies examined the use of other interventions for male sexual dysfunction including: behavioural methods (one case series^132^; n = 10); intraurethral Alprosatadil (two non-comparative case series;^133,^ ^134^ n = 30); vacuum devices (two case series;^135,^ ^136^ n = 50); sacral stimulators (one case series;^137^ n = 33); side effects associated with Viagra® (10 studies—five RCTs^123,^ ^138–141^ and five case-series studies^126–128,^ ^130,^ ^131^) and, side effects associated with intracavernous injections of prostaglandin and/or papaverine (seven studies—six non-comparative case-series^112,^ ^113,^ ^115–117,^ ^142^ and one RCT;^143^ n = 287). In one methodological article, rectal probe electrical stimulation is described as a treatment for erection.^64^ In 1998, Potter^144^ describes a non-statistical trend to improvement in sexual function with fampiridine SR (4-aminopyradine) in a small group of 29 patients.

We identified two studies that described the psychosocial benefits of treating impotence in SCI males;^145,^ ^146^ however, these studies did not specifically address any of the questions posed by the consortium. In 1992, Jaworski and colleagues used a case-control study design to describe a positive impact on marital relationships in 30 couples post-penile implant or intracavernous injection, and in 1993, Richards et al. used a noncomparative case-series design to describe similar results in 17 couples.^145,^ ^146^ Both emphasized the need for a wider approach to treating relationship issues after SCI, rather than emphasizing erectile function alone.

## General Results

Although a large body of literature exists regarding sexuality and SCI, some general observations should be made. First, the literature includes many reports of nonoriginal data or summaries of previously published work. Multiple review articles exist and sometimes new case-series data is added to previous work within a review article. Although we highlight such articles, we were unable to use this data in either our summary or pooled analysis since we could not determine the quality of the articles without complete information on the source of the data.

Second, most comparable data for treatment intervention is presented in case-series format. It is of course impossible to conduct RCTs for fertility interventions as clients are unlikely to subject themselves to invasive interventions in self-paying clinics on a random basis. It is also difficult to conduct RCTs for many of the previously invasive sexual dysfunction treatments such as injections and implants, since subjects are unlikely to inject unknown substances into their penises or undergo disfiguring surgery in a trial. Nevertheless, the quality of reporting of many of these case-series studies could have been improved with simple reporting of complete methodology, including how missing data is dealt with, reports on dropouts, follow-up efforts and consistent reporting on side effects.

Finally, the RCTs included in this report suffer due to inconsistent and often incomparable outcome measures preventing pooling of the relevant data. In addition, there is an unfortunate tendency for duplicate publication, whereby data from the same group of patients, but on different aspects of the same trial, is published multiple times in different journals, with the author list rearranged. This results in the false impression that more studies exist with an overall larger group of patients.

We will discuss the results relating to each of the questions posed by the consortium.

## Question 1. What is the Current Fertility Rate for Men and Women After SCI?

### Fertility in Females After SCI

There were no studies found that investigated this question.

### Fertility in Males After SCI

Ejaculation rates. Different aspects of male infertility have been studied. Reports in the literature on this topic can be grouped, and some information pooled. Much of the earlier work in this area centers around interventions to aid males with SCI to ejaculate, either during sexual activities with their partners or in a clinic situation to harvest semen for implantation. Different authors and clinics have chosen different methodologies to aid ejaculation in males with SCI. They include intrathecal or subcutaneous physostigmine with masturbation, penile vibration techniques with or without pharmacologic enhancement, or electroejaculation.

In 1992, Leduc et al.^69^ published the largest study to date of physostigmine in 37 patients with SCI. Side effects included ten episodes of autonomic dysreflexia, five episodes of nausea and vomiting, one episode of hallucination and one episode of dizziness. Patients required multiple medications to inhibit the side effects of physostigmine. Only antegrade ejaculation was counted and the success rate was 54%. The success rate of physostigmine was lower then that obtained with the other techniques described below, and physostigmine also demonstrated a significantly higher side-effect profile. This drug is now very difficult to obtain and this procedure should be considered for historical reference only.

The most common techniques used for semen harvesting include vibration or electrode ejaculation techniques. Many clinics do both procedures, starting with vibration and then going to electrode ejaculation if vibration is unsuccessful. We identified 22 case-series studies that used these techniques. These studies originated in the US, UK and Australia, encompassed a total of 806 patients, and spanned the time period from 1981 to 2002.^38–59^ These case-series studies ranged in quality from 2/19 to 12/19 (Summary Table 1). Fourteen percent of the above studies met 11 of 19 (58%) quality criteria.

We were able to pool ejaculation results from 22 of these case-series studies that used vibration and/or electrode stimulation in males with SCI (Figure 1). Overall, these interventions resulted in an overall ejaculation response rate of 86% (random effects pooled estimate: 0.86 95% C.I. 0.80, 0.93). It is worth noting that with the exception of the study by Chung et al.,^54^ studies published from 1997 onwards report response rates of 100%. When data from studies examining vibration and/or electrode stimulation to provoke ejaculation are pooled, a large degree of heterogeneity is observed. This observation reflects the inclusion of early studies that were aimed at establishing optimal parameters for the technique (e.g., vibration amplitude, electricity parameters), as well as the inclusion of more recent studies which implemented the now common practice of first starting with vibration and later including electroejaculation to increase success rates.

Figure 1. Meta-Analysis—Ejaculation

Forest plot of the success rate of vibration and/or electrode stimulation in noncomparative case-series studies that reported ejaculation as an outcome. The data was pooled and the overall estimate and its confidence interval was calculated using the random effects estimator of Laird & Mosteller.^36^ Quality scores are out of a possible 19. Estimates from studies prior to 1993 are denoted by open circles. Only results from the past 10 years (1993-2003) were pooled to account for changes in techniques and technology.

Reports of other techniques used to harvest semen from males with SCI were identified (Summary Table 1) and include: electrical stimulation of the seminal vesicles and vas deferens;^84^ vas cannulation with implanted sperm reservoirs;^85^ testicular biopsy;^86,^ ^87^ and microsurgical aspiration of the vas deferens.^88^

Pregnancies and live births. Not all authors chose to present both pregnancy and live birth data. However, there is no suggestion in the literature that the spontaneous abortion rate of a pregnancy conceived from an SCI male exceeds that of the general population; therefore, we chose to combine both sets of data. These results represent the number of couples who have achieved at least one pregnancy or live birth over the number of couples who tried to conceive. It is very important to note that some authors reported their fertility rates after very simple procedures such as vibration or electrode ejaculation, whereas some studies were performed in clinics that greatly increased the odds of achieving pregnancy by adding a variety of advanced fertility techniques.

Seventeen studies published between 1987 to 2001, involving a total of 400 patients from the US, UK and Australia, have documented pregnancy rates.^41,^ ^44,^ ^44,^ ^48,^ ^48,^ ^50,^ ^51,^ ^51,^ ^52,^ ^52–54,^ ^54,^ ^55,^ ^55,^ ^57–59,^ ^59,^ ^69,^ ^69–71,^ ^71,^ ^72,^ ^72–74,^ ^147^ Thirteen studies published between 1991 to 2001, involving a total of 341 patients from Canada, US, UK and Australia, have documented live-birth rates.^70^ Eleven of these studies overlap and report both pregnancy and live-birth rates.^44,^ ^48,^ ^51,^ ^52,^ ^54,^ ^55,^ ^59,^ ^69–72^

Data from the 17 studies documenting pregnancy rates were pooled and indicate pregnancy rates of 51% (random effects pooled estimate: 0.51 95% C.I. 0.42, 0.60) (Figure 2). The data suggest considerable improvement in pregnancy rates, from the dismal 0% reported by Halstead in 1987^41^ to the more recently reported rates of 74%^57^ and 73%.^58^ The quality of these studies ranges from 5/19 to 12/19 (Summary Table 3). Twenty percent of the pregnancy studies met 11 of 19 (58%) quality criteria. Data from the 13 studies documenting live-birth rates were pooled and indicate live birth rates of 40% (random effects pooled estimate: 0.40 [95% C.I. 0.33, 0.48]) (Figure 3). The heterogeneity of these pooled results is explained by the addition of advanced fertility techniques that increase the success rates for these endeavors by up to four times, compared with insemination alone. Once again, an improvement in live birth rates over time has occurred with Lucas reporting a success rate of fourteen percent in 1991 and Elliot of sixty-two percent five years later. The quality of these studies ranges from 5/19 to 12/19 (Summary Table 4). Eight percent of the live birth studies met 11 of 19 (58%) quality criteria.

Figure 2. Meta-Analysis—Pregnancy

Forest plot of the success rate for pregnancy in the noncomparative case-series studies that reported pregnancy as an outcome. The data was pooled and the overall estimate and its confidence interval was calculated using the random effects estimator of Laird & Mosteller.^36^ Quality scores are out of a possible 19. Estimates from studies prior to 1993 are denoted by open circles. Only results from the past 10 years (1993-2003) were pooled to account for changes in techniques and technology.

Figure 3. Meta-Analysis—Live Birth

Forest plot of the success rate of live birth in noncomparative case-series studies that reported live birth as an outcome. The data was pooled and the overall estimate and its confidence interval was calculated using the random effects estimator of Laird & Mosteller.^36^ Quality scores are out of a possible 19. Estimates from studies prior to 1993 are denoted by open circles. Only results from the past 10 years (1993-2003) were pooled to account for changes in techniques and technology.

### Are Fertility Rates Changed After Freezing a New Patient's Sperm?

Only one study indirectly addressed this question (Summary Table 2). In 1994, Padron et al.^148^ evaluated the effect of cryopreservation on the quality of sperm in SCI males, and determined that semen obtained from SCI males freezes as reliably as semen obtained from “controls.” However, for both groups, when the optimal method of vapor freezing was used there was still a reduction in sperm motility of approximately 65%. This reduction in motility would obviously be more significant for the SCI group, a group that already has reduced sperm motility as a characteristic of its semen quality.

### Are There Better Fertility Rates Using Electroejaculation or Vibration? Does Order of Method Influence Outcome?

We identified four trials that directly compared vibration and electroejaculation for inducing ejaculation in SCI males.^60–62,^ ^149^ In a controlled clinical trial published in 1997, Brackett et al.^61^ collected semen using vibration and/or electroejaculation from 77 males with SCI. Although total semen volume and sperm counts were similar, the percent motile sperm and percent sperm with rapid linear motion were significantly higher in the vibration-induced samples. This was observed for the vibration compared to electroejaculation groups, as well as within the ten patients who had both procedures performed. This study was a non-RCT and therefore could not be quality assessed using the Jadad scale.

In the same year, Ohl et al.^60^ published results from an RCT that used both vibration and electroejaculation in a random fashion to obtain ejaculate from 11 males with SCI. They found that the antegrade specimen of the vibration-induced ejaculate had a higher quality (i.e., more motility) than the electroejaculate-induced antegrade specimens, however, the electroejaculated group had a higher retrograde volume, evening out the total motile sperm count (greater total volume in electroejaculated samples, better quality in vibration induced samples). The authors reported that the electroejaculate group experienced more pain, and all patients preferred the vibration procedure. This study received a quality score of 2/5 on the Jadad scale.

In 1998, Le Chapelain^150^ analysed semen samples from 39 male SCI subjects and described improved semen quality with vibration-induced ejaculation compared with either electroejaculation or physostigmine.

Finally, Park et al.^62^ reported an abstract in 1999 that used a case-control design to examine both electroejaculation and vibration in 17 males with SCI. Although sperm quality was superior using vibration, this technique was unsuccessfull for those with lesions at and below T10, requiring electroejaculation to be used with the lower lesions.

We were unable to locate any documents demonstrating a superior fertility outcome between vibration and electroejaculation. Therefore, we compared the side-effect profile of the two procedures to determine risk-benefit (Summary Table 3). Of the 21 studies identified that reported ejaculation rates with either technique (Figure 1), ten reported adverse events.^40–43,^ ^45,^ ^47,^ ^49,^ ^50,^ ^53,^ ^59^ Often, authors combined procedures, although they did not always separate the side effects by procedure. However, papers that combined the procedures demonstrated that the vibration technique is less likely to be successful for lower motor neuron (areflexic) injuries than with spastic injuries, and electroejaculation is more likely than vibration to cause autonomic dysreflexia in patients with spastic injuries.^41,^ ^43^ Electroejaculation also has the added side effects of inflammation to the rectal mucosa^47^ and stimulation pain^40,^ ^45,^ ^47,^ ^60^ in incompletely injured patients. Therefore, most clinics that combine these techniques usually try vibration first followed by electoejaculation in the areflexic subjects that tend to not respond to vibration alone. It is recognized that techniques of vibration and electroejaculation, as well as techniques for blocking episodes of autonomic dysreflexia have changed over time and therefore the relative risks of the two techniques may not be comparable as described in the papers examined.

### To Improve Fertility Rates, When Should Invasive Techniques Such as Testicular Biopsy or Intracytoplasmic Sperm Injection be Used?

Invasive techniques to enhance fertility (advanced fertility [AF] techniques) such as in vitro fertilization (IVF) and intracytoplasmic sperm injection (ICSI) have been used more in recent studies. By grouping the 18 studies above that reported either pregnancies or live births (Figures 2 and 3) according to whether they used or did not use AF techniques, one can assess how using AF techniques impacts fertility rates (Summary Table 4). In doing so, one easily observes that to achieve pregnancy and birth rates approaching 50% or greater SCI couples need to use an AF technique.

### Are There Pregnancy Complications and Prospective Obstetric Management Issues for SCI Females?

We did not find any reports that provided the necessary data for us to project the number and frequency of complications and other obstetric issues in females with SCI. There are numerous case reports, however, without the larger sample size obtained with a case-series study, it is difficult to conduct further research or inform practice or policy regarding this important health issue.

## Question 2. How has the Availability of Viagra® and Other Remediation Affected Sexual Dysfunction and Adjustment After SCI?

By far, the majority of articles regarding sexual dysfunction after SCI are either opinion pieces or review articles (Appendix C; List of Excluded Studies). The only RCTs that were identified examined Viagra® for the treatment of erectile dysfunction. However, we did identify multiple case-series studies that had similar outcome measures, allowing their data to be pooled.

### Interventions for Female Sexual Dysfunction

We found six articles that used a case-control design^6,^ ^100–104^ and one article that used a RCT design^105^ to examine the phenomena of sexual arousal in response to physical and cognitive stimulation in women with SCI (Summary Table 5).

The studies by Komisaruk et al.^103^ and Whipple et al.,^104^ appear to be separate reports on the same cohort of 16 women with SCI (n = 6 with upper SCI, n = 10 with lower SCI). In a case-control study published in 1997, Komisaruk and colleagues^103^ measured altered pain thresholds with genital stimulation in 16 SCI and five non-SCI females. The authors found that similar to their able-bodied counterparts, pain thresholds were increased with genital self-stimulation even in women with complete SCI. This finding led the authors to postulate that in the women with upper SCI, genitospinal visceral afferent pathways function (although unrecognized by the American Spinal Injury Association criteria) and/or there exists a functional genital afferent pathway that bypasses the spinal cord and projects directly to the brain. Whipple and colleagues^104^ studied the 16 SCI females in the laboratory during self-stimulation and reported that only those with lesions below T-10 experienced increases in blood pressure; no SCI subjects had alterations in heart rate. Three females with complete SCI experienced orgasm with genital self-stimulation.

Sipski has published four case-control studies examining this topic in the most detail.^6,^ ^100–102^ It is unknown, however, whether all of these patients represent new or restudied patients, although the outcome measures are different between the studies as the author is examining different phenomena. In 1996, Sipski et al.^102^ demonstrated that even in females with supposedly complete SCI (n = 10), manual genital stimulation increased their sexual arousal, although requiring a higher level of concentration than able-bodied controls (n = 10). In a later study, Sipski et al.^6^ demonstrated that with manual and audiovisual stimulation combined, greater than 50% of SCI women (n = 68) experienced orgasms that could not be differentiated from able-bodied controls (n = 21). Those with complete lower motor neuron dysfunction affecting S2–S5 had the lowest orgasm rate, and those with preservation of sensory function in dermatomes T11-L2 had greatest preservation of psychogenic-mediated sexual function. In another study, Sipski et al.^101^ found similar orgasm rates among SCI women, with higher orgasm rates observed among women stimulated with a vibrator and among women who reportedly had higher sexual drive and greater awareness of their anatomic sexual function. Finally, Sipski et al.^100^ demonstrated that women with complete SCI could respond with audiovisual stimulation in those physiologic functions that are controlled above the level of their injuries, whereas genital physiologic response could only be achieved by stimulation below the level of the injury. Overall, Sipski advocates using these data for behavioral counselling in SCI women, to help them achieve a higher level of sexual satisfaction by learning how their body works sexually after SCI.

The six case-control studies that addressed interventions for female sexual dysfunction all scored equal to, or above five on the NOS, with the highest score of seven obtained by Sipski et al.^102^

In addition, Sipski et al. performed a preliminary RCT study that evaluated Viagra® for sexual dysfunction in 19 women with SCI.^105^ The authors found a modest physiologic effect, and the results of this study launched a large multicenter trial. The RCT received a quality score of 2 on the Jadad scale (Summary Table 8).

### Male Sexual Dysfunction

Aside from a number of RCTs evaluating Viagra®, all of the studies that we identified which addressed this topic were case-series studies. The most common problems faced when trying to analyze this literature is that many authors chose different outcome measures. For example, some authors use a validated erectile grading system such as Schramek's, whereas others used their own grading system; some authors used all or parts of the IEFF sexual satisfaction rating scale, whereas others designed their own scales. When authors use either an on/off grading system or a common question on the IEFF, we have pooled the data when appropriate.

Behavioral interventions. We found only one study, a case-series study, that examined behavioral interventions.^132^ Courtois et al.^132^ demonstrated improvement in penile rigidity in ten SCI males before and after biofeedback followed by home perineal muscle training exercises. No measurements of sexual satisfaction were incorporated into the study. The quality score was 11/19.

Topical agents. An attractive alternative to either systemic medication or injected medication is the use of a topical vasoactive agent absorbed into the penis to stimulate erection in SCI males. We identified three noncomparative case-series studies^106–108^ and one placebo-controlled clinical trial^109^ that evaluated these agents (Summary Table 6). Sonsken et al.^108^ evaluated the effect of applying transcutaneous nitroglycerin to the penis in 17 males with SCI, and found that five had a complete (full rigidity) response, seven had a partial response, and five failed to respond to the treatment. Six participants experienced headache with the treatment but no other serious side effects developed. Beretta et al.^106^ performed a similar study using transcutaneous minoxidil in 15 males with SCI, and found that only four males had sufficient erection for vaginal penetration, while the others had an incomplete or no response. Only one patient reported experiencing headache. Kim and colleagues have studied both topical papaverine^109^ and topical prostaglandin E1^107^ in SCI males. Both agents appeared to be quite safe, with no symptoms reported and only a slight drop in blood pressure reported for the papaverine group. Kim et al.^107,^ ^109^ reported that cavernous artery diameter was significantly increased for both papaverine and prostaglandin E1 as assessed by color flow Doppler ultrasound, although only approximately a quarter of both groups sustained a clinical erection with the treatment and there are no reports of using the medication during sexual activity.

Intraurethral Alprosatadil. We identified two case-series studies that evaluated intraurethral Alprostadil (prostaglandin) in males with SCI (Summary Table 7). Bodner^133,^ ^151^ evaluated intraurethral Alprostadil in 15 males with SCI who had all responded to intracavernous injections of prostaglandin in the past, as measured by achieving a 5 out of 5 score on the Scrameks's erectile response grading system. Patients required the addition of a penile ring in order to prevent systemic hypotension. Only three achieved a grade 4 erection sufficient for intercourse, and all three patients were dissatisfied with the quality of the erection and did not continue to use the medication at home. Waldbaum^134^ found similar results, and once again noted that the penile ring was necessary to prevent systemic hypotension.

Intracavernous injections. Intracavernous (penile) injections of vasoactive substances have reported to treat SCI male impotence in the literature for several decades. Injected substances include papaverine, phentolamine, prostaglandin E1, or combinations of two or three of the above. Many clinics use combination therapy (papaverine, phentolamine, prostaglandin E1) for economic reasons, and there is no clear difference in efficacy between these substances.

Using “satisfactory erection” as a common outcome measure we were able to pool data from eight noncomparative case-series studies performed from 1987 to 1999, and involving a total of 263 patients (Figure 4).^110–117^ These studies took place in the US, Australia, Italy, India, China and France. Overall these interventions resulted in a 90% satisfactory erection response rate (random effects pooled estimate: 0.90 [95% C.I. 0.83, 0.97]). One notes the very high success rates for these injections in males with SCI alone as a cause for their erectile dysfunction.

Figure 4. Meta-Analysis—Intracavernous Injections

Forest plot of the success rate of intracavernous injections in noncomparative case-series studies that reported satisfactory erections as an outcome. The data was pooled and the overall estimate and its confidence interval was calculated using the random effects estimator of Laird & Mosteller.^36^ Quality scores are out of a possible 19.

The studies by Zaslau et al.^115^ and by Sidi et al.^116^ were performed in individuals with SCI and either hypertension or diabetes. These studies found that the combination of SCI and another comorbidity decreases the efficacy of the injections.

The quality of these studies ranged from 6/19 to 13/19. Thirty-eight percent of the intracavernous injection studies met 11 of 19 (58%) quality criteria, with the highest score obtained by Sidi et al.^116^

Vacuum tumescence devices. We found only two case-series studies that examined external vacuum pump devices for erectile dysfunction in males with SCI.^135,^ ^136^

In 1989, Zasler et al.^135^ studied a novel vacuum pump system (Synergist) that uses a silicon sheath in 20 males with SCI, and reported that patient and partner assessments of the device efficacy and sex-life satisfaction with the device were very good to excellent. Although the device was required to stay on during intercourse, all patients in the study had complete SCI and therefore diminished sensation was not an issue. However, the silicon sheath did provide some protection for the partner. No side effects were reported. This report received a 13/19 quality assessment score. It is not known whether this device is still marketed.

In 1992, Heller et al.^136^ studied two similar commercially available vacuum-pump systems in 30 males with SCI. All 30 subjects were trained on how to use the device in the clinic, and then 17 opted to purchase the device and use it at home. All 17 couples were satisfied with using the device during sexual activity. Some patients experienced transient testicle swelling (n = 3) and some experienced transient petechial hemorrhages (n = 5), although all of these side effects were resolved within 1 hour of use. This report received a quality assessment score of 8/19.

Penile implants. Now considered as one of the oldest treatments for erectile dysfunction, penile implants have been used in SCI males for decades, although with decreasing frequency. While this topic has been frequently discussed in opinion pieces, we found only five case-series studies that examined penile implants for either erectile dysfunction or erectile dysfunction plus urinary incontinence (Summary Table 8).^118–122^ These case-series studies took place in the US, Germany and Japan, and involved a total of over 360 SCI males. A variety of different prostheses were used including inflatable, semirigid, semiflexible and flexible devices. Complications included infections, extrusions of the devices, perforations, pain, and mechanical device failure. The quality scores for these studies ranged from 5/19 to 7/19.

Sacral stimulators. Sacral stimulators have been championed by Brindley and others as a method of achieving continence with low voiding pressures in patients with complete SCI In general, the procedure is reserved for complete injuries since it necessitates a sacral rhizotomy with loss of a reflex erection, reflex voiding, or defecation; Brindley describes the stimulator as a way of voluntarily controlling these functions. We identified a single case-series study^137^ that reported erection rates in SCI males treated with sacral stimulators for bladder control. van der Aa et al.^137–152^ reported that 29 of 33 subjects with implants could achieve a full sustainable erection by stimulating the S2 or S3 anterior routes. The report of this case-series study did not, however, state how the stimulator-induced erection impacted sexual function, or if there were side effects such as bladder or bowel incontinence during sexual activity. The study by van der Aa et al.^137^ received a 5/19 quality assessment score.

Viagra® (sildafenil), RCTs. Although we originally identified nine reports of RCTs that examined Viagra® in males with SCI,^123,^ ^124,^ ^138–141,^ ^153–155^ careful analysis revealed that only two of these reports were separate trials;^123,^ ^124^ the remaining studies were repeat reports in separate journals. Data from these trials come from the UK, France and Australia., and involve a total of 205 male subjects with SCI (Summary Table 9). Different types of randomized trial designs, such as crossover and parallel, and different outcome measures were used in these studies, and the results were not poolable for meta-analysis. Both of these studies received a quality rating of 3/5 on the Jadad scale.

Viagra (sildafenil), case series. Many of the case-series studies also used a variety of outcome measures, however, we were able to identify seven studies that assessed the subject's report of the drug improving erectile function for sexual intercourse when the drug was used at home.^125–131^ These studies took place from 1999 to 2001 in the US, Germany, Spain, Switzerland and Japan. Overall, Viagra® resulted in a 79% successful erectile function (random effects pooled estimate: 0.79 [95% C.I. 0.68, 0.90]) (Figure 4). The analysis of these noncomparative case-series studies shows a high level of heterogeneity which is best explained by the subjective assessment of the outcome measure, with no standardized questionnaires being used across studies, and the fact that measurements were not obtained in the clinic, but rather secondhand from the patients “personal experience.” For the studies where quality could be assessed (i.e. full reports), the quality ranged from 9/19 to 16/19. The Gans et al. study,^125^ which met 16 of 19 (84%) quality criteria, was the only study identified by this systematic review to achieve such a high rating.

Figure 5. Meta-Analysis—Viagra®

Forest plot of the use of Viagra® in noncomparative case-series studies that reported improved erectile function as an outcome. The data was pooled and the overall estimate and its confidence interval was calculated using the random effects estimator of Laird & Mosteller.^36^

### Is Viagra Really More Benign Than Intracavernous Injections?

Intracavernous injections have a significantly higher efficacy than Viagra® (90% versus 79%). To compare the side-effect profile of intracavernous injections with that of Viagra®, we extracted data from the studies described above that reported side effects. Ten studies from the US, Europe and Japan conducted from 1998 to 2002 and including a total of over 600 patients reported that the most common side effects observed with Viagra® were short-lived, and included headache, flushing and infrequent dizziness (Summary Table 10).^123,^ ^126–128,^ ^130,^ ^131,^ ^138–141^ Note that all of these studies excluded patients on nitrate medications and that there were no reported sudden deaths. With regards to intracavernal injections, eight studies carried out from 1986 to 1999 in the US, Australia, Italy, India, China and France and studying a total of 263 patients reported transient local side effects, such as pain and swelling at the injection site.^112–117,^ ^142,^ ^143^ The most serious was priapism (prolonged erection), which can be avoided by doing doseage adjustments in the clinic with a reliable subject.

### How Does the Morbidity of Prostaglandin Injections Compare With the Older, Less Expensive Papaverine or Phentolamine

Although similar in efficacy, prostaglandin E1 is less stable at room temperature and much more expensive than papaverine or phentolamine. Proponents cite a shorter half-life (less chance of priapism) and less injection-site pain and scarring as reasons to use this substance despite its expense. We identified six noncomparative case-series studies^112,^ ^113,^ ^115–117,^ ^142^ and one RCT^143^ that reported the numbers of side effects, and the adverse reactions are listed in Summary Table 11. The quality of the case-series studies ranged from 5/19 to 13/19. Thirty-three percent of the papaverine/prostaglandin intracavernous injection studies met 11 of 19 (58%) quality criteria. The RCT of Renganathan et al.^143^ received a Jadad score of 0/5.

### What is the Morbidity of Vacuum Tumescence Devices?

As described above in the two identified reports of studies of vacuum tumescence devices,^135,^ ^136^ when used with proper clinic instruction and according to the specifications of the manufacturers, these devices have a very low morbidity rate with no irreversible morbidity's noted. Although there are case reports of penile ischemia in the literature, these case reports serve only as a warning not to leave the device on too long and cannot help us with ascertaining a complication rate.

In a comparative cases series, Chancellor et al.^156^ compared vacuum-pump devices with papaverine injections in 18 males with SCI. The injections and pumps were equally effective and neither group suffered any complications during the study. After trying both treatments, seven patients chose to remain with the pump and another seven chose the injections. A third arm of this study used topical minoxidil, but unfortunately no patients achieved satisfactory results with this treatment.

### What Indications, if Any, Remain for Implantable Penile Prosthetic Devices?

See Summary Table 8 for the results of the five case-series studies that evaluated penile implants in patients with SCI. It is notable that although penile implants result in a high level of satisfaction for those clients who do not have complications, the serious complication rate is as high as 10%. Furthermore, patients who have an implant removed are no longer candidates for other treatment options as they are likely to have damage to the penile tissues that would make them nonresponsive to intracavernous injections or vacuum devices. These devices are, however, useful to assist those who need them for external application of condom drainage systems. They also could be used in patients who failed to respond to oral or injectable medications and vacuum devices, or those who find these alternatives unacceptable.