# Introduction

## Overview

Spinal cord injury (SCI) is most often the result of a trauma to the spinal cord, but can also be associated with congenital or degenerative disease. In the United States alone, there are currently approximately a quarter million people with SCI.^1^ Every year, there are approximately 10,000 people in the U.S. who survive an acute traumatic injury to the spinal cord, the majority of whom are male and under the age of 25.^2^ Persons with SCI experience a myriad of acute and long-term physical and psychosocial consequences that impact on their quality of life. In addition to paralysis, persons with SCI will likely experience problems with bladder and bowel control, as well as alterations in sexual functioning.^1,^ ^3–5^

The impact of a SCI on sexual functioning depends on the degree of the injury and its location on the spinal cord.^6,^ ^7^ Sexual dysfunction in persons with SCI may have both physiological and psychological (e.g., body image, self esteem) elements that can be distressing regardless of the persons' gender, age or culture. The balance between physiologic and psychosocial elements coupled with factors such as gender, age and culture will all influence how a person with SCI adjusts to their new sexual identity.

Both men and women report a decreased desire for sexual activity following their injury.^8,^ ^9^ Frequency of sexual activity is also known to decrease after injury in both men and women.^8,^ ^9^ In men with SCI, factors affecting sexuality typically include erectile and ejaculatory dysfunction.^10–12^ Factors affecting women with SCI may include difficulties having comfortable intercourse, and the ability to reach or feel orgasm.^6,^ ^13,^ ^14^ Many authors and clinicians include issues of infertility, pregnancy and delivery when speaking of broader issues of sexuality and disability.

Although some men with SCI are unable to have erections, many still maintain the ability to have some erectile function, albeit of insufficient quality and duration for intercourse.^15^ Many techniques currently exist to remediate erectile dysfunction in men with SCI. These include devices such as the vacuum erection device as well as the injection of vasoactive drugs into the penis.^16,^ ^17^ A recent innovation to improve erectile function in men with SCI has been the approval of the drugs such as sildenafil (Viagra®).

Remediation of sexual dysfunction in women with SCI has until recently been largely unreported. However, it has been suggested that treatment of sexual dysfunction in women should focus on improving the ability of women with SCI to become aroused and to achieve orgasm.^3^

The ability to become a parent is an important issue for younger people with SCI. For women with SCI, their hormonal status generally remains unchanged, except for a temporary period of amenorrhea following their injury.^18,^ ^19^ They can usually carry a child safely to term and may be able to deliver a child naturally depending on the medical status and physical limitations to do with the abdomen, spine or pelvis.^19^ However, infertility is an issue for men with SCI.^15,^ ^20,^ ^21^ Infertility results from the combination of ejaculatory dysfunction and abnormal sperm quantity and quality. Techniques to remediate erectile dysfunction and ejaculation have vastly improved the fertility potential of men with SCI.^22–26^ Stimulation to obtain ejaculate for insemination of a partner is now routinely performed. Usually, ejaculate is obtained through the use of penile vibratory stimulation or electroejaculation, but other techniques to treat SCI-related male infertility are myriad.

Health care providers have become increasingly aware of the importance of sexuality in the rehabilitation process.^25,^ ^26^ Current approaches to “best practices” concerning the topic of sexuality and reproductive health in persons with SCI are opinion-based, typically generated by clinical experience with small patient populations in select hospitals and rehabilitation facilities. The Consortium for Spinal Cord Medicine (sponsored by the Paralyzed Veterans of America) has identified the issue of sexuality and reproductive health to be a high priority topic for improving the quality of life for persons with SCI.

## Phase 1 Feasibility Study

Last year, at the request of the Consortium for Spinal Cord Medicine, the Agency for Healthcare Research and Quality (AHRQ) commissioned the University of Ottawa's evidence-based practice center to conduct a feasibility study to determine if there is sufficient credible literature to support a comprehensive systematic review on the topic of “Sexuality and Reproductive Health Following SCI.”

The Consortium for Spinal Cord Medicine drafted eight specific questions that address the key issues on the topic of sexuality and reproductive health in persons with SCI (Table 1). We developed a search strategy based on these questions to examine the existing evidence base regarding the topic of “Sexuality and Reproductive Health Following SCI.” We anticipated that there may be specific gaps in the literature, with data absent or scant for some of the questions.

Table 1. Key issues on the topic of sexuality and reproductive health in persons with SCI as identified by the Consortium for Spinal Cord Medicine

1. | When do people become sexually active after SCI?
2. | What is the frequency of sexual activity in the years post injury?
3. | What is the current fertility rate for men and women after SCI?
4. | How has the availability of Viagra^®^ and/or other remediation affected sexual function, frequency of activity, and adjustment after SCI?
5. | What are the unique issues of sexuality for women after SCI?
6. | Are there interventions shown to improve sexual responsiveness in women with SCI?
7. | What is the optimal sequencing of effective procedures when pursuing fertility in the SCI male?
8. | When is the most effective time to present information on sexuality after SCI?

In addressing the original question regarding the feasibility of a comprehensive systematic review of sexuality and fertility in SCI, we conclude that such a review is feasible on the whole, but only useful in the specific. That is, some of the questions have enough evidence from which a review could generate useful recommendations, however, other topics would not be answerable given the current state of the literature.

### Summary of Findings—Existing Evidence Base

What is the current fertility rate for men and women after SCI? We concluded that there is a sufficient body of literature to complete a comprehensive systematic review and meta-analysis on issues relating to fertility/pregnancy rates/live births in persons with SCI. Although most of these studies only report frequency data and/or percentage of “success,” they report sufficient data to provide meaningful information. Along this suggestion we believe there is sufficient usable data to permit a systematic review and possibly a meta-analysis for other topics such as pregnancy complications and prospective obstetric management.

How has the availability of Viagra® and/or other remediation affected sexual function, frequency of activity, and adjustment after SCI? We concluded that a systematic review and meta-analysis could be carried out specifically addressing treatments available for treating impotence in males with SCI. The permits of such an undertaking would need to be considered in light of the possible duplication of reports we identified. As such, and if not corrected, the estimates from such a meta-analysis could lead to biased estimates of the intervention's effectiveness.

What are the unique issues of sexuality for women after SCI? There is a new and growing body of literature addressing sexual issues in females with SCI. Many of these studies are relatively well designed qualitative interviews and surveys, often involving significant numbers of patients. The literature does address the unique issues of sexuality in women. We did not believe that a systematic review addressing this question would provide additional insights to clinicians and others.

Are there interventions shown to improve sexual responsiveness in women with SCI? There are as of yet few published trials of interventions to improve sexual responsiveness in women after SCI. We did not believe that a systematic review on this topic would provide meaningful information.

What is the optimal sequencing of effective procedures when pursuing fertility in the SCI male? This question is not well addressed in the current literature, except to say that with increasing options available the situation is improving. The literature widely accepts that fertility is not substantially altered in women after SCI. Furthermore, in males, fertility rates can only be deduced in those who choose to be fertile, and will vary according to the degree of pursuit of invasive procedures. However, there is a reasonable body of studies regarding the success rates of individual techniques and a systematic review would help guide clinicians in choosing the order of techniques to apply based on cost, success and potential side effects.

When do people become sexually active after SCI?, What is the frequency of sexual activity in the years post injury?, and When is the most effective time to present information on sexuality after SCI? We found almost no useful literature addressing these questions, although well structured interviews with rigorous attention to qualitative design could answer all three of these questions, i.e., when do patients become active, how active do they become, and when do they want information. Unfortunately, the literature regarding these questions is largely based on the expression of the clinician, rather than the opinion of the patient. Therefore, we concluded that a systematic review would not be useful.

### Conclusions

In summary, we identified a reasonably large body of evidence examining different aspects of sexuality and reproductive health following SCI. In general, these studies are of a lower level of evidence and open to several sources of bias. On the basis of this report, AHRQ requested a comprehensive evidence report that incorporates and builds on findings from the Ottawa EPC Phase I Feasibility Study.

Obviously, not all sexual health questions could be addressed in a systematic review of the literature. There are many other noteworthy questions, including questions on impact of quality of life on sexual health, the differences in practice from specialized to general centers, and many questions regarding quality of life and women's sexual health. These questions are not addressed in sufficient thoroughness in the literature to warrant a systematic review. Also, systematic reviews of qualitative literature likely would not add any new insights to this field of practice. This was discussed somewhat in the feasibility study mentioned earlier. The Consortium of Spinal Cord Medicine helped focus this review by posing a series of questions for a systematic review, based on their clinical experience and on the results of the Phase 1 Feasibility Study.