# Appendix F. Additional Acknowledgments

The UO-EPC gratefully acknowledges the following individuals who served on our Technical Expert Panel (TEP). Acknowledgment does not reflect endorsement of this report.

- David Chen, MD
- Assistant Professor of Physical Medicine and Rehabilitation,
- Department of Physical Medicine and Rehabilitation,
- Northwestern University Medical School; & Spinal Cord Injury Program,
- Rehabilitation Institute of Chicago,
- Chicago, IL

- Stanley H. Ducharme, PhD
- Senior Consultant, Private Practice in Clinical/Health Psychology,
- Boston University Medical Center,
- Boston, MA

- Stacy L. Elliott, MD
- Clinical Professor, Department of Psychiatry;
- Associate Member, Division of Urology,
- Department of Surgery, Faculty of Medicine
- University of British Columbia
- Vancouver, BC

- Arthur Leader, MD
- Professor of Obstetrics, Gynaecology & Medicine Chief, Division of Reproductive Medicine
- University of Ottawa
- Ottawa, ON

- Todd A. Linsenmeyer, MD
- Director of Urology
- Kessler Institute for Rehabilitation;
- Associate Professor, Physical Medicine and Rehabilitation & Surgery (Division of Urology)
- UMDNJ-New Jersey Medical School,
- Newark, NJ

- Shawn Marshall, MD
- Assistant Professor,
- Department of Medicine,
- University of Ottawa
- Ottawa, ON

The UO-EPC gratefully acknowledges the following individuals who reviewed the initial draft of this evidence report, and provided constructive feedback. Acknowledgement does not reflect endorsement of this report.

- David Atkins, MD, MPH
- Chief Medical Officer
- Center for Outcomes and Evidence
- Agency for Healthcare Research Quality
- Rockville, MD

- Nancy Brackett, PhD, HCLD
- Research Assistant Professor of Neurological Surgery & Urology
- University of Miami School of Medicine
- Miami, FL

- Gerald Brock, MD, FRCS
- Associate Professor,
- Department of Surgery, Division of Urology
- St. Joseph's Health Centre
- London, ON

- Anthony S. Burns, MD
- Assistant Professor
- Department of Rehabilitation Medicine
- Thomas Jefferson University
- Philadelphia, PA

- Peter N. Kolettis, MD
- Associate Professor, Division of Urology
- The University of Alabama (Birmingham)
- Birmingham, AL