# Appendix E. Evidence Tables

Evidence Table 1. Non-comparative case series studies of fertility rates in pts with spinal cord injury

Author, Year, Location | Study Characteristics | Study Design & Duration/Eligibility Criteria/ Quality Assessment | Intervention (e.g.,Pharmacological/Device/Behavioural/Surgical/other) | Outcomes/Follow-up | Adverse Events/Complications
Bensman 1966, US | • Enrolled/ evaluated: N=5/N=5 | • Study Design: NCS | • Pharmacologic: NR | • Outcomes: | • A/E:
(Ref ID 1627) | • % males: 100% | • Duration: NR | • Device: Electrostimulator(n=5) | • Seminal Parameters: sperm obtained in 3/5 pts; 1^st^ pt SpC 410K sperm/ cm4 and 20–30% of sperm abnormal forms; 2nd pt SpC 1.3 mln sperm/ cm4, all non-motile; 3rd pt 14K sperm/cm4 obtained | • Local: discomfort around area of electrode; sensation of voiding (n=3); bladder contraction (n=5)
| • Race/ethnicity: NR | • Eligibility Criteria: | • Amplitude: sin current of 20–30 mA | • EJ Rates: 0/5 AG; 3/5 RG | • Systemic: headache, rise in BP in 4/5
| • Age: 24.2 (21–32) y | • Inclusion: NR | • Frequency: 2–10 cycle/m | • Follow-up: NR
| • Level of Injury: C4–L2 | • Exclusion: NR | • Mode/Admin. Route: rectal probe; duration of ES maintained for 5–10 m
| • ASIA Level: NR | • Quality Assessment: 4/19 (+) reported | • Other Device: NR
| • Duration since injury: (0.5–13) y | | • Surgical: NR
| • Previous fertility: NR | | • Procedure: NR
| • Drop-outs: n=0 | | • Bladder catheterization
| • Lost in follow-up: n=0 | | • -with/without alkalinization: not performed, urine acidic in all cases post ES
| • Number of sites: 1 | | • Epidydimal aspiration (MESA/PESA): NR
| • Funding: NR | | • Testicular biopsy: NR
| | | • Behavioural: NR
| | | • Laboratory techniques: NR
Beretta, 1989, Italy | • Enrolled/evaluated: n=102/n=102 | • Study Design: NCS | • Pharmacologic: NR | • Outcomes: | • A/E:
(Ref ID 695) | • % males: 100% | • Duration: 3 mo | • Device: vibrator Le Vibrion | • Measures of Fertility Rates: | • Local: NR
| • Race/ethnicity: NR | • Eligibility Criteria: | • Amplitude: NR | • Seminal Parameters: S increase in sperm concentration over 3 mo (p< 0.05) with no correlation to increase in vol. S decrease in abnormal sperm (% of motility and morphology P<0.01), S increase in sperm concentration (p<0.05), no increase in volume. S increase in motility (p<0.01) | • Systemic: 2 reports of headache, 2 reports of increased BP
| • Age: 25.6 (NR) y | • Inclusion: No secondary neurological sequelae, empty & not irritated rectum & bladder; (-) urine cultures; T12, L1 & L2 myelomeres must be intact | • Frequency: 100 VS/ sec | • EJ Rates: Total EJs =78, AG = 68, RG = 20
| • Level of Injury: (n=17) Cervical 7 complete, 10 Incomplete; (n=41) T1–T10 (22 complete, 19 Incomplete); (n=21) T11-L1; (n=15) L2–L5 3 complete, 12 Incomplete; (n=8) Sacral, 3 complete, 5 incomplete | • Exclusion: NR | • Mode/Admin. Route: applied to penile surface for 10 m, some pts used vibrator at home | • Pregnancy rates: (n=3)
| • ASIA Level: NR | • Quality Assessment: 11/19 (+) reported | • Surgical: (n=6) couples: | • Follow-up: (n=15)
| • Duration since injury: 6.1 y | | • Penile Implants | • Length: weekly follow-ups
| • Previous fertility: NR | | • Procedural: NR | • Duration: NR
| • Dropouts: n=0 | | • Behavioural: NR | • Results: abnormal spermatozoa steeple decreased over 3 m
| • Lost in follow-up: NR | | • Laboratory techniques (n=6): AHI
| • N of sites: 1 | | • If sperm quality good, female partners underwent fertility investigations, prolactin & progesterone assays in 2nd phase of menstrual cycle & cervical score determination. Homologous intracervical insemination performed during ovulation.
| • Funding: NR | | • Intrauterine insemination: NR
| | | • IVF: NR
| | | • Intracytoplasmic sperm injection: NR
| | | • Embryo cryopreservation: NR
| | | • Sperm cryopreservation: NR
| | | - ejaculated
| | | -biopsy
Beretta, 1987, Italy | • Enrolled/ evaluated: n=142/n=142 | • Study Design: NCS | • Pharmacologic: NR | • Outcomes: | • A/E: NR
(Ref ID 984) | • % males: 100% | • Duration: NR | • Device: Vibrator (n=142) | • EJ Rates: 99/142(69.7%)
| • Race/ethnicity: NR | • Eligibility Criteria: | • Amplitude: 30 Watts; 220 V | • Pregnancy rates: 4/21(19%)
| • Age: 26.1 (NR) y | • Inclusion: no secondary neurology sequelae; empty & non-irritated rectum & bladder; negative urine cultures; no lesions of D12, L1, L2 | • Frequency: 100Hz | • Follow-up: (n=2)
| • Level of Injury: n=79 > T11; n=48 thoraco-lumbar; n=15 sacral; n=59 complete & 83 incomplete | • Exclusion: NR | • Mode/Admin. Route: VS applied to penile surface for 10 m, wkly for 3 m | • Length: NR
| • ASIA Level: NR | • Quality Assessment: 5/19 (+) reported | • Other Device: NR | • Duration: 3 m
| • Duration since injury: mean 5.9 y | | • Surgical: NR | • Results: before /after tx (wkly VS) study of seminal parameters in 2 pts: S increase in sperm concentration(p<0.05); no Δ in semen volume; S decrease in abnormal spermatozoa (p<0.05); S (+) increase in motility & morphologic features over 3 m (p<0.01)
| • Previous fertility: NR | | • Procedure: NR
| • Drop-outs: NR | | • Behavioural: NR
| • Lost to follow-up: NR | | • Laboratory techniques (n=21):
| • Number of sites: 1 | | • Donor sperm insemination: NR
| • Funding: NR | | • Sperm preparation: NR
| | | • Intrauterine insemination: NR
| | | • IVF: in 3/4 which resulted in pregnancy/ 1/4 used auto-insemination
| | | • Intracytoplasmic sperm injection: NR
| | | • Embryo cryopreservation: NR
| | | • Sperm cryopreservation: NR
Brackett, 1995, US | • Enrolled/ evaluated: 23 SCI couples; 2 other couples 1 MS, 1 transverse myilitis/ n=23 couples | • Study Design: NCS | • Pharmacologic: NR | • Outcomes: | • A/E: NR
(Ref ID 572) | • % males: 50% of couples | • Duration: May 1991-Sep 1994, retrospective study | • Device: Oster Model 129-01A (n = 4) | • Measures of Fertility Rates: 13/22 conceptions
| • Race/ethnicity: NR | • Eligibility Criteria: | • Amplitude: NR | • Seminal Parameters: normal sperm concentration (136± 32 mln/cc) but poor SpMot (12.6± 1.1%); SpMor within normal levels (50.2± 6.9%); all measures lower in RG vs. AG; NS dfs in sperm parameters of SCI vs. 2 other pts
| • Age: SCI men 35.2±1.1; 26–42 y; female pts, 24–42 y, | • Inclusion: NR | • Frequency: NR | • Cycle Function: 21/23 females had 52 clomiphene citrate tx, 4 of them had 8 cycles of ovulation induction using hMG and /or FSH.
| • Level of Injury: cervical in 7; thoracic in 12; lumbar in 2 | • Exclusion: NR | • Mode/Admin. Route: mean time of stimulating frenulum until EJ, 2.5±0.7 m | • Pregnancy rates: 71% in IVF; 27% in IUI; total 11/22
| • ASIA Level: NR | • Quality Assessment: 10/19 (+) reported | • Other Device (n = 19): Electrostimulator/ | • Miscarriage/ectopic: 1 case, medically treated
| • Duration since injury: 13.1 (5–28) y | | • Amplitude/voltage: 1 to max of 8V | • Induced abortion: 2 spontaneous abortions in pt with 3 pregnancies
| • Previous fertility: NR | | • Mode/Admin: anesthesia/ general anesthesia in 5 (4/5 SCI pts) | • Live Births: 8/23
| • Drop-outs: n=0 | | • Surgical: NR | • Singletons: 8/23
| • Lost to follow-up: n=0 | | • Procedure (n=23): | • Follow-up: NR
| • Number of sites: 1 | | • Bladder catheterization
| • Funding: Partially supported by NLB from the Miami Project to Cure Paralysis | | • -with/without alkalinization: sodium bicarbonate (20 g /6 hrs for 72 hrs) pre VS /ES
| | | • Epidydimal aspiration (MESA/PESA): NR
| | | • Testicular biopsy: NR
| | | • Behavioural: NR
| | | • Laboratory techniques (in 23 SCI couples):
| | | • Donor sperm insemination: NR
| | | • Sperm preparation: by all techniques in n=22-swim-up
| | | • Intrauterine insemination: 60 cycles of IUI in 22 couples with clomiplene Citrate (50–100 mg/d, orally for 5 ds)/ gondotropins (hMZG &/or FSH, 75–225IU/d, i.m.)
| | | • IVF/GIFT: IVF-ET in n=6 with embryo transfer @ 48 hr post retrieval; GIFT in n=4 with laparascopic gamete transfer
| | | • Intracytoplasmic sperm injection: NR
| | | • Embryo cryopreservation: NR
Brackett, 1997, US | • Enrolled/ evaluated: n=77/ n=77 | • Study Design: NCS | • Pharmacologic: NR | • Outcomes: | • A/E: NR
(Ref ID 308) | • % males: 100% | • Duration: NR | • Device: Sunbeam Model 1850–1 Vibrator | • Seminal Parameters: no Δ in SpC of vs. ES (155.0± 41.9 mln vs. 191.3± 50.0mln); in AG, S greater SpC with vs. ES (141.7± 24.4 mln vs. 89.9 ± 11.6 mln); in RG mean SpC greater in ES vs. VS (95.4± 9.1 vs. 38.1±6.3); mean percent motile sperm greater in vs. ES (18.5±2.5 vs. 10.1± 1.5%); mean % of sperm with rapid linear motion in VS S > vs. in ES in total ejaculate (12.8±2.1 vs. 5.7± 1.0%) & RG fraction (13.6± 1.3 vs. 6.2± 0.7%); within pt comparisons of vs. ES revealed NS Δ in total SpC in total EJ or AG or RG fractions between specimens obtained with 2 methods
| • Race/ethnicity: NR | • Eligibility Criteria: | • Amplitude: NR | • Follow-up: NR
| • Age: NR | • Inclusion: NR | • Frequency: NR
| • Level of Injury: 45% cervical; 51% thoracic; 4% lumbar; 39% quadriplegic (all incomplete0; 61% paraplegic (43% complete) | • Exclusion: NR | • Mode/Admin. Route: 5 m VS & 1 m rest then resumed for 5 m; 1–3 trials of VS/ pt then assigned to 1/3 grps: VS only, ES only or VS+ES
| • ASIA Level: NR | • Quality Assessment: 8/19 (+) reported | • Other Device: Electrical stimulator
| • Duration since injury: NR | | • Type: Seager Model 14
| • Previous fertility: NR | | • Mode/Admin. Route: NR
| • Drop-outs: NR | | • Surgical: NR
| • Lost to follow-up: NR | | • Procedure:
| • Number of sites: 1 | | • Bladder catheterization
| • Funding: grant from Miami Project to Cure Paralysis & State of Florida Specific Appropriation No. 224 for Spinal Cord Research | | • -with/without alkalinization: 41% intermittent catheterization, 36% external catheter, 14% voluntary voiding, & 8% suprapubic & 1% Foley catheter
| | | • Epidydimal aspiration (MESA/PESA): NR
| | | • Testicular biopsy: NR
| | | • Behavioural: NR
| | | • Laboratory techniques: NR
Brackett 2000, US | • Enrolled/ evaluated: n=26; n=12 SCI, n=14 ctrl/n=26 | • Study Design: NCS | • Pharmacologic (n = x): NR | • Outcomes: | • A/E: NR
(Ref ID 950) | • % males: 100% | • Duration: 3 mo | • Device: (Vibrator Le Vibrion) (n = 8) | • Measures of Fertility Rates:
| • Race/ethnicity: NR | • Eligibility Criteria: | • Amplitude: NR | • Seminal Parameters: % of motile & viable sperm in vas aspirated (VAS) vs. ejaculated specimen (EJ): S df between VAS of SCI < ctrls (p < 0.001), S between EJ of SCI < ctrls (p < 0.0001), S df between VAS > EJ in SCI (p < 0.0001), NS df between VAS & EJ of ctrls
| • Age: SCI 37 (NR) y; ctrl 34.9 (20–40) y | • Inclusion: No secondary neurological sequel, empty & not irritated rectum & bladder, negative urine culture, T12 & L1 & L2 myelomeres must be intact | • Frequency: NR | • Sperm viability: S df between VAS of SCI < VAS of ctrl (p<0.02), S df between EJ of SCI < EJ of ctrl (p < 0.0001), S between VAS > EJ in SCI (p <0.0001).
| • Level of Injury: C4–L1 (n=9) data missing in (n=3) SCI | • Exclusion: NR | • Mode/Admin. Route: NR | • Follow up: EJ in (n=6) SCI 2–6 mo after vas aspiration revealed sperm parameters similar to ejaculates before aspiration.
| • ASIA Level: NR | • Quality Assessment: 7* (NOS) | • Other Device (n = 8):
| • Duration since injury: 14.6 (5–23) y | | • Type Electroejaculator
| • Previous fertility: NR | | • Manufacturer: NR
| • Dropouts: n=5 | | • Surgical: NR
| • Lost in follow-up: n=20 | | • Procedure: NR
| • N of sites: 1 | | • Behavioural (n = 14):
| • Funding: NIH: Grant State of Florida Specific Appropriations & the Miami Project to Cure Paralysis | | • masturbation in ctrl grp to obtain specimen
| | | • Laboratory techniques: (n = 26):
| | | • Donor sperm insemination: NR
| | | • Sperm preparation (vas deferens aspiration): Sperm removed by aspiration of vas deferens of normal ctrls (12/14) during standard vasectomy during local anesthesia. Epididymis milked & vas divided vas then lavaged & aspirated with 0.1 to 0.2 ml of sterile sperm buffering solution in 5 mg/ml Vas aspiration in SCI pts (9/12) obtained after anesthesia & hemisectioned mirosurgically. Cannulation, lavage & aspiration performed as in ctrls. Vas aspiration specimen then compared with AG EJ obtained from both grps.
Brindley, 1981, UK | • Enrolled/ evaluated: n=37/ n=37 | • Study Design: NCS | • Pharmacologic (n=x): NR | • Outcomes: | • A/E: Pain preventing sufficient stimulation to produce EJ n=6
(Ref ID 1830) | • % males: 100% | • Duration: NR | • Device: Electrostimulator (n =37) | • Measures of Fertility Rates:
| • Race/ethnicity: NR | • Eligibility Criteria: | • Amplitude: NR | • Seminal Parameters: Some motile spermatozoa seen in semen of 14/15 AG, & in urine of 2/9 RG. Motile spermatozoa range from 0–2.5 per mlns in (n=10), 2.5–5 in (n=2), 5–10 in (n=3), 10–20 in (n=5), 20–40 in (n=4), 40–80 in (n=5), & 80–100 in (n=2). Semen resulting in pregnancy in one 30 y old complete T6 contained 200 mlns spermatozoa per ml with 1% motility.
| • Age: NR | • Inclusion: NR | • Frequency: Sinusoidal current of 15–35 Hz, or rectangular pulse for duration of 100 microseconds, resistant of 40 Ω on, 72–99 V for up to 30 sec. | • EJ Rates: AG EJ=12 on 1^st^ attempt, 2 on 2^nd^ & 1 on 3^rd^; RG EJ = 7 on 1st attempt & 2 on 2^nd^. No sperm in (n=7), 3 of them failed to produce urine specimen; in 4 of these semen contained no spermatozoa.
| • Level of Injury: lesions below, at or above L2. | • Exclusion: NR | • Admin. Site: Obturator nerve | • Follow-up: NR
| • ASIA Level: NR | • Quality Assessment: 2/19 (+) reported | • Other Device: NR
| • Duration since injury: NR | | • Surgical: NR
| • Previous fertility: NR | | • Procedure: NR
| • Dropouts: n=0 | | • Behavioural: NR
| • Lost in follow-up: NR | | • Laboratory techniques: NR
| • N of sites: 1
| • Funding: NR
Brindley, 1981, UK | • Enrolled/ evaluated: n=178: n=175 SCI; n=5 other/ n=NR | • Study Design: NCS | • Pharmacologic (n = x): NR | • Outcomes: | • A/E:
(Ref ID 801) | • % males: 100% | • Duration: NR | • Device: Electrostimulator (n=89) | • Measures of Fertility Rates: | • Local: Contractions of striated muscles i.e. contraction of abdominal muscles in 6/146 AG EEJ without general anesthesia, & in 1/47 unsuccessful & in 1/44 RG EEJ. Bilateral contraction of adductors in 4 pts. After-effects on spasm: some have reported less spasm after EEJ. Mictuition: mixture of urine & semen in 10/37 AG. Erection: occurs in some but not all cases. Contraction of dartos muscle: more frequently in SCI with one complete T8 lesion.
| • Race/ethnicity: NR | • Eligibility Criteria: | • Amplitude: Peak voltage up to 108v | • Seminal Parameters: | • Systemic: Rise in blood pressure BP
| • Age: NR | • Inclusion: NR | • Frequency: frequency of pulse 30, 15, 10 per sec, time between pulses 10ms | • EJ Rates: In SCI pts external success in EEJ (n=36); RG success (n=14); Definite failure: (n=32)
| • Level of Injury: n=22 C6–T1; n=50 T2–T12; n=12 L1 or below; (n=17 incomplete, n=14 flaccid, n=53 complete) | • Exclusion: NR | • Mode/Admin. Route: NR | • In 7 pts electro stimulation intolerably painful.
| • ASIA Level: NR | • Quality Assessment: 5/19 (+) reported | • Other Device: NR | • Correlates of failure: In 9 of 20 definite failures EEJ seemed to have its proper effect on prostate, seminal vesicles, & vasa deferntia, but pts azoospermic from disease or injury of upper genital tract.
| • Duration since injury: NR | | • Surgical: NR | • Follow-up: NR
| • Previous fertility: NR | | • Procedure: NR
| • Dropouts: n=0 | | • Behavioural: NR
| • Lost in follow-up: NR | | • Laboratory techniques: NR
| • N of sites: 1
| • Funding: NR
Brindley, 1984, UK | • Enrolled/ evaluated: n=81/n=81 | • Study Design: NCS | • Pharmacologic: NR | • Outcomes: | • A/E: NR
(Ref ID 756) | • % males: 100% | • Duration: NR | • Device: The Ling 201 Vibrator (n=81) | • Measures of Fertility Rates:
| • Race/ethnicity: NR | • Eligibility Criteria: | • Amplitude: about 2.5mm | • EJ Rates: (n=154): in SCI C5–T1 there 23 AG, 7 RG, 6 external failure, 0 pain (total (n=43); in SCI T2–12, 40 AG, 18 RG, 20 definite failure, 5 external failure, in 5 pain prevented EJ (total 88); in SCI L1 or below, 6 AG, 3 RG, 30 definite failure, 1 external failure & in 15 pain prevented EJ (total n=23).
| • Age: NR | • Inclusion: NR | • Frequency: 80Hz | • With regard to time since injury, in pts with SCI< 6 mo post injury 14 AG, 2 RG, 3 definite failure, 5 external failure, & in 4 pain prevented EJ (n=28); in SCI> 6mo, 55 AG, 26 RG, 27 definite failure 5 external failure, & in 5 pain prevented EJ.
| • Level of Injury: 5-L1 or below | • Exclusion: NR | • Mode/Admin. Route: NR | • Pregnancy rates: n=11
| • ASIA Level: NR | • Quality Assessment: 6/19 (+) reported | • Other Device: NR | • Live Births: n=9
| • Duration since injury: (n=28) < 6 mo, (n=126) > 6 mo | | • Surgical: NR | • Follow-up: NR
| • Previous fertility: None | | • Procedure: NR
| • Dropouts: n=0 | | • Behavioural: NR
| • Lost in follow-up: NR | | • Laboratory techniques: NR
| • N of sites: 1
| • Funding: NR
Brindley1986, UK | • Enrolled/evaluated: n=12/ n=12 | • Study Design: NCS | • Pharmacologic: NR | • Outcomes: | • A/E:
(Ref ID 729) | • % males: 100% | • Duration: 36 mo | • Device: NR | • Measures of Fertility Rates: | • Systemic: (n=2) Infected reservoirs, (n=1) obstruction of reservoir requiring revision, 1 removed
| • Race/ethnicity: NR | • Eligibility Criteria: | • Surgical (n=12): Sperm Reservoir Implanted Sperm Reservoir for Obstructive (alumina & glass silicone rubber) | • Seminal Parameters: Sperm retrieval from right reservoir in paras: vol=0.2–1.0, Count=20–140, Motility=0–30%. Retrieval from left reservoir in paras: Vol=0.2–0.8, Count=0–80, Motility=0–1%,
| • Age: NR | • Inclusion: NR | • Technique: inserted via inguinal incisions. Prophylactic antibiotics given for 7d | • Sperm Retrieval from pt's with vasal obstruction, right reservoir: Vol=0.1–0.8, Count=0–233, Motility=0–30%; Left reservoir, Vol=0. 2–0.6, Count=0–30, Motility=0–30%
| • Level of Injury: all paraplegic pts | • Exclusion: NR | • Behavioural: NR | • Pregnancy rates: (n=2) (17%)
| • ASIA Level: NR | • Quality Assessment: 6/19 (+) reported | • Laboratory techniques (n=12) | • Live Births: (n=2)
| • Duration since injury: 0–10 y | | • AIH: pts injected tissue culture medium into reservoirs & either provokes orgasm (SCI) or wait 1 h. Reaspiration yielded a mixture or culture & presumable fresh spermatozoa. | • Singletons: (n=2)
| • Previous fertility: n=7 azospermia due to obstruction of abdominal part of vas deferens; n=2 cystectomy; n=1 ejaculatory cyst; n=1 imperforate anus, n=1 Panproctocolectomy; n=1 Tuberculosis, n=1bladder exstrophy | | | • Follow-up:
| • Dropouts: n=0 | | | • Length: monthly check up
| • Lost in follow-up: NR | | | • Duration:
| • N of sites: 1 | | | • Results: aspirates examined microscopically. Upon identification of motile spermatozoa, instruction in artificial insemination given.
| • Funding: NR
Brinsden, 1997, UK | • Enrolled/ evaluated: n=35 couples/ n=35 couples | • Study Design: NCS | • Pharmacologic: NR | • Outcomes: | • A/E: NR
(Ref ID 528) | • % male: 50% | • Duration: NR | • Device: electrical stimulator/ Vibrator | • Measures of Fertility Rates:
| • Race/ethnicity: NR | • Eligibility Criteria: | • Amplitude/Frequency: NR | • Seminal Parameters: when fertilization occurred, initial mean total SpC 83 mln/ml; Initial mean total motile SpC 5.3 mln/ml; Initial mean motility 15%. Post sperm preparation mean SpC 3.8 mln/ml; mean motility 65%; n of cycles to acolyte recovery 67/71 (94.4%)
| • Age: male 32.2 (24–47) y; female partner 29.4 (21–43) y | • Inclusion: NR | • Laboratory techniques: | • Pregnancy rates: 18 total; (n=14) fresh embryo transfers; (n=4) frozen embryo transfers; n of total delivered clinical pregnancies 14; pregnancy rate per tx cycle started: 21.2% (18/85); Clinical pregnancy rate per couple 51.4% (18/35)
| • Level of Injury: C5-L1 | • Exclusion: other methods of assisted fertilization used | • AG: a two-step Percoll gradient, & resuspention in Earle's culture medium. Sperm concentration adjusted to 100 000/ml | • Miscarriage/ectopic: (n=4) (3 in first trimester, 1 in a second trimester)
| • ASIA Level: NR | • Quality Assessment: 9/19 (+) reported | • RG: centrifuged at 200 g for 5 m resuspended in Earle's culture medium & centrifugation repeated. | • Live Births: (n=14)
| • Duration since injury: 8.5 (1–27) y | | • Intrauterine insemination: NR | • Singletons: (n=13)
| • Previous fertility: tubal factor infertility in 3/35 female; endometriosis in 2/35 | | • IVF: 71 cycle of IVF obtained by TREE. N of cycles to oocyte recover (%) 67(94.4); n of couples with complete failure of fertilization (%), 9 (13.4); n of embryo transfers cancelled: 2; n of fresh embryo transfer cycles: 54; n of fresh embryos transferred/cycle mean: 2.4; n of cycles with spare embryos cryopreserved (%): 22/54(40.7); n of spare embryos cryoprederved mean: 2.70. | • Multiples: 5 diagnosed as twins on early ultrasound, 2 of which delivered single babies
| • Dropouts: n=0 | | • Intracytoplasmic sperm injection | • Additional Outcomes: Overall clinical pregnancy rate per stimulated IVF tx started 25.4% (18/71); Overall clinical pregnancy rate per fresh embryo transfer 25.9% (14/54); Overall clinical pregnancy rate per frozen-thawed embryo transfer cycle 28.6% (4/14)
| • Lost in Follow-up: N/A | | • Embryo cryopreservation: n of couples with cryopreserve embryos: (n=11), n of thawed embryo transfer cycles 14, n of embryos transferred mean: 2.3; n of clinical pregnancies/ transfer (%): 4(28.6), n of live births / couple with frozen embryos (%), 4(36.4) | • Follow-up: NR
| • N of sites: 1
| • Funding: NR
Buch, 1993, US | • Enrolled/evaluated: n=18/ n=18 | • Study Design: NCS | • Pharmacologic: | Outcomes: | • A/E: NR
(Ref ID 624) | • % males: 100% | • Duration: 2.5 | • Drug name nifedipine (tx of hypertension) | • Measures of Fertility Rates:
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose: 5–10 mg | • Seminal Parameters: average total SpC in both RG & AG EJs: 304 mln/ml; average total motile SpC 83 mln/ml; average % of motile sperm 21%
| • Age: 31 (22–43) y | • Inclusion: men older than 19 Y with SCI for fertility evaluation | • Duration: NR | • EJ Rates: total 89%; in quadriplegics 100% (7/7) & in paraplegics 82% (9/11)
| • Level of Injury: Cervical C5–C6: 7,Thoracic T3–T12: 11(ASIA scores: A 12; B-D 6) | • Exclusion: NR | • Schedule: at each session | • Pregnancy rates: 50% (3/6) (one woman got pregnant twice)
| • ASIA Level: NR | • Quality Assessment: 8/19 (+) reported | • Mode/Admin. Route: Sublingual (5–10 m pre-swallowing) | • Live Births: n=2
| • Duration since injury: 8.8 (2–22) y | | • Device: rectal probe for EJ | • Follow-up: NR
| • Previous fertility: NR | | • Amplitude: up to 600 mA
| • Dropouts: n=2 | | • Frequency: 60 Hz
| • Lost in follow-up: NR | | • Mode/Admin. Route: NR
| • N of sites: 1 | | • Other Device: NR
| • Funding: Paralyzed Veterans of American Spinal Cord Injury Research Foundation | | • Surgical: NR
| | | • Procedure:
| | | • Bladder catheterization
| | | -with/without alkalinization: Oral sodium bicarbonate 36 hr pre-tx (alkalization of urine)/Oral antibiotics 7–10 d pre-tx
| | | • protoscopy: ruling out rectal injury pre EEJ
| | | • Behavioural: NR
| | | • Laboratory techniques:
| | | • Sperm preparation: Std analysis on AG & RG specimens. (RG centrifuged @ 600 times gravity for 10 m, aspirated & resuspended over volume of 1–4ml. Bigger's Whitten & Wittingham solution then mixed with AG, frozen & thawed.
| | | • intrauterine insemination: in all couples; 2–4 cycles; with or without oral clomipene, nest 3 cycles with human menopausal gonadotropin ovarian stimulation & progress to IVF if IUI failed
Le Chapelain1998, France | • Enrolled/ evaluated: n=39/ n=10 evaluated for conception | • Study Design: NCS | • Pharmacologic (n = 9): | • Outcomes: | • A/E: NR
(Ref ID 522) | • % males: 100% of 39 SCI; 50% of 10 couples | • Duration: 5 yr retrospective study | • Drug name: physostigmine | • Measures of Fertility Rates:
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose: 2mg | • Seminal Parameters: mean volume of sperm obtained by VS S higher (p=0.0136) vs. that of ES; % motile form S higher in vs. ES (p=0.0330); NS in number of spermatozoa & % of normal form in vs. ES
| • Age: 28.5 (19–49) Y | • Inclusion: NR | • Duration: NR | • EJ Rates: 30/39 (77%) ejaculated
| • Level of Injury: 17 tetraplagics C4–8 (8 complete, 9 incomplete); 15 paraplegic T1–T10 (all complete); 7 paraplegic pts T11-L2 (complete or incomplete) | • Exclusion: NR | • Schedule: 10 m post administration of Metoclopramide (10mg) | • 12/18 (68%) ejaculated with VS; rate of success 86% in tetraplegic grp, 62% in T1–T10 paraplegic subgrp, & 33% in T11-L2 subgrp
| • ASIA Level: NR | • Quality Assessment: 11/19 (+) reported | • Mode/Admin. Route: injection of physostigmine followed by VS 10–15 m later | • 13/19 (68%) with ES ejaculated; rate of success 83% in tetraplegic grp, 66% in T1–T10 grp & 50% in T11-L2 grp
| • Duration since injury: NR | | • Device: Vibrion Vibrator (n=18) | • 6/9 (66%) ejaculated with
| • Previous fertility: NR | | • Amplitude: 2–4.5 mm | • physostigmine injection; rate of success 100% in tetraplegic grp, 33% in T1–T10 grp & 0% in T11-L2 grp
| • Drop-outs: n=0 | | • Frequency: 100 Hz | • Pregnancy rates: 3/10
| • Lost to follow-up: NR | | • Mode/Admin. Route: 3 m VS followed by 1 m pause for max of 3 cycles/session | • Miscarriage/ectopic: 1/10 spontaneous
| • Number of sites: 1 | | • Other Device: Electrostimulator (Stimed)(n=19) | • Live Births: 2/10
| • Funding: NR | | • Frequency: 50 Hz | • Singletons: 2/10
| | | • Intensity: 125 mA | • Follow-up: NR
| | | • Duration: up to 10 m/session
| | | • Note: at least 2 distinct sessions with physostigmine/ VS or ES attempts conducted for each pt.
| | | • Surgical: NR
| | | • Procedure: NR
| | | • Bladder catheterization:
| | | • without alkalinization after tx
| | | • Epidydimal aspiration (MESA/PESA): NR
| | | • Testicular biopsy: NR
| | | • Behavioural: NR
| | | • Laboratory techniques:
| | | • Donor sperm insemination: NR
| | | • Sperm preparation: NR
| | | • Intrauterine insemination: n=3
| | | • IVF: in one couple reported
| | | • Intracytoplasmic sperm injection: NR
| | | • Embryo cryopreservation: NR
| | | • Sperm cryopreservation: NR
Chapelle, 1983, France | • Enrolled/ evaluated n=20/ n=20 | • Study Design: NCS | • Pharmacologic (n =20): | • Outcomes: | A/E:
(Ref ID 1404) | • % males:100% | • Duration: NR | • Drug name intervention: PSC injection, ISN | • Measures of Fertility Rates: | • Systemic: Orthostatic hypotension 15–60 m post injection, tachycardia<140 b/min, nausea in 33%, & vomiting in 3 pts, 3 times in one of them. Sense of well being, floating in space, & euphoria 10 m after injection of physostigmine, accompanied with tired feeling. Other side effects reported to be related to pre-study medication (i.e. anticholinergic agents)
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose: Baseline: PCS - 4 mg, average 2 mg 30 m after N-buthylhyocine 40 mg followed by masturbation 15 m later several wks ISN (following lumbar puncture) 0.25 or 0.5 mg mixed with cerebrospinal fluid, injected intrathecally. (Some pts received a supplementary injection of 1 mg PCS when no results obtained from first injection 30 m later. | • Erectile function: erection easier to obtain & maintain after PSC test. Erection not affected in 60% of cases when PSC negative & improved in 40%. When PSC test positive, erection improved in 80% of cases. indication of PSC & ISN are identical but latter presents fewer disadvantages
| • Age: NR | • Inclusion: NR | • Duration: NR | • Follow-up:
| • Level of Injury: NR | • Exclusion: NR | • Schedule: NR | • Pts used PSC at home without any medical supervision if they had experimented & responded to their test in hospital.
| • ASIA Level: NR | • Quality Assessment: 8/19 (+) reported | • Mode/Admin. Route: injection of PSC or ISN test not performed if lesion affected T12, L1 or L2 & PSC test negative
| • Duration since injury: NR | | • Device: NR
| • Previous fertility: NR | | • Other Device: NR
| • Dropouts: NR | | • Surgical: NR
| • Lost in follow-up: NR | | • Procedure: NR
| • N of sites: 1 | | • Behavioural (n = 20):
| • Funding: NR | | • Type: masturbation
| | | • Duration: NR
| | | • Frequency: 15 m post-injection
| | | • Laboratory techniques: NR
Chen, 1997, US | • Enrolled/ evaluated: n=14/ n=14 | • Study Design: NCS | • Pharmacologic: NR | • Outcomes: | • A/E:
(Ref ID 2069) | • % males: 100% | • Duration: NR | • Device: Ling 201 Vibrator (n = 14) | • Seminal Parameters: sperm in 43/51(84%) AG; & in 39/61(64%) RG; SpC in AG (mean 74.1 mln) > RG (mean, 40 mln) (NS); NS dfs between AG & RG in SpMot, progressive motility, or normal morphology, with motility being low & progressive motility being high in general | • Systemic: rise in BP in 4/14; additional complications i.e. headache & increase in spasticity
| • Race/ethnicity: NR | • Eligibility Criteria: | • Amplitude: 205 mm | • EJ Rates: AG in 51/61(84%) trials; AG in 1st cycle of VS in 41/61(80%) trials; RG in 100% of trials
| • Age: 30.7 (25–41) y | • Inclusion: NR | • Frequency: 80Hz | • Follow-up: NR
| • Level of Injury: T6-L5 | • Exclusion: < 6 ms since SCI | • Mode/Admin. Route: VS to dorsal surface of penis near frenulum, in cycles of 3.5 on m-1.5 off;
| • ASIA Level: n=8 A; n=4 B; n=2 C | • Quality Assessment: 10/19 (+) reported | • Schedule: every 2–4 wk
| • Duration since injury: 6.9 y; range, 1–16 y | | • Other Device: Vibrators
| • Previous fertility: NR | | • Type: panabrator; 4-in-1; Magic Wand; thrive Model 91
| • Drop-outs: n=0 | | • Manufacturer: Panasonic Industrial NJ; Wahl Clipper Corp, IL; Hitachi Appliance Corp, GA; Daita Electronic Co, respectively
| • Lost to follow-up: n=0 | | • Surgical: NR
| • Number of sites: 1 | | • Procedure: NR
| • Funding: US Dept. of Education; NIDRR Research; Rehabilitation Institute of Chicago | | • Behavioural: NR
| | | • Laboratory techniques: NR
Chen, 1999, US | • Enrolled/ evaluated: n=14/ n=14 | • Study Design: NCS | • Pharmacologic: NR | • Outcomes: | • A/E:
(Ref ID 952) | • % males: 100% | • Duration: NR | • Device: Vibrator Ling 201, Panabrator; 4-in-1; Magic W&; Thrive Model 91 (n = 14) | • Measures of Fertility Rates: | • Systemic: 28.5% (n=4) increased blood pressure; 7.1% (n=1) headache; 7.1% (n=14) increased spasticity
| • Race/ethnicity: NR | • Eligibility Criteria: | • Amplitude: NR | • Seminal Parameters: sperm concentration: AG 81.4(101.4) mln/ml, range 0.03–473.0 mln/ml; SpMot: AG 37.0 (6.7)%, range 0–60%; RG 15.2 (30.8)%, range 0–63; sperm progressive motility: AG 58.1(23.1) %, range 0–92%; RG 57.0 (37.9) %, range 0–100%; normal morphology: AG 35.7 (11.0) %, range 8–52%; RG mean 31.1 (15.7) %; range 0–58%
| • Age: 30 (25–41) y | • Inclusion: >6 m onset of SCI | • Frequency: NR | • NS between AG & RG samples with respect to SpC, SpMot, progressive motility & normal morphology
| • Level of Injury: (n=8) Cervical, (n=6) Thoracic, n=8 Lumbar | • Exclusion: NR | • Mode/Admin. Route: 3,5 m on & 1.5 m off until AG ejaculate obtained or until 4 cycles completed | • EJ Rates: AG EJ rate: 84% (51/61), RG ejaculate rate 100% (61/61)
| • ASIA Level: NR | • Quality Assessment: 9/19 (+) reported | • Other Device: NR | • Follow-up: NR
| • Duration since injury: 6.9 (1–16) y | | • Surgical: NR
| • Previous fertility: NR | | • Procedure: NR
| • Dropouts: n=0 | | • Behavioural: NR
| • Lost in follow-up: NR | | • Laboratory techniques (n = 14): Sperm preparation: Std semen analysis for semen volume, sperm concentration, count, motility, progressive SpMot, & normal SpMor. Biochemical analysis using enzdymatic EJ.
| • N of sites: 1
| • Funding: US Dept. Education; NIDRR; Rehabilitation Institute of Chicago
Chung, 1997, US | • Enrolled/ evaluated: n=27/ n=27 | • Study Design: NCS; retrospective observational study | • Pharmacologic (n = 27): nifidepine | • Outcomes: | • A/E: NR
(Ref ID 547) | • % males: 100% | • Duration: NR | • Dose: 10 mg | • Seminal Parameters:
| • Race/ethnicity: NR | • Eligibility Criteria: | • Frequency: | • AG (mean, SD) (n=92): pH 7.4+-0.1; volume 16.5+-2.8 ml, SpC 64.6+-10.0 mln/ml; total SpC 578.5+-93.6 mln/ml; motility 16.7%+-1.5%; normal morphology 28.6%+-2.0%
| • Age: (27–48) y | • Inclusion: unejaculatory men with SCI or retroperitoneal LND, who treated at Rehabilitation Center at Tampa General Hospital between September 1991 & October 1995 | • Admin: 15 m pre-during & post procedure as prophylaxis for autonomic dysreflexia | • RG (mean, SD) (n=34): pH 6.8+-0.1; volume 45.8+-6.4 ml; SpC 8.2+-2.7 mln/ml; total SpC 2.9.8+-69.6 mln/ml; motility 6.9%+-1.9%; normal morphology 26.7%+-3.7%
| • Level of Injury: NR | • Exclusion: NR | • Device: Electrostimulator(n =27): Amplitude: 2 V & increased progressively at 1- to 2-V increments per stimulation every 4 to 6 seconds until EJ occurred | • EJ Rates: sperm recovery rate: 93% (86/93); solely AG ejaculate in 63% (59/93); combination of AG & RG in 35% (33/93); 1 solely RG ejaculate
| • ASIA Level: NR | • Quality Assessment: 9/19 (+) reported | • Other Device: NR | • Pregnancy rates: 7 pregnancies in 13 couples with a total of 56 IUIs; pregnancy rate per IUI attempt 12.5% (7/56)
| • Duration since injury: NR (3–25) y | | • Surgical: NR | • Induced abortion: 2 spontaneous abortions
| • Previous fertility: NR | | • Procedure (n=x): | • Live Births: 4 term live births; 1 on-going twin pregnancy
| • Dropouts: n=0 | | • Bladder catheterization: Alkalization of urine with a 24-hr regimen of sodium bicarbonate before EEJ | • Follow-up: NR
| • Lost in follow-up: NR | | • Epidydimal aspiration (MESA/PESA)
| • N of sites: 1 | | • Testicular biopsy
| • Funding: NR | | • Behavioural (n = x):
| | | • Laboratory techniques (n = x):
| | | • Sperm preparation:
| | | • Both AG & RG with swim-up technique
| | | • Intrauterine insemination: specimen washed twice & centrifuged &resuspended in 0.2mL of medium, layered with same medium & incubated for 1h @ 37°C & top layer collected for insemination
| | | • IVF
| | | • Intracytoplasmic sperm injection
| | | • Embryo cryopreservation
| | | • Sperm cryopreservation: -ejaculated: -biopsy
Dahlberg, 1995, Finland | • Enrolled/ evaluated: n=63 participated for fertility tx/ 35 couples evaluated for conception | • Study Design: NCS | • Pharmacologic (n=35): | • Outcomes: | • A/E: NR
(Ref ID 573) | • % males: 100% of n=63; 50% of 35 couples | • Duration: NR | • Drug name: S/L Nifidepine | • Measures of Fertility Rates:
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose: 10–30 mg | • Seminal Parameters: concentration before preparation 87 mln/ml (range 1.2–200 mln); post preparation 32 mln/ ml. (range .6–88 mln). Sperm mobility before prep 18% (range 2–42) & after prep 25% (range 0–9).
| • Age: NR | • Inclusion: NR | • Duration: NR | • EJ Rates: EJs obtained in 20 pts with VS & in 9 with ES; RG EJ in 8 pts(spermatozoa in n=2
| • Level of Injury: NR | • Exclusion: NR | • Schedule: 30 m pre-procedure | • Pregnancy rates: (n=24)
| • ASIA Level: NR | • Quality Assessment: 7/19 (+) reported | • Mode/Admin. Route: sublingually | • Miscarriage/ectopic: (n=4)
| • Duration since injury: NR | | • Device: Vibrator (n=27): | • Live Births: (n=24)
| • Previous fertility: NR | | • Amplitude: NR | • Singletons: (n=20)
| • Dropouts: n=0 | | • Frequency: NR | • Multiples: 2 sets of twins
| • Lost in follow-up: NR | | • Mode/Admin. Route: NR | • Follow-up: NR
| • N of sites: 1 | | • Other Device: Electrostimulator (n=13)
| • Funding: NR | | • Brindley's technique / no anesthesia
| | | • Surgical: NR
| | | • Behavioural:
| | | • Laboratory techniques:
| | | • Sperm preparation: swim-up technique used followed by sperm discontinuous Percoll gradient (40/90%)
| | | • home insemination once per cycle
| | | • Intrauterine insemination: 4–6 cycles in all EEJ cases
| | | • IVF: 3^rd^ choice of tx if 1st two did not result in pregnancy; down-regulation with intranasal buserelin acetate 1200 μg daily, started on 23rd d of previous cycle
de Lamirande 1995, Canada | • Enrolled/ evaluated: n=207: n=20 healthy volunteers, n=166 non-SCI infertile, n=21 SCI/ n=207 | • Study Design: NCS | • Pharmacologic (19/ 21 SCI): | • Outcomes: | • A/E: NR
(Ref ID 960) | • % males: 100% | • Duration: NR | • Drug/ dose: name 40 mg of butylbromide at time 0. 1/2 h later, 2 mg of physostigmine SC following by semen collection (masturbation). In 2 other SCI men Nifedipine 5–10 mg sublingually pre electro stimulation to prevent Autonomic Dysreflexia | • Seminal Parameters: SpMot in SCI men ranged from 0% to 20% in whole semen (23/32 samples), this measure did not Δ slightly after Percoll gradient centrifugation (20/32 samples). In 9 of 23 samples with poor motility a rise in ROS after Percoll washing observed, no increase in ROS noted after Percoll wash when same comparison made with semen with motility>20%.
| • Race/ethnicity: NR | • Eligibility Criteria: | • Device: Electrostimulation (EEJ probe modes) (n = 2 SCI) | • Additional outcomes: ROS in normal pts are lower than those for infertile men (p<0.05) or those with SCI (p<0.0001). ROS levels lower in infertile men compare to SCI (p<0.0001). No df in level of ROS in SCI grp for level of lesion or duration of injury.
| • Age: SCI 28.1(20–40) y; healthy volunteers (n=20) NR (23–43) y, Infertile grp: NR | • Inclusion: NR | • Amplitude: NR | • Follow-up: NR
| • Level of Injury: n=9 Cervical, n=12 Thoracic & Lumbar, (15 Complete, 6 incomplete) | • Exclusion: NR | • Frequency: NR
| • ASIA Level: NR | • Quality Assessment: 8/19 (+) reported | • Mode/Admin. Route: NR
| • Duration since injury: 5.8 (0.5–14) y | | • Other Device: NR
| • Previous fertility: NR | | • Surgical: NR
| • Dropouts: (n=21) failed to respond to vibratory stimulation to ejaculate | | • Procedure: NR
| • Lost in follow-up: NR | | • Behavioural (SCI pts):
| • N of sites: 1 | | • Type: masturbation following injection of physostigmine
| • Funding: MRC, Canada | | • Duration: until EJ occurred
| | | • Frequency: NR
| | | • Laboratory techniques:
| | | • Sperm preparation: discontinuous Percoll gradients buffered with HEPES-balanced saline.
| | | • Reactive Oxygen Species Determination: ROS detected by luminescence during 10 s stirring analyzed sample following 10-fold dilution of Percoll-washed spermatozoa.
Halstead 1987, US | • Enrolled/ evaluated: n=12 couples/ n=12 couples | • Study Design: NCS | • Pharmacologic: NR | • Outcomes: | • A/E:
(Ref ID 986) | • % males: 50% of 12 couple | • Duration: 18 mo | • Device: (ES by rectal probe (38 occasion in 12 SCI) | • Measures of Fertility Rates: | • Systemic: Mild autonomic dysreflexia in (n=3), disruption of normal bowel program in (n=1). Pain & discomfort in pts with incomplete lesions & some preservation of sensation (all cervical lesions & L1).
| • Race/ethnicity: NR | • Eligibility Criteria: | • Amplitude: 8–15 V & 200–400 MA | • Seminal Parameters: Semen retrieval in 50% (6 of 12) of emissions, volume range=0.2–2.9cc; Sperm concentration range=7.5–678 mln/cc; %motility range=0–60%; %Normal morphology range=0–55%. Only 4 of 9 produced semen with live SpC adequate for AI.
| • Age: NR (23–38) y | • Inclusion: Traumatic SCI, age>18 y, medically stable, with preference given towards married pts. | • Frequency: Stimulation discontinued if BP>200 mm HG systolic or 130 mm Hg diastolic or for any other side effects/discomfort. | • EJ Rates: 10 of 12(83%) produced sperm on at least one occasion; Sperm obtained in 32 of 38 rectal probe EJs.
| • Level of Injury: n=4 C5–C6; n=7 T3–T12; n=1 L1 | • Exclusion: NR | • Mode/Admin. Route: max. of 25 stimulation/cycle (60 cycle/sec). | • Pregnancy rates: Spouse of pts artificially inseminated but no pregnancy achieved
| • ASIA Level: n=7 A; n=1 B; n=3 C; n=1 D | • Quality Assessment: 12/19 (+) reported | • Other Device: NR | • Live Births: n=0
| • Duration since injury: 5mo to 18 y | | • Surgical: NR | • Follow-up: NR
| • Previous fertility: NR | | • Procedure:
| • Dropouts: n=0 | | • Bladder catheterization: prior to RPE with a sterile catheterisation technique. In/out sterile bladder irrigation with normal saline post EJ to assess RG.
| • Lost in follow-up: | | • Protoscopy: test of rectal mucosa
| • N of sites: 1 | | • Behavioural: NR
| • Funding: Bob & Vivian Smith Foundation, Houston, & Model Rehabilitation Spinal Cord Injury System Grant, TIRR, funded by National Institute of Handicapped Research | | • Laboratory techniques: NR
Hellstrom, 1989, US | • Enrolled/ evaluated: n=13: n=11 SCI, n=1 diabetic & n=1 MS/ n=13 | • Study Design: NCS | • Pharmacologic: NR | • Outcomes: | • A/E: NR
(Ref ID 692) | • % males: 100% | • Duration: 14 mo | • Device: EEJ × 49 AI 2(All SCI pts) | • Measures of Fertility Rates:
| • Race/ethnicity: NR | • Eligibility Criteria: | • Amplitude: NR | • Seminal Parameters: (n=4) normal SpC & motilities (30% or greater); 3 pts had adequate sperms counts but low motilities (5% or less); 3 pts had mod abnormalities. Of 5 pts with markedly abnormal histograms, 4 remained azoospermic despite repeated attempts at EE
| • Age: 32.1(26–45) y | • Inclusion: all pts underwent physical exam, medical hx & lab work. No definite criteria listed. All pts included that attended EEJ clinic | • Frequency: 3 trial for each pt | • Ovulation rates: Ovulation problems in one partner are reported.
| • Level of Injury: n=6 Cervical; n=5 Thoracic | • Exclusion: NR | • Mode/Admin. Route: NR | • Pregnancy rates: 1 of 2 AI following EEJ.
| • ASIA Level: NR | • Quality Assessment: 8/19 (+) reported | • Other Device: NR | • Additional Outcomes:
| • Duration since injury: 7.7 (4–12) y | | • Surgical: NR | • Testicular biopsy results: 8 bilateral & 5 unilateral biopsies performed. In (n=5) normal histograms found, (n=3) mildly abnormal, & in (n=5) markedly abnormal. There no relationship with semen quality & level or completeness or duration of SCI
| • Previous fertility: NR | | Behavioural: NR | • Follow-up: NR
| • Dropouts: n=0 | | • Procedure (All pts):
| • Lost in follow-up: NR | | • Bladder catheterization with/without alkalinization: alkalization by admin. Of sodium bicarbonate orally for 36 hr. followed by rinse & instillation with tissue culture growth medium.
| • N of sites: 1 | | • Epidydimal aspiration (MESA/PESA)
| • Funding: American Urological Association Scholarship & University of California | | • Testicular biopsy: in all men testicular aspiration with a 23-gauge needle. DNA histograms collected within 4 d after aspiration.
| | | • Laboratory techniques: NR
Heruti, 2001, Israel | • Enrolled/evaluated: n=84 (including 49 couples)/ n=33 followed for pregnancy | • Study Design: NCS | • Pharmacologic: NR | • Outcomes: | • A/E:
(Ref ID 454) | • % males: 100% of n=84; 50% of 33 couples | • Duration: NR | • Device: | • Measures of Fertility Rates: | • Local: 19.1% (16/84) pts, abdominal spasm, pain
| • Race/ethnicity: NR | • Eligibility Criteria: | • Amplitude: maximum voltage 20 V | • Seminal Parameters: | • Systemic: increased BP, syncope
| • Age: 31.3 (19–45) y | • Inclusion: NR | • Frequency: maximum current 300 mA | • AG EJ sperm parameters (77 pts), sperm volume (cc): mean 1.44+-1.3, range 0.1–8; sperm concentration (mln/cc): mean 31.5+-45.5, range 0–340; total SpC (mln/cc): mean 57.9+-86.3, range 0–1020; SpMot (%): mean 7.9+-13.9, range (0–70); total motile sperms (mln): mean 4.8+-14.6, range (0–111); motility grade (0–4): mean 2.1+-0.8, range (0–3.5); SpMor (% normal sperm) mean 10.5+-12.8, range 0–58.
| • Level of Injury: cervical 29 (34.5%), thoracic 50 (59.5%), lumbar 5 (5.9%), | • Exclusion: NR | • Mode/Admin. Route: following an anoscopic examination of rectal mucosa, lubricated probe inserted into rectum with pt in left lateral decubitus position. | • RG EJ sperm parameters (77 pts): sperm volume NA, sperm concentration NA, total SpC (mln/cc): mean 12.3+-33.4, range 0–450; SpMot (%): mean 4.2+-11.8, range (0–84); total motile sperms (mln): mean 0.6+-2.7, range (0–36.3); motility grade (0–4): mean 1.9+-0.9, range (0–3.5); SpMor (% normal): mean 5.3+-8.0, range 0–55
| • ASIA Level: n=63 A; n=15 B; n=5 C; n=1 D | • Quality Assessment: 11/19 (+) reported | • Other Device: NR | • S dif. between AG & RG in all seminal parameters.
| • Duration since injury: 7.1 (4 mo-34) y | | • Surgical: NR | • EJ Rates: successful EJ rate: 34.9% (124/350) of stimulations & 54.8% (46/84) pts; total EJ rate 98.6% (350/355); no S df found between pts with LMN & UMN
| • Previous fertility: NR | | • Procedure (n=84): | • Pregnancy rates: overall rate/couple 69.2%; after IUI: 33.3% (5/15); after IVF: 70% (14/20)
| • Dropouts: n=0 | | • Bladder catheterization | • Live Births: n=26
| • Lost in follow-up: NR | | -plastic catheter, used saline solution & 20cc Ham's F-10 solution | • Follow-up: NR
| • N of sites: 1 | | • Behavioural: NR
| • Funding: NR | | • Laboratory techniques (n = 84):
| | | • Donor sperm insemination
| | | • Sperm preparation: Sperms prepared by filtration with mini-percol in 3 gradients. Pentoxyl-phyllin & deoxy-adenosine to accelerate motility
| | | • Intrauterine insemination: IUI is first line of tx with sperm analysis > 10.mln/cc
| | | • IVF: If 3 cycles of tx have failed, pts are referred for IVF. IVF is primary tx for Pts with <10 mln sperm/cc or mechanical problems of female
| | | • Intracytoplasmic sperm injection: ICSI is used for all pts that reach IVF, as this method is more successful with low sperm rates
Hirsch 1992, US | • Enrolled/ evaluated: n=9/n=7 | • Study Design: NCS | • Pharmacologic: | • Outcomes: | • A/E: NR
(Ref ID 974) | • % male: 100% | • Duration: NR | • Drug name: nifedipine | • Measures of Fertility Rates:
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose: 20 mg | • Semen analysis: vol., 2.5±2.8mL; mean SpC 74.4±113.3 mln/mL; mean motile concentration: 28.6±54.0 mln/mL; No correlation between semen analysis parameters & severity of histopathologic defect observed on testicular biopsy. In seminal
| • Age: NR | • Inclusion: NR | • Duration: NR | • plasma 71% (5/7) demonstrated (+) antisperm antibody response.
| • Level of Injury: (n=2) L1&T3 (excluded from analysis) (n=7) C5–T12, n=5 complete, n=2 incomplete | • Exclusion: NR | • Schedule: NR | • Additional Outcomes:
| • ASIA Level: NR | • Quality Assessment: 7/19 (+) reported | • Mode/Admin. Route: sublingually | • No relation found between level & degree of SCI, semen analysis (sperm concentration, %of motile spermatozoa & semen volume) & testicular biopsy (n=6); active sperm (n=1)
| • Duration since injury: 6.8 (5–12) y | | • Device: Electrical stimulator | • Follow-up: NR
| • Previous | | • Amplitude: NR
| • fertility: NR | | • Frequency: with sine wave of 60 Hz, with 1 V increments for max of 3 sec. & rest of 0.5 sec
| • Dropouts: n=2 | | • Mode/Admin. Route: NR
| • Lost in follow-up: NR | | • Other Device: NR
| • N of sites: 1 | | • Surgical: NR
| • Funding: Regional Spinal Cord Injury Center of the Delaware Valley; NIDRR | | • Procedure:
| | | • Bladder catheterization
| | | • -with/without alkalinization: Pre tx Medication: 2-d oral sodium bicarbonate tore alkalinize urine
| | | • Epidydimal aspiration (MESA/PESA)
| | | • Behavioural: NR
| | | • Laboratory techniques:
| | | • Sperm preparation: A-G ejaculates analyzed after liquefaction for 30 m at 370C. Seminal plasma separated by at centrifugation at 2,000 RPM for 10 m. Samples frozen at –200C until time of testing. ELISA performed on seminal plasma. Microtiter plates prepared by coating with 100ug/ml for 1 hr at 250C. Plates washed × 3 with PBS & coated overnight at 40C with sperm suspended in PBS at concentration of 2.5 × 10 sperm/well. To decrease non-specific binding plates washed × 3 with PBS coated with 200uL/well of blocking agent & left on plate × 15 m. After blocking step, each well filled with 100 uL of serial dilutions of test seminal plasma as well as (+) & (-) ctrls. Plate incubated for 1 hr at 370C. After incubation, 10-step wash with PBS Tween 1% N.G. Sperformed & plate coated with blocking agent. After this each well (apart from 1^st^ row used for blanking) filled with 100 uL of alkaline phosphates conjugated, goat antihuman IgG, IgA & IgM, heavy &light chain specific secondarily antibody sol. Plate read for absorbance at wavelength of 405 nm on Titertek ELISA scanning spectrophotometer.
| | | • Background absorbance calculated by averaging secondary antibody row absorbance values. This value subtracted from observed absorbance values to obtain actual absorbance values. Values > than 0.100 indicative of (+) reaction
Hultling, 1994, Sweden | • Enrolled/ evaluated: 12 couples/ n=12 couples | • Study Design: NCS | • Pharmacologic: physostigmine in combination with vibration/ nifedipine (tx of autonomic dysreflexia) | • Outcomes: | • A/E: NR
(Ref ID 598) | • % males: 50% of 12 couples | • Duration: NR | • Device: Vibrator & (n = 12) | • Measures of Fertility Rates:
| • Race/ethnicity: NR | • Eligibility Criteria: | • Amplitude: NR | • Seminal Parameters: concentration (mln/ml): median 91; range 3.5–202; % of motile sperm: median 11; range 5–57; total motile SpC (mln/ml): median 73; range 11–442; concentration in prepared sperm (mln/ml): median 29.5; range 2.5–2.5; % of motile sperm in prepared sperm: median 27.5; range 0.2–99; total count of motile sperm in prepared sperm (mln/ml): median 2; range 0.16–32
| • Age: 34 (27–38) y | • Inclusion: infertile male pts with SCI living in stable relationships with their female partners who express a strong wish for fatherhood & attending Solberga Spinal Cord Injury Project during January 1992 – November 1993 | • Frequency: NR | • Ovulation rates: 23 ovulatory cycles in 12 women partners
| • Level of Injury: cervical C4–C6: (n=4); thoracic T4–T12: (n=7); lumbar L3: 1 | • Exclusion: NR | • Mode/Admin. Route: VS used first in combination with physostigmine | • Pregnancy rates: 7 pregnancies in 6 couples (2 pregnancies in 1 couple)
| • ASIA Level: n=8 A; n= 2 C; n=2 D | • Quality Assessment: 6/19 (+) reported | • Other Device: Electrical stimulator: | • Miscarriage/ectopic: n=3
| • Duration since injury: (4–33) y | | • Mode/Admin. Route: transrectal ES usually under general anesthesia. | • Live Births: n=3
| • Previous fertility: all spouses of SCI pts had regular menstrual cycles & healthy on routine gyn. Exam; 7 nulligravidae, 5 I–II gravidae; 3 had children from previous marriages | | • Surgical: NR | • Singletons: n=1
| • Dropouts: n=0 | | • Procedure: NR | • Multiples: n=1
| • Lost in follow-up: NR | | • Behavioural: NR | • Follow-up: NR
| • N of sites: 1 | | • Laboratory techniques:
| • Funding: MRC, Sweden; Spinalis Foundation; Karolinska Institute | | • IVF: GnRH-agonist (nafarelin/buserelin) intranasally starting d 1 or 21; HMG or Fertinorm HPR daily 10–12 ds (150–300 IU/d). Both partners received prophylactic antibiotic tx with metronodazol & doxycycline.
| | | • Oocyte retrieval: 37 hrs after vaginal ultrasound-guided follicular aspiration then percultured for 3–4 hrs pre-insemination
Hultling, 1997, Sweden | • Enrolled/evaluated: 25couples/ n=25 couples | • Study Design: NCS | • Pharmacologic (n=25): | • Outcomes: | • A/E: NR
(Ref ID 538) | • % male: 50% of 25 couples | • Duration: NR | • Drug name: nifedipine | • Measures of Fertility Rates:
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose: 10–25 mg | • Seminal Parameters: total SpC: median 185.9 mln, range 0.01–978; motile SpC: median 32 mln, range 15–97.1
| • Age: male: age 34 (25–51) y; women: age 31 (21–38) y | • Inclusion: stable relationship, motile spermatozoa in a diagnostic sample | • Duration: NR | • Ovulation rates: total n of ovulatory cycles of female partner: 52
| • Level of Injury: range C2–L3 | • Exclusion: NR | • Schedule: NR | • Pregnancy rates: 16 clinical pregnancies (30.7%)
| • ASIA Level: n=18 A; n=7: NR | • Quality Assessment: 9/19 (+) reported | • Mode/Admin. Route: sublingually pre-ES or VS | • Miscarriage/ectopic: 4 in 1^st^ or 2^nd^ trimester & 1 case of intrauterine death in wk 31 of gestation
| • Duration since injury: NR | | • Device: Vibrator | • Fertilization rate (total n of fertilized eggs/total n of eggs): 52.3% (300/573); n of embryos (% of fertilized): 84.7%
| • Previous fertility: n=18 women nulligravidae; n=7 gravidae I–II; n=4 children born from previous relationship; n=2 women had a hx of endometriosis & n=2 PCOS; n of previous pregnancies: 7 gravidae I–II | | • Amplitude: 2.5 mm | • (254/300)
| • Dropouts: n=0 | | • Frequency: 100 Hz | • Live Births: (n=11)
| • Lost in follow-up: NR | | • Mode/Admin. Route: duration of 204 m & repeated up to 8 times | • Singletons: (n=9)
| • N of sites: 1 | | • Other Device: Electrical stimulator: | • Multiples: 2 sets of twins
| • Funding: MRC, Sweden; Spinalis Foundation; Karolinska Institute Funds; Norrbacka Eugenia Foundation | | • Type: | • Follow-up: NR
| | | • Manufacturer
| | | • Voltage: 7–35 V
| | | • Duration: 2–4 s
| | | • Mode/Admin. All pts with residual sensation in perineum &/or rectum underwent EEJ with general anesthesia: atropine prior to induction; alfentanyl 1–2 mg; 2–3 mg/kg propofol administered & supplemented with 5–15 mg/kg/h
| | | • Surgical: NR
| | | • Behavioural: NR
| | | • Laboratory techniques (25 couples):
| | | • Ovarian stimulation: Down-regulation with gonadotrophin-releasing hormone agonist, nafarelin, or buserelin, stating on cycle d 1 or 21. HMG, or purified FSH
| | | • IVF: antibiotic tx with metronidazole, 0.5 g 3× a d for 5 d & doxycycline, 0.1 g a d for 7 d, given prophylactic to all couples
| | | • Embryo transfer: n=47
Kolettis, 2002, US | • Enrolled/ evaluated: n=27(including 9 SCI with their partners)/ n=9 evaluated for conception | • Study Design: NCS | • Pharmacologic: NR | • Outcomes: | • A/E: NR
(Ref ID 424) | • % males: 50% of couples | • Duration: 1993-2001 | • Device: Electrical stimulator(n=27) | • Seminal Parameters: initial prep median total motile SpC & motility /procedure 6 mln & 7% respectively; 28 cycles(32%) yielded no motile sperm
| • Race/ethnicity: NR | • Eligibility Criteria: | • Amplitude: 12–18 V/ current of 400–600 mA | • EJ Rates: 112 EJ attempts made, 43/112(38%) AG; 24(21%) RG; 45(40%) AG+RG
| • Age: NR | • Inclusion: NR | • Frequency: NR | • Cycle Function: 25 cycles of IUI, 3 cycles of IVF & 3 cycles of IVF-ICSI
| • Level of Injury: n=10 cervical, n=16 thoracic, n=1 lumbar | • Exclusion: NR | • Mode/Admin. Route: 30 sec bursts of stimulation performed | • Pregnancy rates: 3/9
| • ASIA Level: NR | • Quality Assessment: 8/19(+) reported | • Other Device: NR | • Live Births: 2/9(both twins)
| • Duration since injury: NR | | • Surgical: NR | • Multiples: 2 sets of twins
| • Previous fertility: NR | | • Procedure: NR | • Follow-up: NR
| • Drop-outs: n=0 | | • Behavioural: NR
| • Lost to follow-up: n=0 | | • Laboratory techniques:
| • Number of sites: 1 | | • Donor sperm insemination: NR
| • Funding: NR | | • Sperm preparation: NR
| | | • Intrauterine insemination: 25 cycles performed
| | | • IVF: 3 cycles of IVF
| | | • Intracytoplasmic sperm injection: 2 cycles of IVF-ICSI performed
| | | • Embryo cryopreservation: NR
| | | • Sperm cryopreservation: NR
Leduc, 1992, Canada | • Enrolled/evaluated: n=37/n=3 evaluated for conception | • Study Design: NCS | • Pharmacologic: | • Outcomes: | • A/E:
(Ref ID 2252) | • % males: 100% of 37; 50% of couples | • Duration: NR | • Drug name Butylbromure hyoscine, Interventional drug specified for this review: Physostigmine | • Measures of Fertility Rates: | • Systemic: (n=8) had autonomic dysreflexia: hypertension & headache following EJ, (n=2) autonomic dysreflexia with no EJ, (n=5) nausea with vomiting once, (n=1) hallucination, (n=1) dizziness
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose/admin: Butylbromure hyoscine injection: 40 mg subcutaneous 30 m prior to administration of physostignime: 2 mg subcutaneous & repeated (1–2 mg) if not EJ reached (n=7 up to 4mg); Nifedipine: 10 mg sublingual | • Seminal Parameters (n=46): Mean SpC: 134 mln/mL, Range: 2–285. Mean motility: 28%, range: 1–67%
| • Age: 29.5 (19–61) y | • Inclusion: NR | • Device: NR | • Insemination rates: Insemination performed once in one of partners, 3 times in another & 15 times in other
| • Level of Injury: n=15 Cervical; n=22 Thoracic (29 complete; 8 incomplete) | • Exclusion: NR | • Other Device: NR | • Pregnancy rates: (n=3) in 3 couples
| • ASIA Level: NR | • Quality Assessment: 6/19 (+) reported | • Procedure: NR | • Live Births: (n=3)
| • Duration since injury: 3 mo-23 y mean 7.4 y | | • Behavioural: NR | • Follow-up: NR
| • Previous fertility: NR | | • Laboratory techniques:
| • Dropouts: n=13 | | • Donor sperm insemination
| • Lost in follow-up: NR | | • Sperm preparation: Semen collected for analysis post physostigmine induced EJ in a sterile container
| • N of sites: 1 | | • Intrauterine insemination: 0.5 ml of unwashed fresh sperm inseminated into cervix. This procedure also done at home as well as in hospital
| • Funding: NR | | • IVF in 6 couples
| | | • Intracytoplasmic sperm injection
Lim, 1994, Australia | • Enrolled/evaluated: n=12/n=12 | • Study Design: NCS | • Pharmacologic (n=x): NR | • Outcomes: | • A/E:
(Ref ID 333) | • % male: 100% | • Duration: 26 mo | • Device: Electrical stimulator (n=12) | • Measures of Fertility Rates: | • Local: 8.3% (1/12) severe stomach cramps
| • Race/ethnicity: NR | • Eligibility Criteria: | • Amplitude: 500 mA | • Seminal Parameters:
| • Age: 13 (21–36) y | • Inclusion: NR | • Frequency: sine wave currency 20 Hz at a maximum of 16 V | • Sperm volume: range 0.1–8.5 ml; sperm concentration: 0–500 mln/ml; SpMot: 0–80%; normal forms: 6–46%
| • Level of Injury: n=6 C4–C6; n=7 T10–T12; n=1 L2 | • Exclusion: NR | • Mode/Admin. Route: | • repeated stimulation had a + effect on semen quality
| • ASIA Level: NR | • Quality Assessment: 10/19 (+) reported | • Other Device (n=12): | • Volumes & concentration of sperm greater in EEJ vs. VE, but NS noted in SpMot
| • Duration since injury: 8 (1–24) y | | • Type: vibrator @ 60 Hz | • Additional outcomes: Silicone catheters had minimal effects on SpMot & viability. All lubricant gel found to adversely affect sperm quality
| • Previous fertility: NR | | • Manufacturer: Jeou Jen Electric Co. | • Follow-up: NR
| • Dropouts: n=0 | | • Surgical: NR
| • Lost in follow-up: NR | | • Procedure (n=12):
| • N of sites: 1 | | • Bladder catheterization: Foley catheter/no alkalization
| • Funding: NR | | • SpMot /manual assessment of % of motile sperm & motility analysis
| | | • Behavioural: NR
| | | • Laboratory techniques: NR
Lucas, 1991, UK | • Enrolled/evaluated: n=14: n=12 SCI; n=2 diabetic/n=14 | • Study Design: NCS | • Pharmacologic (n=12, SCI T6): | • Outcomes: | • A/E: NR
(Ref ID 667) | • % males: 100% | • Duration: 26 sessions | • Drug name: glyceryltrinitrate or nifedipine | • Measures of Fertility Rates:
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose: 20–40 mg | • Seminal Parameters: Vol. range: drops to 5.5 ml; % of progressive motility: 0–60; Sperm concentration 0–260
| • Age: 34.6 (25–46) y | • Inclusion: NR | • Duration: NR | • Pregnancy rates: (n=1) (AIH, RG ejaculate)
| • Level of Injury: 92%, n=3 Cervical; n=9 thoracic (n=10 complete, n=2 incomplete) | • Exclusion: NR | • Schedule: 20 m pre-procedure | • Live Births: (n=1)
| • ASIA Level: NR | • Quality Assessment: 6/19 (+) reported | • Mode/Admin. Route: sublingually | • Singletons: (n=1)
| • Duration since injury: 9.9 (2–22) y | | • Device: Electrical stimulator (n=14) | • Multiples: none
| • Previous fertility: secondary anorgasmy, due to diabetes (n=2) | | • Amplitude: up to 35 V, current up to 900 mA | • Genetic abnormalities: none
| • Dropouts: (n=2) | | • Frequency: 50 Hz | • Follow-up: NR
| • Lost in follow-up: NR | | • Mode/Admin. Route: rectal probe (PVC, 11/8 or 1¼ inches in diameter) with pressure to contact with ant. Rectal wall
| • N of sites: 1 | | • Other Device: NR
| • Funding: NR | | • Surgical: NR
| | | • Procedure (n=14):
| | | • Bladder catheterization
| | | - aseptically & washed with Ham's F 10 solution. Recatheterization after an AG EJ or 100% erection
| | | • Protoscopy: after procedure
| | | • Testicular biopsy: NR
| | | • Behavioural: NR
| | | • Laboratory techniques (n=14):
| | | • Donor sperm insemination
| | | • Sperm preparation: (n=8) centrifusion / & resuspension in a solution of 10% wife's serum supply. By Hams F 10 solution (swim up) to prepare for AIH
| | | • Embryo cryopreservation:
| | | • Sperm cryopreservation: (n=9)
| | | -ejaculated: Std technique with egg yolk & glycerol
Mallidis, 1994, Australia | • Enrolled/evaluate: n=7/n=7 | • Study Design: NCS | • Pharmacologic: NR | • Outcomes: | • A/E: NR
(Ref ID 966) | • % male: 100% | • Duration: EEJ performed every 2 d | • Device: Electrical stimulator (n=7) | • Measures of Fertility Rates:
| • Race/ethnicity: NR | • Eligibility Criteria: | • Amplitude NR | • Seminal Parameters:
| • Age: NR (18–39) y | • Inclusion: 2–15 d post-injury, Traumatic SCI, No known hx of testicular dysfunction | • Frequency: every 2 d; 2–13 EJ/pt | • Of 6 pts that started EEJ 2–3 d after injury, 5 had few sperms (<2-×10 mill/ml) & 1 had no sperm in first sample.
| • Level of Injury: n=6 C4 –6 , n=2 T4 –9 | • Exclusion: NR | • Mode/Admin. Route: insertion of rectal probe (CGS electroejaculator) | • 3 pts who had EEJ 48 h later had no sperm in semen.
| • ASIA Level: NR | • Quality Assessment: 8/19 (+) reported | • Other Device: NR | • Samples collected from 4 men bet. 6–10 d after injury had normal sperm & motility.
| • Duration since injury: 2–15 d | | • Surgical: NR | • Subsequent samples tended to have decreasing sperm viability & motility.
| • Previous fertility: NR | | • Procedure: | • 5 pts produced samples suitable for cryopreservation. Post-thaw sperm-motility recovery (range 36%–74%, mean 55%) similar to that of normal-donor cryopreseved semen. 2 pts did not produce samples suitable for cryopreservation
| • Dropouts: n=2 | | • Bladder catheterization – suprapubic indwelling catheter, nasogastric tube & intravenous line for fluid & medication inserted & calf stimulator applied | • EJ Rates: 46 EJs done (range 2–13 per pt)
| • Lost in follow-up: NR | | • Behavioural: NR | • Additional Outcomes: processes responsible for loss of semen quality appear to become established quickly after SCI. Post-thaw motility showed that cryopreserved samples as good as those stored from healthy men. collection of semen early after SCI can insure fertility
| • N of sites: 1 | | • Laboratory techniques (n=7): | • Follow-up: NR
| • Funding: NR | | • Donor sperm insemination
| | | • Sperm preparation: semen collected in warm, sterile plastic jar
| | | • Sperm cryopreservation:
| | | • -ejaculated: TEST egg-yolk buffer & vapour-frozen. Post-thaw motility after cryopreservation
| | | • Protoscopy: pre/post procedure
Mallidis, 2000, Australia US | • Enrolled/evaluated: n=9/n=9 | • Study Design: NCS | • Pharmacologic: NR | • Outcomes: | • A/E: NR
(Ref ID 472) | • % male: 100% | • Duration: 4 consecutive d | • Device: Electrical stimulation (n=9) | • Measures of Fertility Rates:
| • Race/ethnicity: NR | • Eligibility Criteria: | • Amplitude: max 16 V | • Seminal Parameters: mean SpMot increase on d 2 vs. d 1 23 (6.9) %; mean sperm viability increase on d 2 vs. d 1 24.9 (6.8) %.
| • Age: 28 (22–36) y | • Inclusion: males 16–40 y; ≥6 mo duration of SCI; no known or suspected testicular dysfunction (past undescended tests or infertility) | • Frequency: sine-wave current 20 Hz | • Overall, major gains in SpMot & viability achieved by d 2, although in 3 pts, improvement in motility & viability continued into d 3
| • Level of Injury: n=2 C5–C6; n=6 T4–T11; n=1 L2 | • Exclusion: NR | • Mode/Admin. Route: daily EEJ for 4 consecutive d n=6; EEJ for 3 consecutive d n=2 & EEJ for 1 d n=1 | • Testicular Biopsy: normal n=3; one-side normal n=1, other had moderately severe hypospermatogenesis; slight hypospermatogenesis n=1.
| • ASIA Level: NR | • Quality Assessment: 8/19 (+) reported | • Other Device: NR | • Additional Outcomes: Electron Microscopy: (n=9) all 9 d 1 samples showed marked degeneration of spermatozoa; samples after repeated EJ showed improved ultra structure with fewer degenerative features
| • Duration since injury: 54 (8–103) mo | | • Surgical: NR | • Follow-up: NR
| • Previous fertility: NR | | • Penile Implants
| • Dropouts: n=0 | | • Procedure:
| • Lost in follow-up: NR | | • Bladder catheterization: NR
| • N of sites: 1 | | • Epidydimal aspiration (MESA/PESA): NR
| • Funding: NR | | • Testicular biopsy: fine needle tissue aspiration biopsy in (n=5) (>1mont pre EEJ n=2/ on last d of EEJ n=3)
| | | • Behavioural: NR
| | | • Laboratory techniques (n=9):
| | | • Electron Microscopy: in 15 semen samples
Nehra, 1996, US | • Enrolled/ evaluated: n=78; 33 couples for conception/ 27 couples evaluated for conception | • Study Design: NCS | • Pharmacologic: | • Outcomes: | • A/E: NR
(Ref ID 91) | • % males: 100% | • Duration: NR | • Drug name: clomiphene citrate daily (ovulatory enhancement) | • Measures of Fertility Rates:
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose: 50 mg | • Seminal Parameters: after EE: mean sperm concentration: 170 mln/cc; SpMot: 11.3%;
| • Age: 26.9 (23–40) y | • Inclusion: NR | • Duration: on d 5–9 of cycle | • EJ Rates: overall EJ rate after vibratory stimulation: 44% (34/78); by level of injury: cervical 54% (20/37); thoracic above T10 54% (14/26); thoracic below T10 0% (0/15)
| • Level of Injury: cervical 37; thoracic above T10 26; thoracic below T10 15 | • Exclusion: NR (pts with poor semen quality not candidates of assisted fertilization) | • Schedule: NR | • Pregnancy rates: overall pregnancy rate: 63% (17/27)
| • ASIA Level: NR | • Quality Assessment: 7/19 (+) reported | • Device: Electrical stimulator | • Miscarriage/ectopic (n=1)
| • Duration since injury: NR | | • Amplitude: 22 V, max of 420 mA | • Live Births: 20 live births in 14 couples (3 triplets, 2 twins & 9 singletons); one couple is expecting triplets & one -singleton
| • Previous fertility: NR | | • Frequency: 60 Hz | • Singletons: (n=9)
| • Dropouts: 6/33 poor semen quality not candidates of assisted fertilization | | • Mode/Admin. Route | • Multiples: 2 twins, 3 triplets
| • Lost in follow-up: NR | | • Other Device: | • Follow-up: NR
| • N of sites: NR | | • Type: Vibrator oscillation rate of 1800 rmp
| • Funding: NR | | • Manufacturer: NR
| | | • Admin: 3–4 m stimulation 3 × if necessary
| | | • Surgical: NR
| | | • Procedure:
| | | • Bladder catheterization: NR
| | | • Epidydimal aspiration (MESA/PESA): NR
| | | • Testicular biopsy: in 3 pts revealed maturation arrest pattern.
| | | • Behavioural: NR
| | | • Laboratory techniques:
| | | • Donor sperm insemination
| | | • Sperm preparation: NR
| | | • Conception techniques: cervical self-insemination (n=5), IVF & gamete intrafallopian transfer (n=12)
| | | • IVF: for intrauterine insemination with human menopausal gonadotropins. IVF & gamete intrafallopian transfer combined with rectal probe EEJ (before laparoscopic oocyte harvesting or just after trasvaginal ultrasound guided oocyte retrieval. Fertilization assessed at 24 h & uterine transfer accomplished for max of 4 selected embryos 48–72 h post oocyte retrieval
| | | • Embryo cryopreservation: in all excess embryos
| | | • Sperm cryopreservation: ejaculated; biopsy
Matthews, 1996, US | • Enrolled/evaluated: n=40: n=18 SCI; n= 9 retroperitoneal LND; n=9 idiopathic or psychogenic; n=4 diabetes mellitus/ n=33 couples evaluated for conception | • Study Design: NCS | • Pharmacologic: NR | • Outcomes: | • A/E: NR
(Ref ID 563) | • % male: 100%of 40 SCI; 50% of 33 couples | • Duration: NR | • Device: Electrical stimulator | • Measures of Fertility Rates:
| • Race/ethnicity: NR | • Eligibility Criteria: | • Amplitude: NR | • Seminal Parameters: motile sperm recovery rate: 16/18 (89%); mean total motile sperm recovered per rectal probe EEJ (mln): total 360(73); AG 92(19); RG 351(54); RG ejaculate contained Sly more motile sperm (p<0.05); % motility: AG 25(3)%; RG 24(2)%
| • Age: NR | • Inclusion: men with ejaculatory function | • Frequency: NR | • EJ Rates: 94% (17/18)
| • Level of Injury: n=2 cervical; n=15 thoracic; n=1 lumbar | • Exclusion: NR | • Mode/Admin. Route: rectal probe insertion | • Cycle Function: mean total IUI cycles 3.2(0.6); mean intrauterine insemination cycles (pregnancy): 3.0(0.8); % IUI per cycle fecundity=14.3
| • ASIA Level: NR | • Quality Assessment: 9/19 (+) reported | • Other Device: NR | • Pregnancy rates: 45% (5/11)
| • Duration since injury: NR | | • Surgical: NR | • Follow-up: NR
| • Previous fertility: NR | | • Procedure: NR
| • Dropouts: n=0 | | • Behavioural: NR
| • Lost in follow-up: NR | | • Laboratory techniques:
| • N of sites: 1 | | • Sperm preparation; NR
| • Funding: NR | | • Intrauterine insemination: 126 cycles in n=33
| | | • IVF: n=7, total of 14 cycles
| | | • Intracytoplasmic sperm injection: NR
Odum, 1995, Denmark | • Enrolled/evaluated: n=12/ n=12 | • Study Design: NCS | • Pharmacologic: NR | • Outcomes: | • A/E: NR
(Ref ID 1166) | • % male: 100% | • Duration: 12 mo | • Device: Vibrator (n=12) | • Measures of Fertility Rates:
| • Race/ethnicity: NR | • Eligibility Criteria: | • Amplitude: peak to peak 2.5 mm | • Seminal Parameters: (Seminal plasma Somatostatin Concentration: SSC): Marginal SD between SpMot rates in SCI below T6 (0%motile range: 0–30) & SCI at or above T6 (median=16%motile range: 10–37) (p=0.09). A trend towards lower motility in samples with SSC vs. samples without SSC (correlation coefficient =-0.66); normal SSC in lesions below T6; SSC did not correlate with semen volume, SpC, or morphology; type of stimulation (VS vs. ES) did not effect semen quality or SSC
| • Age: NR (21–45) y | • Inclusion: NR | • Frequency: 100 Hz | • Follow-up: every 3 mo for (n=5) resulted in no S dfs in SSC vs. baseline with repeated VE performed at home
| • Level of Injury: C2–T12; n=9 complete, n=3 incomplete | • Exclusion: NR | • Mode/Admin. Route: once wkly for a period between 6–12 mo
| • ASIA Level: NR | • Quality Assessment: 7/19 (+) reported | • Other Device: electrical stimulator
| • Duration since injury: 7 (1–29) y | | • Dose/Frequency: NR
| • Previous fertility: NR | | • Surgical: NR
| • Dropouts: n=0 | | • Behavioural: NR
| • Lost in follow-up: NR | | • Laboratory techniques:
| • N of sites: 1 | | • Donor sperm insemination: NR
| • Funding: Gerda & Aage Haensch's Fond & Danish Biotechnology Center for Neuropeptide Research | | • Sperm preparation: NR
| | | • Plasma extraction (frozen & thawed & proteinase inhibitors added to final concentrations: benxamidine 50 mM, EDTA 0.3 mM, leupeptin 1μM & PMSF 100μ & centrifuged at 2000 G for 20 m
Ohl, 1989, US | • Enrolled/evaluated: n=48 / n=48 | • Study Design: NCS | • Pharmacologic: NR | • Outcomes: | • A/E: NR
(Ref ID 385) | • % male: 100% | • Duration: NR | • Device: Electrical Stimulator | • Measures of Fertility Rates:
| • Race/ethnicity: NR | • Eligibility Criteria: | • Amplitude: 500–600 mA | • Seminal Parameters: average total SpC =765 mln/ml & average total motile SpC =226 mln/ml; predominant forward progression 3+; average SpMot 25%; average N morphological forms 22%; successful EJ rate: 71% (34/48)
| • Age: 31 (20–53) y | • Inclusion: NR | • Frequency: NR | • EJ Rates: Successful EJ rate by type of bladder management: intermittent catheterization: 85%; indwelling urethral catheter 50%; sphincterotomy 50%; spontaneous voiding 38%. Successful EJ rate by level of SCI: thoracic 90%; cervical 60%; lumbar 50%. Successful EJ rate by ASIA: A 77%; B-D 61%
| • Level of Injury: n=15 cervical (31%); n=29 thoracic (61%); n=4 lumbar (8%); (56% complete; 44% incomplete) | • Exclusion: NR | • Mode/Admin. Route: NR | • Follow-up: NR
| • ASIA Level: NR | • Quality Assessment: 4/19 (+) reported | • Other Device: NR
| • Duration since injury: 8 y; (4 mo-34) | | • Surgical: NR
| • Previous fertility: NR | | • Procedure:
| • Dropouts: n=0 | | • Bladder catheterization in (n=48)
| • Lost in follow-up: NR | | • -15–10 ccHamm's F 10 solution with 20 mm Hepes buffer in case of pH 6.5.
| • N of sites: 1 | | • Methods: Intermittent catheterization in 28, Suprapubic tube in 2; Indwelling urethral catheter 2; Sphicterotomy in 8; Spontaneous voiding in8
| • Funding: Supported in part by Eastern Paralyzed Veterans Association | | • Epidydimal aspiration (MESA/PESA)
| | | • Testicular biopsy
| | | • Behavioural: NR
| | | • Laboratory techniques: NR
Ohl, 1992, US | • Enrolled/evaluated: n=38 Neurogenic bladder grps: n=28 SCI & n=1 MS; Normal bladder grp: n=7; Cancer; n=1 diabetic neuropathy; n=1 psychogenic/ n=33 evaluated for conception | • Study Design: NCS | • Pharmacologic: NR | • Outcomes: | • A/E: NR
(Ref ID 649) | • % male: 100% of 38 SCI pts; 50% of couples | • Duration: NR | • Device: Electrical Stimulator (n=38) | • Measures of Fertility Rates:
| • Race/ethnicity: NR | • Eligibility Criteria: | • Amplitude: up to 500 mA | • Seminal Parameters: Effect of bladder management on SpC in NGB grp: In AG of non-ISC grp average total SpC 50% lower but motility & total motile SpC slightly higher than ISC grp. In RG no Δ in SpMot, but average SpC & average total SpC substantially higher in ISC grp. In both AG&RG combined average total motile sperm slightly higher in
| • Age: 31.6 (23–47) y | • Inclusion: NR | • Frequency: NR | • Infection rates: In first EEJ (n=5) semen & urine positive; In second EEJ 7 of 16 urine positive & 6 of 12 semen positive; All positive cultures in neurogenic bladder (NGB) grp
| • Level of Injury: (n=9) cervical, (n=18) thoracic, (n=1) lumbar), | • Exclusion: NR | • Mode/Admin. Route: mean stimulation time, 7–8 m. (bulbous urethra massaged during stimulation) (n=16) underwent second EEJ trial with cultures | • Pregnancy rates: (n=8); 5 in NGB grp (3 thoracic, 2 cervical, 1LMN, 4UMN) & 3 in non-NGB
| • ASIA Level: NR | • Quality Assessment: 6/19 (+) reported | • Other Device: NR | • Follow-up: (artificial insemination)
| • Duration since injury: NR | | • Surgical: NR | • Length: 15–18 mo
| • Previous fertility: NR | | • Procedure (n=29): | • Results: (n=24) in NGB & (n=9) in normal bladder
| • Dropouts: n=0 | | • Bladder catheterization | • Pregnancy rate: 44% for ISC & 7% for other types of bladder management.
| • Lost in follow-up: NR | | • Alkalization: sodium bicarbonate orally at 12 & 1 hr pre procedure to ctrl urinary acidity (EEJ). Type of bladder management: ISC in (n=12), sphincterotomy/condom in (n=5); reflex voiding in (n=8); indwelling urethral catheter in (n=1); suprapubic catheter in (n=2); lleal loop in (n=1)
| • N of sites: 1 | | • Behavioural: NR
| • Funding: Eastern Paralyzed Veterans Association | | • Laboratory techniques: NR
Ohl, 1997, US | • Enrolled/ evaluated: n=11/ n=11 | • Study Design: NCS | • Pharmacologic: NR | • Outcomes: | • A/E: NR
(Ref ID 305) | • % males: 100% | • Duration: NR | • Device: FertiCareclinic Vibrator (n = 5) | • Seminal Parameters: NS in AG SpC in VS vs. ES; greater motility (26.0 vs. 10.7%), viability (25.2 vs. 9.7%) & motile SpC (185 mln vs. 97 mln) in VS; NS in immunobead test, cervical mucus penetration or sperm penetration assay; percent hamster egg penetration S (53.7% for VS vs. 22.1% ES, p=0.06); greater pain scores for ES vs. VS (5.2 vs. 1.7); all pts preferred VS.
| • Race/ethnicity: NR | • Eligibility Criteria: | • Amplitude: 2.5 mm | • Follow-up: NR
| • Age: NR | • Inclusion: NR | • Frequency: 100 Hz
| • Level of Injury: NR | • Exclusion: NR | • Mode/Admin. Route: 3 m of VS or until EJ occurred
| • ASIA Level: NR | • Quality Assessment: 8/19 (+) reported | • Other Device (n = 6): Electrostimulator
| • Duration since injury: NR | | • Type: Seager Model 11 (double dagger) with 1.25 inch probe
| • Previous fertility: NR | | • Manufacturer: NR
| • Drop-outs: n=0 | | • Surgical: NR
| • Lost to follow-up: NR | | • Procedure:
| • Number of sites: 1 | | • Bladder catheterization
| • Funding: NR | | • -with/without alkalinization: without alkalization pre & post tx.
| | | • Epidydimal aspiration (MESA/PESA): NR
| | | • Testicular biopsy: NR
| | | • Behavioural: NR
| | | • Laboratory techniques: NR
Ohl, 2001, US | • Enrolled/ evaluated: n=87 (SCI) | • Study Design: NCS | • Pharmacologic: sublingual nifedipine given to pts above T6 prone to dysrelexia | • Outcomes: 28/87 SCI couples achieved at least one pregnancy | • A/E:
(Ref ID 3059) | • males: 50% | • Duration: NR | • Device: electroejaculation with Seager machine | • Seminal Parameters: NR | • Systemic: NR
| • Race/ethnicity: NR | • Eligibility Criteria: | • Amplitude: NR | • EJ Rates: NR | • Local: NR
| • Age: NR | • Inclusion: NR | • Frequency: NR | • Follow-up: followed to pregnancy or failure
| • Level of Injury: NR | • Exclusion: NR | • Mode/Admin. Route: rectal
| • ASIA Level: NR | • Quality Assessment: 6/19 (+) reported | • Schedule: NR
| • Duration since NR | | • Other Device:
| • Previous fertility: NR | | • Type: catheter to obtain retrograde specimen
| • Drop-outs: n=NR | | • Manufacturer: NR
| • Lost to follow-up: NR | | • Surgical: female partners underwent hysterosalpingography & laparoscopies to exclude structural female infertility
| • Number of sites:1 | | • Behavioural: NA
| • Funding: NR | | • Laboratory techniques: artificial insemination enhanced with gonadotropin therapy, IVF was performed on those who could not conceive & who could afford associated costs
Perkash, 1985, US | • Enrolled/evaluated: n=30/ n=30 | • Study Design: NCS | • Pharmacologic: NR | • Outcomes: | • A/E:
(Ref ID 989) | • % male: 100% | • Duration: NR | • Device: Electrical stimulator (n=30) | • Measures of Fertility Rates: | • Local: (n=8) intolerance of electro stimulation
| • Race/ethnicity: NR | • Eligibility Criteria: | • Amplitude: (Current: stepwise from low to high currents every 2 sec enough to elicit penile tumescence &/or seminal emission0 | • Seminal Parameters: SpC in (n=18)>40 mln. Total SpC in 22 pts>20 mln; SpMor: mean 55%, range 40–75%; Sperm progressive motility <20% in 27 of 35 specimens, no motile in 10 specimens & less than 10% motile in 13, 10–20% motile in 4 & more than 30%motile in 5.
| • Age: 32 (20–47) y | • Inclusion: NR | • Frequency: 20 Hz | • Biopsy: Biopsy specimens (n=13) suggested normal testicular morphology, with tube atrophy & spermatogenesis activity only mildly reduced.
| • Level of Injury: n=27 T2–T12; n=3 L1–L3 | • Exclusion: NR | • Mode/Admin. Route: | • Serum testosterone & luteinizing hormone values Sly higher (p<0.05) in SCI than normal volunteers.
| • ASIA Level: NR | • Quality Assessment: 7/19 (+) reported | • Other Device: NR | • Follow-up: NR
| • Duration since injury: 6.3 (0.3–21.7) y | | • Surgical: NR
| • Previous fertility: NR | | • Procedure:
| • Dropouts: n=8 | | • Bladder catheterization: irrigation with neomycin sulfate-polymyxin B sulfate solution/drainage
| • Lost in follow-up: NR | | • Epidydimal aspiration (MESA/PESA): NR
| • N of sites: 1 | | • Testicular biopsy: (n=13) volunteered with no anesthesia via std surgical procedure
| • Funding: NIMH; base grant from NIH to Yerkes Regional Primate Research Centre of Emory University; & grant from Spinal Cord Research Foundation of the paralyzed veterans of America | | • Serum hormone analysis: (n=30) levels of estradiol-17ß/Follicle-stimulation & luteinizing hormones /Serum prolactin via radioimmunoassay
| | | • Behavioural: NR
| | | • Laboratory techniques: NR
Pryor, 1995, US | • Enrolled/evaluated: n=6/ n=6 | • Study Design: NCS | • Pharmacologic: | • Outcomes: | • A/E: NR
(Ref ID 591) | • % male: 100% | • Duration: NR | • Drug name: in cases 1, 2, & 4 ephedrine (& sodium bicarbonate) | • Measures of Fertility Rates:
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose: 50 mg | • Seminal Parameters: Case 1 ejaculatory vol. AG -1.1ml–3.0 ml, RG10–81 ml. SpC 30.5 mln/ml to 106 mln/ml. Motility<1%–30%, Morphology 16–52% normal; Case 2 AG =. 4–3.2 ml, RG =32.5–110ml.SpC .3 mln/ml to 2,800 mln/ml; Motility 0%–35%; Morphology - 6–10%normal. Case 3 AG 0.7–4.5 ml RG 1.8–78 ml. SpC 50.5 mln/ml; Motility 0–45%; Morphology 9–16% normal; Case 4 AG 0 ml RG 55–125 ml. SpC 0–600 mln/ml; Morphology 24% normal; Case 5 AG vol. 2–20ml RG 60–340ml; Count 1.28 mln/ml-30.5 mln/ml; Motility 25–35%; Morphology 3% normal; Case 6 AG vol. 1 unable to ejaculate 0–3.1 RG vol.28–55; Count .93–13 mln/ml; Motility <10%–70%. Morphology Not available
| • Age: NR (30–36) y | • Inclusion: hx & physical exam, preliminary lab evaluation, informed consent (1 trial of vibratory stimulation to determine seminal parameters, rule out infection & to determine need for sympathomietics) | • Duration: 10 d | • EJ Rates: Case 2–4 EJ; Case 3 – 7 EJ; Case 4– 3 EJ; Case 5–2 EJ & Case 6–4 EJ reported
| • Level of Injury: C4–C7 | • Exclusion: NR | • Schedule: NR | • Ovulation rates: 6 case 1 conceived in 5th cycle, 5/6 normal ovulatory functions. 1/6 irregular ovulatory function
| • ASIA Level: NR | • Quality Assessment: 5/19 (+) reported | • Mode/Admin. Route: NR | • Infection rates: (n=1) UTI
| • Duration since injury: 6–18 y | | • Device: Vibrator (Acuvibe 6002) | • Pregnancy rates: (n=5)
| • Previous fertility: NR | | • Amplitude: NR | • Miscarriage/ectopic: (n=1) at 9 wks gestation
| • Dropouts: n=0 | | • Frequency: Vibrator speed range from 2,800rpm to 4, 29,000rpm | • Live Births: (n=5)
| • Lost in follow-up: NR | | • Mode/Admin. Route: Time from vibrator application to EJ varied from 5–45 m/ stimulation/ rest in 5 m increments for subsequent vibrations | • Follow-up: NR
| • N of sites: 1 | | • Other Device: NR
| • Funding: NR | | • Surgical: NR
| | | • Behavioural: NR
| | | • Laboratory techniques (n=6):
| | | • Sperm preparation
| | | • -swim-up technique
| | | • Intrauterine insemination: in all cases; case 2 partner: imipramine 25 mg t.i.d for 10 d, case 6 & 3 partners put on clomiphene citrate to regulate ovulation cycles
Pryor, 2001, US | • Enrolled/evaluated: 11 couples/ n=11 couples | • Study Design: NCS | • Pharmacologic: | • Outcomes: | • A/E: NR
(Ref ID 439) | • % male: 50% of couples | • Duration: NR | • Drug name/Dose/ Admin: nifedipine to prevent headache & autonomic dysreflexia; 50 mg clomiphene citrate on d 5 through 9 of menstrual cycle to enhance female partner's ovulatory cycle; hCG, 10 000 IU, administered when dominant follicle 15–20 mm & estradiol range of each follicle 200–300 pg/ml)/ Oral sodium bicarbonate | • Measures of Fertility Rates:
| • Race/ethnicity: NR | • Eligibility Criteria: | • Device: Electrical Stimulation | • Seminal Parameters: motile SpC affected by sperm prep technique. Mean no. of progressively motile sperm available for insemination S lower (p<0.005) in protocol 1 (3.3± 0.8), than in protocols 2 & 3 (17.5 ± 6.0 mln & 12.8 ± 5.8) mln).
| • Age: NR | • Inclusion: quadriplegic men with SCI presented at Abbott Injury Fertility Program over 3 y, who desired paternity | • Amplitude: 0–10 V for 1st & 2nd stimulation, 15–29 V, 20–30 V, & 15–20 V for subsequent stimulations | • Pregnancy rates: no pregnancy in protocol 1, 6 out of 10 pregnancies in protocol 2; 2 out of 4 pregnancies in protocol 3
| • Level of Injury: NR | • Exclusion: NR | • Frequency: NR | • Live Births: (n=8/11) (73%)
| • ASIA Level: NR | • Quality Assessment: 10/19 (+) reported | • Mode/Admin. Route: 30 sec stimulation followed by 45 sec rest. Repeated stimulations administered for second time. Following stimulations admin with higher voltages | • Follow-up: NR
| • Duration since injury: NR | | • Other Device: Vibrator
| • Previous fertility: NR | | • Type: Acuvibe 6002
| • Dropouts: n=0 | | • Manufacturer; Brookston
| • Lost in follow-up: NR | | • Surgical: NR
| • N of sites: 1 | | • Procedure:
| • Funding: NR | | • Bladder catheterization: irrigation with Ham's F-10 solution
| | | • -alkalinization by oral sodium bicarbonate solution for 36–48 h
| | | • Epidydimal aspiration (MESA/PESA): NR
| | | • Testicular biopsy: NR
| | | • Behavioural: NR
| | | • Laboratory techniques (n=11 couples):
| | | • Donor sperm insemination: in protocol 2:32–34 h after infection of hCG; in protocol 3: 38–40 h after injection of hCG
| | | • Sperm preparation:
| | | • -swim-up technique in (n=11)
| | | • -sperm WASH in (n=25)
| | | • -density gradient in (n=8)
| | | • -sperm incubation in (n=8)
| | | • Intrauterine insemination: In Protocol 1: 24 h after LG surge detection in non-stimulated cycles (self-monitored by pts); IVF in (n=1)
Rawicki, 1991, Australia | • Enrolled/evaluated: n=39 SCI (& their partners)/ n=38 | • Study Design: NCS | • Pharmacologic: | • Outcomes: | • A/E:
(Ref ID 655) | • % male: 50% of couples | • Duration: 5 y | • Drug name: physostigmine (SP) following admin. of an peripherally actin anticholinergic agent i.e. Buscopan (40 mg i.m.) tx of side effects: “ Labetolol 100mg p.o. or Nifedipine 10 mg p.o. 30 m prior to EJ in event of autonomic dysreflexia (in all C7 or above when BP>40/30; systolic BP>150)” | • Measures of Fertility Rates: | • Systemic: Autonomic Dysreflexia in pts with lesions at or above C7 following EEJ & VE. Superficial trauma resulting in bruising in one man & ulcer in another following VE. Following Superficial Physostigmine (SP) blurring of vision with Buscopan in 4 of 5, nausea & vomiting in 2 of 5, & in 2 of 5 marijuana like highs lasting up to 1 h
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose SP: NR | • EJ Rates: High chance of obtaining semen in men with lesions at T8 or above: AG in (n=18), RG in (n=3); in 3 of 10 SCI T10–12 semen also obtained
| • Age: NR | • Inclusion: Pts recruited since 1985 | • Duration: NR | • Pregnancy rates: 8 pregnancies in 6/15 couples
| • Level of Injury: n=35 C4–L5 | • Exclusion: NR | • Schedule: NR | • Follow-up: NR
| • ASIA Level: NR | • Quality Assessment: 7/19 (+) reported | • Mode/Admin. Route: combined with ES/VS
| • Duration since injury: NR | | • Device: Electrical stimulator
| • Previous fertility: NR | | • Amplitude: 30 V
| • Dropouts: n=0 | | • Frequency: 10 Hz
| • Lost in follow-up: | | • Mode/Admin. Route: through a rectal probe, to stimulate sympathetic nerves to seminal vesicles & ampulla of vas deferens causing semen emission
| • N of sites: 1 | | • Other Device: Vibrator
| • Funding: NR | | • Frequency: 80 Hz
| | | • application: glans of frenulum
| | | • Mode/Admin. Route: in combination with ES & SP
| | | • Surgical: NR
| | | • Procedure: NR
| | | • Behavioural:
| | | • Type: masturbation
| | | • Duration: NR
| | | • Frequency: NR
| | | • Laboratory techniques:
| | | • IVF & donor egg (n=1)
Rutkowski, 1995, Australia | • Enrolled/evaluated: n=70/ n=70 | • Study Design: NCS | • Pharmacologic: NR | • Outcomes: | • A/E: NR
(Ref ID 959) | • % male: 100 % | • Duration: data collection period: 1988-1994 | • Device: Electrical stimulator (n=34) 9/34 failed to ejaculate with VS | • Measures of Fertility Rates:
| • Race/ethnicity: NR | • Eligibility Criteria: | • Amplitude: voltage of 22–30 | • Seminal Parameters: Neurological level (p<0.0072) & method of bladder management (p<0.0115) found to be S predictors of presence or absence of spermatozoa in samples. No df between catheters & non-catheter grp across 3 neurological levels (C1–8, T1–9, & T10 & below)
| • Age: 30 (19–59) y | • Inclusion: SCI pts assessed between 1988-1994 at Royal North for enhancement/fertility issues | • Frequency: 10 or 50 Hz | • Follow-up: NR
| • Level of Injury: n=36 C1–C8; n=19 T1–T9; n=15 T10-L2 | • Exclusion: NR | • Mode/Admin. Route: 3 cycle for duration of 45 s
| • ASIA Level: NR | • Quality Assessment: 9/19 (+) reported | • Other Device: Vibrator (n=36)
| • Duration since injury: 6 (3 mo- 2) y | | • Type: NR
| • Previous fertility: NR | | • Mode/Admin. Route: 3.5 m stimulation with 1 m rest repeated 3 times for lesions above T10
| • Dropouts: n=0 | | • Surgical: NR
| • Lost in follow-up: NR | | • Procedure:
| • N of sites: 1 | | • Bladder catheterization: 3 techniques: Clean intermittent self-catheterization (CISC); indwelling urethral catheter (IDC) or suprapubic catheter (SPC); drainage without a catheter (i.e. voiding by reflex or staining)
| • Funding: NR | | • Behavioural: NR
| | | • Laboratory techniques: NR
Sarkarati, US, 1987 | • Enrolled/evaluated: n=34/ n=34 | • Study Design: NCS | • Pharmacologic: NR | • Outcomes: | • A/E:
(Ref ID 985) | • % male: 100 | • Duration: 5 y | • Device: Vibrator (n=33) | • Measures of Fertility Rates: | • Local: n=4 pain prohibited EEJ.
| • Race/ethnicity: NR | • Eligibility Criteria: | • Amplitude: 1.6–2.4 mm for 3.5 m on, 1.6–2.4 off | • Seminal Parameters: AG semen from VE in (n=7) & from EEJ in (n=8): SpC range 0–250 mln/mL; Semen volume, range 1cc to 7cc in VE vs. 0.5–5 cc in EE; Normal Morphology ranges 7–250 mln in VE vs. 8–220 mln in EE | • Systemic: Minor headache & /or Δ in BP 20–40 mm. Hg) observed n=10 with SCI<6 mo
| • Age: 16–36 y | • Inclusion: NR | • Frequency: 80Hz | • EJ Rates: VE (n=33) resulted in AG in 7 & RG in 1; EEJ resulted in AG in 8 & RG in 9 of 22. No response to VE or EEJ obtained in 5 of 34 & in 4 pain prohibited EEJ.
| • Level of Injury: n=14 C5–6; n=13 T1–9; n =7 T10-L3 | • Exclusion: NR | • Mode/Admin. Route: max of 3–4 cycles | • Follow-up: NR
| • ASIA Level: NR | • Quality Assessment: 10/19 (+) reported | • Other Device: Electrostimulator (n=26)
| • Duration since injury: (n=11)<6 mo | | • Type: Soft silicone glove finger
| • Previous fertility: NR | | • Manufacturer: C.M. & rew 43 L&croft Rd, London, Engl.
| • Dropouts: n=5 | | • Amplitude: 80–90 V
| • Lost in follow-up: | | • Frequency: 15/30 cycle/sec
| • N of sites: 1 | | • Mode/Admin. Route: pain prevented ES in (n=4) (Brindley's technique)
| • Funding: NR | | • Surgical: NR
| | | • Procedure: NR
| | | • Behavioural: NR
| | | • Laboratory techniques: NR
Siösteen 1990, Sweden | • Enrolled/ evaluated: n= 32/ n=33 | • Study Design: NCS | • Pharmacologic: NR | • Outcomes: | • A/E:
(Ref ID 979) | • % males: 100% | • Duration: 6 ms | • Device: Vibrator (Relax/Ling 201) (n = 29) | • Seminal Parameters:4–6 ms of wkly VS in 16/22 pts with AG EJ resulted in a rise of semen volume & of fructose & acid phosphate levels in seminal plasma, suggesting improved function of seminal vesicles & prostate; sperm penetration capacity (SPC) showed strong evidence of long term stimulation effect (normal SPC in 4 pts pre- tx vs. 11 pts post-tx) | • Systemic: headache; rise in BP(tx: repositioning; 6.5 mg dihydralazine)
| • Race/ethnicity: NR | • Eligibility Criteria: | • Amplitude: 1.5 mm/ 2.5 mm | • EJ Rates: AG in 22/32, RG in 7/32; no EJ in 3 pts
| • Age (mean & range of male & partner) | • Inclusion: NR | • Frequency: 100 Hz/ 80 Hz | • Follow-up: NR
| • Level of Injury: C4–L1 | • Exclusion: injury <6 mo | • Mode/Admin. Route: 3.5 m VS -1.5 m rest
| • ASIA Level: NR | • Quality Assessment: 11/19 (+) reported | • Other Device: Electrostimulator (n=3)
| • Duration since injury: 2 (1–23) y | | • Type: NR
| • Previous fertility: NR | | • Voltage: up to 80 V
| • Drop-outs: n=6 | | • Frequency: 15–30 Hz
| • Lost to follow-up: NR | | • Mode/Admin.: obturator nerve site , ES continued for up to 40 sec
| • Number of sites: 1 | | • Surgical: NR
| • Funding: grants from Norrbacka-Eugenia Foundation; National Association of People Disabled by Road Accidents; Poliomeyelitis; Ted Söderlund Foundation; Greta & Einar Asker Foundation | | • Procedure: NR
| | | • Behavioural: NR
| | | • Laboratory techniques: NR
Sonksen, 1994, Denmark | • Enrolled/evaluated: n=66: Population I n=25; Population II n=41/ n=66 | • Study Design: NCS | • Pharmacologic (n=9): | • Outcomes: | • A/E:
(Ref ID 327) | • % male: 100 % | • Duration: NR | • Drug name: glycerine nitrate | • Measures of Fertility Rates: | • Local: NR
| • Race/ethnicity: NR | • Eligibility Criteria: NR | • Dose: 0.5 mg | • Seminal Parameters: | • Systemic: Light headache during AG EJ in (n=4)
| • Age: Population I: 27 (19–42) y, Population II: 29 (18–44) y | • Inclusion: NR | • Duration: NR | • EJ Rates: in (n=58) of 66 (88%): AG response in PVS: 62%, RG response in PVS: 26%, no EJ in (n=8). No relation between level of cord lesion, completeness, & stimulation time required to obtain AG EJ. No relation between EJ response & completeness of cord lesion, age or y since lesion.
| • Level of Injury: Pop I - C3–L1, Pop II - C2–L1:(total of n=44 with complete lesion) | • Exclusion: NR | • Schedule: NR | • Follow-up: NR
| • ASIA Level: NR | • Quality Assessment: 9/19 (+) reported | • Mode/Admin. Route: sublingually
| • Duration since injury: Pop I: Range 0.6–39 y, Pop II: Range 0.2–27 y | | • Device: Vibrator A
| • Previous fertility: NR | | • Amplitude: 0–10 mm peak to peak
| • Dropouts: n=0 | | • Frequency: 0–120 Hz
| • Lost in follow-up: NR | | • Mode/Admin. Route: vibrator held steady against frelunum for max of 3 m & 1 m rest. Cycle repeated for max of 6 times (6 cycle completed for all pts)
| • N of sites: 1 | | • Other Device: Vibrator B
| • Funding: NR | | • Amplitude: 1.5 mm peak to peak
| | | • Frequency: stationary at 100 Hz
| | | • Mode/Admin. Route: same as vibrator A
| | | • Surgical: NR
| | | • Procedure: NR
| | | • Behavioural: NR
| | | • Laboratory techniques: NR
Sonksen, 1997, Denmark | • Enrolled/evaluated: n=28 couples/ n=28 couples | • Study Design: NCS | • Pharmacologic: | • Outcomes: | • A/E: NR
(Ref ID 531) | • % male: 50 % of couples | • Duration: NR | • Drug name: (SCI >T6) nifedipine | • Measures of Fertility Rates:
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose: 10 mg | • Seminal Parameters: total SpC: median 65 mln, range 0.1–480 mln; sperm concentration: median 43 mln, range 0.2–120 mln; SpMot: median 13%, range 1%–60%; Sperm normal morphology: median 34%, range 15–55%
| • Age: men: 31(24–42) y, female partners: 29 (19–39) y | • Inclusion: NR | • Duration: NR | • EJ Rates: 79% with PVS & 21% with EEJ
| • Level of Injury: C2–L4; (n=26 above T10) | • Exclusion: NR | • Schedule: 15 m pre PVS & EEJ | • Pregnancy rates: 35.7% (10/28)
| • ASIA Level: NR | • Quality Assessment: 9/19 (+) reported | • Mode/Admin. Route: 15 m prior to PVS or EEJ (prevention of autonomic dysreflexia) | • Miscarriage/ectopic: none
| • Duration since injury: 8 (1–22) y | | • Device: Electrostimulator | • Induced abortion: none
| • Previous fertility: NR | | • Amplitude: max voltage 30 V | • Live Births: (n=9)
| • Dropouts: n=0 | | • Frequency: 600 mA | • Singletons: (n=7)
| • Lost in follow-up: NR | | • Mode/Admin. Route: median total n of 20 stimulation (range, 16–28) | • Multiples: 1 set of twins
| • N of sites: 1 | | • Other Device: Vibrator | • Follow-up: 16 couples performed home PVS & vaginal self-insemination. Four couples achieved pregnancy with delivery of four babies
| • Funding: NR | | • Frequency: NR | • Length: 2 y
| | | • Mode/ Admin. Route: stimulation periods of up to 3 m & 2 m rest for up to 6 cycles
| | | • Surgical: NR
| | | • Procedure:
| | | • Bladder catheterization
| | | • with 10 mL of a sperm-friendly medium via a 14 F silicone catheter pre/post EEJ
| | | • Epidydimal aspiration (MESA/PESA): NR
| | | • Testicular biopsy: NR
| | | • Behavioural: NR
| | | • Laboratory techniques:
| | | • Donor sperm insemination
| | | • Sperm preparation: NR
| | | • Intrauterine insemination: in (n=3); 38 h following hCG injection. In these cases clomiphene citrate admin. 50–100 mg /d, on d 3 to 7 of cycle
| | | • IVF: in (n=1) treated with gonadotropin-releasing hormone (Gn-RG) analogue buserelin, followed by stimulation of human menopausal gonadotropins
| | | • Intracytoplasmic sperm injection; in 2 (drug admin. as IVF)
| | | • Self-insemination: in (n=4)
Taylor, 1999, Australia | • Enrolled/evaluated: n=19 couples/ n=19 couples | • Study Design: NCS | • Pharmacologic: NR | • Outcomes: | • A/E: NR
(Ref ID 500) | • % male: 50% of couples | • Duration: NR | • Device: Vibrator (n=19) | • Measures of Fertility Rates:
| • Race/ethnicity: NR | • Eligibility Criteria: | • Amplitude: NR | • Seminal Parameters: SpMot recorded as poor in SCI period of 1–24 y & consistently low 18 y post SCI
| • Age: NR (24–44) y | • Inclusion: NR | • Frequency: NR | • Pregnancy rates: per tx cycle in pts having; Intrauterine insemination 12% (11/92); gamete intra-Fallopian transfer 38.9% (8/18); intracytoplasmic sperm injection 19.2% (5/21). Success rate higher in SCI ≥ 10 y, 20/23 (87%) compare to rate of 22% in SCI ≤ 10 y
| • Level of Injury: n=9 C4–C6; n=10 T4–T12/L1 | • Exclusion: NR | • Mode/Admin. Route: NR | • Follow-up: NR
| • ASIA Level: NR | • Quality Assessment: 7/19 (+) reported | • Other Device: Electrostimulator (n=10)
| • Duration since injury: 9.3 (1–24) y | | • Type: NR
| • Previous fertility: NR | | • Manufacturer: NR
| • Dropouts: n=0 | | • Surgical: NR
| • Lost in follow-up: NR | | • Procedure:
| • N of sites: 1 | | • Bladder catheterization
| • Funding: NR | | • -with instilling of 20 mL phosphate buffered Tyrode tissue culture medium pre EEJ
| | | • Epidydimal aspiration (MESA/PESA): NR
| | | • Testicular biopsy: NR
| | | • Behavioural: NR
| | | • Laboratory techniques:
| | | • Donor sperm insemination
| | | • Sperm preparation
| | | • - wash in (n=14)
| | | • - DG in 15
| | | • Intrauterine insemination: (1st tx) in 15 couples by daily monitoring of serum LE hormone; multiple attempts in all but 1
| | | • IVF & embryo transfer: in cases with poor SpC (n=1)
| | | • Intracytoplasmic sperm injection: in 8 couples other methods had failed due poor sperm quality.
| | | • GIFT: (2nd choice) in 7 couples
VerVoort, 1988, US | • Enrolled/evaluated: n=7/ n=7 | • Study Design: NCS | • Pharmacologic (n=6): | • Outcomes: | • A/E: NR
(Ref ID 982) | • % male: 100% | • Duration: NR | • Drug name: Nifedipine | • Measures of Fertility Rates:
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose: 10 mg | • EJ Rates: Repeat EEJ attempts performed at least 2 wks apart. EEJ (AG or RG) in 3 of 9 (33%) without nifedipine, & 19 of 22 (86.4%) with nifedipine
| • Age: 29 (21–38) y | • Inclusion: BP elevation during EEJ | • Duration: NR | • Additional Outcome: S increase in mean maximum current delivered without nifedipine (367±112) mA vs. with nifedipine 172±69 mA, (p<0.05); Increase in current delivery resulted in greater success at sperm collection
| • Level of Injury: C4–C7 | • Exclusion: NR | • Schedule: 10–15 m pre EEJ | • Follow-up: NR
| • ASIA Level: A-C(no designation) | • Quality Assessment: 10/19 (+) reported | • Mode/Admin. Route: NR
| • Duration since injury: 8.8 (0.5–19) y | | • Device: Electrostimulator (n=6)
| • Previous fertility: NR | | • Amplitude: without medication 125–300 mA; with medication: 175–500 mA
| • Dropouts: n=1 | | • Frequency
| • Lost in follow-up: NR | | • Mode/Admin. Route
| • N of sites: 1 | | • Other Device: NR
| • Funding: NIDRR & PMRERF | | • Surgical: NR
| | | • Procedure: NR
| | | • Behavioural: NR
| | | • Laboratory techniques: NR
Wang, 1992 Taiwan | • Enrolled/ evaluated: n=25/ n=25 | • Study Design: NCS | • Pharmacologic: NR | • Outcomes: | • A/E:
(Ref ID 973) | • % males: 100% | • Duration: Aug 1990- May 1991, prospective study | • Device: Electrostimulator(Seager Model) (n = 25) | • Seminal Parameters: SpMot <5% in most cases; no motile spermatozoa in 6/21; no S correlation in sperm quality & quantity with method of bladder management, age, level of injury or injury period; improved sperm analysis in 14/21 in later attempts of ES | • Local: 4/25 (1, T11; 3, T12) local pain during ES
| • Race/ethnicity: NR | • Eligibility Criteria: | • Amplitude: 434±54 mA/ 21.7±2.7 V(15–25 V) | • EJ Rates: 21/25; RG in 12/21; pure AG in 9/21; | • Systemic: autonomic dysreflexia in 2/25 (10 mg sulingual nifedipine); mild rectal edema in 2/25; petechia in 3/25
| • Age: 31(19–43) y | • Inclusion: NR | • Frequency: max of 60 stimulations | • Infection rates: all pts had at least one episode/yr of UTI
| • Level of Injury: C5–T12 (all complete) | • Exclusion: NR | • Mode/Admin. Route: rectal probe; left lateral ducubitus position | • Follow-up:
| • ASIA Level: NR | • Quality Assessment: 11/19 (+) reported | • Other Device: NR | • Length: wkly stimulation
| • Duration since injury: 6 (0.3–14) y | | • Surgical: NR | • Duration: NR
| • Previous fertility: NR | | • Procedure (n=25): | • Results: in 19 occasions weekly ES resulted in deterioration of sperm quality (SpC reduction of 52±23%, total motile SpC reduced by 61± 27%)
| • Drop-outs: n=0 | | • Bladder catheterization
| • Lost to follow-up: NR | | • -with/without alkalinization: blastic catheter & instillation with 20 mL ham's F-10 solution
| • Number of sites: 1 | | • Epidydimal aspiration (MESA/PESA): NR
| • Funding: NR | | • Testicular biopsy: NR
| | | • Behavioural: NR
| | | • Laboratory techniques: NR
Warner, 1986, US | • Enrolled/ evaluated: n=31/n=31 | • Study Design: NCS | • Pharmacologic: NR | • Outcomes: | • A/E: NR
(Ref ID 1339) | • % males: 100% | • Duration: NR | • Device: Electrical stimulator Model 3(n = 31) | • Measures of Fertility Rates: NR
| • Race/ethnicity: NR | • Eligibility Criteria: | • Amplitude: NR | • Seminal Parameters: NR
| • Age: NR | • Inclusion: NR | • Frequency: up to 100 Hz | • EJ Rates: 22/31 tolerated current of 160–200 mA sufficient to induce erection; 14/22 AG; 7/22 RG only; 9/22 RG+AG (2/22 no emission)
| • Level of Injury: T2-L3 | • Exclusion: NR | • Current: 160–200 mA (0.29–0.36 mA/mm2) | • Erection: 2/22 no erection with emission; 1/22 erection with no emission & 1/22 produced neither; 16/22 produced both erection& emission.
| • ASIA Level: NR | • Quality Assessment: 3/19 (+) reported | • Mode/Admin. Route: rectal probe ES; semen collected by Foley catheter | • Pregnancy rates: NR
| • Duration since injury: NR | | • Other Device: NR | • Live Births: NR
| • Previous fertility: NR | | • Surgical: NR | • Follow-up: NR
| • Drop-outs: (n=9) intolerant to ES | | • Procedure: NR
| • Lost to follow-up: NR | | • Behavioural: NR
| • Number of sites: 1 | | • Laboratory techniques: NR
| • Funding: NR

SCI = spinal cord injury; AB = able-bodied; NR = not reported; NA = not applicable; y = year; d = day; mo = month; wk = week; m = minute; hrs = hours; ctrl = control(s); grp = group; pbo = placebo; NCS = non-comparative case series; mA = milliamphere; mg = milligrams; μg = microgram; V = volts; Hz = hertz; mln = millions; tx = treatment; hx = history; Δ = change; S = significant; NS = nonsignificant; df(s) = difference(s); pts = participants; n = n of participants; enrolled = n qualified; evaluated = n analyzed; t.i.d = three times daily; b.i.d = two times daily; (+) = positive; (-) negative; A/E = adverse event; EJ = EJ; SpC = sperm count; SpMot = sperm motility; SpMor = sperm morphology; VS = vibratory stimulation; ES = electrical stimulation; IVF = in vitro fertilization; AG = antegrade; RG = retrograde; EJ = ejaculation; AIH = articficial insemination from husband; AIH = artificial insemination from husband; BP = blood pressure; EEJ = electro ejaculation; EEJ = electroejaculation; FSH = follicle-stimulating hormone; LH = luteinizing hormone; NIDRR = National Institute of Disability Research & Rehabilitation; MRC = medical research council; NIDRR = National Institute on Disability Research & Rehabilitation; NIDRR = National Institute on Disability & Rehabilitation Research; PMRERF = Physical Medicine & Rehabilitation Education & Research Foundation; NIH = National Institute of Health; NIMH = National Institutes of Mental Health; NIH = Nation Institute of Health; PCS = physostigmine; ISN = intrathecal neostigmine; UTI = urinary tract infection; RG = retrogradeEEJ = electro ejaculation; s = seconds; POC = polycystic ovary syndrome; MS = multiple sclerosis; IUI = intra-uterine insemination

Evidence Table 2. Case-control studies of fertility rates in patients with SCI

Author, Year, Location | Study Characteristics | Study Design & Duration/Eligibility Criteria/Quality Assessment | Intervention (e.g., Pharmacologic/Device/Behavioural/Surgical/Other) | Outcomes/Follow-up | Adverse Events/Complications
Brackett,1994, US | • Enrolled/ evaluated: total (n=107): SCI n=66; ctrl n=21, non-injured normospermic men; non-injured infertile n=20/ n=NR | • Study Design: Case-control Study | • Pharmacologic: NR | • Outcomes: | • A/E: NR
(Ref ID 1208) | • % male: 100% | • Duration: NR | • Device: (Vibrator Oster) (SCI n=66) | • Measures of Fertility Rates:
| • Race/ethnicity: NR | • Eligibility Criteria: | • Amplitude NR | • Semen analysis: SpC, SpMot & % normal SpMor (AG & RG in SCI / AG in non-injured infertile & normospermic grps.). SpC: lower counts in IC (57.1: 0–75 mln) vs. SCI (231. 0–1 billion)(p < 0.01), & to NC (231.7: 19 mln to 1 billion)(p < 0.02). SpMot: S higher % of SpMot in NC (59.6: 4.6 %, range: 20–92 %) vs. SCI (27.2 +/- 3.7 %, range: 1–70 %)(p < 0.0002), & also vs. IC (26.6 +/- 6.8 %, range: 20–90 %)(p < 0.0005). SpMor: S dfs in SpMor in SCI & NC: SCI (60.7 +/- 3.5 %, range: 20–88 %) vs. NC (70.7 +/- 2.0 %, range: 56–89 %)(p <0.05). No S df between mean SpMor in SCI & IC or IC & NC
| • Age: SCI 30.8 (19–47) y; non-injured. normospermic 26.5 (19–40) y; non-injured. Infertile 34.2 (29–40) y | • Inclusion: healthy | • Frequency NR | • Additional outcomes: Incidence of endocrine outliers: 42% of SCI had 1 or more hormone outliers. Incidence of outliers in SCI of T8 & T10 slightly > vs. SCI of other levels (C1 to C7 - p < 0.01, T1 to T7 - p < 0.01, & T11 to L5 - p< 0.05) - In SCI, SpC slightly & inversely correlated to levels of FSH (r = -0.400, p < 0.02) - IC pts with elevated FSH had SpCs ranging from 0 to 5 mln; Hormone levels: LH levels in SCI (22.1 +/- 2.8 %) slightly lower than IC (23.3 +/- 4.8 %)(p < 0.05); in NC (33.0 +/- 4.5 %), mean did not differ from SCI & IC.
| • Level of Injury: 36% cervical, 56% thoracic, 8% lumbar, 39% quadriplegic (incomplete), 61% paraplegic (43% complete, 57% incomplete) | • Exclusion: presence or absence of pyuria | • Mode/Admin. Route: 5 m vibration & 1 m rest; repeated if no EJ occurred | • Follow-up: NR
| • ASIA Level: NR | • Quality Assessment: 7 * (NOS) | • Other Device (SCI n = 66):
| • Duration since injury: 8.1 (1–25) y | | • Type: Electroejaculator
| • Previous fertility: infertile pts (n=20): abnormal semen analysis due to varicocele, testicular failure, ejaculatory dysfunction & idiopathic infertility. | | • Manufacturer: NR
| • Dropouts: n=0 | | • Surgical: NR
| • Lost in follow-up: NR | | • Procedure (SCI n=66):
| • N of sites: 1 | | • Bladder catheterization with/without alkalinization with 25–50 mL sperm washing medium added to bladder
| • Funding: Miami Project to Cure Paralysis | | • Epidydimal aspiration (MESA/PESA): NR
| | | • Testicular biopsy: NR
| | | • Behavioural (ctrls n=41):
| | | • Type: masterbation
| | | • Duration: NR
| | | • Frequency: NR
| | | • Laboratory techniques (n=107):
| | | • Measurement of serum levels of hormones by radioimmunoassay using Amerlex LH radioimmunoassay kit or by micropartical enzyme immunoassay IMX system (ref range: 4–23 mIU/mL)
Brackett, 1994, US | • Enrolled/ evaluated: n=87 (SCI n=66, non-SCI, ctrl n=21)/ n=87 | • Study Design: Case-control Study | • Pharmacologic: NR | • Outcomes: | • A/E: NR
(Ref ID 1185) | • % male: 100% | • Duration: 25 mo | • Device: (Vibrator & Electrostimulator in (n=66) | • Measures of Fertility Rates:
| • Race/ethnicity: NR | • Eligibility Criteria: | • Amplitude: NR | • Semen analysis: Total SpC similar in SCI & ctrl (mean +/- SEM: 278.9 (67.4) (range: 19.2 mln - 1.1 mln) & 231.4 (53.9) (2.3 mln - 2.0 mln), respectively. Mean SpMot slightly lower in SCI (13.7) (0–55 %) vs. ctrl (61.3) (20–92%); % of normal forms per ejaculate. Slightly lower in SCI (47.2: 20–72%) vs. ctrl (72.4) (56–94%); NS dfs in SpC, SpMot, SpMor in To, Ts, Td (Oral minus Scrotal) of each grp. In each grp, To, Ts & Td each related to serum LH & FSH levels no S; Not generalized scrotal thermoregulatory dysfunction in SCI men, scrotal temperature not appear to contribute to poor semen quality in SCI men & elevated gonadotropin levels not related to elevated scrotal temperatures in SCI men, as reported in non-injured, infertile men.
| • Age: SCI 30.8 (19–47) y; ctrl 26.5 (19–40) y | • Inclusion: good general health in SCI & ctrl no hx of fertility problem SCI >1y post-injury | • Frequency: NR | • Follow-up: NR
| • Level of Injury: 36% cervical, 56% thoracic, & 81% lumbar | • Exclusion: NR | • Mode/Admin. Route: VS: in seated position, applied to penis for 5 m if no EJ, 1 m rest & resumed for additional 5 m
| • ASIA Level: NR | • Quality Assessment: 8 * (NOS) | • Other Device (n=87):
| • Duration since injury: 8.1 (1–25) y | | • Type: Diatek Model 600/ digital oral & scrotal temperature measurements
| • Previous fertility: NR | | • Manufacturer: NR
| • Dropouts: (n=24) | | • Surgical: NR
| • Lost in follow-up: | | • Procedure:
| • N of sites: 1 | | • Bladder catheterization
| • Funding: Miami Project to Cure Paralysis | | • -with/out alkalinization in all SCI using 25–50 mL of sperm washing medium.
| | | • Behavioural:
| | | • Type: self-masturbation following 3–7 d of abstinence
| | | • Laboratory techniques (n=66):
| | | • Donor sperm insemination: NR
| | | • Sperm preparation: NR
| | | Serum hormone measured by radioimmunoassay (RIA) using Amerlez LH RIA kit or microparticle enzyme immunoassay (MEIA) using IMx system.
Brackett, 1997 US | • Enrolled/ evaluated: total n=19; SCI n=10; ctrl n=9/ n=19 | • Study Design: Case-control Study | • Pharmacologic: NR | • Outcomes: | • A/E: NR
(Ref ID 1135) | • % male: 100% | • Duration: NR | • Device: Vibrator (n = 4) | • Measures of Fertility Rates:
| • Race/ethnicity: NR | • Eligibility Criteria: | • Amplitude: NR | Semen analysis: Effect of temperature on sperm characteristics baseline & % decrease in SpMot: S > decrease in SpMot in specimens from SCI vs. ctrls at 4, 6 & 8 hrs vs. time 0. S dfs at all time points at incubated temp. Heat did not affect rate of degradation in motility in ctrl specimens but hastened degradation in motility in specimens of SCI. % decrease in rapid linear SpMot: S > decrease in rapid linear motility in specimens from SCI vs. ctrls at 6 & 8 hrs after collection at room temp., & at all time points at incubated temp. Heat did not slightly affect rate of degradation in rapid linear motility in ctrl specimens. Heat had S effect on specimens from SCI. Decrease in rapid linear motility by 50% within first 2 hrs, & by 8 hrs 0% rapid linear SpMot
| • Age: SCI 33.1 (2.9) y; healthy ctrl 30.3 (1.8) y | • Inclusion: no medication known to affect semen quality taken within 6 mo prior to study; SCI grp > 1 y post injury | • Frequency: NR | • Follow-up: NR
| • Level of Injury: C4–C5 (n=5), T5–T6 (n=4), T12 (n=1) | • Exclusion: NR | • Mode/Admin. Route: NR
| • ASIA Level: NR | • Quality Assessment: 8 * (NOS) | • Other Device (n=6):
| • Duration since injury: 1 (2.4) y | | • Type: Electrostimulator
| • Previous fertility: no hx of infertility in ctrl grp | | • Amplitude: starting at 1 V & increased to an average of 10 V
| • Dropouts: n=0 | | • Surgical (n = x): NR
| • Lost in follow-up: n=19 | | • Penile Implants
| • N of sites: 1 | | • Procedure (n=x): NR
| • Funding: State of Florida Specific Appropriation No. 610 for Spinal Cord Research; Miami Project to Cure Paralysis | | • Bladder catheterization
| | | • -with/without alkalinization: NR
| | | • Epidydimal aspiration (MESA/PESA): NR
| | | • Testicular biopsy: NR
| | | • Behavioural (ctrl n=9):
| | | • Type: masturbation following 3–7 d of abstinence
| | | • Duration: NR
| | | • Frequency: NR
| | | • Laboratory techniques (n=19):
| | | • Sperm preparation: 15–20 m liquification of semen at room temperature. SpMot & viability at time of 0. Specimens then divided into 2 aliquots, 1 at room temp. (23°C) & 1 at body temp. (37°C). SpMot & viability for each at 2, 4, 6 & 8 hrs after time 0)
Hirsch, 1991, US | • Enrolled/ evaluated: n=29: SCI n=14; ctrl n=15/ n=29 | • Study Design: Case-control study | • Pharmacologic: NR | • Outcomes: | • A/E: NR
(Ref ID 976) | • % males: 100% | • Duration: 4–6 mo | • Device: NR | • Measures of Fertility Rates:
| • Race/ethnicity: NR | • Eligibility Criteria: | • Other Device: NR | • Seminal Parameters: SCI pts showed S lower mean SpC & higher Sertoli cell count vs. ctrls (p<0.05). No df in either mean internal tubular diameter or tubular wall thickness noted. No correlation between tubular wall thickness & mean sperm or Sertoli cell count for either grp. Sertoli cell-to-spermatid ratio S > for SCI grp (p<0.0001). Within SCI grp neither micrometric parameters nor Sertoli cell-to-sperm ratio showed any relationship to level, duration, or degree of injury.
| • Age: SCI 28.4 (17–42) y; ctrl 36 (29–51) y | • Inclusion: NR | • Surgical: | • Follow-up: NR
| • Level of Injury: cervical, thoracic, lumbar (not specific) | • Exclusion: NR | • Biopsy
| • ASIA Level: NR | • Quality Assessment: 7 * (NOS) | • Procedure (n=14):
| • Duration since injury: NR | | • Bladder catheterization; NR
| • Previous fertility: SCI 2/14 previous pregnancies pre-injury | | • Epidydimal aspiration (MESA/PESA): NR
| • Drop-outs: n=0 | | • Testicular biopsy: in n=14 tubular diameter & tubular wall thickness measured by AO fialr micrometer eye pieces (Model 426B)
| • Lost to follow-up: 0 | | • Behavioural: NR
| • N of sites: 1 | | • Laboratory techniques:
| • Funding: Regional Spinal Cord Injury Center of the Delaware Valley; NIDRR | | • Donor sperm insemination
| | | • Sperm preparation (swim-up & discontinuous gradient
| | | • Intrauterine insemination
| | | • IVF
| | | • Intracytoplasmic sperm injection
| | | • Embryo cryopreservation
| | | • Sperm cryopreservation: ejaculated & biopsy
Hirsch, 1994, US | • Enrolled/evaluated: n=16: SCI n=10,vasectomized men n=6/ n=16 | • Study Design: Case-control Study | • Pharmacologic: NR | • Outcomes: | • A/E: NR
(Ref ID 965) | • % male: 100% | • Duration: NR | • Device: NR | • Measures of Fertility Rates:
| • Race/ethnicity: NR | • Eligibility Criteria: | • Other Device: NR | • Biopsy results: SpMot & viability measured at 0, 2, 4, 6 & 5 hrs after semen collection. Both anatomical & functional obstruction of male genital tract exerts similar spermatogenic insult. In both cause of neurogenic infertility is more likely to be at post-testicular level. Spermatid/Sertoli cell ratio no S df between grps. Similar values for tubular wall thickness noted in both grps. No S dfs between grps in % of haploid, diploid & tetraploid cells. Mean % of haploid cells in tissue of vasectomized (54.2%) & SCI (47.4%) men comparable
| • Age: 30.1 (5.2) y; ctrl 37.2 (6.7) y | • Inclusion: ctrl grp: within range of age & duration since presence of outcome (infertility) to SCI grp, no hx of infertility | • Surgical: NR | • Follow-up: NR
| • Level of Injury: NR | • Exclusion: NR | • Procedure (n=16):
| • ASIA Level: NR | • Quality Assessment: 4 * (NOS) | • Testicular biopsy: 10 randomly selected round seminiferous tubules analyzed, & mean tubular thickness measured from photomicrographs obtained after magnification with enlargement of print.
| • Duration since injury: 6–8 y | | • Histometric values: mean concentration of late spermatids /tubule; mean ratio of spermatids to Sertoli cells /tubule; tubular wall thickness
| • Previous fertility: n=6 vasactomized men (mean interval for vasectomy (8.8) y | | • Behavioural: NR
| • Dropouts: n=0 | | • Laboratory techniques:
| • Lost in follow-up: NR | | • DNA flow cytometric analysis
| • N of sites: 1
| • Funding: Regional Spinal Cord Injury Center of the Delaware Valley; NIDRR
Hou 1995, US | • Enrolled/evaluated: n=116: SCI n=12; non-SCI n=104/ n=NR | • Study Design: Case-control Study | • Pharmacologic: NR | • Outcomes: | • A/E: NR
(Ref ID 1180) | • % male: 100% | • Duration: NR | • Device: Vibrator | • Measures of Fertility Rates:
| • Race/ethnicity: NR | • Eligibility Criteria: | • Amplitude: NR | • Semen analysis: % SpMot & % normal SpMor from SCI (36.5 +/- 6.8, 44.0 +/- 2.4) men slightly poorer than those from non-SCI men 70.5 (1.2), 50.8 (0.7) (p < 0.01); % of spermatozoa unstained by Aniline Blue not slightly different in non-SCI men 83.4 (1.1 %) vs. SCI men 79.7 (4.8 %)
| • Age: NR | • Inclusion: NR | • Frequency: NR | • Follow-up: NR
| • Level of Injury: NR | • Exclusion: NR | • Mode/Admin. Route: NR
| • ASIA Level: NR | • Quality Assessment: 5 * (NOS) | • Other Device: NR
| • Duration since injury: NR | | • Surgical: NR
| • Previous fertility: NR | | • Procedure: NR
| • Dropouts: NR | | • Behavioural (n = 104):
| • Lost in follow-up: NR | | • Type: self- masturbation
| • N of sites: 1 | | • Duration: NR
| • Funding: Dr. Ralph & Marion C. Falk Medical Trust | | • Frequency: NR
| | | • Laboratory techniques (n=116):
| | | • Sperm preparation: Aniline Blue Staining
Martin 1983, US | • Enrolled/evaluated: n=20: SCI n=8; ctrl n=12/ n=20 | • Study Design: Case-control Study | • Pharmocologic: NR | • Outcomes: | • A/E: NR
(Ref ID 1406) | • % male: 100% | • Duration: NR | • Device: Rectal Probe Electrostimulator | • Measures of Fertility Rates:
| • Race/ethnicity: NR | • Eligibility Criteria: | • Amplitude | • Erection: Erection elicited repeatedly in only 1 of intact pts, & no seminal emissions or EJs occurred. Use of 60 Hz & 20 Hz currents ineffective in eliciting erection & mean maximally tolerable current level for these frequencies, respectively, 29mA & 29 mA. Repositioning of probe ineffective in initiation of erection during stimulation
| • Age: SCI NR (24–41) y; ctrl NR (23–26) y | • Inclusion: NR | • Frequency: 60 Hz, 20 Hz, & 0.25 Hz | • Follow-up: NR
| • Level of Injury: T3–T12 (n=3) T12-L1 (n=2) L2 n=1 | • Exclusion: NR | • Mode/Admin. Route: dorsal lithotomy position (after bowel movement) intact subjects & 1st 5 pts controlled current delivery by themselves
| • ASIA Level: NR | • Quality Assessment: 4 * (NOS) | • Other Device: NR
| • Duration since injury: (1–20) y | | • Surgical: NR
| • Previous fertility: NR | | • Procedure: NR
| • Dropouts: n=0 | | • Behavioural: NR
| • Lost in follow-up: NR | | • Laboratory techniques: NR
| • N of sites: 1
| • Funding: NIMH
Monga, 2001, US | • Enrolled/evaluated: 7 SCI; 5 ctrls/NR | • Study Design: Case-control Study | • Pharmacologic: NR | • Outcomes: | • A/E: NR
(Ref ID 947) | • % males: 100% male | • Duration: NR | • Device: FERTI CARE Vibrator (6/7 SCI) | • Seminal Parameters: Semen samples from men with SCI showed azoospermia (n=3) & severe asthenospermia (n=2). Majority (65%) of sperm from asthenospermic samples showed degenerative Δs & S axonemal defects. Incubation of normal sperm with SCI seminal plasma induced concentration-dependent decrease in SpMot (43%) accompanied by S drop in intracellular ATP content (33%).
| • Race/ethnicity: NR | • Eligibility Criteria: | • Amplitude: 2.5 mm | • Follow-up: NR
| • Age: (27–54) y | • Inclusion: NR | • Frequency: 100 Hz
| • Level of Injury: all cervical (n=5 incomplete lesion) | • Exclusion: NR | • Mode/Admin. Route: NR
| • ASIA Level: NR | • Quality Assessment: 5 * (NOS) | • Other Device: NR
| • Duration since injury: (5–31) y | | • Surgical:
| • Previous fertility: NR | | • Penile Implants
| • Drop-outs: n=0 | | • Procedure (n=7):
| • Lost to follow-up: 0 | | • Bladder catheterization
| • N of sites: 1 | | • - without alkalinization
| • Funding: American Paraplegia Society grant | | • Behavioural (n = 5 ctrl, n=1 SCI):
| | | • Type: masturbation
| | | • Duration: NR
| | | • Frequency: NR
| | | • Laboratory techniques: NR
Padron 1994 US | • Enrolled/ evaluated: n= 19: SCI n=9; ctrl n=10/ n=19 | • Study Design: Case-control Study | • Pharmacologic ( in SCI grp): | • Outcomes: | • A/E: NR
(Ref ID 1197) | • % male: 100% | • Duration: NR | • Drug name: nifedipine | • Measures of Fertility Rates:
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose: 30–40 mg | • Semen analysis: Mean % SpMot in fresh & thawed samples for each method of freezing in SCI S lower vs. ctrl pts; mean % SpMot in SCI: 17+/-6.8 mln vs. 210+/-5.4 mln in ctrls (p, 0.05); % drop in SpMot after freezing not S different in SCI & ctrl pts. Freezing by Vapor only superior for retention of motility vs. other methods of freezing. For ctrl pts mean % drop in motility S less with Vapor only vs. two other methods (<p=0.05 & p<0.002). % of sperm with rapid linear motility (%RL) not S different between SCI & ctrl for fresh or thawed samples.
| • Age: SCI 30.2 (1.2) y; ctrl 24.3 (3.6) y | • Inclusion: good health >1 y post injury | • Duration: NR | • Follow-up: NR
| • Level of Injury: NR | • Exclusion: NR | • Schedule: 15 m pre EJ in SCI
| • ASIA Level: NR | • Quality Assessment: 4 * (NOS) | • Mode/Admin. Route: in SCI with hx or autonomic dysreflexia
| • Duration since injury: mean: 6.2 (1.1) y | | • Device: Vibrostimulator (n=5)
| • Previous fertility: NR | | • Amplitude: NR
| • Dropouts: n=0 | | • Frequency: 5 m vibration, repeated if no EJ occurred for 2nd 5 m after 1 m rest period EJ
| • Lost in follow-up: NR | | • Mode/Admin. Route: on frenulum on dorsal aspect for 5 m
| • N of sites: 1 | | • Other Device: Electrical Stimulator (n=4)
| • Funding: Miami Project to Cure Paralysis | | • Type: Seager Model 12
| | | • Manufacturer: National Rehab Hospital, Washington D.C.
| | | • Surgical: NR
| | | • Procedure: NR
| | | • Behavioural (n = 10):
| | | • Type: masturbation
| | | • Duration: NR
| | | • Frequency: NR
| | | • Laboratory techniques (n = 19):
| | | • Sperm cryopreservation: EJ done for all ejaculated samples / freezing using Vapor only; Vapor + liquid nitrogen & liquid nitrogen only.

SCI = spinal cord injury; AB = able-bodied; NR = not reported; NA = not applicable; y = year; d = day; mo = month; wk = week; m = minute; hrs = hours; ctrl = control(s); grp = group; pbo = placebo; NCS = non-comparative case series; mg = milligrams; μg = microgram; tx = treatment; hx = history; Δ = change; S = significant; NS = nonsignificant; df(s) = difference(s); pts = participants; n = n of participants; enrolled = n qualified; evaluated = n analyzed; t.i.d = three times daily; b.i.d = two times daily; (+) = positive; (-) = negative; A/E = adverse event; EJ = ejaculation; SpC = sperm count; SpMot = sperm motility; SpMor = sperm morphology; VS = vibratory stimulation; ES = electrical stimulation; IVF = in vitro fertilization; FSH = follicle-stimulating hormone; LH = luteinizing hormone; AG = antegrade; RG = retrograde; mln = millions; NOS = Newcastle Ottawa Scale; Hz = hertz; mA = milliamps; NIMH = National Institute of Mental Health; NIDRR = National Institute of Disability Research & Rehabilitation; V = volt

Evidence Table 3. Evidence from conference proceedings of fertility rates in patients with SCI

Author, Year, Location | Study Characteristics | Study Design & Duration/Eligibility Criteria/Quality Assessment | Intervention (e.g., Pharmacologic/Device/Behavioural/Surgical/other) | Outcomes/Follow-up | Adverse Events/Complications
Elliott, 2000, ND | • Enrolled/ evaluated: 57/57 | • Study Design: Abstract from conference proceeding - interventional (time series before/after trial) | • Pharmacologic: NR | • Outcomes: | • A/E: NR
(Ref ID 3013) | • % males: 50% of couples | • Duration: NR | • Device: Vibrator (n=26) | • Pregnancy rates: 18/26 (69.2%) in VS grp; 34% in ES grp
| • Race/ethnicity: NR | • Eligibility Criteria: | • Amplitude: NR | • Miscarriage/ectopic: NR
| • Age: NR | • Inclusion: NR | • Frequency: NR | • Live Births: 17/26 in VS grp; 11/29(24%) in ES grp
| • Level of Injury: above T10 | • Exclusion: NR | • Mode/Admin. Route: NR | • Singletons: NR
| • ASIA Level: NR | • Quality Assessment: NA | • Other Device (n=29): Electrostimulator | • Follow-up: NR
| • Duration since injury: NR | | • Type: NR
| • Previous fertility: NR | | • Manufacturer: NR
| • Dropouts: NR | | • Surgical: NR
| • Lost in follow-up: NR | | • Procedure: NR
| • N of sites: 1 | | • Behavioral: NR
| • Funding: NR | | • Laboratory techniques (n=26; VS grp):
| | | • Donor sperm insemination: NR
| | | • Sperm preparation: NR
| | | • Intrauterine insemination: in 20% with/ without medication
| | | • IVF: in 50% of VS cases
| | | • Intracytoplasmic sperm injection: in 30% of VS cases
| | | • Embryo cryopreservation: NR
| | | • Sperm cryopreservation: NR
Loecher-Ernst, 1998, Germany | • Enrolled/ evaluated: n=229/127 couples evaluated for conception | • Study Design: Abstract from conference proceeding - interventional (time series before/after trial) | • Pharmacologic: NR | • Outcomes: | • A/E: NR
(Ref ID 3020) | • % males: 100% | • Duration: NR | • Device: Vibrator | • Measures of Fertility Rates: NR
| • Race/ethnicity: NR | • Criteria Eligibility: | • Amplitude: NR | • Seminal Parameters: reduced motility & divergence in sperm count in all ejaculates; quality not improved with repeated stimulation; ES resulted in lower quality semen
| • Age: NR | • Inclusion: NR | • Frequency: NR | • Ejaculation Rates: semen was retrieved in 168/229 (73%); 161/168(96%) with VS; 7/168(4%) with ES
| • Level of Injury: NR | • Exclusion: NR | • Mode/Admin. Route: NR | • Pregnancy rates: 52/127 (41%); (82/127 including 2nd pregnancies & twins)
| • ASIA Level: NR | • Quality Assessment: NA | • Other Device: Electrostimulator | • Miscarriage/ectopic: 19/82 (1twin)
| • Duration since injury: NR | | • Type: NR | • Induced abortion: NR
| • Previous fertility: NR | | • Manufacturer: NR | • Live Births: rate NR; 63 healthy children including 2nd babies
| • Drop-outs: NR | | • Surgical: NR | • Singletons: 63 including 2nd babies
| • Lost in follow-up: NR | | • Procedure: NR | • Multiples: 5 sets of twins
| • N of sites: NR | | • Behavioral: NR | • Follow-up: NR
| • Funding: NR | | • Laboratory techniques:
| | | • Donor sperm insemination: NR
| | | • Sperm preparation: NR
| | | • Intrauterine insemination+ VS at home: in 28 couples
| | | • IVF: 8 couples
| | | • Implantation of alloplastic spermatocele: 27 cases
| | | • Embryo cryopreservation: NR
| | | • Sperm cryopreservation: NR
Seager, 2000, ND | • Enrolled/ evaluated: total n=565:n=460 SCI; n=105 other& 2^nd^ grp of 16 couples with SCI prior to puberty evaluated for conception/ n=565 & 16 couples | • Study Design: Abstract from conference proceeding - interventional (time series before/after trial) | • Pharmacologic: NR | • Outcomes: | • A/E: NR
(Ref ID 3012) | • % males: 100% | • Duration: NR | • Device: Seager Electrostimulatror (n=460 SCI; n=105 other) | • Measures of Fertility Rates: 2nd grp of SCI, 15/16 had sperm in ejaculate & fertility potential similar to SCI post-puberty
| • Race/ethnicity: NR | • Eligibility Criteria: | • Amplitude: 200 mamp; range 100–700 mamp/ 9 V | • Seminal Parameters: NR
| • Age 32.1 (16–61) y | • Inclusion: NR | • Frequency: NR | • Ejaculation Rates: success rate expectancy by authors, 100%
| • Level of Injury: NR | • Exclusion: NR | • Mode/Admin. Route: NR | • Follow-up: NR
| • ASIA Level: ANR | • Quality Assessment: NA | • Other Device: NR
| • Duration since injury: NR | | • Surgical: NR
| • Previous fertility: NR | | • Procedure: NR
| • Dropouts: NR | | • Behavioral: NR
| • Lost in follow-up: NR | | • Laboratory techniques: NR
| • N of sites: 1
| • Funding: NR
Park, 1999, Korea | • Enrolled/ evaluated: n=17/ n=17 | • Study Design: Abstract from conference proceeding - interventional (time series before/after trial) | • Pharmacologic: NR | • Outcomes: | • A/E: NR
(Ref ID 3002) | • % males: 100% | • Duration: NR | • Device: Ferticare Vibrator (n=17) | • Measures of Fertility Rates: rate of adequate sperm quality in lesions above T10 81.8% in vs. & 66.7% in ES; in lesions T10 & below, 82.6% in ES (rate for VS is NR)
| • Race/ethnicity: NR | • Eligibility Criteria: | • Amplitude: NR | • Seminal Parameters: Sperm quality not improved with repeated EJ.
| • Age: NR | • Inclusion: NR | • Frequency: NR | • Ejaculation Rates: 100% in ES, in lesions above T10 91.7%, in lesions at or below T10, NR
| • Level of Injury: above & below T10 | • Exclusion: NR | • Mode/Admin. Route: 3 times/ wk | • Pregnancy rates: NR
| • ASIA Level: NR | • Quality Assessment: NA | • Other Device (n = 17): Electrostimulator | • Follow-up: NR
| • Duration since injury: NR | | • Type: Seager
| • Previous fertility: NR | | • Manufacturer: NR
| • Dropouts: NR | | • Mode/Admin. Route: 3 times/ wk
| • Lost in follow-up: NR | | • Surgical: NR
| • N of sites:1 | | • Procedure: NR
| • Funding: NR | | • Behavioral: NR
| | | • Laboratory techniques: NR

SCI = spinal cord injury; AB = able-bodied; NR = not reported; NA = not applicable; y = year; d = day; mo = month; wk = week; hrs = hours; m = minute; ctrl = control(s); grp = group; pbo = placebo; μg = microgram; mg = milligrams; tx = treatment; hx = history; Δ = change; S = significant; NS = nonsignificant; df(s) = difference(s); pts = participants; n = n of participants; enrolled = n qualified; evaluated = n analyzed; A/E = adverse event; EJ = ejaculation; SpC = sperm count; SpMot = sperm motility; SpMor = sperm morphology; VS = vibratory stimulation; ES = electrical stimulation; mln = millions; AG = antegrade; RG = retrograde; IVF = in vitro fertilization

Evidence Table 4. RCT evidence of sildenafil & other remediation for the treatment of sexual dysfunction in individuals after SCI

Author, Year, Location | Study Characteristics | Study Design & Duration/Quality Assessment/Eligibility Criteria | Intervention (e.g.,Pharmacologic/Device/Behavioral/Surgical/other) | Outcomes/Follow-up | Adverse Events/Complications
Derry, 1998, UK | • Enrolled/evaluated: n=27/n=27 | • Study Design: Part 1:randomised, double-blind, 2 -way cross over design Part 2: randomized, double-blind, parallel-grp design | • Pharmacologic (n=27): | • Outcomes: | • A/E: NR
(Ref ID 58) | • % males: 100% | • Duration: 28 d | • Drug name: sildenafil | • Anatomic/Physiologic: After 28 d of tx., 9/12 pts (75%) on sildenafil & 1/14 pts (7%) on pbo reported that tx improved erections (p=0.0043). 8/12 pts (67%) on sildenafil & 2/13 pts (15%) on pbo wanted to continue tx (p=0.018)
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose: 50 mg | • Psychological: questions assessing satisfaction with sex life demonstrated S df with pts receiving sildenafil > pbo (p=0.0122).
| • Age: NR (21–49) y | • Inclusion: 1. documented hx of SCI ≥6 mo, 2. female partner, 3. ED solely attributable to SCI, 4. ability to achieve grade, reflexogenic erectile response, 5. pts must stop self intracavernous injections 1 wk pre screening | • Duration: 28 d | • Sexual Satisfaction: S improvement in sexual satisfaction reported by pts taking sildenafil (p=0.012)
| • Level of Injury: T6-L5 | • Exclusion: T5 level or above genital anatomic deformities causing penile ED hypotension <80/50, stroke, subarahnoid haemorrhage, bleeding disorder, peptic ulcer disorder, nitrate or anticoagulant use, excessive alcohol use, clinical depression | • Schedule: NR | • Additional Outcomes: oral sildenafil (not > 1 × d) S improves quality of erections & satisfaction with sex life in men with SCI & ED between T6 & L5
| • ASIA Level: Sildenafil grp, A n=8; B n=2; C n=2; D n=1; pbo grp, A n=6; B n=1; C n=3; D n=4 | • Quality Assessment: 3/5 Jadad scale | • Mode/Admin. Route max 1 dose / d | • Follow-up: NR
| • Duration since injury: ≥6 mo | | • Device: Vibrator (n=27)
| • Drop-outs: n=2 | | • Amplitude: NR
| • Lost in Follow-up: NR | | • Frequency: NR
| • N of sites: 3 | | • Mode/Admin. Route: NR
| • Funding: Pfizer | | • Other Device: NR
| | | • Surgical: NR
| | | • Behavioral: NR
Giuliano, 1999, UK | • Enrolled/evaluated: n=178/n=NR | • Study Design: randomized double-blind pbo ctrl cross-over design | • Pharmacologic (n=178): | • Outcomes: | • A/E:
(Ref ID 284) | • % males: 100% | • Duration: 20 wk | • Drug name: sildenafil/ pbo | • IIEF: 83% (168/178) reported improved erections with sildenafil vs. 12% on pbo (p<0.0001) | • Systemic: headache mild or moderate in 25/178 & severe in 5/178; facial flushing in 7%; dyspepsia in 3% & mild & transient visual abnormalities in 2%; 1 withdrawal post-pbo reported due to A/E
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose: 25, 50 or 100 mg of drug/ pbo | • GEQ2: ability to achieve intercourse improved in (132/166) 80% on sildenafil vs. 10% on pbo
| • Age: NR (19–63) y | • Inclusion: SCI men >18 with ED (cause by SCI); SCI >6 mo | • Duration: 6 wk with 2 wk wash out period | • Ability to achieve (p<0.0001)& maintain an erection for intercourse (p<0.0001); satisfaction with sexual intercourse (p<0.0001); frequency of ejaculation (p=0.0012; satisfaction with sexual relationship with partner (p<0.0001) all improved vs. pbo
| • Level of Injury: NR | • Exclusion: NR | • Schedule: approximately 1 hr pre-sex activity | Follow-up: NR
| • ASIA Level: NR | • Quality Assessment: 2/5 Jadad scale | • Mode/Admin. Route: oral
| • Duration since injury: 0.7–38 y | | • Device: NR
| • Drop-outs: 2/178 active phase; 3/178 pbo phase; | | • Other Device: NR
| • Lost to follow-up: NR | | • Surgical: NR
| • N of sites: 1 | | • Behavioral: NR
| • Funding: NR
Hultling, 1999, Sweden | • Enrolled/ evaluated: n=329/n=178 | • Study Design: Part 1: RCT parallel design Part 2: RCT cross-over design | • Pharmacologic (n=209): | • Outcomes: | • A/E: NR
(Ref ID 285) | • % males: 100% | • Duration: 12 wk study duration; washout - 4 wk, done after first 6 wk | • Drug name: sildenafil | • Anatomic/Physiologic: erection: S improvement perceived by partners both in ability to achieve & to maintain erections when taking sildenafil vs. pbo.
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose: 25–100 mg on demand | • Sexual Satisfaction: ability to have intercourse assessed by SCI pts considered improved by 80% of those on sildenafil vs. pbo (effect of 10%). # of attempts at intercourse also much improved in both grp taking sildenafil
| • Age: NR (19–81) y | • Inclusion: NR | • Duration: 4 wk | • Follow-up:
| • Level of Injury: C5-L1 | • Exclusion: NR | • Schedule: NR | • Length: NR
| • ASIA Level: A-D, no designation | • Quality Assessment: 3/5 Jadad scale | • Mode/Admin. Route: NR | • Duration: NR
| • Duration since injury: NR | | • Device: NR | • Results: other results not covered above. sildenafil S improved erectile function in pts with ED of broad-spectrum aetiology & those with ED due to SCI
| • Drop-outs: n=0 | | • Other Device: NR
| • Lost in Follow-up: NR | | • Surgical: NR
| • N of sites: 1 | | • Behavioral: NR
| • Funding: NR
Giuliano, 1999, France | • Enrolled/evaluated: n=178/n=170 | • Study Design: randomized double blind cross over | • Pharmacologic: | • Outcomes: | • A/E:
(Ref ID 49/2049) | • % males: 100% | • Duration: 20 wk: 4 wk run-in phase with no tx, two 6-wk, double-blind, cross over tx separated by 2-wk washout, & 2-wk f/u | • Drug name: sildenafil (n=89, n=85 completed tx)/ pbo (n=89, n=86 completed tx) | • Anatomic/Physiologic: 111/143 SCI with ED (78%) reported improved erections & preferred sildenafil to pbo. 127/168 (76%) including those with no residual erectile function at baseline, showed improved erections. (+) drug effect in 132/166 (80%), pbo effect in 17/166 men (10%). In n= 25 pts with no residual sexual function 16 (64%) had (+) drug effect & all preferred sildenafil to pbo (p<0.001). | • Systemic: pbo grp: n=8 headaches; n=2 flushing; n=1 tx related A/E; n=1 lab test abnormality. sildenafil grp: n=30 headache; n=12 flushing; n=5 dyspepsia; n=5 rhinitis; n=4 abnormal vision; n=3 tx related A/E
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose: initial dose 50 mg of sildenafil up to 100 mg (4 tablets) or adjusted downward to 1 tablet (25 mg). After 6 wk of tx, 4.6%, 36.8%, & 58.6% of pts receiving 25 mg, 50 mg & 100 mg of sildenafil, respectively/or matching pbo. | • Psychological: S drug effect in erection (to achieve & maintain) in reports of IIEF & pts log activity vs. pbo (p<.005). Median proportion of successful intercourse in pts log=55% with sildenafil vs. 0% in pbo (p<0.001)
| • Age: 38 (NR) y | • Inclusion: Men ≥18 y who sustained traumatic SCI at least 6 mo pre screening & with ED solely attributed to SCI. Stable relationship with female partner for 6 mo | • Duration: 38 d for each tx period | • Sexual Satisfaction: discontinuation rate of sildenafil 2% vs. 1% for pbo. When data for all pts (including those with no residual erectile function at baseline) analyzed, at baseline 127/168 (76%) reported improved erections & preference for sildenafil vs. 7/168 (4%) with improved erections & preference for pbo (p<0.001).
| • Level of Injury: NR | • Exclusion: 1. genital/anatomical deformities impeding ED; 2. hx of stroke/ MI or any S CVD within last 6 mo; 3. diabetes, 4.major haematological, renal, or hepatic abnormalities; 5. unwillingness to forego use of vacuum devices, intracavernous injection tx, or other tx for ED during study; 6. concomitant tx with nitrates | • Schedule: 1 hr pre-sex. activity | • Follow-up: NR
| • ASIA Level: A n=95 (53%); B n=20; C n=12; D n=27; n=24 not categorized by ASIA scale | • Quality Assessment: 3/5 Jadad scale | • Mode/Admin. Route:
| • Duration since injury: pbo/sildenafil grp = 10.3 (0.70–35) y; sildenafil/pbo grp 11.7 (0.74–38) y | | • Device: NR
| • Drop-outs: n=8 | | • Surgical: NR
| • Lost in Follow-up: NR | | • Behavioral: NR
| • N of sites: 19
| • Funding: Pfizer
Hultling, 2000, Australia | • Enrolled/evaluated: n=178/n=178 | • Study Design: RCT cross-over design | • Pharmacologic (n=178): | • Outcomes: | • A/E: NR
(Ref ID 281) | • % males: 100% | • Duration: run-in-period: 2–4 wk protocol: 6 wk for each pbo or sildenafil washout period: 2 wk | • Drug name: sildenafil | • Anatomic/Physiologic: NR
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose: upward & downward titration flexible dose of 25 mg 1 hr pre sexual activity (not > 1 × d), increased to maximum of 100 mg, & adjusted 25 mg, respectively for each period. | • Psychological: statistically S (p<0.05) improvements in favour of sildenafil at end of tx seen in 4/10 pts for general mental, physical, & psychosocial parameters. No S dfs in end-of-tx scores between sildenafil & pbo grps for PGWB Index measure of self-ctrl, MOS Family Survey, health vs. 1 y ago, or MOS SF-12 physical summary score.
| • Age: 38 (19–63) y | • Inclusion: ≥ 18 y, traumatic SCI at least 6 mo pre screening, clinical diagnosis of ED caused only by SCI, & involvement in stable relationship with female for at least past 6 mo | • Duration: pts randomized to 2 homogeneous grp receiving pbo & sildenafil in random order. Active, 2–4 wk of run-in-period + 14 wk intervention length (6wk+2wk+6wk); pbo, flexible dose matching dose of sildenafil | • Sexual Satisfaction: S increase in overall satisfaction with sex life (increase of 49% over baseline) & sexual relationship with partner (34% improvement over baseline) with sildenafil > pbo (p<0.0001 for tx effect)
| • Level of Injury: NR | • Exclusion: laboratory abnormalities, genital anatomical deformities, primary sexual disorder other than ED, major psychiatric or psychological disorder, including major depression, diabetes mellitus, hx of stroke or MI within last 6 mo | • Schedule | • Pt logs/diaries/ Other: trend towards higher doses of pbo (4% at 25 mg to 81% at 100 mg) vs. sildenafil (5% at 25 mg to 59%at 100 mg). Erectile problem questionnaire: summary score improved S with sildenafil vs. pbo, percentage of Δ from baseline in pbo (4.5%), vs. 22.5% in sildenafil (p<0.0001)
| • ASIA Level: NR | • Quality Assessment: 2/5 Jadad scale | • Mode/Admin. Route | • Follow-up: NR
| • Duration since injury: 11.7 (0.78) y | | • Device: NR
| • Drop-outs: n=0 | | • Other Device: NR
| • Lost in Follow-up: NR | | • Surgical: NR
| • N of sites: 19 | | • Behavioral: NR
| • Funding: Pfizer
Maytom, 1999, UK | • Enrolled/ evaluated: n=27/n=26 | • Study Design: RCT: cross-over design | • Pharmacologic (n=27): | • Outcomes: | • A/E:
(Ref Id 55) | • % males: 100% | • Duration: study has 2 parts: 1. RCT, double blind two-way cross over & assessed reflexogenic erectile response to PVS after single dose of sildenafil or pbo; 2. randomized, double-blind-pbo controlled parallel-grp evaluation of sildenafil in home setting | • Drug name: sildenafil | • Anatomic/Physiologic: Part 1. 17/26 (65%) had erections of > than 60% rigidity at penile base; Part 2, 9/12 (75%) pts on sildenafil & 1/14 (7%) pts on pbo reported tx improved erections. | • Systemic: sildenafil /pbo: Headache 4/1, dyspepsia 1/0, rash 2/3; anxiety 1/0, dizziness 1/0, vomiting 1/0, rectal disorder 1/0, respiratory tract infection 4 /2, increased cough 0/1, asthenia 0 /1, malaise 0/ 1,fFlu 0/ 1, epididymitis 0/ 1, orchitis 0/ 1. Total events = 15/12.
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose: 50 mg | • Psychological: analysis of diary data showed no df between grps with respect to mean # of erections hard enough for penetration (p=0.08). End of tx questionnaire indicated no S dfs between grps with respect to frequency of erections hard enough for sexual intercourse (p=0.47), or that lasted as long as pt would have liked (p=0.11)
| • Age: NR (21–49) y | • Inclusion: 1. males aged 18–55 y; 2. documented hx of SCI (sustained at least 6 mo prior to screening); 3. female partner; 4. ED solely attributable to SCI; 5. ability to achieve at least grade 2 reflexogenic erectile response to PVS; 6. stable dose of drug therapy 1 mo pre screening | • Duration: 28 d | • Sexual Satisfaction: pts in sildenafil grp more satisfied with their sex life (p=0.001)
| • Level of Injury: T6-L5 | • Exclusion: 1. pts with lesions at or above T5 level; 2. pts with genetic anatomical deformities causing ED; 3. vascular or endocrine causes of ED; 4. postural hypotension, BP <80/50 mmHg; 5. major haematological, renal, hepatic abnormalities; 6. diabetes; 7. hx of stroke, subarachnoid haemorrhage; 8. bleeding disorder; 9. active peptic ulceration; 10. use of nitrates or anticoagulant meds; 11. involvement with an experimental drug within last 3 mo; 12. alcohol use > than 28 units of alcohol per wk; 13. clinical depression | • Schedule: | • Follow-up:
| • ASIA Level: NR | • Quality Assessment: 3/5 Jadad scale | • Mode/Admin. Route: 1 hr pre sexual activity (not to be taken > 1 × d), | • Length: NR
| • Duration since injury: NR | | • Device: NR | • Duration: RN
| • Drop-outs: NR | | • Other Device: NR | • Results: 8/12 (67%) men on sildenafil & 2/13 (15%) on pbo indicated that they wished to continue tx (p<0.02). Mean proportion of successful attempts at sexual intercourse 30% & 15%, respectively (p=0.21).
| • Lost in Follow-up: NR | | • Surgical: NR
| • N of sites: 3 | | • Behavioral: NR
| • Funding: Pfizer
Potter, 1998, Canada, US | • Enrolled/ evaluated: n=29/n=28 | • Study Design: RCT cross-over design | • Pharmacologic (n=29): | • Outcomes: | • A/E:
(Ref Id 1097) | • % males: 97% | • Duration: 4 wk run-in-period; 2 wk drug/pbo; 1 wk washout period | • Drug name: Fampridine-SR | • Psychological: no statistically S benefits of drug on measures of pain or bowel, bladder & sexual function or functional independence. | • Systemic: Mild & transient giddiness or light-headedness at onset of taking drug (n=5)
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose: 12.5 mg b.i.d. for wk 1 & increased to 17.5 mg b.i.d on wk 2. Washout period of 7 d, & pbo with matching dose & titration pattern for next 2 wk | • Sexual Satisfaction: no S effects on sexual function as result of 4-ap. Some improvement in sexual function defined by stronger, more frequent, & more sustained penile erections reported in 5 (19%) following Fampridine-SR vs. 4 (15%) following pbo (p=0.739),
| • Age: Parkwood: 36.6 (26.9–46.4) y; VAMC hospital: 45.6 (37.5–53.7) y | • Inclusion: range 21–65 y, medical diagnosis of incomplete teraplegia/paraplegia made >2 y prior to study, neurological level of injury C4-T12, medically stable & able to breathe independently, & stable neurological deficits for >60 d prior to study. Also exhibition 5 or more of the following: paresis, sensory loss, pain, spasticity, bowel, & bladder of sexual dysfunction. If female, had to be post-menopausal or surgically sterile, or using an acceptable method of birth ctrl. | • Duration: 5 wk | • Follow-up: NR
| • Level of Injury: n=18 C4–7; n=11 T3–12 | • Exclusion: risk of epileptiform seizures, hx of CVD, cancer, diabetes, impaired hepatic or renal function, or S liver disease < 6 mo pre-study or total bilirubin > 2× upper limit of normal range; known allergy to pyridine-containing medicine, infections, neurologic, degenerative or psychiatric disorders to impair completion of protocol or provide informed consent or any illness or abnormality that may jeopardize their safety or interfere with conduct of study. Pts who had received any investigational drug < 30 d prior to study, had hx of substance abuse, unable to discontinue excluded concomitant medications, tx with an antispasticity compound & could not maintain stable daily dosage or had received any drug known to cause S major organ toxicity < 3 mo prior to study, or considered unlikely to complete study also excluded. Also, pregnancy/potential pregnancy, or lactation. | • Schedule: NR
| • ASIA Level: B n=6; C n=12; D n=11 | • Quality Assessment: 3/5 Jadad scale | • Mode/Admin. Route: random assignment to Fampridine-SR or pbo during first period followed by washout period & cross over to receive opposite tx
| • Duration since injury: Parkwood 99.9 (64.0) mo; VAMC: 217.7(111.8) mo | | • Device: NR
| • Drop-outs: n=1 SCI | | • Other Device: NR
| • Lost in Follow-up: NR | | • Surgical: NR
| • N of sites: 2 | | • Behavioral: NR
| • Funding: NR
Renganathan, 1997, India | • Enrolled/ evaluated: n=28/n=28 | • Study Design: RCT cross-over design | • Pharmacologic (n=28): | • Outcomes: | • A/E:
(Ref ID 307) | • % males: 100% | • Duration: NR | • Drug name: transdermal nitro-glycerine vs. intracavernous injection of papaverine | • Anatomic/Physiologic: erectile index compared between 2 grps with statistically S df (p=0.045) in favour of papaverine. Erection occurred in 5 m & subsided after 30–40 m in most pts with injection of paparvarine of 10 mg. Higher doses (20, 40, & 60 mg) maintained erection for longer duration. | • Systemic: mild oedema with papaverine injections; 2. mild headache with nitro-glycerine; 3. prolonged erection > 6 hr
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose: NR | • Follow-up:
| • Age: NR (16–60) y | • Inclusion: SCI with ED | • Duration: NR | • Length: NR
| • Level of Injury: NR | • Exclusion: duration of lesion < 3 mo, age < 16 -> 60 y, active infection, hyposadias, impotence prior to injury | • Schedule: NR | • Duration: NR
| • ASIA Level: NR | • Quality Assessment: 0/5 Jadad scale | • Mode/Admin. Route: NR | • Results: Mean value for erectile index in papaverine grp 164.5 & in nitro-glycerine grp 106.
| • Duration since injury: > 3 mo post SCI | | • Device: NR
| • Drop-outs: n=0 | | • Other Device: NR
| • Lost in Follow-up: NR | | • Surgical: NR
| • N of sites: 1 | | • Behavioral: NR
| • Funding: NR
Sipski, 2000, US | • Enrolled/ evaluated: n=19/n=19 | • Study Design: RCT cross-over | • Pharmacologic (n=19 ): | • Outcomes: | • A/E:
(Ref ID 475) | • % males: 0% (all female) | • Duration: 2 d | • Drug name: sildenafil | • Anatomic/Physiologic: | • Systemic: 1. flushing 4/19 on sildenafil vs. 1/19 on pbo; 2. headache 2/19 on sildenafil vs. 1/19 on pbo; 3. mild vision Δs 2/19 on sildenafil vs. 1/19 on pbo; 4. fatigue 3/19 on pbo vs. 1/19 sildenafil; 5. 1 pts. had pelvic pain on both d. All side effects self-limiting & of brief duration.
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose: 50 mg | • S Δs in VPA (p<.02) with increasing levels of sexual stimulation. Borderline S effect of drug tx (p<0.07) observed, with markedly increased VPA on sildenafil vs. pbo in manual plus visual stimulation condition. Lesser increases observed in visual stimulation alone condition.
| • Age: NR (35–58) y | • Inclusion: 1. non-pregnant women between 7–14 d of last menses (pregnancy test done) | • Duration: NR | • Psychological: S increases in Subjective Arousal (SA) observed with both drug (p<0.01) & sexual stimulation conditions (p=0.001), & borderline S (p<0.07) effect of drug administration on VPA noted. Maximal responses occurred when sildenafil combined with visual stimulation & manual stimulation. Cardiovascular data showed modest increases in HR (+/- 5 BPM) an mild decreases in BP (+/- 4 mmHg) across all stimulation conditions, consistent with peripheral vasodilatory mechanism of drug
| • Level of Injury: 14 women had UMN & 5 had LMN injuries affecting sacral cord | • Exclusion: NR | • Schedule: NR | • Follow-up: NR
| • ASIA Level: NR | • Quality Assessment: 2/5 Jadad scale | • Mode/Admin. Route: NR
| • Duration since injury: 131.47 (15–457) mo | | • Device: NR
| • Drop-outs: n=0 | | • Other Device: NR
| • Lost in Follow-up: NR | | • Surgical: NR
| • N of sites: 1 | | • Behavioral (n=19)
| • Funding: NIH | | • Type: video/visual stimulation
| | | • Duration: NR
| | | • Frequency: NR

SCI = spinal cord injury; AB = able-bodied; NR = not reported; NA = not applicable; y = year; d = day; mo = month; wk = week; hrs = hours; m = minute; cm = centimeters; sec = seconds; mg = milligrams; μg = microgram; ctrl = control(s); grp = group; pbo = placebo; RCT = randomized clinical trial; tx = treatment; hx = history; Δ = change; S = significant; df(s) = difference(s); NS = nonsignificant; pts = participants; n = n of participants; enrolled = n qualified; evaluated = n analyzed; (+) = positive; A/E = Adverse Events; HR = heart rate; BP = blood pressure; t.i.d = three times daily; b.i.d = two times daily; ED = erectile dysfunction; IIEF = Index of Erectile Function; CVD = cardiovascular disease; MI = myocardial infarction; PGWB = psychological general well-being; MOS-SF = Medical Outcome Short-Form Health Survey; UMN = upper motor neuron; LMN = lower motor neuron; NIH = Nation Institute of Health; VPA = vaginal pulse amplitude; BPM = beats per minute; mmHG = millimeters of mercury; mmHG = millimetres of mercury; PVS = penile vibratory stimulation

Evidence Table 5. Evidence from other study designs regarding sildenafil & other remediation for the treatment of sexual dysfunction in individuals after SCI

Author, Year, Location | Study Characteristics | Study Design & Duration/Quality Assessment/ Eligibility Criteria | Intervention (e.g.,Pharmacologic Device// Behavioral/Surgical/other | Outcomes/Follow-up | Adverse Events/Complications
Beretta, 1986, Italy | • Enrolled/ evaluated: n=22/ n=NR | • Study Design: NCS | • Pharmacologic (n=22): | • Outcomes: | • A/E:
(Ref ID 402) | • % males: 100% | • Duration: NR | • Drug name: papaverine | • Anatomic/Physiologic: 20/22 obtained erection with complete rigidity, with mean duration of 4.1 hrs | • Systemic: long lasting pulsatile erection in 7/22, lasting > 5 hrs (controlled by intraglandular injection of ethilefrine & aspirations of corpus)
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose: 20–30 mg | • Sexual Satisfaction: 20/22 successful intercourse
| • Age: NR (18–52) y | • Inclusion: NR | • Duration: NR | • Follow-up:
| • Level of Injury: n=7 above T10–T11; n=10 thoracolumbar; n=5 sacral; n=9 complete; n=13 incomplete lesion | • Exclusion: NR | • Schedule: NR | • Length: 3 mo
| • ASIA Level: NR | • Quality Assessment: 5/19 (+) reported | • Mode/Admin. Route: injection into one of cavernous bodies | • Duration: NR
| • Duration since injury: ≥ 1 y | | • Device: NR | • Results: 20/22 offered training in self-injection; 10/20 accepted self-injection & had coitus 1 × wk for > 3 mo
| • Dropouts: n=0 | | • Other Device: NR
| • Lost to follow-up: NR | | • Surgical: NR
| • N of sites: 1 | | • Behavioral: NR
| • Funding: NR
Beretta, 1993, Italy | • Enrolled/ evaluated: n=15/ n=NR | • Study Design: NCS | • Pharmacologic (n=x): None | • Outcomes: | • A/E:
(Ref ID 339) | • % Males: 100% | • Duration: NR | • Drug name: Prostaglandin E1 injection -2% Minoxidil solution | • Anatomic/Physiologic: | • Systemic: Headache following minoxidil application in 1 subject. No medication required
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose: 1 ml of 2.5–10 micrograms 1 ml 2% minoxidil solution (Regaine-Upjohn) up to 60 ml of 2% minoxidil solution | • n=9 (+) response: 4 with complete & 5 with partial response. n=6 no response, NR, NR, Complete response achieved only in paraplegics with dorsal lesion. No relation between level of lesion & results of minoxidil test
| • Age: 29.4 (20–38) y | • Inclusion: Pts who achieved erection sufficient for vaginal penetration after Prostaglandin E1 injection included | • Duration: NR | • Psychological: NR
| • Level of Injury: n=9 T2–7; n=2 T12-L1; n=4 L1–L5 (n=12 Complete n=3 Incomplete) | • Exclusion: NR | • Schedule: NR | • Sexual Satisfaction: NR
| • ASIA Level: NR | • Quality Assessment: 8/19 (+) reported | • Mode/Admin. Route: (2ml/d) to try at home if complete or partial response to minoxidil achieved | • Pts logs/diaries:
| • Duration since injury: 1.3 (1–2) y | | • Device: NR | • Interviews:
| • Dropouts: n=0 | | • Other Device: | • Follow-up:
| • Lost in follow-up: NR | | • Surgical: NR | • Length: NR
| • N of sites: 1 | | • Behavioral: NR | • Duration: NR
| • Funding: NR | | | • Results: 9 pts with complete or partial response continued to use minoxidil (2ml/d) at home for 1 mo. Result of subjective evaluations based on questionnaires: 26.6%(4 of 9) obtained an erectile response to minoxidil solution sufficient for vaginal penetration. All paraplegic with complete dorsal level who had obtained a complete response during minoxidil test. 3 SCI men chose to use minoxidil vs. prostaglandin E1 injection.
Bodner, 1999, US | • Enrolled/ evaluated: n=15/ n=NR | • Study Design: NCS | • Pharmacological (n=15): | • Outcomes: | • A/E:
(Ref ID 293) | • % Males: 100% | • Duration: NR | • Drug name: intraurethral prostaglandin E1 - MUSE | • Anatomic/Physiologic: all pts required max dose of alprostadil (MUSE, 1000 μg); with intracavernosal injection (papaverine with or without phentolamine) 12/15 achieved grade 1–3 erections, 3/15 achieved grade 4 erections, 15/15 achieved grade 5 erection | • Systemic: n=3 who did not use constricting band experienced transient hypotensive episode of 5–10 m; n=1 transient episode of blood from urethral meatus after inserting MUSE
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose: 125 miug with escalation to 1000 miug | • Psychological: NR
| • Age: 47 (30–70) y | • Inclusion: men with SCI at least 1 y after injury previously treated by intracavernous injection therapy for SD (Previous SD Treatments: n=15: either papaverine or in combination with phentolamine for intracavernous injection therapy) | • Duration: NR | • Sexual Satisfaction: complete satisfaction n=0 with quality of erection using MUSE; n=3 with grade 4 erection after MUSE returned to use of intracavernous injection therapy.
| • Level of Injury: quadriplegia 7;paraplegia 8 (>sacral reflex arc) | • Exclusion: NR | • Schedule: NR | • Pt logs/diaries: NR
| • ASIA Level: NR | • Quality Assessment: 8/19 (+) reported | • Mode/Admin. Route: injection | • Interviews: NR
| • Duration since injury: 7 y | | • Device: NR | • Follow-up: NR
| • Dropouts: n=0 | | • Other Device (n=12 ):
| • Lost in follow-up: NR | | • Type: constricting band on penis with application of MUSE
| • N of sites: 1 | | • Manufacturer: NR
| • Funding: NR | | • Surgical: NR
| | | • Behavioral: NR
Chancellor, 1994, US | • Enrolled/ evaluated: n=18/ n=NR | • Study Design: NCS | • Pharmacologic (n=18): | • Outcomes: | • A/E: NR
(Ref ID 335) | • % Males: 100% | • Duration: NR | • Drug name: 2% minoxidil solution, intracorporeal papaverine injection | • Anatomic/Physiologic: Topical application of minoxidil caused minimun response subjectively & objectively. % of Δ in rigidity: minoxidil tx:0–15%, VCD therapy: 30–80%(median rigidity of 57%), intercorporeal papaverine injection: 30–100%(median 77%). Erectile rigidity S less (p<0.05) with topical minoxidil than with either VCD or papaverine. No S df in rigidity between VCD therapy & papaverine (p=0.34)
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose: 10 mg intracorporeal papaverine | • Psychological: NR
| • Age: 29 (19–65) y | • Inclusion: No ED prior to SCI. Ability to achieve only poorly sustained reflex erection inadequate for intercourse, no hypertension, no previous use of antihypertensive meds & minoxidil orally or topicaly, no prior therapy for ED | • Duration: NR | • Sexual Satisfaction: Topical application of minoxidil caused minimum response subjectively & objectively.% of Δ in rigidity: minoxidil tx:0–15%, VCD therapy: 30–80%(median rigidity of 57%), intercorporeal papaverine injection: 30–100%(median 77%). Erectile rigidity S less (p<0.05) with topical minoxidil than with either VCD or papaverine. No S df in rigidity between VCD therapy & papaverine (p=0.34)
| • Level of Injury: C7–L3, n=15 thoracics | • Exclusion: hx of psychogenic impotence, diabetes mellitus, thyroid, renal, hepatic or vascular disease, myocardial infarction or use of organic nitrates or nitrites | • Schedule: sequential order for each pts, with 15 m interval (or to full detumscence) | • Pts logs/diaries: NR
| • ASIA Level: NR | • Quality Assessment: 8/19 (+) reported | • Mode/Admin. Route: injection of papavarine/ 1 ml of 2% minoxidil solution sprayed onto glans penis | • Interviews: NR
| • Duration since injury: NR | | • Device: NR | • Follow-up: NR
| • Dropouts: n=0 | | • Other Device: NR
| • Lost in follow-up: NR | | • Surgical (n=18)
| • N of sites: 1 | | • Type: VCD
| • Funding: NR | | • Behavioral: NR
Chapelle, 1988, France | • Enrolled/ evaluated: n=135/ n=NR | • Study Design: NCS | • Pharmacological (n=135): | • Outcomes: | • A/E:
(Ref ID 1318) | • % Males: 100% | • Duration: NR | • Drug name: physostigimine+ N- \buthyigyoscine | • Anatomic/Physiologic: relation between testicular vol & SCI in n=86 pts (45 from EJ grp & 41 from ANEJ grp): Mean testicular vol did not differ S from that of ctrl. Testicular vol. slightly lower in ANEJ grp than EJ grp (t= 1.8, not S) Mean testicular vol did not differ S from that of SCI pts & ctrl. The relation between testicular vol & SCI in n=86 pts (45 from EJ grp & 41 from ANEJ grp): Mean testicular vol did not differ S from that of Control. Testicular vol. slightly lower in ANEJ grp than EJ grp (t= 1.8, not S) Mean testicular vol did not differ S from that of SCI pts & ctrl | • Systemic: Autonomic Dysreflexia
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose: 0.2 mg/ 40mg | • Psychological: NR
| • Age: NR (18–47) y | • Inclusion: NR | • Duration: NR | • Sexual Satisfaction: NR
| • Level of Injury: T12-L2 | • Exclusion: urological or medical causes of testicular damage (orchiepididymis, destructive functional tx of lower urinary tract, cryptorchidy & systemic lupus | • Schedule: NR | • Pt logs/diaries: NR
| • ASIA Level: NR | • Quality Assessment: 8/19 (+) reported | • Mode/Admin. Route: intervention consisted of 3 physostigimine tests. Each test = 0.2mgs s/c (in association with 40 mgs N-buthyihyoscine) followed by masturbation | • Interviews: NR
| • Duration since injury: NR (0.5–33) y | | • Device: NR | • Follow-up: NR
| • Dropouts: n=0 | | • Other Device: NR
| • Lost in follow-up: NR | | • Surgical: NR
| • N of sites: 1 | | • Behavioral (n=135)
| • Funding: NR | | • type: masturbation post medication tx
| | | • Duration/Frequency: NR
Costa, 1992, France | • Enrolled/ evaluated: n=26/ n=NR | • Study Design: NCS | • Pharmacologic (n=26): | • Outcomes: | • A/E
(Ref ID 353) | • % Males: 100% | • Duration: NR | • Drug name: moxisylyte, dissolved in 2 ml physiological saline | • Anatomic/Physiologic: successful erections (10–20 m) obtained in all pts. NS decrease of BP with admin of drug. NS df between screening lab tests performed pre & post tx. Metabolites found in plasma: Unconjugated DAM, glucuronide & sulpho derivates of DAM & MDAM. The elimination half-lives are 0.89 +/-0.35 h for unconjugated DAM, 2.16 +/-0.85 h for conjugated VAM, & 5.32 +/-3.23 h for conjugated MDAM. | • Systemic: 1 case of sleepiness
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose: 30 mg | • Follow-up: NR
| • Age: 31.2 (24–39) y | • Inclusion: screening included haematology, urinalysis, liver function test (alkaline phosphatase, total bilirubin & lactic deshydrogenase), hx & physical exam. All had normal height (178.5 +/-5.7cm) & weight (75.8 +/-12.5kg). No hx or allergies, no drugs of any kind in 2 wk pre-tx. No drugs of enzyme inducers or inhibitors in 3 mo pre study. | • Duration: NR
| • Level of Injury: all complete lesions with paraplegic - upper levels of spinal cord | • Exclusion: NR | • Schedule: NR
| • ASIA Level: NR | • Quality Assessment: 12/19 (+) reported | • Mode/Admin. Route: Intracavernous injection; blood sampling before dosing (20ml) & at 0.08, 0.17, 0.33, 0.55, 1, 1.5, 2, 2.5, 3, 3.5, 4 & 8h post dosing (10 ml)
| • Duration since injury: NR | | • Device: NR
| • Dropouts: n=0 | | • Other Device: NR
| • Lost in follow-up: NR | | • Surgical: NR
| • N of sites: 1 | | • Behavioral: NR
| • Funding: NR
Costa, 1993, France | • Enrolled/ evaluated: n=12/ n=NR | • Study Design: NCS | • Pharmacological (n=12): | • Outcomes: | • A/E: NR
(Ref ID 344) | • % Males: 100% | • Duration: NR | • Drug name: moxisylyte | • Anatomic/Physiologic: NS df between 4 injection vols. (0.4, 0.8,1.2 & 2 ml 20 mg moxisylyte) for mean max rigidity (2.8, 2.8, 2.3 & 2.3), abdominopenile angle (100,101,107 & 101 degrees), penile length increase (33,34,36 & 35 mm), penile circumference increase (31.5,32,31 & 29 mm), duration of erection (47,62.5,60,57 m).
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose: 20 mg | • Follow-up: NR
| • Age: 34 (25–43) y | • Inclusion: Erectile impotence due to post-traumatic paraplegia | • Duration: NR
| • Level of Injury: n=1 C6–7 n=7 T3–T12 n=2 T12-L1 n=1 L1 All complete SCI | • Exclusion: Peyronie's disease, impotence related to another etiology than SCI, unbalanced bladder, bedsores, cardiac, renal, hepatic or ventilatory failure, systolic blood pressure below 10 cm Hg | • Schedule: NR
| • ASIA Level: NR | • Quality Assessment: 8/19 (+) reported | • Mode/Admin. Route: 4 different vols: 0.4, 0.8, 1.2 & 2 ml. 7 d interval between injections
| • Duration since injury: 3–26 y | | • Device: NR
| • Dropouts: n=0 | | • Other Device: NR
| • Lost in follow-up: NR | | • Surgical: NR
| • N of sites: 1 | | • Behavioral: NR
| • Funding: NR
Courtois, 2001, Canada | • Enrolled/ evaluated: n=10/ n=NR | • Study Design: NCS | • Pharmacological: NR | • Outcomes: | • A/E: NR
(Ref ID 1657) | • % Males: 100% | • Duration: 4 wk | • Device: NR | • Anatomic/Physiologic: SCI pts could achieve initial tumescence, revealed by an average increase in penile circumference of 2.01 cm at beginning of training program. Following 4 wk of training, tumescence improved & reached an average of 3.22cm increase in penile circumference. Post 4 wk of stopping tx average tumescence dropped to 2.66 cm. Penile rigidity moved from 43% pre training to 59% at end of training program & back to 47% following secession of tx.
| • Race/ethnicity: n=2 cervical, n=7 Thoracic, n=1 lumbar; all UMN lesions, n= 6 Incomplete, n=4 Complete | • Eligibility Criteria: | • Other Device (n =10): | • Follow-up: NR
| • Age: 37.7 (25–52) y | • Inclusion: screening test included neurological examination to verify lesion level & perineal muscle activity. Sexual evaluation to confirm ED defined by plethsmographic recording, reflex responses within normal latency (i.e. under 40 msec) | • Type: Rigiscan Device (erectile measurements)
| • Level of Injury: NR | • Exclusion: NR | • Manufacturer: NR
| • ASIA Level: NR | • Quality Assessment: 11/19 (+) reported | • Surgical: NR
| • Duration since injury: 7.1(1–23) y | | • Behavioral (n=10):
| • Dropouts: n=0 | | • Type: Perineal training to investigate role of these muscles in erection. Technique combined with biofeedback & home exercises.
| • Lost in follow-up: n=2
| • N of sites: 1
| • Funding Source: FRSQ & Foundation Andre Senecal
Earle, 1992, Australia | • Enrolled/ evaluated: n=22/ n=NR | • Study Design: NCS | • Pharmacologic (n=19): | • Outcomes: | • A/E:
(Ref ID 359) | • % Males: 100% | • Duration: NR | • Drug name: Papaverin, /mixture of papaverine 40 mg & phentolamine, Prostaglandin E1 | • Anatomic/Physiologic: 19/22 achieved full erection following injections.14 pts continued to use self injection, 8 used papaverine, 1 used combination of papaverine/ phentolamine & 3 used prostagl & in E1. 8 pts felt spontaneous erections improved with injections while 5 had unreliable spontaneous erections | • Local: bruising
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose: initial injection of 2–5 mg; max 80 mg, mixture of papaverine 40 mg & phentolamine 0.5 mg, prostaglandin E1 1–2 microgram | • Sexual Satisfaction: partner subjective responses towards injection tx: favorable in 9, 1 not willing, 1 apprehensive & 1 partner glad not required every time | • Systemic: blood in urethra, & prolonged erections
| • Age: 35.2 (20–45) y | • Inclusion: NR | • Duration: NR | • Follow-up: NR | • Other: lack of confidence
| • Level of Injury: C5–7 n=3, T5–12 n=8, L1 n=2, S1 n=1 (n=3 tetraplegic & rest are paraplegic); 11 complete, 3 incomplete | • Exclusion: NR | • Schedule: range 1 × wk to 1–4 × wk
| • ASIA Level: NR | • Quality Assessment: 7/19 (+) reported | • Mode/Admin. Route: mixture of papaverine 40 mg & phentolamine administered if pts failed to respond to papaverine alone
| • Duration since injury: 27 (15–42) y | | • Device: NR
| • Dropouts: n=5 | | • Other Device: Surgical: NR
| • Lost in follow-up: NR | | • Behavioral: NR
| • N of sites: 1
| • Funding: NR
Gans, 2001, US | • Enrolled/ evaluated: n=17/n=NR | • Study Design: NCS | • Pharmacologic (n=17): | • Outcomes: | • A/E:
(Ref ID 269) | • % Males: 100% | • Duration: Feb.- Sept. 1998 | • Drug name: sildenafil | • Anatomic/Physiologic: mean duration of erection increased to 10 m post-tx. Scores from IIEF questionnaire (all p<0.05): mean scores of confidence that one could get & keep erection increased 1.6–3.8; mean score of frequency of erections hard enough for penetration increased from 1.1–3.8; mean scores of frequency of ability to maintain erection post penetration of partner increased 1.3–4.1; mean duration of erection increased from 8.4–10 m; difficulty maintaining erection to completion of intercourse improved 1.4–4.3. | • In n=1 hypotension resulting in dropout.
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose: starting dose 25 mg with increase of dose in 25 mg increments; mean dose 73.4+/-33.5 mg | • Sexual Satisfaction: mean scores frequency of satisfaction with attempted sexual intercourse increased 1.3–4.1(p<0.05); mean scores of satisfaction with therapy increased 1.8 with previous therapy to 3.5 post sildenafil (p<0.05)
| • Age: 40.3 (25–58) y | • Inclusion: hx of organic ED, SCI, & a consistent sexual partner | • Duration: NR | • Follow-up: (n=6)
| • Level of Injury: cervical 4; thoracic 12; lumbar 1 | • Exclusion: unwillingness to participate in f/u appointments, use of organic nitrates or nitric oxide donor compounds, dependency on alcohol or drugs, or major, uncontrolled medical illness, previous hx of ischemic events (e.g., myocardial infarction or stroke), or abnormal baseline testosterone | • Schedule: NR | • Length: NR
| • ASIA Level: NR | • Quality Assessment: 16/19 (+) reported | • Mode/Admin. Route: oral (no ctrl wash-out period pre to tx) | • Duration: mean duration f/u 5.3 +/-2.2 mo
| • Duration since injury: 9.8 (3–21) y | | • Device: NR | • Results: NS in erectile function between early & long-term f/u except for an improvement in quality of erection. All 6 pts stated that they would recommend sildenafil therapy to a friend with ED SCI, no S Δ in frequency of successful intercourse between f/u periods
| • Dropouts: n=1 | | • Surgical: NR
| • Lost in follow-up: 10 | | • Behavioral: NR
| • N of sites: 1
| • Funding: NR
Golji, 1979, US | • Enrolled/ evaluated: n=30/ n=NR | • Study Design: NCS | • Pharmacologic (n=25): | • Outcomes: | • A/E:
(Ref ID 414) | • % Males: 100% | • Duration: 2 y | • Drug name: Gentamicin (non interventional) | • Psychological: 18/20 wished they had penile implant sooner & 2 indicated marriages could have been saved if penile implant earlier. | • Systemic: extrusion of penile prosthesis in 2 pts caused by infection
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose: NR | • Sexual Satisfaction: 68% of pts with choice of oral sex pre-operation & remaining 42% with no specific pattern in sexual satisfaction result of operation: (+) Δ in sexual pleasure in intercourse & morale of pts & their partners
| • Age: NR (25–60) y | • Inclusion: impotence due to SCI | • Duration: 1 d preoperatively & 3–4 d postoperatively Schedule: NR | • Follow-up: NR
| • Level of Injury: 36% cervical, 4% lumbar; 68% complete, 32% incomplete | • Exclusion: NR | • Mode/Admin. Route: orally; most underwent another wk of other antibiotic urinary antiseptic therapy.
| • ASIA Level: NR | • Quality Assessment: 7/19 (+) reported | • Device: NR
| • Duration since injury: NR | | • Surgical (n=25):
| • Dropouts: n=5 | | • Type: Small-Carrion penile prosthesis
| • Lost in follow-up: NR | | • Behavioral: NR
| • N of sites: 1
| • Funding: NR
Green, 1986, US | • Enrolled/ evaluated: n=40/ n=NR | • Study Design: NCS | • Pharmacological: NR | • Outcomes: | • A/E:
(Ref ID 192) | • % Males: 100% | • Duration: 1981-1986 | • Device: NR | • Sexual Satisfaction: 86% (31/36) intercourse regularly & pleased with their decision for implants; partners confirmed satisfaction as well; 11% (4/36) dissatisfied: all had semi-rigid implants & stated rods not rigid enough to sustain vaginal penetration; 1 wife not satisfied; 1 pt died but wife stated they had regular intercourse. | • Local: no immediate postoperative complications
| • Race/ethnicity: NR | • Eligibility Criteria: | • Other Device: NR | • Follow-up:
| • Age: 33 (21–60) y | • Inclusion: SCI pts suitable for penile prosthesis no less than 9–12 m post injury with: 1. stable bladder programs; 2. recent urologic X-ray evaluation; 3. sterile urine at time of implantation; 4. free of open skin lesions | • Surgical (n=36): | • Result: 8.3% (3/36) pts had extruded rods, all happened >2 y post implantation; 1 pt had paraphimosis requiring circumcision; 1 pt with an inflatable prosthesis had minor erosion through fossa navicularis that spontaneously healed
| • Level of Injury: NR | • Exclusion: NR | • Type: penile implants: 1. semi-rigid penile implants; 2. inflatable penile implants
| • ASIA Level: A n=31; B-D n=9 | • Quality Assessment: 7/19 (+) reported | • Behavioral: NR
| • Duration since injury: > 0.75 –1 y
| • Dropouts: n=4
| • Lost in follow-up: NR
| • N of sites: 1
| • Funding: NR
Gross, 1996, Germany | • Enrolled/ evaluated: n=209/ n=NR | • Study Design: NCS (Retrospective study) | • Pharmacological: NR | • Outcomes: | • A/E:
(Ref ID 85) | • % Males: 100% | • Duration: 1980-1992 | • Device: NR | • Anatomic/Physiologic: n=179 evaluable. 234 operations in 209 pts with revision due to perforation, infection or malfunction. 143/209 initially received semi-rigid, 59 semi-flexible & 7 flexible penile prosthesis. After revisions, 127 still had a semi-rigid, 74 a semi-flexible & 8 a flexible prosthesis. | • Local: infection led to removal of implants in 14/179 (6.7%); bilateral perforation in n=6, repeated bilateral perforation in n=2 & unilateral perforation in 13: total 7% of 179 pts. perforation occurred with 9.4% of semi-rigid prostheses & 2.7% of semi-flexible prostheses.
| • Race/ethnicity: NR | • Eligibility Criteria: | • Other Device: NR | • Sexual Satisfaction: Of pts treated for penile retraction, 92% satisfied with their sexual life, & of those treated for ED, 83% satisfied. | • Systemic: n=13 death
| • Age: 39.9 (16–72) y | • Inclusion: NR | • Surgical (n=209): | • Follow-up: n=165
| • Level of Injury: 77% paraplegic, 23% tetraplegic | • Exclusion: NR | • Type: semi-rigid (Jonas) prosthesis (in 49 pts with ED, 113 pts with penile retraction & 47 with both); prosthesis implanted under strict aseptic conditions with antibiotic prophylaxis 3 d pre & 5 d post surgery. | • Duration: mean of 5 y since implantation (range 0.6–11.4),
| • ASIA Level: NR | • Quality Assessment: 5/19 (+) reported | • Behavioral: NR | • Results: 126/165 used penile prostheses for external condom drainage, 116(92%) succeeded; ED main indicator for penile prostheses in n=83 (11 tetra & 72 para). 70/83(84%) reported satisfactory sexual intercourse post-tx. Reasons for not using prostheses were: unsatisfactory surgical result in 5 pts, lack of stability in 2 pts, subcoronal ventral deviation in 3 pts, & lack of interest in rest.
| • Duration since injury: NR
| • Dropouts: n=37
| • Lost in follow-up: n=17
| • N of sites: 1
| • Funding: NR
Heller, Israel, 1992 | • Enrolled/ evaluated: n=30 (neurological impotence)/ n=NR | • Study Design: NCS | • Pharmacological: NR | • Outcomes: | • A/E:
(Ref ID 149) | • % Males: 100% | • Duration: NR | • Device: NR | • Psychological: questionnaires used but scales not given | • Local: 17% (3/17) complained of suction around testicles with VTCT use; 17% (3/17) reported occasional swelling of testicles; 33% reported petechial hemorrhages
| • Race/ethnicity: NR | • Eligibility Criteria: | • Other Device (n=30): | • Sexual Satisfaction: 83% of 17 pts reported very satisfied with sexual relationship after using VTCT; 100% of their partners reported very satisfied with present sexual relationship; this enhancement in satisfaction attributed to following: pts felt that they had a greater ability to give pleasure to sexual partners resulting in increased desire to engage in sexual activity; partners felt enhancement secondary to engaging in a more “natural” sexual relationship
| • Age: NR | • Inclusion: NR | • Type: vacuum tumescence | • Follow-up: NR
| • Level of Injury: NR | • Exclusion: NR | • Manufacturer: 2 different VTCT devices: 1. Eracaid system, Osborn Medical Systems, Augusta, Georgia, USA; 2. Ved brand vacuum system, Mission Pharmaceuticals
| • ASIA Level: NR | • Quality Assessment: 8/19 (+) reported | • Surgical: NR
| • Duration since injury: NR | | • Behavioral: NR
| • Dropouts: n=13
| • Lost in follow-up: NR
| • N of sites: 1
| • Funding: NIDRR; US Dept. of Education; USIEF
Hirsch, 1994, US | • Enrolled/ evaluated: n=27: SCI n=14; MS n=7; discogenic disease n=6/NR | • Study Design: NCS | • Pharmacological (n=27): | • Outcomes: | • A/E: NR
(Ref ID 326) | • % Males: 100% | • Duration: NR | • Drug name: intracavernous prostaglandin E1 - PGE-1 | • Sexual Satisfaction: all pts completing protocol reported excellent penile rigidity & duration of erection on standardized home assessment questionnaires; no objective data available from article
| • Race/ethnicity: NR | • Eligibility Criteria: | • | • Follow-up:
| • Age: 31.5 (22–39) y | • Inclusion: NR | • Duration: NR | • Duration: quarterly f/u visits up to 28 mo
| • Level of Injury: NR | • Exclusion: NR | • Schedule: NR | • Results: NR
| • ASIA Level: NR | • Quality Assessment: 6/19 (+) reported | • Mode/Admin. Route: NR
| • Duration since injury: 8 y | | • Device: NR
| • Dropouts: n=15 (8 SCI; 4 MS; 3 discogenic disease) | | • Other Device: NR
| • Lost in follow-up: NR | | • Surgical: NR
| • N of sites: 1 | | • Behavioral: NR
| • Funding: NR
Iwatsubo, 1986, Japan | • Enrolled/ evaluated: n=37/n=NR | • Study Design: NCS | • Pharmacological: NR | • Outcomes: | • A/E:
(Ref ID 404) | • % Males: 100% | • Duration: 5 y | • Device: NR | • Sexual Satisfaction: 15 pts (41%) reported improved marital life. 18 pts (48%) reported no benefit & 4 pts (11%) reported dissatisfaction. | • Systemic: pain n=1; 46 y-old T12 complete: implant removed; irritation in a 29 y-old C7 complete: modification made
| • Race/ethnicity: NR | • Eligibility Criteria: | • Other Device: NR | • Pt logs/diaries: questionnaire survey result in 37 pts: 32 pts (86%) reported satisfaction with regards to better condom fitting & easier intermittent catheterisation, 5 pts (14%) dissatisfied/ discontinued.
| • Age: 42 (21–63) y | • Inclusion: all SCI with urinary incontinence or impotence | • Surgical (n=37): | • Follow-up: NR
| • Level of Injury: 10 tetraplegic 23 paraplegic 4 walking with cauda equine | • Exclusion: NR | • Type: Shirai-type Penile Implant
| • ASIA Level: NR | • Quality Assessment: 5/19 (+) reported | • Behavioral: NR
| • Duration since injury: mean 5 y
| • Dropouts: n=2
| • Lost in follow-up: n=2 implant removed due to infection
| • N of sites: 1
| • Funding: NR
Jaworski, 1992, US | • Enrolled/ evaluated: n=80/n=56/ SCI n=30; DBT n=26 | • Study Design: Case-control Study | • Pharmacological: | • Outcomes: | • A/E: NR
(Ref ID 150) | • % Males: 100% | • Duration: NR | • Drug name: Papavarine/phentolamine injection & penile prosthesis implant | • Sexual Satisfaction: vs. a normative sample both DBT & SCI males found to have better body image post-implant/injection. Also engaged in more sexual activities.
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose: NR | • Pt logs/diaries: SCI men scored higher on sexual information & attitudes vs. DBT men; DBT men scored slightly higher on overall adjustment in relationship than SCI men (p < 0.07)
| • Age: SCI 37.2 (NR) y; DBT; 51.4 (NR) y | • Inclusion: All pts screened for testosterone & prolactin levels, general physical exam & urinanalysis | • Duration: NR | • Measures of sexual satisfaction (sexual activities, frequency & 2 measures of satisfaction): pre-tx (implant/injection) S df between SCI > DTB (p = 0.08); SCI more satisfied overall in sexual encounters (frequency, variety, duration, interest, communication) vs. DBT; S time effect for all outcome measures, with S improvement for SCI & DBT males “on all measures” from pre to post procedure (p = 0.0001).
| • Level of Injury: L-3 (10%) T-20 (67%) C-7 (23%), 63% motor & sensory complete | • Exclusion: NR | • Schedule: NR | • Follow-up: NR
| • ASIA Level: NR | • Quality Assessment: 3 * (NOS) | • Mode/Admin. Route: NR
| • Duration since injury: NR | | • Device: NR
| • Dropouts: n=0 | | • Other Device (n=56):
| • Lost in follow-up: NR | | • Type: snap gauge nocturnal penile tumescence monitoring
| • N of sites: 1 | | • Manufacturer
| • Funding: NIDRR; US Dept. of Education | | • Surgical: NR
| | | • Behavioral: NR
Kapoor, 1993, India | • Enrolled/ evaluated: n=101/n=NR | • Study Design: NCS | • Pharmacologic (n=109): | Outcomes: | • A/E:
(Ref ID 341) | • % Males: 100% | • Duration: NR | • Drug name: papaverine | • Anatomic/Physiologic: Dose-erection relation: all pts in younger age grp (up to 30 y) required 7.5–15 mg of papaverine. Older age grps required a higher dosage. 78 pts had good erection within 10 m duration & 20 over 22 m. Duration of erection less than 1 h in 35, 1–2 h in 29, 2–4 h in 31 & more than 4 h in 3 pts. Lag period of erection onset 10 m in 78 pts, 20 m in 13 pts, & 30 m in 7 pts. | • Systemic: Subcutaneous haematoma in 3 pts, Cavernosa fibrosis in 2 after prolonged use (over 36 mon), prolonged erection (more than 4 h) with 1 pts needing cavernosal wash with dopamine solution, & systematic effects in 1 so case dosage reduced.
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose: starting at 7.5 mg & increased according to status of erection | • Sexual Satisfaction: 98 pts achieved good erections & enjoyed coitus with their spouse
| • Age: NR (20–51) y | • Inclusion: baseline tests (urine, hemoglobin, liver function tests & ECG) | • Duration: NR | Follow-up:
| • Level of Injury: C4–L4; n=9 complete, & n=27 incomplete tetraplegic; n=23 complete & n=42 incomplete paraplegic | • Exclusion: NR | • Schedule: 2–3 × wk | • Length: NR
| • ASIA Level: NR | • Quality Assessment: 10/19 (+) reported | • Mode/Admin. Route: intracavernous injection to posterolateral aspecto of penis at base | • Duration: monthly intervals
| • Duration since injury: all>1 y | | • Device: NR | • Results: NR
| • Dropouts: n=0 | | • Other Device: NR
| • Lost in follow-up: NR | | • Surgical: NR
| • n of sites: 1 | | • Behavioral: NR
| • Funding: NR
Kim, 1995, US | • Enrolled/ evaluated: n=10: SCI n=9; mild arterial insufficiency n=1 | • Study Design: NCS | • Pharmacologic (n=10): | • Outcomes: | • A/E:
(Ref ID 318) | • % Males: 100% | • Duration: 5 d (interventions & assessments done on d 1, 3 & 5) | • Drug name: 0.04% prostaglandin E1 topical gel | • Anatomic/Physiologic: mean cavernous artery diameter (cm): pre-application 0.09 +/-0.02 & post-application 0.11 +/-0.04; (p<0.05) mean peak flow velocity (cm/sec): pre-application 15.4 +/-6.4 & post-application 22.8 +/-7.3 (p<0.05); clinical erection (grade 4 & 5) occurred in 2 pts who did not have erections with pbo gel; mean diastolic BP variations (mm Hg): pre-application 78, post-application 83 (p<0.0001); mean HR variation (beats/m): pre-application 59 & post-application 64 (p<0.01); NS Δ;'s in systolic & diastolic BP. | • Local: facial redness in 1 pts with a previous hx of psoriasis
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose: NR | • Follow-up: NR
| • Age: 33 (19–50) y | • Inclusion: NR | • Duration: 1h
| • Level of Injury: n=4 cervical; n=5 thoracic | • Exclusion: if hormonal or yohimbine therapy used within 6 m | • Schedule: d 3
| • ASIA Level: NR | • Quality Assessment: 10/19 (+) reported | • Mode/Admin. Route: medication applied to penis, scrotum &perineum
| • Duration since injury: NR | | • Device: NR
| • Dropouts: n=1 | | • Other Device (n=10):
| • Lost in follow-up: NR | | • Type: color flow Doppler ultrasound, & L10-5 linear array transducer
| • N of sites: 1 | | • Application: 10 m post -tx, to measure velocity & angle.
| • Funding: Pharmedic Company | | • Surgical: NR
| | | • Behavioral: NR
Kim, 1995, US | • Enrolled/ evaluated: n=20: n=13 SCI; n=7 other/ n=NR | • Study Design: non-RCT | • Pharmacologic (n=x): | • Outcomes: | • A/E:
(Ref ID 322) | • % Males: 100% | • Duration: each pts evaluated on 5 separate d for a 13-d period | • Drug name: 5.5%, 7%, 15%, & 20% topical papaverin gel; color flow Doppler ultrasound with a L10-5 linear array transducer | • Anatomic/Physiologic: SCI pts grp (n=12): mean cavernous artery diameter increased 36% from 0.11–0.15 cm (p<0.001); mean peak systolic flow velocity increased 21% 13.8–17.5 cm/sec (p=0.06); after genital application of papaverin BP Δ's did not reach statistical S; mean HR decrease after application statistically S: from 68 beats/m to 63 beats/m at 30 m (p<0.0004); clinical erection of grade 5 noted in 3/17 pts (18%) with both papaverin & placebo gel applications, but in papaverin grp duration of erection longer: 38.7 +/-18.7 m vs 8.0 +/-4.6 m. (NS) | • Local: forearm skin rash in 1 pts
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose: papaverin gel: mean 295 mg; range 133–500 mg | • Pt logs/diaries/ Other: mean serum papaverin levels after genitalia application (ng/ml): 10.5 at time 0, 9.9 +/-3.3 at 15 m, 13.8 +/-4.4 at 30 m, & 15.1 +/-4.8 at 60 m.
| • Age: 40 (19–73) y | • Inclusion: NR | • Duration: NR | • Follow-up: NR
| • Level of Injury: n=8 cervical; n=5 thoracic | • Exclusion: pts excluded if hormonal therapy used within 6 mo | • Schedule: NR
| • ASIA Level: NR | • Quality Assessment: NA | • Mode/Admin. Route: NR
| • Duration since injury: 5.9 (0.6–27) y) | | • Device: NR
| • Dropouts: n=3 | | • Other Device: NR
| • Lost in follow-up: NR | | • Surgical: NR
| • N of sites: 1 | | • Behavioral: NR
| • Funding: Pharmedic Company
Komisaruk, 1997, US | • Enrolled/ evaluated: n=32: SCI n=16; ctrl n=16/ n=NR | • Study Design: Case-control Study | • Pharmacologic: NR | • Outcomes: | • A/E: NR
(Ref ID 530) | • % Males: 0%(all female) | • Duration: NR | • Device: NR | • Anatomic/Physiologic: Ctrl Grp: vaginal self stimulation S increased PD threshold by 66.7 +/-18.5%(p<0.01), & PT by 42.5 +/-10.5%(p<0.01).Cervical self-stimulation S increased PD threshold by 34.9% +/-1% (p<0.05) & PT threshold by 28.3% +/-8.2% (p<0.01) over control resting condition. Cervical self-stimulation in grp with lower SCI S increased PD threshold by 33.8% +/-10.2% & PT(p<0.05) & PT threshold by 27.2+/-7.6%(p<0.01). In upper SCI, vaginal self stimulation S increased PD threshold by 91.6%+/-32.9%(p<0.01) & PT threshold by 46.1% +/-8.8%(p<0.01) over corresponding ctrl resting condition; cervical self stimulation in this grp increased PD threshold by 72. +/-34.6%(P<0.05), & PT threshold by 36.5% +/-9.6%(p<0.01); S higher increase in PD threshold by vaginal or cervical self stimulation in grp with upper SCI vs. grp with lower SCI (p<0.01 & p<0.05)
| • Race/ethnicity: NR | • Eligibility Criteria: | • Other Device (n=32): | • Follow-up: NR
| • Age: SCI 37.2 (25–55) y; ctrl 45.4 (35–56) y | • Inclusion: SCI: incomplete at least 1-y post injury, no hx of autonomic dysreflexia, minimum age 21 y. Uterus & cervix intact in all pts | • Type Pain threshold measurement: Frey & Passive stimulator
| • Level of Injury: SCI T10 &/or above n=6; SCI T10 & below n=10 | • Exclusion: psychosis or severe depression, cystocele or hysterectomy | • Surgical: NR
| • ASIA Level: NR | • Quality Assessment: 6 * (NOS) | • Behavioral (n=32)
| • Duration since injury: 12.4 (2–27 y) | | • Type: self stimulation of vaginal, cervical, sensate region in random order
| • Dropouts: n=1 SCI | | • Duration: 90 m total consisting of 12 m stimulation for each experimental condition preceded & followed by resting, non-stimulation rest period.
| • Lost in follow-up: NR | | • Frequency: 1 ×/ experimental condition
| • N of sites: 1
| • Funding: NR
Martin, 1983, US | • Enrolled/ evaluated: n=20/ SCI n=12; healthy ctrl n=8 | • Study Design: Case-control study | • Pharmacologic: NR | • Outcomes: | • A/E: NR
(Ref ID 1406) | • % males: 100% | • Duration: NR | • Device: Rectal Probe Electrostimulator | • Anatomic/Physiologic: erections with max. tumescence in 1 ctrl pt, with no seminal emissions or ejaculations; 6/10 SCI achieved erection with 20 Hz stimulation; surface area & intensity of applied current directly affected extent of RPE-induced penile tumescence; use of 60 Hz & 20 Hz currents ineffective in eliciting erection
| • Race/ethnicity: NR | • Eligibility Criteria: | • Amplitude: NR | • Interviews: verbalized descriptions of threshold current sensations included tenesmus, rectum burning sensation, testicular pain resembling intense pressure in rectum, bladder or bowel, suprabubic midline discomfort, pain at base of penis & sensation of gluteal muscle spasm.
| • Age: healthy grp - NR (23–26) y; SCI NR (24–41) y; NR (24–39) y | • Inclusion: NR | • Frequency: 60 Hz, 20 Hz, & 0.25 Hz | • Follow-up: NR
| • Level of Injury: T3–T12 n=3; T12-L1 n=2; L2 n=1 | • Exclusion: NR | • Mode/Admin. Route: dorsal lithotomy position (after bowel movement) intact subjects & 1st 5 pts controlled current delivery by themselves
| • ASIA Level: NR | • Quality Assessment: 4 * (NOS) | • Other Device: NR
| • Duration since injury: NR | | • Surgical: NR
| • Drop-outs: n=0 | | • Behavioural: NR
| • Lost to follow-up: NR
| • N of sites: 1
| • Funding: NIMH
Montague, 1994, US | • Enrolled/ evaluated: n=47: SCI n=12, non-traumatic neurological disorders n=25, peripheral nerve injuries n=10/ n= NR | • Study Design: NCS | • Pharmacologic: NR | • Outcomes: | • A/E:
(Ref ID 1736) | • % of Males: 100% | • Duration: July 1987 to July 1992 | • Device: NR | • Anatomic/Physiologic: 91% of pts implanted in study had functioning prosthesis. Penile prosthesis implants (SCI) increased incidence of infection & erosion, so considered alternative tx (e.g., vacuum devices/intracavernous injection therapy) | • Systemic: 2 pts had prosthesis removed 1 & 26 mo post implantation for infection. Of devices removed for infection, 1 semi-rigid device (AMS Malleable 600) & 1 inflatable device (AMS 700CX). 1 device removed for erosion post 6 wk implantation (device hydralic (hydroflex)), 2 devices mechanical failure, a DuraPhase cable fracture 34 mo post implant & a Duraflex hydraulic leak 24 mo post implant. Infection rate 4%, erosion rate 2%, mechanical failure 4%
| • Race/ethnicity: NR | • Eligibility Criteria: | • Other Device: NR | • Follow-up: NR
| • Age: 48 (19–71) y | • Inclusion: Neurogenic Impotence | • Surgical (n=47):
| • Level of Injury: NR | • Exclusion: NR | • Type: Prostheses implant: AMS 700CX (13) AMS Malleable 600 (10) AMS Ultrex (9) DuraPhase (9) Hydroflex (5) Dynaflex
| • ASIA Level: NR | • Quality Assessment: 6/19 (+) reported | • Behavioral: NR
| • Duration since injury: NR
| • Dropouts: n=0
| • Lost in follow-up: NR
| • N of sites: 1
| • Funding: NR
Richards, 1993, US | • Enrolled/ evaluated: n=17/ n=NR | • Study Design: NCS | • Pharmacologic (n=17): | • Outcomes: | • A/E: NR
(Ref ID 1759) | • % Males: 100% | • Duration: NR | • Drug name: Intracavernous injection of vasoactive (Not specified) | • Psychological: > overall satisfaction subsequent to tx implementation. In SII examination of subscale pre-tx, both partners dissatisfied with frequency of sexual activity (male > females). Males reported < self-acceptance vs. partners pre-tx.
| • Race/ethnicity: 76% white | • Eligibility Criteria: | • Dose: NR | • Sexual Satisfaction: Both pts & partner expressed increased satisfaction with frequency of sexual activity post intervention (injection). However, SCI males reported > improvement in sexual pleasure & self-acceptance vs. partners (self acceptance p = 0.05, sexual pleasure p = 0.01)
| • Age: NR | • Inclusion: SCI Diagnosed by urologist as having neurologically based impotence; steady sexual partner; couples with ongoing substance abuse, poor self-esteem, marked relationship instability/discord, or active partner opposition to procedure documented &referred for appropriate tx. If tx recommended followed & successful, couple then enrolled. | • Duration: NR | • Follow-up: NR
| • Level of Injury: NR (76.4% paraplegic; 74.6%complete) | • Exclusion: NR | • Schedule: NR
| • ASIA Level: NR | • Quality Assessment: 9/19 (+) reported | • Mode/Admin. Route: NR
| • Duration since injury: NR | | • Device: NR
| • Dropouts: n=0 | | • Other Device: NR
| • Lost in follow-up: NR | | • Surgical: NR
| • N of sites: 1 | | • Behavioral: NR
| • Funding: NIDRR; US Dept. of Education, & MRRTC
Sanchez, 2001, Spain | • Enrolled/ evaluated: n=170/ n=NR | • Study Design: NCS | • Pharmacologic: | • Outcomes: | • A/E:
(Ref ID 12) | • % Males: 100% | • Duration: NR | • Drug name: sildenafil | • Anatomic/Physiologic: 150 (88.2%) pts reported improved erection; improvement confirmed by 85.3% (99/116) of partners; presence of orgasmic perception pre-tx (p=0.021) & erection grades 3 & 4 (p=0.006) S association with (+) response to sildenafil tx; of total attempts (603) at sexual intercourse made during study, 431 (71.5%) successful; no S Δ's seen in ejaculatory function after tx; level of SCI, ASIA, causes of SCI, ED duration, age, smoking or drinking habits, pre-tx with caverjet, presence of bulbocavernous reflex & ejaculation not factors predicting response to sildenafil | • Systemic: In 24.1% (41/170): 10 headache; 15 flushing; 7 G.I. discomfort; 8 nasal congestion; 7 visual disturbances; 9 dry mouth, restlessness, palpitations, hiccup; 1 pt (0.59%) discontinued tx due to unbearable abdominal pain
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose: starting dose 50 mg up to 100 mg, 30–45 m before start of sexual activity/ 1 × d | • Sexual Satisfaction: sildenafil S improved pts satisfaction with sexual activity & overall satisfaction with sexual life (p<0.001)
| • Age: 37.3 (19–65) y | • Inclusion: men >18 y with SCI who overcome period of medullary shock, with stable partner & ED | • Duration: NR | • Follow-up: NR
| • Level of Injury: cervical 35 (20.6%); thoracic 99 (58.2%); lumbar 30 (17.6%); sacrococcygeal 6 (3.6%) | • Exclusion: pts with anatomic deformities of penis; pts in whom sexual activity not advised (i.e., pts with severe cardiovascular dysfunction such as unstable angina or severe heart failure not controlled with drugs; hypotension (BP<90/50 mmHg); recent hx (less than 3 mo) of stroke or acute myocardial infarction); pts treated with any drug or therapy for ED that not willing to discontinue during study; pts treated with drugs containing nitrates; hx of retinitis pigmentosa; severe liver or kidney failure; pts already treated with sildenafil | • Schedule: NR
| • ASIA Level: n=94 A; n= 14 B; n=27 C; n=29 D | • Quality Assessment: 8/19 (+) reported | • Mode/Admin. Route: NR
| • Duration since injury: 7.7+/-66 (0.2–32.7) y | | • Device: NR
| • Dropouts: n=0 | | • Other Device: NR
| • Lost in follow-up: NR | | • Surgical: NR
| • N of sites: 16 | | • Behavioral: NR
| • Funding: NR
Schmid, 2000, Switzerland | • Enrolled/ evaluated: n=41/ n=NR | • Study Design: NCS | • Pharmacologic (n=41): | • Outcomes: | • A/E
(Ref ID 280) | • % Males: 100% | • Duration: July-December 1998 | • Drug name: oral sildenafil | • Anatomic/Physiologic: 38 pts (93%) reported improved erections (grade 3–4) post sildenafil permitting sexual intercourse 1 h post intake of drug; using IIEF questionnaire: erectile function improved from a mean score of 9.2+/-4.4 to 25.4+/-4.2 (p<0.05); orgasm & ejaculation function slightly but NS increased from a mean of 3.8+/-2.7 to 5.2+/-3.7; NS Δ's in sexual desire post tx from a mean of 6.7+/-2.3 to 7.5+/-1.9 | • Systemic: 10% (4/41) showed mild to moderate side effects, (e.g., headache (3 pts), dizziness (2 pts), flushing (2 pts), dyspepsia (1 pts) & blurred vision (1 pts)
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose: 50 mg sildenafil given 3 ×, doses then adapted, PRN, according to pts self-reports | • Sexual Satisfaction: using IIEF questionnaire: intercourse satisfaction improved from mean of 4.5+/-2.5 to 10.5+/-2.0 (p<0.05); overall sex life satisfaction improved from a mean of 4.2+/-2.0 to 7.8+/-1.6 (p<0.05)
| • Age: 36.5 (20–63) y | • Inclusion: documented hx of chronic SCI (traumatic lesion or spinal disease for > 6 mo) & ED attributable only to SCI | • Duration: NR | • Follow-up: questionnaires completed pre-tx & post tx3 mo
| • Level of Injury: cervical C4–C7: 6; thoracic T1–T12: 19; lumbar L1–L5: 8; conus cauda: 4 | • Exclusion: pts prone to autonomic dysreflexia &/or high BP, known or suspected ED of vascular origin, cardiovascular diseases, bleeding disorders, hx of stroke, peripheral neuropathy, brain damage, clinical depression, endocrine diseases, pts taking drugs such as nitrates or anticoagulants, which could interact with sildenafil | • Schedule: NR | • Length: NR
| • ASIA Level: NR | • Quality Assessment: 10/19 (+) reported | • Mode/Admin. Route: NR | • Duration: NR
| • Duration since injury: 5.9 y (0.5–26) y | | • Device: vibrator: El-star Elektronik (n= 41) | • Results: NR
| • Dropouts: n=5 | | • Amplitude: NR
| • Lost in follow-up: NR | | • Frequency: NR
| • N of sites: 1 | | • Mode/Admin. Route: NR
| • Funding: IRP & SNF | | • Other Device: NR
| | | • Surgical: NR
| | | • Behavioral: NR
Sidi, 1987, US | • Enrolled/ evaluated: n=66/ n=NR | • Study Design: NCS | • Pharmacologic (n=66): | • Outcomes: | • A/E:
(Ref ID 399) | • % Males: 100% | • Duration: 1 y | • Drug name:averine hydrochloride (30 mg/ml), or a combination of papaverine (25 mg/ml) & phentolamine mesylate (0.83mg/ml) | • Anatomic/Physiologic: Average dose required to induce functional erection: Papaverine/phentolamine for 13 UMN 0.42+/-0.246, for 9 LMN 0.37+/-0.299. Papaverine for 10 UMN 0.403+/-0.183, for 10 LMN 0.32+/-0.166. Dose of papaverine/phentolamine in 10 pts (6 UMN, 4 LMN) who did not respond to papaverine alone: 0.395+/-0.37 & 0.4+/-0.297, respectively. No S df in average required doses observed between pts with UMN & LMN lesions or between thoracic, cervical & lumbar in both grps | • Systemic: Sustained erections that required irrigation in 4 pts (2 discontinued, & 2 responded to lower doses). Compromised arterial penile blood flow in 2 pts diabetes mellitus n=1, Peyronie's disease =1. Removal of a penile prosthesis n=1
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose papaverine (25 mg/ml) & phentolamine mesylate (0.83mg/ml) 2 × wk | • Follow-up:
| • Age: 35.8 (18–61) y | • Inclusion: NR | • Duration: NR | • Length: NR
| • Level of Injury: 14 cervical, 32 thoracic & 6 lumbar, 29 UMN, 21 complete 23 LMN, 15 complete | • Exclusion: NR | • Schedule: NR | • Duration: NR
| • ASIA Level: NR | • Quality Assessment: 13/19 (+) reported | • Mode/Admin. Route | • Results: Last f/u result in n=52(total): 15 (29%) not practising vasoactive intracavernous therapy for various reasons. Frequency of use for 37 (71%) practicing vasoactive intracavernous pharmocotherapy ranged from < 1 × mo to 1–2 × wk.
| • Duration since injury: NR | | • Device: NR
| • Dropouts: n=14 | | • Other Device: NR
| • Lost in follow-up: NR | | • Surgical: NR
| • N of sites: 1 | | • Behavioral: NR
| • Funding: NR
Sipski, 1995, US | • Enrolled/evaluated: n=21:13 SCI/ 8 AB/ n=NR | • Study Design: Case-control Study | • Pharmacologic: NR | • Outcomes: | • A/E: NR
(Ref ID 578) | • % Males: 0% (all female) | • Duration: NR (78 m study protocol) | • Device: NR | • Anatomic/Physiologic:
| • Race/ethnicity: NR | • Eligibility Criteria: | • Other Device: NR | • VMP: Baseline 2–5 all S > vs. initial baseline (p<0.05) indicating increasing cumulative excitation effect; No S df in baselines for SCI; ABs had S > mean baseline VPA vs. complete SCI subjects (p=0.03); S increase in VPA in response to A/V stimulation over baseline (p=0.03); addition of manual stimulation to AV resulted in (+) response in VPA in all pts
| • Age: SCI 30 (25–44) y; AB 36 (24–49) y | • Inclusion: regular menstrual cycles, no hx of gynecological or neurological surgery, no psychiatric disorders & medically stable. SCI pts of ASIA A tetraplegia of above T | • Surgical: NR | • Subjective arousal: AB pts showed S > levels vs. SCIs (p=0.04); arousal levels during A/V stimulation combined with manual stimulation S df between AB & SCI (p=0.04)
| • Level of Injury: n=9 C4–7, n=4 T2–5 | • Exclusion: NR | • Behavioral (n=21): | • Interviews/ Other: Divorce: 1 SCI, 3 AB
| • ASIA Level: A n=13(tetraplegic) | • Quality Assessment: 6 * (NOS) | • Type Erotic A/V & erotic A/V combined with manual stimulation of clitoral region | • Follow-up: NR
| • Duration since injury: (12–232) mo | | • Duration 6 m baseline, 12 m AV stimulation, 6 m baseline, 12 m of AV + manual stimulation, & 6 m final baseline
| • Dropouts: n=0 | | • Frequency: NR
| • Lost in follow-up: NR
| • N of sites: 1
| • Funding: NIH
Sipski, 1995, US | • Enrolled/ evaluated: n=35 (25 SCI; 10 AB)/NR | • Study Design: Case-control Study | • Pharmacologic: NR | • Outcomes: | • A/E: NR
(Ref ID 571) | • % Males: 0% (all female) | • Duration: d 2 of 3 d study protocol | • Device: NR | • Anatomic/Physiologic:
| • Race/ethnicity: NR | • Eligibility Criteria: | • Other Device (n=35): | • NS df between any pts grps for HR, SBP, & DBP. HR & RR in AB at orgasm>baseline (HR: p=0.002 & RR: p=0.03); for SCIs S increase in HR (p=0.005), RR (p=0.001), &SBP (p=0.05) at orgasm
| • Age: SCI 32 (NR) y; AB 34 (NR) y | • Inclusion: 1. normal menstrual cycles, 2. no gyne- or neurological surgery, 3. free from psychiatric disorders, 4. medically stable | • Type: Physiological measurements - PPS | • The ability to achieve orgasm S &(+) related to pts pinprick sensory scores in T11-L2 dermatomes(r=0.49), pinprick sensory scores in S3–S5 dermatomes(r=0.048), light touch sensory scores in T11-L2 dermatomes(r=0.47) & light touch sensory scores in S3–S5 dermatomes(r=0.45); all p<0.01.
| • Level of Injury: n=20 C4–7, n=5 T1–5 | • Exclusion: NR | • Manufacturer | • Whether pts had orgasm seemed related to SCI but not to degree or type of SCI.
| • ASIA Level: NR | • Quality Assessment: 5 * (NOS) | • Surgical: NR | • S df between neurologically intact pts (mean time to orgasm=15.11 m) & pts with no lower extremity function (mean time to orgasm =34.63)
| • Duration since injury: 98 (10–242) mo | | • Behavioral (n=35): | • Psychological: NR
| • Dropouts: n=0 | | • Type: A/V (sexually explicit video), manual & vibratory stimulation (with vaginal lubricant) to reach orgasm | • DSFI: SCIs scored S higher on sexual role subscale (m=52.80) vs. Abs (m38.89) (p=0.005). ABs indicated > sexual satisfaction (m=54.89) vs. SCIs (m=48.24) (p=0.04).
| • Lost in follow-up: NR | | • Duration: up to 75 m | • Follow-up: NR
| • N of sites: 1 | | • Frequency: NR
| • Funding: NIH
Sipski, 1996, US | • Enrolled/ evaluated: n=20: n=10 SCI; n=10 control/ n= NR | • Study Design: Case-control study | • Pharmacologic: NR | • Outcomes: | • A/E: NR
(Ref ID 562) | • % Males: 0% (all female) | • Duration: 3 d protocol | • Device: NR | • Anatomic/Physiologic:
| • Race/ethnicity: NR | • Eligibility Criteria: | • Other Device (n=20): | • Comparison of VPA within grps showed S df between baseline conditions for AB subjects. Baseline 3 to 5 S greater vs. initial baseline (p<0.05) indicating increasing cumulative excitation effect. NS df in baselines for complete SCI. Normal subjects S greater mean baseline VPA (m=8.95) vs. complete SCI (m=4.71)(p<0.03)
| • Age: SCI 30 (NR) y; ctrl 35 (NR) y | • Inclusion: All subjects require clearance from gynecologist & verification of absence of gynecologic problems. Monitoring of menstrual cycles for a min of 2 mo pre study participation. All study testing performed between d 16–21 of menstrual cycle | • Type Sphincter EMG: Dantec Couterpoint device(no.9018A0041) | • Psychological:
| • Level of Injury: n=6 C4–6, n=3 T2–5 | • Exclusion: NR | • Manufacturer Dantec Medical Inc., Grass Instruments, Ferrall Instruments | • NS Δ in complete SCIs in subjective arousal with performance of distracting task in conjunction with manual genital stimulation, however showed S increases in arousal when distracting task eliminated.
| • ASIA Level: n=10 A (tetraplegic) | • Quality Assessment: 7 * (NOS) | • Surgical: NR | • Follow-up: NR
| • Duration since injury: 93 (12–242) mo | | • Behavioral (n=20):
| • Dropouts: n=0 | | • Type: manual stimulation
| • Lost in follow-up: NR | | • Duration: 6 m baseline +12 m of Stroop (distraction test), +6min of baseline, + 12 m of Stroop test combined with manual stimulation, +6 m baseline +12 m of baseline followed by 12 m masturbation & 6 final m of baseline
| • N of sites: 1 | | • Frequency: NR
| • Funding: NIH
Sipski, 2001, US | • Enrolled/ evaluated: Arousal study: 68 SCI, 21 AB; Orgasm study: 66 SCI, 66 ctrl/ n=NR | • Study Design: Case-control study | • Pharmacologic (n=x): NR | • Outcomes: | • A/E: NR
(Ref ID 462) | • % Males: 0% (all female) | • Duration: 2 d protocol: d 1 pre study testing, d 2 - 78 m arousal or a 75 m orgasm protocol performed | • Device: NR | • Mean VPA: In ctrl subjects (n=21) S increase in VPA with 28.4 vs. baseline 23.0 (p<0.001). SCI: S increase in VPA with 15.7 vs. 13.9(p<0.001).
| • Race/ethnicity: NR | • Eligibility Criteria: | • Other Device: NR | • Orgasm study results: Historically, 55% of SCI reported orgasmic ability post-SCI, vs. 44% orgasmic in laboratory. (100% of ctrl reported historically & laboratory orgasm). No S dfs in orgasmic ability between SCI according to SS at T11-L2 & S2–S5 dermatomes, completeness of injury & UMN or LMN dysfunction.
| • Age: Arousal study - SCI 33.9 (NR) y; ctrl 34.1 (NR) y. Orgasm study - SCI 32.8 (NR) y; ctrl (NR) y | • Inclusion: NR | • Surgical: NR | • Differences in genital responsiveness to A/V based on degree of sensory impairment affecting T11-L2 dermatomes. Regardless of level of injury, marked dfs in response observed based on degree of combined light touch & in prick sensory preservation at T11-L2 dermatomes. No dfs in genital responsiveness occurred when women classified based on sensory preservation in sacral (S2–S5) or thoracic (T6–T9) dermatomes.
| • Level of Injury: Arousal: C2–L4, 55 UMN (S3–5), 13 LMN, 41 incomplete & 27 complete Orgasm: NR, 12 LMN (S2–5), 50 UMN, 40 complete & 22 incomplete | • Exclusion: neurological surgery with altered structure of nervous system, genital surgery, irregular or absent menstrual cycles, & active medical or psychiatric problems | • Behavioral (All pts) | • Subjective Characteristic of Orgasm: Data reporting location of stimulation to reach orgasm similar for both grps of SCI vs. ctrl
| • ASIA Level: NR | • Quality Assessment: 5 * (NOS) | • Type: A/V erotic stimulation/vaginal/ manual clitoral stimulation (until arousal or orgasm reached) | • DSFI:SCIs scored S lower (m=46.8) vs. ctrl (m=53.0)(p=0.02); SCIs scored lower vs. ctrl in body image (p=0.02); SCIs S less sexually satisfied vs. ctrl on specific & global measures of sexual satisfaction.
| • Duration since injury: 127 (15–494) mo | | • Duration: 78 m
| • Dropouts: n=6 | | • Frequency: Arousal 5 × 6 m baseline periods alternated with 4 stimulus conditions: 2 × 12 m A/V followed by 2 × 12 m AVM: Orgasm: up to 75 m manual stimulation
| • Lost in follow-up: NR
| • N of sites: 1
| • Funding: NIH
Sonksen, 1992, Denmark | • Enrolled/evaluated: n=17/ n=NR | • Study Design: NCS | • Pharmacologic (n=12): | • Outcomes: | • A/E:
(Ref ID 356) | • % Males: 100% | • Duration: NR | • Drug name: Papaverine | • Anatomic/Physiologic: 12/17 responded (+) to nitro-glycerine test: 5 complete response (full rigidity), 7 partial response (some rigidity & /or tumescence) & 5 failed to respond. Median plaster application time: 75 m. Duration of erections in 5 with complete response: 20–45 m post removal of plaster | • Systemic: headaches in n=6, 2/6 required tx with mild analgesics (i.e. paracetamol)
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose: 5–60 mg | • Follow-up: NR
| • Age: 41 (19–51) y | • Inclusion: (+) erection response to 5–60 mg of papaverine injection sufficient for vaginal penetration | • Duration: NR
| • Level of Injury: C2–L3, n=13 complete n=4 incomplete | • Exclusion: NR | • Schedule: NR
| • ASIA Level: NR | • Quality Assessment: 7/19 (+) reported | • Mode/Admin. Route: NR
| • Duration since injury: 7 (1–27) y | | • Device: NR
| • Dropouts: n=0 | | • Other Device:
| • Lost in follow-up: NR | | • Type: Transcutaneous nitro-glycerin plaster (10mg/24 h)
| • N of sites: 1 | | • Surgical: NR
| • Funding: NR | | • Behavioral: NR
Tang, 1995, Republic of China | • Enrolled/ evaluated: n=15/ n=NR | • Study Design: NCS | • Pharmacologic (n=15): | • Outcomes: | • A/E:
(Ref ID 314) | • % Males: 100% | • Duration: NR | • Drug name: prostaglandin E1 | • Anatomic/Physiologic: | • Local: 2 (13.3%) pts complained of discomfort at injection site
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose: starting at 0.5 mg with increased dosage to achieve a rigid erection of grade 5 & lasting for at minimum 20 m (a max. dosage of 20 mg would be applied) | • pre-injection Schramek grading: grade 1 – 8 (53%) pts; grade 2 - 1(7.4%) pt; grade 3 - 2 (13.4%) pts; grade 4 – 1 (6.7%) pts; grade 5 - 3 (20%) pts; post-injection Schramek grading: grade 5 – 14 (93.3%) pts; grade 2 - 1 pt (6.7%); erectile condition post-tx found to be S higher vs. pre-tx (p<0.001); no S dosage effect of prostaglandin E1 found in df between pre-tx & post-tx
| • Age: 38.5 (25–50) y | • Inclusion: NR | • Duration: NR | • Follow-up: NR
| • Level of Injury: C5 1; T4–T12 6; L1–L3 8 (n=8 incomplete lesion) | • Exclusion: NR | • Schedule: max. recommended injection frequency 2 × wk
| • ASIA Level: NR | • Quality Assessment: 12/19 (+) reported | • Mode/Admin. Route intracavernous injection
| • Duration since injury: mean 6.3 y | | • Device: NR
| • Dropouts: n=0 | | • Other Device: NR
| • Lost in follow-up: NR | | • Surgical: NR
| • N of sites: 1 | | • Behavioral: NR
| • Funding: NR
van der Aa, 1995, Netherlands | • Enrolled/ evaluated: n=17/n=NR | • Study Design: NCS | • Pharmacologic: NR | • Outcomes: | • A/E:
(Ref ID 1172) | • % Males: 82%(14) males, 18%(3) females | • Duration: NR | • Device: NR | • Anatomic/Physiologic: | • Other: Disadvantage of posterior rhizotomy: loss of reflex erection
| • Race/ethnicity: NR | • Eligibility Criteria: | • Other Device (n=17): Finetech-Brindley bladder control system | • Sustained full erection in all (n=14) male pts, in 12 pts by stimulation of S2 anterior roots; in 2pts by stimulating S3 anterior roots
| • Age: NR (21–54) y | • Inclusion: Complete lesion of spinal cord, no previous bladder outlet surgery, incontinence, & at least 12 mo post-injury | • Type NR | • Additional Outcomes: Bladder capacity: increase capacity postoperation by >100 ml in 2 pts& >400 ml in 8 pts; Continence: all but 1 continent; Bowel function: 13 pts using implant for defaecation
| • Level of Injury: C5 16 T1–10, All complete lesion | • Exclusion: NR | • Manufacturer NR | • Follow-up:
| • ASIA Level: NR | • Quality Assessment: 3/19 (+) reported | • Surgical: NR | • Length: 1–6 y (longest followup: 4 y)
| • Duration since injury: (1–15) y | | • Behavioral: NR | • Duration: NR
| • Dropouts: n=0 | | | • Results: Although loss of erection is expected post posterior rhizotomy, in this study all male pts managed to achieve erection, usually by stimulating S2 roots
| • Lost in follow-up: NR
| • N of sites: 1
| • Funding: NR
van der Aa, 1999, Netherlands | • Enrolled/ evaluated: n=38/NR | • Study Design: NCS | • Pharmacologic: NA | • Outcomes: | • A/E:
(Ref ID 1075) | • % Males: 87%(33) male; 13%(5) female | • Duration: NR | • Device: NA | • Anatomoic/Physiologic: | • Systemic: death in 3 pts. 1 within 2 wk post intervention & 2 during f/u; pulmonary embolism in 1 pts; implant failure in 3 pts 8, 6 & 3 y post implantation. Cerebro-spinal fluid collection in 3 pts
| • Race/ethnicity: NR | • Eligibility Criteria: | • Other Device (n=38): | • Implant driven sustained full erection achieved in 29/33 males (by stimulating S3 anterior roots in 2 pts, & in 27 pts by stimulation S2 anterior roots. Erection not achieved in 4 pts. BC (n=37): increase in BC observed in all (due to posterior rhizotomy), in 15 more than 200 cc & in 14 pts more than 400 cc. Residual urine volume (n=37): No increase observed postoperation. 27 pts use implant for bowel function. Decrease in urinary tract infection rate postoperation
| • Age: NR (18–59) y | • Inclusion: Completeness of lesion & intact efferent nerve supply to bladder wall minimum 12 mo post-injury | • Type Brindley bladder controller | • Psychological: NR
| • Level of Injury: 9 C4–6 29 T1–12 (all complete) | • Exclusion: NR | • Manufacturer: NR | • Sexual Satisfaction: NR
| • ASIA Level: NR | • Quality Assessment: 5/19 (+) reported | • Surgical: NA | • Pt logs/diaries: NR
| • Duration since injury: (1–39) y | | • Behavioral: NA | • Interviews: NR
| • Dropouts: n=3 | | | • Follow-up: NR
| • Lost in follow-up: n=2
| • N of sites: 1
| • Funding: NR
Whipple, 1996, US | • Enrolled/ evaluated: n=16/ n=NR | • Study Design: Case-control Study | • Pharmacologic: NR | • Outcomes: | • A/E: NR
(Ref ID 1713) | • % Males: 0% (all female) | • Duration: NR | • Device: NR | • Anatomic/Physiologic: multiple orgasms in 1 SCI T11 from vaginal self stimulation, she had increase in SBP, one SCI T8 had six orgasms in lab, two from vaginal self -stimulation, one from cervical self-stimulation, & three from hypersensitive area stimulation
| • Race/ethnicity: | • Eligibility Criteria: | • Other Device (n=16): | • Psychological: NR
| • Age: SCI 37.2 (NR) y; ctrl 45.4 (NR) y | • Inclusion: SCI grp complete ASIA A SCI>1y, with intact uterus & cervix | • Type A pressure transducer embedded in holder behind & aluminum head (Providing self-application to vaginal wall or to cervix) | • Sexual Satisfaction: NR
| • Level of Injury: at or below T6 | • Exclusion: psychosis, depression, or hx of cystocele, hysterectomy | • Manufacturer: NR | • Pt logs/diaries: NR
| • ASIA Level: NR (all complete) | • Quality Assessment: 6 * (NOS) | • Surgical: NR | • Divorce: 2 in SCI & 3 in ctrl grp
| • Duration since injury: 12.4 (2–27) y | | • Behavioral: | • Additional Outcomes: higher incident of SCI women living with partner vs. women without SCI. BP increased S in response to vaginal & cervical self-stimulation only in complete SCI below T10. No Δ in HR in SCI grp. 3 /16 in SCI, n=1 as high as T7 & n=1 without SCI self reported orgasms during laboratory study.
| • Dropouts: n=0 | | • Type vaginal self-stimulation, cervical self-stimulation & hypersensitive area self-stimulation | • Follow-up: NR
| • Lost in follow-up: NR | | • Duration: 90 m
| • N of sites: 1 | | • Frequency: Each experimental condition performed once, preceded & followed by rest period
| • Funding: NR
Zaslau, 1999, US | • Enrolled/ evaluated: n=28/ n=37 | • Study Design: NCS | • Pharmacologic (n=28): | • Outcomes: | • A/E:
(Ref ID 283) | • % Males: 100% | • Duration: May 1994 to March 1997 | • Drug name mixture of PGE-1 & papaverin | • Anatomic/Physiologic: | • Local: 7% (2/28) reported pain & discomfort at injection site
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose: post initial test dose of 0.5 cc, doses adjusted in increments of 0.05 cc, up to a maximum of 1.0 cc | • Erection: 85% of pts rated pharmacologically produced erections as good or excellent with a mean erection of 43 m; vs. all pts reported never or sometimes being able to ejaculate, 21% of those treated became able to ejaculate > 50% of time, 60% reported being always or almost always successful at intercourse representing a S improvement from 93% reporting successful intercourse occurring never or almost never; 35% pts reported being able to have successful intercourse 25–50% of time
| • Age: 43.7 (24–72) y | • Inclusion: NR | • Duration: NR | • Psychological: NR
| • Level of Injury: 13 cervical 15 thoracic & 9 lumbar | • Exclusion: NR | • Schedule: 43% of pts inject themselves >1 × wk | • Sexual Satisfaction: 77% of pts moderately or extremely satisfied with therapy; 90% of participants would recommend this tx to a friend
| • ASIA Level: NR | • Quality Assessment: 10/19 (+) reported | • Mode/Admin. Route: intracavernous injectable. papaverine 1500 mg/50 ml is combined with PGE-1 1000 miug/2ml; normal saline (48cc) is added to mixture, then subdivided into 10 vials with 10 ml of vasoactive substances/vival. Each vial contains 30 mg/ml papaverine & 10 miμg/ml of PGE-1 | • Pt logs/diaries: NR
| • Duration since injury: 8.6 y (1–20) y | | • Device: NR | • Interviews: NR
| • Dropouts: n=5 | | • Other Device: NR | • Follow-up:
| • Lost in follow-up: NR | | • Surgical: NR | • Length: quarterly f/u visits
| • N of sites: 1 | | • Behavioral: NR | • Duration: mean f/u of 15 mo
| • Funding: NR | | | • Results: NR
Zasler, 1989, US | • Enrolled/ evaluated: n=20/ n=NR | • Study Design: NCS | • Pharmacologic: NR | • Outcomes: | • A/E:
(Ref ID 386) | • % Males: 100% | • Duration: 1y (included intervention +follow-up) | • Device: Synergist erection system) (n=20) | • Anatomic/Physiologic: NR | • Local: iscomfort during intercourse with use of device in n=1. Another partner reported that she could feel seam of device. Several episodes of reflex micturition by males (n=2), resulting in loss of tumescent state but maintenance of voided urine within device
| • Race/ethnicity: NR | • Eligibility Criteria: | • Manufacturer Synergist Ltd.,Fannin, Houston, TX | • Reflexogenic erectile capability: absent in 4 pts, partial tumescence (insufficient for vaginal penetration), & n=6 complete. Snap-gauge assessment: n=8 without any broken bands, n=4 with one, n=2 with two & n=6 with all three band broken. This assessment correlated well(r=0.92, p<0.001) with subjective reports of erectile capability
| • Age: 40 (21–65) y | • Inclusion: At least 1 y post injury, with neurogenic impotence, steady partner | • Frequency: NR | • Psychological: NR
| • Level of Injury: C4–L2: 9 cervical 10 thoracic 1 lumbar, n=13 complete n=7 incomplete | • Exclusion: NR | • Mode/Admin. Route Couples assessed for first questionnaire after 20 times use of device. Usage of intervention device varied from several times per mo to as frequently as daily during f/u period | • Sexual Satisfaction: See follow-up
| • ASIA Level: NR | • Quality Assessment: 13/19 (+) reported | • Other Device: NR | • Pt logs/diaries: NR
| • Duration since injury: ≥ 1y post | | • Surgical: NR | • Interviews: NR
| • Dropouts: n=2 | | • Behavioral: NR | • Follow-up (n=15 pts & n=14 partners): Sexual Satisfaction questionnaire
| • Lost in follow-up: NR | | | • Duration: Baseline & at 6 mo
| • N of sites: 1 | | | • Results: quality of vaginal intercourse rated very good to excellent vs. to previous best since injury(r=0.78, p<0.001), 2 couples rated as fair to good (orogenital preference)
| • Funding: NR

SCI = spinal cord injury; AB = able-bodied; NR = not reported; NA = not applicable; y = year; d = day; mo = month; wk = week; m = minute; hrs = hours; ctrl = control(s); grp = group; pbo = placebo; NCS = non-comparative case series; mg = milligrams; miμg/μg = microgram; tx = treatment; hx = history; Δ = change; S = significant; NS = nonsignificant; df(s) = difference(s); pts = participants; n = n of participants; enrolled = n qualified; evaluated = n analyzed; t.i.d = three times daily; b.i.d = two times daily; (+) = positive; A/E = adverse event; ED = erectile dysfunction; SD = sexual dysfunction; IIEF = Index of Erectile Function; μg = microgram; NOS = Newcastle Ottawa Scale; DSFI = Derogastis Sexual Function Inventory; A/V = audio visual; VPA = vaginal pulse amplitude; UMN = upper motor neuron; LMN = lower motor neuron; NIH = National Institute of Health; BP = blood pressure; HR = heart rate; SBP = systolic blood pressure; cm = centimeters; sec = seconds; RCT = randomized clinical trial; A/E = Adverse Events; PD = pain detecting; PT = pain tolerance; PPS = photoelectric pulse sensor; DBP = diastolic blood pressure; RR = respiratory rate; Hz = Hertz; NIMH = National Institute of Mental Health; MS = multiple sclerosis; mm HG = millimetre(s) of mercury; ; NIDRR = National Institute on Disability & Rehabilitation Research; MRRTC = Medical Rehabilitation Research & Training Centre; NIDRR = The National Institute on Disability & Rehabilitation Research; USIEF = US Israel Educational Foundation; FRSQ = Fonds de la Recherche en Sante du Quebec; BC = bladder capacity; IRP = International Institute for Research in Paraplegia; SNF = Swiss National Science Foundation; PB = blood pressure; VCD = vacuum constriction device; μg/miμg = microgram; DBT = diabetics

Evidence Table 6. Evidence from conference proceedings regarding sildenafil & other remediation for the treatment of sexual dysfunction in individuals after SCI

Author, Year, Location | Study Characteristics | Study Design & Duration/Quality Assessment/Eligibility Criteria | Intervention (e.g.,Pharmacologic/Device/Behavioral/Surgical/other) | Outcomes/Follow-up | Adverse Events/ Complications
Anonymous, 1999 UK | • Enrolled/ evaluated: n=26/n=26 | • Study Design: Abstract from conference proceeding | • Pharmacologic (n=26): | • Outcomes: | • A/E:
(Ref ID 2071) | • % males: 100% | • Duration: 28 d | • Drug name: sildenafil /pbo | • Anatomic/Physiologic: Improved quality of erections post sildenafil tx: After 28 d, 75% of sildenafil-tx & 7% of pbo-tx men reported improved erections. Sildenafil grp had > % of successful attempts at sexual intercourse (30% vs.15%). Total of 67% of sildenafil grp wanted to continue tx vs. 15% of pbo grp. | • Systemic: n=2 with possible sildenafil-related A/E - dyspepsia & respiratory disorder. Neither stopped tx.
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose: 50 mg | • Follow-up: NR
| • Age: NR (21–49) y | • Inclusion: Ability to achieve at min. moderate reflexogenic erectile response to PVS | • Duration: 28 d for both tx
| • Level of Injury: T6-L5 | • Exclusion: NR | • Schedule: 1 hr pre sexual activity but not > 1× per d
| • ASIA Level: NR | • Quality Assessment: NA | • Mode/Admin. Route: NR
| • Duration since injury: NR | | • Device: NR
| • Drop-outs: n=0 | | • Other Device: NR
| • Lost in Follow-up: NR | | • Surgical: NR
| • N of sites: 1 | | • Behavioral: NR
| • Funding: Pfizer
Bodner, 1998, US | • Enrolled/ evaluated: n=15/NR | • Study Design: Abstract from conference proceeding - interventional (time series before/after trial) | • Pharmacologic (n=15): | • Outcomes: | • A/E:
(Ref ID 3021) | • % male: 100% | • Duration: NR | • Drug name: alprostadil (MUSE) | • Anatomic/Physiologic: NR | • Local: no evidence of priapism
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose: 125–1000 μg | • Psychological: NR | • Systemic: transient hypotension in 8/15
| • Age: NR | • Inclusion: SCI ≥1 y post injury | • Duration: NR | • Sexual Satisfaction: only effective dose 1000 μg, 3/15 used MUSE at home; 0/15 satisfied with quality of erection vs. IC tx (rate of 50–60% vs. IC tx); hypotension in 8/17 used MUSE without Actis ring; 7/15 used Actis ring with no transient hypotension
| • Level of Injury: NR | • Exclusion: NR | • Schedule: NR | • Patient logs/diaries: NR
| • ASIA Level: NR | • Quality Assessment: NA | • Mode/Admin. Route: intraurethral admin. By physician or pts | • Interviews: NR
| • Duration since injury: all ≥ 1y | | • Device: NR | • Follow-up: NR
| • Dropouts: n=0 | | • Other Device: Type: Actis ring
| • Lost in follow-up: NR | | • Surgical: NR
| • N of sites: 1 | | • Behavioral: NR
| • Funding: NR
Clontz, 1999, US | • Enrolled/ evaluated: n=12/NR | • Study Design: Abstract from conference proceeding - interventional (time series before/after trial) | • Pharmacologic (n=12): | • Outcomes: | • A/E:
(Ref ID 3023) | • % males: 100% | • Duration: NR | • Drug name: sildenafil | • Anatomic/Physiologic: NR | • Systemic: visual Δs in 1/12; headache in 3/12
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose: 50 mg | • Psychological: NR
| • Age: 40 (21–54) y | • Inclusion: NR | • Duration: NR | • Sexual Satisfaction: mean IIEF scores of satisfaction (4 wk f/u; range 1–10) male, 8.9 female, 9.0; erectile function improved in 9/12 (75%); 3/12(25%) experienced side effects
| • Level of Injury: n=5 cervical; n=5 thoracic; n=2 lumbar; (8/12 incomplete; 4/12 complete) | • Exclusion: NR | • Schedule: NR | • Patient logs/diaries:
| • ASIA Level: NR | • Quality Assessment: NA | • Mode/Admin. Route: 5 samples of sildenafil/ pts | • Interviews:
| • Duration since injury: NR | | • Device: NR | • Follow-up:
| • Dropouts: n=0 | | • Other Device: NR | • Duration: NR
| • Lost in follow-up: NR | | • Surgical: NR | • Result: all pts (n=12) continued to use sildenafil
| • N of sites: 1 | | • Behavioral: NR
| • Funding: NR
Kier, 1999, US | • Enrolled/ evaluated: n=29/NR | • Study Design: Abstract from conference proceeding - interventional (time series before/after trial) | • Pharmacologic (n=29): | • Outcomes: | • A/E:
(Ref ID 3033) | • % males: 100% | • Duration: NR | • Drug name: sildenafil | • Anatomic/Physiologic: NR | • Systemic: headache (17%); dizziness (3%); flushing (3%)
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose: 50 mg | • Psychological: NR
| • Age: 39.3 (21–54) y | • Inclusion: NR | • Duration: NR | • Sexual Satisfaction: IIEF post 4 wks, improvement in ED - 83%(24/29); mean Δ in IIEF 18.3; range -39 to +55; mean pt & partner satisfaction, 8.29, & 8.46, respectively (range 1–10)
| • Level of Injury: n=11 cervical, n=14 thoracic, n=4 lumbar; 17/29 complete lesion, 12/29 incomplete lesion | • Exclusion: NR | • Schedule: NR | • Patient logs/diaries: NR
| • ASIA Level: NR | • Quality Assessment: NA | • Mode/Admin. Route: 5 dose of 50 mg /pt | • Interviews: NR
| • Duration since injury: NR | | • Device: NR | • Follow-up:
| • Dropouts: n=0 | | • Other Device: NR | • Length: NR
| • Lost in follow-up: NR | | • Surgical: NR | • Duration: NR
| • N of sites: 1 | | • Behavioral: NR | • Results: 25/29 (86%) found sildenafil effective & continue to use tx at home
| • Funding: NR
Laschke, 2002, Germany | • Enrolled/ evaluated: n=69/n=NR | • Study Design: Abstract from conference proceeding - interventional (time series before/after trial) | • Pharmacologic (n=69): | • Outcomes: | • A/E:
(Ref ID 3041) | • % Males: 100% | • Duration: 12 wk /IIEF questionnaire completed at 4, 8 & 12 wk | • Drug name: sildenafil | • Anatomic/Physiologic: erection & overall sexual satisfaction improvement of approx. 90% in responder grp | • Systemic: flushing & headache in 25% of pts. 10% had impairment of chromatic vision
| • Race/ethnicity: | • Eligibility Criteria: | • Dose: NR | • Follow-up:
| • Age: NR | • Inclusion: NR | • Duration: NR | • Length: 2–3 mo f/u
| • Level of Injury: NR | • Exclusion: NR | • Schedule: NR | • Results: scores on IIEF NS Δ's in efficacy
| • ASIA Level: NR | • Quality Assessment: NA | • Mode/Admin. Route: NR
| • Duration since injury: NR | | • Device: NR
| • Dropouts: n=0 | | • Other Device: NR
| • Lost in follow-up: NR | | • Surgical: NR
| • N of sites: 1 | | • Behavioral: NR
| • Funding: NR
Raviv, 2000, Israel | • Enrolled/ evaluated: n=60/NR | • Study Design: Abstract from conference proceeding - interventional (time series before/after trial) | • Pharmacologic (n=60): | • Outcomes: | • A/E: NR
(Ref ID 3006) | • % males: 100% | • Duration: NR | • Drug name: sildenafil | • Anatomic/Physiologic: NR
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose: starting dose of 50 mg increased to 100 mg (25 mg in 13 quadriplegic pts) | • Psychological: NR
| • Age: 35.2 (19–58) y | • Inclusion: NR | • Duration: NR | • Sexual Satisfaction: UMN grp success rate as defined by improvement in ability to have sexual intercourse, & wish to continue tx, 31/35(89%); in UMN grp, 18/25(72%); overall success rate 49/60(82%); IIEF score improvement from mean, 5.48 to 6.55 (p<0.001)
| • Level of Injury: 35 UMN, 13–35 quadriplegic; 25 LMN | • Exclusion: NR | • Schedule: NR | • Patient logs/diaries: NR
| • ASIA Level: NR | • Quality Assessment: NA | • Mode/Admin. Route: oral | • Interviews: NR
| • Duration since injury: 26.8 (4–56) y | | • Device: NR | • Follow-up: NR
| • Dropouts: (n=0) | | • Other Device: NR
| • Lost in follow-up: NR | | • Surgical: NR
| • N of sites: 1 | | • Behavioral: NR
| • Funding: NR
Shenot, 1999, US | • Enrolled/ evaluated: n=29/NR | • Study Design: Abstract from conference proceeding -interventional (time series before/after trial) | • Pharmacologic (n=29): | • Outcomes: | • A/E:
(Ref ID 3024) | • % males: 100% | • Duration: NR | • Drug name: sildenafil | • Anatomic/Physiologic: NR | • Systemic: headache (7%); flushing (7%)
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose: starting dose 50 mg; titrated to 100 mg if submaximal result obtained with 50 mg | • Psychological: NR
| • Age: 26.3 (NR) y | • Inclusion: NR | • Duration: NR | • Sexual Satisfaction: all pts used 100 mg sildenafi; (efficacy at 6–8 wks using a physician-administered questionnaire) (+) drug effect on duration & rigidity of erections in 12/29(41%); erections satisfactory for intercourse in 4/29(14%)
| • Level of Injury: C5-L1 | • Exclusion: NR | • Schedule: NR | • Patient logs/diaries: NR
| • ASIA Level: NR | • Quality Assessment: NA | • Mode/Admin. Route: oral | • Interviews: NR
| • Duration since injury: NR | | • Device: NR | • Follow-up: NR
| • Dropouts: n=0 | | • Other Device: NR
| • Lost in follow-up: NR | | • Surgical: NR
| • N of sites: 1 | | • Behavioral: NR
| • Funding: NR
Takeda, 2000, Japan | • Enrolled/ evaluated: n=36/NR | • Study Design: Abstract from conference proceeding - interventional (time series before/after trial) | • Pharmacologic (n=36): | • Outcomes: | • A/E:
(Ref ID 3005) | • % males: 100% | • Duration: 3 mo | • Drug name: sildenafil | • Anatomic/Physiologic: IIEF5 score range 1–16 with mean of 5.8; drug assessed effective 22(56%); ineffective 5(13%); & unknown in 12 pts (efficacy evaluation only in pts with successful sexual intercourse followed 1 mo post dispensing the drug) | • Systemic: autonomic dysreflexia in n=6 included headache, facial flush, chest strangled feeling
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose: NR | • Psychological: NR
| • Age: 33.9 (18–59) y | • Inclusion: NR | • Duration: 3 mo | • Sexual Satisfaction: NR
| • Level of Injury: n=10 cervical; n=5 T1–6; n=12 T7–12; n=9 lumbar lesions | • Exclusion: NR | • Schedule: NR | • Patient logs/diaries: NR
| • ASIA Level: NR | • Quality Assessment: NA | • Mode/Admin. Route: oral | • Interviews: NR
| • Duration since injury: NR | | • Device: NR | • Follow-up: NR
| • Dropouts: (n=0) | | • Other Device: NR
| • Lost in follow-up: NR | | • Surgical: NR
| • N of sites: 1 | | • Behavioral: NR
| • Funding: NR
Waldbaum, 1998, US | • Enrolled/ evaluated: n=15/NR | • Study Design: Abstract from conference proceeding - interventional (time series before/after trial) | • Pharmacologic (n=15): | • Outcomes: | • A/E: NR
(Ref ID 3004) | • % males: 100% | • Duration: NR | • Drug name: MUSE/prostaglandin E1 | • Anatomic/Physiologic: 4/15 achieved erection (grade?) with MUSE tx; 7/8/ remainder 11 pts achieved erection with prostaglandine E1 tx.
| • Race/ethnicity: NR | • Eligibility Criteria: | • Dose: NR | • Psychological: NR
| • Age: NR | • Inclusion: NR | • Duration: NR | • Sexual Satisfaction: NR
| • Level of Injury: NR | • Exclusion: NR | • Schedule: NR | • Patient logs/diaries: NR
| • ASIA Level: NR | • Quality Assessment: NA | • Mode/Admin. Route: intraurethral admin of MUSE; intracavernous injection of prostaglandine E1(alprostadil) | • Interviews: NR
| • Duration since injury: NR | | • Device: NR | • Follow-up: NR
| • Dropouts: n=0 | | • Other Device: NR
| • Lost in follow-up: NR | | • Surgical: NR
| • N of sites: 1 | | • Behavioural: NR
| • Funding: NR

SCI = spinal cord injury; AB = able-bodied; NR = not reported; NA = not applicable; y = year; d = day; mo = month; wk = week; hrs = hours; m = minute; cm = centimeters; sec = seconds; mg = milligrams; μg = microgram; ctrl = control(s); grp = group; pbo = placebo; RCT = randomized clinical trial; tx = treatment; hx = history; Δ = change; S = significant; df(s) = difference(s); NS = nonsignificant; pts = participants; n = n of participants; enrolled = n qualified; evaluated = n analyzed; (+) = positive; A/E = Adverse Events; HR = heart rate; BP = blood pressure; t.i.d = three times daily; b.i.d = two times daily; ED = erectile dysfunction; IIEF = Index of Erectile Function; PVS = penile vibratory stimulation; A/E = adverse event; IC = intracavernosal; UMN = upper motor neuron; LMN = lower motor neuron

## Listing of Studies Included in Evidence Tables

### Fertility

Bensman A, Kottke F J. Induced emission of sperm utilizing electrical stimulation of the seminal vesicles and vas deferens. Arch Phys Med Rehabil. 1966;47(7):436-43. [pmid: 4952412].
Beretta G, Chelo E, Zanollo A. Reproductive aspects in spinal cord injured males. Paraplegia. 1989;27(2):113-8. [pmid: 2717193].
Beretta G, Zanollo A, Chelo E, Livi C, Scarselli G. Seminal parameters and auto-immunity in paraplegic/quadraplegic men. Acta Eur Fertil. 1987;18(3):203-5. [pmid: 3439407].
Brackett N L, Abae M, Padron O F, Lynne C M. Treatment by assisted conception of severe male factor infertility due to spinal cord injury or other neurologic impairment. J Assist Reprod Genet. 1995;12(3):210-6. [pmid: 8520188].
Brackett N L, Davi R C, Padron O F, Lynne C M. Seminal plasma of spinal cord injured men inhibits sperm motility of normal men. J Urol. 1996;155(5):1632-5. [pmid: 8627840].
Brackett N L, Lynne C M, Aballa T C, Ferrell S M. Sperm motility from the vas deferens of spinal cord injured men is higher than from the ejaculate. J Urol. 2000;164(3 Pt 1):712-5. [pmid: 10953131].
Brackett N L, Lynne C M, Weizman M S, Bloch W E, Abae M. Endocrine profiles and semen quality of spinal cord injured men. J Urol. 1994;151(1):114-9. [pmid: 8254785].
Brackett N L, Lynne C M, Weizman M S, Bloch W E, Padron O F. Scrotal and oral temperatures are not related to semen quality of serum gonadotropin levels in spinal cord-injured men. J Androl. 1994;15(6):614-9. [pmid: 7721665].
Brackett N L, Padron O F, Lynne C M. Semen quality of spinal cord injured men is better when obtained by vibratory stimulation versus electroejaculation. J Urol. 1997;157(1):151-7. [pmid: 8976239].
Brackett N L, Santa-Cruz C, Lynne C M. Sperm from spinal cord injured men lose motility faster than sperm from normal men: the effect is exacerbated at body compared to room temperature. J Urol. 1997;157(6):2150-3. [pmid: 9146604].
Brindley G S. Electroejaculation and the fertility of paraplegic men. Sex Disabil. 1981;3(3):225-9.
Brindley G S. The fertility of men with spinal injuries. Paraplegia. 1984;22(6):337-48. [pmid: 6335235].
Brindley G S. Electroejaculation: its technique, neurological implications and uses. J Neurol Neurosurg Psychiatry. 1981;44(1):9-18. [pmid: 6451670].
Brindley G S, Scott G I, Hendry W F. Vas cannulation with implanted sperm reservoirs for obstructive azoospermia or ejaculatory failure. Br J Urol. 1986;58(6):721-3. [pmid: 3801834].
Brinsden P R, Avery S M, Marcus S, Macnamee M C. Transrectal electroejaculation combined with in-vitro fertilization: effective treatment of anejaculatory infertility due to spinal cord injury. Hum Reprod. 1997;12(12):2687-92. [pmid: 9455836].
Buch J P, Zorn B H. Evaluation and treatment of infertility in spinal cord injured men through rectal probe electroejaculation. J Urol. 1993;149(5 Pt 2):1350-4. [pmid: 8479034].
Chapelle P A, Blanquart F, Puech A J, Held J P. Treatment of anejaculation in the total paraplegic by subcutaneous injection of Physostigmine. Paraplegia. 1983;21(1):30-6. [pmid: 6835690].
Chen D, Hartwig D M, Roth E J. Comparison of sperm quantity and quality in antegrade V retrograde ejaculates obtained by vibratory penile stimulation in males with spinal cord injury. Am J Phys Med Rehabil. 1997;78(1):46-55. [pmid: 9923429].
Chen D, Hartwig D M, Roth E J. Comparison of sperm quantity and quality in antegrade V retrograde ejaculates obtained by vibratory penile stimulation in males with spinal cord injury. Am J Phys Med Rehabil. 1999;78(1):46-51. [pmid: 9923429].
Chung P H, Verkauf B S, Mola R, Skinner L, Eichberg R D, Maroulis G B. Correlation between semen parameters of electroejaculates and achieving pregnancy by intrauterine insemination. Fertil Steril. 1997;67(1):129-32. [pmid: 8986697].
Dahlberg A, Ruutu M, Hovatta O. Pregnancy results from a vibrator application, electroejaculation, and a vas aspiration programme in spinal-cord injured men. Hum Reprod. 1995;10(9):2305-7. [pmid: 8530657].
de Lamirande E, Leduc B E, Iwasaki A, Hassouna M, Gagnon C. Increased reactive oxygen species formation in semen of patients with spinal cord injury. Fertil Steril. 1995;63(3):637-42. [pmid: 7851599].
Elliott S L, Griffin S, Ekland M, Nigro M. Vibrostimulation - techniques and results. J Spinal Cord Med. 2000;23(3):175.
Elliott S L, Nigro M, Ekland M B, Griffin S, Allison G. The Vancouver experience: sperm retrieval program. J Spinal Cord Med. 2002;25(Suppl1):s14.
Halstead L S, VerVoort S, Seager S W. Rectal probe electrostimulation in the treatment of anejaculatory spinal cord injured men. Paraplegia. 1987;25(2):120-9. [pmid: 3495772].
Hellstrom W J, Stone A R, Deitch A D, deVere White R W. The clinical application of aspiration deoxyribonucleic acid flow cytometry to neurologically impaired men entering an electroejaculation program. J Urol. 1989;142(2 Pt 1):309-12. [pmid: 2787410].
Heruti R J, Katz H, Menashe Y, Weissenberg R, Raviv G, Madjar I, et al. Treatment of male infertility due to spinal cord injury using rectal probe electroejaculation: the Israeli experience. Spinal Cord. 2001;39(3):168-75. [pmid: 11326328].
Hirsch I H, McCue P, Allen J, Lee J, Staas W E. Quantitative testicular biopsy in spinal cord injured men: comparison to fertile controls. J Urol. 1991;146(2):337-41. [pmid: 1856929].
Hirsch I H, Sedor J, Callahan H J, Staas W E. Antisperm antibodies in seminal plasma of spinal cord-injured men. Urology. 1992;39(3):243-7. [pmid: 1546417].
Hirsch I H, Sedor J, Kulp D, McCue P J, Staas W E Jr. Objective assessment of spermatogenesis in men with functional and anatomic obstruction of the genital tract. Int J Androl. 1994;17(1):29-34. [pmid: 8005706].
Hou J W, Chen D, Jeyendran R S. Sperm nuclear maturity in spinal cord-injured men: evaluation by acidic aniline blue stain. Arch Phys Med Rehabil. 1995;76(5):444-5. [pmid: 7537955].
Hultling C, Levi R, Garoff L, Nylund L, Rosenborg L, Sjoblom P, et al. Assisted ejaculation combined with in vitro fertilisation: an effective technique treating male infertility due to spinal cord injury. Paraplegia. 1994;32(7):463-7. [pmid: 7970847].
Hultling C, Rosenlund B, Levi R, Fridstrom M, Sjoblom P, Hillensjo T. Assisted ejaculation and in-vitro fertilization in the treatment of infertile spinal cord-injured men: the role of intracytoplasmic sperm injection. Hum Reprod. 1997;12(3):499-502. [pmid: 9130750].
Kolettis P N, Lambert M C, Hammond K R, Kretzer P A, Steinkampf M P, Lloyd L K. Fertility outcomes after electroejaculation in men with spinal cord injury. Fertil Steril. 2002;78(2):429-31. [pmid: 12137889].
Le Chapelain L, Nguyen V T, Dehail P, Berjon J J, Barat M, Mazaux J M, et al. Ejaculatory stimulation, quality of semen and reproductive aspects in spinal cord injured men. Spinal Cord. 1998;36(2):132-6. [pmid: 9495004].
Leduc B E, Roy D, Poulin O. The use of physostigmine in men with spinal cord injury with ejaculatory dysfunction. Can J Rehab. 1992;5(4):231-5.
Lim T C, Mallidis C, Hill S T, Skinner D J, Carter P D, Brown D J, et al. A simple technique to prevent retrograde ejaculation during assisted ejaculation. Paraplegia. 1994;32(3):142-9. [pmid: 8008416].
Loecher-Ernst D, Grosse J, Mandalka B, Kramer G, Stohrer M. Semen retrieved and fertility in 229 spinal cord injured males:longterm results of a fertility program in spinal cord injured males. J Spinal Cord Med. 1998;21(2):164.
Lucas M G, Hargreave T B, Edmond P, Creasey G H, McParland M, Seager S W. Sperm retrieval by electroejaculation. Preliminary experience in patients with secondary anejaculation. Br J Urol. 1991;67(2):191-4. [pmid: 2004235].
Mallidis C, Lim T C, Hill S T, Skinner D J, Brown D J, Johnston W I, et al. Necrospermia and chronic spinal cord injury. Fertil Steril. 2000;74(2):221-7. [pmid: 10927035].
Mallidis C, Lim T C, Hill S T, Skinner D J, Brown D J, Johnston W I, et al. Collection of semen from men in acute phase of spinal cord injury. Lancet. 1994;343(8905):1072-3. [pmid: 7909101].
Martin D E, Warner H, Crenshaw T L, Crenshaw R T, Shapiro C E, Perkash I. Initiation of erection and semen release by rectal probe electrostimulation (RPE). J Urol. 1983;129(3):637-42. [pmid: 6834568].
Matthews G J, Gardner T A, Eid J F. In vitro fertilization improves pregnancy rates for sperm obtained by rectal probe ejaculation. J Urol. 1996;155(6):1934-7. [pmid: 8618291].
Monga M, Dunn K, Rajasekaran M. Characterization of ultrastructural and metabolic abnormalities in semen from men with spinal cord injury. J Spinal Cord Med. 2001;24(1):41-6. [pmid: 11587434].
Nehra A, Werner M A, Bastuba M, Title C, Oates R D. Vibratory stimulation and rectal probe electroejaculation as therapy for patients with spinal cord injury: semen parameters and pregnancy rates. J Urol. 1996;155(2):554-9. [pmid: 8558659].
Odum L, Sonksen J, Biering-Sorensen F. Seminal somatostatin in men with spinal cord injury. Paraplegia. 1995;33(7):374-6. [pmid: 7478725].
Ohl D A, Bennett C J, McCabe M, Menge A C, McGuire E J. Predictors of success in electroejaculation of spinal cord injured men. J Urol. 1989;142(6):1483-6. [pmid: 2585621].
Ohl D A, Denil J, Fitzgerald-Shelton K, McCabe M, McGuire E J, Menge A C, et al. Fertility of spinal cord injured males: effect of genitourinary infection and bladder management on results of electroejaculation. J Am Paraplegia Soc. 1992;15(2):53-9. [pmid: 1583503].
Ohl D A, Sonksen J, Menge A C, McCabe M, Keller L M. Electroejaculation versus vibratory stimulation in spinal cord injured men: sperm quality and patient preference. J Urol. 1997;157(6):2147-9. [pmid: 9146603].
Padron O F, Brackett N L, Weizman M S, Lynne C M. Semen of spinal cord injured men freezes reliably. J Androl. 1994;15(3):266-9. [pmid: 7928669].
Park C I, Shin J, Kim D, Cho S. Ejaculatory induction and semen analysis with vibratory and electrical stimulation in spinal cord injured patients. Arch Phys Med Rehabil. 1999;80:1195.
Perkash I, Martin D E, Warner H, Blank M S, Collins D C. Reproductive biology of paraplegics: results of semen collection, testicular biopsy and serum hormone evaluation. J Urol. 1985;134(2):284-8. [pmid: 3927013].
Pryor J L, Kuneck P H, Blatz S M, Thorp C, Cornwell C E, Carrell D T. Delayed timing of intrauterine insemination results in a significantly improved pregnancy rate in female partners of quadriplegic men. Fertil Steril. 2001;76(6):1130-5. [pmid: 11730739].
Pryor J L, LeRoy S C, Nagel T C, Hensleigh H C. Vibratory stimulation for treatment of anejaculation in quadriplegic men. Arch Phys Med Rehabil. 1995;76(1):59-64. [pmid: 7811177].
Rawicki H B, Hill S. Semen retrieval in spinal cord injured men. Paraplegia. 1991;29(7):443-6. [pmid: 1784510].
Rutkowski S B, Middleton J W, Truman G, Hagen D L, Ryan J P. The influence of bladder management on fertility in spinal cord injured males. Paraplegia. 1995;33(5):263-6. [pmid: 7630651].
Sarkarati M, Rossier A B, Fam B A. Experience in vibratory and electro-ejaculation techniques in spinal cord injury patients: a preliminary report. J Urol. 1987;138(1):59-62. [pmid: 3496469].
Seager S W J, Halstead L S. Electroejaculation - techniques and results. J Spinal Cord Med. 2000;23(3):174.
Siosteen A, Forssman L, Steen Y, Sullivan L, Wickstrom I. Quality of semen after repeated ejaculation treatment in spinal cord injury men. Paraplegia. 1990;28(2):96-104. [pmid: 2235028].
Sonksen J, Biering-Sorensen F, Kristensen J K. Ejaculation induced by penile vibratory stimulation in men with spinal cord injuries. The importance of the vibratory amplitude. Paraplegia. 1994;32(10):651-60.
Sonksen J, Sommer P, Biering-Sorensen F, Ziebe S, Lindhard A, Loft A, et al. Pregnancy after assisted ejaculation procedures in men with spinal cord injury. Arch Phys Med Rehabil. 1997;78(10):1059-61. [pmid: 9339152].
Taylor Z, Molloy D, Hill V, Harrison K. Contribution of the assisted reproductive technologies to fertility in males suffering spinal cord injury. Aust N Z J Obstet Gynaecol. 1999;39(1):84-7. [pmid: 10099757].
VerVoort S M, Donovan W H, Dykstra D D, Syers P. Increased current delivery and sperm collection using nifedipine during electroejaculation in men with high spinal cord injuries. Arch Phys Med Rehabil. 1988;69(8):595-7. [pmid: 3408330].
Wang Y H, Chiang H S, Wu C H, Lien I N. Electroejaculation in spinal cord injured males. J Formos Med Assoc. 1992;91(4):413-8. [pmid: 1358310].
Warner H, Martin D E, Perkash I, Speck V, Nathan B. Electrostimulation of erection and ejaculation and collection of semen in spinal cord injured humans. J Rehabil Res Dev. 1986;23(3):21-31. [pmid: 3490567].

### Sexual Dysfunction

Beretta G, Saltarelli O, Marzotto M, Zanollo A, Re B. Transcutaneous minoxidil in the treatment of erectile dysfunctions in spinal cord injured men. Acta Eur Fertil. 1993;24(1):27-30. [pmid: 8303971].
Beretta G, Zanollo A, Fanciullacci F, Catanzaro F. Intracavernous injection of papaverine in paraplegic males. Acta Eur Fertil. 1986;17(4):283-4. [pmid: 3577592].
Bodner D R, Haas C A, Krueger B, Seftel A D. Intraurethral alprostadil for treatment of erectile dysfunction in patients with spinal cord injury. Urology. 1999;53(1):199-202. [pmid: 9886612].
Bodner D R, Seftel A, Krueger B. Intraurethral Alprostsdil (MUSE) for treatment of erectile dysfunction in spinal cord injured patients. J Spinal Cord Med. 1998;21(2):186-7.
Chancellor M B, Rivas D A, Panzer D E, Freedman M K, Staas W E Jr. Prospective comparison of topical minoxidil to vacuum constriction device and intracorporeal papaverine injection in treatment of erectile dysfunction due to spinal cord injury. Urology. 1994;43(3):365-9. [pmid: 8134992].
Chapelle P A, Roby-Brami A, Yakovleff A, Bussel B. Neurological correlations of ejaculation and testicular size in men with a complete spinal cord section. J Neurol Neurosurg Psychiatry. 1988;51(2):197-202. [pmid: 3346683].
Clontz D, Kier A, Land D, Hudson B, Kennelly M. Effects of sildenafil on spinal cord injury patients suffering from erectile dysfunction. J Spinal Cord Med. 1999;22(1):48-9.
Costa P, Bressolle F, Sarrazin B, Mosser J, Navratil H, Galtier M. Moxisylyte plasma kinetics in humans after intracavernous administration. Biopharm Drug Dispos. 1992;13(9):671-9. [pmid: 1467454].
Costa P, Sarrazin B, Bressolle F, Mottet N, Louis J F, Saudubray F, et al. Is the volume injected a parameter likely to influence the erectile response observed after intracavernous administration of an alpha-blocking agent?. Eur Urol. 1993;24(1):43-7. [pmid: 8365438].
Courtois F, Mathieu C, Charvier K. Sexual rehabilitation for men with spinal cord injury: Preliminary report on a behavioral strategy. Sex Disabil. 2001;19(2):153-7.
Derry F A, Dinsmore W W, Fraser M, Gardner B P, Glass C A, Maytom M C, et al. Efficacy and safety of oral sildenafil (Viagra) in men with erectile dysfunction caused by spinal cord injury. Neurology. 1998;51(6):1629-33. [pmid: 9855514].
Earle C M, Keogh E J, Ker J K, Cherry D J, Tulloch A G, Lord D J. The role of intracavernosal vasoactive agents to overcome impotence due to spinal cord injury. Paraplegia. 1992;30(4):273-6. [pmid: 1625897].
Gans W H, Zaslau S, Wheeler S, Galea G, Vapnek J M. Efficacy and safety of oral sildenafil in men with erectile dysfunction and spinal cord injury. J Spinal Cord Med. 2001;24(1):35-40. [pmid: 11587433].
Giuliano F, Hultling C, El Masry WS, Luchner E, Stien R, Maytom MC, et al. Sildenafil citrate (VIAGRA): a novel oral treatment for erectile dysfunction caused by traumatic spinal cord injury. Int J Clin Pract 1999;Supplement. 102:24–6.
Giuliano F, Hultling C, El Masry W S, Smith M D, Osterloh I H, Orr M, et al. Randomized trial of sildenafil for the treatment of erectile dysfunction in spinal cord injury. Sildenafil Study Group. Ann Neurol. 1999;46(1):15-21. [pmid: 10401776].
Golji H. Experience with penile prosthesis in spinal cord injury patients. J Urol. 1979;121(3):288-9. [pmid: 430620].
Green B G, Sloan S L. Penile prostheses in spinal cord injured patients: combined psychosexual counselling and surgical regimen. Paraplegia. 1986;24(3):167-72. [pmid: 3748596].
Gross A J, Sauerwein D H, Kutzenberger J, Ringert R H. Penile prostheses in paraplegic men. Br J Urol. 1996;78(2):262-4. [pmid: 8813925].
Heller L, Keren O, Aloni R, Davidoff G. An open trial of vacuum penile tumescence: constriction therapy for neurological impotence. Paraplegia. 1992;30(8):550-3. [pmid: 1522995].
Hirsch I H, Smith R L, Chancellor M B, Bagley D H, Carsello J, Staas W E Jr. Use of intracavernous injection of prostaglandin E1 for neuropathic erectile dysfunction. Paraplegia. 1994;32(10):661-4. [pmid: 7831071].
Hultling C. Partners' perceptions of the efficacy of sildenafil citrate (VIAGRA) in the treatment of erectile dysfunction. Int J Clin Pract 1999;Supplement. 102:16–8.
Hultling C, Giuliano F, Quirk F, Pena B, Mishra A, Smith M D. Quality of life in patients with spinal cord injury receiving Viagra (sildenafil citrate) for the treatment of erectile dysfunction. Spinal Cord. 2000;38(6):363-70. [pmid: 10889565].
Iwatsubo E, Tanaka M, Takahashi K, Akatsu T. Non-inflatable penile prosthesis for the management of urinary incontinence and sexual disability of patients with spinal cord injury. Paraplegia. 1986;24(5):307-10. [pmid: 3774367].
Jaworski T M, Richards J S, Lloyd L K. Retrospective review of sexual and marital satisfaction of spinal cord injury and diabetic males post penile injection or implant. Urology. 1992;40(2):127-31. [pmid: 1502747].
Kapoor V K, Chahal A S, Jyoti S P, Mundkur Y J, Kotwal S V, Mehta V K. Intracavernous papaverine for impotence in spinal cord injured patients. Paraplegia. 1993;31(10):675-7. [pmid: 8259331].
Kier AJ, Kennelly MJ, Holdren RE, Land DG, Hudson BS, Clontz DR. Sildenafil effects on spinal cord patients with erectile dysfunction. 16th American association of spinal cord injury nurses conference 1999;32–3.
Kim E D, McVary K T. Topical prostaglandin-E1 for the treatment of erectile dysfunction. [see comments.]. J Urol. 1995;153(6):1828-30. [pmid: 7752328].
Kim E D, el Rashidy R, McVary K T. Papaverine topical gel for treatment of erectile dysfunction. J Urol. 1995;153(2):361-5. [pmid: 7815584].
Komisaruk B R, Gerdes C A, Whipple B. ‘Complete’ spinal cord injury does not block perceptual responses to genital self-stimulation in women. Arch Neurol. 1997;54(12):1513-20. [pmid: 9400361].
Laschke S, Carl S, Staehler G, Gerner H J. Efficacy and reproducibility of sildenafil (Viagra) in erectile dysfunction in spinal cord injured men. J Spinal Cord Med. 2002;25(Suppl1):s43. [pmid: 11939466].
Martin D E, Warner H, Crenshaw T L, Crenshaw R T, Shapiro C E, Perkash I. Initiation of erection and semen release by rectal probe electrostimulation (RPE). J Urol. 1983;129(3):637-42. [pmid: 6834568].
Maytom M C, Derry F A, Dinsmore W W, Glass C A, Smith M D, Orr M, et al. A two-part pilot study of sildenafil (VIAGRA) in men with erectile dysfunction caused by spinal cord injury. Spinal Cord. 1999;37(2):110-6. [pmid: 10065749].
Montague D K. Penile prosthesis implantation in men with neurogenic impotence. Sex Disabil. 1994;12(1):94-8.
Sildenafil in men with spinal cord injury. Nurses Drug Alert 1999;23(2): 12
Potter P J, Hayes K C, Segal J L, Hsieh J T, Brunnemann S R, Delaney G A, et al. Randomized double-blind crossover trial of fampridine-SR (sustained release 4-aminopyridine) in patients with incomplete spinal cord injury. J Neurotrauma. 1998;15(10):837-49. [pmid: 9814639].
Raviv G, Heruti R J, Shaked A, Katz H, Ohry A, Ramon J, et al. Sexual rehabilitation: clinical experience with sildenafil citrate (Viagra) in spinal cord injured patients. Int J Impot Res. 2000;12(Suppl 5):s1.
Renganathan R, Suranjan B, Kurien T. Comparison of transdermal nitroglycerin and intracavernous injection of papaverine in the treatment of erectile dysfunction in patients with spinal cord lesions. Spinal Cord. 1997;35(2):99-103. [pmid: 9044517].
Richards J S. Treatment of erectile dysfunction secondary to spinal cord injury: Sexual and psychosocial impact on couples. Rehabil Psych. 1993;37(3):211-3.
Sanchez R A, Vidal J, Jauregui M L, Barrera M, Recio C, Giner M, et al. Efficacy, safety and predictive factors of therapeutic success with sildenafil for erectile dysfunction in patients with different spinal cord injuries. Spinal Cord. 2001;39(12):637-43. [pmid: 11781860].
Schmid D M, Schurch B, Hauri D. Sildenafil in the treatment of sexual dysfunction in spinal cord-injured male patients. Eur Urol. 2000;38(2):184-93. [pmid: 10895011].
Shenot P J, Rajan R, Rivas D A. Initial experience with sildenafil (viagra) in spinal cord injured men with erectile dysfunction. J Spinal Cord Med. 1999;22(1):49.
Sidi A A, Cameron J S, Dykstra D D, Reinberg Y, Lange P H. Vasoactive intracavernous pharmacotherapy for the treatment of erectile impotence in men with spinal cord injury. J Urol. 1987;138(3):539-42. [pmid: 2442418].
Sipski M L, Alexander C J, Rosen R. Sexual arousal and orgasm in women: effects of spinal cord injury. Ann Neurol. 2001;49(1):35-44. [pmid: 11198294].
Sipski M L, Alexander C J, Rosen R C. Physiological parameters associated with psychogenic sexual arousal in women with complete spinal cord injuries. Arch Phys Med Rehabil. 1995;76(9):811-8. [pmid: 7668950].
Sipski M L, Alexander C J, Rosen R C. Orgasm in women with spinal cord injuries: a laboratory-based assessment. Arch Phys Med Rehabil. 1995;76(12):1097-102. [pmid: 8540784].
Sipski M L, Rosen R C, Alexander C J, Hamer R M. Sildenafil effects on sexual and cardiovascular responses in women with spinal cord injury. Urology. 2000;55(6):812-5. [pmid: 10840082].
Sipski M L, Rosen R C, Alexander C J. Physiological parameters associated with the performance of a distracting task and genital self-stimulation in women with complete spinal cord injuries. Arch Phys Med Rehabil. 1996;77(5):419-24. [pmid: 8629915].
Sonksen J, Biering-Sorensen F. Transcutaneous nitroglycerin in the treatment of erectile dysfunction in spinal cord injured. Paraplegia. 1992;30(8):554-7. [pmid: 1522996].
Takeda H, Otani T, Ito Y. Efficacy of sildenafil citrate for ED associated with spinal cord injury. Int J Impot Res. 2000;12(Sup 2):s19. [pmid: 10982308].
Tang S F, Chu N K, Wong M K. Intracavernous injection of prostaglandin E1 in spinal cord injured patients with erectile dysfunction. A preliminary report. Paraplegia. 1995;33(12):731-3.
van der Aa H E, Alleman E, Nene A, Snoek G. Sacral anterior root stimulation for bladder control: clinical results. Arch Physiol Biochem. 1999;107(3):248-56. [pmid: 10650355].
van der Aa H E, Hermens H, Alleman E, Vorsteveld H. Sacral anterior root stimulation for bladder control in patients with a complete lesion of the spinal cord. Acta Neurochir (Wien). 1995;134(12):88-92. [pmid: 7668136].
Waldbaum J, Chen D, Nussbaum S B, Hartwig D M. Use of transurethral alprostadil to treat erectile dysfunction in spinal cord injured patients. Arch Phys Med Rehabil. 1998;79:1184.
Whipple B. Sexual responses to self-stimulation in women with complete spinal cord injury. J Sex Res. 1996;33(3):231-40.
Zaslau S, Nicolis C, Galea G, Britanico J, Vapnek J M. A simplified pharmacologic erection program for patients with spinal cord injury. J Spinal Cord Med. 1999;22(4):303-7. [pmid: 10751135].
Zasler N D, Katz P G. Synergist erection system in the management of impotence secondary to spinal cord injury. Arch Phys Med Rehabil. 1989;70(9):712-6. [pmid: 2774893].