# Appendix D. Data Assessment and Data Abstraction Forms

## Relevance Assessment Forms

### Sexual Dysfunction Eligibility Criteria

Measures of sexual dysfunction under consideration:

A. Psychologic: Validated sexual function questionnaire for males and/or females, structured interviews with qualitative analysis, educational component, global efficiency, or patient logs.
B. Physiologic: Penile and/or clitoral engorgement, endocrine, ultrasound testing of testicular size.

1. Does the article contain an original report of a measure of sexual dysfunction? (see list above)
  Yes
  No
  Can't Tell
  Interventions under consideration for sexual dysfunction:
  A. Cognitive/behavioral: Masturbation, intercourse
  B. Device: Penile rings, vibrators, vacuum devices
  C. Prescription medications: Intracavernous injections, oral, subcutaneous injections, intrameatal MUSE, creams
  D. Surgical intervention; Penile implants, spinal cord stimulators or E. Hormonal interventions.
2. Does the article discuss an intervention for sexual dysfunction? (see list above)
  Yes
  No
  Can't Tell
3. Does the article report an original intervention trial or series with a pre and post measure for sexual dysfunction after spinal cord injury?
  Yes
  No
  Can't Tell

### Fertility Eligibility Criteria

Measures of fertility rates under consideration:

Pregnancies, live birth rates, sperm motility, successful sperm harvesting, ejaculations, sperm count, % viable sperm, hormonal, ovulation rates, cycle function, other measures of sperm morphology, volume of ejaculation.

1. Does the article contain an original report of a measure of fertility rates in males, females or both?
  Yes
  No
  Can't Tell
  Fertility interventions under consideration:
  1. Physical: masturbation, intercourse, or
  2. Device: vibration, electrode ejaculation, home insemination or
  3. Prescription medications: sympathetic agonists, physostigmine, etc.,
  4. Surgical intervention; vas aspiration, testicular biopsy, ICSI, artificial insemination, spinal cord stimulators, or
  5. Laboratory techniques.
2. Does the article discuss a fertility intervention?
  Yes
  No
  Can't Tell
3. Does the article report an original intervention trial after spinal cord injury?
  Yes
  No
  Can't Tell
4. Does the article include pre and post intervention fertility rates?
  Yes
  No
  Can't Tell
5. Were results for SCI reported separately?
  Yes
  No
6. Is this a non-English language article?
  Yes
  No

## Data Abstraction Forms

### Sexual Dysfunction

1. Initials of reviewer:
2. Reference identification # (Refid):
3. Author, Year:
4. Number of review-relevant studies that this report describes
5. Publication status (select one):
6. If you answered ‘Other’ to the preceding question, specify:
7. If other included reports refer to this same study, provide the Refid(s)
8. Country in which the study was conducted (select all that apply):)
9. If you answered ‘Other’ to the preceding question, specify: Number of sites: (text)
10. Funding source type (select all that apply):
11. Specify the funding source(s):
12. Study design (select one): Other (Please specify)
13. If you answered ‘Other’ to the preceding question, specify:
14. Total # of individuals screened:
15. Full sample size (enrolled in study):
16. Full sample size (completing study):
17. Full sample's percentage of male participants:
18. Comments, including notable differences between study arms / cohorts re ‘% male participants’:
19. Mean age (SD/SE; range) of all study participants:
20. Comments, including notable differences between study arms/cohorts re age:
21. Sample's percentage of married participants:
22. Comments, including notable differences between study arms/ cohorts re % of married participants:
23. From which racial groups were participant's drawn (select all that apply)?)
24. Specify each racial group's percentage/proportion of full sample:
25. Comments, including notable differences between study arms/cohorts re racial composition:
26. Specify each socioeconomic status group's percentage/proportion of full sample: Comments, including notable differences between study arms/cohorts re socioeconomic status:
27. Specify number of previous pregnancies:
28. Specify patient prescription drug history specific to SCI versus other:
29. Specify partner prescription drug history specific to SCI versus other:
30. Specify previous sexual dysfunction of patient:
31. Specify previous sexual dysfunction of partner:
32. Specify previous sexual dysfunction treatment of patient (Note: treatment type, duration, dose etc.):
33. Specify previous sexual dysfunction treatment of partner (Note: treatment type, duration, dose etc.):
34. Specify patient history of STD:
35. Specify partner history of STD:
36. Specify patient psychiatric/psychological history (e.g., depression):
37. Specify partner psychiatric/psychological history (e.g., depression):
38. Specify pre-existing cognitive impairments:
39. Specify previous patient drug and/or alcohol abuse:
40. Specify previous partner drug and/or alcohol abuse:
41. Specify patient general medical history including prior diseases, and/or conditions Specify partner general medical history including prior diseases, and/or conditions: Specify other causes of sexual dysfunction:
42. Concurrent conditions (list all that apply): (text)
43. Specify the type and severity (mean; SD/SE; range: with units) of each concurrent condition, as well as how it was defined and diagnosed:
44. Specify the percentage/proportion of the whole sample re each type of each concurrent condition:
45. Comments, including notable differences between study arms/cohorts re concurrent conditions:
46. Specify pre-study medications or treatments for each concurrent condition, with dose/frequency:
47. Comments, including notable differences between study arms / cohorts re pre-study medication(s) or treatments, including dose/frequency:
48. Specify cause of spinal cord injury:
49. Specify the level of spinal cord injury:
50. Specify ASIA Level:
51. Specify duration since spinal cord injury:
52. Please list general comments, including notable differences between arms/cohorts re participants' baseline control of condition? (e.g., do any red flags stand out between the groups?):
53. List of study's inclusion criteria:
54. List of study's exclusion criteria:
55. Intention of study (select all that apply)
56. Type of study (select one):
57. Data were analyzed according to which criterion (select one)?
58. Study duration, including units (includes run-in period protocol/duration, washout protocol/duration, etc.):
59. Specify product name used for pharmacologic, device and/or other intervention(s): Specify name of manufacturer of pharmacologic, device or other intervention product: Medications allowed or mandated during the study (dose/ frequency):
60. Comments, including notable differences between study arms/ cohorts re participants' medication:
61. Concurrent therapies (e.g., physiotherapy; occupational therapy; chiropractic; counseling etc.) allowed or mandated during the study (intensity; frequency; duration):
62. Comments, including notable differences between study arms/ cohorts re participants' concurrent therapies:
63. Permitted or required medications or treatments for concurrent conditions (specify dose/ frequency, and for which concurrent condition):
64. Outcomes assessed (e.g. efficacy, incidence, prevalence, etc):
65. Number of study arm/ cohorts (note: in a cross-over trial, each different phase is considered an exposure / intervention arm):
66. Define the study arms or cohorts of interest to the present review: (text Study arm number:
67. Sample size at study entry: (text)
68. Sample size of those who completed the study:
69. Intervention length (weeks, months):
70. Arm Type/Group Type (placebo, active, control):
71. Intervention/ exposure type (e.g. drug or placebo):
72. Dose / frequency:
73. Timing (AM, PM):
74. Study arm number (Click here if there is no more arm/cohort):
75. Sample size at study entry:
76. Sample size of those who completed the study:
77. Intervention length (weeks, months):
78. Arm type (placebo, active, control):
79. Intervention/ exposure type (e.g. drug or placebo):
80. Dose / frequency:
81. Timing (AM, PM):
82. Study arm number (Click here if there is no more arm/cohort):
83. Sample size at study entry:
84. Sample size of those who completed the study:
85. Intervention length (weeks, months):
86. Arm type (placebo, active, control):
87. Intervention/ exposure type (e.g. drug or placebo):
88. Dose / frequency:
89. Timing (AM, PM):
90. Study arm number:
91. Sample size at study entry:
92. Sample size of those who completed the study:
93. Intervention length (weeks, months):
94. Arm type (placebo, active, control):
95. Intervention/ exposure type (e.g. drug or placebo): Sexual Dysfunction: Quality Assessment
96. Dose / frequency:
97. Timing (AM, PM):
98. Anatomic/Physiologic (e.g., clitoral engorgement; errection; penile tumes. girth; EMG; vaginal lubrication):
99. Sexual satisfaction:
100. Psychological (e.g., sexual functioning questionnaires; depression scale & scores): Infection rates:
101. Divorce:
102. Additional Outcomes Not Covered Above - Other(s):
103. Specify Follow-up(s) (length; duration & results):
104. Adverse events/ side effects reported in the present study (including local (e.g., infection); systemic (e.g., hypotension, death, etc.);
105. Other (e.g., psychological etc.) per study arm/cohort:
106. General Study Comments (Identify any problems with the research design (e.g., definition of placebo/control(s); inappropriateness of run-in and washout periods), or its implementation):

### Fertility

1. Initials of reviewer:
2. Reference identification # (Refid):
3. Author, Year:
4. Number of review-relevant studies that this report describes:
5. Publication status (select one):
6. If you answered ‘Other’ to the preceding question, specify:
7. If other included reports refer to this same study, provide the Refid(s):
8. Country in which the study was conducted (select all that apply): (check)
9. If you answered ‘Other’ to the preceding question, specify: (text)
10. Number of sites: (text)
11. Funding source type (select all that apply): (check
12. Specify the funding source(s): (text)
13. Study design (select one):
14. Other (Please specify)
15. If you answered ‘Other’ to the preceding question, specify: (text)
16. Total # of individuals screened: (text)
17. Full sample size (enrolled in study): (text)
18. Full sample size (completing study): (text)
19. Full sample's percentage of male participants: (text)
20. Comments, including notable differences between study arms / cohorts re ‘% male participants’: (text)
21. Mean age (SD/SE; range) of all study participants: (text)
22. Comments, including notable differences between study arms/cohorts re age: (text)
23. Sample's percentage of married participants: (text)
24. Comments, including notable differences between study arms/ cohorts re % of married participants: (text)
25. From which racial groups were participants drawn (select all that apply)? (check) Specify each racial group's percentage/proportion of full sample: (text)
26. Comments, including notable differences between study arms/cohorts re racial composition:
27. Specify each socioeconomic status group's percentage/proportion of full sample: (text)
28. Comments, including notable differences between study arms/cohorts re socioeconomic status: (text)
29. Specify previous gynaecological/obstetric history of patient: (text)
30. Specify previous gynaecological/obstetric history of partner: (text)
31. Specify previous birth control use: (text)
32. Specify number of previous pregnancies: (text)
33. Specify complications of previous pregnancies: (text)
34. Specify previous abortions and list reasons if provided: (text)
35. Specify patient prescription drug history specific to SCI versus other: (text)
36. Specify partner prescription drug history specific to SCI versus other: (text)
37. Specify previous fertility treatment of patient (Note: note treatment type, duration, dose etc.): (text)
38. Specify previous fertility treatment of partner (Note: note treatment type, duration, dose etc.): (text)
39. Specify patient history of STD: (text)
40. Specify partner history of STD: (text)
41. Specify patient psychiatric/psychological history (e.g., depression): (text)
42. Specify partner psychiatric/psychological history (e.g., depression): (text)
43. Specify pre-existing cognitive impairments: (text)
44. Specify previous patient drug and/or alcohol abuse: (text)
45. Specify previous partner drug and/or alcohol abuse: (text)
46. Specify patient general medical history including prior diseases, and/or conditions: (text)
47. Specify partner general medical history including prior diseases, and/or conditions: (text)
48. Specify other causes of infertility: (text)
49. Concurrent conditions (list all that apply): (text)
50. Specify the type and severity (mean; SD/SE; range: with units) of each concurrent condition, as well as how it was defined and diagnosed: (text)
51. Specify the percentage/proportion of the whole sample re each type of each concurrent condition: (text)
52. Comments, including notable differences between study arms/cohorts re concurrent conditions: (text)
53. Specify pre-study medications or treatments for each concurrent condition, with dose/frequency: (text)
54. Comments, including notable differences between study arms / cohorts re pre-study medication(s) or treatments, including dose/frequency: (text)
55. Specify cause of spinal cord injury: (text)
56. Specify the level of spinal cord injury: (text)
57. Specify ASIA Level: (text)
58. Specify duration since spinal cord injury: (text)
59. Please list general comments, including notable differences between arms/cohorts re participants' baseline control of condition? (e.g., do any red flags stand out between the groups?): (text)
60. List of study's inclusion criteria: (text)
61. List of study's exclusion criteria: (text)
62. Intention of study (select all that apply) (check)
63. Type of study (select one): (mult)
64. Data were analyzed according to which criterion (select one)? (mult)
65. If you answered ‘Other’ to the preceding question, specify:
66. Study duration, including units (includes run-in period protocol/duration, washout protocol/duration, etc.): (text)
67. Specify product name used for pharmacologic, device and/or other intervention(s): (text) Specify name of manufacturer of pharmacologic, device or other intervention product: (text)
68. Medications allowed or mandated during the study (dose/ frequency): (text)
69. Comments, including notable differences between study arms/ cohorts re participants' medication: (text)
70. Concurrent therapies (e.g., physiotherapy; occupational therapy; chiropractic; counseling etc.) allowed or mandated during the study (intensity; frequency; duration): (text)
71. Comments, including notable differences between study arms/ cohorts re participants' concurrent therapies: (text)
72. Permitted or required medications or treatments for concurrent conditions (specify dose/ frequency, and for which concurrent condition): (text)
73. Outcomes assessed (e.g. efficacy, incidence, prevalence, etc): (text)
74. Timing of outcome assessments and when, relative to start of intervention (e.g. at week 4): (text)
75. Number of study arm/ cohorts (note: in a cross-over trial, each different phase is considered an exposure / intervention arm): (text)
76. Define the study arms or cohorts of interest to the present review: (text)
77. Study arm number: (text)
78. Sample size at study entry: (text)
79. Sample size of those who completed the study: (text)
80. Intervention length (weeks, months): (text)
81. Arm type (placebo, active, control): (text)
82. Intervention/ exposure type (e.g. drug or placebo): (text)
83. Dose / frequency: (text)
84. Timing (AM, PM): (text)
85. Study arm number (Click here if there is no more arm/cohort): (text)
86. Sample size at study entry: (text)
87. Sample size of those who completed the study: (text)
88. Intervention length (weeks, months): (text)
89. Arm type (placebo, active, control): (text)
90. Intervention/ exposure type (e.g. drug or placebo): (text)
91. Dose / frequency: (text
92. Timing (AM, PM): (text)
93. Study arm number (Click here if there is no more arm/cohort): (text)
94. Sample size at study entry: (text)
95. Sample size of those who completed the study: (text)
96. Intervention length (weeks, months): (text)
97. Arm type (placebo, active, control): (text)
98. Intervention/ exposure type (e.g. drug or placebo): (text)
99. Dose / frequency: (text)
100. Timing (AM, PM): (text)
101. Study arm number (Click here if there is no more arm/cohort): (text)
102. Sample size at study entry: (text)
103. Sample size of those who completed the study: (text)
104. Intervention length (weeks, months): (text)
105. Arm type (placebo, active, control): (text)
106. Intervention/ exposure type (e.g. drug or placebo): (text)
107. Dose / frequency: (text)
108. Timing (AM, PM): (text)
109. Seminal parameters (e.g., specify ejaculation volume; sperm concentration; sperm motility; morphology): (text)
110. Ejaculation rates (frequency): (text)
111. Cycle function: (text)
112. Ovulation rates (e.g., specify total # of ovulatory cycles of the female partner; state the # of cycles with fertilization; state the # of pregnancy rates per treatment cycle): (text)
113. Pregnancy rates (specify # reported): (
114. Miscarriage/ectopic pregnancy rates (genetic or other): (text)
115. Induced Abortion(s) (genetic or other): (text)
116. Live births (e.g., # of births and if singletons, twins or higher order): (text)
117. Psychological (e.g., sexual functioning questionnaires; depression scale & scores): (text)
118. Genetic abnormalities: (text)
119. Infection rates: (text)
120. Divorce: (text)
121. Additional Outcomes Not Covered Above:
122. Other(s): (text)
123. Specify Follow-up(s) (length; duration & results): (text)
124. Adverse events/ side effects reported in the present study (including local (e.g., infection); systemic (e.g., hypotension, death, etc.);
125. Other (e.g., psychological etc.) per study arm/cohort: (text)
126. General Study Comments (Identify any problems with the research design (e.g., definition of placebo/control(s); inappropriateness of run-in and washout periods), or its implementation): (text)

## Quality Assessment Forms—RCTs

### Jadad Scale

Descriptor | | | Yes | No
Was the study described as randomized (this includes the use of words such as randomly, random, and randomization)?
The method used to generate the sequence of randomization was described and it was appropriate (table of random numbers, computer generated, etc)
Was the report of allocation concealment: | Adequate | Inadequate | Unclear
Was the study described as double blind?
The method of double blinding was described and it was appropriate (identical placebo, active placebo, dummy, etc)?
Was there a description of withdrawals and dropouts?

### Allocation Concealment

Refers to the technique used to implement the randomization sequence, not to generate it.

Adequate
• Sequentially numbered, opaque, sealed envelopes (SNOSE)
• Pharmacy controlled
• Numbered or ordered containers
• Central randomization - for example by telephone to a trials office or other method whose description contained elements convincing of concealment - for example a secure computer assisted method.
Inadequate
• Alternation
• Reference to case record numbers or to dates of birth
Unclear
• No mention of an allocation concealment approach at all
• An approach that does not fall into either adequate or inadequate allocation concealment

## Quality Assessment Forms—Case-Control and Cohort Studies

### Newcastle-Ottawa Scale (NOS)

Descriptor | Yes | No | Can't tell
Was the therapeutic intervention reported?
Were the inclusion/exclusion criteria reported?
Was follow-up reported as an inclusion criterion?
Was the sample size determination reported (cases accrued consecutively or non consecutively over a specified time period)?
Were the sample size calculations (and any assumptions) reported?
Was the time period for accrual of cases and whether they were accumulated prospectively or retrospectively reported?
Were the sources of participants (same or different clinicians, one or more center) reported?
Were how the outcome assessments made and who made them reported?
Was blinding reported?
Were the primary and secondary measures reported?
Was the timing of the outcome measures reported?
Was a follow-up schedule reported?
Were efforts used to maintain follow-up with participants reported?
Did the authors report on compliance with follow-up?
Was the method of data collection reported?
Were any participant exclusions from data analysis reported?
Was the statistical approach for analyzing the data reported?
Did the authors report any missing data and how it was handled in the data analysis?
Did the authors report any adverse events?

## Quality Assessment Forms—Noncomparative Case-Series Studies

[underlined: Quality assessment] | yes | partial | no | n/a
1. Question / objective sufficiently described?
2. Design evident and appropriate to answer study question?
3. Subject characteristics sufficiently described?
4. Subjects appropriate to the study question?
5. Controls used and appropriate? (if no control, check no)
6. Method of subject selection described and appropriate?
7. If random allocation to treatment groups was possible, is it described? (if not possible, check n/a)
8. If blinding of investigators to intervention was possible, is it reported? (If not possible, n/a)
9. If blinding of subjects to intervention was possible, is it reported? (If not possible, n/a)^1^
10. Outcome measure well defined and robust to measurement bias? Means of assessment reported?
11. Confounding accounted for?
12. Sample size adequate?
13. Post hoc power calculations or confidence intervals reported for statistically non significant results?
14. Statistical analyses appropriate?
15. Statistical tests stated?
16. Exact p-values or confidence intervals stated?
17. Attrition of subjects and reason for attrition recorded?
18. Results reported in sufficient detail?
19. Do the results support the conclusions?
Sum (items 1–19)

## Quality Assessment Forms—Abstracts

[image]