# Appendix B. Letter to Industry Representative

December 29, 2003

Director, Research & Development

Pfizer Global Research & Development

Canada Head Office

4747 Levy Street, Building B114

St-Laurent, Quebec

H4R 2P9

RE: Letter to Industry Representatives from the University of Ottawa Evidence-based Practice Center Investigating Sexuality and Reproductive Health Following Spinal Cord Injury

Dear Sir or Madam:

I am writing on behalf of the University of Ottawa's Evidence-based Practice Center. We are conducting two systematic reviews concerning sexuality and reproductive health following spinal cord injury. They are as follows:

1. What is the current fertility rate for men and women after SCI?
2. How has the availability of Viagra and other remediation affected sexual function, frequency of activity, and adjustment after SCI?

These reviews are being conducted under a contract from the Agency for Healthcare Research and Quality (AHRQ). We are contacting you to see if there is any evidence, including unpublished studies, abstracts and other documentation, that you want considered for inclusion in the reviews.

For the fertility rate systematic review we will consider the following studies for possible inclusion:

- All randomized or quasi-randomized (i.e., trials in which the treatment allocation method was intended to be random but might have been biased, for example, allocation by day of the week), studies or series of any treatment intervention for fertility after spinal cord injury.

For the remediation systematic review we will consider the following types of studies for possible inclusion:

- All randomized or quasi-randomized (i.e., trials in which the treatment allocation method was intended to be random but might have been biased, for example, allocation by day of the week), trials or series of any treatment intervention for sexual dysfunction after spinal cord injury.

Our focus is on human studies reported in English and limited to conventional interventions, so animal, chemical, or complementary and alternative medicine intervention studies are not necessary.

The specific questions that the systematic review will address are detailed in the attachment. As well, we understand that we will require permission to cite any information provided to us and introduced into the public domain.

We look forward to receiving any information that you might have.

Best regards,

Dan Deforge, MD

Physiatrist-in-Chief, TRC

Chief, Division of PM&R

The Rehabilitation Centre

505 Smyth Road, Rm. 1104

Ottawa, Ontario, CANADA

K1H 8M2

Phone: +1 (613) 737-7350 x 5524

Email: ddeforge@ottawahospital.on.ca

c.c. David Moher,

Co-Director, University of Ottawa Evidence-based Practice Center

Director, Chalmers Research Group, Children's Hospital of Eastern Ontario Research Institute.