# Appendix A. Search Strategies

## Search Strategy 1

1. comarr$.au.
2. (Female Sexual Function Index or FSFI).mp.
3. (Brief Index of Sexual Functioning or BISF-W).mp.
4. (Changes in Sexual Functioning Questionnaire or CSFQ).mp.
5. (Derogatis Interview for Sexual Functioning or DISF).mp.
6. (Golombok Rust Inventory of Sexual Satisfaction or GRISS).mp.
7. (International Index of Erectile Function or IIEF).mp.
8. (Brief Male Sexual Function Inventory or BMSFI).mp.
9. exp reproduction/
10. (reproducti$ or impoten$ or sex$ or ejaculat$ or erectile or menstruat$ or menopaus$ or hysterectom$ or infertil$ or orgasm$ or pregnanc$ or contracept$).mp.
11. (gay or lesbian or bisexual$ or transgender$ or homosexual$).mp.
12. or/2–11
13. Spinal Cord Injuries/
14. Paraplegia/
15. Quadriplegia/
16. Traumatic cord.mp.
17. post-traumatic myelopathy.mp.
18. (spinal cord inj$ or parapleg$ or quadripleg$ or tetrapleg$).mp.
19. meningomyelocele/ or spinal dysraphism/ or spina bifida cystica/ or spina bifida occulta/
20. (cerebral palsy not spinal cord).mp.
21. or/13–18
22. 21 not (19 or 20)
23. limit 22 to animal
24. limit 22 to human
25. 23 and 24
26. 22 not (23 not 25)
27. exp Sex Behavior/sn [Statistics & Numerical Data]
28. sexual$ activ$.mp.
29. sexual adjust$.mp.
30. sex$ counsel$.mp.
31. or/27–30
32. 12 and (sn or ep).fs.
33. (31 or 32) and 26
34. 12 and (1 or 26)
35. limit 34 to female
36. limit 34 to male
37. 34 and (35 not 36)
38. (menstruat$ or menopaus$ or hysterectom$ or pregnanc$).mp.
39. cesarean.mp.
40. obstetr$.ti.
41. obstetr$.mp.
42. or/38–41
43. 12 and 26 and (37 or 42)
44. 43 not 33
45. Fertility/
46. Birth Rate/
47. FERTILIZATION/
48. fertili$.mp.
49. conception.mp.
50. infertility.mp.
51. INFERTILITY, FEMALE/
52. infertility, male/
53. or/45–52
54. (53 and 26 and 34) not (33 or 44)
55. limit 54 to (adolescence <13 to 18 years> or adult)
56. viagra.mp.
57. Sildenafil citrate.mp.
58. Sildenafil.mp.
59. midodrine.mp.
60. Gutron.mp.
61. Electroejaculat$.mp.
62. Ultrex.mp.
63. Cialis$.mp.
64. Vasomax$.mp.
65. penile prosthesis.mp.
66. (prosthes#s adj2 (penis or penile)).mp.
67. (vacuum adj2 (constriction or device)).mp.
68. ((negative pressure or suction) adj device).mp. [mp=title, abstract, cas registry/ec number word, mesh subject heading]
69. negative pressure device$.mp.
70. vibromassage.mp.
71. massage.mp.
72. vibration.mp.
73. intracavernous.mp.
74. Alprostadil.mp.
75. PROSTAGLANDINS E, SYNTHETIC/ or PROSTAGLANDINS F/
76. Prostaglandin-e1.mp.
77. Papaverine.mp.
78. surgical collection.mp.
79. caverject.mp.
80. (MUSE and prostaglandin).mp.
81. Medicated Urethral System for Erection.mp.
82. vas aspiration.mp.
83. testicular biopsy.mp.
84. aspiration.mp.
85. or/56–84
86. 85 and 26
87. limit 86 to male
88. (Impoten$ or erectile).mp.
89. 86 and 88
90. ((87 or 89) and 34) not (33 or 44 or 45)
91. or/56–60
92. limit 91 to female
93. (92 and 26) not (33 or 44 or 55 or 90)
94. 34 not (33 or 44 or 55 or 90 or 93)

## Search Strategy 2

1. comarr$.au.
2. (Female Sexual Function Index or FSFI).mp.
3. (Brief Index of Sexual Functioning or BISF-W).mp.
4. (Changes in Sexual Functioning Questionnaire or CSFQ).mp.
5. (Derogatis Interview for Sexual Functioning or DISF).mp.
6. (Golombok Rust Inventory of Sexual Satisfaction or GRISS).mp.
7. (International Index of Erectile Function or IIEF).mp.
8. (Brief Male Sexual Function Inventory or BMSFI).mp.
9. sexual satisfaction/
10. (reproducti$ or impoten$ or sex$ or ejaculat$ or erectile or menstruat$ or menopaus$ or hysterectom$ or infertil$ or orgasm$ or pregnanc$ or contracept$).mp.
11. (gay or lesbian or bisexual$ or transgender$ or homosexual$).mp.
12. or/2–11
13. Spinal Cord Injuries/
14. Paraplegia/
15. Quadriplegia/
16. Traumatic cord.mp.
17. post-traumatic myelopathy.mp.
18. (spinal cord inj$ or parapleg$ or quadripleg$ or tetrapleg$).mp.
19. meningomyelocele/ or spinal dysraphism/ or spina bifida cystica/ or spina bifida occulta/
20. (cerebral palsy not spinal cord).mp.
21. or/13–18
22. 21 not (19 or 20)
23. limit 22 to animal
24. limit 22 to human
25. 23 and 24
26. 22 not (23 not 25)
27. 12 and (1 or 26)