# Appendixes

Appendix A. Search Strategies

Appendix B. Letter to Industry Representative

Appendix C. Modified QUOROM Flow Chart

Appendix D. Data Assessment and Data Abstraction Forms

Appendix E. Evidence Tables

Appendix F. Additional Acknowledgments