# Definitions of Terminology

The definitions of key words, as they are used in this report, are provided below.

endogenous melatonin = melatonin levels in either blood/serum/plasma, urine, saliva or cerebrospinal fluid and/or phase of melatonin rhythm in either blood/serum/plasma, urine, saliva or cerebrospinal fluid

effectiveness = the degree to which an intervention does what it is intended to do, under ordinary conditions

exogenous melatonin = melatonin that is administered to individuals from a source outside of the body

half-life of melatonin (t_1/2_) = time required for circulating levels of melatonin to be reduced to half of its peak value

percentage time in REM sleep (% time spent in REM sleep)= amount of time spent in REM sleep expressed as a percentage of total sleep time

REM latency = amount of time required to begin REM sleep after sleep onset

sleep disorder = primary sleep disorder, secondary sleep disorder, sleep restriction

- primary sleep disorder = sleep disorder is not accompanied by another clinical problem that could potentially be its cause
- secondary sleep disorder = sleep disorder is accompanied by another clinical problem that may be its cause
- sleep restriction = sleep disorder is due to altered sleep schedules or transmeridian air travel, such as in shift-work disorder and jet-lag, respectively.

sleep efficiency = amount of time spent asleep expressed as a percentage of the time spent in bed

sleep onset latency (SOL) = amount of time required before the onset of stage one sleep after retiring to bed

sleep quality = overall quality of sleep

total sleep time (TST) = total time spent asleep while in bed

wakefulness after sleep onset (WASO) = amount of time spent awake in bed following first attainment of stage one sleep