# Flow Diagrams

## Flow Diagram 1. Analytic Framework

[image]

## Flow Diagram 2. Study Retrieval and Selection for Melatonin and Sleep Disorders Review

[image]