# List of Excluded Studies

### Excluded-Topic

Seven hundred and ninety-six studies were excluded from the review. Of these, 328 were reviews, book chapters or commentaries, and have not been included in this chapter. Other reasons for exclusion included inappropriate topic (n=36), study design (n=272), intervention (n=21), population (n=7) and outcomes (n=101). Three studies were not included because of inadequate reporting of outcomes. The reports of 25 studies were unobtainable at the time of this writing and two were realized upon completion of the final report.

We sought to synthesize evidence related to four topic areas, including the physiology and pharmacology of melatonin; the populations that would benefit most from melatonin treatment; the effectiveness of melatonin treatment; and the safety of melatonin treatment. The following studies were excluded because the topic of the study was not appropriate to any of the questions of the review.

Brainard G C, Hanifin J P, Greeson J M, et al. Action spectrum for melatonin regulation in humans: evidence for a novel circadian photoreceptor. English. 2001;21:6405-12.
Brainard G C, Hanifin J P, Rollag M D, et al. Human melatonin regulation is not mediated by the three cone photopic visual system. English. 2001;86:433-6. 2001045653).
Brismar K, Hylander B, Eliasson K, Rossner S, Wetterberg L. Melatonin secretion related to side-effects of beta-blockers from the central nervous system. English. 1988;223:525-30.
Cajochen C, Wyatt J K, Czeisler C A, Dijk D J. Separation of circadian and wake duration-dependent modulation of EEG activation during wakefulness. English. 2002;114:1047-60. 2002360738).
Cornwell A C, Feigenbaum P, Kim A. SIDS, abnormal nighttime REM sleep and CNS immaturity. English. 1998;29:72-9.
Costantini A, Paoli F. Melatonin: Quantitative Analysis in Pharmaceutical Oral Dosage Forms Using Thin-Layer Chromatography (Tlc) Densitometry. English. 1998;53:443-7.
Daya S, Walker R B, Glass B D, Anoopkumar-Dukie S. The effect of variations in pH and temperature on stability of melatonin in aqueous solution. English. 2001;31:155-8.
Dijk D J. Investigator: Dijk DJ. Circadian variation of EEG power spectra in NREM and REM sleep in humans: dissociation from body temperature. English. 1999;8:189-95.
Dijk D J, Shanahan T L, Duffy J F, Ronda J M, Czeisler C A. Variation of electroencephalographic activity during non-rapid eye movement and rapid eye movement sleep with phase of circadian melatonin rhythm in humans. English. 1997;505:851-8. 1998014724).
Ebisawa T, Kajimura N, Uchiyama M, et al. Alleic variants of human melatonin 1a receptor: function and prevalence in subjects with circadian rhythm sleep disorders. English. 1999;262:832-7.
Ebisawa T, Uchiyama M, Kajimura N, et al. Genetic polymorphisms of human melatonin 1b receptor gene in circadian rhythm sleep disorders and controls. English. 2000;280:29-32.
Ebisawa T, Uchiyama M, Kajimura N, et al. Association of structural polymorphisms in the human period3 gene with delayed sleep phase syndrome. English. 2001;2:342-6. 2001164928).
Fauteck J D, Lerchl A, Bergmann M, et al. The adult human cerebellum is a target of the neuroendocrine system involved in the circadian timing. English. 1994;179:60-4.
Gaddy J R, Rollag M D, Brainard G C. Pupil size regulation of threshold of light-induced melatonin suppression. English. 1993;77:1398-401.
Goh V H, Tong T Y, Lim C L, Low E C, Lee L K. Circadian disturbances after night-shift work onboard a naval ship. English. 2000;165:101-5.
Hohjoh H, Takasu M, Shishikura K, Takahashi Y, Honda Y, Tokunaga K. Significant association of the arylalkylamine N-acetyltransferase ( AA-NAT) gene with delayed sleep phase syndrome. English. 2003;4:151-3.
Huether G, Hajak G, Reimer A, et al. The Metabolic-Fate of Infused L-Tryptophan in Men - Possible Clinical Implications of the Accumulation of Circulating Tryptophan and Tryptophan-Metabolites. English. 1992;109:422-32.
Iuvone PM. Circadian rhythms of melatonin biosynthesis in retinal photoreceptor cells: signal transduction, interactions with dopamine, and speculations on a role in cell survival. Kato S , Osborne NN , Tamai M_. Proceedings of an International Symposium: Retinal degeneration and regeneration. Amsterdam/New York: Kugler Pub., 1996: 3–16.
Karkela J, Vakkuri O, Kaukinen S, Huang W Q, Pasanen M. The influence of anaesthesia and surgery on the circadian rhythm of melatonin. English. 2002;46:30-6.
Mishima K MYSKTTEMSMaHY. Circadian rhythmicity of cell-mediated immunity in human and influences of sleep deprivation. 1998. CN-00282999.
Monteleone P, Catapano F, Tortorella A, Di Martino S, Maj M. Plasma melatonin and cortisol circadian patterns in patients with obsessive-compulsive disorder before and after fluoxetine treatment. English. 1995;20:763-70.
Murck H, Steiger A. Mg2+ reduces ACTH secretion and enhances spindle power without changing delta power during sleep in men -- possible therapeutic implications. English. 1998;137:247-52.
Palazidou E, Franey C, Arendt J, Stahl S, Checkley S. Evidence for a functional role of alpha-1 adrenoceptors in the regulation of melatonin secretion in man. English. 1989;14:131-5.
Palazidou E, Papadopoulos A, Ratcliff H, Dawling S, Checkley S A. Noradrenaline uptake inhibition increases melatonin secretion, a measure of noradrenergic neurotransmission, in depressed patients. eng. 1992;22:309-15.
Palazidou E, Papadopoulos A, Sitsen A, Stahl S, Checkley S. An alpha 2 adrenoceptor antagonist, Org 3770, enhances nocturnal melatonin secretion in man. English. 1989;97:115-7.
Payne J K. The trajectory of fatigue in adult patients with breast and ovarian cancer receiving chemotherapy. English. 2002;29:1334-40.
Reber A, Huber P R, Ummenhofer W, et al. General anaesthesia for surgery can influence circulating melatonin during daylight hours. English. 1998;42:1050-6.
Sassone-Corsi P, Whitmore D, Cermakian N, Foulkes NS. Rhythmic Transcription: The Molecular Basis of Circadian Melatonin synthesis. 5th International Arnold Rikli symposium: Biologic effects of light. 1998: 3–10.
Savaskan E, Olivieri G, Brydon L, et al. Cerebrovascular melatonin MT1-receptor alterations in patients with Alzheimer's disease. English. 2001;308:9-12.
Stoschitzky K, Sakotnik A, Lercher P, et al. Influence of beta-blockers on melatonin release. English. 1999;55:111-5.
Suvanto S, Harma M, Laitinen J T. The prediction of the adaptation of circadian rhythms to rapid time zone changes. English. 1993;36:111-6. 1993064055).
Thapan K, Arendt J, Skene D J. An action spectrum for melatonin suppression: evidence for a novel non-rod, non-cone photoreceptor system in humans. English. 2001;535:261-7.
Uchikawa O, Fukatsu K, Tokunoh R, et al. Synthesis of a Novel Series of Tricyclic Indan Derivatives as Melatonin Receptor Agonists. English. 2002;45:4222-39.
Weaver D R, Reppert S M. The Mel1a melatonin receptor gene is expressed in human suprachiasmatic nuclei. English. 1996;8:109-12.
Wehr T A, Schwartz P J, Turner E H, Feldman-Naim S, Drake C L, Rosenthal N E. Bimodal patterns of human melatonin secretion consistent with a two-oscillator model of regulation. English. 1995;194:105-8.
Yuan H, Chan C W, Sturner W Q, Pang S F, Brown G M. Comparison of [125I]iodomelatonin binding sites in infant cerebellum of sudden infant death syndrome and non-sudden infant death syndrome. English. 1995;197:154-8.

### Excluded-Design

In general, only controlled clinical trials were included for each question of the review, except for questions pertaining to the pharmacology of exogenous melatonin and the basic mechanism by which melatonin produces sleepiness. For the latter questions, uncontrolled clinical trials, case-series, cohort, cross-sectional and case-control studies were also included. The following studies did not have the design that was appropriate to the question(s) of the review to which they were potentially relevant.

Aeschbach D, Sher L, Postolache T T, Matthews J R, Jackson M A, Wehr T A. A longer biological night in long sleepers than in short sleepers. English. 2003;88:26-30. 2003041840).
Akerstedt T, Gillberg M, Wetterberg L. The circadian covariation of fatigue and urinary melatonin. English. 1982;17:547-54.
Anonymous. Jet lag takes flight with melatonin. English. 6. 1995:5. 1995211500).
Aoki H, Ozeki Y, Yamada N. Hypersensitivity of melatonin suppression in response to light in patients with delayed sleep phase syndrome. English. 2001;18:263-71.
Arendt J. Use of melatonin in circadian rhythm disturbances. English. 1993;9:469-71. 1993297394).
Attenburrow M E, Dowling B A, Sharpley A L, Cowen P J. Case-control study of evening melatonin concentration in primary insomnia[comment]. English. 1996;312:1263-4.
Barnes R G, Forbes M J, Arendt J. Shift type and season affect adaptation of the 6-sulphatoxymelatonin rhythm in offshore oil rig workers. English. 1998;252:179-82.
Baskett J J, Cockrem J F, Todd M A. Melatonin levels in hospitalized elderly patients: a comparison with community based volunteers. English. 1991;20:430-4.
Baskett J J, Wood P C, Broad J B, Duncan J R, English J, Arendt J. Melatonin in older people with age-related sleep maintenance problems: a comparison with age matched normal sleepers. English. 2001;24:418-24.
Benhaberou-Brun D, Lambert C, Dumont M. Association between melatonin secretion and daytime sleep complaints in night nurses. English. 1999;22:877-85.
Berga S L, Yen S S. Circadian pattern of plasma melatonin concentrations during four phases of the human menstrual cycle. English. 1990;51:606-12.
Bersani G, Garavini A. Melatonin add-on in manic patients with treatment resistant insomnia. English. 2000;24:185-91.
Bersani G, Garavini A. Evening melatonin administration in manic patients with treatment resistant insomnia. Italian. 2000;35:126-30. 2000201901).
Birketvedt G S, Florholmen J, Sundsfjord J, et al. Behavioral and neuroendocrine characteristics of the night-eating syndrome[comment]. J Am Med Assoc. 1999;282(7):657-63.
Bjorksten K S, Basun H, Wetterberg L. Disorganized sleep-wake schedule associated with neuroendocrine abnormalities in dementia A clinical study. English. 1995;10:107-13. 1995071693).
Blaicher W, Speck E, Imhof M H, et al. Melatonin in postmenopausal females. English. 2000;263:116-8.
Blazejova K, Nevsimalova S, Illnerova H, Hajek I, Sonka K. Sleep disorders and the 24-hour profile of melatonin and cortisol [Czech]. Czech. 2000;101:347-51.
Boivin D B, James F O. Circadian adaptation to night-shift work by judicious light and darkness exposure. English. 2002;17:556-67.
Boivin D B, James F O, Santo J B, Caliyurt O, Chalk C. Non-24-hour sleep-wake syndrome following a car accident. English. 2003;60:1841-3.
Bojkowski C J, Arendt J. Annual changes in 6-sulphatoxymelatonin excretion in man. English. 1988;117:470-6.
Brismar K, Mogensen L, Wetterberg L. Depressed melatonin secretion in patients with nightmares due to beta-adrenoceptor blocking drugs. English. 1987;221:155-8.
Bruce J, Tamarkin L, Riedel C, Markey S, Oldfield E. Sequential cerebrospinal fluid and plasma sampling in humans: 24-hour melatonin measurements in normal subjects and after peripheral sympathectomy. English. 1991;72:819-23.
Brusco L I, Fainstein I, Marquez M, Cardinali D P. Effect of melatonin in selected populations of sleep-disturbed patients. English. 1999;8:126-31.
Brusco L I, Marquez M, Cardinali D P. Melatonin treatment stabilizes chronobiologic and cognitive symptoms in Alzheimer's disease. English. 1998;19:111-5. 1999013451).
Buguet A. Is sleeping sickness a circadian disorder? The serotonergic hypothesis. English. 1999;16:477-89. 1999271105).
Buguet A. Circadian disorders in sleeping sickness. English. 1997;2:39-47. 1997168522).
Cagnacci A, Soldani R, Romagnolo C, Yen S S. Melatonin-induced decrease of body temperature in women: a threshold event. English. 1994;60:549-52.
Cajochen C, Khalsa S B, Wyatt J K, Czeisler C A, Dijk D J. Investigator: Dijk DJ. EEG and ocular correlates of circadian melatonin phase and human performance decrements during sleep loss. English. 1999;277:R640-9.
Campbell S S, Murphy P J. Extraocular circadian phototransduction in humans[comment]. English. 1998;279:396-9.
Carden S M. Entrainment of Free-running Circadian Rhythms by Melatonin in Blind People, by R L Sack, R W Brandes, A R Kendall, and A J Lewy New Engl J Med 343:1070–7, 2000, and Melatonin, Circadian Rhythms and Sleep (Editorial), by J Arendt N Engl J Med 343:1114–6, 2000. English. 2001;46:299-300.
Carskadon M A, Wolfson A R, Acebo C, Tzischinsky O, Seifer R. Adolescent sleep patterns, circadian timing, and sleepiness at a transition to early school days. English. 1998;21:871-81.
Cavallo A, Good W V, Douglas Ris M, Succop P. Dose response to melatonin treatment for disordered sleep rhythm in a blind child. English. 2002;3:159-61. 2002137904).
Checkley S A, Murphy D G, Abbas M, et al. Melatonin rhythms in seasonal affective disorder. English. 1993;163:332-7.
Chou I C, Tsai F J, Yu M T, Tsai C H. Smith-Magenis syndrome with bilateral vesicoureteral reflux: A case report. English. 2002;101:726-8. 2003011510).
Chung K F. Melatonin use in sleep disorders. English. 1997;19:669-72. 1998037033).
Circadian Variations in Serum Steroids and Melatonin in Burn Patients. Proceedings- American Burn Association; 1996 1996: 28: 165.
Citera G, Arias M A, Maldonado-Cocco J A, et al. The effect of melatonin in patients with fibromyalgia: a pilot study. English. 2000;19:9-13.
Claustrat B, Brun J, Garry P, Roussel B, Sassolas G. A once-repeated study of nocturnal plasma melatonin patterns and sleep recordings in six normal young men. eng. 1986;3:301-10.
Claustrat B, Buguet A, Geoffriau M, et al. Plasma melatonin rhythm is maintained in human African trypanosomiasis. English. 1998;68:64-70.
Coetzee J A, Theron J J, van der Merwe C A. Consecutive melatonin circadian rhythms in normal volunteers. English. 1989;75:163-5.
Cohen-Mansfield J, Garfinkel D, Lipson S. Melatonin for treatment of sundowning in elderly persons with dementia - A preliminary study. English. 2000;31:65-76. 2000335738).
Comperatore C A, Lieberman H R, Kirby A W, Adams B, Crowley J S. Melatonin efficacy in aviation missions requiring rapid deployment and night operations. English. 1996;67:520-4.
Costa G, Bertoldi A, Kovacic M, Ghirlanda G, Minors D S, Waterhouse J M. Hormonal secretion of nurses engaged in fast-rotating shift systems… XIIth International Symposium on Night and Shiftwork. Foxwoods symposium series, June 1995. English. 1997;3:S35-9.
Costa G, Koller M. Melatonin excretion during night shift work. Wwdu -International Scientific Conference. 1994;3:E9-E11.
Cronin A J, Keifer J C, Davies M F, King T S, Bixler E O. Melatonin secretion after surgery. English. 2000;356:1244-5. 2000364700).
Cronin A J, Keifer J C, Rung G, Shaheen J. Postoperative Sleep Disturbance Is Associated With Altered Melatonin Plasma Concentration. Anesthesiology -Philadelphia Then Hagerstown. 1998;89(Number 3; supp a):A1210.
Cugini P, Touitou Y, Bogdan A, et al. Is melatonin circadian rhythm a physiological feature associated with healthy longevity? A study of long-living subjects and their progeny. English. 2001;18:99-107.
Czeisler C A, Shanahan T L, Klerman E B, et al. Suppression of melatonin secretion in some blind patients by exposure to bright light[comment]. English. 1995;332:6-11.
Dagan Y, Yovel I, Hallis D, Eisenstein M, Raichik I. Evaluating the role of melatonin in the long-term treatment of delayed sleep phase syndrome (DSPS). English. 1998;15:181-90.
Dalton E J, Rotondi D, Levitan R D, Kennedy S H, Brown G M. Use of slow-release melatonin in treatment-resistant depression. English. 2000;25:48-52.
Danilenko K V, Putilov A A, Russkikh G S, Duffy L K, Ebbesson S O. Diurnal and seasonal variations of melatonin and serotonin in women with seasonal affective disorder. English. 1994;53:137-45.
Dawson D, Encel N, Lushington K. Improving adaptation to simulated night shift: timed exposure to bright light versus daytime melatonin administration. English. 1995;18:11-21.
De Leersnyder H, De Blois M C, Claustrat B, et al. Inversion of the circadian rhythm of melatonin in the Smith-Magenis syndrome. English. 2001;139:111-6.
de Leiva A, Tortosa F, Peinado M A, Serrano J, Rodriguez-Espinosa J, Puig-Domingo M. Episodic nyctohemeral secretion of melatonin in adult humans: lack of relation with LH pulsatile pattern. English. 1990;122:76-82.
Deacon S, Arendt J. Adapting to phase shifts, II Effects of melatonin and conflicting light treatment. English. 1996;59:675-82.
Deacon S, Arendt J. Adapting to phase shifts, I An experimental model for jet lag and shift work. English. 1996;59:665-73.
Deacon S J, Arendt J. Phase-shifts in melatonin, 6-sulphatoxymelatonin and alertness rhythms after treatment with moderately bright light at night. English. 1994;40:413-20.
Demisch LRTaGK. Influence of chronic b-adrenoreceptor blocker treatment on sleep quality and melatonin secretion. 25. 1992:98. CN-00279899.
den Boer J A, Westenberg H G. Behavioral, neuroendocrine, and biochemical effects of 5-hydroxytryptophan administration in panic disorder. English. 1990;31:267-78.
Dijk D J, Duffy J F, Riel E, Shanahan T L, Czeisler C A. Ageing and the circadian and homeostatic regulation of human sleep during forced desynchrony of rest, melatonin and temperature rhythms. English. 1999;516:611-27.
Duffy J F, Dijk D J, Hall E F, Czeisler C A. Investigator: Czeisler CA. Relationship of endogenous circadian melatonin and temperature rhythms to self-reported preference for morning or evening activity in young and older people. English. 1999;47:141-50.
Duffy J F, Zeitzer J M, Rimmer D W, Klerman E B, Dijk D J, Czeisler C A. Peak of circadian melatonin rhythm occurs later within the sleep of older subjects. English. 2002;282:E297-303.
Englund CE LRKD. Bright light amelioration of shift work. 7. 1990:33–6. CN-00358324. EMBASE 1990369643.
Espezel H, Jan J E, O'Donnell M E, Milner R. The use of melatonin to treat sleep-wake-rhythm disorders in children who are visually impaired. English. 1996;90:43-50. 1996029739).
Etzioni A, Luboshitzky R, Tiosano D, Ben-Harush M, Goldsher D, Lavie P. Melatonin replacement corrects sleep disturbances in a child with pineal tumor. English. 1996;46:261-3. 1996163513).
Fainstein I, Bonetto A J, Brusco L I, Cardinali D P. Effects of melatonin in elderly patients with sleep disturbance: A pilot study. English. 1997;58:990-1000. 1998041154).
Farbos B, Bourgeois-Bougrine S, Cabon P, Mollard R, Coblentz A. Sleepiness during night-shift - Sleeping habits or melatonin rhythm? A laboratory study. English. 2000;25:283-94. 2000047556).
Fauteck J, Schmidt H, Lerchl A, Kurlemann G, Wittkowski W. Melatonin in epilepsy: first results of replacement therapy and first clinical results. English. 1999;8:105-10.
Fauteck J-D, Schmidt H, Kurlemann G, Wittkowski W. Melatonin rhythms and therapeutic application of melatonin in children with severe sleep disturbances of different etiology. Experimental and Clinical Endocrinology and Diabetes. 1997;105(Sup 1):112.
Fertl E, Auff E, Doppelbauer A, Waldhauser F. Circadian secretion pattern of melatonin in de novo parkinsonian patients: evidence for phase-shifting properties of l-dopa. English. 1993;5:227-34.
Fiorina P, Lattuada G, Silvestrini C, Ponari O, Dall'Aglio P. Disruption of nocturnal melatonin rhythm and immunological involvement in ischaemic stroke patients. English. 1999;50:228-31.
Follenius M, Weibel L, Brandenberger G. Distinct modes of melatonin secretion in normal men. English. 1995;18:135-40.
Force RWHLBM. Psychotic episode after melatonin. 31. 1997:1408.
Foret J, Daurat A, Touitou Y, Aguirre A, Benoit O. The effect on body temperature and melatonin of a 39-H constant routine with two different light levels at nighttime. English. 1996;13:35-45. 1996185479).
Friedmann P D, Herman D S, Freedman S, Lemon S C, Ramsey S, Stein M D. Treatment of sleep disturbance in alcohol recovery: A national survey of addiction medicine physicians. English. 2003;22:91-103. 2003196691).
Fujita Y, Asukata I, Ohkoshi H, et al. Effect of jet lag on the circadian rhythm of plasma melatonin. English. 1989;26:73-9. 1990319681).
Gibertini M, Graham C, Cook M R. Self-report of circadian type reflects the phase of the melatonin rhythm. English. 1999;50:19-33.
Gilbert S S, van den Heuvel C J, Dawson D. Daytime melatonin and temazepam in young adult humans: equivalent effects on sleep latency and body temperatures. English. 1999;514:905-14.
Gould E L, Loesch D Z, Martin M J, Hagerman R J, Armstrong S M, Huggins R M. Melatonin profiles and sleep characteristics in boys with fragile X syndrome: a preliminary study. English. 2000;95:307-15.
Griefahn B. The validity of the temporal parameters of the daily rhythm of melatonin levels as an indicator of morningness. English. 2002;19:561-77.
Griefahn B, Blaszkewicz M, Gerngro H, Romer H C. The course of the melatonin synthesis as a reliable indicator of the position of individual circadian phases. German. 2002;52:34-42. 2002093960).
Griefahn B, Kunemund C, Golka K, Thier R, Degen G. Melatonin synthesis: a possible indicator of intolerance to shiftwork. English. 2002;42:427-36.
Grof E, Grof P, Brown G M, Arato M, Lane J. Investigations of melatonin secretion in man. English. 1985;9:609-12.
Haimov I, Laudon M, Zisapel N, et al. Sleep disorders and melatonin rhythms in elderly people. English. 1994;309:167. 1994223034).
Hajak G, Huether G, Blanke J, et al. The influence of intravenous L-tryptophan on plasma melatonin and sleep in men. English. 1991;24:17-20.
Hajak G, Rodenbeck A, Staedt J, Bandelow B, Huether G, Ruther E. Nocturnal plasma melatonin levels in patients suffering from chronic primary insomnia. English. 1995;19:116-22.
Hakola T, Harma M I, Laitinen J T. Circadian adjustment of men and women to night work. English. 1996;22:133-8.
Hanger MA. Effect of light on melatonin in the institutionalized elderly. English.1993:94 p.
Hansen T, Bratlid T, Lingjarde O, Brenn T. Midwinter insomnia in the subarctic region: evening levels of serum melatonin and cortisol before and after treatment with bright artificial light. English. 1987;75:428-34.
Harma M, Laitinen J, Partinen M, Suvanto S. The effect of four-day round trip flights over 10 time zones on the circadian variation of salivary melatonin and cortisol in airline flight attendants. English. 1994;37:1479-89.
Harma M I, Hakola T, Akerstedt T, Laitinen J T. Age and adjustment to night work. English. 1994;51:568-73.
Hashimoto S, Nakamura K, Honma S, Honma K I. Free-running of plasma melatonin rhythm prior to full manifestation of a non-24 hour sleep wake syndrome. Psychiatry and Clinical Neurosciences. 1998;52(Number 2):264-5. [pmid: 9628187].
Hatonen T, Kirveskari E, Heiskala H, Sainio K, Laakso M L, Santavuori P. Melatonin ineffective in neuronal ceroid lipofuscinosis patients with fragmented or normal motor activity rhythms recorded by wrist actigraphy. English. 1999;66:401-6.
Hayakawa T, Kamei Y, Urata J, Shibui K. Trials of bright light exposure and melatonin administration in a patients with non-24 hour sleep-wake syndrome. Psychiatry and Clinical Neurosciences. 1998;52(Number 2):261. [pmid: 9628185].
Heikkila E, Hatonen T H, Telakivi T, et al. Circadian rhythm studies in neuronal ceroid-lipofuscinosis (NCL). English. 1995;57:229-34.
Hoban T M, Lewy A J, Sack R L, Singer C M. The effects of shifting sleep two hours within a fixed photoperiod. English. 1991;85:61-8. 1991195227).
Honma K, Honma S, Kohsaka M, Fukuda N. Seasonal variation in the human circadian rhythm: dissociation between sleep and temperature rhythm. English. 1992;262:R885-91.
Hung JCARENAJRL. Use of melatonin in the treatment of sleep disturbances in children with neurological or behavioral disorders. 3. 1998:250–6.
Huwig-Poppe C, Voderholzer U, Backhaus J, Riemann D, Konig A, Hohagen F. The Tryptophan Depletion Test: Impact on Sleep in Healthy Subjects and Patients with Obsessive-Compulsive Disorder. Advances in Experimental Medicine and Biology. 1999;467:35-42. [pmid: 10721036].
Iguchi H, Kato K I, Ibayashi H. Melatonin serum levels and metabolic clearance rate in patients with liver cirrhosis. English. 1982;54:1025-7.
Ihara H, Madokoro S, Nakagawa H, Misaki K, Ito T, Isaki K. A case of delayed sleep phase syndrome: Chronobiological study. English. 1994;48:451-2. 1994263382).
Illnerova H, Zvolsky P, Vanecek J. The circadian rhythm in plasma melatonin concentration of the urbanized man: the effect of summer and winter time. English. 1985;328:186-9.
Ivanenko A, Crabtree V M, Tauman R, Gozal D. Melatonin in children and adolescents with insomnia: a retrospective study. English. 2003;42:51-8.
Jan J E, Hamilton D, Seward N, Fast D K, Freeman R D, Laudon M. Clinical trials of controlled-release melatonin in children with sleep-wake cycle disorders. English. 2000;29:34-9.
Jan M M. Melatonin for the treatment of handicapped children with severe sleep disorders. English. 2000;23:229-32.
Johnson K, Page A, Williams H, Wassemer E, Whitehouse W. The use of melatonin as an alternative to sedation in uncooperative children undergoing an MRI examination. English. 2002;57:502-6.
Kanikowska D, Hirata Y, Hyun K, Tokura H. Acute phase proteins, body temperature and urinary melatonin under the influence of bright and dim light intensities during the daytime. English. 2001;20:333-8.
Karadottir R, Axelsson J. Melatonin secretion in SAD patients and healthy subjects matched with respect to age and sex. English. 2001;60:548-51.
Karasek M, Pawlikowski M, Nowakowska-Jankiewicz B, et al. Circadian variations in plasma melatonin, FSH, LH, and prolactin and testosterone levels in infertile men. English. 1990;9:149-57.
Katz G, Durst R, Knobler H Y. Exogenous melatonin, jet lag, and psychosis: Preliminary case results [6]. English. 2001;21:349-51. 2001182866).
Kennaway D J, Goble F C, Stamp G E. Factors influencing the development of melatonin rhythmicity in humans. English. 1996;81:1525-32.
Kennaway D J, Royles P. Circadian rhythms of 6-sulphatoxy melatonin, cortisol and electrolyte excretion at the summer and winter solstices in normal men and women. English. 1986;113:450-6.
Kennaway D J, Van Dorp C F. Free-running rhythms of melatonin, cortisol, electrolytes, and sleep in humans in Antarctica. English. 1991;260:R1137-R1144. 1991243839).
Kennaway D J, Voultsios A. Circadian rhythm of free melatonin in human plasma. English. 1998;83:1013-5.
Kitajima T, Tomita S, Hayakawa T, Kayukawa Y, Ohta T. Successful treatment of non-24-hour sleep-wake syndrome with melatonin. 1997. CN-00281822.
Klerman E B, Goldenberg D L, Brown E N, Maliszewski A M, Adler G K. Investigator: Brown EN. Circadian rhythms of women with fibromyalgia. English. 2001;86:1034-9.
Klerman E B, Zeitzer J M, Duffy J F, Khalsa S B S, Czeisler C A. Absence of an increase in the duration of the circadian melatonin secretory episode in totally blind human subjects. English. 2001;86:3166-70. 2001258055).
Knook L, Kavelaars A, Sinnema G, Kuis W, Heijnen C J. High nocturnal melatonin in adolescents with chronic fatigue syndrome. English. 2000;85:3690-2.
Koorengevel K M, Beersma D G, den Boer J A, van den Hoofdakker R H. A forced desynchrony study of circadian pacemaker characteristics in seasonal affective disorder. English. 2002;17:463-75.
Kos-Kudla B, Ostrowska Z, Kozlowski A, et al. Circadian rhythm of melatonin in patients with colorectal carcinoma. English. 2002;23:239-42.
Krauchi K, Cajochen C, Wirz-Justice A. A relationship between heat loss and sleepiness: effects of postural change and melatonin administration. English. 1997;83:134-9.
Kripke D F, Elliot J A, Youngstedt S D, Smith J S. Melatonin: marvel or marker?. English. 1998;30:81-7.
Kunz D, Bes F. Melatonin as a therapy in REM sleep behavior disorder patients: an open-labeled pilot study on the possible influence of melatonin on REM-sleep regulation. English. 1999;14:507-11.
Kunz D, Bes F. Melatonin effects in a patient with severe REM sleep behavior disorder: case report and theoretical considerations. English. 1997;36:211-4.
Laakso M L, Porkka-Heiskanen T, Alila A, Stenberg D, Johansson G. Twenty-four-hour rhythms in relation to the natural photoperiod: a field study in humans. English. 1994;9:283-93.
Laakso M L, Porkka-Heiskanen T, Alila A, Stenberg D, Johansson G. Correlation between salivary and serum melatonin: dependence on serum melatonin levels. English. 1990;9:39-50.
Laaksol M L, Leinonen L, Hatonin T, Alila A, Heiskala H. Melatonin, cortisol and body temperature rhythms in Lennox-Gastaut patients with or without circadian rhythm sleep disorders. English. 1993;240:410-6. 1993277421).
Laberge L, Carrier J, Lesperance P, et al. Sleep and circadian phase characteristics of adolescent and young adult males in a naturalistic summertime condition. English. 2000;17:489-501.
Lack L, Wright H. The effect of evening bright light in delaying the circadian rhythms and lengthening the sleep of early morning awakening insomniacs. English. 1993;16:436-43. 1993241681).
Lack L C, Mercer J D, Wright H. Circadian rhythms of early morning awakening insomniacs. English. 1996;5:211-9.
Lafrance C, Dumont M, Lesperance P, Lambert C. Daytime vigilance after morning bright light exposure in volunteers subjected to sleep restriction. English. 1998;63:803-10.
Lancioni G E, O'Reilly M F, Basili G. Review of strategies for treating sleep problems in persons with severe or profound mental retardation or multiple handicaps [Review] [82 refs]. English. 1999;104:170-86.
Landis C, Lentz MJ, Riffle S et al. Hormonal and cytokine relationships with indices of well-being: hormones and sleep in women with and without fibromyalgia... 33rd Annual Communicating Nursing Research Conference/14th Annual WIN Assembly, “Building on a Legacy of Excellence in Nursing Research,” held April 13–15, 2000 at the Adam's Mark Hotel, Denver, Colorado. English.2000.
Lapierre O, Dumont M. Melatonin treatment of a non-24-hour sleep-wake cycle in a blind retarded child. English. 1995;38:119-22. 1995238872).
Leger D, Guilleminault C, Santos C, Paillard M. Sleep/wake cycles in the dark: sleep recorded by polysomnography in 26 totally blind subjects compared to controls. English. 2002;113:1607-14.
Lehmann EDCOCRP. Somnolence associated with melatonin deficiency after pinealectomy. 347. 1996:323.
Lemmer B, Kern R I, Nold G, Lohrer H. Jet lag in athletes after eastward and westward time-zone transition. English. 2002;19:743-64.
Leproult R, Van Reeth O, Byrne M M, Sturis J, Van Cauter E. Sleepiness, performance, and neuroendocrine function during sleep deprivation: effects of exposure to bright light or exercise. English. 1997;12:245-58.
Lewy A J, Bauer V K, Hasler B P, Kendall A R, Pires M L N, Sack R L. Capturing the circadian rhythms of free-running blind people with 05 mg melatonin. English. 2001;918:96-100. 2001379954).
Lewy A J, Hasler B P, Emens J S, Sack R L. Pretreatment circadian period in free-running blind people may predict the phase angle of entrainment to melatonin. English. 2001;313:158-60.
Lewy A J, Newsome D A. Different types of melatonin circadian secretory rhythms in some blind subjects. English. 1983;56:1103-7.
Lissoni P, Resentini M, Mauri R, Morabito F, Djemal s, Fraschini F. Melatonin circadian rhythm in normal subjects nad in case series of delayed puberty. English. 1984;1984:127-36.
Liu X, Uchiyama M, Shibui K, et al. Diurnal preference, sleep habits, circadian sleep propensity and melatonin rhythm in healthy human subjects. English. 2000;280:199-202. 2000061225).
Lockley S W, Skene D J, Butler L J, Arendt J. Sleep and activity rhythms are related to circadian phase in the blind. English. 1999;22:616-23.
Lockley S W, Skene D J, Tabandeh H, Bird A C, Defrance R, Arendt J. Relationship between napping and melatonin in the blind. English. 1997;12:16-25.
Luboshitzky R, Lavi S, Lavie P. The association between melatonin and sleep stages in normal adults and hypogonadal men. English. 1999;22:867-74.
Luboshitzky R, Lavi S, Thuma I, Lavie P. Nocturnal melatonin and luteinizing hormone rhythms in women with hyperprolactinemic amenorrhea. English. 1996;20:72-8.
Luboshitzky R, Lavi S, Thuma I, Lavie P. Increased nocturnal melatonin secretion in male patients with hypogonadotropic hypogonadism and delayed puberty. English. 1995;80:2144-8.
Luboshitzky R, Shen-Orr Z, Tzischichinsky O, Maldonado M, Herer P, Lavie P. Actigraphic sleep-wake patterns and urinary 6-sulfatoxymelatonin excretion in patients with Alzheimer's disease. English. 2001;18:513-24.
Luboshitzky R, Wagner O, Lavi S, Herer P, Lavie P. Abnormal melatonin secretion in male patients with hypogonadism. English. 1996;7:91-8.
Ludemann P, Zwernemann S, Lerchl A. Clearance of melatonin and 6-sulfatoxymelatonin by hemodialysis in patients with end-stage renal disease. English. 2001;31:222-7.
Lushington K, Dawson D, Kennaway D J, Lack L. The relationship between 6-sulphatoxymelatonin and polysomnographic sleep in good sleeping controls and wake maintenance insomniacs, aged 55–80 years. English. 1999;8:57-64.
Lushington K, Dawson D, Kennaway D J, Lack L. The relationship between 6-sulphatoxymelatonin rhythm phase and age in self-reported good sleeping controls and sleep maintenance insomniacs aged 55–80 years. English. 1999;147:111-2.
Lynch H J, Wurtman R J, Moskowitz M A, Archer M C, Ho M H. Daily rhythm in human urinary melatonin. English. 1975;187:169-71.
Madokoro S, Nakagawa H, Misaki K, Ihara H, Ito T, Isaki K. Nocturnal melatonin profiles before and one year after beginning shift-work. English. 1997;51:17-22.
Markey S P, Higa S, Shih M, Danforth D N, Tamarkin L. The correlation between human plasma melatonin levels and urinary 6-hydroxymelatonin excretion. English. 1985;150:221-5.
Martin S K, Eastman C I. Sleep logs of young adults with self-selected sleep times predict the dim light melatonin onset. English. 2002;19:695-707. 2002281018).
Matthews C D, Guerin M V, Wang X. Human plasma melatonin and urinary 6-sulphatoxy melatonin: studies in natural annual photoperiod and in extended darkness. English. 1991;35:21-7.
Middleton B, Arendt J, Stone B M. Human circadian rhythms in constant dim light (8 lux) with knowledge of clock time. English. 1996;5:69-76. 1996214173).
Millet B, Touitou Y, Poirier M F, et al. Plasma melatonin and cortisol in patients with obsessive-compulsive disorder: relationship with axillary temperature, physical activity, and clinical symptoms. English. 1998;44:874-81.
Milstein V, Small J G, Spencer D W. Melatonin for sleep EEG. English. 1998;29:49-53.
Minors D, Waterhouse J, Hume K, et al. Sleep and circadian rhythms of temperature and urinary excretion on a 228 hr ‘day’. Chronobiology International. 1988;5(1):65-80. [pmid: 3370718].
Mishima K, Okawa M, Hishikawa Y, Hozumi S, Hori H, Takahashi K. Morning bright light therapy for sleep and behavior disorders in elderly patients with dementia. English. 1994;89:1-7.
Mishima K, Okawa M, Shimizu T, Hishikawa Y. Diminished melatonin secretion in the elderly caused by insufficient environmental illumination. English. 2001;86:129-34.
Mishima K, Tozawa T, Satoh K, Matsumoto Y, Hishikawa Y, Okawa M. Melatonin secretion rhythm disorders in patients with senile dementia of Alzheimer's type with disturbed sleep-waking. English. 1999;45:417-21. 1999100228).
Miyamoto A, Oki J, Takahashi S, Okuno A. Serum melatonin kinetics and long-term melatonin treatment for sleep disorders in Rett syndrome[comment]. English. 1999;21:59-62.
Miyazaki T, Hashimoto S, Masubuchi S, Honma S, Honma K I. Phase-advance shifts of human circadian pacemaker are accelerated by daytime physical exercise. English. 2001;281:R197-205.
Monk T H, Buysse D J, Reynolds C F, Kupfer D J. Endogenous circadian performance rhythms - relationship to temperature, cortisol, melatonin, mood and alertness. International Congress Series -Amsterdam- Excerpta Medica Then Elsevier Science-. 1998;1152:557-62.
Monteleone P, Catapano F, Del Buono G, Maj M. Circadian rhythms of melatonin, cortisol and prolactin in patients with obsessive-compulsive disorder. English. 1994;89:411-5.
Morita T, Teramoto Y, Tokura H. Inhibitory effect of light of different wavelengths on the fall of core temperature during the nighttime. English. 1995;45:667-71.
Morita T, Tokura H, Wakamura T, Park S J, Teramoto Y. Effects of the morning irradiation of light with different wavelengths on the behavior of core temperature and melatonin in humans. English. 1997;16:103-5.
Muller H L, Handwerker G, Wollny B, Faldum A, Sorensen N. Melatonin secretion and increased daytime sleepiness in childhood craniopharyngioma patients. English. 2002;87:3993-6.
Munoz-Hoyos A, Jaldo-Alba F, Molina-Carballo A, Rodriguez-Cabezas T, Molina-Font J A, Acuna-Castroviejo D. Absence of plasma melatonin circadian rhythm during the first 72 hours of life in human infants. English. 1993;77:699-703.
Murialdo G, Costelli P, Fonzi S, et al. Circadian secretion of melatonin and thyrotropin in hospitalized aged patients. English. 1993;5:39-46.
Nagtegaal E, Peeters T, Swart W, Smits M, Kerkhof G, van der Meer G. Correlation between concentrations of melatonin in saliva and serum in patients with delayed sleep phase syndrome. English. 1998;20:181-3.
Nagtegaal J E, Kerkhof G A, Smits M G, Swart A C, Van Der Meer Y G. Delayed sleep phase syndrome: A placebo-controlled cross-over study on the effects of melatonin administered five hours before the individual dim light melatonin onset. English. 1998;7:135-43.
Nagtegaal J E, Smits M G, Swart A C, Kerkhof G A, van der Meer Y G. Melatonin-responsive headache in delayed sleep phase syndrome: preliminary observations. English. 1998;38:303-7.
Nickelsen T, Samel A, Maass H, Vejvoda M, Wegmann H, Schoffling K. Circadian patterns of salivary melatonin and urinary 6-sulfatoxymelatonin before and after a 9 hour time-shift. English. 1991;294:493-6.
Nowak R, McMillen I C, Redman J, Short R V. The correlation between serum and salivary melatonin concentrations and urinary 6-hydroxymelatonin sulphate excretion rates: two non-invasive techniques for monitoring human circadian rhythmicity. English. 1987;27:445-52.
Nurnberger J I J, et al. Adkins S, Lahiri D K. Melatonin suppression by light in euthymic bipolar and unipolar patients. English. 2000;57:572-9.
O'Brien I A, Lewin I G, O'Hare J P, Arendt J, Corrall R J. Abnormal circadian rhythm of melatonin in diabetic autonomic neuropathy. English. 1986;24:359-64.
Ohashi Y, Okamoto N, Uchida K, Iyo M, Mori N, Morita Y. Daily rhythm of serum melatonin levels and effect of light exposure in patients with dementia of the Alzheimer's type. English. 1999;45:1646-52.
Ohashi Y, Okamoto N, Uchida K, Iyo M, Mori N, Morita Y. Differential pattern of the circadian rhythm of serum melatonin in young and elderly healthy subjects. English. 1997;6:301-6.
Okawa M, Uchiyama M, Ozaki S, Shibui K. Melatonin treatment for circadian rhythm sleep disorders. Psychiatry and Clinical Neurosciences. 1998;52(Number 2):259-60. [pmid: 9628184].
Oldani A, Ferini-Strambi L, Zucconi M, Stankov B, Fraschini F, Smirne S. Melatonin and delayed sleep phase syndrome: Ambulatory polygraphic evaluation. English. 1994;6:132-4. 1995029384).
Owens J A, Rosen C L, Mindell J A. Medication use in the treatment of pediatric insomnia: results of a survey of community-based pediatricians. eng. 2003;111:e628-35.
Paavonen E J, Nieminen-Von Wendt T, Vanhala R, Aronen E T, Von Wendt L. Effectiveness of melatonin in the treatment of sleep disturbances in children with asperger disorder. English. 2003;13:83-95.
Pacchioni M, Camisasca R, Caminiti M, Andreotti A C, Pontiroli A E. Cabergoline, prolactin and melatonin release at night in healthy men. English. 2000;23:135-6.
Palm L, Blennow G, Wetterberg L. Long-term melatonin treatment in blind children and young adults with circadian sleep-wake disturbances. English. 1997;39:319-25.
Parry B L. Jet lag: minimizing it's effects with critically timed bright light and melatonin administration [Review] [10 refs]. English. 2002;4:463-6.
Partonen T, Vakkuri O, Lamberg-Allardt C. Effects of exposure to morning bright light in the blind and sighted controls. English. 1995;15:637-46.
Partonen T, Vakkuri O, Lonnqvist J. Suppression of melatonin secretion by bright light in seasonal affective disorder. English. 1997;42:509-13.
Pavel S, Goldstein R, Petrescu M. Vasotocin, melatonin and narcolepsy: possible involvement of the pineal gland in its patho-physiological mechanism. English. 1980;1:281-4.
Pillar G, Shahar E, Peled N, Ravid S, Lavie P, Etzioni A. Melatonin improves sleep-wake patterns in psychomotor retarded children. English. 2000;23:225-8. 2000361330).
Piovesan A, Terzolo M, Borretta G, et al. Circadian profile of serum melatonin in Cushing's disease and acromegaly. English. 1990;7:259-61.
Portaluppi F, Cortelli P, Avoni P, et al. Progressive disruption of the circadian rhythm of melatonin in fatal familial insomnia. English. 1994;78:1075-8.
Press J, Phillip M, Neumann L, et al. Normal melatonin levels in patients with fibromyalgia syndrome. English. 1998;25:551-5.
Putilov A A. Multi-component physiological response mediates therapeutic benefits of bright light in winter seasonal affective disorder. English. 1998;29:367-86. 1998402277).
Quera-Salva M A, Defrance R, Claustrat B, De Lattre J, Guilleminault C. Rapid shift in sleep time and acrophase of melatonin secretion in short shift work schedule. English. 1996;19:539-43.
Quera-Salva M A, Guilleminault C, Claustrat B, et al. Rapid shift in peak melatonin secretion associated with improved performance in short shift work schedule. English. 1997;20:1145-50.
Quera-Salva M A, Lesieur O, Mc Cann C, et al. Rapid shift in sleep time and acrophase of melatonine secretion in short shift work schedule. French. 1997;58:630. 1997371914).
Ramstad K, Loge J H. Melatonin treatment of a blind child with serious sleep disorders [Norwegian]. Norwegian. 2002;122:1005-6.
Rao M L, Muller-Oerlinghausen B, Mackert A, Stieglitz R D, Strebel B, Volz H P. The influence of phototherapy on serotonin and melatonin in non-seasonal depression. English. 1990;23:155-8.
Reid K J, Chang A M, Dubocovich M L, Turek F W, Takahashi J S, Zee P C. Familial advanced sleep phase syndrome. English. 2001;58:1089-94. 2001253474).
Riemann D, Klein T, Rodenbeck A, et al. Nocturnal cortisol and melatonin secretion in primary insomnia. English. 2002;113:17-27.
Rigante D, Mariotti P, Ricci R, Della Marca G. Melatonin in sleep disturbances of the mucopolysaccharidoses. Journal of Inherited Metabolic Disease. 1998;21(Supp 2):119. [pmid: 9686350].
Roach G D, Rodgers M, Dawson D. Circadian adaptation of aircrew to transmeridian flight. English. 2002;73:1153-60. 2002444670).
Roberts-Thomson I C, Knight R E, Kennaway D J, Pannall P R. Circadian rhythms in patients with abdominal pain syndromes. English. 1988;18:569-74.
Roden M, Koller M, Pirich K, Vierhapper H, Waldhauser F. The circadian melatonin and cortisol secretion pattern in permanent night shift workers. English. 1993;265:R261-7.
Rodenbeck A, Huether G, Ruther E, Hajak G. Altered circadian melatonin secretion patterns in relation to sleep in patients with chronic sleep-wake rhythm disorders. English. 1998;25:201-10.
Rommel T, Demisch L. Influence of chronic beta-adrenoreceptor blocker treatment on melatonin secretion and sleep quality in patients with essential hypertension. English. 1994;95:39-48.
Ross C, Davies P, Whitehouse W. Melatonin treatment for sleep disorders in children with neurodevelopmental disorders: an observational study. English. 2002;44:339-44.
Rufiange M, Dumont M, Lachapelle P. Correlating retinal function with melatonin secretion in subjects with an early or late circadian phase. English. 2002;43:2491-9.
Sack R L, Blood M L, Lewy A J. Melatonin rhythms in night shift workers. English. 1992;15:434-41.
Sack R L, Brandes R W, Kendall A R, Lewy A J. Entrainment of free-running circadian rhythms by melatonin in blind people [comment]. English. 2000;343:1070-7.
Samkova L, Vondrasova D, Hajek I, Illnerova H. A fixed morning awakening coupled with a low intensity light maintains a phase advance of the human circadian system. English. 1997;224:21-4. 1997078780).
Schwartz P J, Rosenthal N E, Wehr T A. Serotonin 1A receptors, melatonin, and the proportional control thermostat in patients with winter depression. English. 1998;55:897-903.
Shanahan T L, Czeisler C A. Light exposure induces equivalent phase shifts of the endogenous circadian rhythms of circulating plasma melatonin and core body temperature in men. English. 1991;73:227-35. 1991308342).
Shanahan T L, Kronauer R E, Duffy J F, et al. Melatonin rhythm observed throughout a three-cycle bright-light stimulus designed to reset the human circadian pacemaker. English. 1999;14:237-53.
Sharkey K M, Fogg L F, Eastman C I. Effects of melatonin administration on daytime sleep after simulated night shift work. English. 2001;10:181-92.
Sharp K H, Vaughn G M, Cosby P W, Sewell C E, Kennaway D J. Alterations of temperature, sleepiness, mood, and performance in residents are not associated with changes in sulfatoxymelatonin excretion. Journal of Pineal Research. 1988;5(6):499-512. [pmid: 3225734].
Sheldon S H. Pro-convulsant effects of oral melatonin in neurologically disabled children. English. 1998;351:1254. 1998132907).
Sherer M A, Weingartner H, James S P, Rosenthal N E. Effects of melatonin on performance testing in patients with seasonal affective disorder. English. 1985;58:277-82.
Shibui K, Uchiyama M, Okawa M. Melatonin rhythms in delayed sleep phase syndrome. English. 1999;14:72-6.
Shibui K, Uchiyama M, Okawa M, et al. Diurnal fluctuation of sleep propensity and hormonal secretion across the menstrual cycle. English. 2000;48:1062-8.
Shilo L, Dagan Y, Smorjik Y, et al. Patients in the intensive care unit suffer from severe lack of sleep associated with loss of normal melatonin secretion pattern. English. 1999;317:278-81.
Shinohara K, Uchiyama M, Okawa M, et al. Menstrual changes in sleep, rectal temperature and melatonin rhythms in a subject with premenstrual syndrome. English. 2000;281:159-62.
Shochat T, Luboshitzky R, Lavie P. Nocturnal Melatonin Onset Is Phase Locked to the Primary Sleep Gate. English. 1997;42:R364-R370.
Siebler M, Steinmetz H, Freund H J. Therapeutic entrainment of circadian rhythm disorder by melatonin in a non-blind patient. English. 1998;245:327-8.
Singer C, Tractenberg R, Kaye J, et al. The Adcs Clinical Trial of Melatonin for the Sleep Disturbance of Alzheimer's Disease. English. 2002;10:65.
Smits M G, Van Rooy R, Nagtegaal J E. Influence of melatonin on quality of life in patients with chronic fatigue and late melatonin onset. English. 2002;10:25-36. 2002378090).
Soszynski P, Zgliczynski S, Pucilowska J. The circadian rhythm of melatonin in hypothyroidism and hyperthyroidism. English. 1988;119:240-4.
Srinivasan V. Review article The pineal gland: Its physiological and pharmacological role. English. 1989;33:263-72. 1990066496).
Szymanska A, Rabe-Jablonska J, Karasek M. Diurnal profile of melatonin concentrations in patients with major depression: relationship to the clinical manifestation and antidepressant treatment. English. 2001;22:192-8.
Takahashi T, Sasaki M, Itoh H, et al. Melatonin alleviates jet lag symptoms caused by an 11-hour eastward flight. Psychiatry and Clinical Neurosciences. 2002;56(No 3):301-2. [pmid: 12047605].
Tamarkin L, Ehrenkranz J R L, Sidbury J B. Circadian patterns of melatonin in normal children, exogenous obesity and Prader-Willi syndrome patients. Pediatric Research. 1980;14(4, II):484.
Tarquini B, Borghi G, Galluzzi F, La Cauza F, Mattei P, Salti R. Diurnal melatonin in 3 prepuberal children. English. 1989;12:133.
Terzolo M, Piovesan A, Ali A, et al. Circadian profile of serum melatonin in patients with Cushing's syndrome or acromegaly. English. 1995;18:17-24.
Tomoda A, Miike T, Iwatani N, et al. Effect of long-term melatonin administration on school-phobic children and adolescents with sleep disturbances. English. 1999;60:607-12. 1999426150).
Tomoda A, Miike T, Uezono K, Kawasaki T. A school refusal case with biological rhythm disturbance and melatonin therapy. English. 1994;16:71-6.
Touitou Y, Motohashi Y, Reinberg A, et al. Effect of shift work on the night-time secretory patterns of melatonin, prolactin, cortisol and testosterone. English. 1990;60:288-92.
Tresguerres J A, Ariznavarreta C, Granados B, et al. Circadian urinary 6-sulphatoxymelatonin, cortisol excretion and locomotor activity in airline pilots during transmeridian flights. English. 2001;31:16-22.
Tzischinsky O, Pal I, Epstein R, Dagan Y, Lavie P. The importance of timing in melatonin administration in a blind man. English. 1992;12:105-8. 1992241214).
Uchida K, Okamoto N, Ohara K, Morita Y. Daily rhythm of serum melatonin in patients with dementia of the degenerate type. English. 1996;717:154-9.
Uchiyama M, Okawa M, Shibui K, et al. Poor compensatory function for sleep loss as a pathogenic factor in patients with delayed sleep phase syndrome. English. 2000;23:553-8.
Uchiyama M, Shibui K, Hayakawa T, et al. Larger phase angle between sleep propensity and melatonin rhythms in sighted humans with non-24-hour sleep-wake syndrome. English. 2002;25:83-8.
Ulfberg J, Micic S, Strom J. Afternoon serum-melatonin in sleep disordered breathing. English. 1998;244:163-8.
Vakkuri O. Melatonin in human and animal tissues: an analytical physiological study. Oulu: University of Oulu, 1986.
Vakkuri O. Diurnal rhythm of melatonin in human saliva. English. 1985;124:409-12.
Van Cauter E, Moreno-Reyes R, Akseki E, et al. Rapid phase advance of the 24-h melatonin profile in response to afternoon dark exposure. English. 1998;275:E48-54.
van Coevorden A, Mockel J, Laurent E, et al. Neuroendocrine rhythms and sleep in aging men. English. 1991;260:E651-61.
Vangelova K K, Dalbokova D L. Variations in 6-sulphatoxymelatonin excretion and oral temperature under a 12-hour shiftwork environment. Reviews on Environmental Health. 1998;13(4):221-6. [pmid: 9987817].
Vasavan Nair N P, Schwartz G, Ng Ying Kin N M K, Thakur M. Melatonin and cortisol circadian rhythms in Alzheimer's Disease patients and normal elderly subjects. International Congress Series -Amsterdam- Excerpta Medica Then Elsevier Science. 1998;1152:357-62.
Voderholzer U, Laakmann G, Becker U, et al. Circadian profiles of melatonin in melancholic depressed patients and healthy subjects in relation to cortisol secretion and sleep. English. 1997;71:151-61.
Voderholzer U, Riemann D, Gann H, et al. Transient total sleep loss in cerebral Whipple's disease: a longitudinal study. English. 2002;11:321-9.
Waldhauser F, Weiszenbacher G, Frisch H, Zeitlhuber U, Waldhauser M, Wurtman R J. Fall in nocturnal serum melatonin during prepuberty and pubescence. English. 1984;1:362-5.
Wehr T A. In short photoperiods, human sleep is biphasic. English. 1992;1:103-7. 1992219325).
Whitson P A, Putcha L, Chen Y M, Baker E. Investigator: Whitson PA, Putcha L. Melatonin and cortisol assessment of circadian shifts in astronauts before flight. English. 1995;18:141-7.
Wikner J, Hirsch U, Wetterberg L, Rojdmark S. Fibromyalgia--a syndrome associated with decreased nocturnal melatonin secretion [comment]. English. 1998;49:179-83.
Wikner J, Svanborg E, Wetterberg L, Rojdmark S. Melatonin secretion and excretion in patients with obstructive sleep apnea syndrome. English. 1997;20:1002-7.
Williams G, Pirmohamed J, Minors D, et al. Dissociation of body-temperature and melatonin secretion circadian rhythms in patients with chronic fatigue syndrome. English. 1996;16:327-37.
Willig R P, Braun W, Commentz J C, Stahnke N. Circadian fluctuation of plasma melatonin in Prader-Willi's syndrome and obesity. English. 1986;279:411-5.
Wirz-Justice A, Graw P, Krauchi K, et al. Morning or night-time melatonin is ineffective in seasonal affective disorder. English. 1990;24:129-37.
Wright K P J, Myers B L, Plenzler S C, Drake C L, Badia P. Acute effects of bright light and caffeine on nighttime melatonin and temperature levels in women taking and not taking oral contraceptives. English. 2000;873:310-7.
Wyatt J K, Ritz-De Cecco A, Czeisler C A, Dijk D J. Circadian temperature and melatonin rhythms, sleep, and neurobehavioral function in humans living on a 20-h day. English. 1999;277:R1152-R1163. 1999390941).
Yang C M, Spielman A J, D'Ambrosio P, Serizawa S, Nunes J, Birnbaum J. A single dose of melatonin prevents the phase delay associated with a delayed weekend sleep pattern [comment]. English. 2001;24:272-81.
Yoon I Y, Song B G. Role of morning melatonin administration and attenuation of sunlight exposure in improving adaptation of night-shift workers. English. 2002;19:903-13.
Youngstedt S D, Kripke D F, Elliott J A. Melatonin excretion is not related to sleep in the elderly. English. 1998;24:142-5.
Youngstedt S D, Kripke D F, Elliott J A, Klauber M R. Circadian abnormalities in older adults. English. 2001;31:264-72.
Zhao Z Y, Xie Y, Fu Y R, Bogdan A, Touitou Y. Aging and the circadian rhythm of melatonin: a cross-sectional study of Chinese subjects 30–110 yr of age. English. 2002;19:1171-82.
Zhdanova I V, Wurtman R J, Wagstaff J. Effects of a low dose of melatonin on sleep in children with Angelman syndrome. English. 1999;12:57-67. 1999180932).
Zisapell N. Melatonin-dopamine interactions: From basic neurochemistry to a clinical setting. English. 2001;21:605-16. 2002184809).

### Excluded-Population

For all questions of the review, the population of the study could include individuals of any age, gender, ethnicity and socioeconomic status; however, these individuals were required to be free of any type of sleep disorder in the case of the question relating to the effect of melatonin on normal sleepers, and to suffer from a sleep disorder in the case of the question relating to the effect of melatonin on people with sleep disorders. Studies involving animals were excluded. The following studies did not have the population that was appropriate to the question(s) of the review to which they were potentially relevant.

Ayala-Guerrero F, Pineda B B T, Hernandez M A, Mexicano G. Effect of Melatonin on Sleep. Proceedings- Western Pharmacology Society. 1998;41:25-8.
Kalsbeek A, Strubbe J H, Buijs R M. Circadian control of corticosterone, melatonin and insulin release: important roles for suprachiasmatic nucleus efferents and the autonomic nervous system. International Congress Series -Amsterdam- Excerpta Medica Then Elsevier Science. 1998;1152:411-4.
Oxenkrug G F, Requintina P J. Melatonin and jet lag syndrome: experimental model and clinical implications. eng. 2003;8:139-48.
Sharma V K, Chidambaram R, Yadunandam A K. Melatonin enhances the sensitivity of circadian pacemakers to light in the nocturnal field mouse Mus booduga. English. 2003;297A:160-8.
Slotten H, Pitrosky B, Pevet P. Entrainment of Rat Circadian Rhythms by Daily Administration of Melatonin: Influence of the Mode of Administration. Advances in Experimental Medicine and Biology. 1999;460:279-82. [pmid: 10810523].
Vachharajani N N, Yeleswaram K, Boulton D W. Preclinical pharmacokinetics and metabolism of BMS-214778, a novel melatonin receptor agonist. English. 2003;92:760-72.
Wirz-Justice A, Cajochen C, Kruchi K, Mri D, Graw P. Timed Melatonin Administration on Circadian Rhythms and Vigilance States CONFERENCE ABSTRACT. 1996. CN-00285692.

### Excluded-Intervention

For questions pertaining to the administration of exogenous melatonin to a study population, any formulation, dosage, timing, frequency and duration of melatonin administration was acceptable; however, melatonin was required to be the primary intervention, and in the case of controlled trials, compared to placebo. The following studies involved either an inappropriate intervention or a co-intervention.

Bougrine S, Mollard R, Ignazi G, Coblentz A. Days off and bright light: Effects on adaptation to night work. English. 1998;21:187-98. 1998058963).
Cagnacci A, Soldani R, Yen S S. Contemporaneous melatonin administration modifies the circadian response to nocturnal bright light stimuli. English. 1997;272:R482-6.
De Leersnyder H, Bresson J L, de Blois M C, et al. Beta 1-adrenergic antagonists and melatonin reset the clock and restore sleep in a circadian disorder, Smith-Magenis syndrome. English. 2003;40:74-8.
De Leersnyder H, De Blois M C, Vekemans M, et al. beta<inf>1</inf>-adrenergic antagonists improve sleep and behavioural disturbances in a circadian disorder, Smith-Magenis syndrome. English. 2001;38:586-90. 2001318554).
Dolberg O T, Hirschmann S, Grunhaus L. Melatonin for the treatment of sleep disturbances in major depressive disorder. English. 1998;155:1119-21.
Haffmans P M J, Sival R C, Lucius S A P, Cats Q, Van Gelder L. Bright light therapy and melatonin in motor restless behaviour in dementia: A placebo-controlled study. English. 2001;16:106-10. 2001046585).
Hajak G, Rodenbeck A, Adler L, et al. Nocturnal melatonin secretion and sleep after doxepin administration in chronic primary insomnia. English. 1996;29:187-92.
Hajak G, Rodenbeck A, Bandelow B, Friedrichs S, Huether G, Ruther E. Nocturnal plasma melatonin levels after flunitrazepam administration in healthy subjects. English. 1996;6:149-53.
Krauchi K, Cajochen C, Danilenko K V, Wirz-Justice A. The hypothermic effect of late evening melatonin does not block the phase delay induced by concurrent bright light in human subjects. English. 1997;232:57-61.
Leibenluft E, Schmidt P J, Turner E H, et al. Effects of leuprolide-induced hypogonadism and testosterone replacement on sleep, melatonin, and prolactin secretion in men. English. 1997;82:3203-7.
Loo H, Hale A, D'haenen H. Determination of the dose of agomelatine, a melatoninergic agonist and selective 5-HT<inf>2C</inf> antagonist, in the treatment of major depressive disorder: A placebo-controlled dose range study. English. 2002;17:239-47. 2002340721).
Nave R, Iani C, Herer P, Gopher D, Lavie P. Residual effects of daytime administration of melatonin on performance relevant to flight. English. 2002;131:87-95.
Okawa M, Uchiyama M, Ozaki S, Shibui K, Ichikawa H. Circadian rhythm sleep disorders in adolescents: clinical trials of combined treatments based on chronobiology. English. 1998;52:483-90.
Rose D A, Kahan T L. Melatonin and sleep qualities in healthy adults: pharmacological and expectancy effects. English. 2001;128:401-21.
Schlager D S. Early-morning administration of short-acting beta blockers for treatment of winter depression. English. 1994;151:1383-5.
Shilo L, Sabbah H, Hadari R, et al. The effects of coffee consumption on sleep and melatonin secretion. English. 2002;3:271-3. 2002227153).
Strassman R J, Peake G T, Qualls C R, Lisansky E J. Lack of an acute modulatory effect of melatonin on human nocturnal thyrotropin and cortisol secretion. English. 1988;48:387-93.
Takahashi T, Sasaki M, Itoh H, et al. Re-entrainment of the circadian rhythms of plasma melatonin in an 11-h eastward bound flight. English. 2001;55:275-6. 2001225754).
Tanaka H, Kakutani S, Araki A, Fukuda I, Oka R, Cho K. Combined use of melatonin and low-dose flunitrazepam for treatment of sleep disturbance in a child with spastic quadriplegia: evaluation using polysomnography [Japanese]. Japanese. 2002;34:528-32.
Tooley G A, Armstrong S M, Norman T R, Sali A. Acute increases in night-time plasma melatonin levels following a period of meditation. English. 2000;53:69-78.
Youngstedt S D, Kripke D F, Elliott J A. Circadian phase-delaying effects of bright light alone and combined with exercise in humans. English. 2002;282:R259-66.

### Excluded-Outcome

A study was included for a particular question of the review if it analyzed at least one of the pre-determined outcomes relevant to that question. The following studies did not report on any of the outcomes that were appropriate to the question(s) of the review to which they were potentially relevant

Akbulut H, Icli F, Buyukcelik A, Akbulut K G, Demirci S. The role of granulocyte-macrophage-colony stimulating factor, cortisol, and melatonin in the regulation of the circadian rhythms of peripheral blood cells in healthy volunteers and patients with breast cancer. English. 1999;26:1-8.
Anton-Tay FDJLaF-GA. On the effect of melatonin upon human brain. Its possible therapeutic implications. 10. 1971:841–50. CN-00334726.
Arendt J, Aldhous M, Marks V. Alleviation of jet lag by melatonin: preliminary results of controlled double blind trial. English. 1986;292:1170.
Arendt J, Bojkowski C, Folkard S, et al. Some effects of melatonin and the control of its secretion in humans. English. 1985;117:266-83.
Atkinson G, Buckley P, Edwards B, Reilly T, Waterhouse J. Are there hangover-effects on physical performance when melatonin is ingested by athletes before nocturnal sleep?. English. 2001;22:232-4.
Attenburrow M E, Dowling B A, Sargent P A, Sharpley A L, Cowen P J. Melatonin phase advances circadian rhythm. English. 1995;121:503-5.
Bellipanni G, Bianchi P, Pierpaoli W, Bulian D, Ilyia E. Effects of melatonin in perimenopausal and menopausal women: a randomized and placebo controlled study. English. 2001;36:297-310.
Bojkowski CJ AMEJea. Suppression of nocturnal plasma melatonin and 6-sulphatoxymelatonin by bright and dim light in man. 19. 1987:437–40. CN-00381007; EMBASE 1987206723).
Braam W, Smits M. Melatonin Treatment for Chronic Sleep Problems in People With Intellectual Disability: a Randomized Placebo-Controlled Study. English. 2000;44:110.
Bruhl T, Pflug B, Kohler W, Touitou Y, Lemmer B . Bright light in the morning but not in the evening affects circadian rhythms in plasma cAMP, melatonin and cortisol in healthy subjects. 7. 1990:29–32. CN-00358323; EMBASE 1990369642).
Byerley WF, Risch SC, Gillin JC et al. Biological effect of bright light. 13. 1989:683–6. CN-00261859.
Cagnacci A, Soldani R, Yen S S. Hypothermic effect of melatonin and nocturnal core body temperature decline are reduced in aged women. English. 1995;78:314-7.
Cajochen C, Krauchi K, von Arx M A, Mori D, Graw P, Wirz-Justice A. Daytime melatonin administration enhances sleepiness and theta/alpha activity in the waking EEG. English. 1996;207:209-13.
Carman J S, Post R M, Buswell R, Goodwin F K. Negative effects of melatonin on depression. English. 1976;133:1181-6.
Deacon S, English J, Arendt J. Acute phase-shifting effects of melatonin associated with suppression of core body temperature in humans. English. 1994;178:32-4.
Demitrack M A, Lewy A J, Reus V I. Pineal-adrenal interactions: the effect of acute pharmacological blockade of nocturnal melatonin secretion. English. 1990;32:183-9.
Dijk D J, Roth C, Landolt H P, et al. Melatonin effect on daytime sleep in men: suppression of EEG low frequency activity and enhancement of spindle frequency activity. English. 1995;201:13-6.
Emser W, Dechoux R, Weiland M, Wirz-Justice A. Melatonin decreases the amplitude of the b-wave of the human electroretinogram. English. 1993;49:686-7.
Fourtillan J B, Brisson A M, Fourtillan M, Ingrand I, Decourt J P, Girault J. Melatonin secretion occurs at a constant rate in both young and older men and women. English. 2001;280:E11-22.
Gasio P F, Krauchi K, Cajochen C, et al. Dawn-Dusk Simulation Light Therapy of Disturbed Circadian Rest- Activity Cycles in Demented Elderly. English. 2003;38:207-16.
Graw P, Werth E, Krauchi K, Gutzwiller F, Cajochen C, Wirz-Justice A. Early morning melatonin administration impairs psychomotor vigilance. English. 2001;121:167-72.
Hashimoto S, Kohsaka M, Nakamura K, Honma H, Honma S, Honma K. Midday exposure to bright light changes the circadian organization of plasma melatonin rhythm in humans. English. 1997;221:89-92.
Hatonen T, Alila A, Laakso M L. Exogenous melatonin fails to counteract the light-induced phase delay of human melatonin rhythm. English. 1996;710:125-30.
Heiman D L. Effects of melatonin on nocturnal sleep and athletic performance the next day. English. 2002;12:56. 2002077304).
Hughes R J, Badia P. Sleep-promoting and hypothermic effects of daytime melatonin administration in humans. English. 1997;20:124-31.
Jean-Louis G, von Gizycki H, Zizi F. Predictors of subjective sleepiness induced by melatonin administration. English. 1999;47:355-8.
Kahan T L, Hays J, Hirashima B, Johnston K. Effects of melatonin on dream bizarreness among male and female college students. English. 2000;2:74-83. 2000188049).
Kirby A Wa, Clayton M, Rivera P, Comperatore C A. Melatonin and the reduction or alleviation of stress. English. 1999;27:78-85.
Klerman E B, Shanahan T L, Brotman D J, et al. Photic resetting of the human circadian pacemaker in the absence of conscious vision. English. 2002;17:548-55.
Krahn L E, Lin S C, Klee G G, Lu P Y, Ory S J, Zimmermann R C. The effect of presynaptic catecholamine depletion on 6-hydroxymelatonin sulfate: A double blind study of alpha-methyl-para-tyrosine. English. 1999;9:61-6. 1999057206).
Krauchi K, Cajochen C, Mori D, Graw P, Wirz-Justice A. Early evening melatonin and S-20098 advance circadian phase and nocturnal regulation of core body temperature. English. 1997;272:R1178-88.
Kripke D F, Mullaney D J, Klauber M R, Risch S C, Gillin J C. Controlled Trial of Bright Light for Nonseasonal Major Depressive-Disorders. Biological Psychiatry. 1992;31(2):119-34. [pmid: 1737074].
Kunz D, Bes F. Exogenous melatonin in periodic limb movement disorder: an open clinical trial and a hypothesis. English. 2001;24:183-7.
Laakso M L, Hatonen T, Stenberg D, Alila A, Smith S. One-hour exposure to moderate illuminance (500 lux) shifts the human melatonin rhythm. English. 1993;15:21-6.
Lagarde D, Chappuis B, Billaud P F, Ramont L, Chauffard F, French J. Evaluation of pharmacological aids on physical performance after a transmeridian flight. English. 2001;33:628-34.
Leibenluft E F-NSTEWTRN. Effects of exogenous melatonin administration and withdrawal in five patients with rapid-cycling bipolar disorder. [see comments.]. 58. 1997:383–8. CN-00144872.
Lemmer B, Bruhl T, Witte K, Pflug B, Kohler W, Touitou Y. Effects of bright light on circadian patterns of cyclic adenosine monophosphate, melatonin and cortisol in healthy subjects. English. 1994;130:472-7.
Leppamaki S, Partonen T, Vakkuri O, LA nnqvist J, Partinen M, Laudon M. Effect of controlled-release melatonin on sleep quality, mood, and quality of life in subjects with seasonal or weather-associated changes in mood and behaviour. English. 2003;13:137-45.
Lewy A J, Ahmed S, Latham Jackson J M, Sack R L. Melatonin shifts human circadian rhythms according to a phase-response curve. English. 1992;9:380-92. 1992309837).
Lewy A J, Bauer V K, Cutler N L, et al. Morning vs evening light treatment of patients with winter depression[comment]. English. 1998;55:890-6.
Lieberman H R, Garfield G, Waldhauser F, Lynch H J, Wurtman R J, et al. Possible behavioral consequences of light-induced changes in melatonin availability. English. 1985;453:242-52.
Lindblom N, Heiskala H, Hatonen T, et al. No evidence for extraocular light induced phase shifting of human melatonin, cortisol and thyrotropin rhythms. English. 2000;11:713-7.
Lingjaerde O, Bratlid T, Hansen T. Insomnia during the “dark period” in northern Norway An explorative, controlled trial with light treatment. English. 1985;71:506-12.
Lissoni P, Rovelli F, Pittalis S, et al. [Therapy with melatonin does not suppress its endogenous production in healthy volunteers] [Italian]. Italian. 1999;90:84-5.
Lockley S W, Skene D J, James K, Thapan K, Wright J, Arendt J. Melatonin administration can entrain the free-running circadian system of blind subjects. English. 2000;164:R1-6.
Mallo C, Zaidan R, Faure A, Brun J, Chazot G, Claustrat B. Effects of a four-day nocturnal melatonin treatment on the 24 h plasma melatonin, cortisol and prolactin profiles in humans. English. 1988;119:474-80.
Manfredini R, Manfredini F, Conconi F. Standard melatonin intake and circadian rhythms of elite athletes after a transmeridian flight. English. 2000;28:182-6. 2000299293).
Matsumoto M, Sack R La, Blood M L, Lewy A J. The amplitude of endogenous melatonin production is not affected by melatonin treatment in humans. English. 1997;22:42-4.
Matsumoto Y, Mishima K, Satoh K, et al. Total sleep deprivation induces an acute and transient increase in NK cell activity in healthy young volunteers. English. 2001;24:804-9.
McIntyre I M, Norman T R, Burrows G D, Armstrong S M. Melatonin rhythm in human plasma and saliva. English. 1987;4:177-83.
McIntyre I M, Norman T R, Burrows G D, Armstrong S M. Human melatonin response to light at different times of the night. English. 1989;14:187-93.
McLellan T M, Gannon G A, Zamecnik J, Gil V, Brown G M. Low doses of melatonin and diurnal effects on thermoregulation and tolerance to uncompensable heat stress. English. 1999;87:308-16.
Mclellan T M, Smith I F, Gannon G A, Zamecnik J. Melatonin Has No Effect on Tolerance to Uncompensable Heat Stress in Man. English. 2000;83:336-43.
Middleton B, Arendt J, Stone B M. Complex effects of melatonin on human circadian rhythms in constant dim light. English. 1997;12:467-77.
Middleton B A, Stone B M, Arendt J. Melatonin and fragmented sleep patterns. English. 1996;348:551-2.
Miyauchi F, Nanjo K, Kato H, Sasaki T, Yonezawa M, Tsukada Y. The effects of light exposure on plasma concentrations of melatonin, LH, FSH and prolactin in women [Japanese]. Japanese. 1990;66:737-46.
Miyauchi F, Nanjo K, Otsuka K. Effects of continuous lighting on secretion of melatonin and pituitary hormones in women [Japanese]. Japanese. 1991;43:529-34.
Monteleone P, Esposito G, La Rocca A, Maj M. Does bright light suppress nocturnal melatonin secretion more in women than men?. English. 1995;102:75-80.
Nagtegaal J E, Laurant M W, Kerkhof G A, Smits M G, van der Meer Y G, Coenen A M. Effects of melatonin on the quality of life in patients with delayed sleep phase syndrome. English. 2000;48:45-50.
Nathan P J, Burrows G D, Norman T R. Melatonin sensitivity to dim white light in affective disorders. English. 1999;21:408-13.
Nathan P J, Burrows G D, Norman T R. The effect of dim light on suppression of nocturnal melatonin in healthy women and men. English. 1997;104:643-8.
Nathan PJ, Salmon K, Maguire KP, Burrows GD, Norman TR. The Pharmacodynamic Effects of Single Oral Doses of Melatonin in Humans. 1998. CN-00283202.
Nave R, Herer P, Haimov I, Shlitner A, Lavie P. Hypnotic and hypothermic effects of melatonin on daytime sleep in humans: lack of antagonism by flumazenil. English. 1996;214:123-6.
Nishiyama K, Yasue H, Moriyama Y, et al. Acute effects of melatonin administration on cardiovascular autonomic regulation in healthy men. English. 2001;141:E9.
O'Meara K H, Rogers N L, Powell J P IV, Carlin M M, Szuba M P, Dinges D F. Subjective adaptation during chronic sleep restriction at an adverse circadian phase. Sleep. 2002;25(Abstract Supplement):A310-1.
Paccotti P, Terzolo M, Piovesan A, Torta M, Vignani A, Angeli A. Effects of exogenous melatonin on human pituitary and adrenal secretions Hormonal responses to specific stimuli after acute administration of different doses at two opposite circadian stages in men. English. 1988;15:279-87.
Park S J, Tokura H. Bright light exposure during the daytime affects circadian rhythms of urinary melatonin and salivary immunoglobulin A. English. 1999;16:359-71.
Parry B L, Cover H, Mostofi N, et al. Early Versus Late Partial Sleep-Deprivation in Patients With Premenstrual Dysphoric Disorder and Normal Comparison Subjects. English. 1995;152:404-12.
Paul M A, Brown G, Buguet A, et al. Melatonin and zopiclone as pharmacologic aids to facilitate crew rest. English. 2001;72:974-84.
Pawlikowski M, Kolomecka M, Wojtczak A, Karasek M. Effects of six months melatonin treatment on sleep quality and serum concentrations of estradiol, cortisol, dehydroepiandrosterone sulfate, and somatomedin C in elderly women. English. 2002;23:17-9.
Peled N, Shorer Z, Peled E, Pillar G. Melatonin effect on seizures in children with severe neurologic deficit disorders. English. 2001;42:1208-10.
Pierard C, Beaumont M, Enslen M, et al. Resynchronization of hormonal rhythms after an eastbound flight in humans: effects of slow-release caffeine and melatonin. English. 2001;85:144-50.
Ribeiro D C, Hampton S M, Morgan L, Deacon S, Arendt J. Altered postprandial hormone and metabolic responses in a simulated shift work environment. English. 1998;158:305-10.
Rice J, Mayor J, Tucker HA, Bielski RJ. Effect of light therapy on salivary melatonin in seasonal affective disorder. 56. 1995:221–8. CN-00186130; EMBASE 1995187675).
Rogers N L, Phan O, Kennaway D J, Dawson D. Effect of daytime oral melatonin administration on neurobehavioral performance in humans. English. 1998;25:47-53.
Rogers N L, Van Dongen H P, Powell J W IV, et al. Neurobehavioural functioning during chronic sleep restriction at an adverse circadian phase. Sleep. 2002;25(Abstract Supplement):A126-7.
Sack R L, Lewy A J, Blood M L, Stevenson J, Keith L D. Melatonin administration to blind people: phase advances and entrainment. English. 1991;6:249-61.
Samel A, Wegmann H M, Vejvoda M, Maass H, Gundel A, Schutz M. Influence of melatonin treatment on human circadian rhythmicity before and after a simulated 9-hr time shift. English. 1991;6:235-48.
Satoh K, Mishima K. Hypothermic action of exogenously administered melatonin is dose-dependent in humans. English. 2001;24:334-40.
Sharkey K M, Eastman C I. Melatonin phase shifts human circadian rhythms in a placebo-controlled simulated night-work study. English. 2002;282:R454-63.
Shilo L, Dagan Y, Smorjik Y, et al. Effect of melatonin on sleep quality of COPD intensive care patients: a pilot study. English. 2000;17:71-6.
Siegrist C, Benedetti C, Orlando A, et al. Lack of changes in serum prolactin, FSH, TSH, and estradiol after melatonin treatment in doses that improve sleep and reduce benzodiazepine consumption in sleep-disturbed, middle-aged, and elderly patients. English. 2001;30:34-42.
Slotten H A, Krekling S. Does melatonin have an effect on cognitive performance?. English. 1996;21:673-80.
Spitzer R L, Terman M, Malt U F, et al. The efficacy of melatonin in the treatment of jet lag. English. 1998;52:135. 1998226562).
Strassman R J, Qualls C R, Jonathan Lisansky E, Peake G T. Sleep deprivation reduces LH secretion in men independently of melatonin. English. 1991;124:646-51. 1991214929).
Suhner A, Schlagenhauf P, Tschopp A, Hauri-Bionda R, Friedrich-Koch A, Steffen R. Impact of melatonin on driving performance. English. 1998;5:7-13.
Tagaya H, Uchiyama M, Shibui K, et al. Non-rapid-eye-movement sleep propensity after sleep deprivation in human subjects. English. 2002;323:17-20.
Tanaka H, Araki A, Ito J, Tasaki T, Miyamoto A, Cho K. Improvement of hypertonus after treatment for sleep disturbances in three patients with severe brain damage. English. 1997;19:240-4.
Touitou Y, Benoit O, Foret J, et al. Effects of a two-hour early awakening and of bright light exposure on plasma patterns of cortisol, melatonin, prolactin and testosterone in man. English. 1992;126:201-5.
Tozawa T, Mishima K, Satoh K et al. Melatonin replacement therapy for rest-activity rhythm disorders in patients with senile dementia of Alzheimer's type. 1998. CN-00285146.
Trinder J, Armstrong S M, O'Brien C, Luke D, Martin M J. Inhibition of melatonin secretion onset by low levels of illumination. English. 1996;5:77-82.
Tzischinsky O, Lavie P. Melatonin possesses time-dependent hypnotic effects. English. 1994;17:638-45.
Uchiyama M, Okawa M, Shibui K, et al. Poor recovery sleep after sleep deprivation in delayed sleep phase syndrome. English. 1999;53:195-7.
van de Luit L, van der Meulen J, Cleophas T J, Zwinderman A H. Amplified amplitudes of circadian rhythms and nighttime hypotension in patients with chronic fatigue syndrome: improvement by inopamil but not by melatonin. English. 1998;49:903-8.
Wassmer E, Carter P F, Quinn E, et al. Melatonin is useful for recording sleep EEGs: a prospective audit of outcome. English. 2001;43:735-8.
Wassmer E, Quinn E, Whitehouse W, Seri S. Melatonin as a sleep inductor for electroencephalogram recordings in children. English. 2001;112:683-5.
Williams G, Waterhouse J, Mugarza J, Minors D, Hayden K. Therapy of circadian rhythm disorders in chronic fatigue syndrome: no symptomatic improvement with melatonin or phototherapy. English. 2002;32:831-7.
Wirz-Justice A, Werth E, Renz C, Muller S, Krauchi K. No evidence for a phase delay in human circadian rhythms after a single morning melatonin administration. English. 2002;32:1-5.
Zaidan R, Geoffriau M, Brun J, et al. Melatonin is able to influence its secretion in humans: description of a phase-response curve. English. 1994;60:105-12.
Zhdanova I V, Piotrovskaya V R. Melatonin treatment attenuates symptoms of acute nicotine withdrawal in humans. English. 2000;67:131-5.
Zimmermann R C, Krahn L, Klee G, Delgado P, Ory S J, Lin S C. Inhibition of presynaptic catecholamine synthesis with alpha-methyl-para-tyrosine attenuates nocturnal melatonin secretion in humans. English. 1994;79:1110-4.

### Excluded-Reporting

The following studies did not provide an adequate amount of information regarding their outcomes for their inclusion in the quantitative analysis.

Cardinali D P, Gvozdenovich E, Kaplan M R, et al. A double blind-placebo controlled study on melatonin efficacy to reduce anxiolytic benzodiazepine use in the elderly. English. 2002;23:55-60.
Lushington K, Pollard K, Lack L, Kennaway D J, Dawson D. Daytime melatonin administration in elderly good and poor sleepers: effects on core body temperature and sleep latency. English. 1997;20:1135-44.
Spitzer R L, Terman M, Williams J B, et al. Jet lag: clinical features, validation of a new syndrome-specific scale, and lack of response to melatonin in a randomized, double-blind trial. English. 1999;156:1392-6.

### Excluded-Un-Obtainable

The reports of the following studies could not be obtained.

Arendt J. Investigations on the Use of Light and Melatonin for Alleviation of Problems Related to Jetlag and Shift Work. Biologic Effects of Light; 1993; 219–27.
Arendt J, Aldhous M. Further evaluation of the treatment of jet-lag by melatonin: a double-blind crossover study. Annual Review of Chronopharmacology. 1988;5:53-5.
Arendt J, Aldhous M, Wright J. Synchronization of a disturbed sleep-wake cycle in a blind man by melatonin treatment. 1. 1988:772–3.
Boivin D B, Czeisler C A. Investigator: Czeisler CA. Resetting of circadian melatonin and cortisol rhythms in humans by ordinary room light. English. 1998;9:779-82.
Claustrat B, Brun J, Geoffriau M, Zaidan R, Mallo C, Chazot G. Nocturnal plasma melatonin profile and melatonin kinetics during infusion in status migrainosus. English. 17. 1997:511–7; discussion 487.
Cole RJ CLKDAKEJaRK. Light mask treatment of circadian phase disorders. Conference abstract. 1997. CN-00279503.
Dollins AB, Lynch HJ, Deng MH, Wurtman RJ, Lieberman HR. Effects of bright light on human nocturnal performance, mood and serum melatonin levels. 17. 1991:729.
Effects of Exogenous Melatonin on Mood and Sleep Efficiency in EM Academic Emergency Medicine 1999 6(Number 5):502.
Haworth J. A pilot, double-blind, placebo controlled, parellel group study of the effect of melatonin treatment in patients with Alzheimer's disease and sleep. 2001. CN-00342737.
Ho SC. Sleep regulation in old people: the role of bright light and melatonin. English.2001:400 p.
Ishizaki A, Sugama M, Takeuchi N. Usefulness of melatonin for developmental sleep and emotional/behavior disorders--studies of melatonin trial on 50 patients with developmental disorders [Japanese]. Japanese. 31. 1999 428–37.
Kato M, Kajimura N, Sekimoto M, Watanabe T. Melatonin treatment for rhythm disorder. Psychiatry and Clinical Neurosciences. 1998;52(Number 2):262-3. [pmid: 9628186].
Kendel K, Cramer H, Wita C. Influence of melatonin on EEG and human sleep: automatic EEG analyses and polygraphic night sleep investigations [abstract]. 34. 1973:698–9. CN-00300970.
Krahn LE, Lu PY, Klee G, Lin S-C, Zimmermann RC. The Effect of Modified Acute Tryptophan Depletion on Melatonin and Sleep Architecture. 1996. CN-00215506.
Lavie P, Luboshitzky R. Melatonin: Possible Role in Human Sleep and Reproduction. Symposium; 9th: Bioscience. ?, 190?: 209–22.
Moreno J, Belmont A, Heinze G et al. Chronopharmacology of melatonin in a group of normal subjects in Mexico city. Spanish. 20. 1997:8–12. 1998022130).
Nathan PJ SKMKBGaNT. The Pharmacokinetics of Different Oral Formulations of Melatonin: An Acute Study in Humans. 1998. CN-00283203.
Neuroendocrinology Letters 2001; 22(No 4).
Reiter EKGSRUMWFaBG. Sleeping disorders in retarded children: Does Melatonin have a sustained sleep-inducing effect? 147. 1999:907. CN-00339080.
Rodenbeck A, Hajak G, Cohrs S, Staedt J. Desynchronisation Between Light - Dark Cycle, Sleep - Wake Rhythm and Circadian Melatonin: Treatment of “Sleep - Wake Rhythm Disorders”. Biometeorology-International Congress 1996; 14 abstracts(1):105.
Sack LR and Lewy LA. Melatonin Advances Circadian Rhythms In Humans. 1988. CN-00284219.
Serfaty M. Double-blind randomised controlled cross-over trial to determine the effect of low dose melatonin on sleep disorders in the elderly. 2000. CN-00303217.
Singer C, Colling E, Tractenberg R, et al. The Adcs Clinical Trial of Melatonin for the Sleep Disturbance of Alzheimer's Disease: Case Report of an Unusual Sleep/Wake Cycle and Response to Melatonin. English. 2002;10:92.
Smith MG. Impact of sleep/wake schedule disorders at daytime functioning: influence of melatonin. 6. 1999:177. CN-00309319.
Wehr T A, Moul D E, Barbato G, et al. Conservation of photoperiod-responsive mechanisms in humans. English. 1993;265:R846-57.

### Addendum

The authors acknowledge the existence of the following two studies, which they became aware of only upon completion of the final report.

Garfinkel D, Laudon M, Zisapel N. Improvement of sleep quality by controlled-release melatonin in benzodiazepine-treated elderly insomniacs. English. 1997;24:223-31. 1997049410).
Smits M G, Nagtegaal E E, van der Heijden J, Coenen A M, Kerkhof G A. Melatonin for chronic sleep onset insomnia in children: a randomized placebo-controlled trial. English. 2001;16:86-92.