# References and Included Studies

### References

1 National Institute of Health. National Institute of Health. National Center on Sleep Disorder Research. 2003. [underlined: www.nhlbi.nih.gov/health/prof/sleep/res_plan/sleep-rplan.pdf]
2 Roller L. Treating sleep disorders. 83. 2002:443–7.
3 Grustein R. Insomnia. Diagnosis and management. Austr Fam Phys. 2002;31(11):995-1000.
4 NCCAM Clearinghouse. General information about CAM and the NCCAM [Web Page]. 2002; Available at http://nccam.nih.gov/health/whatiscam/#1.
5 World Health Organization. International Classification of Diseases, 9th Revision, Clinical Modification. Salt Lake City, UT: Medicode Pub, 1995.
6 Reite M, Ruddy J, Nagel K. Evaluation and Management of Sleep Disorders, Third Edition. Washington, DC: American Psychiatric Publishing, Inc, 2002.
7 Wagner D R. Circadian Rhythm Sleep Disorders. English. 1999;1:299-308.
8 Czeisler C A, Kronauer R E, Allan J S, et al. Bright light induction of strong (type 0) resetting of the human circadian pacemaker. Science. 1989;244(4910):1328-33. [pmid: 2734611].
9 Cole R J, Smith J S, Alcala Y C, Elliott J A, Kripke D F. Bright-light mask treatment of delayed sleep phase syndrome. English. 2002;17:89-101.
10 Lack L, Wright H. The effect of evening bright light in delaying the circadian rhythms and lengthening the sleep of early morning awakening insomniacs. English. 1993;16:436-43. 1993241681).
11 Campbell S S, Dawson D, Anderson M W. Alleviation of sleep maintenance insomnia with timed exposure to bright light. J Am Geriatr Soc. 1993;41(8):829-36. [pmid: 8340561].
12 Zeitzer J M, Dijk D J, Kronauer R, Brown E, Czeisler C. Sensitivity of the human circadian pacemaker to nocturnal light: melatonin phase-resettng and suppression. J Physiol. 2000;526(Pt 2):695-702. [pmid: 10922269].
13 Khalsa S B, Jewett M E, Cajochen C, Czeisler C A. A phase response curve to single bright light pulses in human subjects. J Physiol. 2003;549(Pt 3):945-52. [pmid: 12717008].
14 Mendelson W B, Jain B. An assessment of short-acting hypnotics. Drug Saf. 1995;13(4):257-70. [pmid: 8573298].
15 Attele A S, Xie J T, Yuan C S. Treatment of insomnia: An alternative approach. English. 2000;5:249-59. 2000227931).
16 Gordon N. The therapeutics of melatonin: a paediatric perspective [Review] [39 refs]. English. 2000;22:213-7.
17 Leone R M, Silman R E. Melatonin can be differentially metabolized in the rat to produce N-acetylserotonin in addition to 6-hydroxy-melatoni. Endocrinology. 1984;114(5):1825-32. [pmid: 6714168].
18 Young I M, Leone R M, Francis P, Stovell P, Silman R E. Melatonin is metabolized to N-acetyl serotonin and 6-hydroxymelatonin in man. Journal of Clinical Endocrinology and Metabolism. 1985;60(1):114-19. [pmid: 3964785].
19 Melatonin and the mammalian pineal gland. London: Chapman and Hall, 1885.
20 Vijayalaxmi, Thomas C R Jr, Reiter R J, Herman T S. Melatonin: From basic research to cancer treatment clinics. English. 2002;20:2575-601. 2002179877).
21 The Merck Index, 10th ed. Rahway, New Jersey: Merck and Co, 1983.
22 Wurtman R J. Melatonin as a hormone in humans: a history. Yale J Biol Med. 1985;58(6):547-52. [pmid: 3914144].
23 Lerner A B, Case J D, Takahashi Y, Lee T H, Mori W. Isolation of melatonin, the pineal gland factor that lightens melanocytes. J Am Chem Soc. 1958;80:2587.
24 Tan D X, Manchester L C, Hardeland R, et al. Melatonin: a hormone, a tissue factor, an autocoid, a paracoid, and an antioxidant vitamin. J Pineal Res. 2003;34(1):75-8. [pmid: 12485375].
25 Anton-Tay FDJLaF-GA. On the effect of melatonin upon human brain. Its possible therapeutic implications. 1971;10:841-50. CN-00334726.
26 Cramer H, Rudolph J, Consbruch U, Kendel K. On the effects of melatonin on sleep and behavior in man. Adv Biochem Psychopharmacol. 1974;11(0):187-91. [pmid: 4367644].
27 Arendt J, Borbely A A, Franey C, Wright J. The effects of chronic, small doses of melatonin given in the late afternoon on fatigue in man: a preliminary study. Neurosci Lett. 1984;45(3):317-21. [pmid: 6728321].
28 Lieberman H R, Waldhauser F, Garfield G, Lynch H J, Wurtman R J. Effects of melatonin on human mood and performance. Brain Res. 1984;323(2):201-7. [pmid: 6525511].
29 Reiter R J. Melatonin: clinical relevance. English. 2003;17:273-85.
30 Geoffriau M, Brun J, Chazot G, Claustrat B. The physiology and pharmacology of melatonin in humans [Review] [49 refs]. English. 1998;49:136-41.
31 Brzezinski A. Melatonin in humans. English. 1997;336:186-95. 1997025177).
32 Tricoire H, Locatelli A, Chemineau P, Malpaux B. Melatonin enters the cerebrospinal fluid through the pineal recess. Endocrinology. 2002;143(1):84-90. [pmid: 11751596].
33 Skinner D C, Malpaux B. High melatonin concentrations in third ventricular cerebrospinal fluid are not due to Galen vein blood recirculating through the choroid plexus. Endocrinol. 1999;140(10):4399-405.
34 Karasek M. Melatonin in humans - where we are 40 years after its discovery. English. 1999;20:179-88. 1999427845).
35 Kennaway D J, Stamp G E, Goble F C. Development of melatonin production in infants and the impact of prematurity. J Clin Endocrinol Metab. 1992;75(2):367-9. [pmid: 1639937].
36 Waldhauser F, Weiszenbacher G, Tatzer E, et al. Alterations in nocturnal serum melatonin levels in humans with growth and aging. J Clin Endocrinol Metab. 1988;66(3):648-52. [pmid: 3350912].
37 Dawson D, van den Heuvel C J. Integrating the actions of melatonin on human physiology [Review] [89 refs]. English. 1998;30:95-102.
38 Zaidan R, Geoffriau M, Brun J, et al. Melatonin is able to influence its secretion in humans: description of a phase-response curve. English. 1994;60:105-12.
39 Jan J E, Espezel H. Melatonin treatment of chronic sleep disorders. Dev Med Child Neurol. 1995;37(3):279-80. [pmid: 7890134].
40 Caldwell J L. The use of melatonin: an information paper [Review] [54 refs]. English. 2000;71:238-44.
41 Shanahan T L, Czeisler C A. Physiological effects of light on the human circadian pacemaker. Semin Perinatol. 2000;24(4):299-320. [pmid: 10975436].
42 Satoh K, Mishima K. Hypothermic action of exogenously administered melatonin is dose-dependent in humans. English. 2001;24:334-40.
43 Deacon S, Arendt J. Melatonin-induced temperature suppression and its acute phase-shifting effects correlate in a dose-dependent manner in humans. English. 1995;688:77-85.
44 Commentz J C, Uhlig H, Henke A, Hellwege H H, Willig R P. Melatonin and 6-hydroxymelatonin sulfate excretion is inversely correlated with gonadal development in children. Horm Res. 1997;47(3):97-101. [pmid: 9050947].
45 Berga S L, Mortola J F, Yen S S. Amplification of nocturnal melatonin secretion in women with functional hypothalamic amenorrhea. J Clin Endocrinol Metab. 1988;66(1):242-4. [pmid: 3335608].
46 Sainz R M, Mayo J C, Reiter R J, Antolin I, Esteban M M, Rodriguez C. Melatonin regulates glucocorticoid receptor: an answer to its antiapoptotic action in thymus. FASEB J. 1999;13(12):1547-56. [pmid: 10463946].
47 Gonzalez-Haba M G, Garcia-Maurino S, Calvo J R, Goberna R, Guerrero J M. High-affinity binding of melatonin by human circulating T lymphocytes (CD4+). FASEB J. 1995;9(13):1331-5. [pmid: 7557023].
48 Sauer L A, Dauchy R T, Blask D E. Polyunsaturated fatty acids, melatonin, and cancer prevention. Biochem Pharmacol. 2001;61(12):1455-62. [pmid: 11377374].
49 Lissoni P. Is there a role for melatonin in supportive care?. Support Care Cancer. 2002;10(2):110-6. [pmid: 11862501].
50 Dubocovich M L, Rivera-Bermudez M A, Gerdin M J, Masana M I. Molecular pharmacology, regulation and function of mammalian melatonin receptors. Front Biosci. 2003;8:d1093-108. [pmid: 12957828].
51 Ebisawa T, Karne S, Lerner M R, Reppert S M. Expression cloning of a high-affinity melatonin receptor from Xenopus dermal melanophores. Proc Natl Acad Sci U S A. 1994;91(13):6133-7. [pmid: 7517042]. [pmcid: 44152].
52 Morgan P J, Barrett P, Howell H E, Helliwell R. Melatonin receptors: localization, molecular pharmacology and physiological significance. Neurochem Int. 1994;24(2):101-46. [pmid: 8161940].
53 Zhdanova I V, Wurtman R J, Regan M M, Taylor J A, Shi J P, Leclair O U. Melatonin treatment for age-related insomnia. English. 2001;86:4727-30.
54 Andrade C, Srihari B S, Reddy K P, Chandramma L. Melatonin in medically ill patients with insomnia: a double-blind, placebo-controlled study. English. 2001;62:41-5.
55 Haimov I, Lavie P, Laudon M, Herer P, Vigder C, Zisapel N. Melatonin replacement therapy of elderly insomniacs. English. 1995;18:598-603.
56 James S P, Sack D A, Rosenthal N E, Mendelson W B. Melatonin administration in insomnia. English. 1990;3:19-23.
57 Almeida Montes L G, Ontiveros Uribe M P, Heinze Martin G. CortA(C)s Sotres J. Treatment of primary insomnia with melatonin: a double-blind, placebo-controlled, crossover study. English. 2003;28:191-6.
58 Garfinkel D, Laudon M, Nof D, Zisapel N. Improvement of sleep equality in elderly people by controlled-release melatonin. 346. 1995:541–4. CN-00170338. EMBASE 1995261201.
59 Smits M G, Van Stel H F, Van Der Heijden K, Meijer A M, Coenen A M, Kerkhof G A. Melatonin improves health status and sleep in children with idiopathic chronic sleep-onset insomnia: A randomized lacebo-controlled trial. J Am Acad Child Adolesc Psychiatry. 2003;42(11):1286-93. [pmid: 14566165].
60 Ellis C M, Lemmens G, Parkes J D. Melatonin and insomnia. English. 1996;5:61-5.
61 Suhner A, Schlagenhauf P, Hofer I, Johnson R, Tschopp A, Steffen R. Effectiveness and tolerability of melatonin and zolpidem for the alleviation of jet lag. English. 2001;72:638-46.
62 Spitzer R L, Terman M, Williams J B, et al. Jet lag: clinical features, validation of a new syndrome-specific scale, and lack of response to melatonin in a randomized, double-blind trial. English. 1999;156:1392-6.
63 Suhner A, Schlagenhauf P, Johnson R, Tschopp A, Steffen R. Comparative study to determine the optimal melatonin dosage form for the alleviation of jet lag. English. 1998;15:655-66.
64 Petrie K, Dawson A G, Thompson L, Brook R. A double-blind trial of melatonin as a treatment for jet lag in international cabin crew. English. 1993;33:526-30.
65 Petrie K, Conaglen J V, Thompson L, Chamberlain K. Effect of melatonin on jet lag after long haul flights. English. 1989;298:705-7.
66 Jockovich M, Cosentino D, Cosentino L, Wears R L, Seaberg D C. Effect of exogenous melatonin on mood and sleep efficiency in emergency medicine residents working night shifts. English. 2000;7:955-8.
67 Wright S W, Lawrence L M, Wrenn K D, Haynes M L, Welch L W, Schlack H M. Randomized clinical trial of melatonin after night-shift work: efficacy and neuropsychologic effects[comment]. English. 1998;32:334-40.
68 James M, Tremea M O, Jones J S, Krohmer J R. Can melatonin improve adaptation to night shift?. English. 1998;16:367-70.
69 Jorgensen K M, Witting M D. Does exogenous melatonin improve day sleep or night alertness in emergency physicians working night shifts?. English. 1998;31:699-704.
70 Folkard S, Arendt J, Clark M. Can melatonin improve shift workers' tolerance of the night shift? Some preliminary findings. English. 1993;10:315-20.
71 Kayumov L, Brown G, Jindal R, Buttoo K, Shapiro C M. A randomized, double-blind, placebo-controlled crossover study of the effect of exogenous melatonin on delayed sleep phase syndrome. English. 2001;63:40-8.
72 Nagtegaal J E, Smits M G, Swart A C, Kerkhof G A, van der Meer Y G. Melatonin-responsive headache in delayed sleep phase syndrome: preliminary observations. English. 1998;38:303-7.
73 Camfield P, Gordon K, Dooley J, Camfield C. Melatonin appears ineffective in children with intellectual deficits and fragmented sleep: six “N of 1” trials[comment]. English. 1996;11:341-3.
74 Dahlitz M, Alvarez B, Vignau J, English J, Arendt J, Parkes J D. Delayed sleep phase syndrome response to melatonin. English. 1991;337:1121-4.
75 Smith MG. Impact of sleep/wake schedule disorders at daytime functioning: influence of melatonin. 6. 1999:177. CN-00309319.
76 Jan J E, Espezel H, Appleton R E. The treatment of sleep disorders with melatonin[comment]. English. 1994;36:97-107.
77 Cavallo A, Good W V, Douglas Ris M, Succop P. Dose response to melatonin treatment for disordered sleep rhythm in a blind child. English. 2002;3:159-61. 2002137904).
78 Serfaty M, Kennell-Webb S, Warner J, Blizard R, Raven P. Double blind randomised placebo controlled trial of low dose melatonin for sleep disorders in dementia. English. 2002;17:1120-7.
79 Gehrman PR, Connor D, Marler M et al. Bright light improves sleep but melatonin does not in severe Alzheimer's Disease. 25. 2002:A438–9.
80 McArthur A J, Budden S S. Sleep dysfunction in Rett syndrome: a trial of exogenous melatonin treatment. English. 1998;40:186-92.
81 O'callaghan F J K, Clarke A A, Hancock E, Hunt A, Osborne J P. Use of Melatonin to Treat Sleep Disorders in Tuberous Sclerosis. English. 1999;41:123-6.
82 Dodge N N, Wilson G A. Melatonin for treatment of sleep disorders in children with developmental disabilities. English. 2001;16:581-4.
83 Leibenluft E, Feldman-Naim S, Turner EH, Wehr TA, Rosenthal NE. Effects of exogenous melatonin administration and withdrawal in five patients with rapid-cycling bipolar disorder. [see comments.]. 58. 1997:383–8. CN-00144872.
84 Sherer M A, Weingartner H, James S P, Rosenthal N E. Effects of melatonin on performance testing in patients with seasonal affective disorder. English. 1985;58:277-82.
85 Wirz-Justice A, Graw P, Krauchi K, et al. Morning or night-time melatonin is ineffective in seasonal affective disorder. English. 1990;24:129-37.
86 Miyamoto A, Oki J, Takahashi S, Okuno A. Serum melatonin kinetics and long-term melatonin treatment for sleep disorders in Rett syndrome[comment]. English. 1999;21:59-62.
87 Chou I C, Tsai F J, Yu M T, Tsai C H. Smith-Magenis syndrome with bilateral vesicoureteral reflux: A case report. English. 2002;101:726-8. 2003011510).
88 Zhdanova I V, Wurtman R J, Wagstaff J. Effects of a low dose of melatonin on sleep in children with Angelman syndrome. English. 1999;12:57-67. 1999180932).
89 Boeve B F. Melatonin for treatment of REM sleep behavior disorder in neurologic disorders: results in 14 patients. Sleep Med. 2003;4(4):281-4. [pmid: 14592300].
90 Garfinkel D, Laudon M, Nof D, Zisapel N. Improvement of sleep quality in elderly people by controlled-release melatonin[comment]. English. 1995;346:541-4.
91 Baskett J J, Broad J B, Wood P C, et al. Does Melatonin Improve Sleep in Older People? A Randomised Crossover Trial. English. 2003;32:164-70.
92 Matsumoto M. The hypnotic effects of melatonin treatment on diurnal sleep in humans. English. 1999;53:243-5.
93 Waldhauser F, Waldhauser M, Lieberman H R, Deng M H, Lynch H J, Wurtman R J. Bioavailability of oral melatonin in humans. Neuroendocrinol. 1984;39(4):307-13.
94 Wright J, Aldhous M, Franey C, English J, Arendt J. The effects of exogenous melatonin on endocrine function in man. English. 1986;24:375-82.
95 Van Wieringen S, Jansen T, Smits M G, Nagtegaal J E, Coenen A M L. Melatonin for chronic whiplash syndrome with delayed melatonin onset: Randomised, placebo-controlled trial. English. 2001;21:813-20. 2002032315).
96 Rogers N L, Phan O, Kennaway D J, Dawson D. Effect of daytime oral melatonin administration on neurobehavioral performance in humans. English. 1998;25:47-53.
97 Sheldon S H. Pro-convulsant effects of oral melatonin in neurologically disabled children. English. 1998;351:1254. 1998132907).
98 Carman J S, Post R M, Buswell R, Goodwin F K. Negative effects of melatonin on depression. English. 1976;133:1181-6.
99 Hong Y G, Riegler J L. Is melatonin associated with the development of autoimmune hepatitis?. J Clin Gastroenterol. 1997;25(1):376-8. [pmid: 9412927].
100 Herxheimer A, Petrie KJ. Melatonin for preventing and treating jet lag [update in Cochrane Database Syst Rev 2002;(2):CD001520; PMID: 12076414. English2001:CD001520.
101 Olde Rikkert M G, Rigaud A S. Melatonin in elderly patients with insomnia A systematic review [Review] [25 refs]. English. 2001;34:491-7.
102 Chase J E, Gidal B E. Melatonin: therapeutic use in sleep disorders [Review] [41 refs]. English. 1997;31:1218-26.
103 Willey C, Phillips B. Is melatonin likely to help children with neurodevelopmental disability and chronic severe sleep problems? [Review] [6 refs]. English. 2002;87:260.
104 Sugden D. Psychopharmacological effects of melatonin in mouse and rat. J Pharmacol Exp Ther. 1983;227(3):587-91. [pmid: 6655558].
105 U. S. Food and Drug Administration Center for Food Safety and Applied Nutrition. Dietary Supplement Health and Education Act of 1994, 1994.
106 Sleep Foundation. Melatonin: the basic facts [Web Page]. 2003;
107 Institute Med Ntl Acad. Not provided [Web Page]. Not provided; Available at http://www.iom.edu/project.asp? id=4605. (Accessed ?).
108 Natural Health Products Directorate. Overview of the Natural Health Products Regulations Guidance Document [Web Page]. 2003; Available at www.hc-sc.gc.ca/hpfb-dgpsa/nhpd/dpsn/overview_nhp_regs_e.html. (Accessed January 2004).
109 Standing Committee on the Food Chain and Animal Health. Section on General Food Law; Summary Record of 6th Meeting [Web Page]. 2003; Available at http://europa.eu.int/comm/food/fs/rc/scfcah/general/agen04_en.pdf.
110 MIMS Consumer Health Group, A. Expert calls for melatonin approval [Web Page]. 2002; Available at www.mydr.com.au/default.asp?Article=3622.
111 Reviewer's Handbook Glossary. Chichester, UK: John Wiley & Sons, Ltd., 2004.
112 Moher D, Pham B, Lawson M L, Klassen T P. The inclusion of reports of randomised trials published in languanges other than English in systematic reviews. Health Technol Assess. 2003;7(41):1-90. [pmid: 14670218].
113 Jadad A R, Moore R A, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Controlled Clin Trials. 1996;17:1-12. [pmid: 8721797].
114 Schulz K F, Chalmers I, Hayes R J, Altman D. Empirical evidence of bias. Dimensions of methodological quality associated with estimates of treatment effects in controlled trials. J Am Med Assoc. 1995;273(5):408-12.
115 Downs S H, Black N. The feasibility of creating a checklist for the assessment of the methodological quality both of randomized and non-randomized studies of health care interventions. J Epidemiol Commun Health. 1998;52:377-84.
116 DerSimonian R, Laird N. Meta-analysis in clinical trials. Controlled Clin Trials. 1986;7:177-88. [pmid: 3802833].
117 Bailey K. Inter-study differences: How should they influence the interpretation and analysis of results?. Stat Med. 1987;6:351-8. [pmid: 3616288].
118 Higgins J P T, Thompson S G. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002;21(11):1539-58. [pmid: 12111919].
119 Deeks JJ, Altman DG, Bradburn MJ. Statistical methods for examining heterogeneity and combining results from several studies in meta-analysis. Systematic Reviews in Health Care 2001; 300.
120 Begg C B, Mazumdar M. Operating characteristics of a rank correlation test for publication bias. Biometrics. 1994;50:1088-101. [pmid: 7786990].
121 Egger M, Smith G D, Schneider M, Minder C. Bias in meta-analysis detected by a single graphical test. Br Med J. 1997;315:629-34. [pmid: 9310563]. [pmcid: 2127453].
122 Duval S, Tweedie R. A nonparametric “trim and fill” method of accounting for publication bias in meta-analysis. J Am Med Assoc. 2000;95(449):89-98.
123 Satomura T, Sakamoto T, Shirakawa S, et al. Hypnotic action of melatonin during daytime administration and its comparison with triazolam. English. 2001;55:303-4.
124 Seabra M L, Bignotto M, Pinto L R Jr, Tufik S. Randomized, double-blind clinical trial, controlled with placebo, of the toxicology of chronic melatonin treatment. English. 2000;29:193-200.
125 Serfaty M A, Osborne D, Buszewicz M J, Raven P W. The effect of exogeneous melatonin in major depression. Chronobiol Int. 2003;20:1191-2.
126 Luboshitzky R, Levi M, Shen-Orr Z, Blumenfeld Z, Herer P, Lavie P. Long-term melatonin administration does not alter pituitary-gonadal hormone secretion in normal men. English. 2000;15:60-5.
127 Shah J, Langmuir V, Gupta S K. Feasibility and functionality of OROS melatonin in healthy subjects. English. 1999;39:606-12.
128 Lushington K, Galka R, Sassi L N, Kennaway D J, Dawson D. Extraocular light exposure does not phase shift saliva melatonin rhythms in sleeping subjects. English. 2002;17:377-86.
129 Shamir E, Barak Y, Plopsky I, Zisapel N, Elizur A, Weizman A. Is melatonin treatment effective for tardive dyskinesia?. J Clin Psychiatry. 2000;61(8):556-8. [pmid: 10982197].
130 Shamir E, Barak Y, Shalman I, et al. Melatonin treatment for tardive dyskinesia: a double-blind, placebo-controlled, crossover study. Arch Gen Psychiatry. 2001;58(11):1049-52. [pmid: 11695951].
131 Shamir E, Laudon M, Barak Y, et al. Melatonin improves sleep quality of patients with chronic schizophrenia. English. 2000;61:373-7.
132 Shamir E, Rotenberg V S, Laudon M, Zisapel N, Elizur A. First-night effect of melatonin treatment in patients with chronic schizophrenia. English. 2000;20:691-4.
133 Shirakawa S-I, Sakamoto T, Uchimura N, Tsutsumi Y, Tanaka J, Maeda H. Effect of melatonin on sleep and rectal temperature of young healthy evening types. English. 2001;55:301-2. 2001225764).
134 Shirakawa S-I, Tsuchiya S, Tsutsumi Y, Kotorii T. Time course of saliva and serum melatonin levels after ingestion of melatonin. Psychiatry Clin Neurosci. 1998;52(2):266-7. [pmid: 9628188].
135 Singer C, Tractenberg R E, Kaye J, et al. A multicenter, placebo-controlled trial of melatonin for sleep disturbance in Alzheimer's disease. Sleep. 2003;26(7):893-901. [pmid: 14655926].
136 Skene D J, Deacon S, Arendt J. Use of melatonin in circadian rhythm disorders and following phase shifts [Review] [23 refs]. English. 1996;56:359-62.
137 Zhdanova I V, Wurtman R J, Regan M M, Taylor J A, Shi J P, Leclair O U. Melatonin treatment for age-related insomnia. English. 2001;86:4727-30.
138 Waldhauser F, Saletu B, Trinchard-Lugan I. Sleep laboratory investigations on hypnotic properties of melatonin. English. 1990;100:222-6.
139 Haimov I, Lavie P, Laudon M, Herer P, Vigder C, Zisapel N. Melatonin replacement therapy of elderly insomniacs. English. 1995;18:598-603.
140 James S P, Sack D A, Rosenthal N E, Mendelson W B. Melatonin administration in insomnia. English. 1990;3:19-23.
141 Dawson D, Rogers N L, van den Heuvel C J, Kennaway D J, Lushington K. Effect of sustained nocturnal transbuccal melatonin administration on sleep and temperature in elderly insomniacs. English. 1998;13:532-8.
142 Beaumont M, Batejat D, Pierard C, et al. Caffeine or melatonin effects on sleep and sleepiness after rapid eastward transmeridian travel. J Appl Physiol. 2004;96(1):50-8. [pmid: 12959951].
143 Smits MG VSHVDHKMACAKGA. Melatonin Improves Health Status and Sleep in Children With Idiopathic Chronic Sleep-Onset Insomnia: A Randomized Placebo-Controlled Trial. 42. 2003:1286–93.
144 Hood E, Buttross S, Parks B. A placebo-controlled, double-blind, crossover trial of melatonin in the management of sleep disturbances in children with behavioral disorders. English. 1999;47:114.
145 Claustrat B, Brun J, David M, Sassolas G, Chazot G. Melatonin and jet lag: confirmatory result using a simplified protocol[comment]. English. 1992;32:705-11.
146 Fraschini F, Cesarani A, Alpini D, Esposti D, Stankov B M. Melatonin Influences Human Balance. English. 1999;8:111-9.
147 Paccotti P, Terzolo M, Torta M, et al. Acute administration of melatonin at two opposite circadian stages does not change responses to gonadotropin releasing hormone, thyrotropin releasing hormone and ACTH in healthy adult males. English. 1987;10:471-7.
148 Jean-Louis G, von Gizycki H, Zizi F. Melatonin effects on sleep, mood, and cognition in elderly with mild cognitive impairment. English. 1998;25:177-83.
149 Monti J M, Alvarino F, Cardinali D, Savio I, Pintos A. Polysomnographic study of the effect of melatonin on sleep in elderly patients with chronic primary insomnia. English. 1999;28:85-98. 1999095367).
150 Naguib M, Samarkandi A H. Premedication With Melatonin: a Double-Blind, Placebo- Controlled Comparison With Midazolam. English. 1999;82:875-80.
151 Edwards B J, Atkinson G, Waterhouse J, Reilly T, Godfrey R, Budgett R. Use of melatonin in recovery from jet-lag following an eastward flight across 10 time-zones. English. 2000;43:1501-13.
152 Almeida Montes L G, Ontiveros Uribe M P, Cortes Sotres J, Heinze Martin G. Treatment of primary insomnia with melatonin: A double-blind, placebo-controlled, crossover study. J Psychiatry Neurosci. 2003;28(3):191-6. [pmid: 12790159]. [pmcid: 161743].
153 Di W-D, Kavda A, Johnston A, Silman R. Variable bioavailability of oral melatonin. 336. 1997:1028–129.
154 Aldous M, Franey C, Wright J, Arendt J. Plasma Concentrations of Melatonin in Man Following Oral Absorption of Different Preparations. Br J Clin Pharmacol. 1985;19:517-21. [pmid: 3994899]. [pmcid: 1463812].
155 Debus O M, Lerchl A, Bothe H W, et al. Spontaneous central melatonin secretion and resorption kinetics of exogenous melatonin: a ventricular CSF study. English. 2002;33:213-7.
156 Helrich E, Neef C, Merkus FWWM. Population pharmacokinetics of intranasally administered low dose melatonin. 53. 2002:543–4.
157 Hoffmann H, Dittgen M, Hoffmann A, et al. Evaluation of an oral pulsatile delivery system for melatonin in humans. English. 1998;53:462-6.
158 Kovacs J, Brodner W, Kirchlechner V, Arif T, Waldhauser F. Measurement of urinary melatonin: a useful tool for monitoring serum melatonin after its oral administration. English. 2000;85:666-70.
159 Lee B, Ryu S, Choi H, et al. Batch variation and pharmacokinetics of oral sustained release melatonin-loaded sugar spheres in human subjects. Arch Pharmacal Res. 1997;20(6):555-9.
160 Van Den Heuvel C J, Kennaway D J, Dawson D. Thermoregulatory and soporific effects of very low dose melatonin injection. English. 1999;276:E249-E254. 1999078469).
161 Lewy A J, Bauer V K, Ahmed S, et al. The human phase response curve (PRC) to melatonin is about 12 hours out of phase with the PRC to light. English. 1998;15:71-83.
162 Deacon S, Arendt J. Melatonin-induced temperature suppression and its acute phase-shifting effects correlate in a dose-dependent manner in humans. English. 1995;688:77-85.
163 Benes L, Claustrat B, Horriere F, et al. Transmucosal, oral controlled-release, and transdermal drug administration in human subjects: a crossover study with melatonin. J Pharm Sci. 1997;86(10):1115-9. [pmid: 9344167].
164 Cagnacci A, Elliott J A, Yen S S. Melatonin: a major regulator of the circadian rhythm of core temperature in humans. English. 1992;75:447-52.
165 Cagnacci A, Soldani R, Laughlin G A, Yen S S. Modification of circadian body temperature rhythm during the luteal menstrual phase: role of melatonin. English. 1996;80:25-9.
166 Dawson D, Gibbon S, Singh P. The hypothermic effect of melatonin on core body temperature: is more better?. English. 1996;20:192-7.
167 Dollins A B, Lynch H J, Wurtman R J, et al. Effect of pharmacological daytime doses of melatonin on human mood and performance. English. 1993;112:490-6.
168 Dollins A B, Zhdanova I V, Wurtman R J, Lynch H. Deng MH Investigator: Wurtman RJ. Effect of inducing nocturnal serum melatonin concentrations in daytime on sleep, mood, body temperature, and performance. English. 1994;91:1824-8.
169 Kane M A, Johnson A, Nash A E, et al. Serum melatonin levels in melanoma patients after repeated oral administration. English. 1994;4:59-65.
170 MacFarlane J G, Cleghorn J M, Brown G M, Streiner D L. The effects of exogenous melatonin on the total sleep time and daytime alertness of chronic insomniacs: a preliminary study. English. 1991;30:371-6.
171 Niederhofer H, Staffen W, Mair A, Pittschieler K. Brief report: melatonin facilitates sleep in individuals with mental retardation and insomnia. J Autism Dev Disord. 2003;33(4):469-72. [pmid: 12959427].
172 Rajaratnam S M, Dijk D J, Middleton B, Stone B, Arendt J. Melatonin phase-shifts human circadian rhythms with no evidence of changes in the duration of endogenous melatonin secretion or the 24-hour production of reproductive hormones. J Clin Endocrinol Metab. 2002;88(9):4303-9.
173 Cavallo A, Ritschel W A. Pharmacokinetics of melatonin in human sexual maturation. English. 1996;81:1882-6.
174 Yoon I, Jeong D, Kwon K, Kang S. Homeostatic and circadian factors in improving adaptation of rapidly rotating night shift workers. Sleep 2000; 23(Abstract Supplement 2):A186.
175 Arnulf I, Quintin P, Alvarez J C, Touitou Y, Derenne J P, Leboyer M. Mid-morning tryptophan depletion delays REM sleep onset in healthy subjects. Neuropsychopharmacol. 2001;23(5):843-51.
176 Bunnell D E, Treiber S P, Phillips N H, Berger R J. Effects of evening bright light exposure on melatonin, body temperature and sleep. English. 1992;1:17-23. 1992163170).
177 Buxton O M, L'Hermite-Baleriaux M, Turek F W, van Cauter E. Daytime naps in darkness phase shift the human circadian rhythms of melatonin and thyrotropin secretion. English. 2000;278:R373-82.
178 Costa G, Kovacic M, Bertoldi A, Minors D, Waterhouse J. The use of a light visor during night work by nurses. English. 1997;28:16-25. 1997132808).
179 Danilenko K V, Wirz-Justice A, Krauchi K, Weber J M, Terman M. The human circadian pacemaker can see by the dawn's early light. English. 2000;15:437-46.
180 Ecker AJ, Schaechter J, Price NJ et al. Changes in plasma melatonin secretion following chronic sleep restriction. Sleep 2000; 23(Abstract Supplement 2):A184–5.
181 Goichot B, Weibel L, Chapotot F, Gronfier C, Piquard F, Brandenberger G. Effect of the shift of the sleep-wake cycle on three robust endocrine markers of the circadian clock. English. 1998;275:E243-8.
182 Higuchi S, Motohashi Y, Liu Y, Ahara M, Kaneko Y. Effects of VDT tasks with a bright display at night on melatonin, core temperature, heart rate, and sleepiness. English. 2003;94:1773-6.
183 Horne J A, Donlon J, Arendt J. Green light attenuates melatonin output and sleepiness during sleep deprivation. English. 1991;14:233-40.
184 Jelinkova-Vondrasova D, Hajek I, Illnerova H. Adjustment of the human circadian system to changes of the sleep schedule under dim light at home. English. 1999;265:111-4.
185 Jimerson D C, Lynch H J, Post R M, Wurtman R J, Bunney W E Jr. Urinary melatonin rhythms during sleep deprivation in depressed patients and normals. English. 1977;20:1501-8.
186 Samel A, Wegmann H M, Vejvoda M. Pre-adaptation to shiftwork in space. English. 1993;29:593-9.
187 Wehr T A. The durations of human melatonin secretion and sleep respond to changes in daylength (photoperiod). English. 1991;73:1276-80.
188 Cole R J, Smith J S, Alcala Y C, Elliott J A, Kripke D F. Bright-light mask treatment of delayed sleep phase syndrome. English. 2002;17:89-101.
189 Ando K, Kripke D F, Cole R J, Elliott J A. Light mask 500 lux treatment for delayed sleep phase syndrome. Prog Neuro-Psychopharmacol Biol Psychiatry. 1999;23(1):15-24.
190 Budnick L D, Lerman S E, Nicolich M J. An evaluation of scheduled bright light and darkness on rotating shiftworkers: trial and limitations. English. 1995;27:771-82.
191 Cajochen C, Zeitzer J M, Czeisler C A, Dijk D J. Investigator: Czeisler CA, Dijk DJ. Dose-response relationship for light intensity and ocular and electroencephalographic correlates of human alertness. English. 2000;115:75-83.
192 Dollins AB, Lynch HJ, Wurtman RJ, Deng MH, Lieberman HR. Effects of illumination on human nocturnal serum melatonin levels and performance. 53. 1993:153–60. CN-00392108; EMBASE 1993026694).
193 Horowitz T S, Cade B E, Wolfe J M, Czeisler C A. Efficacy of bright light and sleep/darkness scheduling in alleviating circadian maladaptation to night work. English. 2001;281:E384-91.
194 Lavoie S, Paquet J, Selmaoui B, Rufiange M, Dumont M. Vigilance levels during and after bright light exposure in the first half of the night. Chronobiol Int. 2003;20(6):1019-38. [pmid: 14680141].
195 Ross J K, Arendt J, Horne J, Haston W. Night-shift work in Antarctica: sleep characteristics and bright light treatment. English. 1995;57:1169-74.
196 von Treuer K, Norman T R, Armstrong S M. Overnight human plasma melatonin, cortisol, prolactin, TSH, under conditions of normal sleep, sleep deprivation, and sleep recovery. English. 1996;20:7-14.
197 Boulos Z, Macchi M M, Sturchler M P, et al. Light visor treatment for jet lag after westward travel across six time zones. English. 2002;73:953-63.
198 Goh V H, Tong T Y, Lim C L, Low E C, Lee L K. Effects of one night of sleep deprivation on hormone profiles and performance efficiency. English. 2001;166:427-31.
199 Gordijn M C, Beersma D G, Korte H J, van den Hoofdakker R H. Effects of light exposure and sleep displacement on dim light melatonin onset. English. 1999;8:163-74.
200 Redwine L, Hauger R L, Gillin J C, Irwin M. Effects of sleep and sleep deprivation on interleukin-6, growth hormone, cortisol, and melatonin levels in humans. English. 2000;85:3597-603.
201 Koorengevel K M, Gordijn M C, Beersma D G, et al. Extraocular light therapy in winter depression: a double-blind placebo-controlled study[erratum appears in Biol Psychiatry 2002 Jan 15;51(2);194]. English. 2001;50:691-8.
202 Rao M L, Pelzer E, Papassotiropoulos A, Tiemeier H, Jonck L, Moller H J. Selective slow-wave sleep deprivation influences blood serotonin profiles and serum melatonin concentrations in healthy subjects. English. 1996;40:664-7.
203 Partonen T, Vakkuri O, Lamberg-Allardt C, Lonnqvist J. Effects of bright light on sleepiness, melatonin, and 25-hydroxyvitamin D(3) in winter seasonal affective disorder. English. 1996;39:865-72.
204 Kubota T, Uchiyama M, Suzuki H, et al. Effects of nocturnal bright light on saliva melatonin, core body temperature and sleep propensity rhythms in human subjects. English. 2002;42:115-22.
205 Burgess H J, Sletten T, Savic N, Gilbert S S, Dawson D. Effects of bright light and melatonin on sleep propensity, temperature, and cardiac activity at night. English. 2001;91:1214-22.
206 Daurat A, Foret J, Touitou Y, Benoit O. Detrimental influence of bright light exposure on alertness, performance, and mood in the early morning. English. 1996;26:8-14.
207 Dijk D J, Beersma D G M, Daan S, Lewy A J. Bright morning light advances the human circadian system without affecting NREM sleep homeostasis. Am J Physiol - Reg Integr Comparative Physiol. 1989;256(1):25-1.
208 Wakamura T, Tokura H. The influence of bright light during the daytime upon circadian rhythm of core temperature and its implications for nocturnal sleep. English. 2000;2:41-9.
209 Daurat A, Aguirre A, Foret J, Benoit O. Disruption of sleep recovery after 36 hours of exposure to moderately bright light. English. 1997;20:352-8.
210 Kelly T L, Kripke D F, Hayduk R, Ryman D, Pasche B, Barbault A. Bright light and LEET effects on circadian rhythms, sleep and cognitive performance. English. 1997;13:251-8.
211 Bougrine S, Mollard R, Ignazi G, Coblentz A. Appropriate use of bright light promotes a durable adaptation to night-shifts and accelerates readjustment during recovery after a period of night-shifts. Work Stress. 1995;9(23):314-26. [pmid: 11539393].
212 Gordijn M C, Beersma D G, Korte H J, Van den Hoofdakker R H. Testing the hypothesis of a circadian phase disturbance underlying depressive mood in nonseasonal depression. English. 1998;13:132-47.
213 von Treuer K, Norman T R, Armstrong S M. Overnight human plasma melatonin, cortisol, prolactin, TSH, under conditions of normal sleep, sleep depreivation and sleep recovery. J Pineal Res. 1996;20(1):7-14. [pmid: 8648563].
214 Salin-Pascual R J, Ortega-Soto H, Huerto-Delgadillo L, Camacho-Arroyo I, Roldan-Roldan G, Tamarkin L. The effect of total sleep deprivation on plasma melatonin and cortisol in healthy human volunteers. English. 1988;11:362-9.
215 Weibel L, Spiegel K, Gronfier C, Follenius M, Brandenberger G. Twenty-four-hour melatonin and core body temperature rhythms: Their adaptation in night workers. English. 1997;272:R948-R954. 1997102315).
216 Morris M, Lack L, Barrett J. The effect of sleep/wake state on nocturnal melatonin excretion. English. 1990;9:133-8. 1991006017).
217 Danilenko K V, Cajochen C, Wirz-Justice A. Is sleep per se a zeitgeber in humans?. English. 2003;18:170-8.
218 Edwards B J, Atkinson G, Waterhouse J, Reilly T, Godfrey R, Budgett R. Use of melatonin in recovery from jet-lag following an eastward flight across 10 time-zones. Ergonom. 2000;43(10):1501-13.
219 Terlo L, Laudon M, Tarasch R, Schatz T, Caine Y G, Zisapel N. Effects of low doses of melatonin on late afternoon napping and mood. English. 1997;28:2-15. 1997132807).
220 Zhdanova I V, Wurtman R J, Lynch H J, et al. Sleep-inducing effects of low doses of melatonin ingested in the evening. English. 1995;57:552-8.
221 Mishima K, Satoh K, Shimizu T, Hishikawa Y. Hypnotic and hypothermic action of daytime-administered melatonin. English. 1997;133:168-71.
222 Holmes A L, Gilbert S S, Dawson D. Melatonin and zopiclone: the relationship between sleep propensity and body temperature. English. 2002;25:301-6.
223 Cagnacci A, Soldani R, Yen S S. The effect of light on core body temperature is mediated by melatonin in women. English. 1993;76:1036-8.
224 Eastman C I, Martin S K, Hebert M. Failure of extraocular light to facilitate circadian rhythm reentrainment in humans. English. 2000;17:807-26.
225 Strassman R J, Qualls C R, Lisansky E J, Peake G T. Elevated rectal temperature produced by all-night bright light is reversed by melatonin infusion in men. English. 1991;71:2178-82.
226 Morita T, Tokura H. Effects of lights of different color temperature on the nocturnal changes in core temperature and melatonin in humans. English. 1996;15:243-6.
227 Fletcher A, Van den Heuvel C, Dawson D. Sleeping with an electric blanket: Effects on core temperature, sleep, and melatonin in young adults. English. 1999;22:313-8. 1999174642).
228 Wright K J, Badia P, Myers B L, Plenzler S C, Hakel M. Caffeine and light effects on nighttime melatonin and temperature levels in sleep-deprived humans. Brain Res. 1997;747(1):78-84. [pmid: 9042530].
229 Ferini-Strambi L, Zucconi M, Biella G, et al. Effect of melatonin on sleep microstructure: preliminary results in healthy subjects. English. 1993;16:744-7.
230 Suhner A, Schlagenhauf P, Hofer I, Johnson R, Tschopp A, Steffen R. Effectiveness and tolerability of melatonin and zolpidem for the alleviation of jet lag. English. 2001;72:638-46.
231 Lewy A J, Ahmed S, Jackson J M, et al. Melatonin shifts human circadian rhythms according to a phase response curve. Chronobiol Int. 1992;9(5):380-92. [pmid: 1394610].
232 Pollack C P, Tryon W W, Nagaraja H, et al. How accurately does wrist actigraphy identify the states of sleep and wakefulness?. Sleep. 2001;24(8):957-65. [pmid: 11766166].
233 deSouza L, Benedito-silva A A, Pires M L, et al. Further validation of actigraphy for sleep studies. Sleep. 2003;26(1):81-5. [pmid: 12627737].
234 Vallieres A, Morin C M. Actigraphy in the assessment of insomnia. Sleep. 2003;26(7):902-6. [pmid: 14655927].
235 Kushida C A, Chang A, Gadkary C, et al. Comparison of actigraphic, polysomnographic and subjective assessment of sleep parameters in sleep-disordered patients. Sleep Med. 2001;2(5):389-96. [pmid: 14592388].
236 Scholle S, Scholle H C, Kemper A, et al. First night effect in children and adolescents undergoing polysomnography for sleep-disordered breathing. Clin Neurophysiol. 2003;114(11):2138-45. [pmid: 14580612].
237 Le Bon O, Arpi S. Effect of the first sleep night in polysomnography: classification by variable sensitivity and factorial analysis of differences between nights. Rev Neurol. 2003;159(Suppl):6S42-7. [pmid: 14646799].
238 Gillette MU, Tischkau SA. Suprachiasmatic nucleus: the brain's circadian clock. Recent Prog Horm Res 1999; 54:33–58; 58–9.

### Included Studies

Aldous M, Franey C, Wright J, Arendt J. Plasma Concentrations of Melatonin in Man Following Oral Absorption of Different Preparations. Br J Clin Pharmacol. 1985;19:517-21. [pmid: 3994899]. [pmcid: 1463812].
Almeida Montes L G, Ontiveros Uribe M P, Cortes Sotres J, Heinze Martin G. Treatment of primary insomnia with melatonin: A double-blind, placebo-controlled, crossover study. J Psychiatry Neurosci. 2003;28(3):191-6. [pmid: 12790159]. [pmcid: 161743].
Ando K, Kripke D F, Cole R J, Elliott J A. Light mask 500 lux treatment for delayed sleep phase syndrome. Prog Neuro-Psychopharmacol Biol Psychiatry. 1999;23(1):15-24.
Andrade C, Srihari B S, Reddy K P, Chandramma L. Melatonin in medically ill patients with insomnia: a double-blind, placebo-controlled study. J Clin Psychiatry. 2001;62(1):41-5. [pmid: 11235927].
Arendt J, Borbely A A, Franey C, Wright J. The effects of chronic, small doses of melatonin given in the late afternoon on fatigue in man: a preliminary study. Neurosci Lett. 1984;45(3):317-21. [pmid: 6728321].
Arnulf I, Quintin P, Alvarez J C, Touitou Y, Derenne J P, Leboyer M. Mid-morning tryptophan depletion delays REM sleep onset in healthy subjects. Neuropsychopharmacol. 2001;23(5):843-51.
Attenburrow M E, Cowen P J, Sharpley A L. Low dose melatonin improves sleep in healthy middle-aged subjects. Psychopharmacol. 1996;126(2):179-81.
Baskett J J, Broad J B, Wood P C, et al. Does melatonin improve sleep in older people? A randomised crossover trial. Age Ageing. 2003;32(2):164-70. [pmid: 12615559].
Beaumont M, Batejat D, Pierard C, et al. Caffeine or melatonin effects on sleep and sleepiness after rapid eastward transmeridian travel. J Appl Physiol. 2004;96(1):50-8. [pmid: 12959951].
Benes L, Claustrat B, Horriere F, et al. Transmucosal, oral controlled-release, and transdermal drug administration in human subjects: a crossover study with melatonin. J Pharm Sci. 1997;86(10):1115-9. [pmid: 9344167].
Bougrine S, Mollard R, Ignazi G, Coblentz A. Appropriate use of bright light promotes a durable adaptation to night-shifts and accelerates readjustment during recovery after a period of night-shifts. Work Stress. 1995;9(23):314-26. [pmid: 11539393].
Boulos Z, Macchi M M, Sturchler M P, et al. Light visor treatment for jet lag after westward travel across six time zones. English. 2002;73:953-63.
Budnick L D, Lerman S E, Nicolich M J. An evaluation of scheduled bright light and darkness on rotating shiftworkers: trial and limitations. English. 1995;27:771-82.
Bunnell D E, Treiber S P, Phillips N H, Berger R J. Effects of evening bright light exposure on melatonin, body temperature and sleep. English. 1992;1:17-23. 1992163170).
Burgess H J, Sletten T, Savic N, Gilbert S S, Dawson D. Effects of bright light and melatonin on sleep propensity, temperature, and cardiac activity at night. English. 2001;91:1214-22.
Buxton O M, L'Hermite-Baleriaux M, Turek F W, van Cauter E. Daytime naps in darkness phase shift the human circadian rhythms of melatonin and thyrotropin secretion. English. 2000;278:R373-82.
Cagnacci A, Elliott J A, Yen S S. Melatonin: a major regulator of the circadian rhythm of core temperature in humans. English. 1992;75:447-52.
Cagnacci A, Soldani R, Laughlin G A, Yen S S. Modification of circadian body temperature rhythm during the luteal menstrual phase: role of melatonin. English. 1996;80:25-9.
Cagnacci A, Soldani R, Yen S S. The effect of light on core body temperature is mediated by melatonin in women. English. 1993;76:1036-8.
Cajochen C, Krauchi K, Danilenko K V, Wirz-Justice A. Evening administration of melatonin and bright light: interactions on the EEG during sleep and wakefulness. English. 1998;7:145-57.
Cajochen C, Krauchi K, Mori D, Graw P, Wirz-Justice A. Melatonin and S-20098 increase REM sleep and wake-up propensity without modifying NREM sleep homeostasis. English. 1997;272:R1189-96.
Cajochen C, Zeitzer J M, Czeisler C A, Dijk D J. Investigator: Czeisler CA, Dijk DJ. Dose-response relationship for light intensity and ocular and electroencephalographic correlates of human alertness. English. 2000;115:75-83.
Camfield P, Gordon K, Dooley J, Camfield C. Melatonin appears ineffective in children with intellectual deficits and fragmented sleep: six “N of 1” trials [comment]. English. 1996;11:341-3.
Cavallo A, Ritschel W A. Pharmacokinetics of melatonin in human sexual maturation. English. 1996;81:1882-6.
Claustrat B, Brun J, David M, Sassolas G, Chazot G. Melatonin and jet lag: confirmatory result using a simplified protocol [comment]. English. 1992;32:705-11.
Cole R J, Smith J S, Alcala Y C, Elliott J A, Kripke D F. Bright-light mask treatment of delayed sleep phase syndrome. English. 2002;17:89-101.
Costa G, Kovacic M, Bertoldi A, Minors D, Waterhouse J. The use of a light visor during night work by nurses. English. 1997;28:16-25. 1997132808).
Dahlitz M, Alvarez B, Vignau J, English J, Arendt J, Parkes J D. Delayed sleep phase syndrome response to melatonin. English. 1991;337:1121-4.
Danilenko K V, Cajochen C, Wirz-Justice A. Is sleep per se a zeitgeber in humans?. English. 2003;18:170-8.
Danilenko K V, Wirz-Justice A, Krauchi K, Weber J M, Terman M. The human circadian pacemaker can see by the dawn's early light. English. 2000;15:437-46.
Daurat A, Aguirre A, Foret J, Benoit O. Disruption of sleep recovery after 36 hours of exposure to moderately bright light. English. 1997;20:352-8.
Daurat A, Foret J, Touitou Y, Benoit O. Detrimental influence of bright light exposure on alertness, performance, and mood in the early morning. English. 1996;26:8-14.
Dawson D, Gibbon S, Singh P. The hypothermic effect of melatonin on core body temperature: is more better?. English. 1996;20:192-7.
Dawson D, Rogers N L, van den Heuvel C J, Kennaway D J, Lushington K. Effect of sustained nocturnal transbuccal melatonin administration on sleep and temperature in elderly insomniacs. English. 1998;13:532-8.
Deacon S, Arendt J. Melatonin-induced temperature suppression and its acute phase-shifting effects correlate in a dose-dependent manner in humans. English. 1995;688:77-85.
Debus O M, Lerchl A, Bothe H W, et al. Spontaneous central melatonin secretion and resorption kinetics of exogenous melatonin: a ventricular CSF study. English. 2002;33:213-7.
Di W-D, Kavda A, Johnston A, Silman R. Variable bioavailability of oral melatonin. 336. 1997:1028–129.
Dijk D J, Beersma D G M, Daan S, Lewy A J. Bright morning light advances the human circadian system without affecting NREM sleep homeostasis. Am J Physiol - Reg Integr Comparative Physiol. 1989;256(1):25-1.
Dodge N N, Wilson G A. Melatonin for treatment of sleep disorders in children with developmental disabilities. English. 2001;16:581-4.
Dollins A B, Lynch H J, Wurtman R J, et al. Effect of pharmacological daytime doses of melatonin on human mood and performance. English. 1993;112:490-6.
Dollins A B, Zhdanova I V, Wurtman R J, Lynch H J, Deng M H. Investigator: Wurtman RJ. Effect of inducing nocturnal serum melatonin concentrations in daytime on sleep, mood, body temperature, and performance. English. 1994;91:1824-8.
Dollins AB, Lynch HJ, Wurtman RJ, Deng MH, Lieberman HR. Effects of illumination on human nocturnal serum melatonin levels and performance. 53. 1993:153–60. CN-00392108; EMBASE 1993026694).
Eastman C I, Martin S K, Hebert M. Failure of extraocular light to facilitate circadian rhythm reentrainment in humans. English. 2000;17:807-26.
Ecker A J, Schaechter J, Price N J, et al. Changes in plasma melatonin secretion following chronic sleep restriction. Sleep. 2000;23(Abstract Supplement 2):A184-5.
Edwards B J, Atkinson G, Waterhouse J, Reilly T, Godfrey R, Budgett R. Use of melatonin in recovery from jet-lag following an eastward flight across 10 time-zones. English. 2000;43:1501-13.
Ellis C M, Lemmens G, Parkes J D. Melatonin and insomnia. English. 1996;5:61-5.
Ferini-Strambi L, Zucconi M, Biella G, et al. Effect of melatonin on sleep microstructure: preliminary results in healthy subjects. English. 1993;16:744-7.
Fletcher A, Van den Heuvel C, Dawson D. Sleeping with an electric blanket: Effects on core temperature, sleep, and melatonin in young adults. English. 1999;22:313-8. 1999174642).
Folkard S, Arendt J, Clark M. Can melatonin improve shift workers' tolerance of the night shift? Some preliminary findings. English. 1993;10:315-20.
Fraschini F, Cesarani A, Alpini D, Esposti D, Stankov B M. Melatonin Influences Human Balance. English. 1999;8:111-9.
Garfinkel D, Laudon M, Nof D, Zisapel N. Improvement of sleep quality in elderly people by controlled-release melatonin. 346. 1995:541–4. CN-00170338. EMBASE 1995261201.
Goh V H, Tong T Y, Lim C L, Low E C, Lee L K. Effects of one night of sleep deprivation on hormone profiles and performance efficiency. English. 2001;166:427-31.
Goichot B, Weibel L, Chapotot F, Gronfier C, Piquard F, Brandenberger G. Effect of the shift of the sleep-wake cycle on three robust endocrine markers of the circadian clock. English. 1998;275:E243-8.
Gordijn M C, Beersma D G, Korte H J, van den Hoofdakker R H. Effects of light exposure and sleep displacement on dim light melatonin onset. English. 1999;8:163-74.
Gordijn M C, Beersma D G, Korte H J, Van den Hoofdakker R H. Testing the hypothesis of a circadian phase disturbance underlying depressive mood in nonseasonal depression. English. 1998;13:132-47.
Haimov I, Lavie P, Laudon M, Herer P, Vigder C, Zisapel N. Melatonin replacement therapy of elderly insomniacs. English. 1995;18:598-603.
Helrich E, Neef C, Merkus FWWM. Population pharmacokinetics of intranasally administered low dose melatonin. 53. 2002:543–4.
Higuchi S, Motohashi Y, Liu Y, Ahara M, Kaneko Y. Effects of VDT tasks with a bright display at night on melatonin, core temperature, heart rate, and sleepiness. English. 2003;94:1773-6.
Hoffmann H, Dittgen M, Hoffmann A, et al. Evaluation of an oral pulsatile delivery system for melatonin in humans. English. 1998;53:462-6.
Holmes A L, Gilbert S S, Dawson D. Melatonin and zopiclone: the relationship between sleep propensity and body temperature. English. 2002;25:301-6.
Hood E, Buttross S, Parks B. A placebo-controlled, double-blind, crossover trial of melatonin in the management of sleep disturbances in children with behavioral disorders. English. 1999;47:114.
Horne J A, Donlon J, Arendt J. Green light attenuates melatonin output and sleepiness during sleep deprivation. English. 1991;14:233-40.
Horowitz T S, Cade B E, Wolfe J M, Czeisler C A. Efficacy of bright light and sleep/darkness scheduling in alleviating circadian maladaptation to night work. English. 2001;281:E384-91.
James M, Tremea M O, Jones J S, Krohmer J R. Can melatonin improve adaptation to night shift?. English. 1998;16:367-70.
James S P, Mendelson W B, Sack D A, Rosenthal N E, Wehr T A. The effect of melatonin on normal sleep. English. 1987;1:41-4.
James S P, Sack D A, Rosenthal N E, Mendelson W B. Melatonin administration in insomnia. English. 1990;3:19-23.
Jan J E, Espezel H, Appleton R E. The treatment of sleep disorders with melatonin [comment]. English. 1994;36:97-107.
Jean-Louis G, von Gizycki H, Zizi F. Melatonin effects on sleep, mood, and cognition in elderly with mild cognitive impairment. English. 1998;25:177-83.
Jelinkova-Vondrasova D, Hajek I, Illnerova H. Adjustment of the human circadian system to changes of the sleep schedule under dim light at home. English. 1999;265:111-4.
Jimerson D C, Lynch H J, Post R M, Wurtman R J, Bunney W E Jr. Urinary melatonin rhythms during sleep deprivation in depressed patients and normals. English. 1977;20:1501-8.
Jockovich M, Cosentino D, Cosentino L, Wears R L, Seaberg D C. Effect of exogenous melatonin on mood and sleep efficiency in emergency medicine residents working night shifts. English. 2000;7:955-8.
Jorgensen K M, Witting M D. Does exogenous melatonin improve day sleep or night alertness in emergency physicians working night shifts?. English. 1998;31:699-704.
Kane M A, Johnson A, Nash A E, et al. Serum melatonin levels in melanoma patients after repeated oral administration. English. 1994;4:59-65.
Kayumov L, Brown G, Jindal R, Buttoo K, Shapiro C M. A randomized, double-blind, placebo-controlled crossover study of the effect of exogenous melatonin on delayed sleep phase syndrome. English. 2001;63:40-8.
Kelly T L, Kripke D F, Hayduk R, Ryman D, Pasche B, Barbault A. Bright light and LEET effects on circadian rhythms, sleep and cognitive performance. English. 1997;13:251-8.
Koorengevel K M, Gordijn M C, Beersma D G, et al. Extraocular light therapy in winter depression: a double-blind placebo-controlled study [erratum appears in Biol Psychiatry 2002 Jan 15;51(2):194]. English. 2001;50:691-8.
Kovacs J, Brodner W, Kirchlechner V, Arif T, Waldhauser F. Measurement of urinary melatonin: a useful tool for monitoring serum melatonin after its oral administration. English. 2000;85:666-70.
Kubota T, Uchiyama M, Suzuki H, et al. Effects of nocturnal bright light on saliva melatonin, core body temperature and sleep propensity rhythms in human subjects. English. 2002;42:115-22.
Lavoie S, Paquet J, Selmaoui B, Rufiange M, Dumont M. Vigilance levels during and after bright light exposure in the first half of the night. Chronobiol Int. 2003;20(6):1019-38. [pmid: 14680141].
Lee B, Ryu S, Choi H, et al. Batch variation and pharmacokinetics of oral sustained release melatonin-loaded sugar spheres in human subjects. Arch Pharmacal Res. 1997;20(6):555-9.
Lewy A J, Bauer V K, Ahmed S, et al. The human phase response curve (PRC) to melatonin is about 12 hours out of phase with the PRC to light. English. 1998;15:71-83.
Luboshitzky R, Levi M, Shen-Orr Z, Blumenfeld Z, Herer P, Lavie P. Long-term melatonin administration does not alter pituitary-gonadal hormone secretion in normal men. English. 2000;15:60-5.
Lushington K, Galka R, Sassi L N, Kennaway D J, Dawson D. Extraocular light exposure does not phase shift saliva melatonin rhythms in sleeping subjects. English. 2002;17:377-86.
MacFarlane J G, Cleghorn J M, Brown G M, Streiner D L. The effects of exogenous melatonin on the total sleep time and daytime alertness of chronic insomniacs: a preliminary study. English. 1991;30:371-6.
Matsumoto M. The hypnotic effects of melatonin treatment on diurnal sleep in humans. English. 1999;53:243-5.
McArthur A J, Budden S S. Sleep dysfunction in Rett syndrome: a trial of exogenous melatonin treatment. English. 1998;40:186-92.
Mishima K, Satoh K, Shimizu T, Hishikawa Y. Hypnotic and hypothermic action of daytime-administered melatonin. English. 1997;133:168-71.
Monti J M, Alvarino F, Cardinali D, Savio I, Pintos A. Polysomnographic study of the effect of melatonin on sleep in elderly patients with chronic primary insomnia. English. 1999;28:85-98. 1999095367).
Morita T, Tokura H. Effects of lights of different color temperature on the nocturnal changes in core temperature and melatonin in humans. English. 1996;15:243-6.
Morris M, Lack L, Barrett J. The effect of sleep/wake state on nocturnal melatonin excretion. English. 1990;9:133-8. 1991006017).
Naguib M, Samarkandi A H. Premedication With Melatonin: a Double-Blind, Placebo-Controlled Comparison With Midazolam. English. 1999;82:875-80.
Nave R, Peled R, Lavie P. Melatonin improves evening napping. English. 1995;275:213-6.
Nickelsen T, Demisch L, Demisch K, Radermacher B, Schoffling K. Influence of subchronic intake of melatonin at various times of the day on fatigue and hormonal levels: a placebo-controlled, double-blind trial. English. 1989;6:325-34.
Niederhofer H, Staffen W, Mair A, Pittschieler K. Brief report: melatonin facilitates sleep in individuals with mental retardation and insomnia. J Autism Dev Disord. 2003;33(4):469-72. [pmid: 12959427].
O'Callaghan F J K, Clarke A A, Hancock E, Hunt A, Osborne J P. Use of Melatonin to Treat Sleep Disorders in Tuberous Sclerosis. English. 1999;41:123-6.
Paccotti P, Terzolo M, Torta M, et al. Acute administration of melatonin at two opposite circadian stages does not change responses to gonadotropin releasing hormone, thyrotropin releasing hormone and ACTH in healthy adult males. English. 1987;10:471-7.
Partonen T, Vakkuri O, Lamberg-Allardt C, Lonnqvist J. Effects of bright light on sleepiness, melatonin, and 25-hydroxyvitamin D(3) in winter seasonal affective disorder. English. 1996;39:865-72.
Petrie K, Conaglen J V, Thompson L, Chamberlain K. Effect of melatonin on jet lag after long haul flights. English. 1989;298:705-7.
Petrie K, Dawson A G, Thompson L, Brook R. A double-blind trial of melatonin as a treatment for jet lag in international cabin crew. English. 1993;33:526-30.
Pires M L, Benedito-Silva A A, Pinto L, Souza L, Vismari L, Calil H M. Acute effects of low doses of melatonin on the sleep of young healthy subjects. English. 2001;31:326-32.
Rajaratnam S M, Dijk D J, Middleton B, Stone B, Arendt J. Melatonin phase-shifts human circadian rhythms with no evidence of changes in the duration of endogenous melatonin secretion or the 24-hour production of reproductive hormones. J Clin Endocrinol Metab. 2002;88(9):4303-9.
Rao M L, Pelzer E, Papassotiropoulos A, Tiemeier H, Jonck L, Moller H J. Selective slow-wave sleep deprivation influences blood serotonin profiles and serum melatonin concentrations in healthy subjects. English. 1996;40:664-7.
Redwine L, Hauger R L, Gillin J C, Irwin M. Effects of sleep and sleep deprivation on interleukin-6, growth hormone, cortisol, and melatonin levels in humans. English. 2000;85:3597-603.
Reid K, Van den Heuvel C, Dawson D. Day-time melatonin administration: effects on core temperature and sleep onset latency. English. 1996;5:150-4.
Ross J K, Arendt J, Horne J, Haston W. Night-shift work in Antarctica: sleep characteristics and bright light treatment. English. 1995;57:1169-74.
Salin-Pascual R J, Ortega-Soto H, Huerto-Delgadillo L, Camacho-Arroyo I, Roldan-Roldan G, Tamarkin L. The effect of total sleep deprivation on plasma melatonin and cortisol in healthy human volunteers. English. 1988;11:362-9.
Samel A, Wegmann H M, Vejvoda M. Pre-adaptation to shiftwork in space. English. 1993;29:593-9.
Satomura T, Sakamoto T, Shirakawa S, et al. Hypnotic action of melatonin during daytime administration and its comparison with triazolam. English. 2001;55:303-4.
Seabra M L, Bignotto M, Pinto L R Jr, Tufik S. Randomized, double-blind clinical trial, controlled with placebo, of the toxicology of chronic melatonin treatment. English. 2000;29:193-200.
Serfaty M, Kennell-Webb S, Warner J, Blizard R, Raven P. Double blind randomised placebo controlled trial of low dose melatonin for sleep disorders in dementia. English. 2002;17:1120-7.
Serfaty M A, Osborne D, Buszewicz M J, Raven P W. The effect of exogeneous melatonin in major depression. Chronobiol Int. 2003;20:1191-2.
Shah J, Langmuir V, Gupta S K. Feasibility and functionality of OROS melatonin in healthy subjects. English. 1999;39:606-12.
Shamir E, Barak Y, Plopsky I, Zisapel N, Elizur A, Weizman A. Is melatonin treatment effective for tardive dyskinesia?. J Clin Psychiatry. 2000;61(8):556-8. [pmid: 10982197].
Shamir E, Barak Y, Shalman I, et al. Melatonin treatment for tardive dyskinesia: a double-blind, placebo-controlled, crossover study. Arch Gen Psychiatry. 2001;58(11):1049-52. [pmid: 11695951].
Shamir E, Laudon M, Barak Y, et al. Melatonin improves sleep quality of patients with chronic schizophrenia. English. 2000;61:373-7.
Shamir E, Rotenberg V S, Laudon M, Zisapel N, Elizur A. First-night effect of melatonin treatment in patients with chronic schizophrenia. English. 2000;20:691-4.
Shirakawa S-I, Sakamoto T, Uchimura N, Tsutsumi Y, Tanaka J, Maeda H. Effect of melatonin on sleep and rectal temperature of young healthy evening types. English. 2001;55:301-2. 2001225764).
Shirakawa S-I, Tsuchiya S, Tsutsumi Y, Kotorii T. Time course of saliva and serum melatonin levels after ingestion of melatonin. Psychiatry Clin Neurosci. 1998;52(2):266-7. [pmid: 9628188].
Singer C, Tractenberg R E, Kaye J, et al. A multicenter, placebo-controlled trial of melatonin for sleep disturbance in Alzheimer's disease. Sleep. 2003;26(7):893-901. [pmid: 14655926].
Smits M G, Van Stel H F, Van Der Heijden K, Meijer A M, Coenen A M, Kerkhof G A. Melatonin improves health status and sleep in children with idiopathic chronic sleep-onset insomnia: A randomized lacebo-controlled trial. J Am Acad Child Adolesc Psychiatry. 2003;42(11):1286-93. [pmid: 14566165].
Strassman R J, Qualls C R, Lisansky E J, Peake G T. Elevated rectal temperature produced by all-night bright light is reversed by melatonin infusion in men. English. 1991;71:2178-82.
Suhner A, Schlagenhauf P, Hofer I, Johnson R, Tschopp A, Steffen R. Effectiveness and tolerability of melatonin and zolpidem for the alleviation of jet lag. English. 2001;72:638-46.
Suhner A, Schlagenhauf P, Johnson R, Tschopp A, Steffen R. Comparative study to determine the optimal melatonin dosage form for the alleviation of jet lag. English. 1998;15:655-66.
Terlo L, Laudon M, Tarasch R, Schatz T, Caine Y G, Zisapel N. Effects of low doses of melatonin on late afternoon napping and mood. English. 1997;28:2-15. 1997132807).
Van Den Heuvel C J, Kennaway D J, Dawson D. Thermoregulatory and soporific effects of very low dose melatonin injection. English. 1999;276:E249-E254. 1999078469).
Van Wieringen S, Jansen T, Smits M G, Nagtegaal J E, Coenen A M L. Melatonin for chronic whiplash syndrome with delayed melatonin onset: Randomised, placebo-controlled trial. English. 2001;21:813-20. 2002032315).
von Treuer K, Norman T R, Armstrong S M. Overnight human plasma melatonin, cortisol, prolactin, TSH, under conditions of normal sleep, sleep deprivation, and sleep recovery. English. 1996;20:7-14.
Wakamura T, Tokura H. The influence of bright light during the daytime upon circadian rhythm of core temperature and its implications for nocturnal sleep. English. 2000;2:41-9.
Waldhauser F, Saletu B, Trinchard-Lugan I. Sleep laboratory investigations on hypnotic properties of melatonin. English. 1990;100:222-6.
Wehr T A. The durations of human melatonin secretion and sleep respond to changes in daylength (photoperiod). English. 1991;73:1276-80.
Weibel L, Spiegel K, Gronfier C, Follenius M, Brandenberger G. Twenty-four-hour melatonin and core body temperature rhythms: Their adaptation in night workers. English. 1997;272:R948-R954. 1997102315).
Wright J, Aldhous M, Franey C, English J, Arendt J. The effects of exogenous melatonin on endocrine function in man. English. 1986;24:375-82.
Wright K J, Badia P, Myers B L, Plenzler S C, Hakel M. Caffeine and light effects on nighttime melatonin and temperature levels in sleep-deprived humans. Brain Res. 1997;747(1):78-84. [pmid: 9042530].
Wright S W, Lawrence L M, Wrenn K D, Haynes M L, Welch L W, Schlack H M. Randomized clinical trial of melatonin after night-shift work: efficacy and neuropsychologic effects [comment]. English. 1998;32:334-40.
Yoon I, Jeong D, Kwon K, Kang S. Homeostatic and circadian factors in improving adaptation of rapidly rotating night shift workers. Sleep. 2000;23(Abstract Supplement 2):A186.
Zhdanova I V, Wurtman R J, Lynch H J, et al. Sleep-inducing effects of low doses of melatonin ingested in the evening. English. 1995;57:552-8.
Zhdanova I V, Wurtman R J, Morabito C, Piotrovska V R, Lynch H J. Effects of low oral doses of melatonin, given 2–4 hours before habitual bedtime, on sleep in normal young humans. English. 1996;19:423-31.
Zhdanova I V, Wurtman R J, Regan M M, Taylor J A, Shi J P, Leclair O U. Melatonin treatment for age-related insomnia. English. 2001;86:4727-30.
Zisapel N, Tarash R, Laudon M. Effects of fast- and controlled-release melatonin formulations on daytime sleep and mood. Pineal update; from molecular mechanisms to clinical implications. 1997: 355–60.