# Acknowledgments

We are grateful to members of the technical expert panel for providing input on the direction and scope of the review. We thank Dr. Richard Nahin, Dr. Nancy Pearson and the National Center for Complementary and Alternative Medicine, National Institutes of Health, as well as Ms. Margaret Coopey and the Agency for Healthcare Research and Quality for insight and recommendations. We are also grateful to Ms. Michelle Tubman, Dr. Mia Lang, Ms. Maria Ospina, Mr. Victor Juorio and Ms. Ellen Crumley for their contribution to the systematic review process.

Investigating authors acknowledge the following financial support: Dr. Sunita Vohra is supported by: Agency for Healthcare Research and Quality (USA); Canadian Institutes of Health Research; Change Foundation; Department of Pediatrics, Stollery Children's Hospital; Natural Health Products Directorate, Health Canada; Ontario Mental Health Foundation; Stollery Children's Hospital Foundation; The Hospital for Sick Children Foundation; and the University of Alberta. Dr. Glen Baker is supported by Canadian Institutes of Health Research, Canada Research Chairs Program and Zyprexa Research Foundation.