# Discussion

## Key Observations of the Literature Review

### Effectiveness of Exogenous Melatonin in Normal Sleepers

#### Normal Sleepers

- Melatonin [underlined: decreased sleep onset latency (SOL)] in normal sleepers (weighted mean difference (WMD): -3.9 min; 95 percent confidence interval (CI): -5.3 min., -2.6 min.). The magnitude of this effect appears to be clinically insignificant. The moderate heterogeneity across studies may be partially explained by differences in the timing and duration of melatonin administration, the method of measurement of sleep outcomes and the overall quality of studies. There was evidence of possible publication bias in the selection of studies that were analyzed; we found a greater number of studies reporting positive results compared to negative results.
- Melatonin [underlined: increased sleep efficiency] in normal sleepers (WMD: 2.3 percent; 95 percent CI: 0.7 percent, 3.9 percent), and this effect was dependent on the timing of sleep, such that the effect of melatonin was greater in daytime sleepers (daytime sleep: WMD: 8.0 percent; 95 percent CI: 1.0 percent, 15.0 percent; night-time sleep: WMD: 1.2 percent; 95 percent CI: 0 percent, 2.4 percent). The magnitude of this effect appears to be clinically insignificant. The substantial heterogeneity across studies analyzed for this outcome may be partially explained by differences in the timing of melatonin administration. There was considerable evidence of possible publication bias in the selection of studies analyzed; we found a greater number of studies reporting positive results compared to negative results.
- Overall, melatonin [underlined: did not] [underlined: have an effect on REM latency] in normal sleepers, although doses of 1mg to 3 mg produced a significant increase in REM latency compared to placebo (WMD: 12.7 min.; 95 percent CI: 6.8 min., 18.6 min.), while both higher and lower doses did not show this effect. The substantial heterogeneity in results across studies may be partially explained by differences in the gender of the population and the duration of melatonin administration.
- Generally, these studies were of low to moderate quality.

### Effectiveness of Exogenous Melatonin in People with Sleep Disorders

#### People with a Primary Sleep Disorder

- Melatonin [underlined: decreased sleep onset latency] in people with a primary sleep disorder (WMD: -10.7 min.; 95 percent CI: -17.6 min., -3.7 min.). SOL was decreased greatly in people with delayed sleep phase syndrome (WMD: -38.8 min.; 95 percent CI: -50.3 min., -27.3 min.). The magnitude of this effect appears to be clinically significant. SOL was decreased marginally in patients with insomnia (WMD: -4.3min.; 95 percent CI: - 8.4 min., -0.1 min.). The magnitude of this effect appears to be clinically insignificant. SOL was reduced more in children (less than 17 years) (WMD: -17.0 min., 95 percent CI: -33.5 min, -0.5 min.) than in adults (18–65 years) (WMD: -11.2; 95 percent CI: -27.7 min, 5.4 min.) or elderly patients (greater than 65 years) (WMD: -7.8 min.; 95 percent CI: -17.4 min., 1.7 min.). The effects of melatonin did not vary with dose or duration of treatment. The substantial heterogeneity across studies may be partially explained by differences in the age of the population, their primary diagnosis, study design, the method of measurement of sleep outcomes and whether allocation of participants to interventions was concealed. If the analysis is approached using the Fixed Effects Model, melatonin does not have any effect on sleep onset latency in people with primary insomnia.
- Melatonin [underlined: did not] [underlined: have an effect on sleep efficiency] in people with primary sleep disorders; the effects of melatonin did not vary by age, type of primary sleep disorder, dose or duration of treatment. The substantial heterogeneity in the results across studies may be partially explained by the age of the population and whether allocation of participants to interventions was concealed.
- Melatonin did not have an effect on sleep quality, wakefulness after sleep onset (WASO), total sleep time, or percent time spent in REM sleep
- Generally, these studies were of moderate to high quality.

#### People with a Secondary Sleep Disorder

- Melatonin [underlined: did not] [underlined: have an effect on sleep onset latency] in people with a secondary sleep disorder; the effects of melatonin did not differ between children and adults; the effect of melatonin did not vary with dose or duration of treatment. The substantial heterogeneity across studies may be partially explained by the age of the population, the duration of melatonin administration, the method of measurement of sleep outcomes and whether allocation of participants to interventions was concealed.
- Melatonin [underlined: increased sleep efficiency] in people with a secondary sleep disorder (WMD: 1.9 percent; 95 percent CI: 0.5 percent, 3.3 percent); the effect of melatonin did not vary by age, dose or duration of treatment. The magnitude of this effect appears to be clinically insignificant.
- Melatonin did not have an effect on WASO or percent time spent in REM sleep in people with a secondary sleep disorder, but increased total sleep time in this population
- Generally, these studies were of moderate to high quality.

#### People Suffering from Sleep Restriction

- Melatonin [underlined: did not] [underlined: have an effect on sleep onset latency] in people suffering from sleep restriction; the effect of melatonin did not vary by dose or type of sleep restriction disorder i.e. shift-work and jet lag
- Melatonin [underlined: did not] [underlined: have an effect on sleep efficiency] in people suffering from sleep restriction; the effect of melatonin did not vary by dose
- Melatonin did not have an effect on sleep quality, WASO and percent time spent in REM sleep in people suffering from sleep restriction, but significantly increased total sleep time in this population
- Generally, these studies were of moderate to high quality.

See Table 28 for a summary of the evidence surrounding the effect of melatonin on sleep in various populations.

Table 28. Summary of the Evidence Surrounding the Effect of Melatonin on Sleep in Various Populations

| Normal Sleepers | Primary Sleep Disorder | Secondary Sleep Disorder | Sleep Restriction
Sleep Onset Latency | Decreased | Decreased | No Effect | No Effect
| WMD: -3.9 min; 95 percent CI: -5.3 min., -2.6 min. | WMD: -10.7 min.; 95 percent CI: -17.6 min., -3.7 min.
| N=20 | N=12 | N=6 | N=9
Sleep Efficiency | Increased | No Effect | Increased | No Effect
| WMD: 2.3 percent; 95 percent CI: 0.7 percent, 3.9 percent | N=9 | WMD: 1.9 percent; 95 percent CI: 0.5 percent, 3.3 percent | N=5
| N=13 | | N=6

Abbreviations: WMD: weighted mean difference, CI: confidence interval

### Safety of Exogenous Melatonin

- The most commonly reported adverse effects of melatonin were nausea (incidence: ~ 1.5 percent), headache (incidence: ~ 7.8 percent), dizziness (incidence: 4.0 percent) and drowsiness (incidence: 20.33 percent); however, these effects were not significant compared to placebo. This result did not change by dose, the presence or absence of a sleep disorder, type of sleep disorder, duration of treatment, gender, age, formulation of melatonin, use of concurrent medication, study design, quality score and allocation concealment score.
- Generally, these studies were of moderate to high quality.

### Formulations, Pharmacology, and Mechanisms of Action of Exogenous Melatonin

- A number of different formulations of melatonin have been used in clinical trials on humans; it is unclear how these formulations are different in terms of content, quality and effectiveness in treating sleep disorders
- The half-life of melatonin ranged from 0.54h to 2h. The peak circulating concentration of melatonin ranged from 14.75pg/ml to 64 730 pg/ml, reflecting a dose range of 0.003mg to 75mg. The time required to reach peak values ranged from 0.25h to 13h. There is evidence from one study that exogenous melatonin penetrates the blood-brain-barrier
- The basic mechanism by which melatonin produces sleepiness in humans is unclear, although three main hypothesis have been proposed; the mechanism may involve a phase-shift of the endogenous circadian pacemaker, a reduction in core body temperature and/or a direct action on somnogenic structures of the brain

### Melatonin and other Pharmacological Treatments for Sleep Disorders

- There are no differences in the effects of melatonin and triazolam on normal sleepers; zopiclone reduced SOL to a greater extent than melatonin during particular periods of investigation of normal sleepers in one study; there were no differences in the effect of melatonin and zolpidem on alleviation of jet lag in one study; however, there were more reports of adverse effects with zolpidem than with melatonin.

### Endogenous Melatonin and Sleep and Temperature Rhythms

- There is evidence linking endogenous melatonin to the sleep cycle; manipulation of endogenous melatonin was often accompanied by changes in the sleep cycle and vice versa; an analysis of the correlation between changes in the two variables was often not conducted, and in cases where it was conducted, the results were mixed.
- There is evidence linking endogenous melatonin to the temperature rhythm; manipulation of endogenous melatonin was often accompanied by changes in the temperature rhythm; manipulation of the temperature rhythm was accompanied by changes in endogenous melatonin in one out of two studies; an analysis of the correlation between changes in the two variables was often not conducted, and in cases where it was conducted, the results were mixed.

## Discussion of Key Observations of this Review

### Effectiveness of Melatonin in Normal Sleepers

One cannot draw strong conclusions regarding the effect of melatonin on the sleep cycle of normal sleepers due to the heterogeneity in results of studies relevant to this topic, evidence of possible publication bias in this selection of studies, and the relatively low quality of these studies. The results of this review suggest that the heterogeneity across studies may partially be due to details of the intervention, such as the timing and duration of melatonin administration, as well as the method of measurement of sleep outcomes, the gender of the population and the overall quality of studies. Indeed, the timing of melatonin administration has been shown to predict its effect on circadian rhythms, such that melatonin delays circadian rhythms following morning administration and advances circadian rhythms following afternoon or early evening administration.^231^ In addition to timing of melatonin administration, the results of studies may be affected by the particular method used to assess sleep outcomes. The studies employed either polysomnography, actigraphy or questionnaires/sleep diaries. Indeed, many studies have found a discrepancy in the results obtained by actigraphy and/or sleep diaries compared to polysomnography. There is evidence that actigraphy overestimates sleep parameters such as sleep onset latency and sleep efficiency,^232^ ^233^ however, there is other evidence that actigraphy and sleep diaries underestimate sleep efficiency and total sleep time.^234^ Kushida et al. (2001)^235^ have not found a difference in sleep efficiency and total sleep time by the three methods. A “first night effect” has been described with the use of polysomnography to measure sleep outcomes in children^236^ and adults,^237^ whereby laboratory conditions tend to result in more awakenings and less REM sleep during the first night of recording compared to subsequent nights. Such an effect would tend to underestimate the effect of melatonin on sleep, but could be bypassed by longer study duration.

Our literature review indicated that melatonin decreased sleep onset latency and increased sleep efficiency in normal sleepers and that the effect on sleep efficiency, but not on sleep onset latency, was more pronounced in normal sleepers that were given melatonin and tested during the day versus those that were given melatonin and tested during the night. These results may reflect differences in the conditions of studies involving daytime sleep versus night time sleep. For example, many of the studies involving daytime sleep used the Multiple Sleep Onset Latency Test (MSLT) to assess sleep onset latency, and sleep opportunities were relatively short compared to those for night-time sleepers. Thus, the increased sleep efficiency in normal sleepers tested during the daytime compared to the night-time could simply reflect shorter sleep opportunities. However, the possibility exists that melatonin is more effective in maintaining daytime sleep compared to night-time sleep in normal sleepers. The finding that melatonin significantly increased REM latency only when administered at doses between 1 and 3mg, and not at lower or higher doses, may indicate that melatonin modulates sleep architecture in normal sleepers in a dose-dependent manner. However, given that melatonin did not have any overall effect on sleep efficiency in this population, further research into the pharmacodynamics of melatonin in terms of its effect on REM latency in normal sleepers is required to confirm the possible dose-dependency of this effect.

### Effectiveness of Melatonin in the People with Primary Sleep Disorders

Our literature review indicated that melatonin reduced sleep onset latency to a greater extent in people with delayed sleep phase syndrome than in people with insomnia. This finding may indicate that the effects of melatonin on people with primary sleep disorders are mediated by a direct re-setting of the endogenous circadian pacemaker rather than via a direct action on somnogenic structures of the brain, given that individuals with delayed sleep phase syndrome are distinguished from individuals with insomnia by the presence of a circadian abnormality. It is also possible that melatonin may initially act on somnogenic structures of the brain to promote sleep; the reduction in sleep onset latency would decrease evening light exposure, which would in turn promote a phase-advance of the endogenous melatonin rhythm and a re-setting of the endogenous clock. That is, the reduction in sleep onset latency would decrease exposure to evening light, which normally delays the pacemaker,^12^ such that individuals would only receive phase-advancing morning light,^12^ advancing the rhythm of endogenous melatonin and alleviating the sleep disorder. The finding that the effect of melatonin on sleep onset latency in people with primary sleep disorders was greater for children than adults or the elderly was based on only one study involving children,^59^ and the effect of melatonin on sleep efficiency in people with secondary sleep disorders did not vary with age. Thus, one cannot draw a firm conclusion on the effect of age on the effectiveness of melatonin in people with primary sleep disorders, and further research in this area is required. Our literature survey indicates that there is no evidence to suggest that the effect of melatonin on sleep onset latency in people with primary sleep disorders and on sleep efficiency in people with secondary sleep disorders is dependent on dose or duration of melatonin administration. Similarly, we found no evidence to suggest that the effect of melatonin on sleep onset latency and sleep efficiency in normal sleepers is dose dependent. These findings appear to contrast with the finding that the effect of melatonin on REM latency in normal sleepers is dose-dependent. It appears that research into the pharmacodynamics of melatonin with respect to the dose-dependence of the effect of melatonin on various sleep parameters is required. The finding that melatonin had an effect on sleep onset latency, but not on sleep efficiency, in people with primary sleep disorders supports the hypothesis that melatonin exerts its effects on this population by acting as a phase-re-setter rather than as a hypnotic.

It is noteworthy that the observations of this review regarding the effects of melatonin on people with primary sleep disorders are based on studies with relatively short trial durations of four weeks or less. Therefore, the effects of melatonin on sleep onset latency and sleep efficiency reported here may reflect only the short-term effects of melatonin on this population. It is necessary that trials of longer duration be conducted in order to determine the long-term effects of melatonin on this population.

Interestingly, the authors did not come across studies involving the use of melatonin in people with sleep apnoea, a type of sleep disorder. The search strategies employed in this review would have captured such studies, which suggests that research in this area is lacking. Nonetheless, it is important to consider that the effects of melatonin reported herein may not be applicable to people with sleep apnoea, and research into the area of melatonin and sleep apnoea is necessary in order to understand the effects of exogenous melatonin on this population.

The authors noted the working definitions of sleep onset latency in the studies included in the review. For studies employing sleep diary, questionnaire or actigraphy in the measurement of SOL, and for which a definition of SOL was provided in the report, this outcome was defined in a similar manner across studies. By contrast, for studies employing polysomnography in the measurement of SOL, and for which a definition of SOL was provided in the report, this outcome was defined slightly differently across studies. In the current review, a subgroup analysis was conducted based on the method of measurement of sleep outcomes. This analysis allowed us to examine whether the differences in the working definitions of SOL among studies employing sleep diary/questionnaire, compared to studies employing polysomnography, for measurement of sleep outcomes, could potentially yield differences in the observed effect of melatonin on SOL. However, the subtle differences in the working definitions of SOL in studies employing polysomnography precluded us from performing a subgroup analysis based on working definition within this group of studies, since individual subgroups of this analysis would be based on only one study in most cases and would not provide meaningful results. Future research in the area of melatonin and sleep disorders requires that working definitions of primary outcomes be clearly defined such that appropriate comparisons across studies can be made.

### Effectiveness of Melatonin in People with Secondary Sleep Disorders

The summary estimate of the effect of melatonin on sleep onset latency in people with secondary sleep disorders is markedly changed by the results of a study by Shamir et al.^132^ When the results of this study are incorporated into the analysis, the results suggest that melatonin does not have an effect on sleep onset latency in people with secondary sleep disorders, whereas if the results of this study are omitted, they suggest that melatonin does have an effect. Moreover, although the summary estimate indicated that melatonin increased sleep efficiency in people with secondary sleep disorders, the study by Shamir et al. did not find such an increase. The study was unique in that polysomnography, rather than actigraphy or questionnaire/sleep diaries, was used to assess sleep outcomes, and the method of concealing treatment allocation was reported and was adequate. It is also noteworthy that this study was of sufficient duration to bypass the “first night effect”, which would tend to underestimate the effect of melatonin on sleep efficiency. Thus, although the results of this study are markedly different from other studies of this category, its results appear to be valid. It is possible that this discrepancy is due to publication or reporting bias, but with only six studies in this category, this bias is impossible to verify. Additional studies that use polysomnography to assess sleep outcomes are required before it can be concluded that melatonin does not affect sleep onset latency or that melatonin increases sleep efficiency in people with secondary sleep disorders.

Similar to the observations related to the effects of melatonin on people with primary sleep disorders, the observations of this review regarding the effects of melatonin on people with secondary sleep disorders are based on studies with relatively short trial durations of four weeks or less. Therefore, the effects of melatonin on sleep onset latency and sleep efficiency reported here may reflect only the short-term effects of melatonin on this population. It is necessary that trials of longer duration be conducted in order to determine the long-term effects of melatonin on this population.

It is noteworthy that the increase in sleep efficiency with melatonin in people with secondary sleep disorders was accompanied by an increase in total sleep time, but no evidence of a change in wakefulness after sleep onset (WASO). This apparent inconsistency may be explained by the difference in the number of studies that reported on the various outcomes; while six studies reported on sleep efficiency and nine studies reported on total sleep time, only three studies reported on WASO. Thus, the outcomes for which there were more data indicated evidence of an effect of melatonin, while the outcome for which there was little data showed a lack of evidence of an effect of melatonin. The latter finding may simply indicate that the there was insufficient power to detect evidence of an effect of melatonin on WASO.

### Effectiveness of Melatonin in People Suffering from Sleep Restriction Disorders

Two other systematic reviews examining the use of melatonin for the alleviation of jet lag concluded that melatonin is effective in alleviating the symptoms of jet lag.^100^ ^102^ These reviews assessed the effectiveness of melatonin in alleviating jet lag by examining the effect of this hormone on global assessments of jet lag, which encompass assessments of both the daytime fatigue and sleep disturbance aspects of jet lag. The results of the current review suggest that melatonin does not affect either sleep onset latency or sleep efficiency in jet lag sufferers or people suffering from shift-work disorder. The current review differs from the previous reviews in that the objective was to determine the effectiveness of melatonin in alleviating the sleep disturbance aspect of jet lag, and not the daytime sleepiness aspect of this disorder. Taken together, the findings of the current review and those of previous reviews suggest that the effectiveness of melatonin in alleviating jet lag may not involve alleviation of the sleep disturbance, but rather, the daytime fatigue associated with jet lag. The lack of substantial heterogeneity or evidence of possible publication bias across studies of this category and the moderate to high quality of the studies lend support to the results of the current review.

### Safety of Melatonin

The findings of this review suggest that exogenous melatonin is a relatively safe substance when used in the short term, over a period of days or weeks, and is safe at relatively high doses and in various formulations. However, the safety of exogenous melatonin when used in the long-term, over months and years, remains unclear.

### Formulations and Pharmacology of Melatonin

In general, the quality of reporting of the content and quality of the various formulations of melatonin that have been used in assessing its effectiveness and safety was poor, and it remains unclear which formulation of melatonin is optimal for the potential treatment of sleep disorders. The details of the formulations used in studies of the pharmacology of melatonin were often not reported, which precluded a quantitative analysis of the half-life of melatonin. Nonetheless, it appears that melatonin has a short half-life, which would tend to suggest that a sustained-release formulation of melatonin would be more effective than a fast-release formulation of melatonin in treating sleep disorders. However, it was unclear from our review of the literature whether the effectiveness of melatonin varies by formulation, and future research in this area is required. The finding that exogenous melatonin penetrates the blood-brain-barrier in one study suggests that exogenous melatonin exerts its effects via a similar mechanism as endogenous melatonin.

### Clinical Significance of Observations of this Review Related to the Effectiveness of Melatonin

One cannot draw firm conclusions regarding the effectiveness of melatonin in normal sleepers due to the presence of heterogeneity and evidence of possible publication bias in the studies relevant to this area. Similarly, the presence of heterogeneity across studies related to people with primary or secondary sleep disorders prevents one from drawing firm conclusions regarding the effectiveness of melatonin in alleviating these disorders.

Despite the inability to draw firm conclusions regarding the effectiveness of melatonin in normal sleepers and the effectiveness of melatonin in the treatment of sleep disorders, one may comment on the clinical significance of the findings of this review based on the current evidence. Indeed, the magnitude of the effects of melatonin appear to be of no clinical significance in all populations studied in this review, except for people suffering from delayed sleep phase syndrome. However, even for the latter population, one cannot definitively conclude that melatonin is effective in alleviating the sleep disturbance, since the observation of melatonin effectiveness in this population was based on only two studies with less that 25 participants. Therefore, there is evidence to suggest that melatonin is not effective in treating most primary and secondary sleep disorders, although there is some evidence to suggest that melatonin is effective in treating delayed sleep phase syndrome. Moreover, there is no evidence to suggest that melatonin is effective in alleviating the sleep disturbance aspect of jet lag and shift-work disorder.

A rigorous comparison of the effectiveness of melatonin and all other treatments for sleep disorders was beyond the scope of this review, and a systematic approach is required to determine how the effects of melatonin compare to other treatments for sleep disorders. However, our literature review revealed a paucity of evidence related to how melatonin compares with other pharmacological agents for sleep disorders in its effectiveness in normal sleepers and people with sleep disorders, and in its safety.

### Link Between Endogenous Melatonin and the Sleep Cycle

Our literature review indicated evidence of a link between endogenous melatonin and the sleep cycle. A key result was that a decrease in endogenous melatonin levels was often accompanied by increased latency to sleep and decreased duration of sleep, as well as increased vigilance and performance during waking hours. In addition, changes in the rhythm of endogenous melatonin were often accompanied by changes in the sleep rhythm. This relationship between endogenous melatonin and the sleep cycle is consistent with a role for exogenous melatonin in the alteration of the sleep cycle in humans. However, the nature of this relationship remains to be defined; it is unclear under what conditions a change in endogenous melatonin will be accompanied by a change in the sleep cycle and how these conditions would affect the magnitude and direction of these changes. A better understanding of this relationship would add to our knowledge of the conditions under which the effects of exogenous melatonin can be optimized. We also found evidence that manipulation of the sleep schedule can produce alterations in endogenous melatonin; however, the direction of these changes varied across studies. It is likely that the variation across studies is due to the particular conditions of sleep-schedule alterations as well the timing of assessment of the melatonin rhythm. It is important to note the possibility that the primary function of the inhibition of the superior cervical ganglion by light may be inhibition of pupil dilation rather than inhibition of endogenous melatonin secretion by the pineal gland, such that the effect of light on endogenous melatonin may be a secondary effect of light in humans.

### Link Between Endogenous Melatonin and the Temperature Rhythm

Similar to the analysis of the link between endogenous melatonin and the sleep cycle, our literature review indicated evidence of a link between endogenous melatonin and the temperature rhythm. Specifically, a reduction in endogenous melatonin levels was often accompanied by an increase in core body temperature, and a shift in the rhythm of endogenous melatonin was often accompanied by a similar shift in the rhythm of core body temperature. The observation of a phase-link in the melatonin and temperature rhythms is consistent with current knowledge that the same biological clock, the SCN, controls both of these rhythms.^238^ It has been suggested that exogenous melatonin induces sleepiness via a reduction in core body temperature, and the relationship between changes in endogenous melatonin and the temperature rhythm is consistent with this proposed mechanism. Only two studies examined the effect of manipulation of body temperature on endogenous melatonin, and the results were opposite. Additional research in this area is required to elucidate the effect of temperature on endogenous melatonin.

## Future Research

In light of the substantial amount of heterogeneity across studies of melatonin for the treatment of primary and secondary sleep disorders, more studies are necessary in this area. It is necessary that the conditions of these studies be clearly defined, especially with respect to the formulation and pharmacology of the melatonin product used in these studies. For studies involving melatonin administration to normal sleepers, the presence of substantial heterogeneity and evidence of publication bias necessitates more research in this area.

In addition to the areas outlined earlier in this report, research is required in various areas within the field of melatonin and sleep disorders research. There were some aspects of some questions of this review that could not be answered by the review, due to a lack of relevant information. For example, it remains unclear how the effects of melatonin vary by age, gender, ethnicity and co-morbid conditions of the population, as well as formulation, timing and duration of melatonin administration. Moreover, the long-term effect of melatonin on people with primary and secondary sleep disorders, beyond four weeks, remains to be determined. The short-term and long-term effects of melatonin on people with sleep apnea also need to be determined. The safety of melatonin in people of different ethnicities and with different timing of administration needs to be determined, as well as the effects of long-term use of melatonin. The mechanism by which melatonin produces sleepiness in humans is unclear as are the mechanisms by which melatonin is absorbed, distributed, metabolized and excreted in humans, and research is in this area is required. There are very few studies that compare the benefits and harms of melatonin and other pharmacological treatments for sleep disorders, and more research in this area is necessary.

## Limitations of the Review

The presence of substantial heterogeneity in the conduct of and results across studies involving administration of melatonin to people with either primary or secondary sleep disorders limits one from drawing any firm conclusions regarding the effectiveness of melatonin in these populations. Similarly, the presence of substantial heterogeneity and evidence of possible publication bias across studies involving normal sleepers prevents one from drawing any firm conclusions on effectiveness of melatonin in this population. The studies did not provide any evidence surrounding the safety of long-term use of melatonin, which prevents one from drawing any conclusions regarding this aspect of its safety. Moreover, one cannot draw any firm conclusions with respect to how melatonin compares with other pharmacological agents for sleep disorders in its effectiveness and safety.

A number of gaps were identified in the area of melatonin and sleep disorders research, which prevented us from addressing certain aspects and/or entire questions of the review. Major shortcomings of the studies included in the analysis of the effectiveness of melatonin for the treatment of sleep disorders and its safety were the quality of reporting with respect to the formulation and pharmacology of the melatonin product used in the study, the details of the sleep disorder suffered by participants and the funding sources for the studies.

## Conclusions

- Evidence suggests that melatonin is not effective in treating most primary sleep disorders with short-term use, although there is some evidence to suggest that melatonin is effective in treating delayed sleep phase syndrome with short-term use.
- Evidence suggests that melatonin is not effective in treating most secondary sleep disorders with short-term use.
- No evidence suggests that melatonin is effective in alleviating the sleep disturbance aspect of jet lag and shift-work disorder.
- Evidence suggests that melatonin is safe with short-term use.
- Evidence suggests that exogenous melatonin has a short half-life and it penetrates the blood-brain-barrier.
- Evidence suggests a link between endogenous melatonin and the sleep cycle
- There is evidence of a link between endogenous melatonin and the temperature rhythm.