# Results

## Literature Review

The database searches yielded 1884 references of potentially relevant articles. An initial screening of titles and abstracts of articles identified from database searches, as well as from hand-searching, yielded 935 studies to which specific inclusion criteria were applied. Of these 935 studies, 796 studies were excluded from the review and 139 studies were included in the review. Of the 796 studies that were excluded from the review, the majority were excluded because they were reviews (n=328). Other reasons for exclusion included inappropriate study topic (n=36), design (n=272), population (n=7), intervention (n=21) and outcomes (n=101). Three studies were not included in the review because of inadequate reporting. The reports of 25 studies were unobtainable at the time of this writing and two were realized upon completion of the final report. The rate of disagreement for study inclusion was approximately 20 percent. These disagreements were usually due to oversight of particular details of study design, and were easily resolved with discussion. In many cases, a given study was relevant to more than one question of the review (Flow Diagram 2). Table 5 outlines the number of studies relevant to each question of the review and the type of analysis that was applied to data relevant to these questions.

Table 5. Number of Studies relevant to Individual Questions of the Review and Type of Analysis Applied to Data Relevant to these Questions

Question | Number of Studies Relevant to Question | Type of Analysis Applied to Data Relevant to Question
Formulations of melatonin | 8: | Qualitative and Quantitative
| (RCTs)
Pharmacology of melatonin | 26: | Qualitative
| (RCTs, CCTs and Case Series)
Endogenous melatonin and the sleep cycle | 44: | Qualitative
| (RCTs and CCTs)
Mechanism of action of melatonin | 11: | Qualitative
| (RCTs and CCTs)
Effect of melatonin on normal sleepers | 21: | Quantitative
| (RCTs and CCTs)
Endogenous melatonin and circadian rhythms | 24: | Qualitative
| (RCTs and CCTs)
Effectiveness of melatonin among types of sleep disorders | 30: | Quantitative
| (RCTs)
Effectiveness of melatonin among types of populations | 29: | Quantitative
| (RCTs)
Effect of melatonin on people with sleep disorders | 30: | Quantitative
| (RCTs)
Appropriate dosage of melatonin for treatment of sleep disorders | 29: | Quantitative
| (RCTs)
Appropriate timing of melatonin administration for treatment of sleep disorders | 0 | Quantitative
Adverse effects of melatonin | 34: | Quantitative
| (RCTs and CCTs)
Adverse effects of melatonin as a function of dose, timing, and patient factors | 33: | Quantitative
| (RCTs and CCTs)
Melatonin and other pharmacological treatments for sleep disorders | 4: | Qualitative
| (RCTs and CCTs)

Abbreviations: RCT: randomized controlled clinical trial; CCT: controlled clinical trial

## Results of Quantitative Analysis

What is the effect of exogenous melatonin on sleep latency, sleep efficiency, and REM latency in healthy people?

Twenty-one studies were relevant to this question of the review. The quality of these studies was assessed using the Downs and Black Checklist.^115^ The overall quality of studies ranged from 11 to 25 on a 29-point scale; most studies had a score between 16 and 20; four studies had a score between 10 and 15;^78^ ^123–125^ and one study had a score of 25.^126^ The quality of reporting ranged from 4 to 11 on an 11-point scale; most studies had a score between seven and nine, three studies had a score between four and six^78^ ^124^ ^125^ and two studies had a score of 10 or 11.^126^ ^127^ The external validity of studies ranged from zero to three on a three-point scale; most studies had a score of zero, five studies had a score of one^124^ ^127–130^ and one study had a score of three.^126^ The internal validity of studies ranged from seven to 11 on a 13-point scale; approximately half of the studies had a score of 10 or 11; five studies had a score of nine;^78^ ^127^ ^131–133^ and six studies had a score of seven or eight.^123–125^ ^134–136^ None of the studies reported a power calculation for the primary outcome and, therefore, it was unclear whether the study had sufficient power to detect a clinically important effect where the probability value for a difference being due to chance is less than 5 percent. In general, these studies were of relatively low quality. Although all studies involved a placebo control, many studies did not involve random allocation of participants to interventions. For studies in which participants were randomly allocated to intervention groups, it was often unclear whether allocation concealment was maintained or whether participants were blinded as to the intervention they received. See Evidence Table C-1 for a description of design characteristics and overall quality scores of studies relevant to this question of the review.

The following three outcomes were examined with respect to effectiveness of melatonin in normal sleepers, the first two being the primary outcomes:

- Sleep Onset Latency: Defined as the amount of time between the subject laying down to sleep and the onset of stage one sleep.
- Sleep Efficiency: Defined as the amount of time the subject spent asleep expressed as a percentage of the total time spent in bed.
- REM Latency: Defined as the amount of time required to begin REM sleep after sleep onset.

### Sleep Onset Latency

#### Primary Analysis

There were a total of twenty studies with data on sleep onset latency for normal sleepers. The combined estimate comparing melatonin to placebo showed that melatonin caused a statistically significantly reduction in sleep onset latency (weighted mean difference (WMD): -3.9 minutes (min.); 95 percent confidence interval (CI): -5.3 min, -2.6 min). This effect appears to be clinically insignificant. Heterogeneity among the studies was moderate (I^2^: 47.1 percent). Nineteen of the twenty studies had a point estimate that favoured melatonin (Figure 3-1).

Figure 1. Meta-Graph: Sleep Onset Latency in Normal Sleepers

#### Subgroup and Sensitivity Analyses

The results of all the subgroup and sensitivity analyses are summarized in Table 6. Subgroups that could not be analyzed for sleep onset latency included age (all studies involved adult participants), ethnicity (not specified in any study), and formulation of melatonin (all studies used fast-release melatonin).

Table 6. Subgroup and Sensitivity Analysis: Sleep Onset Latency in Normal Sleepers

Subgroup | Categorization | Number of studies | Point Estimate (min) | 95 percent Confidence Interval (min) | Heterogeneity | Deeks' Chi-Square p-value
Gender | Male | 14 | -4.4 | -6.3, -2.5 | Moderate (I^2^:46.5 percent) | 0.24
| Mixed | 6 | -3.2 | -5.4, -1.0 | Substantial (I^2^: 51.1 percent)
Use of Concurrent Medication | Yes | 1 | -0.5 | -2.5, 1.5 | NA | NA
| No | 10 | -4.0 | -5.3, -2.6 | Minimal (I^2^: 11.0 percent)
Dosage of Melatonin Administration | < 1 mg | 5 | -7.6 | -11.7, -3.5 | Moderate (I^2^: 37.9 percent) | NA
| 1–3 mg | 10 | -6.1 | -9.1, -3.2 | Substantial (I^2^: 54.0 percent)
| 4–5 mg | 6 | -2.6 | -4.2, -1.1 | Substantial (I^2^: 57.5 percent)
| 6–10 mg | 7 | -6.1 | -8.9, -3.3 | Moderate (I^2^: 30.6 percent)
| > 10 mg | 2 | -3.4 | -7.6, 0.8 | Negligible (I^2^: 0 percent)
Timing of Melatonin Administration | < 1800h | 11 | -4.6 | -6.0, -3.2 | Moderate (I^2^: 29.4 percent) | 0.002
| > 1800h | 10 | -3.2 | -5.5, -1.0 | Moderate (I^2^: 41.9 percent)
Duration of Melatonin Administration | < 1 week | 14 | -4.2 | -5.6, -2.8 | Moderate (I^2^: 43.7 percent) | 0.03
| 1–2 weeks | 1 | -6.3 | -14.3, 1.7 | NA
| 3–4 weeks | 5 | -2.5 | -6.9, 2.0 | Moderate (I^2^: 27.9 percent)
Method of Measurement of Sleep Outcomes | Polysomnography | 14 | -3.7 | -5.0, -2.4 | Moderate (I^2^: 25.0 percent) | 0.001
| Actigraphy | 4 | -2.1 | -4.6, 0.4 | Moderate (I^2^: 34.5 percent)
| Questionnaire | 2 | -8.8 | -12.5, -5.2 | Negligible (I^2^: 0 percent)
Explicit Statement in Report that Subjects did not Suffer from a Sleep Disorder | Yes | 8 | -3.9 | -6.5, -1.3 | Substantial (I^2^: 55.1 percent) | 0.35
| No | 12 | -4.1 | -5.8, -2.4 | Moderate (I^2^: 43.5 percent)
Time of Sleep | Daytime | 9 | -4.6 | -6.0, -3.2 | Moderate (I^2^: 30.9 percent) | NA
| Night time | 13 | -3.0 | -4.9, -1.0 | Moderate (I^2^: 32.5 percent)
Use of Multiple Sleep Onset Latency Test | Yes | 3 | -4.2 | -5.7, -2.6 | Negligible (I^2^: 0 percent) | 0.16
| No | 17 | -4.0 | -5.7, -2.2 | Substantial (I^2^: 51.1 percent)
Study Design | Parallel | 2 | -4.5 | -10.6, 1.6 | Negligible (I^2^: 0 percent) | 0.67
| Crossover | 18 | -3.9 | -5.4, -2.5 | Substantial (I^2^: 51.8 percent)
Quality Score | 10–15 (low) | 4 | -3.8 | -4.9, -2.7 | Negligible (I^2^: 0 percent) | 0.01
| 16–20 (moderate) | 15 | -5.0 | -7.4, -2.7 | Moderate (I^2^: 44.3 percent)
| 21–25 (high) | 1 | -0.5 | -2.5, 1.5 | NA

Abbreviations: NA: not applicable, min: minutes

As can be seen from Table 6, none of the subgroups produced markedly different results from those obtained from the primary analysis. All of the subgroup point estimates favoured melatonin and this result was significant in most cases; the only exceptions were cases with only a small number of studies. Four of the partitions showed a significant Deeks' chi-square value, indicating that heterogeneity was significantly reduced by the partition. Method of measurement of sleep outcomes and timing of melatonin administration had the largest effect. Method of measurement of sleep outcomes showed the questionnaire group to have a larger effect than the other methods, but this could be due to the smaller sample size of only two studies. For all other subgroup analyses, the subgroups had overlapping confidence intervals.

Using the Fixed Effects Model instead of the Random Effects Model tightened the confidence interval but did not greatly change the point estimate (WMD: -3.2; 95 percent CI: -4.0, -2.5).

#### Assessment of Publication Bias

There was evidence of asymmetry in the funnel plot, indicating possible publication bias (Figure 3-2). In the numerical tests, the results of Egger's Graphical Test showed a p-value that was borderline significance, indicating possible bias (p-value: 0.049). Begg's Test (Kendall's S=-39 giving a p-value of 0.217 for 20 studies) and Duvall's Trim and Fill Test did not indicate publication bias.

Figure 2. Funnel Plot: Sleep Onset Latency in Normal Sleepers

Abbreviations: _ES: effect size, _seES: standard error of effect size; note that the smaller studies are associated with a larger standard error.

### Sleep Efficiency

#### Primary Analysis

There were a total of thirteen studies with data on sleep efficiency for normal sleepers. A statistically significant increase in sleep efficiency with melatonin was calculated when comparing melatonin to placebo (WMD: 2.3 percent; 95 percent CI: 0.7 percent, 3.9 percent). This effect appears to be clinically insignificant. Heterogeneity among the studies was substantial (I^2^: 53.9 percent). Eleven of the thirteen studies showed a point estimate indicating increased sleep efficiency with melatonin, one study indicated neutrality between melatonin and placebo, and one study indicated increased sleep efficiency with placebo (Figure 3-3).

Figure 3. Meta-Graph: Sleep Efficiency in Normal Sleepers

#### Subgroup and Sensitivity Analyses

The same subgroups that were analysed for sleep onset latency were also analysed for this outcome except for the use of the multiple sleep onset latency test (there were no studies employing this test) and study design (all studies had a crossover design). The results are summarized in Table 7.

Table 7. Subgroup and Sensitivity Analysis: Sleep Efficiency in Normal Sleepers

Subgroup | Categorization | Number of studies | Point Estimate (percent) | 95 percent Confidence Interval (percent) | Heterogeneity | Deeks' Chi-Square p-value
Gender | Male | 11 | 2.8 | 0.6, 4.9 | Substantial (I^2^: 58.1 percent) | 0.73
| Mixed | 2 | 1.8 | -0.9, 4.5 | Substantial (I^2^: 52.2 percent)
Use of Concurrent Medication | Yes | 6 | 2.2 | 0.1, 4.3 | Moderate (I^2^: 24.4 percent) | NA
| No | 1 | 0.9 | -0.5, 2.2 | NA
Dosage of Melatonin Administration | < 1 mg | 4 | 3.4 | 0.6, 6.1 | Negligible (I^2^: 0 percent) | NA
| 1–3 mg | 6 | 5.1 | 2.9, 7.3 | Minimal (I^2^: 12.7 percent)
| 4–5 mg | 2 | 0.7 | -0.4, 1.9 | Negligible (I^2^: 0 percent)
| 6–10 mg | 5 | 4.8 | -1.1, 10.7 | Substantial (I^2^: 76.6 percent)
| > 10 mg | 1 | 1.8 | -1.5, 5.1 | NA
Timing of Melatonin Administration | < 1800h | 6 | 1.0 | -6.0, 2.5 | Moderate (I^2^: 43.2 percent) | 0.01
| > 1800h | 7 | 4.4 | 1.5, 7.4 | Moderate (I^2^: 43.4 percent)
Duration of Melatonin Administration | < 1 week | 9 | 3.3 | -0.9, 5.7 | Substantial (I^2^: 65.5 percent) | 0.46
| 1–2 weeks | 0 | NA | NA | NA
| 3–4 weeks | 4 | 1.1 | -0.2, 2.3 | Negligible (I^2^: 0 percent)
Method of Measurement of Sleep Outcomes | Polysomnography | 10 | 3.0 | 0.6, 5.3 | Substantial (I^2^: 62.9 percent) | 0.78
| Actigraphy | 3 | 1.3 | 0.0, 2.5 | Neglibible (I^2^: 0 percent)
| Questionnaire | 0 | NA | NA | NA
Explicit Statement in Report that Subjects do not Suffer from a Sleep Disorder | Yes | 6 | 1.5 | -0.2, 3.1 | Moderate (I^2^: 33.8 percent) | 0.41
| No | 7 | 3.7 | 0.5, 6.9 | Substantial (I^2^: 66.4 percent)
Time of Sleep | Daytime | 5 | 8.0 | 1.0, 15.0 | Substantial (I^2^: 70.6 percent) | NA
| Night time | 10 | 1.2 | -0.0, 2.4 | Moderate (I^2^: 20.2 percent)
Study Design | Parallel | 1 | 0.0 | -4.1, 4.1 | NA | 0.50
| Crossover | 12 | 2.6 | 0.9, 4.3 | Substantial (I^2^: 57.0 percent)
Quality Score | 10–15 (low) | 2 | 7.5 | -5.4, 20.3 | Substantial (I^2^: 82.2 percent) | 0.44
| 16–20 (mod.) | 10 | 2.4 | 0.4, 4.5 | Substantial (I^2^: 52.1 percent)
| 21–25 (high) | 1 | 0.9 | -0.5, 2.2 | NA

Abbreviations: NA: not applicable

While most of the subgroups produced estimates there were not markedly different from the primary analysis, some differences are noteworthy. The most striking difference was in time of sleep; the efficiency effect of melatonin was much more prominent in the daytime sleepers. Timing of melatonin administration was the only partitioned result that showed a significant reduction in heterogeneity, but the confidence intervals of the two groups overlapped.

Using the Fixed Effects Model in place of the Random Effects Model gave a slightly lower effectiveness estimate of sleep efficiency but remained significant (WMD: 1.38; 95 percent CI: 0.5, 2.3).

#### Assessment of Publication Bias

All four tests of asymmetry indicated the possible presence of publication bias (Figure 3-4). The funnel plot showed a marked asymmetry that was confirmed by both Begg's Rank Correlation Test (Kendall's S=41—with 13 studies giving a continuity corrected p-value of 0.014) and Egger's Regression Test (bias p-value of 0.005). Duval's Trim and Fill Algorithm added 5 studies to the analysis and gave a modified estimate that was not significant (WMD: 0.9; 95 percent CI: -0.8, 2.7).

Figure 4. Funnel Plot: Sleep Efficiency in Normal Sleepers

Abbreviations: _ES: effect size, _seES: standard error of effect size; note that the smaller studies are associated with a larger standard error.

### REM Latency

#### Primary Analysis

Eleven studies had data on REM latency for normal sleepers. The point estimate showed that REM latency was slightly higher with melatonin but the difference was not significant (WMD: 2.6 min.; 95 percent CI: -4.1 min, 9.2 min). Heterogeneity among the studies was substantial (I^2^: 55.2 percent). Six of the 11 studies had a point estimate that showed an increase in REM latency for melatonin, while five studies showed a decrease (Figure 3-5).

Figire 5/ Meta-Graph: REM Latency in Normal Sleepers

#### Sensitivity and Subgroup Analysis

The subgroups analysed for REM latency in normal sleepers were the same as those analysed for sleep onset latency with the exception of method of measurement (all studies used polysomnography to measure sleep outcomes) and study design (all studies had a crossover design). The results are summarized in Table 8.

Table 8. Subgroup and Sensitivity Analysis: REM Latency in Normal Sleepers

Subgroup | Categorization | Number of studies | Point Estimate (min) | 95 percent Confidence Interval (min) | Heterogeneity | Deeks' Chi-Square p-value
Gender | Male | 9 | -1.2 | -6.2, 3.9 | Minimal (I^2^:17.8 percent) | 0.06
| Mixed | 2 | 17.7 | -8.0, 43.5 | Substantial (I^2^: 80.6 percent)
Use of Concurrent Medication | Yes | 0 | NA | NA | NA | NA
| No | 6 | -4.0 | -8.1, 0.1 | Negligible (I^2^: 0 percent)
Dosage of Melatonin Administration | < 1 mg | 4 | -7.1 | -18.9, 4.7 | Moderate (I^2^: 34.2 percent) | NA
| 1–3 mg | 6 | 12.7 | 6.8, 18.6 | Negligible (I^2^: 0 percent)
| 4–5 mg | 3 | 15.2 | -7.2, 37.5 | Substantial (I^2^: 92.0 percent)
| 6–10 mg | 3 | 3.8 | -7.9, 15.5 | Negligible (I^2^: 0 percent)
| > 10 mg | 1 | 13.6 | -45.9, 18.7 | NA
Timing of Melatonin Administration | < 1800h | 4 | 4.3 | -7.0, 15.5 | Mimimal (I^2^: 13.9 percent) | 0.21
| > 1800h | 7 | 2.6 | -5.6, 10.7 | Substantial (I^2^: 65.3 percent)
Duration of Melatonin Administration | < 1 week | 8 | 0.4 | -5.3, 6.2 | Moderate (I^2^: 39.2 percent) | 0.04
| 1–2 weeks | 0 | NA | NA | NA
| 3–4 weeks | 3 | 11.2 | -13.5, 35.9 | Substantial (I^2^: 69.2 percent)
Explicit Statement in Report that Subjects do not Suffer from a Sleep Disorder | Yes | 6 | 2.5 | -7.5, 12.5 | Substantial (I^2^: 68.7 percent) | 0.09
| No | 5 | 4.8 | -2.2, 11.9 | Negligible (I^2^: 0 percent)
Time of Sleep | Daytime | 2 | 12.4 | -0.0, 24.9 | Negligible (I^2^: 0 percent) | NA
| Night time | 10 | 0.9 | -5.9, 7.6 | Substantial (I^2^: 50.0 percent)
Use of Multiple Sleep Onset Latency Test | Yes | 1 | 12.6 | -0.3, 25.5 | NA | 0.04
| No | 10 | 1.2 | -5.6, 7.9 | Substantial (I^2^: 50.3 percent)
Quality Score | 10–15 (low) | 2 | 3.9 | -20.3, 28.1 | Substantial (I^2^: 54.0 percent) | 0.11
| 16–20 (mod.) | 9 | 1.8 | -5.2, 8.8 | Substantial (I^2^: 54.5 percent)
| 21–25 (high) | 0 | NA | NA | NA

Abbreviations: REM: rapid eye movement, NA: not applicable, min: minutes

All of the subgroup point estimates, except one, showed a non-significant difference in REM latency between melatonin and placebo; the 1–3 mg dosage subgroup, showed increased REM latency compared to both higher and lower doses. Although three of the partitioned subgroups indicated significant reduction in heterogeneity, besides the group already mentioned, there was no indication that REM latency is affected by melatonin.

The point estimate using the Fixed Effects Model in place of the Random Effects Model favoured placebo rather than melatonin, but was not statistically significant (WMD: -0.4, 95 percent CI: -3.9, 3.1).

#### Assessment of Publication Bias

While a visual inspection of the funnel plot seems to indicate some minor asymmetries (Figure 3-6), there was no evidence of publication bias in any of the quantitative tests. Begg's Test (Kendall's S=2; with 11 studies this is a p-value of 0.938), Egger's Test (bias p-value: 0.257) and Duval's Trim and Fill test (no studies added) did not give any indication of any asymmetry in the funnel plot.

Figure 6. Funnel Plot: REM Latency in Normal Sleepers

Abbreviations: _ES: effect size, _seES: standard error of effect size; note that the smaller studies are associated with a larger standard error.

What is the effect of exogenous melatonin on people with sleep disorders?

Thirty randomized controlled trials were relevant to this question. The quality of relevant studies was assessed using the Jadad Scale.^113^ The overall quality scores ranged from two to five on a five-point scale. Three studies had a quality score of two,^125^ ^137^ ^138^ eight studies had a quality score of three,^66^ ^70^ ^80^ ^132^ ^139–142^ 12 studies had a quality score of four^54^ ^60^ ^63^ ^69^ ^71^ ^73^ ^74^ ^81^ ^82^ ^90^ ^131^ ^135^ and seven studies had a quality score of five.^57^ ^61^ ^67^ ^68^ ^78^ ^91^ ^143^ It was unclear whether there was adequate concealment of treatment allocation in all studies except six.^67–69^ ^78^ ^90^ ^143^ All studies were described as randomized and double-blind and a description of withdrawals and dropouts was provided in all reports except six.^80^ ^125^ ^137–139^ ^141^ The method of randomization was described and was appropriate in nine studies,^57^ ^61^ ^63^ ^67^ ^68^ ^78^ ^91^ ^135^ ^143^ while the method of randomization was not described in all other studies. All reports except 11^60^ ^63^ ^66^ ^70^ ^125^ ^132^ ^135^ ^137^ ^138^ ^140^ ^142^ provided a description of an appropriate method of double-blinding; the method of double-blinding was not described in all other reports. These studies differed from studies involving normal sleepers mentioned above in that participants were randomized to intervention groups. However, other aspects of study design such as allocation concealment and blinding were similar to studies involving normal sleepers. See Evidence Table C-2 for a description of design characteristics and overall quality scores of studies relevant to this question of the review.

The following six outcomes were examined with respect to effectiveness of melatonin in people with sleep disorders, the first two being the primary outcomes:

- Sleep Onset Latency: Defined as the amount of time between the subject laying down to sleep, and the onset of stage 1 sleep.
- Sleep Efficiency: Defined as the amount of time the subject spent asleep as a percentage of the total time spent in bed.
- Sleep Quality: Defined as the overall quality of sleep attained. This outcome was measured differently across studies and was thus combined using a Standardized Mean Difference.
- Wakefulness After Sleep Onset (WASO): This is the amount of time spent awake in bed following the first attainment of stage one sleep.
- Total Sleep Time: Defined as the total time spent asleep while in bed.
- Percentage Time in REM Sleep: Defined as the total time spent in REM sleep as a percentage of total sleep time.

### People with a Primary Sleep Disorder

#### Sleep Onset Latency

Primary Analysis. There were 12 studies that examined sleep onset latency in patients with a primary sleep disorder. The combined weighted mean difference (WMD) of the studies showed that those in the melatonin group had a statistically significant shorter sleep onset latency period than those in the placebo group (WMD: -10.7 min.; 95 percent CI: -17.6 min., -3.7 min.), although there was substantial heterogeneity among the studies (I^2^: 81.5 percent). This effect appears to be clinically insignificant. Nine of the 12 studies showed a difference that favoured melatonin (Figure 3-7). These results are based on trials of four weeks or less in duration.

Figure 7. Meta-Graph: Sleep Onset Latency in People with a Primary Sleep Disorder

Sensitivity and Subgroup Analysis. Table 9 summarizes the results of the subgroup and sensitivity analyses of sleep onset latency in patients with a primary sleep disorder. Subdivision by gender was not possible as all studies were mixed gender. Only two studies specified ethnicity—both were Caucasian. For use of concurrent medications, all but two studies either did not specify or had a mixture of patients on and off medications. For dosage, three studies used multiple doses and were included in two or more groups, while two studies were excluded since they did not specify dosage.

Table 9. Subgroup and Sensitivity Analyses: Sleep Onset Latency in People with a Primary Sleep Disorder

Subgroup | Categorization | Number of studies | Point Estimate (min) | 95 percent Confidence Interval (min) | Heterogeneity | Deeks' Chi-Square p-value
Age | Children | 1 | -17.0 | -33.5, -0.5 | NA | 0.002
| Adult | 7 | -11.2 | -27.7, 5.4 | Substantial (I^2^: 84.0 percent)
| Elderly | 4 | -7.8 | -17.4, 1.7 | Substantial (I^2^: 69.6 percent)
Ethnicity | Caucasian | 2 | -17.5 | -33.9, -1.2 | Negligible (I^2^: 0 percent) | NA
Use of Concurrent Medication | Yes | 1 | -14.0 | -28.7, 0.7 | NA | NA
| No | 1 | 1.7 | -30.6, 34.0 | NA
Dosage of Melatonin Administration | < 1 mg | 2 | -0.9 | -5.4, 3.6 | Negligible (I^2^: 0 percent) | NA
| 1–3 mg | 5 | -6.0 | -12.9, 0.8 | Moderate (I^2^: 28.0 percent)
| 4–5 mg | 6 | -13.3 | -30.3, 3.7 | Substantial (I^2^: 90.0 percent)
Duration of Melatonin Administration | < 1 week | 1 | -9.7 | -20.5, 1.1 | NA | 0.07
| 1–2 weeks | 5 | -7.9 | -17.5, 1.6 | Negligible (I^2^: 0 percent)
| 3–4 weeks | 6 | -12.4 | -21.9, -2.8 | Substantial (I^2^: 90.3 percent)
Method of Measurement of Sleep Outcomes | Polysomnography | 5 | -14.2 | -27.9, -0.5 | Substantial (I^2^: 89.5 percent) | 0.001
| Actigraphy | 3 | -8.1 | -21.3, 5.0 | Substantial (I^2^: 70.0 percent)
| Questionnaire | 4 | -2.3 | -23.5, 18.9 | Negligible (I^2^: 0 percent)
Primary Diagnosis | Insomnia | 10 | -4.3 | -8.4, -0.1 | Moderate (I^2^: 44.9 percent) | < 0.00001
| Delayed Sleep-Phase Syndrome | 2 | -38.8 | -50.3, -27.3 | Negligible (I^2^: 0 percent)
Study Design | Parallel | 2 | -17.1 | -32.4, -1.8 | Negligible (I^2^: 0 percent) | 0.03
| Crossover | 10 | -9.9 | -17.2, -2.5 | Substantial (I^2^: 83.8 percent)
Quality Score | Moderate (2–3) | 4 | -5.4 | -11.8, 0.9 | Moderate (I^2^: 37.2 percent) | 0.13
| High (4–5) | 8 | -13.1 | -28.9, 2.8 | Substantial (I^2^: 86.7 percent)
Allocation Concealment | Unclear | 10 | -9.6 | -17.2, -2.0 | Substantial (I^2^: 82.7 percent) | 0.007
| Adequate | 2 | -15.3 | -26.3, -4.4 | Negligible (I^2^: 0 percent)

Abbreviations: NA: not applicable, min: minutes

Many of these sub groupings significantly reduced heterogeneity despite retaining a substantial heterogeneity statistic in at least one subgroup. The one subgroup that is noteworthy is that of primary diagnosis, which substantially reduced the heterogeneity and is the only sub grouping that gave results with non-overlapping confidence intervals. This variable appears to explain much of the heterogeneity in the primary analysis.

Using the Fixed Effects Model rather than Random Effects Model greatly changes the results of the primary analysis as well as the conclusion. One study^91^ received nearly 92 percent of the weight and the new difference was not significant (WMD = -0.32; 95 percent CI -1.3, 0.6).

Assessment of Publication Bias. Assessment of publication bias for sleep onset latency of patients with primary sleep disorders was performed. No obvious asymmetry was evident in the funnel plot (Figure 3-8). Begg's test gave a Kendal's score of S=6—with 12 studies, this constitutes a continuity corrected p-value of 0.732 indicating no publication bias. Performing Duval's Trim and Fill Method, no studies were added to the meta-analysis, and the final results were identical to the primary analysis. The only test that showed any indication of publication bias was Egger's Graphical test, which had a p-value of 0.027 on the bias of the funnel plot.

Figure 8. Funnel Plot: Sleep Onset Latency in People with a Primary Sleep Disorder

Abbreviations: _ES: effect size, _seES: standard error of effect size; note that the smaller studies are associated with a larger standard error.

#### Sleep Efficiency

Primary Analysis. Nine trials were included in the analysis of sleep efficiency for people with primary sleep disorders. Although the WMD did favour melatonin, the difference was not significant (WMD: 1.5 percent; 95 percent CI: -0.7 percent, 3.6 percent) and the heterogeneity among the studies was substantial (I^2^: 62.8 percent). Six out of the nine studies showed a point estimate that favoured melatonin (Figure 3-9). These results are based on trials of four weeks or less in duration.

Figure 9. Meta-Graph: Sleep Efficiency in People with a Primary Sleep Disorder

Sensitivity and Subgroup Analysis. Table 10 summarizes the results of the subgroup analysis of sleep efficiency in patients with a primary sleep disorder. Subdivision by gender and ethnicity was not possible since all studies were of mixed gender and none of the studies specified ethnicity. For use of concurrent medications, all studies either did not specify or had a mixture of patients on and off medications. For subdivision by dosage, three studies used multiple doses and were in multiple groups; one study was excluded, as it did not specify dosage.

Table 10. Subgroup and Sensitivity Analyses: Sleep Efficiency in People with a Primary Sleep Disorder

Subgroup | Categorization | Number of studies | Point Estimate (percent) | 95 percent Confidence Interval (percent) | Heterogeneity | Deeks' Chi-Square p-value
Age | Adult | 6 | -0.0 | -1.6, 1.5 | Minimal (I^2^: 16.1 percent) | 0.004
| Elderly | 3 | 3.6 | -0.8, 8.0 | Substantial (I^2^: 73.0 percent)
Use of Concurrent Medication | Yes | 1 | 8.0 | 4.1, 11.9 | NA | NA
| No | 1 | -1.4 | -4.3, 1.5 | NA
Dosage of Melatonin Administration | < 1 mg | 2 | 3.4 | -4.6, 11.3 | Substantial (I^2^: 78.8 percent) | NA
| 1–3 mg | 5 | 2.4 | -1.7, 6.5 | Substantial (I^2^: 77.9 percent)
| 4–5 mg | 4 | -0.0 | -1.4, 1.3 | Negligible (I^2^: 0 percent)
Duration of Melatonin Administration | < 1 week | 1 | 0.3 | -4.4, 5.0 | NA | 0.91
| 1–2 weeks | 5 | 0.8 | -2.1, 3.8 | Moderate (I^2^: 45.6 percent)
| 3–4 weeks | 3 | 2.6 | -2.1, 7.2 | Substantial (I^2^: 85.7 percent)
Method of Measurement of Sleep Outcomes | Polysomno-graphy | 5 | 0.2 | -2.1, 2.6 | Moderate (I^2^: 31.1 percent) | 0.48
| Actigraphy | 3 | 3.1 | -1.2, 7.5 | Substantial (I^2^: 85.9 percent)
| Questionnaire | 1 | -3.0 | -18.3, 12.3 | NA
Primary Diagnosis | Insomnia | 8 | 1.7 | -0.8, 4.1 | Substantial (I^2^: 67.3 percent) | 0.75
| Sleep-Phase Syndrome | 1 | 0.2 | -3.7, 4.1 | NA
Quality Score | Moderate (2–3) | 4 | 1.7 | -1.2, 4.6 | Moderate (I^2^: 34.0 percent) | 0.39
| High (4–5) | 5 | 1.3 | -1.9, 4.5 | Substantial (I^2^: 75.3 percent)
Allocation Concealment | Unclear | 8 | 0.3 | -0.9, 1.5 | Minimal (I^2^: 6.3 percent) | 0.0002
| Adequate | 1 | 8.0 | 4.1, 11.9 | NA

Abbreviations: NA: not applicable

The only sub-grouping that is noteworthy is that of allocation concealment. Removing the study by Garfinkel et al.,^90^ which was considered to have adequate allocation concealment, removed the vast majority of the heterogeneity from the analysis and the result based on this study was significant. This finding is likely due to chance, since allocation concealment has been associated with smaller, rather than larger, effect sizes.^114^ The remaining eight studies showed no effect. The only other sub grouping that significantly reduced heterogeneity was age, but the resulting confidence intervals were non-overlapping and non-significant.

If we use a fixed effects model instead of a random effects model in our analysis, our point estimate decreases slightly and our confidence interval tightens, but the result is still non-significant (WMD: 0.8; 95 percent CI: -0.3, 1.8).

Assessment of Publication Bias. The funnel plot showed some asymmetry (Figure 3-10), however all other tests did not indicate publication bias. Begg's test gave a Kendal's score of S=7—with nine studies, this constitutes a continuity corrected p-value of 0.529. Egger's Graphical Test had a p-value of 0.441 on the bias of the funnel plot. Finally, Duval's Trim and Fill Method had no studies added to the meta-analysis, and the final results were identical to the primary analysis.

Figure 10. Funnel Plot: Sleep Efficiency in People with a Primary Sleep Disorder

Abbreviations: _ES: effect size, _seES: standard error of effect size; note that the smaller studies are associated with a larger standard error.

#### Sleep Quality

Sleep quality for patients with a primary sleep disorder was recorded in only two studies^57^ ^140^ and measured on different scales. The results were combined using a Standardized Mean Difference (SMD); this outcome is slightly more difficult to interpret since it appears in units of standard deviation. The SMD favoured melatonin over placebo, but the result was not significant (SMD: 0.5; 95 percent CI: -0.1, 1.1). Heterogeneity between the two studies was negligible (I^2^: 0 percent). Both studies had a point estimate that favoured melatonin.

#### Wakefulness After Sleep Onset

WASO was reported in five studies involving administration of melatonin to individuals with primary sleep disorders. Combining them with a WMD showed virtually no difference between placebo and melatonin (WMD: -1.4 min.; 95 percent CI: -21.8 min., 19.0 min.). The heterogeneity among the studies was substantial (I^2^: 84.0 percent). Three of the studies had point estimates that favoured placebo, one study had a point estimate that favoured neither melatonin nor placebo, and one study had a point estimate that favoured melatonin.

#### Total Sleep Time

Eleven studies had data on total sleep time for patients with a primary sleep disorder. Their combined estimate comparing total sleep time between placebo and melatonin using a WMD favoured melatonin but was not significant (WMD: 4.0 min.; 95 percent CI: -10.5 min., 18.5 min.). The studies showed substantial heterogeneity (I^2^: 67.6 percent). Only five of the 11 studies had a point estimate that favoured melatonin.

#### Percentage Time Spent in REM Sleep

Three studies involving melatonin administration to individuals suffering from a primary sleep disorder reported on percentage time spent in REM sleep. Using a WMD to combine the studies gave an estimate that marginally favoured melatonin but was not significant (WMD: 0.4 min.; 95 percent CI: -1.2 min., 2.0 min.). Heterogeneity in the estimate was negligible (I^2^: 0 percent). Two of the three studies had a point estimate that favoured melatonin.

### People with a Secondary Sleep Disorder

#### Sleep Onset Latency

Primary Analysis. There were six trials involving melatonin administration to individuals with a secondary sleep disorder that reported on sleep onset latency. Their combined estimate favoured melatonin but was non-significant (WMD: -13.2 min.; 95 percent CI: -27.3 min., 0.9 min.). Heterogeneity among the studies was substantial (I^2^: 79.2 percent) due primarily to one study^132^ that had a very small standard deviation and an estimate very different from the other five studies. This study had a point estimate that favoured placebo, while the other five studies had point estimates that favoured melatonin (Figure 3-11). These results are based on trials of four weeks or less in duration.

Figure 11. Meta-Graph: Sleep Onset Latency in People with a Secondary Sleep Disorder

Sensitivity and Subgroup Analysis. Table 11 summarizes the results of the subgroup and sensitivity analyses of sleep onset latency for patients with a secondary sleep disorder. Subgroups not analysed below were ethnicity (not specified in any study), concurrent medications (all patients taking additional medications in all studies), and Jadad score (same for all studies). For gender, all study populations were mixed except for a study by McArthur et al.,^80^ which was all female. For dosage, only four studies are listed since one study did not specify dosage,^82^ and another gave varying doses based on weight.^80^ Primary disorder was different for all studies except for two studies that both examined patients with schizophrenia.^131^ ^132^

Table 11. Subgroup and Sensitivity Analyses: Sleep Onset Latency in People with a Secondary Sleep Disorder

Subgroup | Categorization | Number of studies | Point Estimate (min) | 95 percent Confidence Interval (min) | Heterogeneity | Deeks' Chi-Square p-value
Age | Children | 3 | -18.1 | -29.4, -6.8 | Negligible (I^2^: 0 percent) | 0.0001
| Adult | 3 | -6.6 | -24.6, 11.4 | Substantial (I^2^: 79.2 percent)
Gender | Female | 1 | -12.9 | -27.6, 1.8 | NA | NA
Dosage of Melatonin Administration | 1–3 mg | 2 | -4.6 | -29.8, 20.6 | Substantial (I^2^: 78.1 percent) | NA
| 4–5 mg | 1 | -23.4 | -45.2, -1.6 | NA
| 6–10 mg | 1 | -13.5 | -32.5, 5.5 | NA
Duration of Melatonin Administration | 1–2 weeks | 2 | -25.7 | -43.3, -8.0 | Negligible (I^2^: 0 percent) | < 0.00001
| 3–4 weeks | 2 | -4.6 | -29.8, 20.6 | Substantial (I^2^: 78.1 percent)
| > 4 weeks | 2 | -13.1 | -24.8, -1.5 | Negligible (I^2^: 0 percent)
Method of Measurement of Sleep Outcomes | Polysomnography | 1 | 5.8 | 2.5, 9.1 | NA | < 0.00001
| Actigraphy | 3 | -14.5 | -25.0, -4.1 | Negligible (I^2^: 0 percent)
| Questionnaire | 2 | -25.7 | -43.3, -8.0 | Negligible (I^2^: 0 percent)
Co-Morbidity | Schizophrenia | 2 | -4.6 | -29.8, 20.6 | Substantial (I^2^: 78.1 percent) | NA
Study Design | Parallel | 1 | -13.5 | -32.5, 5.5 | NA | 0.08
| Crossover | 5 | -13.5 | -29.7, 2.8 | Substantial (I^2^: 81.0 percent)
Allocation Concealment | Unclear | 5 | -17.4 | -26.4, -8.4 | Negligible (I^2^: 0 percent) | < 0.00001
| Adequate | 1 | 5.8 | 2.5, 9.1 | NA

Abbreviations: NA: not applicable, min: minutes

One study by Shamir et al.^132^ completely dictated the results of the subgroup analysis. Subgroups that omitted this study, showed a significant result in favour of melatonin with negligible heterogeneity, while subgroups that did include this study were non-significant with substantial heterogeneity. The two sub groupings in which this study stood alone do not shed much light on the reason for the difference. The Shamir et al. study^132^ was the only study that used polysomnography to measure sleep outcomes and also the only study that was considered to have adequate allocation concealment.

Using the Fixed Effects Method instead of the Random Effects Method drastically changed the results due to the vast majority of the weight being assigned to the study by Shamir et al.^132^ The point estimate for sleep onset latency favoured placebo and was non-significant (WMD: 3.0; 95 percent CI: -0.1, 6.1).

Assessment of Publication Bias. With only six studies analysing sleep onset latency in patients with a secondary sleep disorder, the number of studies was deemed too few to do any meaningful tests for publication bias.

#### Sleep Efficiency

Primary Analysis. There were six trials for which data were available for comparing melatonin to placebo in sleep efficiency. The WMD of the six studies showed a statistically significant effect that favoured melatonin (WMD: 1.9 percent; 95 percent CI: 0.5 percent, 3.3 percent). This effect appears to be clinically insignificant. Heterogeneity among the studies was negligible (I^2^: 0 percent). Five of the six studies had point estimates that favoured melatonin while one study had a point estimate that favoured neither melatonin nor placebo (Figure 3-12). These results are based on trials of four weeks or less in duration.

Figure 12. Meta-Graph: Sleep Efficiency in People with a Secondary Sleep Disorder

Sensitivity and Subgroup Analysis. Table 12 summarizes the results of the subgroup analysis of sleep efficiency on patients with a secondary sleep disorder. Subgroups that were not possible were gender, ethnicity, timing, and Jadad score. Only three studies could be classified by use of concurrent medications (others were mixed or not specified). For dosage, one study was excluded since it gave varying doses based on weight and another gave multiple doses and was included in multiple categories. Primary disorder was different for all studies except for two studies that both examined patients with schizophrenia.

Table 12. Sensitivity and Subgroup Analyses: Sleep Efficiency in People with a Secondary Sleep Disorder

Subgroup | Categorization | Number of studies | Point Estimate (percent) | 95 percent Confidence Interval (percent) | Heterogeneity | Deeks' Chi-Square p-value
Age | Children | 1 | 3.4 | -3.9, 10.7 | NA | 0.89
| Adult | 3 | 2.6 | -1.3, 6.4 | Substantial (I^2^: 52.9 percent)
| Elderly | 2 | 2.0 | 0.2, 3.8 | Negligible (I^2^: 0 percent)
Use Concurrent Medication | Yes | 3 | 2.3 | -1.4, 6.0 | Moderate (I^2^: 48.9 percent) | NA
Dosage of Melatonin Administration | 1–3 mg | 3 | 1.9 | -0.5, 4.3 | Moderate (I^2^: 47.4 percent) | NA
| 6–10 mg | 3 | 2.2 | 0.1, 4.3 | Negligible (I^2^: 0 percent)
Duration of Melatonin Administration | 1–2 weeks | 1 | 2.0 | -4.1, 8.1 | NA | 0.99
| 3–4 weeks | 4 | 2.5 | -0.5, 5.4 | Moderate (I^2^: 32.6 percent)
| > 4 weeks | 1 | 2.0 | 0.1, 3.9 | NA
Method of Measurement of Sleep Outcomes | Polysomography | 1 | 0.0 | -2.7, 2.7 | NA | 0.28
| Actigraphy | 5 | 2.6 | 1.0, 4.2 | Negligible (I^2^: 0 percent)
Co-Morbidity | Schizophrenia | 2 | 2.3 | -2.9, 7.4 | Substantial (I^2^: 72.5 percent) | NA
Study Design | Parallel | 2 | 2.2 | 0.3, 4.0 | Negligible(I^2^: 0 percent) | 0.93
| Crossover | 4 | 2.0 | -0.7, 4.7 | Moderate (I^2^: 23.8 percent)
Allocation Concealment | Unclear | 4 | 2.6 | 1.0, 4.3 | Negligible (I^2^: 0 percent) | 0.33
| Adequate | 2 | 0.3 | -2.2, 2.8 | Negligible (I^2^: 0 percent)

Abbreviations: NA: not applicable

The only study that did not show a positive effect for sleep efficiency used polysomnography instead of actigraphy as its method to measure sleep outcomes. The two studies considered to have adequate allocation concealment had the lowest sleep efficiency estimates. However, the differences were not enough to significantly reduce heterogeneity in either of the subgroups.

Due to the negligible amount of heterogeneity, using the Fixed Effects Model instead of the Random Effects Model did not change the estimate in the primary analysis. The WMD and confidence interval were identical.

Assessment of Publication Bias. With only six included studies analysing sleep efficiency in patients with a secondary sleep disorder, the number of studies was deemed too few to do any meaningful tests for publication bias.

#### Sleep Quality

There were no studies involving individuals with a secondary sleep disorder that examined sleep quality.

#### Wakefulness After Sleep Onset

Three studies involving individuals with secondary sleep disorders had data on WASO. The combined estimate showed a difference between melatonin and placebo that favoured melatonin but the difference was non-significant (WMD: -6.3 min.; 95 percent CI: -16.6 min, 3.9 min.). Heterogeneity among the studies was moderate (I^2^: 35.3 percent). Two of the three studies had a point estimate that favoured melatonin.

#### Total Sleep Time

There were a total of nine studies that analyzed total sleep time for patients with secondary sleep disorders. The studies showed a combined estimate that significantly favoured melatonin (WMD: 15.6 min.; 95 percent CI: 7.2 min., 24.0 min.). Heterogeneity was negligible (I^2^: 0 percent). Eight out of the nine studies had a point estimate that favoured melatonin.

#### Percentage Time in REM Sleep

There was only one study involving individuals with a secondary sleep disorder that provided data on percent time spent in REM sleep. The WMD favoured placebo but was not significant (WMD: -1.5 percent; 95 percent CI: -4.4 percent, 1.4 percent).

### People Suffering from Sleep Restriction

#### Sleep Onset Latency

Primary Analysis. There were a total of nine studies that provided data on sleep onset latency for patients suffering from sleep restriction. Despite a tight confidence interval, the nine studies did not show a significant effect for melatonin on sleep onset latency (WMD: -1.0 min.; 95 percent CI: -2.3 min., 0.3 min.). Heterogeneity among the studies was minimal (I^2^: 4.0 percent). Six of the nine studies had a point estimate that favoured melatonin (Figure 3-13).

Figure 13. Meta-Graph: Sleep Onset Latency in People Suffering from Sleep Restriction

Sensitivity and Subgroup Analyses. Many of the planned subgroup analyses of sleep onset latency in patients suffering from sleep restriction could not be performed. The subgroups include gender (all studies involved both males and females and did not provide a breakdown by gender), age (subjects' age was similar across studies), ethnicity (not specified in any study), timing (all patients took melatonin before bed), and duration (the duration of melatonin administration was similar across studies). The results of the subgroup analyses that could be performed are summarized in Table 13. Note that only two studies could be classified in terms of concurrent medication use.

Table 13. Subgroup and Sensitivity Analyses: Sleep Onset Latency in People Suffering from Sleep Restriction

Subgroup | Categorization | Number of studies | Point Estimate (min) | 95 percent Confidence Interval (min) | Heterogeneity | Deeks' Chi-Square p-value
Use of Concurrent Medication | No | 2 | -3.4 | -10.4, 3.7 | Substantial (I^2^: 56.7 percent) | NA
Dosage of Melatonin Administration | < 1 mg | 1 | -11.8 | -23.6, -0.0 | NA | NA
| 1–3 mg | 2 | -4.5 | -17.3, 8.3 | Substantial (I^2^: 75.3 percent)
| 4–5 mg | 5 | -1.0 | -4.0, 2.1 | Minimal (I^2^: 18.2 percent)
| 10–20 mg | 1 | -2.0 | -7.5, 3.5 | NA
Method of Measurement of Sleep Outcomes | Polysomnography | 2 | -6.6 | -14.7, 1,5 | Negligible (I^2^: 0 percent) | 0.24
| Actigraphy | 1 | 0.8 | -2.7, 4.3 | NA
| Questionnaire | 6 | -1.1 | -2.2, 0.1 | Negligible (I^2^: 0 percent)
Type of Sleep Restriction | Jet Lag | 3 | -4.7 | -12.6, 3.1 | Minimal (I^2^: 16.9 percent) | 0.17
| Shift Work | 5 | -0.8 | -1.9, 0.3 | Negligible (I^2^: 0 percent)
| Deprivation | 1 | -9.0 | -19.2, 1.2 | NA
Study Design | Parallel | 4 | -6.1 | -11.9, -0.2 | Negligible (I^2^: 0 percent) | 0.08
| Crossover | 5 | -0.8 | -1.9, 0.3 | Negligible (I^2^: 0 percent)
Quality Score | High (4–5) | 5 | -1.2 | -4.6, 2.3 | Minimal (I^2^: 18.6 percent) | 1.00
| Moderate (2–3) | 4 | -0.9 | -2.7, 0.8 | Minimal (I^2^: 12.2 percent)
Allocation Concealment | Unclear | 6 | -1.4 | -3.8, 1.1 | Moderate (I^2^: 26.2 percent) | 0.73
| Adequate | 3 | -0.5 | -3.7, 2.7 | Negligible (I^2^: 0 percent)

Abbreviations: NA: not applicable, min: minutes

Using the Fixed Effect Model in place of the Random Effects Model does not change the conclusions. The point estimate and confidence interval (WMD: -1.0; 95 percent CI: -2.1, 0.1) are comparable to the random effects estimate.

Assessment of Publication Bias. The funnel plot showed no obvious signs of asymmetry (Figure 3-14). There were also no indications of publication bias by any of the tests conducted. Begg's Test gives a Kendall's score of -10, which gives a continuity corrected p-value of 0.348 with nine studies. Egger's Test has a p-value of 0.479 on the bias of the funnel plot. Duval's Trim and Fill Method added no new studies and thus had the same effectiveness estimate.

Figure 14. Funnel Plot: Sleep Onset Latency in People Suffering from Sleep Restriction

Abbreviations: _ES: effect size, _seES: standard error of effect size; note that the smaller studies are associated with a larger standard error.

#### Sleep Efficiency

Primary Analysis. Data on sleep efficiency were available for only five studies that examined patients suffering from sleep restriction. The combined estimate of the studies showed no significant difference between melatonin and placebo with respect to sleep efficiency (WMD: 0.5 percent; 95 percent CI: -0.6 percent, 1.6 percent). Heterogeneity among the studies was moderate (I^2^: 20.9 percent). Four of the five studies had point estimates that favoured melatonin (Figure 3-15).

Figure 15. Meta-Graph: Sleep Efficiency in People Suffering from Sleep Restriction

Sensitivity and Subgroup Analyses. Many subgroup analyses could not be performed, including gender (all studies involved both males and females and did not provide a breakdown by gender), age (subjects' age was similar across studies), ethnicity (not specified in any study), timing (all patients took melatonin before bed), duration (the duration of melatonin administration was similar across studies), use of concurrent medication (not stated in any of the studies) and dosage (different across studies). The partitions that could be performed are outlined in Table 14.

Table 14. Subgroup and Sensitivity Analyses: Sleep Efficiency in People Suffering from Sleep Restriction

Subgroup | Categorization | Number of studies | Point Estimate (percent) | 95 percent Confidence Interval (percent) | Heterogeneity | Deeks' Chi-Square p-value
Method of Measurement of Sleep Outcomes | Polysomnography | 2 | 1.8 | 0.1, 3.5 | Negligible (I^2^: 0 percent) | 0.11
| Actigraphy | 1 | 0.2 | -3.9, 4.3 | NA
| Questionnaire | 2 | -0.2 | -1.1, 0.6 | Negligible (I^2^: 0 percent)
Type of Sleep Restriction | Jet Lag | 1 | 2.9 | -1.4, 7.2 | NA | 0.10
| Shift Work | 3 | -0.2 | -1.1, 0.6 | Negligible (I^2^: 0 percent)
| Deprivation | 1 | 1.6 | -0.2, 3.4 | NA
Study Design | Parallel | 2 | 1.8 | 0.1, 3.5 | Negligible (I^2^: 0 percent) | 0.11
| Crossover | 3 | -0.2 | -1.1, 0.6 | Negligible (I^2^: 0 percent)
Quality Score | High (4–5) | 2 | -0.2 | -1.1, 0.6 | Negligible (I^2^: 0 percent) | 0.14
| Moderate (2–3) | 3 | 1.6 | 0.0, 3.1 | Negligible (I^2^: 0 percent)
Allocation Concealment | Unclear | 2 | -0.2 | -1.1, 0.6 | Negligible (I^2^: 0 percent) | 0.14
| Adequate | 3 | 1.6 | 0.0, 3.1 | Negligible (I^2^: 0 percent)

Abbreviations: NA: not applicable

Interestingly, all four subdivisions above gave negligible heterogeneity in all of their respective subgroups, although it was never a significant reduction in overall heterogeneity.

Using the Fixed Effects Model in place of the Random Effects Model to obtain the estimate of sleep efficiency for patients suffering from sleep restriction did not differ substantially from the primary analysis. The effectiveness estimate slightly favoured melatonin but was non-significant (WMD: 0.2; 95 percent CI: -0.6, 0.9).

Assessment of Publication Bias. There were an insufficient number of studies that involved subjects suffering from sleep restriction that examined sleep efficiency to justify performing tests for publication bias.

#### Sleep Quality

Five studies contained data on sleep quality. The standardized mean difference showed an effectiveness estimate that favoured melatonin but was not significant (SMD: 0.24; 95 percent CI: -0.17, 0.64). Heterogeneity among the studies was substantial (I^2^: 58.5 percent). Four out of the five studies had a point estimate that favoured melatonin.

#### Wakefulness After Sleep Onset

Two studies involving individuals suffering from sleep restriction provided data on WASO. Their combined estimate favoured melatonin but was not significant (WMD: -10.4 min; 95 percent CI: -21.0, 0.2). Heterogeneity between the studies was negligible (I^2^: 0 percent). Both studies' point estimates favoured melatonin.

#### Total Sleep Time

Seven studies involving patients suffering from sleep restriction compared total sleep time between placebo and melatonin; a significant effect that favoured melatonin was observed among the seven studies (WMD: 18.2 min; 95 percent CI: 8.1 min, 28.3 min). Heterogeneity among the studies was negligible (I^2^: 0 percent). Five of the seven studies showed a point estimate that favoured melatonin, one study had a point estimate that neither favoured melatonin or placebo, and one study had a point estimate that favoured placebo.

#### Percentage Time in REM Sleep

Only one study^138^ presented data on percentage time spent in REM sleep. The effectiveness estimate favoured placebo and was non-significant (WMD: -3.6 percent; 95 percent CI: -7.3, 0.1).

Which sleep disorders would be most effectively managed by treatment with melatonin?

As can be seen by the results above, the effect of melatonin on the various sleep disorders varies by outcome.

#### Sleep Onset Latency

For patients with primary sleep disorders, there was too much statistical heterogeneity among the studies to make a valid conclusion about the effect of melatonin on sleep onset latency in a broad sense. However, the heterogeneity largely disappears when we subdivide by type of sleep disorder. We then find that sleep onset latency is reduced substantially (by nearly 39 minutes) by melatonin in patients with delayed sleep phase syndrome, and marginally (by about 4 minutes) in patients with insomnia. Both results are statistically significant, however, the effect of melatonin on sleep onset latency in people with insomnia appears to be clinically insignificant. The reduced heterogeneity lends support to these conclusions.

The results for patients with secondary sleep disorders are also unclear as there was too much statistical heterogeneity in the data to make a firm conclusion. The removal of the study by Shamir et al.^132^ would lead to conclusions that melatonin significantly reduces sleep onset latency, but there are no grounds for its exclusion as it is clinically similar to the other studies in all aspects except for method of measurement and a clear method of allocation concealment. Thus, we can give no real statement as to the effect of melatonin on sleep onset latency for these patients.

Sleep onset latency did not significantly change with melatonin in patients suffering from sleep restriction. This conclusion does not change when we analyze the data by type of sleep restriction (i.e. jet lag or shift work).

#### Sleep Efficiency

There was no significant difference in sleep efficiency between patients with a primary sleep disorder taking either melatonin or placebo. Unlike sleep onset latency, sleep efficiency did not change when we partitioned the studies into sleep phase syndrome patients and patients with insomnia. With heterogeneity substantial in both cases, we can say that there is no evidence that sleep efficiency is changed by melatonin in these patients.

Melatonin had the strongest effect on sleep efficiency among patients with secondary sleep disorders; our results show a statistically significant increase in sleep efficiency with melatonin (about 1.9 percent), however, this effect appears to be clinically insignificant.

There was no effect of melatonin on sleep efficiency in patients suffering from sleep restriction.

#### Other Outcomes

There was no evidence that melatonin affects sleep quality, wakefulness after sleep onset (WASO), or percentage time spent in REM sleep for any of the three sleep disorder groups.

There is evidence that total sleep time is increased with melatonin in individuals suffering from a secondary sleep disorder and those suffering from sleep restriction. There was, however, no evidence of any change in total sleep time in patients with primary sleep disorders.

Which populations based on gender, age, ethnicity, and co-morbid conditions would benefit most from treatment with melatonin?

#### Gender

No information could be obtained regarding the effect of melatonin on sleep disorder patients by gender. All studies but one were a mixed population and a breakdown of data by gender was not available in any of them. The one exception^80^ was an all female study of children with Rett syndrome and the results of this one study were non-significant with respect to both sleep onset latency and sleep efficiency.

#### Age

For patients with primary sleep disorders, there is some evidence that sleep onset latency is reduced more in children (up to 17 years) than in adults (18–65 years) or elderly patients (greater than 65 years). The one study involving children showed a significant reduction in sleep onset latency with melatonin while the studies involving adults and the elderly did not show this overall reduction, despite the presence of studies showing a highly significant reduction of sleep onset latency in this latter category. In terms of sleep efficiency, however, both the studies involving adults and the elderly showed non-significant differences between melatonin and placebo (there were no studies involving children that examined sleep efficiency).

There is no evidence that sleep onset latency is reduced more in children than in adults in studies involving individuals with secondary sleep disorders; none of the studies involving elderly with secondary sleep disorders examined sleep onset latency. Although the three studies involving children showed a significant reduction in sleep onset latency while the three studies involving adults did not, the confidence intervals are fully overlapping. In terms of sleep efficiency, there was no evidence of any differences among the three groups. Although the two studies involving elderly subjects showed a significant difference, they actually had the smallest point estimate. Similar to sleep onset latency, the three confidence intervals are fully overlapping.

No comparisons could be made by age for patients suffering from sleep restriction since all studies examined adult subjects.

#### Ethnicity

Ethnicity was generally not mentioned in any of the studies. Only two studies stated that their patients were all Caucasian. These two studies both involved individuals with primary sleep disorders and did show a significant reduction in sleep onset latency.

#### Co-Morbid Conditions

Regarding the studies involving subjects with secondary sleep disorders, the only co-morbid condition reported in more than one study was schizophrenia, which was present in two studies.^131^ ^132^ The other studies involved patients with different conditions: Rett syndrome,^80^ tuberous sclerosis,^81^ developmental disabilities,^82^ depression,^125^ dementia,^78^ and Alzheimer's disease;^135^ the first three studies involved children, the study by Serfaty et al. ^125^ involved adults, while the last two studies involved the elderly (the two studies by Shamir involved adults). Based on these other differences, it is difficult to discern the effects of melatonin solely by co-morbid condition. We can say that the study that involved children with tuberous sclerosis did show a significant reduction in sleep onset latency with melatonin (WMD: -23.4 min; 95 percent CI: --45.2, -1.6) and the study that involved elderly patients with Alzheimer's showed a significant increase in sleep efficiency with melatonin (WMD: 2.0 percent; 95 percent CI: 0.1, 3.9). It is difficult, however, to draw any conclusions from these results.

What is the appropriate dosage/duration of administration of melatonin for the treatment of sleep disorders? Does the appropriate dosage depend on patients' gender, age, and/or ethnicity?

#### Dosage

We categorized dosage according to the following levels: <1 mg, 1–3 mg, 4–5 mg, 6–10 mg, >10 mg. Among patients with a primary sleep disorder, there was no obvious effect of dose on the outcome of sleep onset latency or sleep efficiency. The point estimate of difference in sleep onset latency increased in magnitude with increasing dosage, while the point estimate of sleep efficiency decreased in magnitude with increasing dosage, but all confidence intervals for both outcomes were overlapping and non-significant.

The breakdown by dosage for patients with a secondary sleep disorder is also inconclusive; all confidence intervals were overlapping and non-significant for both sleep onset latency and sleep efficiency. With only two dosage groups for each outcome, no trends were detectable.

The breakdown of the studies involving sleep restriction also showed no discernable effect of dosage; all confidence intervals were overlapping and non-significant and no trend was detectable. There was no evidence of a dose effect on sleep onset latency or sleep efficiency for subjects suffering from sleep restriction.

A further subdivision by age, gender, or ethnicity was not possible in any of the sleep disorder subgroups due to lack of data.

#### Duration of Administration

When studies involving sleep disorders were subdivided by duration of administration (i.e., <1 week, 1–2 weeks, 3–4 weeks), there was no apparent melatonin effect with respect to either sleep onset latency or sleep efficiency. The results were generally the same (i.e. overlapping confidence intervals) regardless of the duration.

There were no data for subjects suffering from sleep restriction, as all studies were approximately the same duration.

What is the timing of melatonin administration during the sleep/wake cycle that would produce optimal treatment effects?

Without exception, every sleep disorder study administered melatonin to its patients just before they went to bed. As a result there is no information on effect of timing of melatonin administration.

How do different formulations of melatonin differ with respect to effectiveness?

There was insufficient information on melatonin formulations in the sleep disorder studies to allow us to do any subgroup analysis by formulation.

What are the adverse effects of short and long-term use of melatonin?

Thirty-four studies were relevant to this question of the review. The overall quality of these studies was assessed using the Downs and Black Checklist.^115^ The overall quality of studies ranged from 12 to 26 on a 29-point scale; one study had a score of 12,^144^ 13 studies had a score between 16 and 20,^27^ ^60^ ^61^ ^63–65^ ^81^ ^92^ ^94^ ^124^ ^145–147^ 19 studies had a score between 21 and 25^54^ ^66^ ^68^ ^69^ ^71^ ^74^ ^76^ ^78^ ^80^ ^82^ ^90^ ^95^ ^129^ ^130^ ^143^ ^148–151^ and one study had a score of 26.^67^ The quality of reporting ranged from five to 11 on an 11-point scale; two studies had a score of five or six,^63^ ^144^ 15 studies had a score between seven and nine^27^ ^61^ ^64–66^ ^68^ ^76^ ^80–82^ ^92^ ^94^ ^145–147^ and 17 studies had a score between 10 and 11.^54^ ^60^ ^67^ ^69^ ^71^ ^74^ ^78^ ^90^ ^95^ ^124^ ^129^ ^130^ ^143^ ^148–151^ The external validity of studies ranged from zero to three; most studies had a score of one, eight studies had a score of two,^63^ ^66^ ^74^ ^80^ ^82^ ^130^ ^145^ ^151^ four studies had a score of three,^54^ ^67^ ^90^ ^143^ and six studies had a score of zero.^78^ ^94^ ^95^ ^146^ ^147^ ^149^ The quality of internal validity ranged from five to 12 on a 13-point scale; most studies had a score between nine and 11; one study had a score of five,^144^ one study had a score of eight,^27^ one study had a score of 10,^151^ and two studies had a score of 12.^54^ ^130^ A power calculation for the primary outcome was reported for eight studies;^66–68^ ^76^ ^78^ ^82^ ^143^ ^150^ four of these had sufficient power to detect a clinically important effect where the probability value for a difference being due to chance is less than 5 percent,^66–68^ ^150^ while four others did not.^76^ ^78^ ^82^ ^143^ A power calculation was not provided for one study, but it had sufficient power to detect a clinically important effect where the probability value for a difference being due to chance is less than 5 percent.^63^ See Evidence Table C-3 for a description of design characteristics and overall quality scores of studies relevant to this question of the review.

Primary Analysis. There were few reports of adverse events accompanying melatonin administration. The most common adverse events reported were headaches, dizziness, nausea and drowsiness. In all cases there was no significant differences found between melatonin and placebo despite tight confidence intervals.

There were a total of 33 studies with information on headaches. There was no difference between placebo and melatonin (Risk Difference: 0.00; 95 percent CI: -0.02, 0.02) and heterogeneity was minimal (I^2^: 0 percent) (Figure 3-16). The results were similar for dizziness (32 studies; RD: 0.00; 95 percent CI: -0.02, 0.02; I^2^: 0 percent) (Figure 3-17), nausea (33 studies; RD: 0.00; 95 percent CI: -0.02, 0.01; I^2^: 0 percent) (Figure 3-18) and drowsiness (34 studies; RD: 0.00; 95 percent CI: -0.01, 0.02; I^2^: 0 percent) (Figure 3-19).

Figure 16. Meta-Graph: Headaches

Figure 17. Meta-Graph: Dizziness

Figure 18. Meta-Graph: Nausea

Figure 19. Meta-Graph: Drowsiness

Subgroup and Sensitivity Analyses. Analyses were performed on the safety outcomes for the following subgroups: gender, age, use of concurrent medications, dosage, duration, patient category, study design, quality score, and allocation concealment score. The homogeneity of the comparisons made all of these analyses irrelevant. For all outcome measures, the calculated risk difference was not significant and the point estimate was never more than a few percentage points from zero. Thus, no change was observed between melatonin and placebo in terms of headaches, dizziness, nausea or drowsiness for different doses of melatonin, type of sleep disorder (or lack thereof), duration of melatonin treatment, or for any other subgroup mentioned above.

Using the Fixed Effect Model in place of the Random Effects Model did not change any of the results due to the homogeneity of studies for all four outcomes.

A sensitivity analysis using only the studies where the specific outcome was mentioned was also performed, and still none of the results were significant. The point estimate for risk difference of headaches between melatonin and placebo included 14 studies and was just a fraction above zero and not significant (RD: 0.00; 95 percent CI: -0.04, 0.05). This estimate had moderate heterogeneity (I^2^: 33.9 percent). For dizziness, only four studies were included, and again the results were just above zero and non-significant (RD: 0.03; 95 percent CI: -0.03, 0.09) with moderate heterogeneity (I^2^: 36.8 percent). The nausea estimate included five studies and actually favoured melatonin (RD: -0.02; 95 percent CI: -0.05, 0.02), but was also not significant; the heterogeneity was negligible (I^2^: 0 percent). Finally, the drowsiness estimate included nine studies with non-significant results that favoured placebo (RD: 0.03; 95 percent CI: -0.05, 0.11). The heterogeneity for this last estimate was substantial (I^2^: 57.0 percent).

How do the harms of exogenous melatonin vary based on dose, timing of administration, and patient factors such as gender, age, and ethnicity? How do different formulations of melatonin differ with respect to safety?

There was insufficient information to answer this question in terms of timing of melatonin administration (all studies involved melatonin administration just before bed) and ethnicity (no studies reported information on ethnicity). The sub groupings for dose, gender, age, and formulation are provided in Tables 3-11, 3-12, 3-13 and 3-14 below. It is clear from these tables that there is no evidence that the adverse effects of melatonin change by gender, age, dose or formulation. This was to be expected as the primary analysis showed that the adverse effects of melatonin were quite minimal.

## Results of Qualitative Analysis

What are the various formulations of melatonin? How are the formulations different in terms of content, quality as well as safety and effectiveness? What is the clinical importance of any observed differences?

Eight studies were relevant to this question of the review. Three studies were relevant to the question relating to the effectiveness of melatonin in people with sleep disorders, ^58^ ^139^ ^152^ six studies were relevan to the question relating to the safety of melatonin ^63^ ^78^ ^80^ ^90^ ^130^ ^143^ and one study was relevant to both questions. ^90^ See Evidence Table C-4 for a description of study design characteristics and quality scores of studies relevant to this question of the review.

An immediate-release formulation was used in one study,^80^ a fast-release formulation was used in one study,^143^ a slow-release formulation was used in two studies,^57^ ^78^ and a controlled-release formulation was used in two studies.^90^ ^130^ Haimov et al. ^139^ compared slow-release and fast-release formulations and Suhner et al.^63^ compared fast-release and controlled-release formulations. The content and quality of the formulations used in the studies were not adequately described in the reports of these studies. Thus, the corresponding authors of these studies were contacted for additional information regarding the content and quality of the formulations. To summarize the information that is available, the controlled-release formulation used by Garfinkel et al. ^90^ was reported to be synthetic and 100 percent pure and the slow-release formulation used by Serfaty et al. ^78^ was also synthetic. The pharmacokinetics of the slow-release formulation used by Almeida-Montes et al.^57^ was also provided: melatonin concentrations in plasma begin to rise 30 minutes following its administration, attain maximal levels 60 minutes following its administration and reach a stable concentration 6 hours following its administration; release is sustained for 8 hours.^57^ Smits et al. (2003)^143^ and McArthur et al. (1998)^80^ reported that the formulations used in their studies contained carboxymethylcellulose and lactose filler, respectively. Given the paucity of information available to us regarding the details of the melatonin formulations used in the various studies relevant to this question of the review, an in-depth comparison of the content and quality of the various formulations that have been used to assess its effectiveness and safety is not possible.

As mentioned in the “Results of Quantitative Analysis” section above, there was insufficient information on the melatonin formulations used in studies involving individuals with sleep disorders to allow a subgroup analysis of the effect of formulation on the effectiveness of melatonin in the treatment of sleep disorders. However, a subgroup analysis of the effect of formulation on the safety of melatonin reveals a lack of evidence showing that the adverse effects of melatonin vary by formulation.

What is the pharmacology of exogenous melatonin, including pharmacokinetics and pharmacodynamics? How is it absorbed, distributed, metabolized, excreted? What blood levels are achieved? What is its half-life? Does it penetrate the blood brain barrier?

Twenty-six studies were relevant to this question of the review. The quality of these studies was assessed using the Downs and Black Checklist^115^ with the exception that the power of the studies to detect a clinically important difference was not assessed. The overall quality score ranged from eight to 21 on a 29-point scale; one study had a score of eight,^153^ 10 studies had a score between 10 and 15,^133^ ^134^ ^154–161^ 14 studies had a score between 16 and 20,^94^ ^127^ ^162–173^ and one study had a score of 21.^137^ The quality of reporting ranged from five to nine on an 11-point scale; most studies had a score between seven and nine and six studies had a score of five or six.^133^ ^134^ ^153^ ^156^ ^159^ ^164^ Most studies had a score of zero on a three-point scale for external validity and two studies had a score of two.^137^ ^170^ The internal validity of studies ranged from three to 11 on a 13-point scale; most studies had a score between seven and nine; five studies had a score between three and six,^133^ ^134^ ^153^ ^158^ ^159^ and six studies had a score of 10 or 11.^64^ ^137^ ^162^ ^167^ ^168^ ^170^ See Evidence Table C-5 for a description of design characteristics, overall quality scores, and results of studies relevant to this question of the review.

Regarding the pharmacology of exogenous melatonin, the formulation used in the studies was often not reported. Melatonin was administered orally in most studies. The timing of melatonin administration varied across studies, although in many cases, melatonin was administered in the morning. The use of co-medication by study participants was often not specified, and in some cases, participants suffered from a sleep disorder (Evidence Table C-5). Thus, the conditions of the intervention, the characteristics of the population, and the quality of reporting varied across studies relevant to this question of the review, which precluded quantitative pooling of results. Thus, we provide a qualitative synthesis of the evidence pertaining to the pharmacokinetics of exogenous melatonin. The half-life of exogenous melatonin ranged from 0.54 hours (h) to 2h and most studies reported a value between 0.54h and 0.8h. The peak concentration of melatonin achieved in the blood ranged from 14.75pg/ml to 64 730 pg/ml, which reflected a dose range of 0.003mg to 75mg. The time required to reach peak values ranged from 0.25h to 13h and most studies reported a value between 0.5h and 1.0h. The period over which the area under the melatonin versus time curve was calculated varied across studies, precluding both a quantitative and qualitative synthesis of the evidence pertaining to this outcome.

Of the studies that met eligibility criteria for any of the questions of the review involving administration of exogenous melatonin to study participants, none provided a thorough examination of the dose-response relationship of exogenous melatonin with respect to the sleep-related outcomes analyzed in this review. Thus, information on the pharmacodynamics of exogenous melatonin was not available.

Only one study^155^ was identified which examined pharmacokinetic characteristics of exogenous melatonin in cerebrospinal fluid (CSF). In this study, a patient with an external CSF drainage device was examined; drainage was required due to a shunt infection. Five milligrams of melatonin was administered at 20:00h. A rapid rise in melatonin levels in the CSF was evident beginning 10 minutes after its administration and melatonin concentrations in CSF peaked within 80 minutes following its administration. The levels of melatonin in CSF declined rapidly over a period of 5 hours.^155^ This study provides evidence that exogenous melatonin penetrates the blood-brain-barrier.

The mechanism by which melatonin is absorbed, distributed, metabolized, and excreted in man was not described in the studies that met inclusion criteria for this question of the review.

What is the evidence linking endogenous melatonin to sleep cycles?

A study was considered relevant to this question of the review if it involved an intervention that altered endogenous melatonin levels or the sleep cycle, such as a manipulation of light/dark exposure or the sleep schedule, and it examined either melatonin levels in blood, urine, saliva or CSF or an aspect of the sleep cycle, depending on which intervention was used. That is, if the study intervention was designed to manipulate endogenous melatonin, then it was necessary that the study examine the effect of this manipulation on an aspect of the sleep cycle, and vice-versa. These criteria allow for an understanding of the relationship between endogenous melatonin and the sleep cycle via an assessment of the effect of manipulation of one variable on the other.

Forty-four studies were relevant to this question of the review. The overall quality scores, according to the Down's and Black Checklist, ranged from eight to 23 on a 29-point scale; most studies had a score between 16 and 20, one study had a score of eight,^174^ 13 studies had a score between 10 and 15^175–187^ and one study had a score of 23.^188^ The quality of reporting ranged from three to nine on an 11- point scale; most studies had a score between eight and nine inclusive, three studies had a score between three and five^174^ ^176^ ^180^ and 17 studies had a score between six and seven.^175^ ^178^ ^181–187^ ^189–196^ The internal validity of the studies ranged from zero to three on a three-point scale; most studies had a score of zero, seven studies had a score of one,^128^ ^191^ ^194^ ^197–200^ one study had a score of two^188^ and one study had a score of three.^189^ The internal validity of studies ranged from five to 12 on a 13-point scale; most studies had a score between seven and nine; three studies had a score of five or six;^174^ ^177^ ^180^ three studies had a score of 10 or 11^195^ ^201^ ^202^ and one study had a score of 12.^188^ For most studies, a power calculation was not reported, however, for one study, a power calculation was reported and the study had sufficient power to detect a statistically significant effect where the probability value for a difference being due to chance was less than 5 percent.^203^ See Evidence Table C-6 for a description of design characteristics and overall quality scores of studies relevant to this question of the review.

One of three types of interventions was employed in the studies relevant to this question of the review: manipulation of light/dark exposure, manipulation of the sleep schedule and administration of a tryptophan-free mixture. Here, we provide the results of a qualitative analysis of evidence surrounding the relationship between endogenous melatonin and the sleep cycle according to the various interventions that have been used to manipulate one of the variables of this relationship.

### Intervention: manipulation of light/dark exposure

Manipulation of light/dark exposure is designed to alter endogenous melatonin levels. The studies that employed this intervention can be categorized as those involving normal sleepers, people with a sleep disorder and people with a disorder that may or may not be accompanied by a sleep disorder. For most studies, a comparison was made between the effects of light of different intensities on endogenous melatonin and the sleep cycle, with the light of lower intensity serving as a control. The levels of light intensity varied widely across studies, such that a comparison of “bright” and “dim” light involved very different light levels across studies. Here, we use “brighter” to denote the light of higher intensity and “dimmer” to denote the light of lower intensity, for studies in which a comparison was made between the effects of light of different intensities, in order to highlight the fact that these light levels were relative and do not necessarily indicate “bright” or “dim” light in absolute terms.

Normal sleepers. The nature, magnitude, duration and timing of the light stimulus intervention varied across studies. Most studies involved direct application of light of different intensities,^128^ ^176^ ^183^ ^191^ ^194^ ^199^ ^204–209^ while others involved application of these signals within the context of a workstation,^192^ dawn simulation^179^ or video display terminal.^182^ Most studies compared the effect of brighter light to the effect of dimmer light,^128^ ^176^ ^179^ ^182^ ^183^ ^191^ ^192^ ^194^ ^199^ ^204–209^while one study compared the effect of light exposure of long duration (16h) to light exposure of short duration (10h),^187^ and another compared the effect of evening versus morning brighter light administration.^199^ The magnitude of the light stimuli ranged from 0.1 lux to 300 lux for the dimmer light condition and 45 lux to 11000 lux for the brighter light condition, and the duration of light stimuli application ranged from three hours to 36 hours, over hours to weeks. The timing of light administration varied from early morning to late night. Most studies involved ocular light administration, while one study involved extra-ocular light administration applied to the bend of the knee.^128^ Some studies involved application of light stimuli under conditions of prolonged sleep deprivation.^183^ ^192^ ^194^ ^204^ ^206^ ^209^ (Evidence Table C-6)

In the case of studies in which ocular light stimuli were administered in the evening or night, brighter light (BL) tended to suppress endogenous melatonin levels,^176^ ^182^ ^183^ ^191^ ^192^ ^194^ ^205^ ^206^ relative to dimmer light (DL) and one study found a delay in the phase of the melatonin rhythm.^204^ The reduction in endogenous melatonin levels with BL was accompanied by no change in^194^ or increased^205^ sleep onset latency, a smaller and delayed accumulation of REM sleep^176^ and increased REM latency^176^ and NREM period length,^176^ without a change in REM cycle and REM period length.^176^ The suppression of endogenous melatonin levels was also accompanied by increased alertness and performance in some studies,^183^ ^191^ ^206^ while others found no effect of BL on these variables.^182^ ^192^ ^194^ In some studies, the suppression of endogenous melatonin levels and/or the alerting response in the presence of BL only occurred in the early night.^183^ ^206^ In the study in which bright light resulted in a delay of the melatonin rhythm, sleep onset was delayed as well.^204^ (Table 19)

Table 19. Effect of Manipulation of Light/Dark Exposure on Endogenous Melatonin and the Sleep Cycle in Normal Sleepers: Manipulation during Evening or Night

Study | Endogenous Melatonin | Sleep Cycle | Assessment of Correlation
Bunnell, 1992 | ↓ endogenous MLT levels | ↑ REM latency and NREM period length, ≠ REM cycle and period length | Not conducted
Burgress, 2001 | ↓ endogenous MLT levels | ↑ SOL | Not conducted
Cajochen, 2000 | ↓ endogenous MLT levels | ↑ alertness and performance | Positive correlation was found between changes
Daurat, 1996 | ↓ endogenous MLT levels | ↑ alertness and performance | Not conducted
Dollins, 1993 | ↓ endogenous MLT levels | ≠ alertness and performance | Not conducted
Higuchi, 2003 | ↓ endogenous MLT levels | ≠ alertness and performance | Not conducted
Horne, 1991 | ↓ endogenous MLT levels | ↑ alertness and performance | Not conducted
Kubota, 2002 | Delayed MLT rhythm | Delayed sleep onset | No correlation was found between changes
Lavoie, 2003 | ↓ endogenous MLT levels | ≠ SOL, ≠ alertness and performance | None of the vigilance variables were found to correlate to endogenous MLT levels.

Abbreviations: MLT: melatonin, SOL: sleep onset latency, REM: rapid eye movement, NREM: non-REM, ↑: increased ↓: decreased, ≠: no change in

Three studies involved ocular BL administration during the morning or daytime.^179^ ^207^ ^208^ Ocular BL resulted in a phase advance of the melatonin rhythm^179^ ^207^ and a suppression of endogenous melatonin levels, ^179^ ^208^ relative to DL. In a study by Dijk et al., the advance in the melatonin rhythm was accompanied by a reduction in sleep duration and REM sleep, relative to DL;^207^ REM latency, percent time spent in the various sleep stages and sleep quality were unaffected by BL, relative to DL.^207^ In two studies, the suppression of endogenous melatonin levels with BL was accompanied by increased alertness, relative to DL.^179^ ^208^ (Table 20)

Table 21. Effect of Manipulation of Light/Dark Exposure on Endogenous Melatonin and the Sleep Cycle in Normal Sleepers: Manipulation Involves Unique Conditions

Study | Endogenous Melatonin | Sleep Cycle | Assessment of Correlation
Daurat, 1997 | ≠ endogenous MLT levels | ≠ TST, REM latency, WASO and REM sleep | Not conducted
Gordijn, 1999 | ↓ endogenous MLT, ≠ phase of MLT rhythm | ↑ movement time, ↓ duration of first REM episode, delayed sleep termination, ≠ sleep latency and REM latency | Not conducted
Lushington, 2002 | ≠ endogenous MLT levels or phase of MLT rhythm | ↑ wakefulness | Not conducted
Wehr, 1991 | ↓ duration of nocturnal endogenous MLT | ↓ sleep period | Not conducted

Abbreviations: MLT: melatonin, TST: total sleep time, REM: rapid eye movement, WASO: wakefulness after sleep onset, ↑: increased ↓: decreased, ≠: no change in

Table 20. Effect of Manipulation of Light/Dark Exposure on Endogenous Melatonin and the Sleep Cycle in Normal Sleepers: Manipulation During Morning or Daytime

Study | Endogenous Melatonin | Sleep Cycle | Assessment of Correlation
Danilenko, 2000 | Advance of MLT rhythm, ↓ endogenous MLT levels | ↑ alertness, | Phase of MLT rhythm was correlated to sleepiness and mid-point of sleep
Dijk, 1989 | Advance of MLT rhythm | ↓ sleep duration and REM sleep, ≠ REM latency, percent time spent in various sleep stages and sleep quality | No correlation between phase of MLT rhythm, and sleep duration
Wakamura, 2000 | ↓ endogenous MLT levels | ↑ alertness | Not conducted

Abbreviations: MLT: melatonin, REM: rapid eye movement, ↑: increased, ↓: decreased, ≠: no change in

In a study by Gordijn et al. in which the effects of morning and evening ocular light exposure were compared, evening light exposure resulted in suppression of endogenous melatonin levels compared to morning light exposure, although the phase of endogenous melatonin was not affected.^199^ The changes in endogenous melatonin with evening light exposure were accompanied by greater “movement time”, shorter duration of the first REM episode, later time of sleep termination and no change in sleep latency and REM latency, compared to morning BL exposure.^199^ In a study by Wehr et al., exposure to a longer photoperiod resulted in a reduction in the duration of the nocturnal endogenous melatonin rhythm, duration of the sleep period and the nocturnal phase of increasing sleepiness, compared to exposure to a shorter photoperiod.^187^ Similarly in a study by Daurat et al., light exposure or a light/dark cycle were administered for 36 hours during sleep deprivation and no difference was found in endogenous melatonin levels or in total sleep time, REM latency, WASO and REM sleep.^209^ In a study by Lushington et al. in which light stimuli were administered behind the knee, BL did not affect endogenous melatonin, however, it resulted in increased wakefulness, relative to DL.^128^ (Table 13-17)

Five of the studies included in this analysis conducted an analysis of the correlation between endogenous melatonin and the sleep cycle.^179^ ^191^ ^194^ ^204^ ^207^ In the study by Kubota et al., no correlation was found between change in phase of the melatonin rhythm and change in sleep onset with BL administration,^204^ while in the study by Cajochen et al., the alerting response to BL was positively correlated with the degree of suppression of endogenous melatonin levels by BL.^191^ Similarly, in the study by Danilenko et al.,^179^ the phase of the melatonin rhythm was correlated to sleepiness and midpoint of sleep, while in the study by Dijk et al., no correlation was found between phase of the melatonin rhythm and sleep duration.^207^ Lastly, in the study by Lavoie et al., none of the vigilance variables were found to correlate to endogenous melatonin levels.^194^ (Tables 3-15, 3-16, 3-17)

Table 18. Subgroup Analysis: Drowsiness

Subgroup | Categorization | Number of studies | Risk Difference | 95 percent Confidence Interval | Heterogeneity | Deeks' Chi-Square p-value
Gender | Male | 3 | 0.19 | -0.21, 0.60 | Substantial (I^2^: 76.6 percent) | NA
| Female | 2 | 0.00 | -0.07, 0.07 | Negligible (I^2^: 0 percent)
Age | Children | 5 | 0.00 | -0.06, 0.06 | Negligible (I^2^: 0 percent) | 1.00
| Adult | 24 | 0.00 | -0.02, 0.02 | Negligible (I^2^: 0 percent)
| Elderly | 6 | 0.01 | -0.04, 0.05 | Negligible (I^2^: 0 percent)
Dosage | 1–3 mg | 8 | -0.01 | -0.06, 0.04 | Negligible (I^2^: 0 percent) | NA
| 4–5 mg | 13 | 0.00 | -0.03, 0.03 | Negligible (I^2^: 0 percent)
| 6–10 mg | 9 | 0.01 | -0.04, 0.05 | Negligible (I^2^: 0 percent)
| > 10 mg | 2 | 0.32 | -0.37, 1.01 | Substantial (I^2^: 86.4 percent)
Formulation | Fast Release | 2 | -0.07 | -0.19, 0.06 | Negligible (I^2^: 0 percent) | NA
| Slow Release | 4 | -0.01 | -0.06, 0.04 | Negligible (I^2^: 0 percent)

Abbreviations: NA: not applicable

Table 15. Subgroup Analysis: Headaches

Subgroup | Categorization | Number of studies | Risk Difference | 95 percent Confidence Interval | Heterogeneity | Deeks' Chi-Square p-value
Gender | Male | 3 | 0.04 | -0.13, 0.19 | Negligible (I^2^: 0 percent) | NA
| Female | 2 | 0.00 | -0.07, 0.07 | Negligible (I^2^: 0 percent)
Age | Children | 6 | -0.02 | -0.08, 0.03 | Negligible (I^2^: 0 percent) | 0.74
| Adult | 22 | 0.00 | -0.02, 0.03 | Negligible (I^2^: 0 percent)
| Elderly | 5 | 0.00 | -0.06, 0.06 | Negligible (I^2^: 0 percent)
Dosage | 1–3 mg | 8 | 0.00 | -0.05, 0.04 | Negligible (I^2^: 0 percent) | NA
| 4–5 mg | 14 | 0.00 | -0.03, 0.04 | Minimal (I^2^: 18.9 percent)
| 6–10 mg | 9 | 0.00 | -0.04, 0.04 | Negligible (I^2^: 0 percent)
| > 10 mg | 2 | 0.00 | -0.20, 0.20 | Negligible (I^2^: 0 percent)
Formulation | Fast Release | 3 | -0.06 | -0.14, 0.02 | Negligible (I^2^: 0 percent) | NA
| Slow Release | 4 | 0.00 | -0.05, 0.05 | Negligible (I^2^: 0 percent)

Abbreviations: NA: not applicable

Table 16. Subgroup Analysis: Dizziness

Subgroup | Categorization | Number of studies | Risk Difference | 95 percent Confidence Interval | Heterogeneity | Deeks' Chi-Square p-value
Gender | Male | 2 | 0.00 | -0.19, 0.19 | Negligible (I^2^: 0 percent) | NA
| Female | 2 | 0.00 | -0.07, 0.07 | Negligible (I^2^: 0 percent)
Age | Children | 6 | 0.02 | -0.04, 0.08 | Negligible (I^2^: 0 percent) | 1.00
| Adult | 21 | 0.00 | -0.02, 0.02 | Negligible (I^2^: 0 percent)
| Elderly | 5 | 0.00 | -0.06, 0.06 | Negligible (I^2^: 0 percent)
Dosage | 1–3 mg | 8 | 0.00 | -0.04, 0.05 | Negligible (I^2^: 0 percent) | NA
| 4–5 mg | 14 | 0.00 | -0.02, 0.03 | Negligible (I^2^: 0 percent)
| 6–10 mg | 7 | 0.00 | -0.04, 0.04 | Negligible (I^2^: 0 percent)
| > 10 mg | 2 | 0.00 | -0.20, 0.20 | Negligible (I^2^: 0 percent)
Formulation | Fast Release | 3 | 0.05 | -0.04, 0.15 | Minimal (I^2^: 14.6 percent) | NA
| Slow Release | 4 | 0.00 | -0.05, 0.05 | Negligible (I^2^: 0 percent)

Abbreviations: NA: not applicable

Table 17. Subgroup Analysis: Nausea

Subgroup | Categorization | Number of studies | Risk Difference | 95 percent Confidence Interval | Heterogeneity | Deeks' Chi-Square p-value
Gender | Male | 2 | 0.00 | -0.19, 0.19 | Negligible (I^2^: 0 percent) | NA
| Female | 2 | 0.00 | -0.07, 0.07 | Negligible (I^2^: 0 percent)
Age | Children | 6 | -0.02 | -0.08, 0.03 | Negligible (I^2^: 0 percent) | 0.81
| Adult | 21 | 0.00 | -0.02, 0.02 | Negligible (I^2^: 0 percent)
| Elderly | 5 | 0.00 | -0.06, 0.06 | Negligible (I^2^: 0 percent)
Dosage | 1–3 mg | 8 | 0.00 | -0.03, 0.03 | Negligible (I^2^: 0 percent) | NA
| 4–5 mg | 14 | -0.01 | -0.04, 0.02 | Negligible (I^2^: 0 percent)
| 6–10 mg | 9 | 0.00 | -0.04, 0.03 | Negligible (I^2^: 0 percent)
| > 10 mg | 2 | 0.00 | -0.20, 0.20 | Negligible (I^2^: 0 percent)
Formulation | Fast Release | 3 | -0.02 | -0.08, 0.03 | Negligible (I^2^: 0 percent) | NA
| Slow Release | 4 | 0.00 | -0.04, 0.05 | Negligible (I^2^: 0 percent)

Abbreviations: NA: not applicable

### People with a Sleep Disorder

A number of studies in this category examined the relationship of endogenous melatonin and the sleep cycle and these differed in many aspects of study design. Many studies involved shift workers,^174^ ^178^ ^190^ ^193^ ^195^ ^210^ ^211^ while others involved people with delayed sleep phase syndrome^188^ ^189^ or people who suffer from jet-lag.^197^ Most studies involving night-shift workers employed light stimuli during the night-shift,^174^ ^178^ ^190^ ^193^ ^210^ ^211^ although one study employed the stimuli, after the night-shift.^195^ While most studies involved application of light stimuli while participants were awake, one study involved administration of light stimuli during sleep, through closed eyelids.^188^ All studies involved direct application of brighter or dimmer/control light stimuli, and while most studies compared brighter versus dimmer light effects on endogenous melatonin and the sleep cycle,^174^ ^178^ ^188–190^ ^193^ ^195^ ^197^ ^210^ one study examined the effect of the frequency of light stimulation on these variables.^211^ The intensity of the light stimuli ranged from 0.1 lux to 1500 lux for dimmer/control light administration and 660 lux to 12 000 lux for BL administration. The duration of application of light stimuli ranged from two to 12 hours, over hours to weeks. (Evidence Table C-6)

In the case of studies involving administration of light stimuli to night-shift workers during the night shift and comparing BL to DL/control, many studies found that BL resulted in a greater phase delay in endogenous melatonin from baseline measurements compared to dimmer light/control.^174^ ^193^ ^210^ While one study found a suppression of endogenous melatonin levels with BL administration, compared to DL administration,^190^ another study found no change in endogenous melatonin levels following BL administration, compared to DL administration.^178^ Of the studies that reported alterations in endogenous melatonin with BL administration, the effects of BL on the sleep cycle were varied. While one study reported no effect of BL on sleep start time and sleep wake time,^193^ another reported no effect of BL on total sleep time,^190^ and yet another study reported greater sleep time and sleep continuity and no change in sleep latency with BL administration.^210^ While most studies found that BL increased alertness and performance,^174^ ^190^ ^193^ ^210^ another did not find such an effect.^178^ In a study by Ross et al., light stimuli were administered for 2h daily for one week after night shift work; the DL group readapted slightly, but faster than the BL group after the night shift. Moreover, the BL exposure resulted in a reduction in sleep latency but had no effect on sleep duration, sleep quality, night awakenings or mood, compared to DL exposure.^190^ In a study by Boulos et al, participants were administered light stimuli on the first two evenings after a flight from Zurich to New York. Although BL treatment resulted in a greater delay in endogenous melatonin secretion compared to DL, there were no differences between the two groups in sleep efficiency, sleep quality, daytime sleepiness, jet-lag severity or mood.^197^ In another study involving night-shift and examining the effect of various cycles of light exposure on endogenous melatonin and the sleep cycle, 3 or 5 cycles of BL administration were not different in their effects on the phase of the melatonin rhythm nor on sleep quality, performance, or subjective feelings of tiredness.^211^ (Table 22)

Table 22. Effect of Manipulation of Light/Dark Exposure on Endogenous Melatonin and the Sleep Cycle in People with Sleep Disorders

Study | Endogenous Melatonin | Sleep Cycle | Assessment of Correlation
Ando, 1999 | ≠ phase of MLT rhythm | ≠ total sleep period, total sleep time and sleep quality | Not conducted
Bougrine, 1995 | ≠ phase of MLT rhythm | ≠ sleep quality, performance and subjective feelings of tiredness | Not conducted
Boulos, 2002 | Delay in MLT rhythm | ≠ sleep efficiency, sleep quality, daytime sleepiness, jet-lag severity or mood | No correlation was found between phase of MLT rhythm and performance
Budnick, 1995 | ↓ endogenous MLT | ≠ total sleep time, ↑ alertness and performance | Not conducted
Cole, 2002 | ≠ phase of MLT rhythm | ≠ mood, total sleep time, sleep quality, morning sleepiness | Not conducted
Costa, 1997 | ≠ endogenous MLT levels | ≠ alertness and performance | Not conducted
Horowitz, 2001 | Delay in MLT rhythm | ≠ sleep start time and wake time, ↑ alertness and performance | Not conducted
Kelly, 1997 | Delay in MLT rhythm | ↑ sleep time and continuity, ≠ sleep latency, ↑ alertness and performance | Not conducted
Ross, 1995 | Not explicitly stated | ↓ sleep latency, ≠ sleep duration, sleep quality, night awakenings and mood | Not conducted
Yoon, 2000 | Delay in MLT rhythm | ↑ alertness and performance | Not conducted

Abbreviations: MLT: melatonin, ↑: increased ↓: decreased, ≠: no change in

Two studies involving application of light stimuli to individuals with delayed sleep phase syndrome found no effect of BL on the phase of the endogenous melatonin rhythm nor on mood,^188^ ^189^ total sleep period,^189^ total sleep time,^188^ ^189^ morning sleepiness,^197^ or sleep quality,^188^ relative to DL. (Table 22)

In the study by Boulos et al., no correlation was found between dim light melatonin onset and performance following the BL intervention.^197^ (Table 22)

People with a Disorder that may or may not be Accompanied by a Sleep Disorder.

Two studies examined the effect of light on individuals with seasonal affective disorder (SAD) and found no effect of BL on either levels^203^ or timing^201^ of endogenous melatonin secretion, compared to DL. These results were accompanied by a lack of effect of BL on mood,^201^ alertness,^201^ sleepiness,^203^ total sleep duration,^201^ time of awakening,^201^ and sleep onset,^201^ compared to DL. In a similar study, BL resulted in a greater phase advance of endogenous melatonin compared to DL and this effect was accompanied by an earlier tendency for sleep termination and no change in accumulation of wakefulness.^212^ In the study by Gordijn et al., no correlation was found between changes in phase of endogenous melatonin and wake-up time.^212^ (Table 23)

Table 23. Effect of Manipulation of Light/Dark Exposure on Endogenous Melatonin and the Sleep Cycle in People with a Disorder that may or may not be Accompanied by a Sleep Disorder

Study | Endogenous Melatonin | Sleep/Wake Cycle | Assessment of Correlation
Gordijn, 1998 | Advance of MLT rhythm | Earlier tendency for sleep termination | No correlation was found between phase of MLT rhythm and wake-up time
Koorengevel, 2001 | ≠ phase of MLT rhythm | ≠ mood, alertness, total sleep duration, time of awakening and sleep onset | Not conducted
Partonen, 1996 | ≠ endogenous MLT levels | ≠ sleepiness | Not conducted

Abbreviations: MLT: melatonin, ↑: increased, ↓: decreased, ≠: no change in

#### Intervention: manipulation of the sleep schedule

Manipulation of the sleep schedule is designed to affect the sleep cycle. The majority of studies in this category examined the effect of alterations in the sleep schedule in normal sleepers,^177^ ^180^ ^181^ ^184^ ^186^ ^198^ ^200^ ^202^ ^213–217^ although one study examined the effect of this type of intervention on both normal sleepers and depressed individuals (who may have an accompanying sleep disorder).^185^ While many studies assessed the effect of prolonged sleep deprivation on endogenous melatonin,^181^ ^185^ ^198^ ^202^ ^213^ ^214^ ^216^ others assessed the effect of partial sleep deprivation,^200^ sleep restriction^177^ ^180^ or sleep period advance/delay^184^ ^186^ ^215^ ^217^ on endogenous melatonin. (Evidence Table C-6)

The results of the various studies in this category are inconsistent. For example, of the studies examining the effect of prolonged sleep deprivation on normal sleepers, endogenous melatonin was found to increase in some studies,^198^ ^214^ decrease in another study^202^ or remain unchanged in other studies^181^ ^185^ ^213^ ^216^ during or after periods of sleep deprivation. In a study by Redwine et al., sleep deprivation of normal sleepers during the early night did not affect endogenous melatonin levels during either the early or late parts of the night.^200^

Of the studies examining the effect of sleep restriction regimens on endogenous melatonin, one study examined the effect of timing of napping in darkness on endogenous melatonin and found that morning napping resulted in a phase delay of endogenous melatonin, while afternoon napping did not affect the phase of endogenous melatonin.^177^ In a similar study, the sleep restriction regimen involved either a short nap during the night or a short nap during the night accompanied by a short nap during the late afternoon. The sleep restriction conditions resulted in a phase delay of endogenous melatonin with continued elevation of melatonin levels at the end of the nocturnal secretory phase.^180^ It is important to note that changes in napping patterns would change patterns of light exposure, which itself, could have affected endogenous melatonin in these studies, depending on the timing of naps in relation to the endogenous melatonin rhythm.

Four studies examined the effect of sleep period advance/delay on endogenous melatonin.^184^ ^186^ ^215^ ^217^ In a study by Weibel et al., day-active study participants were subjected to an acute shift of their sleep period to daytime; endogenous melatonin was not affected by this shift.^215^ Jelinkova-Vondrasova et al. reported a phase advance of one hour within six days of the endogenous melatonin rhythm following a three hour advance of the sleep period and a phase delay of one hour in six days following a subsequent three hour delay of the sleep period.^184^ In a similar study, when the sleep/wake cycle was shortened by one hour per day, the melatonin rhythm did not achieve complete adjustment within the period of investigation, and when the time shift was reversed by a seven hour delay within two days, resynchronization was achieved satisfactorily only within seven days.^186^ In a study by Danilenko et al, a two-hour phase advance of the sleep period resulted in a small advance in the endogenous melatonin rhythm.^217^

#### Intervention: administration of a tryptophan-free mixture

In these types of studies, administration of a tryptophan-free mixture was designed to reduce endogenous melatonin levels. In a study by Arnulf et al., administration of a tryptophan-free mixture mid-morning, which resulted in reduced serum tryptophan, did not alter endogenous melatonin levels, mood, sleep latency, total sleep time, total sleep duration, duration of wakefulness after sleep onset, stages one-two and three to four of NREM sleep and REM sleep, but did result in increased REM latency.^175^

#### Summary: Endogenous melatonin and the sleep/wake cycle

To summarize, our literature review indicated a link between endogenous melatonin and the sleep cycle. A key result was that a decrease in endogenous melatonin levels was often accompanied by increased latency to sleep and decreased duration of sleep, as well as increased vigilance and performance during waking hours. In addition, changes in the rhythm of endogenous melatonin were often accompanied by changes in the sleep rhythm.

What are the basic mechanisms by which melatonin produces sleepiness?

None of the studies identified through our search met our initial inclusion criteria for this question of the review, namely, that the study characterize and/or evaluate a mechanism by which melatonin produces sleepiness in humans. Thus, the inclusion criteria for this question of the review were revised; a study was considered relevant to this question of the review if it fulfilled the inclusion criteria of the question relating to the effect of melatonin in normal sleepers and the question relating to the effect of melatonin in people with sleep disorders, and the report provided a proposed mechanism by which melatonin produces sleepiness, based on findings of the study. Eleven studies met the revised inclusion criteria for this question of the review. See Evidence Table C-7 for a description of study design characteristics and overall quality scores of these studies.

The mechanisms by which melatonin induces sleepiness in humans have not been fully elucidated. However, a number of hypotheses exists: the mechanism may involve a phase-shift of the endogenous circadian pacemaker, a reduction in core body temperature and/or a direct action on somnogenic areas of the brain. Studies of the effects of melatonin in humans have led to postulates of the mechanism of action of melatonin that either favour or refute one or a number of the current hypotheses of the mechanism by which melatonin promotes sleepiness.

A number of investigators that have been involved in studies of the effect of melatonin on people with sleep disorders have supported the notion that melatonin induces sleepiness through a re-entrainment of the endogenous circadian pacemaker and not through a direct action on somnogenic structures of the brain.^65^ ^74^ ^152^ In one case, this conclusion was based on findings that melatonin advanced sleep onset time without increasing sleep duration,^74^ while in another case it was based on findings that melatonin did not affect polysomnographic and subjective measures of sleep quality^152^ and in yet another case was based on findings that melatonin did not affect sleep duration.^65^ By contrast, others have proposed that the sleep-inducing effects of melatonin may not be mediated by a shift of the endogenous circadian oscillator and may be due to direct actions of the hormone, based on findings that melatonin improved the quality of sleep and increased its duration without affecting either sleep onset time or sleep latency.^70^ Andrade et al. have concluded that melatonin is not a sedative/hypnotic, based on findings that evening melatonin administration advanced sleep onset without producing drowsiness or hangover effects the next day.^54^ Edwards et al. drew the same conclusion based on the finding that melatonin had no significant effect on the ease of getting to sleep or the number of waking episodes in jet-lag sufferers.^218^

A number of investigators that have been involved in studies of the effect of melatonin on normal sleepers have supported the hypothesis that melatonin promotes sleepiness via a direct action on somnogenic structures of the brain.^92^ ^123^ ^219^ ^220^ Zhdanova et al. proposed that their findings of decreased sleep onset latency and latency to stage two sleep with evening administration of melatonin is mediated by a direct action of melatonin rather than via a biological timing mechanism.^220^ In a study by Terlot et al.,^219^ afternoon administration of melatonin resulted in increased feelings of sleepiness, fatigue and confusion and decreased feelings of vigor and concentration, leading the investigators to argue that since the effects of afternoon administration of melatonin were similar to those observed with comparable doses administered at noon or in the evening, the effects of melatonin are not-time dependent and, therefore, may not be mediated by a phase-shifting effect on the endogenous circadian clock.^219^ In a study by Matsumoto et al., morning administration of melatonin was found to increase sleep duration in diurnal sleep, without affecting rectal temperature during this sleep. Based on these results, the investigators suggested that melatonin has a direct hypnotic effect on diurnal sleep.^92^ Satomura et al. supported the latter notion based on findings that daytime administration of melatonin resulted in increased sleep duration and efficiency and, in the case of the higher dose of melatonin, a lack of a hypothermic effect.^123^

In a study by Mishima et al., morning administration of 9 mg of melatonin to normal sleepers had a hypnotic effect, while 3 mg of melatonin did not have this effect. However, both doses induced the same degree of body temperature suppression and the hypnotic effect of exogenous melatonin was sustained during a period when serum melatonin levels and body temperature had returned to physiological values. These findings led the investigators to support the hypothesis that the sleep-inducing action of melatonin is likely not mediated by suppression of body temperature.^221^ In a study by Holmes et al., afternoon administration of melatonin to normal sleepers resulted in a reduction in sleep onset latency and an accompanying decrease in core body temperature, leading the investigators to suggest that the sleep-promoting property of melatonin may involve modulation of core body temperature.^222^

How is endogenous melatonin involved in circadian rhythms?

The scope of this question was limited to an analysis of how endogenous melatonin is involved in the temperature rhythm. The analysis of evidence relevant to this question was approached in a similar manner as for the question relating to the link between endogenous melatonin and the sleep cycle, in that we addressed the link between endogenous melatonin and the temperature rhythm. A study was considered relevant to this question of the review if it involved an intervention that altered endogenous melatonin levels or the temperature rhythm, such as a manipulation of light/dark exposure or body temperature, and it examined either melatonin levels in blood, urine, saliva or CSF or an aspect of the temperature rhythm, depending on which of these variables was manipulated. Thus, if the study intervention was designed to manipulate endogenous melatonin, then it was necessary that the study examine the effect of this manipulation on an aspect of the temperature rhythm, and vice-versa. These criteria allow for an understanding of the relationship between endogenous melatonin and the temperature rhythm via assessment of the effect of manipulation of one variable on the other.

Twenty-four studies were relevant to this question of the review. The overall quality score, based on the Downs and Black Checklist, ranged from 11 to 19 on a 29-point scale; most studies had a score between 16 and 19 and eight studies had a score between 11 and 15.^176^ ^178^ ^179^ ^182^ ^183^ ^223–225^ The quality of reporting ranged from five to nine on an 11-point scale; one study had a score of 5,^176^ 11 studies had a score of six or seven^178^ ^182^ ^183^ ^189^ ^191^ ^193^ ^194^ ^223–226^ and 12 studies had a score between eight and nine.^128^ ^179^ ^199^ ^204–206^ ^208–210^ ^212^ ^227^ ^228^ The external validity of studies ranged from zero to three on a three-point scale; most studies had a score of zero, four studies had a score of one^128^ ^191^ ^194^ ^199^ and one study had a score of three.^189^ The internal validity of studies ranged from five to nine on a 13-point scale; most studies had a score of eight or nine, two studies had a score of five or six^179^ ^224^ and two studies had a score of seven.^176^ ^225^ None of the studies relevant to this question of the review reported a power calculation or addressed whether the study had sufficient power to detect a clinically significant effect where the probability value for a difference being due to chance was less than 5 percent. See Evidence Table C-8 for a description of design characteristics and overall quality scores of studies relevant to this question of the review.

One of two types of interventions was employed in the studies relevant to this question of the review: manipulation of light/dark exposure or manipulation of body temperature. Here, we provide the results of a qualitative analysis of evidence surrounding the relationship between endogenous melatonin and the temperature rhythm according to the interventions that have been used to manipulate one of the variables of this relationship.

#### Intervention: manipulation of light/dark exposure

The studies that employed this intervention can be categorized as those involving normal sleepers, people with a sleep disorder and people with a disorder that may or may not be accompanied by a sleep disorder. For most studies, a comparison was made between the effects of light of different intensities on endogenous melatonin and the temperature rhythm, with the light of lower intensity serving as a control. The levels of light intensity varied widely across studies, such that a comparison of “bright” and “dim” light involved very different light levels across studies. Here, we use “brighter” to denote the light of higher intensity and “dimmer” to denote the light of lower intensity, for studies in which a comparison was made between the effects of light of different intensities, in order to highlight the fact that these light levels were relative and do not necessarily indicate “bright” or “dim” light in absolute terms.

Normal Sleepers. The nature, magnitude, duration and timing of the light stimulus intervention varied across studies. Most studies involved direct application of brighter (BL) or dimmer (DL) stimuli,^128^ ^176^ ^183^ ^191^ ^194^ ^199^ ^204–206^ ^208^ ^209^ ^223–225^ ^228^ while others involved application of these signals within the context of dawn simulation^179^ or a video display terminal.^182^ Most studies compared the effect of BL to DL,^128^ ^176^ ^179^ ^182^ ^183^ ^191^ ^194^ ^199^ ^204–206^ ^208^ ^223–225^ ^228^ while one study compared the effect of evening versus morning BL administration.^199^ The magnitude of the light stimuli ranged from 0.1 lux to 200 lux for DL administration and 45 lux to 13 000 lux for BL administration and the duration of light stimuli application ranged from 2 to 36 hours, over hours to weeks. The timing of light administration varied from early morning to late night. Most studies involved ocular light administration,^176^ ^179^ ^182^ ^183^ ^191^ ^194^ ^199^ ^204–206^ ^208^ ^209^ ^223^ ^225^ ^228^ while two studies involved extra-ocular light administration applied to the bend of the knee.^128^ ^224^ Some studies involved application of light stimuli under conditions of prolonged sleep deprivation.^183^ ^194^ ^204^ ^206^ ^209^ ^224^ ^225^ ^228^ (Evidence Table C-8)

Most studies involved application of light stimuli during the evening or night,^128^ ^176^ ^182^ ^183^ ^191^ ^194^ ^204–206^ ^223–225^ while some studies involved light exposure during the morning or night,^199^ morning,^179^ daytime^208^ or during a prolonged period of sleep deprivation.^209^ ^228^ Of the studies involving application of ocular light stimuli during the evening or night, some studies found that BL delayed the onset of endogenous melatonin secretion, relative to DL^204^ ^223^ and all studies found that BL suppressed endogenous melatonin levels, relative to DL. The delay in the phase of the melatonin rhythm was accompanied by a delay in the core body temperature rhythm in one study,^204^ while the change in phase of the melatonin rhythm was not accompanied by a change in the value or timing of the core body temperature minima in another study.^223^ Of the studies that found a suppression of endogenous melatonin levels with BL, many studies found an accompanying increase in core body temperature,^176^ ^182^ ^194^ ^205^ ^206^ while one study found no change in core body temperature.^191^ In a study by Strassman et al., the suppression of endogenous melatonin levels was accompanied by an increase in minimum rectal temperature and no change in the maximum rectal temperature,^225^ while in a study by Daurat et al., the suppression of endogenous melatonin levels was accompanied by a reduction and delay in the temperature minimum.^206^ In studies by Horne et al. and Bunnell et al., the suppression of endogenous melatonin was not accompanied by any change in oral temperature^183^ or tympanic temperature.^176^ In a study by Wright et al., whereby light exposure occurred during a 45-hour period of sleep deprivation, BL resulted in suppression of endogenous melatonin levels accompanied by increased body temperature, relative to DL.^228^ In a similar study by Daurat et al., whereby either BL or a light/dark cycle were imposed on subjects for 36 hours during sleep deprivation, there were no differences in endogenous melatonin levels between conditions. However, during one of the follow-up nights, the BL group showed increased rectal temperature compared to the light/dark group, although the phase of the temperature rhythm was not different.^209^ In a study by Lushington et al., BL administered behind the knee during the daytime did not have an effect on endogenous melatonin or the phase of nocturnal core body temperature, relative to DL administration.^128^ In a similar study, extra-ocular light exposure in the evening did not affect either the phase of the melatonin rhythm or core body temperature.^224^ In a study by Gordijn et al., the application of light stimuli in the evening resulted in the suppression of endogenous melatonin levels during the early evening, without a change in the phase of the melatonin rhythm, compared to morning light exposure. This effect was accompanied by increased body temperature without a change in the phase of the temperature rhythm.^199^ In a study by Wakamura et al., ocular light stimuli were administered during the daytime and resulted in a suppression of endogenous melatonin levels, which was accompanied by a reduction in minimum core body temperature, no change in maximum core body temperature and an advance of the core body temperature rhythm.^208^ (Table 24)

Table 24. Effect of Manipulation of Light/Dark Exposure on Endogenous Melatonin and the Sleep Cycle in Normal Sleepers: Manipulation During Evening or Night

Study | Endogenous Melatonin | Temperature Rhythm | Assessment of Correlation
Bunnell, 1992 | ↓ endogenous MLT levels | ↑ core body temperature, ≠ tympanic temperature | Not conducted
Burgress, 2001 | ↓ endogenous MLT levels | ↑ core body temperature | Not conducted
Cagnacci, 1993 | Delayed MLT rhythm, ↓ endogenous MLT levels | ≠ value or timing of core body temperature minima | Not conducted
Cajochen, 2000 | ↓ endogenous MLT levels | ≠ core body temperature | Not conducted
Daurat, 1996 | ↓ endogenous MLT levels | ↑ core body temperature, reduced and delayed temperature minima | Not conducted
Eastman, 2000 | ≠ MLT rhythm | ≠ core body temperature | Not conducted
Higuchi, 2003 | ↓ endogenous MLT levels | ↑ core body temperature | Not conducted
Horne, 1991 | ↓ endogenous MLT levels | ≠ oral temperature | Not conducted
Kubota, 2002 | Delayed MLT rhythm, ↓ endogenous MLT levels | Delay in core body temperature minima | No correlation was found between the change in phase of MLT rhythm and temperature rhythm
Lavoie, 2003 | ↓ endogenous MLT levels | ↑ core body temperature | Not conducted
Lushington, 2002 | ≠ endogenous MLT levels or rhythm | ≠ nocturnal core body temperature rhythm | Not conducted
Strassman, 1991 | ↓ endogenous MLT levels | ↑ minimal rectal temperature, ≠ maximal rectal temperature | Not conducted

Abbreviations: MLT: melatonin, ↑: increased ↓: decreased, ≠: no change in

In a study by Danilenko et al., morning BL exposure suppressed endogenous melatonin levels, and the phase shift in the melatonin rhythm (DLMOn and DLMOff) was correlated with the phase shift in the temperature rhythm.{Danilenko, Wirz-Justice, et al. 2000 #22510} By contrast, in a study by Kubota et al., a correlation was not found between the change in phase of the melatonin rhythm and that of the temperature rhythm, following BL administration.^204^ (Table 25)

Table 25. Effect of Manipulation of Light/Dark Exposure on Endogenous Melatonin and the Sleep Cycle in Normal Sleepers: Manipulation Involved Unique Conditions

Study | Endogenous Melatonin | Temperature rhythm | Assessment of Correlation
Danilenko, 2000 | ↓ endogenous MLT levels, shift in MLT rhythm | Shift in temperature rhythm | Shifts in MLT rhythm and temperature rhythm were correlated
Daurat, 1997 | ≠ endogenous MLT | ↑ rectal temperature, ≠ phase of temperature rhythm | Not conducted
Eastman, 2000 | ≠ phase of MLT rhythm | ≠ core body temperature | Not conducted
Gordijn, 1999 | ↓ endogenous MLT levels, ≠ phase of MLT rhythm | ↑ body temperature, ≠ phase of temperature rhythm | Not conducted
Lushington, 2002 | ≠ endogenous MLT levels | ≠ phase of core body temperature rhythm | Not conducted
Wakamura, 2000 | ↓ endogenous MLT levels | ↓ minimum core body temperature, ≠ maximum core body temperature, advance of the core body temperature rhythm | Not conducted
Wright, 1997 | ↓ endogenous MLT levels | ↑ body temperature | Not conducted

Abbreviations: MLT: melatonin, ↑: increased, ↓: decreased, ≠: no change in

People with a Sleep Disorder. A number of studies in this category involved shift workers,^178^ ^193^ ^210^ while another study involved people with delayed sleep phase syndrome.^189^ In the case of all studies involving night-shift workers, light stimuli were administered during the night-shift,^178^ ^189^ ^193^ ^210^ and in the case of the study involving people with delayed sleep phase syndrome light stimuli were administered in the early morning.^189^ The magnitude of the light stimuli ranged from 0.1 lux to 300 lux for dim/control light administration and 400 lux to 4300 lux for BL administration. The duration of light stimuli application ranged from 4 periods of 40-minute exposures to an entire night-shift, over hours to days. All studies involved ocular light administration. (Evidence Table C-8)

Of the studies involving night-shift work,^178^ ^193^ ^210^ BL delayed the melatonin rhythm in two studies^193^ ^210^ and had no effect on endogenous melatonin levels in another study,^178^ relative to DL. Moreover, while the delay in the melatonin rhythm was accompanied by a phase delay in core body temperature in one study,^193^ it was not accompanied by a change in the temperature rhythm in another study.^210^ The lack of effect of BL on endogenous melatonin levels, relative to DL, in the study by Costa et al., was paralleled by a lack of effect on the temperature rhythm.^178^ (Table 26)

Table 26. Effect of Manipulation of Light/Dark Exposure on Endogenous Melatonin and the Sleep Cycle in People with a Sleep Disorder

Study | Endogenous Melatonin | Temperature rhythm | Assessment of Correlation
Ando, 1999 | ≠ MLT rhythm | ≠ temperature rhythm | Not conducted
Costa, 1997 | ≠ endogenous MLT levels | ≠ temperature rhythm | Not conducted
Horowitz, 2001 | Delay MLT rhythm | Delay of core body temperature rhythm | Not conducted
Kelly, 1997 | Delay MLT rhythm | ≠ temperature rhythm | Not conducted

Abbreviations: MLT: melatonin, ↑: increased, ↓: decreased, ≠: no change in

In a study by Ando et al., patients with delayed sleep phase syndrome received either 500 lux for three hours over 12 days prior to awakening or 0.1 lux of the same timing. BL had no significant effect on the phase of either the melatonin or temperature rhythm, compared to DL.^189^

People with a Disorder that may or may not be Accompanied by a Sleep Disorder. One study involved application of either morning or evening light to people with non-seasonal depression. Morning administration of light resulted in a phase advance of both the melatonin and temperature rhythms compared to evening light administration.^212^ Moreover, no correlation was found between the shifts in the phase of the melatonin and temperature rhythms.^212^

#### Intervention: manipulation of body temperature

In a study by Fletcher et al., participants were exposed to heat of 32V, 138W from 0230h until termination of the sleep period. Heating induced an increase in core body temperature, without an effect on endogenous melatonin levels.^227^ In a similar study, participants were exposed to light of different color temperature and the light of higher color temperature was found to increase core body temperature and decrease endogenous melatonin levels.^226^

#### Summary: Endogenous melatonin and the temperature rhythm

To summarize, our literature review indicated evidence of a link between endogenous melatonin and the temperature rhythm. Specifically, a reduction in endogenous melatonin levels was often accompanied by an increase in core body temperature, and a shift in the rhythm of endogenous melatonin was often accompanied by a similar shift in the rhythm of core body temperature.

How do the benefits and harms of melatonin compare to those of other approved pharmacological treatments for sleep disorders?

Only four studies compared the effects of melatonin to other pharmacological treatments for sleep disorders in terms of sleep variables; three of these involved normal sleepers^123^ ^222^ ^229^ and one of these involved people suffering from jet-lag.^61^ The overall quality score, according to the Down's and Black Checklist, ranged from 11 to 20 on a 29-point scale and the quality of reporting ranged from four to eight on an 11-point scale. The external validity of studies ranged from zero to one on a three-point scale; two studies had a score of zero^123^ ^229^ and two studies had a score of one.^222^ ^230^ The internal validity of studies ranged from seven to 11 on a 13-point scale; two studies had a score of seven,^123^ ^229^ one study had a score of eight^222^ and one study had a score of 11.^61^ For none of the studies was a power calculation reported. See Evidence Table C-9 for a description of design characteristics and overall quality scores of studies relevant to this question of the review.

Of the studies involving normal sleepers, two studies compared the effects of melatonin and triazolam,^123^ ^229^ while another study compared the effect of melatonin and zopiclone,^222^ on sleep variables. In a study by Satomura et al., participants received either 1, 3 or 6 mg melatonin or 0.125 mg triazolam at 13:30h; there were no differences in the effect of the two agents on total sleep time, sleep efficiency, and REM latency. Melatonin decreased sleep onset latency to a greater extent than triazolam, however, the effect of these compounds on sleep onset latency was not significantly different from placebo. The authors did not report on adverse events or adverse effects of the two agents, precluding a comparison of the harms of these agents.^123^ In a similar study by Ferini-Strambi et al., participants received either 100 mg melatonin or 0.125 mg triazolam at 22:30h; there were no differences in the effect of the two agents on total sleep time, sleep onset latency, wakefulness after sleep onset, sleep efficiency, number of awakenings, percent time spent in the various sleep stages, REM latency and REM periods. As in the study by Satomura et al., the authors did not report on adverse effects of the two agents, precluding a comparison of the harms of these agents.^229^ In a study by Holmes et al., normal sleepers received either 5mg melatonin or 7.5mg zopiclone at 14:00h and sleep onset latency was assessed hourly from 11:00h to 20:00h using a modified multiple sleep latency test. Zopiclone reduced sleep onset latency to a greater extent than melatonin at 15:00h and from 17:00h to 19:00h. The authors did not report on adverse events or adverse effects of the two agents.^222^

In a study comparing melatonin and zolpidem, air travellers, crossing six to nine time-zones, received either 5mg melatonin or 10mg zolpidem on an eastbound return flight to Switzerland and once daily at bedtime on four consecutive days after the flight.^61^ The agents did not differ in their effects on total sleep time, sleep latency, number of awakenings, wakefulness after sleep onset and overall sleep quality during the flight. Moreover, the agents did not differ in overall sleep quality, sleep onset latency, number of awakenings and wakefulness after sleep onset across the four nights following the flight. When subjects were asked to rate the effectiveness of their study medication in alleviating jet-lag, the responses did not differ between agents. In general, out of the 35 people taking melatonin, only one person reported adverse events, while six people out of 34 people taking zolpidem reported adverse events. The individual taking melatonin who reported adverse events suffered from insomnia and palpitations. Of the individuals taking zolpidem who reported adverse events, four people reported nausea, two people reported vomiting, two people reported confusion, one person reported dizziness, two people reported headache, one person reported lack of concentration, one person reported amnesia, one person reported trembling, one person reported agitation, one person reported palpitation, one person reported difficulties in articulation and one person reported dry mouth.^61^

##### Overall Grade of Evidence Pertaining to Effectiveness and Safety of Melatonin

The source of funding was either not reported or unclear for the majority of studies relevant to the questions relating to the effectiveness of melatonin in people with sleep disorders and the safety of melatonin. Of the studies for which the source of funding was described, most studies received public sources of funding. For studies in which there was a discrepancy in the number of participants enrolled in the study and the number of participants for whom data was analyzed, the planning or conduct of an intention-to-treat analysis was reported in only two studies relevant to the question relating to the effectiveness of melatonin in people with sleep disorders ^78^ ^144^ and two studies relevant to the question relating to the safety of melatonin.^78^ ^135^ The overall evidence surrounding the effectiveness of melatonin for treatment of sleep disorders and the safety of melatonin was graded using the framework of the Oxford Centre for Evidence-based Medicine (Table 27). The evidence surrounding the effectiveness of melatonin for the treatment of sleep disorders receives a grade of “A” and a level of evidence designation of “1b”. The evidence surrounding the safety of melatonin receives a grade of “B” and a level of evidence designation of “2b”.

Table 27. Oxford Centre for Evidence-based Medicine Levels of Evidence

Grade of Recommendation | Level of Evidence | Therapeutic Use
A | 1a | SR (with homogeneity) of RCTs
| 1b | Individual RCT (with Narrow Confidence Interval)
| 1c | All or none
B | 2a | SR (with homogeneity) of cohort studies
| 2b | Individual cohort study (including low quality RCT; e.g., .80 percent follow-up)
| 2c | “Outcomes Research”
| 3a | SR (with homogeneity) of case-control studies
| 3b | Individual case control study
C | 4 | Case series (and poor quality cohort and case-control studies)
D | 5 | Expert opinion without explicit critical appraisal, or based on physiology, bench research or “first principles”

Abbreviations: SR: systematic review, RCT: randomized controlled trial

Adapted from http://minerva.minervation.com/cebm/documents/levels_cebm_23nov99.rtf