# Methods

## Research Team

The research team designated to this Task Order was selected to represent the diverse areas of expertise required to properly elucidate the topic of the review and has both basic and clinical science expertise. The areas of expertise encompassed by the research team include melatonin and pineal cell biology, sleep, complementary and alternative medicine (CAM), neurochemistry, pharmacology, physiology, as well as systematic review methodology. The research team consists of a Core Research Team, which has been involved in the day-to-day operations required to fulfill the Task Order, as well as a Technical Expert Panel (TEP), which has functioned in an advisory capacity. The Core Team consists of two Task Order Leaders with expertise in clinical pharmacology, clinical epidemiology, pediatrics and CAM (Dr. Sunita Vohra) and pharmacology/neurochemistry (Dr. Glen Baker); the Evidence-based Practice Centre (EPC) Director (Dr. Terry Klassen), Associate Director (Dr. Brian Rowe) and Administrative Director (Ms. Lisa Hartling) with expertise in systematic review methodology; and a Project Manager (Dr. Nina Buscemi) and Staff. The Core Team has met on a regular basis to plan the approach for fulfilling the Task Order and to ensure that project activities were conducted in an appropriate and timely manner.

The TEP is multi-disciplinary in nature and has provided the breadth of expertise required to produce a comprehensive Evidence Report on the use of melatonin for the treatment of sleep disorders. During the course of the project, a total of 15 individuals have joined the TEP. Members of the TEP have been consulted during the course of the project, as required, for specific input and guidance, according their particular area of expertise. See Appendix D * for affiliations and areas of expertise of TEP members.

* The Appendixes and Evidence Tables cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/melatntp.htm.

In addition to the individuals mentioned above, the Core Research Team maintained regular communication and dialogue with representatives of the National Center of Complementary and Alternative Medicine (NCCAM) as well as the Task Order Officer of the Agency for Healthcare Research and Quality (AHRQ).

## Methods for the Systematic Review

### Overview

The methods of the University of Alberta Evidence-based Practice Centre (UAEPC) were used to conduct a systematic review and synthesis of evidence relevant to the questions of the review. A number of steps were followed in producing this Evidence Report:

- Comprehensive Search
- Development of Inclusion Criteria
- Study Selection
- Assessment of Study Quality
- Data Extraction
- Data Analysis

### Comprehensive Search

As a first step, a number of biomedical databases were searched. Given the subject area of the review, there was a possibility that these databases would not provide accurate representation of the breadth of research in this area. Thus, our intention was to conduct preliminary searches of these databases, assess publication bias, and if it were found across studies relevant to the questions of the review pertaining to the effectiveness of melatonin in the treatment of sleep disorders, we would expand our search accordingly. Table 2 outlines the electronic databases that were searched and Table 3 outlines the keywords and subject headings that were used in the searches. See Appendix A * for a detailed description of the search strategy.

* The Appendixes and Evidence Tables cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/melatntp.htm.

Table 2. Biomedical Databases Searched

Database | Platform | Dates of Search
MEDLINE® | Ovid | 1982 to June Week 4, 2003
Cochrane Central Register of Controlled Trials | Ovid | 3^rd^ Quarter, 2003
Science Citation Index | ISI Web of Knowledge | July 4, 2003
Biological Abstracts | SilverPlatter version 4.3 | July 4, 2003
International Pharmaceutical Abstracts | OVID | 1970 to August, 2003
NLM® Gateway | http://gateway.nlm.nih.gov/gw/Cmd | August 13, 2003
OCLC Papers First and Proceedings First | OCLC FirstSearch | July 11, 2003
TOXLINE | CSA Internet Database Service | July 4, 2003

Table 3. Keywords and Subject Headings used in Searches

melatonin | restless legs syndrome
melatonine | nocturnal eating (drinking) syndrome
5-methoxy-N-acetyltryptamine | time-zone change syndrome
N-(2-(5-methoxy-1H-indol-3-yl)ethyl)acetamide | Jet lag
N-acetyl-5-methoxytryptamine | parasomnias
3-(2-acetamidoethyl)-5-methoxyindole | confusional arousals
Acetamide, N-(2-(5-methoxy-1H-indol-3-yl)ethyl)-(9CI) | rhythmic movement disorder
Acetamide, N-(2-(5-methoxyindol-3-yl)ethyl)-, N-(2-(5-methoxyindol-3-eyl)ethyl)acetamide, CAS Reg No: 73-31-4 | nocturnal leg cramps
luzindole | nightmares
sleep | nocturnal paroxysmal dystonia
sleep disorders | sudden unexplained nocturnal death syndrome
dyssomnias | snoring
insomnia | congenital central hypoventilation syndrome
narcolepsy | sudden infant death syndrome
hypersomnia | subwakefulness syndrome
central alveolar hypoventilation syndrome | fragmentary myoclonus
periodic limb movement disorder | terrifying hypnagogic hallucinations
circadian

Literature searches were limited to English-language reports of studies on human subjects, with no restrictions applied for age, gender or ethnicity. We searched for reports of phase 1 and 2 clinical trials; phase 3 and 4 randomized clinical trials; quasi-randomized controlled trials; prospective cohorts; case series; registry data; as well as narrative and systematic reviews. In addition to these initial searches, similar searches of MEDLINE® and EMBASE were conducted periodically for more recently published studies that were potentially relevant to the review.

In addition to the electronic searches described above, the reference lists of a random sample of reports, encompassing half of all studies included in the review, were reviewed. The reference lists of narrative and systematic reviews related to melatonin and sleep disorders were also reviewed. We also reviewed the reference list of a Health Canada document on the use of melatonin for the treatment of various disorders as well the reference list of a document from Natural Standard Research Collaboration on the use of melatonin for the treatment of sleep disorders. Lastly, we hand-searched Associated Professional Sleep Society (APSS) Abstracts of 1999 to 2003.

As mentioned above, searches were limited to English-language reports. We sought to avoid the inclusion of non-English language reports in the review, unless deemed necessary, as a means of containing resource requirements for this review, which was already large in scope. The Core Team, in consultation with NCCAM and AHRQ, devised a strategy for inclusion of non-English language reports in the review. Our approach was to evaluate the presence of publication bias across studies relevant to the question of the review pertaining to the effectiveness of melatonin in the treatment of sleep disorders. If publication bias were found, we would expand our search to include non-English language data. We would also expand our search to include non-mainstream data sources. Publication bias refers to a bias in the literature whereby the publication of research is dependent upon the results of research. In Western medical journals, this phenomenon is reflected in the fact that results indicating no effect of an intervention are less likely to be published.^111^ The problem is reversed for CAM-related research, such that studies with negative results are more likely to be published in mainstream Western medical journals (e.g. “MEDLINE®”), and CAM studies with positive results are more likely to be published in smaller journals that may not be accessible on usual search engines.^112^ Thus, it was necessary to assess this bias across studies related to the effectiveness of melatonin included in this review. We considered the use of non-English language reports and expansion of data sources only for the latter question of the review, since this question related to the main thesis of the report.

### Development of Inclusion Criteria

Specific inclusion criteria were developed for each question of the review. In general, only controlled clinical trials were included for each question of the review, except for questions pertaining to the pharmacology of exogenous melatonin and the basic mechanism by which melatonin produces sleepiness. For the latter questions, uncontrolled clinical trials, case-series, cohort, cross-sectional and case-control studies were also included. For all questions of the review, the population of the study could include individuals of any age, gender, ethnicity and socioeconomic status; however, these individuals were required to be free of any type of sleep disorder in the case of the question relating to the effect of melatonin on normal sleepers, and to suffer from a sleep disorder in the case of the question relating to the effect of melatonin on people with sleep disorders. For questions pertaining to the administration of exogenous melatonin to a study population, any formulation, dosage, timing, frequency and duration of melatonin administration was acceptable; however, melatonin was required to be the primary intervention, and in the case of controlled trials, compared to placebo. In addition, a study was included for a particular question of the review if it analyzed at least one of the pre-determined outcomes relevant to that question. Only English-language reports were included in the review.

### Question-Specific Inclusion Criteria

What are the various formulations of melatonin? How are the formulations different in terms of content, quality as well as safety and effectiveness?

A study was considered relevant to the portion of this question that pertains to the differences in the safety of various formulations of melatonin if it met inclusion criteria for the question relating to the safety of melatonin, and the formulation of melatonin used in the study was specified in the report. A study was considered relevant to all other portions of this question if it met inclusion criteria for the question relating to the effectiveness of melatonin, and the formulation of melatonin used in the study was specified in the report.

What is the pharmacology of exogenous melatonin, including pharmacokinetics and pharmacodynamics? How is it absorbed, distributed, metabolized and excreted? What blood levels are achieved? What is its half-life? Does it penetrate the blood-brain barrier?

A study was considered relevant to this question of the review if it met the following inclusion criteria:

- it involved human participants
- melatonin was administered to a group of participants
- at least one of the following outcomes was assessed in participants' serum/plasma/blood within hours of melatonin administration and a value was ascribed to it in the text of the report:
  - - half-life of melatonin (t_1/2_)
  - - time to reach peak concentration of melatonin (T_max_)
  - - peak concentration of melatonin (C_max_)
  - - area under the melatonin versus time curve (AUC)

What is the evidence linking endogenous melatonin to sleep cycles?

A study was considered relevant to this question of the review if it met the following inclusion criteria:

- it was a controlled clinical trial
- it involved human participants
- it involved an intervention that altered either endogenous melatonin or the sleep cycle, such as manipulation of light/dark exposure or manipulation of the sleep schedule, respectively. If the intervention involved light administration, a lower intensity light condition was required as a control. If the intervention involved manipulation of the sleep schedule, a normal sleep schedule condition was required as a control.
- it involved only one intervention; a constant routine was not considered a secondary intervention if it was applied to both the experimental and control groups.
- it assessed the levels of melatonin and/or the phase of the melatonin rhythm in participants' blood, urine, saliva or cerebrospinal fluid in the case where the intervention altered the sleep cycle, or it assessed an aspect of participants' sleep cycle in the case where the intervention altered endogenous melatonin.

What are the basic mechanisms by which melatonin produces sleepiness?

Initially, a study was considered relevant to this question of the review if it met the following inclusion criteria:

- it involved human participants
- it involved administration of exogenous melatonin or an intervention that manipulated endogenous melatonin levels
- it characterized a mechanism by which alterations in endogenous melatonin levels affect sleep propensity

Given the lack of studies that met these inclusion criteria, the latter criteria were revised. A study was considered relevant to this question of the review if it met the inclusion criteria of the question relating to the effectiveness of melatonin in normal sleepers or the question relating to the effectiveness of melatonin in people with a sleep disorder, and the report provided a proposed mechanism by which melatonin produces sleepiness based on findings of the study.

What is the effect of exogenous melatonin on sleep latency, sleep efficiency and REM latency in normal sleepers?

A study was considered relevant to this question of the review if it met the following inclusion criteria:

- it was a controlled clinical trial
- it involved participants that did not have a sleep disorder
- melatonin was administered to a group of participants and placebo was administered to a group of participants
- at least one of the following outcomes was assessed:
- sleep onset latency
- sleep efficiency
- REM latency

How is endogenous melatonin involved in circadian rhythms?

The scope of this question was limited to an analysis of how endogenous melatonin is involved in the temperature rhythm. A study was considered relevant to this question of the review if it met the following inclusion criteria:

- it was a controlled clinical trial
- it involved human participants
- it involved an intervention that altered endogenous melatonin or the temperature rhythm, such as manipulation of light/dark exposure or temperature exposure, respectively. If the intervention involved light administration, a lower intensity light condition was required as a control. If the intervention involved manipulation of the temperature rhythm, a normal temperature condition was required as a control.
- it involved only one intervention; a constant routine was not considered a secondary intervention if it was applied to both the experimental and control groups.
- it assessed the levels of melatonin and/or the phase of the melatonin rhythm in participants' blood, urine, saliva or cerebrospinal fluid in the case where the intervention altered the temperature rhythm, or it assessed an aspect of participants' temperature rhythm in the case where the intervention altered endogenous melatonin.

What is the effect of exogenous melatonin on people with sleep disorders?

A study was considered relevant to this question of the review if it met the following inclusion criteria:

- it was a randomized controlled clinical trial
- it involved human participants who suffer from a sleep disorder and this condition was explicitly mentioned in the report
- melatonin was administered to a group of participants and placebo was administered to a group of participants
- at least one of the following outcomes was assessed:
  - - sleep onset latency
  - - sleep efficiency
  - - sleep quality
  - - wakefulness after sleep onset
  - - total sleep time
  - - percent time in REM sleep

Which sleep disorders would be most effectively managed by treatment with melatonin? Which populations based on gender, age, ethnicity, genetic factors and co-morbid conditions, would benefit most from treatment with melatonin?

What is the appropriate dosage/duration of melatonin for the treatment of sleep disorders? Does the appropriate dosage depend on patients' gender, age, and/or ethnicity? What is the timing of melatonin administration during the sleep/wake cycle that would produce optimal treatment effects?

A study was considered relevant to these questions of the review if it met the inclusion criteria for the question relating to the effectiveness of melatonin in people with sleep disorders, and the report provided the information necessary for the study to be incorporated into a subgroup analysis related to at least one variable specified in the question.

What are the adverse effects of short and long-term use of exogenous melatonin?

A study was considered relevant to this question of the review if it met the following inclusion criteria:

- it included human participants
- melatonin was administered to a group of participants and placebo was administered to a group of participants
- it reported on adverse events and/or adverse effects of the interventions

For this question of the review, short-term melatonin use was defined as less than three months duration and long-term melatonin use was defined as three months or greater duration.

How do the benefits and harms of exogenous melatonin vary based on dose, timing of administration, and patient factors such as gender, age and ethnicity?

A study was considered relevant to this question of the review if it met the inclusion criteria for the question relating to the safety of melatonin, and the report provided the information necessary for the study to be incorporated into a subgroup analysis related to at least one variable specified in the question.

How do the benefits and harms of melatonin compare to those of other approved pharmacological treatments for sleep disorders?

A study was considered relevant to this question of the review if it met the inclusion criteria for the question relating to the effectiveness of melatonin in normal sleepers and the question relating to the effectiveness of melatonin in people with sleep disorders, except that melatonin and another pharmacological treatment for sleep disorders, instead of placebo, were administered to groups of participants.

### Study Selection

The librarian removed all duplicates of the initial search results. In the first stage of study selection, the titles and abstracts of all potentially relevant articles were screened, independently, by two reviewers and classified as “relevant”, “clearly irrelevant” and “unclear”. A given article was considered “relevant” to the review if it was relevant to at least one key question of the review. The full text of all articles deemed “relevant” or “unclear” by each reviewer was retrieved. In the second stage of screening, the reviewers independently appraised the manuscripts using pre-determined inclusion criteria for each key question of the review. Only studies that met all inclusion criteria for a given question of the review, as determined by both reviewers, were considered relevant to that question. Disagreements among reviewers were resolved by discussion and consensus.

### Assessment of Study Quality

For the question pertaining to the effect of melatonin on people with sleep disorders, only randomized controlled trials were used as a source of evidence. Therefore, the Jadad Scale^113^ was used to assess the quality of studies relevant to this question. The Jadad Scale assigns studies a quality score of zero to five, with a score of five indicating high quality. The scale assesses the components of randomization, blinding and reporting of dropouts and withdrawals. To our knowledge, neither this scale nor any other has been validated for the quality assessment of crossover trials. However, this scale has been validated for the quality assessment of randomized-controlled trials, and thus, was considered an appropriate quality assessment tool for this review. The concealment of allocation in the randomized-controlled trials was assessed as “adequate”, “inadequate” and “unclear”.^114^ For all other questions of the review, which relied on evidence from studies of other designs in addition to randomized controlled trials, the Downs and Black Checklist^115^ was used to assess the quality of studies relevant to these questions. This checklist is partially validated and assesses a number of design components including reporting, internal and external validity, and the statistical power of a study to detect a clinically important difference. Two reviewers assessed study quality, independently, and disagreements were resolved by discussion and consensus. The overall quality of the evidence regarding the safety and effectiveness of melatonin in the treatment of sleep disorders was assessed using the framework developed by the Oxford centre for Evidence-Based Medicine. See Appendix B * for Quality Assessment Forms.

* The Appendixes and Evidence Tables cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/melatntp.htm.

### Data Extraction

Data were extracted from all reports of studies that were included in the review using a standardized Data Extraction Form. The type of information extracted from reports included details of study design and inclusion/exclusion criteria; details of the population such as gender, age, ethnicity and type of sleep disorder; the number of individuals that were eligible for, and enrolled in, the study; the number of comparison groups and participants allocated to each group; the number of participants who withdrew from the study; details of the intervention such as the formulation, dosage, timing, frequency and duration of melatonin administration as well as the type and frequency of usage of concurrent medication; and results obtained for pre-determined, question-specific outcomes.

Additional information that was extracted from reports included the name of the first author of the report and year of publication of the report; the country where the study took place; the source of funding for the study; authors' objectives and conclusions; and whether an intention-to-treat analysis was planned or performed. A trained reviewer extracted relevant data from a given report and a second reviewer verified the data that were extracted for that article for accuracy and completion. Disagreements between reviewers were resolved by discussion and consensus. See Appendix B * for the Data Extraction Form.

### Data Analysis

Table 4 outlines the keywords associated with the questions of the review and the type of analysis that was applied to data relevant to these questions. Data relevant to questions relating to the pharmacology of melatonin, the link between endogenous melatonin and the sleep and temperature rhythms, the mechanism of action of melatonin and the benefits and harms of melatonin compared to other pharmacological treatments for sleep disorders were analyzed qualitatively. All components of the question relating to the formulation of melatonin, except for the portion pertaining to the differences in the safety and effectiveness of melatonin formulations, were analyzed qualitatively. Data relevant to questions relating to the effectiveness, safety, and appropriate timing and duration of melatonin treatment were analyzed quantitatively.

Table 4. Questions of the Review and Type of Analysis Applied to Data Relevant to these Questions

Questions | Type of Analysis Applied to Data Relevant to Question
Formulations of melatonin | Qualitative and Quantitative
Pharmacology of melatonin | Qualitative
Endogenous melatonin and the sleep cycle | Qualitative
Mechanism of action of melatonin | Qualitative
Effect of melatonin on normal sleepers | Quantitative
Endogenous melatonin and circadian rhythms | Qualitative
Effectiveness of melatonin among types of sleep disorders | Quantitative
Effectiveness of melatonin among types of populations | Quantitative
Effect of melatonin on people with sleep disorders | Quantitative
Appropriate dosage of melatonin for treatment of sleep disorders | Quantitative
Appropriate timing of melatonin administration for treatment of sleep disorders | Quantitative
Adverse effects of melatonin | Quantitative
Adverse effects of melatonin as a function of dose, timing, and patient factors | Quantitative
Melatonin and other pharmacological treatments for sleep disorders | Qualitative

### Quantitative Analysis

For all continuous outcomes (e.g. sleep onset latency, sleep efficiency) studies were combined using a Weighted Mean Difference (WMD) with the exception of sleep quality where studies were combined using a Standardized Mean Difference (SMD). Due to the large number of studies with a crossover design, the Inverse Variance Method^116^ was used to weight the studies. An effectiveness estimate with corresponding 95 percent confidence interval was computed for each outcome.

We were usually able to calculate the effectiveness estimates for each study exactly (i.e. weighted mean difference, standardized mean difference, risk difference), but occasionally, estimates had to be made by extracting from graphs or using medians. Standard errors of the differences were calculated exactly from available data (i.e. individual patient data or exact p-values) whenever possible. For studies with a parallel design, this calculation was usually accomplished with the standard formula for variance of difference of independent variables: var(A-B) = var(A) + var(B). For studies with a crossover design, the standard error was estimated using the formula for variance of difference of dependant variables: var(A-B) = var(A) + var(B) -2ρ(var(A)var(B))^½^ and using a correlation estimate of 0.5. In cases where this calculation could not be done, standard errors were estimated using conservative p-values (i.e. p < 0.05), inter-quartile ranges, and extracting from graphs. As a last resort, an average of standard deviations of other studies was used to impute standard deviations of a study.

For studies with a parallel design, change from baseline data was used if available, otherwise final data were used. For studies with a crossover design, final data were always used.

When continuous data were presented for multiple conditions, which we wished to combine, a new mean and standard deviation were computed. If the study had a parallel design, the new mean and standard deviation could be computed exactly using the formula:

[image]

where [image] is the mean of the newly formed combined arm, g is the number of groups combined, [image]_i_ are the means of each group (i may take the value of 1 through g), s _y_ is the standard deviation of the newly formed combined arm, n _i_ are the sample sizes of each group, s _i_ are the standard deviations of each group and N is the total new sample size (the sum of the n _i_). If the study had a crossover design, we treated the data as we would a repeated measures experiment. The formula for the mean was the same, but the following formula was used for the standard deviation with the within subject correlation (ρ) being estimated as 0.5.

[image]

Dichotomous outcomes (i.e. safety outcomes) were combined using a Risk Difference with corresponding 95 percent confidence interval. Many studies stated that there were no reported adverse events. These were included in the analysis, but a sensitivity analysis excluding them was also performed, since the lack of reporting on adverse events does not necessarily indicate that they did not occur in the study.

All meta-analyses were performed using a Random Effects Model. Bailey^117^ suggests that the Random Effects Model is more appropriate when making recommendations for management and treatment of the next given patient. Fixed effects were considered in a sensitivity analysis.

All estimates of effectiveness (weighted mean differences, standardized mean differences, and risk differences) were assessed for heterogeneity using the I-squared statistic.^118^ Based on this statistic, heterogeneity for each outcome was classified as negligible (I^2^ = 0 percent), minimal (I^2^ < 20 percent), moderate (20 percent < I^2^ < 50 percent), or substantial (I^2^ > 50 percent). For our primary outcomes, heterogeneity was explored in subgroup analyses using a number of variables. These variables were: age, gender, ethnicity, use of concurrent medication, formulation, dosage, duration of study, method of measurement, study design, and study quality. For patients with sleep disorders, we also examined type of disorder and allocation concealment, while for subjects with normal sleep patterns, we also examined patient description, time of sleep, and use of multiple sleep onset techniques. Deeks' chi-square statistic^119^ was used to test for significant heterogeneity reduction in partitioned subgroups.

We tested for publication bias visually using the Funnel Plot and quantitatively using the Rank Correlation Test,^120^ the Graphical Test,^121^ and the Trim and Fill Method.^122^

### Qualitative Analysis

What are the various formulations of melatonin? How are the formulations different in terms of content, quality as well as safety and effectiveness? What is the clinical importance of any observed differences?

In order to obtain more detailed information regarding the content and quality of the melatonin formulations that were used in the studies relevant to this question of the review, the corresponding authors of these studies were contacted and asked to respond to a short questionnaire. The following is a list of questions that were posed:

1. What are the constituents of the formulation and the relative proportion of each constituent?
2. Was the melatonin component natural or synthetic and what was the purity of this component?
3. Do you have information on the pharmacology of this formulation in humans?

The information provided by corresponding authors was used to supplement information that was provided in the report of these studies. It was used to answer the portion of the question regarding the differences in the content and quality of melatonin formulations that have been used in relevant studies.

What is the pharmacology of exogenous melatonin, including pharmacokinetics and pharmacodynamics? How is it absorbed, distributed, metabolized, excreted? What blood levels are achieved? What is its half-life? Does it penetrate the blood brain barrier?

A detailed Evidence Table was created outlining the design details and results of studies relevant to this question of the review. The results of the studies were also summarized in a Summary Table. The key elements of these tables were summarised.

What is the evidence linking endogenous melatonin to sleep cycles? AND How is endogenous melatonin involved in circadian rhythms?

The studies relevant to these questions of the review were categorized according to details of study design. First, studies were categorized according the type of intervention that was employed; in the case of the question relating to the link between endogenous melatonin and the sleep cycle, these interventions were either alterations in lighting, alterations in the sleep schedule or exposure to another intervention that altered either endogenous melatonin or the sleep cycle; in the case of the question relating to the link between endogenous melatonin and the temperature rhythm, these interventions were either alterations in lighting or temperature. The studies were further subdivided into studies involving participants with or without a sleep disorder or with a disorder other than a sleep disorder. Each of these categories of studies was further categorized according to timing of the intervention. The analysis of data pertaining to these sub-categories of studies began with a summary of the conditions of the intervention and characteristics of the population and continued with a synthesis of the results of each study as they pertain to the question being addressed.

What are the basic mechanisms by which melatonin produces sleepiness?

The studies relevant to this question of the review were categorized as involving participants with or without a sleep disorder and further grouped according to the proposed mechanism by which melatonin produces sleepiness. The findings upon which the proposed mechanisms were based were described for each category of studies.

How do the benefits and harms of melatonin compare to those of other approved pharmacological treatments for sleep disorders?

The studies relevant to this question of the review were categorized as involving participants with or without a sleep disorder and the effects of melatonin and another pharmacological treatment for sleep disorders were compared in terms of their effects on one or more of the following outcomes: sleep onset latency, sleep efficiency, sleep quality, wakefulness after sleep onset, total sleep time and percent time in REM sleep. The adverse events accompanying both treatments were also compared.