# Introduction

## Sleep Disorders

Studies suggest that sleep disorders affect 50 to 70 million Americans, representing approximately 20 percent of the population.^1^ A sleep disorder exists whenever a lower quality of sleep results in impaired functioning or excessive sleepiness.^2^ Insomnia, literally “inability to sleep,” has various etiologies and is the most common sleep disorder, affecting between 6 to 12 percent of the adult population.^3^ In addition to the adult population, difficulties initiating and maintaining sleep are very common in children, affecting about 15 to 25 percent of this population.^1^ Sleep disorders can also be associated with other conditions. For example, psychiatric conditions are the most common cause of insomnia and insomnia is often associated with subsequent development of a psychiatric disorder.^1^ Similarly, many neurological conditions are strongly associated with sleep disorders, with prevalence of sleep disorders up to 80 percent in people with severe mental retardation.^1^

Sleep disorders place a tremendous burden on society due to their association with psychiatric disorders, negative impact on quality of life, safety, productivity and high health care utilization. The National Institutes of Health (NIH) has identified many areas of sleep disorder research that require greater attention, such as the neurobiology of sleep disorders, the effects of sleep disorders and deprivation on performance, and treatment of sleep disorders, including complementary and alternative therapy.

Generally, one of two approaches is used to treat sleep disorders. These approaches are designed to improve performance during waking hours by either improving the amount and quality of sleep, or improving alertness during waking hours. A range of therapies are employed for the treatment of sleep disorders, from behavioral therapy to light therapy to pharmacotherapy. Complementary and alternative therapy is increasingly utilized in the management of sleep disorders. Complementary and alternative medicine (CAM) may be defined as a broad area of healing resources distinct from those intrinsic to the politically dominant health system of a particular society at a given time.^4^ This review will focus on the use of melatonin, a popular therapy within CAM, for the treatment of sleep disorders.

## Classification of Sleep Disorders

Sleep disorders have been classified in various ways (Diagnostic and Statistical Manual of Mental Disorders, 4th Edition, Text Revision [DSM-IV-TR]; International Classification of Diseases, 9th Revision, Clinical Modification [ICD-9-CM]; International Classification of Sleep Disorders [ICSD]). The most recent and detailed classification is the revised version of the International Classification of Sleep Disorders (1990), published by the American Academy of Sleep Medicine.^5^ This document classifies sleep disorders according to four broad categories: dyssomnias, which are characterized by poor sleep; parasomnias, which are characterized by the occurrence of unusual events during sleep; sleep disorders associated with mental, neurological, or medical disorders; and proposed sleep disorders. Dyssomnias, disturbances of the normal sleep or rhythm pattern, are further subdivided into intrinsic (internally-caused), extrinsic (environmentally-caused) and circadian rhythm disorders. Circadian rhythm disorders may also have an intrinsic cause, such as the inability to entrain the sleep-wake cycle to a 24-hour day in non-24-hour sleep wake syndrome, or an extrinsic cause in which the internal circadian apparatus is normal, but the demands of the external environment override it, such as in shift-work disorder or jet lag. Parasomnias involve dysfunctions occurring during sleep, such as nightmares, sleep paralysis or sleepwalking. Sleep disorders often occur in conjunction with mental disorders such as psychoses or mood and anxiety disorders; neurological disorders such as fatal familial insomnia, dementia, and Parkinsonism; and medical disorders such as chronic obstructive pulmonary disease and nocturnal cardiac ischemia (Table 1).^5^

Table 1. Classification of Sleep Disorders according to ICSD

Dyssomnias
Intrinsic Sleep Disorders | Extrinsic Sleep Disorders | Circadian Rhythm Sleep Disorders
Parasomnias
Arousal disorders | Sleep-wake transitional disorders | Parasomnias usually associated with REM sleep | Other parasomnias
Sleep disorders associated with mental, neurologic, and other medical disorders
Associated with mental disorders | Associated with neurological disorders | Associated with other medical disorders
Proposed Sleep Disorders
Short sleeper | Long sleeper | Subwakefulness syndrome | Fragmentary myoclonus
Sleep hyperhidrosis | Menstrual-associated sleep disorder | Pregnancy-associated sleep disorder | Terrifying hypnagogic hallucinations
Sleep-related neurogenic tachypnea | Sleep-related laryngospasm | Sleep choking syndrome

Abbreviations: ICSD = International Classification of Sleep Disorders

## Treatment of Sleep Disorders

The specific treatment used for a given sleep disorder depends on the type and etiology of the disorder.^6^ Generally, the first line of treatment for sleep disorders involves improving sleep hygiene, which may consist of such strategies as strict adherence to a consistent routine seven days per week, a quiet and comfortable sleep environment, wind-down time before bed, stimulus control, avoidance of alcohol and caffeine before sleep and properly-timed exercise.^6^ The American Academy of Sleep Medicine endorses the use of sleep hygiene and stimulus control, but other behavioral treatments, such as biofeedback, sleep restriction, relaxation training and cognitive therapy, may also be used.

### Chronotherapy

Chronotherapy may be used for delayed or advanced sleep phase syndrome and usually involves application of a series of consecutive shifted 24-hour days, thus phase-delaying the sleep cycle three hours per sleep-wake cycle, until the desired bedtime is reached.^7^ Light therapy may be used alone or in conjunction with chronotherapy and is often a treatment of choice for circadian rhythm disorders, since light is the principal synchronizer of circadian timing.^8^ For delayed sleep phase syndrome, bright light exposure in the morning will lead to a phase advance, leading to an earlier time of rising,^9^ while for advanced sleep phase syndrome, bright light exposure in the evening is effective in re-synchronizing the circadian rhythm.^10^ ^11^

Light can shift the timing of the melatonin rhythm in a dose-response manner, with early night exposure resulting in phase delays and late night exposures resulting in phase advances.^12^ ^13^ Light can also suppress endogenous melatonin levels in a dose-response manner.^12^

### Pharmacotherapy

Pharmacotherapy with sedative/hypnotic drugs is also widely used in the treatment of sleep disorders. Hypnotics promote drowsiness and facilitate the onset of sleep, while sedatives induce a calming effect. Ideally, a hypnotic should be rapidly absorbed into the bloodstream, display specific receptor binding, and induce sleep quickly, without causing side effects, buildup of tolerance, physical dependence, and respiratory or central nervous system depression.^14^ However, no hypnotic is perfect. Benzodiazepines are the most commonly prescribed hypnotics and act on the inhibitory neurotransmitter receptors that are directly activated by the amino acid gamma-aminobutyric acid. Drugs of this class can be effective in treating transient insomnia and, due to anxiolytic as well as sedative/hypnotic properties, may be useful in the management of insomnia associated with select psychiatric disorders.^6^ Although there are several chemical classes of benzodiazepines, some benzodiazepines are metabolized in the body to N-desmethyldiazepam (nordiazepam), an active metabolite with a long elimination half-life and sedative effects. Unwanted effects of the benzodiazepines include daytime sedation, respiratory depression, dependence, and rebound insomnia.^6^ Non-benzodiazepine hypnotics include zolpidem and zaleplon. Drugs of this class are more specific, display more rapid onset and shorter duration of action as well as fewer negative effects on memory and motor coordination, and are less likely to result in rebound insomnia, compared to benzodiazepines.^6^ Antidepressants such as tricyclic antidepressants, trazodone and mirtazapine may also have sedative/hypnotic properties. Alternatives to traditional hypnotics include herbal and “natural” products such as St. John's Wort, valerian, kava kava, and melatonin.^15^ These products have been reported to be effective, however, the methodological quality of studies on effectiveness of these products as well as their inconsistent findings, necessitate further research in this area.

## Melatonin

Melatonin (N-acetyl-5-methoxytryptamine) is a neurohormone that is primarily produced by the pineal gland, located behind the third ventricle in the brain.^16^ In the synthesis of melatonin, tryptophan is hydroxylated to 5-hydroxytryptophan, which in turn is decarboxylated to 5-hydroxytryptamine (serotonin). Serotonin is converted to the melatonin precursor and metabolite N-acetylserotonin by the enzyme N-acetyl transferase.^17–19^ N-acetylserotonin is methylated via the enzyme hydroxyindole-o-methyltransferase to produce melatonin.^20^ Approximately 90 percent of melatonin is cleared in a single passage through the liver. Microsomal enzymes of hepatic cells metabolize melatonin to 6-hydroxymelatonin.^20^ The majority of the latter compound is subsequently conjugated with sulphate to produce 6-sulfoxymelatonin, while a smaller proportion is conjugated to glucuronide, prior to excretion in the urine. A small proportion of unmetabolized melatonin is also excreted in the urine.^20^ Commercially available melatonin may be isolated from the pineal glands of beef cattle^21^ or chemically synthesized.

### Discovery and History of Melatonin

Melatonin was discovered as a result of the observation that bovine pineal extracts caused blanching of the skin of tadpoles when it was added to swimming water.^22^ Aaron Lerner, an American dermatologist, isolated and characterized the hormone from beef pineal extracts in 1958, naming it melatonin based on its ability to lighten melanocytes.^23^

Melatonin is present in a number of organisms such as bacteria, algae, fungi, plants, insects and vertebrates, including humans.^24^ Melatonin is also found in foodstuffs such as vegetables, fruits, rice, wheat and herbal medicines.^24^

Early research involving melatonin was conducted on animals and examined its effects on gonadal maturation and circadian systems. These early animal experiments provided evidence for chronobiologic and sleep-inducing effects of melatonin,^22^ suggesting a role for this hormone in sleep and behavior in humans. The first experiments of melatonin on humans were conducted in the early 1970s, which provided evidence of a sleep inducing effect of melatonin in humans.^25^ ^26^ The first study involving administration of chronic small doses of melatonin in human volunteers was conducted in 1984 and this study found that melatonin increased self-rated tiredness.^27^ Sedative-hypnotic effects of melatonin were also noted in a study examining the behavioral effects of melatonin.^28^ In 1984, melatonin was tested for its ability to alleviate the symptoms of jet lag,^27^ and this stimulated further trials of melatonin for the treatment of sleep disorders.

### Physiology of Endogenous Melatonin

Melatonin secretion follows a circadian rhythm and is entrained to the light/dark cycle; light suppresses the production of melatonin, and with the onset of darkness, melatonin is produced and secreted from pinealocytes.^29^ Light input is transmitted from the photic receptors in the retina through the retinohypothalamic tract to the suprachiasmatic nucleus (SCN), which is located in the anterior hypothalamus and functions as the central circadian pacemaker of the body.^30^ During the dark period, the SCN stimulates the release of norepinephrine from the superior cervical ganglion; activation of pinealocyctes by norepinephrine results in production and release of melatonin.^31^

Melatonin is not stored in the pineal gland, but is secreted upon production. The hormone is likely secreted into the bloodstream before entering the cerebrospinal fluid (CSF) of the third ventricle, although it may also be secreted directly into cerebrospinal fluid.^32^ Evidence for direct secretion of melatonin into CSF has been provided by findings that melatonin levels in CSF are substantially higher than in plasma.^33^ Melatonin can also be measured in saliva, where levels are about 70 percent of plasma levels. The onset of melatonin secretion occurs at approximately 2200–2300 hours and maximal plasma concentrations occur at about 0300–0400 hours for a regular sleep cycle.^34^ The offset of melatonin secretion occurs at approximately 0700–0900 hours.^34^ The levels of metabolite in urine correlate positively with plasma levels of the hormone^29^ and provide a non-invasive method of measuring melatonin levels in the body.^35^

Although melatonin is present in plasma of newborns, the circadian rhythm of melatonin does not exist at birth, but appears at 9–12 weeks of age and is fully established by 5–6 months of age.^35^ Melatonin reaches high values at 1–3 years of age, with plasma levels peaking at approximately 250 pg/ml. Melatonin levels in plasma begin to decrease just prior to puberty to peak values of less than 100 pg/ml in adulthood.^36^ There are, however, marked individual differences in the levels of melatonin that are produced by the pineal gland.^29^

### Effects of Exogenous Melatonin

Melatonin has several effects on the body. It is best known as an entrainer of the circadian rhythm.^37^ In mammals, removal of the pineal gland abolishes melatonin secretion.^19^ Exogenous melatonin will cause a phase advance of the melatonin rhythm if given at dusk, and a phase delay if given in the morning.^38^ The constant lag time between the onset of melatonin secretion and the onset of sleep suggests that exogenous melatonin could promote sleep.^39^ Administration of exogenous melatonin to healthy volunteers has been shown to increase sleep propensity, reduce sleep onset latency and decrease REM sleep latency.^40^

The secretion of melatonin is also associated with the thermoregulatory cycle. The circadian rhythm of melatonin inversely correlates with the temperature rhythm in humans; melatonin levels in blood increase as core body temperature decreases.^41^ Administration of pharmacologic, as opposed to physiologic, doses of exogenous melatonin, has been reported to cause a reduction in core body temperature.^42^ ^43^

The secretion of melatonin secretion is also associated with the reproductive rhythm. In humans, melatonin secretion is inversely correlated with gonadal development; peak melatonin levels fall just prior to the onset of puberty.^44^ In addition, higher levels of plasma melatonin have been noted in women with amenorrhea.^45^ Taken together, these findings suggest an inhibitory effect of melatonin on the reproductive rhythm.

Melatonin is also involved in immune function, and evidence suggests an immunoenhancing function for melatonin, via stimulation of natural killer cell activity, regulation of cytokine expression and inhibition of apoptosis in immune cells.^46^ In support of such a function, high affinity melatonin receptors have been detected in human T lymphocytes.^47^ Melatonin has also been shown to have oncostatic effects; it reduces tumor growth in animals and humans,^48^ ^49^ may reduce angiogenesis, protects DNA from mutation, and may also decrease tumor initiation.^29^

### Melatonin Receptors

Melatonin has endocrine, autocrine and paracrine actions,^29^ and some of these actions are receptor-mediated, while others are direct. There are three classes of melatonin receptors, MT1, MT2, and MT3.^50^ In mammalian tissues, the distribution of melatonin receptors appears to be widespread.^29^ The receptors are most consistently found in the SCN and the pars tuberalis of the adenophysis, although current research suggests that few tissues are devoid of melatonin receptors.^29^ MT1 receptors are high affinity receptors that fall into the G-protein coupled receptor superfamily, and binding of melatonin to these receptors results in inhibition of adenylate cyclase activity in target cells.^51^ There are two subgroups of the ML1 receptors, ML1a receptors and ML1b receptors.^52^ The ML1 receptors are likely involved in regulation of retinal function, circadian rhythms and reproduction.^31^ The ML2 receptors are low affinity receptors that are coupled to phosphoinositol hydrolysis.^31^ Activation of MT3 receptors inhibits leukotriene B4-induced leukocyte adhesion and decreases intraocular pressure.^50^

## Sleep Disorders and Melatonin

### Clinical Trials of Melatonin for Sleep Disorders

The circadian phase modulating effects of melatonin point to its potential use in the treatment of circadian rhythm disorders, while the hypnotic/soporific effects of melatonin suggest its potential use in the treatment of insomnia. The use of melatonin in the elderly is considered a potential treatment for sleep disturbances in this population. Similarly, sleep disorders secondary to other medical conditions, such as depression or neurological disorders, may involve circadian rhythm abnormality, and thus could be mitigated by melatonin. A number of randomized controlled trials have been conducted to examine the effect of melatonin in the treatment of various types of insomnia^53–58^ such as sleep maintenance insomnia,^37^ terminal insomnia,^57^ sleep onset insomnia,^59^ psychophysiological insomnia^60^ as well as circadian rhythm disorders such as time zone change (jet lag) syndrome,^61–65^ shift work sleep disorder,^66–70^ delayed sleep phase syndrome,^71–75^ and non-24-hour sleep wake disorder (associated with blindness).^73^ ^76^ ^77^ Randomized controlled trials have also been conducted to examine the effect of melatonin in the treatment of sleep disorders secondary to neurological conditions such as dementia,^78^ Alzheimer's syndrome,^79^ Rett syndrome,^80^ tuberous sclerosis^81^ and various other developmental disabilities^82^ as well as disorders secondary to psychiatric conditions such as depression, bipolar disorder^83^ and seasonal affective disorder.^84^ ^85^ Many case studies have also been conducted, particularly in children, on the use of melatonin for sleep difficulties secondary to neurological syndromes such as Rett syndrome,^86^ Smith-Magenis syndrome,^87^ Angelman syndrome,^88^ autism^82^ and epilepsy.^83^ Randomized controlled trials have also been conducted to examine the effect of melatonin in the treatment of parasomnias and REM sleep behavior disorder.^89^

### Formulation and Dosage of Melatonin Used in Clinical Trials

The trials on melatonin for the treatment of sleep disorders vary in the formulation, timing of administration, frequency and duration of melatonin administration. The providers of melatonin for the various clinical trials on melatonin are diverse; Nestle, Sigma, Neurim, and Regis formulations are common providers. Melatonin products vary from fast-release to sustained release formulations. The formulation of melatonin used in the treatment of sleep disorders may have an effect on sleep outcomes, for example, in one trial, constant-release melatonin improved sleep quality in elderly insomniacs,^90^ but in another trial, fast-release melatonin did not improve sleep quality in elderly insomniacs.^91^ By far the most common method of melatonin administration is orally by capsule; the capsule usually consists of melatonin and lactose in a gelatin capsule. However, melatonin has also been administered by a sublingual tablet route, in patch format, and has also been tested intravenously. Commercially available agents are even more variable; melatonin products available include capsule, tablet (oral or sublingual), lozenge, liquid or spray forms. In trials of melatonin, the hormone has been administered orally or by transbuccal patch in dosages between 0.1 and 10 mg. The duration of melatonin administration in these trials varied from a single, one-time dose of melatonin^92^ to multiple doses of melatonin administered for several months.^86^ In most studies, melatonin is administered thirty minutes to two hours before usual bedtime or desired sleep time. The sleep outcomes analyzed in these studies include such measures as sleep onset latency, total sleep time, sleep duration, quality of sleep, number of awakenings, wake time after sleep onset, sleep efficiency as well as alertness, mood and performance. Some of these studies have found a positive effect of melatonin on these outcomes in people with sleep disorders, whereas some have shown no benefit of melatonin administration, that is, no improvement in sleep quality.

### Adverse Effects of Melatonin

Compared to some pharmacological treatments for sleep disorders, melatonin has a very short half-life and its effects are short-lived.^93^ There have been some side effects of melatonin reported, such as drowsiness and headache.^65^ ^94^ ^95^ In general, most trials have not reported any hangover effects of melatonin, although some trials have reported adverse effects of melatonin on performance.^96^ Melatonin administration in epileptic children has been associated with increased seizure activity.^97^ Melatonin has also been associated with deterioration of mood in depression,^83^ ^98^ and has been reported to be associated with development of autoimmune hepatitis in one case.^99^

## Systematic Reviews on the Use of Melatonin for the Treatment of Sleep Disorders

A small number of systematic reviews have been conducted on the use of melatonin for the treatment of sleep disorders. One systematic review of the effectiveness of melatonin in the treatment of jet lag, which included ten randomized controlled trials with a total of 953 patients, found melatonin to be effective in decreasing subjective ratings of symptoms of jet lag.^100^ The timing of melatonin administration was found to be important for positive effects of the hormone; melatonin must be taken close to the target bedtime at the destination in order to alleviate the symptoms of jet lag. A second systematic review on the effect of melatonin in the treatment of elderly insomniacs found that the administration of exogenous melatonin reduced sleep onset latency and improved sleep quality, as measured by increased sleep efficiency and total sleep time, in elderly people with insomnia, who were characterized with benzodiazepine use and low circulating levels of melatonin.^101^ This review included six small randomized controlled trials with 95 patients. In another review of the effectiveness of melatonin in the treatment of sleep disorders,^102^ evidence was provided that melatonin may have modest effectiveness in treating insomnia, jet lag, and sleep disorders in neurologically impaired patients. This study was based on four trials involving the use of melatonin for the treatment of jet lag, two trials involving the use of melatonin for the treatment of shift work disorder and six trials of melatonin for the treatment of insomnia, all of which were indexed in MEDLINE®. Finally, a review of the effectiveness of melatonin in treating children with neurodevelopmental disability and severe sleep problems found very little good quality evidence for the effectiveness of melatonin in this population, due to small study sizes and difficulties with objective assessments of outcomes, and the authors proposed that melatonin may be more effective in the treatment of sleep onset difficulties rather than fragmented sleep or early morning awakening.^103^ This review included six trials and the report highlighted a lack of significant evidence for the long-term safety of melatonin; one of the included studies reported a notable increase in seizures with melatonin administration.^97^

Although a few systematic reviews have been conducted on the use of melatonin for the treatment of sleep disorders, many focus on the treatment of a particular category of sleep disorders in a specific population. In this systematic review, we broaden the focus to include a review of the use of melatonin for the treatment of a number of categories of sleep disorders, including primary sleep disorders, secondary sleep disorders and sleep restriction, in a number of different populations. Moreover, we review not only the safety and effectiveness of melatonin for the treatment of sleep disorders, but also the pharmacology of exogenous melatonin and the physiology of endogenous melatonin to provide a comprehensive overview of the state of research in this area.

## Melatonin Safety and Legal Status

Melatonin has sometimes been considered a “safe” substance, since it has been shown to have low toxicity in animal studies^104^ and to result in minor and infrequent adverse events in humans (see above). However, its safety has not, in fact, been definitively established; the safety of melatonin products is still under review and these products are regulated differently in various countries. Rigorous safety evaluations of melatonin in humans have not been conducted and clear standards have not been developed for the quality of melatonin formulations.

### Status in the United States

Currently, melatonin falls under the Food and Drug Administration's (FDA's) Dietary Supplement Health and Education Act^105^ in the category “other dietary supplements”. Melatonin is not considered a drug, since it is a naturally occurring substance^106^ and it is designated “generally recognized as safe” (GRAS). Recognizing the lack of a common framework for evaluating the safety of dietary supplements, the Institute of Medicine Food and Nutrition Board has proposed a framework accompanied by six prototype monographs for the evaluation of various dietary supplements, including melatonin.^107^

### Status in Canada

The Natural Health Products Directorate (NHP) of Health Canada has been re-evaluating natural health products such as melatonin. New NHP regulations have come into effect as of January 1st, 2004, which permit natural health products to be sold in Canada if they meet specific licensing, manufacturing, labelling, and safety standards. Melatonin is now available for sale in Canada.^108^

### Status in Europe

In the European Union, melatonin is not considered as a foodstuff but rather a medicine or hormone. It is available by prescription only.^109^

### Status in Australia

Melatonin is an unregistered good under the Therapeutic Goods administration. However, it can be imported for use under the Personal Import Scheme with a prescription.^110^

## Objectives of the Review

The primary objective of this Evidence Report is to provide the details of a comprehensive literature review and synthesis of evidence on the use of melatonin for the treatment of sleep disorders, including not only the safety and effectiveness of melatonin for the treatment of sleep disorders, but also, the pharmacology of exogenous melatonin as well as the physiology of endogenous melatonin. Specifically, we sought to synthesize evidence related to four topic areas, including the physiology and pharmacology of melatonin; the populations that would benefit most from melatonin treatment; the effectiveness of melatonin treatment; and the safety of melatonin treatment.

## Questions of the Review

The specific questions addressed in this Evidence Report are as follows:

### Topic Area 1: Physiology and Pharmacology of Melatonin

1. What are the various formulations of melatonin? How are the formulations different in terms of content and quality as well as safety and effectiveness? What is the clinical importance of any observed differences?
2. What is the pharmacology of exogenous melatonin (including pharmacokinetics and pharmacodynamics)? How is it absorbed, distributed, metabolized and excreted? What blood levels are achieved? Does it penetrate the blood/brain barrier?
3. What is the evidence linking endogenous melatonin to sleep cycles?
4. What are the basic mechanisms by which melatonin produces sleepiness?
5. What is the effect of exogenous melatonin on sleep latency, sleep efficiency, and REM latency in normal sleepers?
6. How is endogenous melatonin involved in circadian rhythms?

### Topic Area 2: Population at Risk

1. Which sleep disorders would be most effectively managed by treatment with melatonin?
2. Which populations, based on gender, age, ethnicity, genetic factors and co-morbid conditions, would benefit most from treatment with melatonin?

### Topic Area 3: Effectiveness of Melatonin

1. What is the effect of exogenous melatonin on people with sleep disorders?
2. What is the appropriate dosage/duration of melatonin for the treatment of sleep disorders? Does the appropriate dosage depend on patients' gender, age, and/or ethnicity?
3. What is the timing of melatonin administration during the sleep/wake cycle that would produce optimum treatment effects?

### Topic Area 4: Safety of Melatonin

1. What are the adverse effects of short and long-term use of exogenous melatonin?
2. How do the benefits and harms of exogenous melatonin vary based on dose, timing of administration, and patient factors such as gender, age and ethnicity?
3. How do the benefits and harms of melatonin compare to those of other approved pharmacological treatments for sleep disorders?