# Appendix D: Technical Expert Panel

The following is a list of the members of the TEP with a brief description of some of their professional affiliations and areas of expertise:

1. Dr. Irvin Mayers, Divisional Director of Pulmonary Medicine, University of Alberta (expertise in pulmonary medicine and sleep disorders)
2. Ms. Shirley Heschuk, Lecturer, University of Alberta (expertise in Pharmacy Law and Ethics, Non-Prescription Drugs, Nutrition, and CAM)
3. Dr. Constance Chik, Professor and Program Director of the Division of Endocrinology and Metabolism, University of Alberta (expertise in neuroendocrinology and pineal cell biology)
4. Dr. Christina Benishin, Associate Professor of Physiology, University of Alberta (expertise in pharmacology, physiology, and CAM)
5. Dr. Gary Hnatko, Associate Professor of Psychiatry, University of Alberta (expertise in psychiatry and sleep disorders)
6. Dr. Carina Majaesic, Pediatric Pulmonologist, University of Alberta Hospital (expertise in pulmonary medicine and immunology)
7. Dr. Nalaka Gooneratne, Assistant Professor, University of Pennsylvania (expertise in sleep and pulmonary critical care)
8. Dr. Irina Zhdanova, Associate Professor, Boston University (expertise in melatonin and sleep disorders)
9. Dr. Manisha Witmans, Pediatric Pulmonologist, University of Alberta Hospital (expertise in sleep disorders)
10. Dr. Larry Pawluk, Associate Clinical Professor of Psychiatry, University of Alberta (expertise in pharmacology and sleep disorders)
11. Dr. Catherine E. Ulbricht, Executive Director of Natural Standard Research Collaboration, Senior Attending Pharmacist Massachusetts General Hospital (expertise in CAM and pharmacology)
12. Dr. Ethan Basch, Chief Editor, Natural Standard Research Collaboration (expertise in CAM)
13. Dr. Adrianne E. Rogers, Professor of Pathology and Public Health, Boston University School of Medicine; Editorial Board Member of Natural Standard Research Collaboration (expertise in toxicology and pathology)
14. Dr. Paul Hammerness, Investigator, Pediatric Psychopharmacolgy Unit, Child and Adolescent Psychiatry, Massachusetts General Hospital; Editor and Author, Natural Standard Research Collaboration (expertise in CAM)
15. Dr. Serguei Aksentsev, Author, Natural Standard Research Collaboration (expertise in CAM)
16. Dr. Alan Carroll, Associate Clinical Professor, Department of Psychiatry, University of Alberta (expertise in psychiatry and neurodevelopment)