# Appendix C: Evidence Tables

Evidence Table C-1: Formulations of Melatonin: Study Characteristics

Author | Year | Population | | Sample Size | N | Study Design | Intervention
Almeida-Montes, LG | 2003 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 16 | Mean (SD): | 50 (NS) | Enrolled: | 10 | Double-blind | Sustained-release MLT
| | Range: | 30–72 | Analyzed: | 10 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | Female: | 4 | Enrolled: | 10 | | [underlined: Dosage and Timing]
| | Male: | 6 | Analyzed: | 10 | | 0.3 mg or 1 mg of MLT 1h before bedtime
| | [underlined: Ethnicity: NS] | | | | | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: Insomnia] | | | | | One dose/day for 14 days
Garfinkel, D | 1995 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 24 | Mean (SD): | 76 (NS) | Enrolled: | 12 | Double-blind | Controlled-release MLT
| | Range: | 68–93 | Analyzed: | 12 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | Female: | 5 | Enrolled: | 12 | | [underlined: Dosage and Timing]
| | Male: | 7 | Analyzed: | 12 | | 2 mg of MLT 2h before desired bedtime
| | [underlined: Ethnicity: NS] | | | | | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: Long-term insomnia] | | | | | One dose/night for 3 weeks
Haimov, I | 1995 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 18 | Mean (SD): | 73.1 (3.9) | Enrolled: | 8 | Double-blind | Sustained-release or Fast-release MLT
| | Range: | NS | Analyzed: | 8 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | Female: | 4 | Enrolled: | 8 | | [underlined: Dosage and Timing]
| | Male: | 4 | Analyzed: | 8 | | 2 mg FR, 2 mg SR or 1 mg SR MLT 2h before desired bedtime
| | [underlined: Ethnicity: NS] | | | | | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: Insomnia] | | | | | One dose/day of 2 mg FR and 2 mg SR for 1 week, and one dose/day of 1 mg SR for 2 months
McArthur, A | 1998 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 21 | Mean (SD): | 10.1 (1.5) | Enrolled: | 9 | Double-blind | Immediate-release MLT
| | Range | 4–17 | Analyzed: | 9 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral or by gastrostomy tube
| | Female: | 9 | Enrolled: | 9 | | [underlined: Dosage and Timing]
| | Male: | 0 | Analyzed: | 9 | | Dosage based on individual body weight, range 2.5–7.5 mg of MLT given 1h before bedtime
| | [underlined: Ethnicity: NS] | | | | | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder:] | | | | | One dose/day for 4 weeks
| | [underlined: Sleep dysfunction] accompanying Rett Syndrome
Serfaty, M | 2002 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 22 | Mean (SD): | 84.2 (7.6) | Enrolled: | 44 | Double-blind | Slow release MLT
| | Range: | NS | Analyzed: | 25 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | Female: | 9 | Enrolled: | 44 | | [underlined: Dosage and Timing]
| | Male: | 16 | Analyzed: | 25 | | 6 mg of MLT at usual bedtime
| | [underlined: Ethnicity: NS] | | | | | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder:] | | | | | One dose/day for 2 weeks
| | [underlined: Sleep disturbances] accompanying dementia
Shamir, E | 2001 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 24 | Mean (SD): | 64.2 (14.3) | Enrolled: | 10 | Double-blind | Controlled-release MLT
| | Range: | 28–82 | Analyzed: | 8 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Not specified
| | Female: | 11 | Enrolled: | 12 | | [underlined: Dosage and Timing]
| | Male: | 11 | Analyzed: | 12 | | 2.5 mg MLT, timing: NS
| | [underlined: Ethnicity: NS] | | | | | [underlined: Frequency and Duration]
Smits, MG | 2003 | [underlined: Age (Years)] | | 3 treatments | | RCT | [underlined: Formulation]
Quality Score | 25 | Mean (SD): | | FR =0.5mg, 5mg | | Double-blind | Fast-release or Controlled-release MLT
| | Treatment group | 9.2 (2.1) | CR= 2mg | | Parallel | [underlined: Route of Administration]
| | Control group | 10.1 (1.7) | [underlined: Treatment Groups] | | | Oral
| | Range: | NS | Enrolled: | NS | | [underlined: Dosage and Timing]
| | [underlined: Gender] | | Analyzed: | NS | | 5 mg of MLT at 19:00 h
| | Treatment group | | [underlined: Control Group] | | | [underlined: Frequency and Duration]
| | Female: | 20 | Enrolled: | NS | | One dose/day for 4 weeks
| | Male: | 6 | Analyzed: | NS
| | Control group
| | Female: | 6
| | Male: | 29
| | [underlined: Ethnicity: NS]
| | [underlined: Sleep Disorder:]
| | [underlined: Idiopathic chronic] sleep-onset insomnia
Suhner, A | 1998 | [underlined: Age (Years)] | | 3 treatment groups | | RCT | [underlined: Formulation]
Quality Score | 20 | Mean (SD): | 36 (NS) | 0.5 mg FR MLT | | Double-blind | Fast-release or Controlled-release MLT
| | Range: | 20–65 | 5.0 mg FR MLT | | Parallel | [underlined: Route of Administration]
| | [underlined: Gender] | | 2 mg CR MLT | | | NS
| | Female: | 148 | [underlined: Treatment Groups] | | | [underlined: Dosage and Timing]
| | Male: | 172 | Enrolled: | NS | | 0.5 mg FR, 5.0 mg FR, 2 mg CR MLT at bedtime after 23:10 h +/-1.52 h
| | [underlined: Ethnicity: NS] | | Analyzed: | NS | | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: Jet lag] | | [underlined: Control Group] | | | One dose/day for 4 days after eastward flight
| | | | Enrolled: | NS
| | | | Analyzed: | NS

Abbreviations: RCT: randomized controlled trial, MLT: melatonin, FR: fast-release, SR: slow-release, SD: standard deviation, mg: milligrams, h: hours, NS: not specified

Evidence Table C-2. Pharmacokinetics of Melatonin: Study Characteristics

Author | Year | Population | | Study Design | N | Intervention
Aldhous, M | 1985 | [underlined: Age (Years)] | | CCT | | [underlined: Formulation]
Quality Score | 14 | mean: | NS | Blindedness: NS | | Slow-release MLT
| | range: | 21–39 | Parallel | | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Treatment Group] | | Oral
| | female: | 6 | 2mg MLT: | | [underlined: Dosage and Timing]
| | male: | 6 | Enrolled: | 5 | 2mg MLT gelatine-coated capsules or 2mg slow release tablets or 2mg MLT in corn oil at 1000h
| | [underlined: Co-Medication: NS] | | Analyzed: | 5 | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: None] | | 2mg MLT slow-release: | | 1 capsule or dose/day for 2 days
| | | | Enrolled: | 5
| | | | Analyzed: | 5
| | | | [underlined: Control Group]
| | | | 2mg MLT in corn oil:
| | | | Enrolled: | 4
| | | | Analyzed : | 4
Outcomes:
[underlined: Half-Life +/-SEM]
2mg MLT capsules, fasting : 0.54h +/- 0.03h; 2 mg MLT I cor oil, fed: 0.67 +/- 0.03h
[underlined: Time to Reach Peak +/- SEM]
2 mg MLT capsules, fed: 0.46h +/-07h; 2 mg MLT in corn oil, fasting: 0.95 +/- 0.42h
[underlined: AUC +/- SEM]
AUC (time period not specified): 2mg MLT capsules, fed: 8036 +/- 2455 pg/mL, 2mg MLT capsules, fasting: 3712 +/- 703 pg-h/ml; 2 mg MLT in corn oil, fed: 5826 +/- 2644 pg-h/mL; 2 mg MLT in corn oil, fasting: 3953 +/- 1533 pg-h/mL
Benes, L | 1997 | [underlined: Age (Years)] | | RCT | | [underlined: Formulation]
Quality Score | 16 | mean (SD): | 23(2) | Blindedness: NS | | Not specified
| | range: | 21–27 | Cross-over | | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Treatment Group] | | Oral (O), Transdermal (TD), Transmucosal (TM)
| | female: | 0 | Enrolled: | 12 | [underlined: Dosage and Timing]
| | male: | 12 | Analyzed: | 12 | 0.76mg (oral), 8 mg (TD), or 0.5 mg (TM) at 0800h
| | [underlined: Co-Medication: None] | | [underlined: Control Group] | | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: None] | | Enrolled: | 12 | Single dose for 3 days one week apart
| | | | Analyzed : | 12
Outcomes:
[underlined: Time to Reach Peak]
O: 1.3h (range 0.5 – 7h), TD: 13.0h (range 10.5 – 14h), TM: 7.9h (range 5–10.5h)
[underlined: Peak [MLT] (Cmax)]
O: 82.4 pg/mL (range 30 – 417 pg/mL), TD: 172.6 pg/mL (range 44 – 856 pg/mL), TM: 193.8 pg/mL (range 153 – 294 pg/mL)
[underlined: AUC]
AUC (0 – 24h): O: 894.3 pg-h/mL (range 247 – 4007), TD: 2226 pg-h/mL (range 626 – 8700), TM: 1820 pg-h/mL (range 1248 – 2830)
Cagnacci, A | 1995 | [underlined: Age (Years)] | | RCT | | [underlined: Formulation]
Quality Score | 16 | mean: | NS | Double-blind | | Not specified
| | range: | 25–35 | Cross-over | | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Treatment Group] | | Oral
| | female: | 12 | Enrolled: | 6 | [underlined: Dosage and Timing]
| | male: | 0 | Analyzed: | 6 | 1mg MLT at 0800h, 0.75mg at 1000h, 0.75 mg at 1200h
| | [underlined: Co-Medication: NS] | | [underlined: Control Group] | | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: None] | | Enrolled: | 6 | Single dose
| | | | Analyzed : | 6
Outcomes:
[underlined: Time to Reach Peak]
1.5 – 2h
[underlined: Peak [MLT] (Cmax) +/-SE]
1984.14 +/- 425.07 pg/mL
Cagnacci, A | 1996 | [underlined: Age (Years)] | | RCT | | [underlined: Formulation]
Quality Score | 13 | mean: | NS | Double-blind | | Not specified
| | range: | 25–35 | Cross-over | | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Treatment Group] | | Not specified
| | female: | 7 | Enrolled: | 7 | [underlined: Dosage and Timing]
| | male: | 0 | Analyzed: | 7 | 1 mg MLT at 0800h, 0.75mg at 1000h, 0.75mg at 1200h, total dose = 2.5mg
| | [underlined: Co-Medication: NS] | | [underlined: Control Group] | | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: None] | | Enrolled: | 7 | 2.5mg/day for 2 days
| | | | Analyzed : | 7
Outcomes:
FP= Follicular Phase LP= Luteal Phase
[underlined: AUC +/-SE]
AUC (0–24h): FP: 637.82 +/- 258.11 pg-h/ml; LP: 668.69 +/- 309.22 pg-h/ml
Cavallo, A | 1996 | [underlined: Age (Years)] | | Case series | | [underlined: Formulation]
Quality Score | 17 | mean: | NS | Blindedness: NS | | Not specified
| | range: | 6–31yrs | [underlined: Treatment Group] | | [underlined: Route of Administration]
| | [underlined: Gender] | | Enrolled: | 30 | Intravenous
| | female: | 18 | Analyzed: | 30 | [underlined: Dosage and Timing]
| | male: | 12 | | | 0.5mug/kg MLT over 10 minutes
| | [underlined: Co-Medication: NS] | | | | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: None] | | | | Single dose
Outcomes:
[underlined: Half-Life +/- SD]
Total Population: 0.76h +/-0.13h. By subject groups: Prepubertal (9; 5M, 4F): 0.67 +/- 0.12 h; Pubertal (8; 4M, 4F): 0.78 +/- 0.11; Adult females (7): 0.81 +/- 0.12; Adult males (9): 0.82 +/- 0.15; Adults, all (16): 0.79 +/- 0.10
[underlined: AUC +/-SD]
AUC (time frame not clear): Total population: 327.5 +/- 145.9 pg-h/mL.
By subject groups: Prepubertal (9; 5M, 4F): 250.9 +/- 91.8 pg-h/ml; Pubertal (8; 4M, 4F): 300.1 +/- 131.0 pg-h/ml; Adult females (7): 384.4 +/- 159.9 pg-h/ml; Adult males (9): 390.2 +/- 173.1 pg-h/ml; Adults, all (16): 376.9 +/- 154.3 pg-h/ml
Dawson, D | 1996 | [underlined: Age (Years)] | | RCT | | [underlined: Formulation]
Quality Score | 17 | mean: | NS | Double-blind | | Not specified
| | range: | 18–38 | Cross-over | | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: 4 MLT dose groups] | | Oral
| | female: | 21 | 0.1, 0.5, 1, or 5 mg; Enrolled in each group: | 8 | [underlined: Dosage and Timing]
| | male: | 11 | Analyzed: | NS | 0.1, 0.5, 1.0, or 5 mg MLT at 1600hr
| | [underlined: Co-Medication: None] | | [underlined: Control group] | | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: None] | | Enrolled in each group: | 8 | Single dose
| | | | Analyzed: | NS
Outcomes:
[underlined: Half-Life +/-SD]
[underlined: Time to Reach Peak +/-SD]
0.1 mg: 1.25 +/-0.48h, 0.5 mg: 0.88 +/-0.33h, 1.0 mg: 0.78 +/-0.47h, 5.0 mg: 0.97 +/-0.75h
[underlined: Peak [MLT] (Cmax) +/-SD]
0.1 mg: 124.5+/-97.8 pg/mL, 0.5 mg: 709.4 +/- 702.0pg/mL, 1.0 mg:
1356.3 +/- 1397.6 pg/mL, 5.0 mg: 5570.5 +/-3842.8 pg/mL
Deacon, S | 1995 | [underlined: Age (Years)] | | RCT | | [underlined: Formulation]
Quality Score | 20 | mean (SD): | 27.2(3.7) | Double-blind | | Not specified
| | range: | 23–34 | Cross-over | | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Treatment Group] | | Oral
| | female: | 3 | Enrolled: | 6 | [underlined: Dosage and Timing]
| | male: | 3 | Analyzed: | 6 | 0.05mg, 0.5mg or 5.0 mg MLT at 1700h
| | [underlined: Co-Medication: None] | | [underlined: Control Group] | | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: None] | | Enrolled: | 6 | Single dose of either 0.05mg, 0.5mg, or 5mg for 1 day, 1 day per session, 4 sessions
| | | | Analyzed : | 6
Outcomes:
[underlined: Half-Life +/-SEM]
0.05 mg: 64.8 +/- 16.2, 0.5 mg: 42.6 +/- 12.6, 5.0 mg: 2 +/- 19.2 (units not specified)
[underlined: Time to Reach Peak]
0.05 mg: 0.5h, 0.5 mg: 1 h, 5.0 mg: 0.5h
[underlined: Peak [MLT] (Cmax) +/-SEM]
0.05 mg: 118 +/- 37 pg/mL (range 13 – 274 pg/mL), 0.5 mg: 1327 +/- 491 pg/mL (range 454 – 3700 pg/mL), 5.0 mg: 18495 +/-
3326 pg/mL (range 7830 – 31450)
Debus, O | 2002 | [underlined: Age (Years)] | | Case series | | [underlined: Formulation]
Quality Score | 14 | mean: | 3.4 | Blindedness: NS | | Not specified
| | range: | one to five | [underlined: Treatment Group] | | [underlined: Route of Administration]
| | [underlined: Gender] | | Enrolled: | 5 | Oral
| | female: | 2 | Analyzed: | 5 | [underlined: Dosage and Timing]
| | male: | 3 | Only Patient 3 took melatonin | | 5mg MLT at 2000h
| | [underlined: Co-Medication: 1 female took] | | | | [underlined: Frequency and Duration]
| | chloral hydrate sleep medication | | | | Single dose
| | [underlined: Sleep Disorder: None]
Outcomes:
[underlined: Time to Reach Peak +/-NS]
Patient 3: 1.2h
[underlined: Peak [MLT] (Cmax) +/-NS]
Patient 3: 18,650 pg/ml (in vCSF)
Di, Wei-Di | 1997 | [underlined: Age (Years)] | | Case series | | [underlined: Formulation]
Quality Score | 8 | mean: | NS | Blindedness: NS | | Not specified
| | range: | 21–32 | [underlined: Treatment Group] | | [underlined: Route of Administration]
| | [underlined: Gender] | | Enrolled: | 4 | Intravenous (IV) and Oral
| | female: | 0 | Analyzed: | 4 | [underlined: Dosage and Timing]
| | male: | 4 | | | 20ug MLT (IV) and 500ug MLT (oral) on 2 separate occasions, timing: NS
| | [underlined: Co-Medication: NS] | | | | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: None] | | | | Single dose
Outcomes:
[underlined: Half-Life +/-SD]
0.78h +/- 0.05h
[underlined: Peak [MLT] (Cmax)(range)]
480 – 9200 pg/mL
Dollins, A | 1993 | [underlined: Age (Years)] | | RCT | | [underlined: Formulation]
Quality Score | 18 | mean (SD): | 25(1.47) | Double-blind | | Not specified
| | range: | 19–39 | Cross-over | | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Treatment Groups] | | Oral
| | female: | 0 | Group 1 enrolled: | 20 | [underlined: Dosage and Timing]
| | male: | 20 | Ingested 10 mg MLT | | 10, 20, 40, or 80 mg MLT capsules at 1145 h
| | [underlined: Co-Medication: NS] | | Group 2 enrolled: | 20 | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: None] | | Ingested 20 mg MLT | | Single dose
| | | | Group 3 enrolled: | 20
| | | | Ingested 40 mg MLT
| | | | Group 4 enrolled: | 20
| | | | Ingested 80 mg MLT
| | | | [underlined: Control Group]
| | | | Group 5 enrolled: | 20
| | | | Ingested placebo.
| | | | Total analysed: NS
Outcomes:
[underlined: AUC +/-SEM]
AUC (1000h to 1630h): 10 mg: 12,228 +/-5736.1 pg/mL, 20 mg: 27,186 +/-14,268.5 pg/mL, 40 mg: 52,557 +/- 26,401.6pg/mL, 80 mg: 106,223 pg/mL +/- 63.038.3
Dollins, A | 1994 | [underlined: Age (Years)] | | RCT | | [underlined: Formulation]
Quality Score | 18 | mean (SD): | 23.05(4.22) | Double-blind | | Not specified
| | range: | 18–24 | Cross-over | | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Treatment Groups] | | Oral
| | female: | 0 | 0.1, 0.3, 1.0, 10mg | | [underlined: Dosage and Timing]
| | male: | 20 | Enrolled: | 20 | 0.1, 0.3, 1.0 or 10mg MLT at 1145h
| | [underlined: Co-Medication: NS] | | Analyzed: | 12 | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: None] | | [underlined: Control Group] | | Single dose/group over 5 days
| | | | Enrolled: | 20
| | | | Analyzed : | 12
| | | | All 20 subjects participated in each treatment group
Outcomes:
[underlined: AUC +/- SEM]
AUC (0000h to 1730h): 0.1 mg: 213.2+/-25.02 pg/ml, 0.3 mg: 459.9 +/-62.7pg/ml, 1.0 mg: 1599.0 +/-141.7pg/ml, 10 mg: 21000.4 +/-3752.3pg/ml
Helrich, E | 2002 | [underlined: Age (Years)] | | RCT | | [underlined: Formulation]
Quality Score | 13 | mean: | 25 | Blindedness: NS | | Not specified
| | range: | NS | Cross-over | | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Treatment Groups] | | Intranasal
| | female: | 0 | 200ug MLT | | [underlined: Dosage and Timing]
| | male: | 8 | Enrolled: | 8 | 0.200mg or 0.4mg MLT, timing: NS
| | [underlined: Co-Medication: NS] | | Analyzed: | 7 | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: None] | | 400 ug MLT | | Single dose
| | | | Enrolled: | 8
| | | | Analyzed : | 8
| | | | [underlined: Control Group]
| | | | Enrolled: | 8
| | | | Analyzed : | 8
Outcomes:
[underlined: Half-Life +/-SD]
0.2mg MLT: 0.73h +/- 0.12h, 0.4mg MLT: 1h +/- 0.33h
[underlined: AUC +/- SD]
AUC (0 – 8h): 200ug MLT: 2.99 +/- 1.16, 400 ug MLT: 598 +/- 2.23 (units not specified)
Hoffman, H | 1998 | [underlined: Age (Years)] | | RCT | | [underlined: Formulation]
Quality Score | 14 | mean: | NS | Blindedness: NS | | Fast- and controlled-release MLT
| | range: | 25–35 | Cross-over | | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Treatment Groups] | | Oral
| | female: | 0 | Fast-release (A) | | [underlined: Dosage and Timing]
| | male: | 15 | Enrolled: | 15 | A (5mg) or B(10mg) or C (10mg) MLT between 0800h and 0830h
| | [underlined: Co-Medication: NS] | | Analyzed: | 15 | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: None] | | Controlled-release (B) | | Single dose
| | | | Enrolled: | 15
| | | | Analyzed: | 15
| | | | Controlled-release (C)
| | | | Enrolled: | 15
| | | | Analyzed: | 15
Outcomes:
[underlined: Half-Life]
A: 0.64h, B: 0.80h, C: 0.84h
[underlined: Time to Reach Peak]
[underlined: Run 1: A: 0.5h, B: 0.75h, C: 0.5h; Run 2: A: NA, B: 3.5h, C: 3.5h]
[underlined: Peak [MLT] (Cmax)]
Run 1: A: 4817.49 pg/mL, B: 3816.36 pg/mL, C: 2260.08 pg/mL
Run 2: A: NA, B: 3028.93 pg/mL, C: 4067.22 pg/mL
[underlined: AUC]
AUC (over 10 hour period): A: 4271.63 pg-h/mL, B: 8382.99 pg-h/mL, C: 9844.03 pg-h/mL
AUC: (0 - infinity): A: 4276.27 pg-h/mL, B: 8454.99 pg-h/mL, C: 9911.39 pg-h/mL
Kane, M | 1994 | [underlined: Age (Years)] | | Case series | | [underlined: Formulation]
Quality Score | 17 | mean: | NS | Blindedness: NS | | Not specified
| | range: | 13–83 | [underlined: Treatment Group] | | [underlined: Route of Administration]
| | [underlined: Gender] | | Enrolled: | 5 | Oral
| | female: | 2 | Analyzed: | 5 | [underlined: Dosage and Timing]
| | male: | 3 | | | 50mg MLT, timing: NS
| | [underlined: Co-Medication: NS] | | | | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: None] | | | | Every 4 hours for the subsequent 24 hours
Outcomes:
[underlined: Time to Reach Peak]
1–2 h
[underlined: Peak [MLT] (Cmax) +/-SE]
41600 +/-17700 pg/mL
Kovacs, J | 2000 | [underlined: Age (Years)] | | Case Series | | [underlined: Formulation]
Quality Score | 15 | mean (SD): | 29.7(7.9) | Blindedness: NS | | Not specified
| | range: | NS | [underlined: Treatment Group] | | [underlined: Route of Administration]
| | [underlined: Gender] | | Enrolled: | 17 | Not specified
| | female: | 5 | Analyzed: | NS | [underlined: Dosage and Timing]
| | male: | 12 | | | 3 mg MLT at 1000h
| | [underlined: Co-Medication: None] | | | | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: None] | | | | Single dose
Outcomes:
[underlined: Time to Reach Peak]
1h
[underlined: Peak [MLT] (Cmax) +/-SD]
4701 +/- 6415 pg/mL (range 940 – 27240 pg/mL)
[underlined: AUC +/- SD]
AUC (0–16h): 9514 +/- 9152 pg-h/mL (range 2451 – 40302 pg-h/mL)
Lee, B | 1997 | [underlined: Age (Years)] | | CCT | | [underlined: Formulation]
Quality Score | 10 | mean: | NS | Blindedness: NS | | Not specified
| | range: | NS | Parallel | | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Treatment Group] | | Oral
| | female: | NS | MLT Batch 1 | | [underlined: Dosage and Timing]
| | male: | NS | Enrolled: | 4 | 0.2 mg MLT at 1000h to 1100h
| | [underlined: Co-Medication: NS] | | Analyzed: | NS | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: None] | | [underlined: Control Group] | | Single dose
| | | | MLT Batch 2
| | | | Enrolled: | 6
| | | | Analyzed : | NS
Outcomes:
[underlined: Time to Reach Peak]
Batch 1: 0.5h, Batch 2: 1.0h
[underlined: Peak [MLT] (Cmax) +/-SD]
Batch 1: 117 +/- 21 pg/mL, Batch 2: 108 +/- 33 pg/ml
[underlined: AUC +/-SD]
AUC (time frame not specified): Batch 1: 515.5 +/- 206.2 pg-h/mL Batch 2: 555.6 +/- 334.9 pg-h/mL
Lewy, A.J | 1998 | [underlined: Age (Years)] | | CCT | | [underlined: Formulation]
Quality Score | 14 | mean: | NS | Blindedness: NS | | Not specified
| | range: | 22–77 | Cross-over | | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Treatment Group] | | Oral
| | female: | 5 | Enrolled: | 6 | [underlined: Dosage and Timing]
| | male: | 1 | Analyzed: | 6 | 0.5mg MLT, the average administration time for the morning dose was 0845h (range 0700–1100h) and for the evening dose was 1730h (range 1700–1800h)
| | [underlined: Co-Medication: NS] | | [underlined: Control Group] | | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: None] | | Enrolled: | 6 | Single dose
| | | | Analyzed : | 6
Outcomes:
[underlined: Half-Life +/- SEM]
after morning dose: 0.84h +/-0.1h, after evening dose: 1.06h +/-0.15h
MacFarlane, J.G | 1991 | [underlined: Age (Years)] | | CCT | | [underlined: Formulation]
Quality Score | 20 | mean: | NS | Double-blind | | Not specified
| | range: | 25–85 | Cross-over | | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Treatment Group] | | Oral
| | female: | 8 | Enrolled: | 6 | [underlined: Dosage and Timing]
| | male: | 5 | Analyzed: | 6 | 75 mg MLT at 2200h
| | [underlined: Co-Medication: Free of all neuro-] | | [underlined: Control Group] | | [underlined: Frequency and Duration]
| | active medications for at least 4 weeks prior to the start of the study | | Enrolled: | 7 | 1 capsule/day for 14 days
| | [underlined: Sleep Disorder: Chronic insomnia] | | Analyzed : | 7
Outcomes:
[underlined: Time to Reach Peak]
1.5 h
[underlined: Peak [MLT] (Cmax)]
64, 730 pg/mL
Niederhofer, H | 2003 | [underlined: Age (Years)] | | RCT | | [underlined: Formulation]
Quality Score | 17 | female | 17 | Double-blind | | Not specified
| | mean: | 15–18 | Cross-over | | [underlined: Route of Administration]
| | range: | | [underlined: Treatment Group] | | Oral
| | male | | Enrolled: | 20 | [underlined: Dosage and Timing]
| | mean | 16 | Analyzed: | 20 | MLT (0.1mg, 0.3mg) capsules 1/2hr before each individuals fixed bedtime
| | range: | 14–18 | [underlined: Control Group] | | [underlined: Frequency and Duration]
| | [underlined: Gender] | | Enrolled: | 20 | 1capusle/day for 7 days
| | female: | 10 | Analyzed : | 20
| | male: | 10
| | [underlined: Co Medication: NS]
| | [underlined: Sleep Disorder: Chronic insomnia]
| | accompanying mental retardation
Outcomes:
[underlined: Time to Reach Peak]
about 2h
[underlined: Peak [MLT] (Cmax)]
0.1mg: 79 pg/mL (range 63 – 118) , 0.3 mg: 234 pg/mL (range 144 – 301)
Rajaratnam, SM | 2002 | [underlined: Age (Years)] | | CCT | | [underlined: Formulation]
Quality Score | 17 | mean (SD): | 24.4(4.4) | Double-blind | | Surged sustained released MLT
| | range: | NS | Cross-over | | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Treatment Group] | | Oral
| | female: | 0 | Enrolled: | 8 | [underlined: Dosage and Timing]
| | male: | 8 | Analyzed: | 8 | 1.5 mg MLT at 1600 h
| | [underlined: Co-Medication: None] | | [underlined: Control Group] | | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: None] | | Enrolled: | 8 | Daily dose for 8 days
| | | | Analyzed : | 8
Outcomes:
[underlined: Time to Reach Peak]
3h
[underlined: Peak [MLT] (Cmax) +/-NS]
626 +/- 212 pg/mL
Shah, J | 1999 | [underlined: Age (Years)] | | RCT | | [underlined: Formulation]
Quality Score | 17 | mean: | NS | Blindedness: NS | | Not specified
| | range: | 60–73 | Cross-over | | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Treatment Group] | | Oral
| | female: | 6 | low dose MLT | | [underlined: Dosage and Timing, Frequency and Duration]
| | male: | 6 | Enrolled: | 12 | Low dose MLT: 0.11mg at 2100hours on Day 1 or Day 15; High dose MLT: 0.44mg at 2100h on Day 1 or 15
| | [underlined: Co-Medication: NS] | | Analyzed: | 11
| | [underlined: Sleep Disorder: None] | | [underlined: Control Group]
| | | | high dose MLT
| | | | Enrolled: | 12
| | | | Analyzed : | 11
Outcomes:
[underlined: Half-Life]
~ 2 hours and did not change with dose
[underlined: Time to Reach Peak +/-SD]
Low dose MLT: 5.8 +/-1.6h, High dose MLT: 5.5 +/-1.0h
[underlined: Peak [MLT] (Cmax) +/-SD]
Low dose MLT: 56.9 +/- 50.8 pg/mL, High dose MLT: 179 +/-97.2 pg/mL
[underlined: AUC +/- SD]
AUC (0 – 12 hours): Low dose MLT: 288 +/-213 pg-h/mL, High dose MLT: 1069 +/-679 pg-h/mL
AUC (0 - infinity) (extrapolated): Low dose MLT: 318 +/-227 pg-h/mL, High dose MLT: 1234 +/- 856 pg-h/mL
Shirawaka, S | 2001 | [underlined: Age (Years)] | | CCT | | [underlined: Formulation]
Quality Score | 10 | mean (SD): | 23.4(1.5) | Blindedness: NS | | Not specified
| | range: | NS | Design: not clear | | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Treatment Group] | | Oral
| | female: | 0 | Enrolled: | NS | [underlined: Dosage and Timing]
| | male: | 7 | Analyzed: | NS | 3mg MLT capsules 15 min prior to starting polysomnographic recordings
| | [underlined: Co-Medication: NS] | | [underlined: Control Group] | | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: None] | | Enrolled: | NS | 1 capsule/day for 2 days
| | | | Analyzed : | NS
Outcomes:
[underlined: Time to Reach Peak]
2.25h
[underlined: Peak [MLT] (Cmax)]
1055.7 pg/mL
Shirakawa, S | 1998 | [underlined: Age (Years)] | | Not specified | | [underlined: Formulation]
Quality Score | 11 | mean (SD): | 31.1(1.1) | [underlined: Treatment Group] | | Not specified
| | range: | NS | Enrolled: | 7 | [underlined: Route of Administration]
| | [underlined: Gender] | | Analyzed: | 7 | Oral
| | female: | 0 | | | [underlined: Dosage and Timing]
| | male: | 7 | | | 3 mg MLT at 0930 h
| | [underlined: Co-Medication: NS] | | | | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: None] | | | | Single dose
Outcomes:
[underlined: Time to Reach Peak]
0.33h
[underlined: Peak [MLT] (Cmax) +/-NS]
3561 +/- 1201 pg/mL
Van Den Heuvel, C | 1999 | [underlined: Age (Years)] | | CCT | | [underlined: Formulation]
Quality Score | 15 | mean (SD): | 23.9(0.7) | Double-blind | | Not specified
| | range: | 17–20 | Cross-over | | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Treatment Group] | | Intravenous
| | female: | 4 | Enrolled: | 8 | [underlined: Dosage and Timing]
| | male: | 4 | Analyzed: | 8 | 3, 10, or 30ug MLT at 1000h
| | [underlined: Co-Medication: None] | | [underlined: Control Group] | | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: None] | | Enrolled: | 8 | Single dose per experimental session
| | | | Analyzed : | 8
Outcomes:
[underlined: Time to Reach Peak]
0.25h
[underlined: Peak [MLT] (Cmax) +/- SE]
3 ug: 14.75 +/- 4.67 pg/mL, 10 ug: 34.84 +/- 5.97 pg/mL, 30 ug: 132.19 +/- 25.74 pg/mL
Wright, J | 1986 | [underlined: Age (Years)] | | CCT | | [underlined: Formulation]
Quality Score | 17 | mean: | NS | Double-blind | | Not specified
| | range: | 22–46 | Cross-over | | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Treatment Group] | | Oral
| | female: | 2 | Enrolled: | 12 | [underlined: Dosage and Timing]
| | male: | 10 | Analyzed: | 12 | 2 mg MLT at 1700h
| | [underlined: Co-Medication: NS] | | [underlined: Control Group] | | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: None] | | Enrolled: | 12 | Daily for 4 weeks each (spring) or 3 weeks (autumn) with 1 week washout
| | | | Analyzed : | 12
Outcomes:
[underlined: Time to Reach Peak]
1 h
[underlined: Peak [MLT] (Cmax)]
1500 pg/mL
Zhdanova, I | 2001 | [underlined: Age (Years)] | | RCT | | [underlined: Formulation]
Quality Score | 21 | mean: | NS | Double-blind | | Not specified
| | range: | >50 | Cross-over | | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Treatment Groups] | | Oral
| | female: | NS | 0.1,.03, or 3.0mg | | [underlined: Dosage and Timing]
| | male: | NS | Enrolled: | NS | 0.1 mg, 0.3 mg, or 3.0 mg MLT, timing: NS
| | [underlined: Co-Medication: NS] | | Analyzed: | 30 | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder:] | | [underlined: Control Group] | | Single dose/day for each experimental session;
| | [underlined: Insomnia] | | Enrolled: | NS | treatment lasted 4 weeks
| | | | Analyzed: | 30
Outcomes:
[underlined: Time to Reach Peak]
Within 2 hours of ingestion
[underlined: Peak [MLT] (Cmax)]
0.1 mg: 84 pg/mL (range 59 – 120) , 0.3 mg: 220 pg/mL(range 124 – 297) , 3.0 mg: 1370 pg/mL (range 957 – 2440)

Abbreviations: RCT: randomized controlled trial, CCT: controlled clinical trial, MLT: melatonin,FR: fast-release, SR: slow-release, SD: standard deviation, SE: standard error, mg: milligrams, h: hours, NS: not specified

Control Group received placebo unless otherwise indicated.

Evidence Table C-3: Melatonin and the Sleep Cycle: Study Characteristics

Author | Year | Population | | Sample Size | N | Study Design | Intervention
Ando, K | 1999 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Treatment:]
Quality Score | 19 | Treatment group: | | Enrolled: | 6 | Blindedness: NS | BL
| | Mean (SD): | 34.4 (13.8) | Analyzed: | 5 | Parallel | [underlined: Control:]
| | Range: | NS | [underlined: Control Group] | | | Placebo light
| | Control Group: | | Enrolled: | 6 | | [underlined: Mode of administration:]
| | Mean (SD): | 32.6 (8.1) | Analyzed: | 5 | | Ocular
| | Range: | NS | | | | [underlined: Dosage and Timing:]
| | [underlined: Gender:] | | | | | BL: 500 lux; Placebo light: 0.1 lux for 3 hours. Clock time: NS
| | Treatment group: | | | | | [underlined: Frequency and Duration:]
| | Female: | 1 | | | | One session/day for 12 days
| | Male: | 4 | | | | [underlined: Sleep deprivation:]
| | Control Group: | | | | | No
| | Female: | 2
| | Male: | 3
| | [underlined: Sleep disorder: Delayed Sleep Phase Syndrome]
Arnulf, I | 2002 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Treatment:]
Quality Score | 14 | Mean (SD): | 26 (5.9) | Enrolled: | 18 | Double-blind | Tryptophan-free amino acid drink
| | Range: | 18–38 | Analyzed: | 17 | Cross-over | [underlined: Control:]
| | [underlined: Gender] | | [underlined: Control Group] | | | Placebo drink
| | Female: | 11 | Enrolled: | 18 | | [underlined: Mode of administration:]
| | Male: | 7 | Analyzed: | 17 | | Oral
| | [underlined: Sleep disorder: None] | | | | | [underlined: Dosage and Timing:]
| | | | | | | Tryptophan-free drink in 250 ml of water at 1030 h
| | | | | | | [underlined: Frequency and Duration:]
| | | | | | | Single dose
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | No
Bougrine, S | 1995 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Treatment:]
Quality Score | 17 | Treatment group: | | Enrolled: | 4 | Blindedness: NS | BL during night shift
| | Mean (SD): | NS | Analyzed: | 4 | Parallel | [underlined: Control:]
| | Range: | 20–30 | | | | BL after night shift
| | Control group: | | [underlined: Control Group] | | | [underlined: Mode of administration:]
| | Mean (SD): | NS | Enrolled: | 6 | | Ocular
| | Range: | 20–30 | Analyzed: | 6 | | [underlined: Dosage and Timing:]
| | [underlined: Gender] | | | | | BL during night shift: 2500–3000 lux for 3 hours (0200–0500 h); BL after night shift: 3 cycles for 3 hours (1200–1500h in 2 controls, 10:00–13:00h in 4 treatment)
| | Female: | NS | | | | [underlined: Frequency and Duration:]
| | Male: | NS | | | | BL during night shift: One session/day for 3 days (Treatment Group) or for 5 days (Control Group);
| | [underlined: Sleep disorder: Shift-work disorder] | | | | | BL after night shift: Three cycles
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | No
Boulos, Z | 2002 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Treatment:]
Quality Score | 19 | Treatment group: | | Enrolled: | 10 | Blindedness: NS | BL
| | Mean (SD): | 27 (3.68) | Analyzed: | 8 | Parallel | [underlined: Control:]
| | Range: | 21–34 | | | | DL
| | Control Group: | | [underlined: Control Group] | | | [underlined: Mode of administration:]
| | Mean (SD): | 24.9 (2.85) | Enrolled: | 10 | | Ocular
| | Range: | 21–34 | Analyzed: | 8 | | [underlined: Dosage and Timing:]
| | [underlined: Gender] | | | | | BL: 3000 lux; DL: 10 lux for 3 hours (1900–2200 h local time, 0100–0400 h departure time)
| | Treatment group: | | | | | [underlined: Frequency and Duration:]
| | Female: | 6 | | | | One session/day for 2 days
| | Male: | 4 | | | | [underlined: Sleep deprivation:]
| | Control Group: | | | | | No
| | Female: | 6
| | Male: | 4
| | [underlined: Sleep disorder: Jet-lag]
Budnick, LD | 1995 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Treatment:]
Quality Score | 16 | Median (IR): | 35 (NS) | Enrolled: | 13 | Blindedness: NS | BL
| | Range: | 24–52 | Analyzed: | 9 | Cross-over | [underlined: Control:]
| | [underlined: Gender] | | [underlined: Control Group] | | | DL
| | Female: | 2 | Enrolled: | 13 | | [underlined: Mode of administration:]
| | Male: | 11 | Analyzed: | 9 | | Ocular
| | [underlined: Sleep disorder: Shift-work disorder] | | | | | [underlined: Dosage and Timing:]
| | | | | | | BL: 6000–12000 lux; DL: 1200–1500 lux on half of their 12h night shifts. Clock time: NS
| | | | | | | [underlined: Frequency and Duration:]
| | | | | | | One session/day for 3 months
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | No
Bunnell, D | 1992 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Treatment:]
Quality Score | 12 | Mean (SD): | NS | Enrolled: | 5 | Blindedness: NS | BL
| | Range: | 20–28 | Analyzed: | 5 | Cross-over | [underlined: Control:]
| | [underlined: Gender] | | [underlined: Control Group] | | | DL
| | Female: | 0 | Enrolled: | 5 | | [underlined: Mode of administration:]
| | Male: | 5 | Analyzed: | 5 | | Ocular
| | [underlined: Sleep disorder: None] | | | | | [underlined: Dosage and Timing:]
| | | | | | | BL: 2500 lux; DL: < 100 lux for 2 h prior to sleep. Clock time: NS
| | | | | | | [underlined: Frequency and Duration:]
| | | | | | | One session/day for 2 nights
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | No
Burgess, H | 2001 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Treatment:]
Quality Score | 17 | Mean (SE): | 21.3 (2.7) | Enrolled: | 16 | Double-blind | BL
| | Range: | NS | Analyzed: | 14 | Cross-over | Control:
| | [underlined: Gender] | | [underlined: Control Group] | | | DL
| | Female: | 8 | Enrolled: | 16 | | [underlined: Mode of administration:]
| | Male: | 8 | Analyzed: | 14 | | Ocular
| | [underlined: Sleep disorder: None] | | | | | [underlined: Dosage and Timing:]
| | | | | | | BL: >3000 lux; DL: < 10 lux for 2 hours. Clock time: NS
| | | | | | | [underlined: Frequency and Duration:]
| | | | | | | Single session
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | No
Buxton, OM | 2000 | [underlined: Age (Years)] | | [underlined: Treatment Groups] | | CCT | [underlined: Treatments:]
Quality Score | 14 | Mean (SD): | 23 (3) | Morning nap: | | Blindedness: NS | Morning nap, Afternoon nap, Evening nap in darkness
| | Range: | 20–30 | Enrolled | 6 | Parallel | [underlined: Control:]
| | [underlined: Gender] | | Analyzed: | 6 | | No nap
| | Female: | 0 | Afternoon nap: | | | [underlined: Timing:]
| | Male: | 25 | Enrolled | 6 | | Morning nap for 6 hours (0900–1500 h); Afternoon nap for 6 hours (1400–2000 h);
| | [underlined: Sleep disorder: None] | | Analyzed: | 5 | | Evening nap for 6 hours (1900-0100 h)
| | | | Evening nap: | | | [underlined: Frequency and Duration:]
| | | | Enrolled | 6 | | Single session
| | | | Analyzed: | 6 | | [underlined: Sleep deprivation:]
| | | | [underlined: Control Group] | | | No
| | | | Enrolled: | 7
| | | | Analyzed: | 6
Cajochen, C | 2000 | [underlined: Age (Years)] | | [underlined: Treatment Groups] | | RCT | [underlined: Treatments:]
Quality Score | 16 | Mean (SD): | 27.8 (8.91) | Enrolled: | 23 | Blindedness: NS | Low level light, Middle level light, High level light
| | Range: | 18–44 | Analyzed: | 20 | Parallel | [underlined: Mode of administration:]
| | [underlined: Gender] | | Low level light | | | Ocular
| | Female: | 1 | Enrolled: | NS | | [underlined: Dosage and Timing:]
| | Male: | 22 | Analyzed: | NS | | Low level light: 23 lux; Middle level light: 230 lux;
| | [underlined: Sleep disorder: None] | | Middle level light | | | High level light: 3190 lux for 6.5 hours. Clock time: NS
| | | | Enrolled: | NS | | [underlined: Frequency and Duration:]
| | | | Analyzed: | NS | | Single session
| | | | High level light | | | [underlined: Sleep deprivation:]
| | | | Enrolled: | NS | | No
| | | | Analyzed: | NS
Cole, R | 2002 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Treatment:]
Quality Score | 23 | Treatment group: | | Enrolled: | 29 | Double-blind | BL
| | Mean (SD): | 25 (6.0) | Analyzed: | 28 | Parallel | [underlined: Control:]
| | Range: | 18–40 | [underlined: Control Group] | | | DL
| | [underlined: Gender] | | Enrolled: | 30 | | [underlined: Mode of administration:]
| | Female: | 27 | Analyzed: | 26 | | Ocular
| | Male: | 32 | | | | [underlined: Dosage and Timing:]
| | [underlined: Sleep disorder: Delayed Sleep Phase] | | | | | BL: 2700 lux; DL: 0.1 lux for 4 hours (before user-scheduled arising time); Clock time: NS
| | Syndrome | | | | | [underlined: Frequency and Duration:]
| | | | | | | One session/day for 26 days
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | No
Costa, G | 1997 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Treatment:]
Quality Score | 15 | Mean (SD): | NS | Enrolled: | 5 | Blindedness: NS | BL
| | Range: | 21–32 | Analyzed: | 5 | Cross-over | [underlined: Control:]
| | [underlined: Gender] | | [underlined: Control Group] | | | DL
| | Female: | 4 | Enrolled: | 5 | | [underlined: Mode of administration:]
| | Male: | 1 | Analyzed: | 5 | | Ocular
| | [underlined: Sleep disorder: Shift-work disorder] | | | | | [underlined: Dosage and Timing:]
| | | | | | | BL: 400–600 lux, 1500 lux, or 3200 lux DL: 40 lux;
| | | | | | | 4 periods of 40 min each at 2 hour-intervals. Clock time: NS
| | | | | | | [underlined: Frequency and Duration:]
| | | | | | | 4 sessions/night shift for 2 nights
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | No
Danilenko, KV | 2000 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Treatment:]
Quality Score | 14 | Mean (SD): | 24.0 (4.8) | Enrolled: | 9 | Blindedness: NS | Light Dawn signal
| | Range: | NS | Analyzed: | 5 | Cross-over | [underlined: Control:]
| | [underlined: Gender] | | [underlined: Control Group] | | | Control signal
| | Female: | 0 | Enrolled: | 9 | | [underlined: Mode of administration:]
| | Male: | 9 | Analyzed: | 5 | | Ocular
| | [underlined: Sleep disorder: None] | | | | | [underlined: Dosage and Timing:]
| | | | | | | Dawn signal: 0.003–0.1 lux for 2.5 h (0330–0600 h);
| | | | | | | Dawn watched for 1.5 h (0600–730 h);
| | | | | | | Control signal: 0.1 lux for 1.5 h (0600–0730 h).
| | | | | | | Sleep truncated at 0.1 lux (0600–0730 h)
| | | | | | | [underlined: Frequency and Duration:]
| | | | | | | One session/day for 9 days
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | No
Danilenko, KV | 2003 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Treatment:]
Quality Score | 16 | Mean (SD): | 24.9 (1.4) | Enrolled: | 12 | Blindedness: NS | Advanced sleep
| | Range: | 20–34 | Analyzed: | 10 | Cross-over | [underlined: Control:]
| | [underlined: Gender] | | [underlined: Control Group] | | | Fixed sleep
| | Female: | 6 | Enrolled: | 12 | | [underlined: Timing:]
| | Male: | 4 | Analyzed: | 10 | | Advanced sleep: 2 h advance, Fixed sleep: 2330-0800 h
| | [underlined: Sleep disorder: None] | | | | | [underlined: Frequency and Duration:]
| | | | | | | Sleep time advanced 20 min/day for 6 days.
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | Yes
Daurat A | 1996 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Treatment:]
Quality Score | 16 | Mean (SD): | 23.6 (1.05) | Enrolled: | 8 | Blindedness: NS | Moderate BL
| | Range: | NS | Analyzed: | 8 | Cross-over | [underlined: Control:]
| | [underlined: Gender] | | [underlined: Control Group] | | | DL
| | Female: | 0 | Enrolled: | 8 | | [underlined: Mode of administration:]
| | Male: | 8 | Analyzed: | 8 | | Ocular
| | [underlined: Sleep disorder: None] | | | | | [underlined: Dosage and Timing:]
| | | | | | | BL: 1000–1500 lux; DL: 50 lux for 14 hours (1800-0800 h)
| | | | | | | [underlined: Frequency and Duration:]
| | | | | | | Single session
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | Yes
Daurat, A | 1997 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Treatment:]
Quality Score | 16 | Mean (SEM): | 23.6 (1.05) | Enrolled: | 10 | Blindedness: NS | Moderate BL
| | Range: | NS | Analyzed: | 10 | Cross-over | [underlined: Control:]
| | [underlined: Gender] | | [underlined: Control Group] | | | DL
| | Female: | 0 | Enrolled: | 10 | | [underlined: Mode of administration:]
| | Male: | 8 | Analyzed: | 10 | | Ocular
| | [underlined: Sleep disorder: None] | | | | | [underlined: Dosage and Timing:]
| | | | | | | BL: 1000–2000 lux, DL: < 50 lux for 14 hours during the nocturnal part of sleepless period (18:00-08:00 h)
| | | | | | | [underlined: Frequency and Duration:]
| | | | | | | Single session
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | Yes
Dijk, DJ | 1989 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Treatment:]
Quality Score | 16 | Mean (SD): | 23.1 (2.5) | Enrolled: | 8 | Blindedness: NS | BL
| | Range: | NS | Analyzed: | 8 | Cross-over | [underlined: Control:]
| | [underlined: Gender] | | [underlined: Control Group] | | | DL
| | Female: | 0 | Enrolled: | 8 | | [underlined: Mode of administration:]
| | Male: | 8 | Analyzed: | 8 | | Ocular
| | [underlined: Sleep disorder: None] | | | | | [underlined: Dosage and Timing:]
| | | | | | | BL: 2000 lux; DL: 1 lux for 3 hours (0600–0900)
| | | | | | | [underlined: Frequency and Duration:]
| | | | | | | Single session
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | No
Dollins, AB | 1993 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Treatment:]
Quality Score | 16 | Mean (SEM): | 23.0 (1.16) | Enrolled: | 24 | Blindedness: NS | Illuminated work stations at three different doses
| | Range: | 19–39 | Analyzed: | 21 | Cross-over | [underlined: Mode of administration:]
| | [underlined: Gender] | | [underlined: Control Group] | | | Ocular
| | Female: | 0 | Enrolled: | 24 | | [underlined: Dosage and Timing:]
| | Male: | 24 | Analyzed: | 21 | | 300 lux, 1500 lux, 3000 lux for 13.5 hours (1630-0800 h)
| | [underlined: Sleep disorder: None] | | | | | [underlined: Frequency and Duration:]
| | | | | | | One session/day for 3 days
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | No
Ecker, AJ | 2000 | [underlined: Age (Years)] | | [underlined: Treatment Group B] | | CCT | [underlined: Treatment:]
Quality Score | 10 | Mean (SD): | 28.5 (4.9) | Enrolled: | 4 | Blindedness: NS | Sleep restriction (Conditions B and C)
| | Range: | NS | Analyzed: | 4 | Parallel | [underlined: Control:]
| | [underlined: Gender] | | [underlined: Treatment Group C] | | | Normal sleep
| | Female: | 5 | Enrolled: | 4 | | [underlined: Timing:]
| | Male: | 8 | Analyzed: | 4 | | Control: 8.2 h anchor sleep (2154-0606 h);
| | [underlined: Sleep disorder: None] | | [underlined: Control Group] | | | Condition B: 4.2 h anchor sleep (2354-0406 h);
| | | | Enrolled: | 5 | | Condition C: 4.2 h anchor sleep (2354-0406 h and a daily 1.2 h nap (1324–1440 h)
| | | | Analyzed: | 5 | | [underlined: Frequency and Duration:]
| | | | | | | One session/day for 10 days
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | Yes
Gordijn, MC | 1998 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Treatment:]
Quality Score | 19 | Mean (SD): | 39.3 (12.1) | Enrolled: | 12 | Blindedness: NS | BL
| | Range: | 23.6–56.5 | Analyzed: | 12 | Cross-over | [underlined: Control:]
| | [underlined: Gender] | | [underlined: Control Group] | | | DL
| | Female: | 6 | Enrolled: | 12 | | [underlined: Mode of administration:]
| | Male: | 6 | Analyzed: | 12 | | Ocular
| | [underlined: Sleep disorder: None] | | | | | [underlined: Dosage and Timing:]
| | | | | | | BL: 2500 lux; DL: < 10 lux (0600–09:00 h or 1800–21:00 h)
| | | | | | | [underlined: Frequency and Duration:]
| | | | | | | One session/day for 3 days during 3 weeks
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | No
Gordijn, MC | 1999 | Patients: | | [underlined: Treatment Groups] | | CCT | [underlined: Treatment:]
Quality Score | 17 | [underlined: Age (Years)] | | Patients: | | Blindedness: NS | BL
| | Mean (SD): | 38.3 (12.2) | Enrolled: | 10 | Cross-over | [underlined: Control:]
| | Range: | NS | Analyzed: | 8 | | DL
| | [underlined: Gender] | | non-Patients: | | | [underlined: Mode of administration:]
| | Female: | 5 | Enrolled: | 8 | | Ocular
| | Male: | 5 | Analyzed: | 8 | | [underlined: Dosage and Timing:]
| | non-Patients: | | [underlined: Control Groups] | | | BL: 2500 lux, DL: < 10 lux. Morning: 0600–0900 h or Evening: 1800–2100 h)
| | [underlined: Age (Years)] | | Patients: | | | [underlined: Frequency and Duration:]
| | Mean (SD): | 38.7 (12.9) | Enrolled: | 10 | | One session/day for 3 days
| | Range: | NS | Analyzed: | 8 | | [underlined: Sleep deprivation:]
| | [underlined: Gender] | | non-Patients: | | | No
| | Female: | 3 | Enrolled: | 8
| | Male: | 5 | Analyzed: | 8
| | [underlined: Sleep disorder: Patients had Nonseasonal]
| | Depression, which may or may not have been accompanied by a sleep disorder.
Goh, VH | 2001 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Treatment:]
Quality Score | 18 | Mean (SD): | NS | Enrolled: | 7 | Blindedness: NS | Total sleep deprivation
| | Range: | 20–30 | Analyzed: | 7 | Parallel | [underlined: Control:]
| | [underlined: Gender] | | [underlined: Control Group] | | | Normal sleep
| | Female: | 0 | Enrolled: | 7 | | [underlined: Timing:]
| | Male: | 14 | Analyzed: | 7 | | Sleep deprivation: 34 hours (0800–1800 h the day after);
| | [underlined: Sleep disorder: None] | | | | | Normal sleep: 8 hours (2400-0800)
| | | | | | | [underlined: Frequency and Duration:]
| | | | | | | Single session
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | Yes
Goichot, B | 1998 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Treatment:]
Quality Score | 13 | Mean (SD): | NS | Enrolled: | 8 | Blindedness: NS | Sleep after a night of sleep deprivation followed by daytime sleep
| | Range: | 23–30 | Analyzed: | 8 | Cross-over | [underlined: Control:]
| | [underlined: Gender] | | [underlined: Control Group] | | | Normal sleep
| | Female: | 0 | Enrolled: | 8 | | [underlined: Timing:]
| | Male: | 8 | Analyzed: | 8 | | Sleep after a night of sleep deprivation: Daytime sleep: 0700–1500 h;
| | [underlined: Sleep disorder: None] | | | | | Normal sleep: 8 hours of sleep (2300-0700 h)
| | | | | | | [underlined: Frequency and Duration:]
| | | | | | | Single session
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | Yes
Higuchi, S | 2003 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Treatment:]
Quality Score | 15 | Mean (SD): | 24.7 (5.6) | Enrolled: | 7 | Blindedness: NS | Video display terminal with Bright display
| | Range: | NS | Analyzed: | 7 | Cross-over | [underlined: Control:]
| | [underlined: Gender] | | [underlined: Control Group] | | | Video display terminal with Dark display
| | Female: | 0 | Enrolled: | 7 | | [underlined: Mode of administration:]
| | Male: | 7 | Analyzed: | 7 | | Ocular
| | [underlined: Sleep disorder: None] | | | | | [underlined: Dosage and Timing:]
| | | | | | | Bright display: 45 lux, Dark display: 15 lux for 3 hours (2300-0200 h)
| | | | | | | [underlined: Frequency and Duration:]
| | | | | | | One session/day for 3 days
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | No
Horne, JA | 1991 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Treatment:]
Quality Score | 15 | Mean (SD): | NS | Enrolled: | 12 | Single-blinded | BL
| | Range: | 19–26 | Analyzed: | 12 | Cross-over | [underlined: Control:]
| | [underlined: Gender] | | [underlined: Control Group] | | | DL
| | Female: | 8 | Enrolled: | 12 | | [underlined: Mode of administration:]
| | Male: | 4 | Analyzed: | 12 | | Ocular
| | [underlined: Sleep disorder: None] | | | | | [underlined: Dosage and Timing:]
| | | | | | | BL: 2000 lux; DL: NS lux for 12 hours (1800-0600 h)
| | | | | | | [underlined: Frequency and Duration:]
| | | | | | | 10-min session/hour for 12 hours
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | Yes
Horowitz, TS | 2001 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Treatment:]
Quality Score | 16 | Mean (SD): | 26.99 (6.22) | Enrolled: | 26 | Blindedness: NS | BL
| | Range: | 20–40 | Analyzed: | 25 | Cross-over | [underlined: Control:]
| | [underlined: Gender] | | [underlined: Control Group] | | | DL
| | Treatment group: | | Enrolled: | 28 | | [underlined: Mode of administration:]
| | Female: | 10 | Analyzed: | 27 | | Ocular
| | Male: | 16 | | | | [underlined: Dosage and Timing:]
| | Control: | | | | | BL: 2500 lux for 6 hours (2300-0500 h);
| | Female: | 18 | | | | DL: 150 lux for 8 hours (2300-0700 h)
| | Male: | 10 | | | | [underlined: Frequency and Duration:]
| | [underlined: Sleep disorder: Shift-work disorder] | | | | | One session/day for 4 days
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | No
Jelinkova-Vondrasova, D | 1999 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Treatment:]
Quality Score | 14 | Mean (SD): | NS | Enrolled: | 8 | Blindedness: NS | Shift of the sleep period: 1) 3 h delay of the sleep period: 0100–0900 h,
| | Range: | 20–24 | Analyzed: | 8 | Cross-over | 2) 3-h advance of the sleep period: 2200-0600 h
| | [underlined: Gender] | | [underlined: Control Group] | | | [underlined: Timing:]
| | Female: | 5 | Enrolled: | 8 | | 3-h delay of the sleep period: 0100–0900 h;
| | Male: | 3 | Analyzed: | 8 | | 3-h advance of the sleep period: 2200 to 0600 h
| | [underlined: Sleep disorder: None] | | | | | [underlined: Frequency and Duration:]
| | | | | | | One session/day for 6 days
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | No
Jimerson, DC | 1977 | Patients: | | [underlined: Treatment Group] | | CCT | [underlined: Treatment:]
Quality Score | 15 | [underlined: Age (Years)] | | Patients: | | Blindedness: NS | Sleep deprivation
| | Mean (SD): | NS | Enrolled : | 6 | Cross-over | [underlined: Control:]
| | Range: | 19–50 | Analyzed: | 5 | | Normal sleep
| | [underlined: Gender] | | non-Patients: | | | [underlined: Timing:]
| | Female: | 5 | Enrolled : | 8 | | Sleep deprivation: 40 hours (0700–2300 h the day after);
| | Male: | 1 | Analyzed: | 5 | | Normal sleep: 8 hours (2300-0700 h)
| | non-Patients: | | [underlined: Control Group] | | | [underlined: Frequency and Duration:]
| | [underlined: Age (Years)] | | Patients: | | | Single session
| | Mean (SD): | NS | Enrolled : | 6 | | [underlined: Sleep deprivation:]
| | Range: | 19–65 | Analyzed: | 5 | | Yes
| | [underlined: Gender] | | non-Patients:
| | Female: | 2 | Enrolled : | 8
| | Male: | 4 | Analyzed: | 5
| | [underlined: Sleep disorder: Patients suffered from]
| | Depression, which may or may not have been accompanied by a sleep disorder.
Kelly, TL | 1997 | [underlined: Age (Years)] | | [underlined: Treatment Groups] | | CCT | [underlined: Treatment:]
Quality Score | 17 | Mean (SD): | NS | LEET group | | Double-blind | BL and LEET therapy (separately and combined)
| | Range: | NS | Enrolled : | 12 | Parallel | [underlined: Control:]
| | [underlined: Gender] | | Analyzed: | 12 | | DL
| | Female: | 0 | BL | | | [underlined: Mode of administration:]
| | Male: | 45 | Enrolled : | 12 | | Ocular
| | LEET group | | Analyzed: | 8 | | [underlined: Dosage and Timing]
| | [underlined: Age (Years)] | | BL + LEET | | | LEET: 20 min. prior to daytime sleep periods. BL: 3500–4300 lux,
| | Mean (SD): | 24.8 (7.9) | Enrolled : | 11 | | DL: 200–300 lux for 4 hours (2200-0200 h)
| | Range: | NS | Analyzed: | 11 | | [underlined: Frequency and Duration:]
| | BL | | [underlined: Control Group] | | | One session/day for 3 days
| | [underlined: Age (Years)] | | DL | | | [underlined: Sleep deprivation:]
| | Mean (SD): | 22.5 (3.5) | Enrolled : | 10 | | No
| | Range: | NS | Analyzed: | 7
| | BL + LEET
| | [underlined: Age (Years)]
| | Mean (SD): | 23.4 (4.1)
| | Range: | NS
| | DL
| | [underlined: Age (Years)]
| | Mean (SD): | 25.2 (7.7)
| | Range: | NS
| | [underlined: Sleep disorder: Shift-work disorder]
Koorengevel, KM | 2001 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Treatment:]
Quality Score | 19 | Treatment group: | | Enrolled : | 15 | Double-blind | Light therapy
| | Mean (SD): | 39.6 (12.2) | Analyzed: | 13 | Parallel | [underlined: Control:]
| | Range: | NS | [underlined: Control Group] | | | Placebo (No light)
| | Control group: | | Enrolled : | 14 | | [underlined: Mode of administration:]
| | Mean (SD): | 43.4 (12.4) | Analyzed : | 11 | | E-O (behind the knees)
| | Range: | NS | | | | [underlined: Dosage and Timing:]
| | [underlined: Gender] | | | | | 13000 lux for 3 hours (0800–1100 h)
| | Treatment group: | | | | | [underlined: Frequency and Duration:]
| | Female: | 11 | | | | One session/day for 5 days
| | Male: | 4 | | | | [underlined: Sleep deprivation:]
| | Control group: | | | | | No
| | Female: | 10
| | Male: | 4
| | [underlined: Sleep disorder: Participants suffered from]
| | SAD, which may or may not be accompanied by a sleep disorder.
Kubota, T | 2002 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Treatment:]
Quality Score | 18 | Mean (SD): | 24 (NS) | Enrolled : | 9 | Blindedness: NS | BL
| | Range: | 20–27 | Analyzed: | 9 | Cross-over | [underlined: Control:]
| | [underlined: Gender] | | [underlined: Control Group] | | | DL
| | Female: | 0 | Enrolled : | 9 | | [underlined: Mode of administration:]
| | Male: | 9 | Analyzed : | 9 | | Ocular
| | [underlined: Sleep disorder: None] | | | | | [underlined: Dosage and Timing:]
| | | | | | | BL: 5000 lux for 5 hours; DL: 10 lux for 5 hours (0000–0500 h)
| | | | | | | [underlined: Frequency and Duration:]
| | | | | | | Single session
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | Yes
Lavoie, S | 2003 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Treatment:]
Quality Score | 17 | Mean (SD): | 26.1 (4.2) | Enrolled : | 7 | Blindedness: NS | BL
| | Range: | 22–35 | Analyzed: | 7 | Parallel | [underlined: Control:]
| | [underlined: Gender] | | [underlined: Control Group] | | | DL
| | Female: | 8 | Enrolled : | 7 | | [underlined: Mode of administration:]
| | Male: | 6 | Analyzed : | 7 | | Ocular
| | [underlined: Sleep disorder: None] | | | | | [underlined: Dosage and Timing:]
| | | | | | | BL: 3000 lux; DL: 15 lux for 4 hours (0030–0430 h)
| | | | | | | [underlined: Frequency and Duration:]
| | | | | | | Single session
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | Yes
Lushington, K | 2002 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Treatment:]
Quality Score | 18 | Mean (SD): | 22.1 (3.0) | Enrolled : | 13 | Single-blind | Light
| | Range: | 13–34 | Analyzed: | 13 | Cross-over | [underlined: Control:]
| | [underlined: Gender] | | [underlined: Control Group] | | | Placebo (No light)
| | Female: | 3 | Enrolled : | 13 | | [underlined: Mode of administration:]
| | Male: | 10 | Analyzed : | 13 | | E-O (behind the knee)
| | [underlined: Sleep disorder: None] | | | | | [underlined: Dosage and Timing:]
| | | | | | | Light: 10000 lux for 3 hours (0100–0400 h)
| | | | | | | [underlined: Frequency and Duration:]
| | | | | | | One session/day for 3 nights
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | No
Morris, M | 1990 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Treatment:]
Quality Score | 17 | Mean (SD): | 27 (NS) | Enrolled : | 8 | Blindedness: NS | Continuous wakefulness
| | Range: | NS | Analyzed: | 8 | Cross-over | [underlined: Control:]
| | [underlined: Gender] | | [underlined: Control Group] | | | Nightime sleep
| | Female: | 3 | Enrolled : | 8 | | [underlined: Timing:]
| | Male: | 5 | Analyzed : | 8 | | Continuous wakefulness: 24 hours; Nightime sleep: 2200-1000 h
| | [underlined: Sleep disorder: None] | | | | | [underlined: Frequency and Duration:]
| | | | | | | Single session
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | Yes
Partonen, T | 1996 | Patients | | [underlined: Treatment Group] | | RCT | [underlined: Treatment:]
Quality Score | 19 | [underlined: Age (Years)] | | Patients: | | Blindedness: NS | BL 1 hour
| | Mean (SEM): | 40.2 (2.2) | Enrolled : | 7 | Parallel | [underlined: Control:]
| | Range: | 23–55 | Analyzed: | 7 | | BL 15 minutes
| | [underlined: Gender] | | non-Patients: | | | [underlined: Mode of administration:]
| | Female: | 16 | Enrolled : | 5 | | Ocular
| | Male: | 0 | Analyzed: | 5 | | [underlined: Dosage and Timing:]
| | non-Patients | | [underlined: Control Group] | | | BL: 3300 lux for: 1 hour, or 15 minutes (between 06:00–08:00 h)
| | [underlined: Age (Years)] | | Patients: | | | [underlined: Frequency and Duration:]
| | Mean (SEM): | 41.6 (3.6) | Enrolled : | 9 | | One session/day for 14 days during the winter
| | Range: | 24–64 | Analyzed: | 9 | | [underlined: Sleep deprivation:]
| | [underlined: Gender] | | non-Patients: | | | No
| | Female: | 13 | Enrolled : | 8
| | Male: | 0 | Analyzed: | 8
| | [underlined: Sleep disorder: Patients suffered from SAD,]
| | which may or may not be accompanied by a sleep disorder.
Rao, ML | 1996 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Treatment:]
Quality Score | 19 | Median (IR): | 25.5 (NS) | Enrolled : | 12 | Single-blind | SWS deprivation
| | Range: | 20–33 | Analyzed: | 12 | Cross-over | [underlined: Control:]
| | [underlined: Gender] | | [underlined: Control Group] | | | Normal sleep
| | Female: | 0 | Enrolled : | 12 | | [underlined: Timing:]
| | Male: | 12 | Analyzed : | 12 | | SWS deprivation; Normal sleep for 12 hours (2100-0900 h)
| | [underlined: Sleep disorder: None] | | | | | [underlined: Frequency and Duration:]
| | | | | | | One session/night for 2 nights
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | Yes
Redwine, L | 2000 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Treatment:]
Quality Score | 17 | Mean (SD): | 35.8 (10.12) | Enrolled : | 31 | Blindedness: NS | Partial sleep deprivation
| | Range: | 25–65 | Analyzed: | 31 | Cross-over | [underlined: Control:]
| | [underlined: Gender] | | [underlined: Control Group] | | | Uninterrupted sleep
| | Female: | 0 | Enrolled : | 31 | | [underlined: Timing:]
| | Male: | 31 | Analyzed : | 31 | | Partial sleep deprivation: Sleep time for 5 hours (2200-300 h);
| | [underlined: Sleep disorder: None] | | | | | Control sleep: Sleep time for 9 hours (2200-0700 h).
| | | | | | | [underlined: Frequency and Duration:]
| | | | | | | One session/night for 2 nights
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | Yes
Ross, JK | 1995 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Treatment:]
Quality Score | 17 | Mean (SD): | NS | Enrolled : | 8 | Blindedness: NS | BL
| | Range: | 21–35 | Analyzed: | 7 | Cross-over | [underlined: Control:]
| | [underlined: Gender] | | [underlined: Control Group] | | | DL
| | Female: | 0 | Enrolled : | 7 | | [underlined: Mode of administration:]
| | Male: | 14 | Analyzed : | 6 | | Ocular
| | [underlined: Sleep disorder: Shift-work disorder] | | | | | [underlined: Dosage and Timing:]
| | | | | | | BL: 2500–3000 lux; DL: < 500 lux for 2 hours (1100–13:00 h)
| | | | | | | [underlined: Frequency and Duration:]
| | | | | | | One session/day for 7 days
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | No
Salin-Pascual RJ | 1988 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Treatment:]
Quality Score | 17 | Mean (SD): | 20.83 (2.97) | Enrolled : | 12 | Blindedness: NS | Sleep deprivation
| | Range: | 16–26 | Analyzed: | 12 | Cross-over | [underlined: Control:]
| | [underlined: Gender] | | [underlined: Control Group] | | | Normal sleep
| | Female: | 3 | Enrolled : | 12 | | [underlined: Timing:]
| | Male: | 9 | Analyzed : | 12 | | Sleep deprivation: 36 hours of sleep-deprivation;
| | [underlined: Sleep disorder: None] | | | | | Normal sleep: ~8 hours (1000-0600 h)
| | | | | | | [underlined: Frequency and Duration:]
| | | | | | | Single session
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | Yes
Samel A | 1993 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Treatment:]
Quality Score | 15 | Mean (SD): | 23.0 (3.3) | Enrolled : | 8 | Blindedness: NS | Sleep-wake cycle advance
| | Range: | 20–29 | Analyzed: | 8 | Cross-over | [underlined: Control:]
| | [underlined: Gender] | | [underlined: Control Group] | | | Normal sleep
| | Female: | 0 | Enrolled : | 8 | | [underlined: Timing:]
| | Male: | 8 | Analyzed : | 8 | | Sleep-wake advance: 7-h advance. Normal sleep: 9 hours. Clock-time: NS.
| | [underlined: Sleep disorder: None] | | | | | [underlined: Frequency and Duration:]
| | | | | | | One session/day for 7 days
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | Yes
von Treuer K | 1996 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Treatment:]
Quality Score | 14 | Mean (SD): | NS | Enrolled : | 9 | Blindedness: NS | Sleep deprivation night
| | Range: | 17–29 | Analyzed: | 9 | Cross-over | [underlined: Control:]
| | [underlined: Gender] | | [underlined: Control Group] | | | Control night
| | Female: | 0 | Enrolled : | 9 | | [underlined: Timing:]
| | Male: | 9 | Analyzed : | 9 | | Sleep deprivation: 36 hours (0700–2000 h the day after); Normal sleep: NS
| | [underlined: Sleep disorder: None] | | | | | [underlined: Frequency and Duration:]
| | | | | | | Single session
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | Yes
Wakamura, T | 2000 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Treatment:]
Quality Score | 17 | Mean (SD): | 20 (2) | Enrolled : | 7 | Blindedness: NS | BL
| | Range: | 18–23 | Analyzed: | 7 | Cross-over | [underlined: Control:]
| | [underlined: Gender] | | [underlined: Control Group] | | | DL
| | Female: | 7 | Enrolled : | 7 | | [underlined: Mode of administration:]
| | Male: | 0 | Analyzed : | 7 | | Ocular
| | [underlined: Sleep disorder: None] | | | | | [underlined: Dosage and Timing:]
| | | | | | | BL: 6000 lux; DL: 2000 lux (1800-bedtime h)
| | | | | | | [underlined: Frequency and Duration:]
| | | | | | | Single session
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | No
Wehr, TA | 1991 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Treatment:]
Quality Score | 14 | Mean (SD): | NS | Enrolled : | 8 | Blindedness: NS | Summer photoperiod
| | Range: | 20–36 | Analyzed: | 7 | Cross-over | [underlined: Control:]
| | [underlined: Gender] | | [underlined: Control Group] | | | Winter photoperiod
| | Female: | 0 | Enrolled : | [underlined: 8] | | [underlined: Dosage and Timing:]
| | Male: | 8 | Analyzed : | 7 | | Summer photoperiod: 16 h of light and 8 hours of darkness for 1 week.
| | [underlined: Sleep disorder: None] | | | | | Winter photoperiod: 10 h of light and 14 h of darkness for 4 weeks. Clock time: NS
| | | | | | | [underlined: Frequency and Duration:]
| | | | | | | Summer photoperiod: One session/day for 1 week
| | | | | | | Winter photoperiod: 1 session/day for 4 weeks
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | No
Weibel, L | 1997 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Treatments:]
Quality Score | 19 | Mean (SD): | NS | Enrolled : | 19 | Non-blinded | Sleep period shift (day-active workers sleeping during the day)
| | Range: | NS | Analyzed: | 19 | Cross-over | [underlined: Control:]
| | [underlined: Gender] | | [underlined: Control Group] | | | Normal sleep (day-active workers sleeping at night)
| | Female: | 0 | Enrolled : | 19 | | [underlined: Timing:]
| | Male: | 19 | Analyzed : | 19 | | Sleep period shift: 8 hours (0700–1500);
| | [underlined: Sleep disorder: None] | | | | | Normal sleep: 8 hours (2300-0700 h)
| | | | | | | [underlined: Frequency and Duration:]
| | | | | | | Single session
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | Yes
Yoon I | 2000 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Treatment:]
Quality Score | 8 | Mean (SD): | NS | Enrolled : | 17 | Non-blinded | Light-1, Light-2
| | Range: | 20–41 | Analyzed: | 17 | Cross-over | [underlined: Control:]
| | [underlined: Gender] | | [underlined: Control Group] | | | Baseline light
| | Female: | NS | Enrolled : | 17 | | [underlined: Dosage and Timing:]
| | Male: | NS | Analyzed : | 17 | | Light-1: 4000–6000 lux for 4 h (night shift) followed by 1h exposure to sunlight or 10000 lux next morning; Light-2:
| | [underlined: Sleep disorder: Shift-work disorder] | | | | | Same light exposure without sunlight/10000 lux. Control: No light exposure. Clock time: NS
| | | | | | | [underlined: Frequency and Duration:]
| | | | | | | One session/day for 4 days
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | No

Abbreviations: RCT: Randomized Controlled Trial, CCT: Controlled Clinical Trial, MLT: Melatonin, SD: Standard Deviation, SE: Standard Error, SEM: Standard Error of the Mean, IR: Inter-quartile range, NS: Not Specified, BL: Bright Light, DL: Dim Light, E-O: Extra-Ocular, Ocular: Eye-directed including room/ambient, SAD: Seasonal Affective Disorder, LEET: Low Energy Emission Therapy, SWS: Slow-wave sleep

Evidence Table C-4: Mechanisms by which Melatonin Produces Sleepiness: Study Characteristics

Author | Year | Population | | Sample Size | N | Study Design | Intervention
Almeida- Montes, LG | 2003 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 5 | Mean (SD): | 50 (NS) | Enrolled: | 10 | Double-blind | Sustained-release (SR) MLT
| | Range: | 30–72 | Analyzed: | 10 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | Female: | 4 | Enrolled: | 10 | | [underlined: Dosage and Timing]
| | Male: | 6 | Analyzed: | 10 | | 0.3 mg or 1 mg of MLT one hour before bedtime
| | [underlined: Sleep Disorder:] | | | | | [underlined: Frequency and Duration]
| | [underlined: Insomnia] | | | | | One dose/day for 14 days
Andrade, C | 2001 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 4 | Treatment group | | Enrolled: | 18 | Double-blind | NS
| | Mean (SD): | 59.7 (11.1) | Analyzed: | 18 | Parallel | [underlined: Route of Administration]
| | Range: | 43–85 | | | | Oral
| | Control group | | [underlined: Control Group] | | | [underlined: Dosage and Timing]
| | Mean (SD): | 51.4 (14.2) | Enrolled: | 15 | | 3 mg MLT taken at night
| | Range: | 23–70 | Analyzed: | 15 | | [underlined: Frequency]
| | [underlined: Gender] | | | | | 1 capsule/night for the first two nights, 2 capsules every alternate night thereafter up to 4 capsules/night
| | Treatment group | | | | | [underlined: Duration]
| | Female: | 4 | | | | 21 patients (MLT n=11, PLB n=10) received treatment for 8 days. 8 patients (MLT n=5, PLB n=3) received treatment for 10 days, and 4 patients (MLT n=2, PLB n=2) received treatment for 16 days
| | Male: | 14
| | Control group
| | Female: | 5
| | Male: | 10
| | [underlined: Sleep Disorder:]
| | [underlined: Insomnia]
Dahlitz, M | 1991 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 4 | Mean (SD): | NS | Enrolled: | 8 | Double-blind | NS
| | Range: | 20–60 | Analyzed: | 8 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | Female: | 0 | Enrolled: | 8 | | [underlined: Dosage and Timing]
| | Male: | 8 | Analyzed: | 8 | | 5 mg MLT at 2200 h
| | [underlined: Sleep Disorder:] | | | | | [underlined: Frequency and Duration]
| | [underlined: Delayed sleep phase syndrome] | | | | | One dose/day for 4 weeks
Edwards, BJ | 2000 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Formulation]
Quality Score | 22 | Treatment Group | | Enrolled: | 14 | Double-blind | Not specified
| | mean (SD): | 40(13) | Analyzed: | 13 | Parallel | [underlined: Route of Administration]
| | range: | NS | [underlined: Control Group] | | | Oral
| | Control Group | | Enrolled: | 17 | | [underlined: Dosage and Timing]
| | mean (SD): | 41(12) | Analyzed: | 13 | | 5mg MLT taken on the plane between 18:00–19:00h and between 22:00 and 23:00h, according to local time at destination and for the next three evenings
| | range: | NS | | | | [underlined: Frequency and Duration]
| | [underlined: Gender] | | | | | 2 capsules/day for first day and then 1 capsule/day for 2 days
| | female: | 3
| | male: | 28
| | [underlined: Sleep Disorder: Jet-lag]
Folklard, S | 1993 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 3 | Mean (SD): | 29 (7) | Enrolled: | 7 | Double-blind | NS
| | Range: | 21–48 | Analyzed: | 7 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | Female: | 2 | Enrolled: | 8 | | [underlined: Dosage and Timing]
| | Male: | 15 | Analyzed: | 8 | | 5 mg MLT at 0642 h
| | [underlined: Sleep Disorder:] | | | | | [underlined: Frequency and Duration]
| | [underlined: Night-shift disorder] | | | | | One dose/day for 6 successive day sleeps taken between night shifts
Holmes, A.L. | 2002 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Formulation]
Quality Score | 15 | Mean (SD): | 20.3 (0.6) | Enrolled: | 12 | Double-blind | NS
| | Range: | 19–25 | Analyzed: | 12 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | Female: | 5 | Enrolled: | 12 | | [underlined: Dosage and Timing]
| | Male: | 7 | Analyzed: | 12 | | 5 mg MLT at 1400 h
| | [underlined: Sleep Disorder:] | | | | | [underlined: Frequency and Duration]
| | [underlined: Normal sleepers] | | | | | Single dose
Mishima, K | 1997 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 16 | Mean (SD): | 22.5 (1.9) | Enrolled: | 6 | Single-blind | NS
| | Range: | | Analyzed: | 6 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | Female: | 0 | Enrolled: | 6 | | [underlined: Dosage and Timing]
| | Male: | 6 | Analyzed: | 6 | | 3 mg or 9 mg MLT at 0930 h
| | [underlined: Sleep Disorder:] | | | | | [underlined: Frequency and Duration]
| | [underlined: Normal sleepers] | | | | | One dose/day for 2 days
Petrie | 1989 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 20 | Mean (SD): | NS | Enrolled: | 20 | Double-blind | NS
| | Range: | 28–68 | Analyzed: | 20 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | NS
| | Female: | 8 | Enrolled: | 20 | | [underlined: Dosage and Timing]
| | Male: | 12 | Analyzed: | 20 | | 5 mg MLT between 1000 h and 1200 h local time
| | [underlined: Sleep Disorder: Jet Lag] | | | | | [underlined: Frequency and Duration]
| | | | | | | One dose/day for 3 days (before flight, during flight, and once a day for 3 days after arrival)
Satomura, T | 2001 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 11 | Mean (SD): | 23.7(1.7) | Enrolled: | 7 | Single-blind | NS
| | Range: | NS | Analyzed: | 7 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | Female: | 0 | Enrolled: | 7 | | [underlined: Dosage and Timing]
| | Male: | 7 | Analyzed: | 7 | | 1 mg, 3 mg, or 6 mg MLT at 1330 h
| | [underlined: Sleep Disorder:] | | | | | [underlined: Frequency and Duration]
| | [underlined: Normal sleepers] | | | | | Single dose
Terlo, L | 1997 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Formulation]
Quality Score | 19 | Mean (SD): | 28(2) | Enrolled: | 10 | Double-blind | NS
| | Range: | NS | Analyzed: | 10 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | Female: | 0 | Enrolled: | 10 | | [underlined: Dosage and Timing]
| | Male: | 10 | Analyzed: | 10 | | 0.1 mg, 0.5 mg or 1 mg MLT at 1600 h
| | [underlined: Sleep Disorder:] | | | | | [underlined: Frequency and Duration]
| | [underlined: Normal sleepers] | | | | | One dose/day for 4 non-consecutive days
Zhdanova, I | 1995 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 18 | Mean (SD): | 26.5(1.3) | Enrolled: | 6 | Double-blind | NS
| | Range: | 25–64 | Analyzed: | 6 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | Female: | 0 | Enrolled: | 6 | | [underlined: Dosage and Timing]
| | Male: | 6 | Analyzed: | 6 | | 0.3 mg, or 1.0 mg MLT at 1800 h or between 2000 h –21:00 h
| | [underlined: Sleep Disorder:] | | | | | [underlined: Frequency and Duration]
| | [underlined: Normal sleepers] | | | | | One dose/day for 9 days

Abbreviations: RCT: randomized controlled trial, CCT: controlled clinical trial, MLT: melatonin, FR: fast-release, SR: slow-release, SD: standard deviation, SE: standard error, mg: milligrams, h: hours, NS: not specified

Control group received placebo unless otherwise indicated

Evidence Table C-5: Effect of Melatonin on Normal Sleepers: Study Characteristics

Author | Year | Population | | Sample Size | N | Study Design | Intervention
Attenburrow M | 1996 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 17 | mean: | 53.9 | Enrolled: | 15 | Double-blind | Not specified
| | range: | 41–67 | Analyzed: | 12 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Not specified
| | female: | 11 | Enrolled: | 15 | | [underlined: Dosage and Timing]
| | male: | 4 | Analyzed: | 12 | | 0.3 or 1.0mg MLT two hours before bedtime (2200–2300h)
| | | | | | | [underlined: Frequency and Duration]
| | | | | | | 0.3 or 1.0mg/night for 3 nights
Baskett, J | 2003 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 25 | mean: | NS | Enrolled: | 20 | Double-blind | Not specified
| | range: | 60–84 | Analyzed: | 14 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 16 | Enrolled: | 20 | | [underlined: Dosage and Timing]
| | male: | 4 | Analyzed: | 14 | | 5mg MLT at bedtime
| | | | | | | [underlined: Frequency and Duration]
| | | | | | | 1 capsule/day for 4 weeks
Cajochen, C | 1998 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 18 | mean (SD): | 27(5) | Enrolled: | 10 | Single-blind | Not specified
| | range: | NS | Analyzed: | 10 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 0 | Enrolled: | 10 | | [underlined: Dosage and Timing]
| | male: | 10 | Analyzed: | 10 | | 5 mg of MLT, timing: NS
| | | | | | | [underlined: Frequency and Duration]
| | | | | | | 1 capsule/week for 2 weeks
Cajochen, C | 1997 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 16 | mean: | NS | Enrolled: | 8 | Double-blind | Not specified
| | range: | 23–32 | Analyzed: | 8 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 0 | Enrolled: | 8 | | [underlined: Dosage and Timing]
| | male: | 8 | Analyzed: | 8 | | 5 mg MLT at 1800h
| | | | | | | [underlined: Frequency and Duration]
| | | | | | | Single dose
Dollins, A.B. | 1994 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 18 | mean (SD): | 23.05(4.22) | Enrolled: | 20 | Double-blind | Not specified
| | range: | 18–24 | Analyzed: | 20 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 0 | Enrolled: | 20 | | [underlined: Dosage and Timing]
| | male: | 20 | Analyzed: | 20 | | 0.1, 0.3, 1.0 or 10mg MLTat 1145h
| | | | | | | [underlined: Frequency and Duration]
| | | | | | | 1 capsule/day for 5 days
Ferini-Strambi | 1993 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Formulation]
Quality Score | 14 | mean (SD): | 25.3(3.6) | Enrolled: | 6 | Single-blind | Not specified
| | range: | NS | Analyzed: | 6 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 0 | Enrolled: | 6 | | [underlined: Dosage and Timing]
| | male: | 6 | Analyzed: | 6 | | 100mg MLT at 1030h
| | | | | | | [underlined: Frequency and Duration]
| | | | | | | 1 tablet on nights 4 and 7
Holmes, A.L. | 2002 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Formulation]
Quality Score | 15 | mean (SD): | 20.3(0.6) | Enrolled: | 12 | Double-blind | Not specified
| | range: | 19–25 | Analyzed: | 12 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 5 | Enrolled: | 12 | | [underlined: Dosage and Timing]
| | male: | 7 | Analyzed: | 12 | | 5 mg MLT at 1400h
| | | | | | | [underlined: Frequency and Duration]
| | | | | | | Single dose
James, S.P | 1987 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 17 | mean: | 29.9 | Enrolled: | 11 | Double-blind | Not specified
| | range: | 21–40 | Analyzed: | 10 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Not specified
| | female: | 3 | Enrolled: | 11 | | [underlined: Dosage and Timing]
| | male: | 7 | Analyzed: | 10 | | 1mg or 5mg MLT at 2245h
| | | | | | | [underlined: Frequency and Duration]
| | | | | | | 1mg or 5mg/day for 3 weeks
Luboshitzky R | 2000 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Formulation]
Quality Score | 19 | mean (SD): | 23.9(2.4) | Enrolled: | 6 | Double-blind | Not specified
| | range: | NS | Analyzed: | 6 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 0 | Enrolled: | 6 | | [underlined: Dosage and Timing]
| | male: | 6 | Analyzed: | 6 | | 6 mg MLT at 1700h
| | | | | | | [underlined: Frequency and Duration]
| | | | | | | 6mg/day for 1 month
Matsumomo M | 1999 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Formulation]
Quality Score | 19 | mean (SD): | 23.7(1.3) | Enrolled: | 6 | Single-blind | Not specified
| | range: | NS | Analyzed: | 6 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Not specified
| | female: | 0 | Enrolled: | 6 | | [underlined: Dosage and Timing]
| | male: | 6 | Analyzed: | 6 | | 10 mg of MLT at 1000h
| | | | | | | [underlined: Frequency and Duration]
| | | | | | | Single dose
Mishima, K | 1997 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 16 | mean (SD): | 22.5(1.9) | Enrolled: | 6 | Single-blind | Not specified
| | range: | NS | Analyzed: | 6 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 0 | Enrolled: | 6 | | [underlined: Dosage and Timing]
| | male: | 6 | Analyzed: | 6 | | 3mg or 9mg MLT capsule at 0930h
| | | | | | | [underlined: Frequency and Duration]
| | | | | | | 1 caspsule/day for 2 days
Nave, R | 1995 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 19 | mean (SD): | 24.6(2.7) | Enrolled: | 12 | Double-blind | Not specified
| | range: | NS | Analyzed: | 12 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 12 | Enrolled: | 12 | | [underlined: Dosage and Timing]
| | male: | 0 | Analyzed: | 12 | | 3mg or 6mg MLT at 1600h and 1730h
| | | | | | | [underlined: Frequency and Duration]
| | | | | | | Single dose/week for 5 weeks
Nickelson, T | 1989 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Formulation]
Quality Score | 16 | female mean (SD): | 30.0(7.9) | Enrolled: | 12 | Double-blind | Not specified
| | male mean (SD): | 30.4(6.2) | Analyzed: | 12 | Parallel | [underlined: Route of Administration]
| | female range: | 23–46 | [underlined: Control Group] | | | Oral
| | male range: | 20–39 | Enrolled: | 13 | | [underlined: Dosage and Timing]
| | [underlined: Gender] | | Analyzed: | 13 | | 50mg of MLT at 0900h or 1900h
| | female: | 11 | | | | [underlined: Frequency and Duration]
| | male: | 14 | | | | 1 capsule/day for 1 week
Pires, M.L | 2001 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 10 | mean: | NS | Enrolled: | 6 | Double-blind | Not specified
| | range: | 22–24 | Analyzed: | 6 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 0 | Enrolled: | 6 | | [underlined: Dosage and Timing]
| | male: | 6 | Analyzed: | 6 | | 0.3 and 1.0 mg MLT at 3 fixed times:1800, 2000, and 2100 hour
| | | | | | | [underlined: Frequency and Duration]
| | | | | | | 3 doses/day of each dose over 9 sessions
Reid, K | 1996 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Formulation]
Quality Score | 15 | mean (SD): | 20.3(2.4) | Enrolled: | 16 | Double-blind | Not specified
| | range: | NS | Analyzed: | 16 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 0 | Enrolled: | 16 | | [underlined: Dosage and Timing]
| | male: | 16 | Analyzed: | 16 | | 5 mg MLT capsule at 1400h
| | | | | | | [underlined: Frequency and Duration]
| | | | | | | Single dose
Satomura, T | 2001 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 11 | mean (SD): | 23.7(1.7) | Enrolled: | 7 | Single-blind | Not specified
| | range: | NS | Analyzed: | 7 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 0 | Enrolled: | 7 | | [underlined: Dosage and Timing]
| | male: | 7 | Analyzed: | 7 | | 1mg, 3mg, 6mg of MLT at 13:30 h
| | | | | | | [underlined: Frequency and Duration]
| | | | | | | Single dose
Seabra, M.L. | 2000 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 20 | mean (SD): | 29(1) | Enrolled: | 30 | Double-blind | Not specified
| | range: | 25–55 | Analyzed: | 30 | Parallel | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 0 | Enrolled: | 10 | | [underlined: Dosage and Timing]
| | male: | 40 | Analyzed: | 10 | | 10 mg MLT one hour before sleep time (approx. 2200h)
| | | | | | | [underlined: Frequency and Duration]
| | | | | | | 1 capusule/day for 28 days
Terlo, L | 1997 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Formulation]
Quality Score | 19 | mean (SD): | 28(2) | Enrolled: | 10 | Double-blind | Not specified
| | range: | NS | Analyzed: | 10 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 0 | Enrolled: | 10 | | [underlined: Dosage and Timing]
| | male: | 10 | Analyzed: | 10 | | 0.1, 0.5 or 1mg MLT tablet at 16:00h
| | | | | | | [underlined: Frequency and Duration]
| | | | | | | 1 tablet/day for 4 non-consecutive days
Zhdanova, I | 1995 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 18 | mean (SD): | 26.5(1.3) | Enrolled: | 6 | Double-blind | Not specified
| | range: | 25–64 | Analyzed: | 6 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 0 | Enrolled: | 6 | | [underlined: Dosage and Timing]
| | male: | 6 | Analyzed: | 6 | | 0.3mg and 1.0mg at 1800h or between 2000h and 2100h
| | | | | | | [underlined: Frequency and Duration]
| | | | | | | Single dose for 9 sessions
Zhdanova, I | 1996 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 16 | mean (SD): | 28.5(1.8) | Enrolled: | 12 | Double-blind | Not specified
| | range: | NS | Analyzed: | 12 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 0 | Enrolled: | 12 | | [underlined: Dosage and Timing]
| | male: | 12 | Analyzed: | 12 | | 0.3 or 1.0mg MLT at 2100h, 2–4 hours before habitual bedtime
| | | | | | | [underlined: Frequency and Duration]
| | | | | | | 1 tablet/day for 2 days
Zisapel, N | 1997 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Formulation]
Quality Score | 17 | mean (SD): | 28(2) | Enrolled: | 10 | Double-blind | Not specified
| | range: | NS | Analyzed: | 10 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 0 | Enrolled: | 10 | | [underlined: Dosage and Timing]
| | male: | 10 | Analyzed: | 10 | | 2mg MLT at 1100h
| | | | | | | [underlined: Frequency and Duration]
| | | | | | | 1 tablet/day for 3 non-consecutive days

Abbreviations: RCT: randomized controlled trial, CCT: controlled clinical trial, MLT: melatonin, FR: fast-release, SR: slow-release, SD: standard deviation, SE: standard error, mg: milligrams, h: hours, NS: not specified

Control group received placebo unless otherwise indicated

Evidence Table C-6: Melatonin and the Temperature Rhythm: Study Characteristics

Author | Year | Population | | Sample Size | N | Study Design | Intervention
Ando, K | 1999 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Treatment:]
Quality Score | 19 | Treatment group: | | Enrolled : | 6 | Blindedness: NS | BL
| | Mean (SD): | 34.4 (13.8) | Analyzed: | 5 | Parallel | [underlined: Control:]
| | Range: | NS | [underlined: Control Group] | | | Placebo light
| | Control Group: | | Enrolled : | 6 | | [underlined: Mode of administration:]
| | Mean (SD): | 32.6 (8.1) | Analyzed : | 5 | | Ocular
| | Range: | NS | | | | [underlined: Dosage and Timing:]
| | [underlined: Gender:] | | | | | BL: 500 lux; Placebo light: 0.1 lux for 3 hours. Clock time: NS
| | Treatment group: | | | | | [underlined: Frequency and Duration:]
| | Female: | 1 | | | | One session/day for 12 days
| | Male: | 4 | | | | [underlined: Sleep deprivation:]
| | Control Group: | | | | | No
| | Female: | 2
| | Male: | 3
| | [underlined: Sleep disorder: Delayed]
| | [underlined: Sleep Phase Syndrome]
Bunnell, D | 1992 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Treatment:]
Quality Score | 12 | Mean (SD): | NS | Enrolled : | 5 | Blindedness: NS | BL
| | Range: | 20–28 | Analyzed: | 5 | Cross-over | [underlined: Control:]
| | [underlined: Gender] | | [underlined: Control Group] | | | DL
| | Female: | 0 | Enrolled : | 5 | | [underlined: Mode of administration:]
| | Male: | 5 | Analyzed: | 5 | | Ocular
| | [underlined: Sleep disorder: None] | | | | | [underlined: Dosage and Timing:]
| | | | | | | BL: 2500 lux; DL: < 100 lux for 2 h prior to sleep. Clock time: NS
| | | | | | | [underlined: Frequency and Duration:]
| | | | | | | One session/day for 2 days
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | No
Burgess, H | 2001 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Treatment:]
Quality Score | 17 | Mean (SE): | 21.3 (2.7) | Enrolled : | 16 | Double-blind | BL
| | Range: | NS | Analyzed: | 14 | Cross-over | Control:
| | [underlined: Gender] | | [underlined: Control Group] | | | DL
| | Female: | 8 | Enrolled : | 16 | | [underlined: Mode of administration:]
| | Male: | 8 | Analyzed : | 14 | | Ocular
| | [underlined: Sleep disorder: None] | | | | | [underlined: Dosage and Timing:]
| | | | | | | BL: >3000 lux; DL: < 10 lux for 2 hours. Clock time: NS
| | | | | | | [underlined: Frequency and Duration:]
| | | | | | | Single session
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | No
Cagnacci, A | 1993 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Treatment:]
Quality Score | 15 | Mean (SD): | NS | Enrolled : | 7 | Blindedness: NS | BL
| | Range: | 23–34 | Analyzed: | 7 | Cross-over | [underlined: Control:]
| | [underlined: Gender] | | [underlined: Control Group] | | | DL
| | Female: | 7 | Enrolled : | 7 | | [underlined: Mode of administration:]
| | Male: | 0 | Analyzed: | 7 | | Ocular
| | [underlined: Sleep disorder: None] | | | | | [underlined: Dosage and Timing:]
| | | | | | | BL: 3000 lux for 4 hours (2100-0100);
| | | | | | | DL: 10 lux for 8 hours (1700-0115 h)
| | | | | | | [underlined: Frequency and Duration:]
| | | | | | | Single session
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | No
Cajochen, C | 2000 | [underlined: Age (Years)] | | [underlined: Treatment Groups] | | RCT | [underlined: Treatments:]
Quality Score | 16 | Mean (SD): | 27.8 (8.91) | Enrolled : | 23 | Blindedness: NS | Low level light, Middle level light, High level light
| | Range: | 18–44 | Analyzed: | 20 | Parallel | [underlined: Mode of administration:]
| | [underlined: Gender] | | Low level light | | | Ocular
| | Female: | 1 | Enrolled : | NS | | [underlined: Dosage and Timing:]
| | Male: | 22 | Analyzed: | NS | | Low level light: 23 lux; Middle level light: 230 lux;
| | [underlined: Sleep disorder: None] | | Middle level light | | | High level light: 3190 lux for 6.5 hours. Clock time: NS
| | | | Enrolled : | NS | | [underlined: Frequency and Duration:]
| | | | Analyzed : | NS | | Single session
| | | | High level light | | | [underlined: Sleep deprivation:]
| | | | Enrolled : | NS | | No
| | | | Analyzed : | NS
Costa, G | 1997 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Treatment:]
Quality Score | 15 | Mean (SD): | NS | Enrolled : | 5 | Blindedness: NS | BL
| | Range: | 21–32 | Analyzed: | 5 | Cross-over | [underlined: Control:]
| | [underlined: Gender] | | [underlined: Control Group] | | | DL
| | Female: | 4 | Enrolled : | 5 | | [underlined: Mode of administration:]
| | Male: | 1 | Analyzed : | 5 | | Ocular
| | [underlined: Sleep disorder: Shift-work disorder] | | | | | [underlined: Dosage and Timing:]
| | | | | | | BL: 400–600 lux, 1500 lux, or 3200 lux DL: 40 lux.
| | | | | | | 4 periods of 40 min each at 2 hour-intervals. Clock time: NS
| | | | | | | [underlined: Frequency and Duration:]
| | | | | | | 4 sessions/night shift for 2 nights
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | No
Danilenko, KV | 2000 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Treatment:]
Quality Score | 14 | Mean (SD): | 24.0 (4.8) | Enrolled : | 9 | Blindedness: NS | Dawn signal (Bright light)
| | Range: | NS | Analyzed: | 5 | Cross-over | [underlined: Control:]
| | [underlined: Gender] | | [underlined: Control Group] | | | Control signal (Dim Light)
| | Female: | 0 | Enrolled : | 9 | | [underlined: Mode of administration:]
| | Male: | 9 | Analyzed : | 5 | | Ocular
| | [underlined: Sleep disorder: None] | | | | | [underlined: Dosage and Timing:]
| | | | | | | Dawn signal watched for 1.5 h (0600–730 h);
| | | | | | | Control signal (0.1 lux) watched for 1.5 h (0600–0730 h);
| | | | | | | [underlined: Frequency and Duration:]
| | | | | | | One session/day for 9 days
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | No
Daurat, A | 1996 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Treatment:]
Quality Score | 16 | Mean (SD): | 23.6 (1.05) | Enrolled : | 8 | Blindedness: NS | Moderate BL
| | Range: | NS | Analyzed: | 8 | Cross-over | [underlined: Control:]
| | [underlined: Gender] | | [underlined: Control Group] | | | DL
| | Female: | 0 | Enrolled : | 8 | | [underlined: Mode of administration:]
| | Male: | 8 | Analyzed : | 8 | | Ocular
| | [underlined: Sleep disorder: None] | | | | | [underlined: Dosage and Timing:]
| | | | | | | BL: 1000–1500 lux; DL: 50 lux for 14 hours (1800-0800 h)
| | | | | | | [underlined: Frequency and Duration:]
| | | | | | | Single session
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | Yes
Daurat, A | 1997 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Treatment:]
Quality Score | 16 | Mean (SEM): | 23.6 (1.05) | Enrolled : | 10 | Blindedness: NS | Moderate BL
| | Range: | NS | Analyzed: | 10 | Cross-over | [underlined: Control:]
| | [underlined: Gender] | | [underlined: Control Group] | | | DL
| | Female: | 0 | Enrolled : | 10 | | [underlined: Mode of administration:]
| | Male: | 8 | Analyzed : | 10 | | Ocular
| | [underlined: Sleep disorder: None] | | | | | [underlined: Dosage and Timing:]
| | | | | | | BL: 1000–2000 lux, DL: < 50 lux for 14 hours during the nocturnal part of sleepless period (1800-0800 h)
| | | | | | | [underlined: Frequency and Duration:]
| | | | | | | Single session
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | Yes
Eastman, CI | 2000 | [underlined: Age (Years)] | | Experiment 1: | | CCT | Experiment 1:
Quality Score | 11 | Experiment 1: | | [underlined: Treatment Group] | | Blindedness: NS | [underlined: Treatment condition:]
| | Mean (SD): | 25 (5.0) | Enrolled : | 16 | Cross-over | BL
| | Range: | NS | Analyzed: | 14 | | [underlined: Controls:]
| | Experiment 2: | | [underlined: Control Group] | | | 1) DL, 2) Medium intensity light
| | Mean (SD): | 25 (5.0) | Enrolled : | 16 | | [underlined: Mode of administration:]
| | Range: | NS | Analyzed : | 14 | | BL: E-O (behind the knee); DL: Ocular;
| | [underlined: Gender] | | Experiment 2: | | | Medium intensity light: Ocular
| | Experiment 1: | | [underlined: Treatment Group] | | | [underlined: Dosage and Timing:]
| | Female: | 4 | Enrolled : | 4 | | E-O light: 13,000 lux; Ocular light: either 10–20 lux;
| | Male: | 12 | Analyzed: | 3 | | or 1000 lux for 3 hours (0300 to 0600 h)
| | Experiment 2: | | [underlined: Control Group] | | | [underlined: Frequency and Duration:]
| | Female: | 0 | Enrolled : | 4 | | One session/day for 2 days
| | Male: | 4 | Analyzed : | 3 | | [underlined: Sleep deprivation:]
| | [underlined: Sleep disorder: None] | | | | | Yes
| | | | | | | Experiment 2:
| | | | | | | [underlined: Treatment condition:]
| | | | | | | BL
| | | | | | | [underlined: Controls:]
| | | | | | | 1) DL, 2) Medium intensity light
| | | | | | | [underlined: Mode of administration: BL: E-O; DL and Medium intensity light: Ocular]
| | | | | | | [underlined: Dosage and Timing:]
| | | | | | | E-O light: 13000 lux; Ocular light: either 10–20 lux
| | | | | | | or 1000 lux for 3 hours (0600 to 0900 h or 0100 to 0400 h)
| | | | | | | [underlined: Frequency and Duration:]
| | | | | | | One session/day for 2 days
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | Yes
Fletcher, A | 1999 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Treatment:]
Quality Score | 18 | Mean (SD): | 20.5 (1.2) | Enrolled : | 16 | Blindedness: NS | Heat administered with electric blanket
| | Range: | 18–23 | Analyzed: | 16 | Cross-over | [underlined: Control:]
| | [underlined: Gender] | | [underlined: Control Group] | | | No heat administered with electric blanket
| | Female: | 7 | Enrolled : | 16 | | [underlined: Dosage and Timing:]
| | Male: | 9 | Analyzed: | 16 | | Heat blanket: 32V, 138W from 2230 h to terminal awakening
| | [underlined: Sleep disorder: None] | | | | | Clock time: NS
| | | | | | | [underlined: Frequency and Duration:]
| | | | | | | Single session
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | No
Gordijn, MC | 1998 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Treatment:]
Quality Score | 19 | Mean (SD): | 39.3 (12.1) | Enrolled : | 12 | Blindedness: NS | BL
| | Range: | 23.6–56.5 | Analyzed: | 12 | Cross-over | [underlined: Control:]
| | [underlined: Gender] | | [underlined: Control Group] | | | DL
| | Female: | 6 | Enrolled : | 12 | | [underlined: Mode of administration:]
| | Male: | 6 | Analyzed : | 12 | | Ocular
| | [underlined: Sleep disorder: None] | | | | | [underlined: Dosage and Timing:]
| | | | | | | BL: 2500 lux; DL: < 10 lux (0600–0900 h or 1800–2100 h)
| | | | | | | [underlined: Frequency and Duration:]
| | | | | | | One session/day for 3 days
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | No
Gordijn, MC | 1999 | Patients: | | [underlined: Treatment Group] | | CCT | [underlined: Treatment:]
Quality Score | 17 | [underlined: Age (Years)] | | Patients: | | Blindedness: NS | BL
| | Mean (SD): | 38.3 (12.2) | Enrolled : | 10 | Cross-over | [underlined: Control:]
| | Range: | NS | Analyzed: | 8 | | DL
| | [underlined: Gender] | | non-Patients: | | | [underlined: Mode of administration:]
| | Female: | 5 | Enrolled : | 8 | | Ocular
| | Male: | 5 | Analyzed: | 8 | | [underlined: Dosage and Timing:]
| | non-Patients: | | [underlined: Control Group] | | | BL: 2500 lux, DL: < 10 lux. Morning: 0600–0900 h or Evening: 1800–2100 h)
| | [underlined: Age (Years)] | | Patients: | | | [underlined: Frequency and Duration:]
| | Mean (SD): | 38.7 (12.9) | Enrolled : | 10 | | One session/day for 3 days
| | Range: | NS | Analyzed: | 8 | | [underlined: Sleep deprivation:]
| | [underlined: Gender] | | non-Patients: | | | No
| | Female: | 3 | Enrolled : | 8
| | Male: | 5 | Analyzed: | 8
| | [underlined: Sleep disorder: Patients suffered from]
| | Nonseasonal Depression, which may or may not be accompanied by a sleep disorder
Higuchi, S | 2003 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Treatment:]
Quality Score | 15 | Mean (SD): | 24.7 (5.6) | Enrolled : | 7 | Blindedness: NS | Video display terminal with Bright display
| | Range: | NS | Analyzed: | 7 | Cross-over | [underlined: Control:]
| | [underlined: Gender] | | [underlined: Control Group] | | | Video display terminal with Dark display
| | Female: | 0 | Enrolled : | 7 | | [underlined: Mode of administration:]
| | Male: | 7 | Analyzed: | 7 | | Ocular
| | [underlined: Sleep disorder: None] | | | | | [underlined: Dosage and Timing:]
| | | | | | | Bright display: 45 lux, Dark display: 15 lux for 3 hours (2300-0200 h)
| | | | | | | [underlined: Frequency and Duration:]
| | | | | | | One session/day for 3 days
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | No
Horne, JA | 1991 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Treatment:]
Quality Score | 15 | Mean (SD): | NS | Enrolled : | 12 | Single-blinded | BL
| | Range: | 19–26 | Analyzed: | 12 | Cross-over | [underlined: Control:]
| | [underlined: Gender] | | [underlined: Control Group] | | | DL
| | Female: | 8 | Enrolled : | 12 | | [underlined: Mode of administration:]
| | Male: | 4 | Analyzed: | 12 | | Ocular
| | [underlined: Sleep disorder: None] | | | | | [underlined: Dosage and Timing:]
| | | | | | | BL: 2000 lux; DL: NS lux for 12 hours (1800-0600 h)
| | | | | | | [underlined: Frequency and Duration:]
| | | | | | | 10-min session/hour for 12 hours
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | Yes
Horowitz, TS | 2001 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Treatment:]
Quality Score | 16 | Mean (SD): | 26.99 (6.22) | Enrolled : | 26 | Blindedness: NS | BL
| | Range: | 20–40 | Analyzed: | 25 | Cross-over | [underlined: Control:]
| | [underlined: Gender] | | [underlined: Control Group] | | | DL
| | Treatment group: | | Enrolled : | 28 | | [underlined: Mode of administration:]
| | Female: | 10 | Analyzed: | 27 | | Ocular
| | Male: | 16 | | | | [underlined: Dosage and Timing:]
| | Control: | | | | | BL: 2500 lux for 6 hours (2300-0500 h);
| | Female: | 18 | | | | DL: 150 lux for 8 hours (2300-0700 h)
| | Male: | 10 | | | | [underlined: Frequency and Duration:]
| | [underlined: Sleep disorder: Shift-work disorder] | | | | | One session/day for 4 days
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | No
Kelly, TL | 1997 | [underlined: Age (Years)] | | [underlined: Treatment Groups] | | CCT | [underlined: Treatment:]
Quality Score | 17 | Mean (SD): | NS | LEET group | 12 | Double-blind | BL and LEET therapy (separately and combined)
| | Range: | NS | Enrolled : | 12 | Parallel | [underlined: Control:]
| | [underlined: Gender] | | Analyzed: | | | DL
| | Female: | 0 | BL | | | [underlined: Mode of administration:]
| | Male: | 45 | Enrolled : | 12 | | Ocular
| | LEET group | | Analyzed: | 8 | | [underlined: Dosage and Timing]
| | [underlined: Age (Years)] | | BL + LEET | | | LEET: 20 min. prior daytime sleep periods. BL: 3500–4300 lux,
| | Mean (SD): | 24.8 (7.9) | Enrolled : | 11 | | DL: 200–300 lux for 4 hours (2200-0200 h)
| | Range: | NS | Analyzed: | 11 | | [underlined: Frequency and Duration:]
| | BL | | [underlined: Control Group] | | | One session/day for 3 days
| | [underlined: Age (Years)] | | DL | | | [underlined: Sleep deprivation:]
| | Mean (SD): | 22.5 (3.5) | Enrolled : | 10 | | No
| | Range: | NS | Analyzed: | 7
| | BL + LEET
| | [underlined: Age (Years)]
| | Mean (SD): | 23.4 (4.1)
| | Range: | NS
| | DL
| | [underlined: Age (Years)]
| | Mean (SD): | 25.2 (7.7)
| | Range: | NS
| | [underlined: Sleep disorder: Shift-work disorder]
Kubota, T | 2002 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Treatment:]
Quality Score | 18 | Mean (SD): | 24 (NS) | Enrolled : | 9 | Blindedness: NS | BL
| | Range: | 20–27 | Analyzed: | 9 | Cross-over | [underlined: Control:]
| | [underlined: Gender] | | [underlined: Control Group] | | | DL
| | Female: | 0 | Enrolled : | 9 | | [underlined: Mode of administration:]
| | Male: | 9 | Analyzed : | 9 | | Ocular
| | [underlined: Sleep disorder: None] | | | | | [underlined: Dosage and Timing:]
| | | | | | | BL: 5000 lux for 5 hours; DL: 10 lux for 5 hours (0000–0500 h)
| | | | | | | [underlined: Frequency and Duration:]
| | | | | | | Single session
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | Yes
Lavoie, S | 2003 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Treatment:]
Quality Score | 17 | Mean (SD): | 26.1 (4.2) | Enrolled : | 7 | Blindedness: NS | BL
| | Range: | 22–35 | Analyzed: | 7 | Parallel | [underlined: Control:]
| | [underlined: Gender] | | [underlined: Control Group] | | | DL
| | Female: | 8 | Enrolled : | 7 | | [underlined: Mode of administration:]
| | Male: | 6 | Analyzed : | 7 | | Ocular
| | [underlined: Sleep disorder: None] | | | | | [underlined: Dosage and Timing:]
| | | | | | | BL: 3000 lux; DL: 15 lux for 4 hours (0030–0430 h)
| | | | | | | [underlined: Frequency and Duration:]
| | | | | | | Single session
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | Yes
Lushington, K | 2002 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Treatment:]
Quality Score | 18 | Mean (SD): | 22.1 (3.0) | Enrolled : | 13 | Single-blind | Light
| | Range: | 13–34 | Analyzed: | 13 | Cross-over | [underlined: Control:]
| | [underlined: Gender] | | [underlined: Control Group] | | | Placebo (No light)
| | Female: | 3 | Enrolled : | 13 | | [underlined: Mode of administration:]
| | Male: | 10 | Analyzed : | 13 | | E-O (behind the knee)
| | [underlined: Sleep disorder: None] | | | | | [underlined: Dosage and Timing:]
| | | | | | | Light: 10000 lux for 3 hours (0100–0400 h)
| | | | | | | [underlined: Frequency and Duration:]
| | | | | | | One session/day for 3 days
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | No
Morita, T | 1996 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Treatment conditions:]
Quality Score | 16 | Mean (SD): | 20.0 (0.63) | Enrolled : | 5 | Blindedness: NS | Daylight; Warm-white light
| | Range: | 19–21 | Analyzed: | 5 | Cross-over | [underlined: Control:]
| | [underlined: Gender] | | [underlined: Control Group] | | | DL
| | Female: | 0 | Enrolled : | 5 | | [underlined: Mode of administration:]
| | Male: | 5 | Analyzed : | 5 | | Ocular
| | [underlined: Sleep disorder: None] | | | | | [underlined: Dosage and Timing:]
| | | | | | | Daylight: 1000 lux (Color temperature: 6500 K); Warm-white light: 1000 lux (Color temperature: 3000 K) for 5 hours (2100-0200 h); 3) DL: 50 lux (1900-0200 h and 0800–0900 h)
| | | | | | | [underlined: Frequency and Duration:]
| | | | | | | Single session
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | No
Strassman, RJ | 1991 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Treatment:]
Quality Score | 14 | Mean (SE): | 26.4 (1.90) | Enrolled : | 17 | Blindedness: NS | BL
| | Range: | 20–36 | Analyzed: | 9 | Cross-over | [underlined: Control:]
| | [underlined: Gender] | | [underlined: Control Group] | | | DL
| | Female: | 0 | Enrolled : | 17 | | [underlined: Mode of administration:]
| | Male: | 17 | Analyzed : | 9 | | Ocular
| | [underlined: Sleep Disorder: None] | | | | | [underlined: Dosage and Timing:]
| | | | | | | BL: > 2500 lux; DL: > 100 lux for 9 hours (2200-0700 h)
| | | | | | | [underlined: Frequency and Duration:]
| | | | | | | Single session
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | Yes
Wakamura, T | 2000 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Treatment:]
Quality Score | 17 | Mean (SD): | 20 (2) | Enrolled : | 7 | Blindedness: NS | BL
| | Range: | 18–23 | Analyzed: | 7 | Cross-over | [underlined: Control:]
| | [underlined: Gender] | | [underlined: Control Group] | | | DL
| | Female: | 7 | Enrolled : | 7 | | [underlined: Mode of administration:]
| | Male: | 0 | Analyzed : | 7 | | Ocular
| | [underlined: Sleep disorder: None] | | | | | [underlined: Dosage and Timing:]
| | | | | | | BL: 6000 lux; DL: 2000 lux (1800-bedtime h)
| | | | | | | [underlined: Frequency and Duration:]
| | | | | | | Single session
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | No
Wright, KP Jr | 1997 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Treatment condition:]
Quality Score | 17 | Mean (SD): | 19.2 (NS) | Enrolled : | 46 | Blindedness: NS | BL
| | Range: | 18–25 | Analyzed: | 40 | Cross-over | [underlined: Control:]
| | [underlined: Gender] | | [underlined: Control Group] | | | DL
| | Female: | 0 | Enrolled : | 46 | | [underlined: Mode of administration:]
| | Male: | 46 | Analyzed : | 40 | | Ocular
| | [underlined: Sleep disorder: Sleep restriction] | | | | | [underlined: Dosage and Timing:]
| | | | | | | BL: 2000 lux; DL: > 100 lux for 12 h (2000-0800)
| | | | | | | [underlined: Frequency and Duration:]
| | | | | | | Single session
| | | | | | | [underlined: Sleep deprivation:]
| | | | | | | Yes

RCT: Randomized Control Trial, CCT: Controlled Clinical Trial, MLT: Melatonin, SD: Standard Deviation, SE: Standard Error, SEM: Standard Error of the Mean, NS: Not Specified, BL: Bright Light, DL: Dim Light, E-O: Extra-Ocular, Ocular: Eye-directed including room/ambient, SAD: Seasonal Affective Disorder, LEET: Low Energy Emission Therapy

Evidence Table C-7: Effect of Melatonin on People with Sleep Disorders: Study Characteristics

Author | Year | Population | | Sample Size | N | Study Design | Intervention
Almeida-Montes, LG | 2003 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 5 | mean: | 50 | Enrolled: | 10 | Double-blind | Sustained-release
| | range: | 30–72 | Analyzed: | 10 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 4 | Enrolled: | 10 | | [underlined: Dosage and Timing]
| | male: | 6 | Analyzed: | 10 | | 0.3 mg or 1 mg MLT one hour before bedtime
| | [underlined: Ethnicity: NS] | | | | | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: Insomnia] | | | | | 1 capsule/day for 14 days
Andrade, C | 2001 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 4 | Treatment group | | Enrolled: | 18 | Double-blind | Not specified
| | mean (SD): | 59.7(11.1) | Analyzed: | 18 | Parallel | [underlined: Route of Administration]
| | range: | 43–85 | [underlined: Control Group] | | | Oral
| | Control group | | Enrolled: | 15 | | [underlined: Dosage and Timing]
| | mean (SD): | 51.4(14.2) | Analyzed: | 15 | | 3mg MLT taken at night
| | range: | 23–70 | | | | [underlined: Frequency]
| | [underlined: Gender] | | | | | 1 capsule/night for first two nights, 2 capsules every alternate night thereafter; up to 4 capsules/night
| | Treatment group | | | | | [underlined: Duration]
| | female: | 4 | | | | 21 patients (melatonin n=11, placebo n= 10) received treatment for 8 days; 8 patients (melatonin n= 5, placebo n= 3) received treatment for 10 days; and 4 patients (melatonin n=2 placebo n=2) received treatment for 16 days
| | male: | 14
| | Control group
| | female: | 5
| | male: | 10
| | [underlined: Ethnicity: NS]
| | [underlined: Sleep Disorder: Insomnia]
Baskett, J | 2003 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 5 | mean: | NS | Enrolled: | 20 | Double-blind | Not specified
| | range: | 60–84 | Analyzed: | 14 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 10 | Enrolled: | 20 | | [underlined: Dosage and Timing]
| | male: | 10 | Analyzed: | 14 | | 5mg MLT at bedtime
| | [underlined: Ethnicity: NS] | | | | | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: Sleep maintenance problems] | | | | | 1 capsule/day for 4 weeks
Beaumont, M | 2004 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 3 | mean (SD): | 35.3(8.1) | Enrolled: | 9 | Double-blind | Not specified
| | range: | 19–47 | Analyzed: | NS | Parallel | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Not specified
| | female: | 9 | Enrolled: | 9 | | [underlined: Dosage and Timing]
| | male: | 18 | Analyzed: | NS | | 5mg MLT on day 1 at 1700h and on days 2 and 3 at 2300h
| | [underlined: Ethnicity: 15] | | | | | [underlined: Frequency and Duration]
| | [underlined: Caucasians, 9 Hispanics] | | | | | 5mg/day for 3 days
| | and 3 African Americans
| | [underlined: Sleep Disorder: Jet lag]
Camfield, P | 1995 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | N of 1RCT | [underlined: Formulation]
Quality Score | 4 | mean: | 8.8 | Enrolled: | 6 | Double-blind | Not specified
| | range | 3 to 13 | Analyzed: | 6 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 2 | Enrolled: | 6 | | [underlined: Dosage and Timing]
| | male: | 4 | Analyzed: | 6 | | 0.5 or 1.0mg MLT at 1800h
| | [underlined: Ethnicity: NS] | | | | | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: Fragmented sleep] | | | | | For each two week interval of 10 week trial, children received MLT or PLB first week with alternative agent given on second week
| | patterns accompanying developmental disabilities
Dahlitz, M | 1991 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 4 | mean: | NS | Enrolled: | 8 | Double-blind | Not specified
| | range: | 20–60 | Analyzed: | 8 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 0 | Enrolled: | 8 | | [underlined: Dosage and Timing]
| | male: | 8 | Analyzed: | 8 | | 5mg MLT at 2200h
| | [underlined: Ethnicity: Caucasian] | | | | | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: Delayed sleep phase] | | | | | 1 capsule/day for 4 weeks
| | syndrome
Dawson, D | 1998 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 3 | mean (SD): | 65.67(1.68) | Enrolled: | 12 | Double-blind | Not specified
| | range: | >55 | Analyzed: | 12 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral (MLT patch placed on the gums)
| | female: | NS | Enrolled: | 12 | | [underlined: Dosage and Timing]
| | male: | NS | Analyzed: | 12 | | 0.5mg MLT at 1900h
| | [underlined: Ethnicity: NS] | | | | | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: Sleep maintenance] | | | | | 0.5mg/day for 4 consecutive days
| | insomnia
Dodge, N | 2000 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 4 | mean: | NS | Enrolled: | 20 | Double-blind | Not specified
| | range: | 1–12 yrs | Analyzed: | 17 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | NS | Enrolled: | 20 | | [underlined: Dosage and Timing]
| | male: | NS | Analyzed: | 17 | | 5mg MLT at 2000h
| | [underlined: Ethnicity: NS] | | | | | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: Sleep disturbance] | | | | | 5mg/day for weeks 2–3 and 5–6 of 6 week study
| | accompanying severe developmental disability
Ellis, C | 1994 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 4 | mean (SD): | 46(11) | Enrolled: | 15 | Double-blind | Not specified
| | range: | 32–67 | Analyzed: | 15 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 6 | Enrolled: | 15 | | [underlined: Dosage and Timing]
| | male: | 9 | Analyzed: | 15 | | 5mg MLTat 2000h
| | [underlined: Ethnicity: NS] | | | | | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: Psychophysiological insomnia] | | | | | 5mg/day for 7 consecutive days
Folklard, S | 1993 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 3 | mean (SD): | 29(7) | Enrolled: | 7 | Double-blind | Not specified
| | range: | 21–48 | Analyzed: | 7 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 2 | Enrolled: | 8 | | [underlined: Dosage and Timing]
| | male: | 15 | Analyzed: | 8 | | 5mg MLTat 0642h
| | [underlined: Ethnicity: NS] | | | | | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: Night-shift disorder] | | | | | 1 capsule/day for 6 successive day sleeps taken between night shifts
Garfinkel, D | 1995 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 4 | mean: | 76 | Enrolled: | 12 | Double-blind | Controlled-release MLT
| | range: | 68–93 | Analyzed: | 12 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 5 | Enrolled: | 12 | | [underlined: Dosage and Timing]
| | male: | 7 | Analyzed: | 12 | | 2 mg MLT two hours before desired bedtime
| | [underlined: Ethnicity: NS] | | | | | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: Long-term insomnia] | | | | | 1 tablet/day for 3 weeks
Haimov, I | 1995 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 3 | mean (SD): | 73.1(3.9) | Enrolled: | 8 | Double-blind | Sustained-release and fast-release MLT
| | range: | NS | Analyzed: | 8 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 4 | Enrolled: | 8 | | [underlined: Dosage and Timing]
| | male: | 4 | Analyzed: | 8 | | 2 mg FR MLT, 2 mg sustained-release MLT or 1 mg sustained-release MLT two hours before desired bedtime
| | [underlined: Ethnicity: NS] | | | | | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: Insomnia] | | | | | 1 tablet/day of 2mg FR and 2mg sustained-release MLT for 1 week and tablet/day of 1mg sustained-release MLT for 2 months
James, M | 1997 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 5 | mean (SD): | 29(8) | Enrolled: | 24 | Double-blind | Not specified
| | range: | 20–41 | Analyzed: | 22 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 5 | Enrolled: | 24 | | [underlined: Dosage and Timing]
| | male: | 17 | Analyzed: | 22 | | 6 mg MLT 0.5h before each consecutive day sleep
| | [underlined: Ethnicity: NS] | | | | | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: Night-shift disorder] | | | | | 6mg/day for 4 treatment cycles lasting 4–6 consecutive night shifts
James, SP | 1990 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 3 | mean: | 33.4 | Enrolled: | 10 | Double-blind | Not specified
| | range: | 20–57 | Analyzed: | 10 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 6 | Enrolled: | 10 | | [underlined: Dosage and Timing]
| | male: | 4 | Analyzed: | 10 | | 1 mg or 5mg MLT given 15 minutes before bedtime
| | [underlined: Ethnicity: NS] | | | | | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: Insomnia] | | | | | 1mg or 5mg MLT/day for 1 week
Jockovich, M | 2000 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 3 | mean: | 28.2 | Enrolled: | 19 | Double-blind | Not specified
| | range: | NS | Analyzed: | 19 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 15 | Enrolled: | 19 | | [underlined: Dosage and Timing]
| | male: | 4 | Analyzed: | 19 | | 1 mg MLT 0.5–1h before daytime sleep
| | [underlined: Ethnicity: NS] | | | | | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: Night-shift disorder] | | | | | 1 caplet/day for 3 consecutive days
Jorgensen | 1998 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 4 | mean: | 32 | Enrolled: | 20 | Double-blind | Not specified
| | range: | 25–40 | Analyzed: | 18 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 2 | Enrolled: | 20 | | [underlined: Dosage and Timing]
| | male: | 16 | Analyzed: | 18 | | 10 mg MLT the morning after each night shift
| | [underlined: Ethnicity: NS] | | | | | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: Night-shift disorder] | | | | | 1 tablet/day for varied amount of time
Kayumov, L | 2001 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 3 | female; mean (SD): | 30.8(12.4) | Enrolled: | 22 | Double-blind | Not specified
| | male; mean (SD): | 35.6(14.0) | Analyzed: | 19 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 7 | Enrolled: | 22 | | [underlined: Dosage and Timing]
| | male: | 15 | Analyzed: | 19 | | 5 mg MLT, timing: NS
| | [underlined: Ethnicity: NS] | | | | | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: Delayed sleep phase syndrome] | | | | | 5mg/day for 4 weeks
McArthur, A | 1998 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 3 | mean (SD): | 10.1(1.5) | Enrolled: | 9 | Double-blind | Immediate-release MLT
| | range: | 4–17 yrs | Analyzed: | 9 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral or by gastrostomy tube
| | female: | 9 | Enrolled: | 9 | | [underlined: Dosage and Timing]
| | male: | 0 | Analyzed: | 9 | | Dosage based on individual body weight, range 2.5–7.5 mg given one hour before bedtime
| | [underlined: Ethnicity: NS] | | | | | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: Sleep dysfunction] | | | | | 1 capsule/day for 4 weeks
| | accompanying Rett syndrome
O'cahllaghan | 1999 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 4 | median: | 11 | Enrolled: | 7 | Double-blind | Not specified
| | range: | Feb-28 | Analyzed: | 7 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 4 | Enrolled: | 7 | | [underlined: Dosage and Timing]
| | male: | 3 | Analyzed: | 7 | | 5 mg MLT 30 minutes before usual bedtime
| | [underlined: Ethnicity: NS] | | | | | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: Delayed sleep onset] | | | | | 1 capsule/day for 2 weeks
| | accompanying tuberous sclerosis
Serfaty, M | 2002 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 5 | mean (SD): | 84.2(7.6) | Enrolled: | 44 | Double-blind | Slow release MLT
| | range: | NS | Analyzed: | 25 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 9 | Enrolled: | 44 | | [underlined: Dosage and Timing]
| | male: | 16 | Analyzed: | 25 | | 6 mg MLT tablet at usual bedtime
| | [underlined: Ethnicity: Not specified] | | | | | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: Sleep disorder associated with dementia] | | | | | 1 tablet/day for 2 weeks
Serfaty, M | 2003 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 2 | mean (SD): | 39.9(11.8) | Enrolled: | NS | Double-blind | Slow-release MLT
| | range: | NS | Analyzed: | NS | Parallel | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 17 | Enrolled: | NS | | [underlined: Dosage and Timing]
| | male: | 14 | Analyzed: | NS | | 6 mg MLT tablet at usual bedtime
| | [underlined: Ethnicity: NS] | | | | | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: Sleep disorder accompanying depression] | | | | | 1 tablet/day for 4 weeks
Shamir, E | 2000 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 4 | mean (SD): | 42.3(13.1) | Enrolled: | 14 | Double-blind | Controlled-release MLT
| | range: | 25–64 | Analyzed: | 14 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Not specified
| | female: | 3 | Enrolled: | 14 | | [underlined: Dosage and Timing]
| | male: | 11 | Analyzed: | 14 | | 2mg MLT taken two hours before the desired bedtime
| | [underlined: Ethnicity: NS] | | | | | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: Poor sleep quality] | | | | | 2 mg MLT/day for 3 weeks
Shamir, E | 2000 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 4 | mean (SD): | 42(5) | Enrolled: | 27 | Double-blind | Controlled-release MLT
| | range: | 24–67 | Analyzed: | 19 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Not specified
| | female: | 7 | Enrolled: | 27 | | [underlined: Dosage and Timing]
| | male: | 12 | Analyzed: | 19 | | 2mg MLT taken two hours before the desired bedtime
| | [underlined: Ethnicity: NS] | | | | | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: DSM-IV insomnia] | | | | | 2 mg MLT/day for 3 weeks
| | accompanying schizophrenia
Singer, C | 2003 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 4 | mean (SD): | 77.4(8.9) | Enrolled: | 104 | Double-blind | Immediate-release MLT
| | range: | NS | Analyzed: | 104 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 88 | Enrolled: | 52 | | [underlined: Dosage and Timing]
| | male: | 69 | Analyzed: | 47 | | 10 mg MLT taken one hour before habitual bedtime
| | [underlined: Ethnicity: NS] | | | | | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: Sleep disturbance] | | | | | 1 capsule/day for 8 weeks
| | accompanying Alzheimer's disease
Smits, M.G | 2003 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 5 | mean (SD): | | Enrolled: | 27 | Double-blind | Fast-release MLT
| | Treatment Group | 9.2(2.1) | Analyzed: | 27 | Cross-over | [underlined: Route of Administration]
| | Control Group | 10.1(1.7) | [underlined: Control Group] | | | Oral
| | range: | NS | Enrolled: | 35 | | [underlined: Dosage and Timing]
| | [underlined: Gender] | | Analyzed: | 35 | | 5mg MLT at 1900h
| | Treatment Group | | | | | [underlined: Frequency and Duration]
| | female: | 7 | | | | 1 dose/ day for 4 weeks
| | male: | 20
| | Control Group
| | female: | 6
| | male: | 29
| | [underlined: Ethnicity: White]
| | [underlined: Sleep Disorder: Idiopathic chronic]
| | sleep-onset insomnia
Suhner, A | 1998 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 4 | mean: | NS | Enrolled: | 240 | Double-blind | Not specified
| | range: | NS | Analyzed: | 174 | Parallel | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Not specified
| | female: | 148 | Enrolled: | 80 | | [underlined: Dosage and Timing]
| | male: | 172 | Analyzed: | 60 | | 0.5mg FR, 5mg FR, 2mg CR MLT or PLB at bedtime on the first day post-flight at 23:10 (+/- 1.52h) and on the following days at 23:29 (+/- 1.12h)
| | [underlined: Ethnicity: NS] | | | | | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: Jet-lag] | | | | | 1 dose/day for 4 days following eastward flight
Suhner, A | 2001 | [underlined: Age (Years) of Compliant (137)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 4 | mean: | 41.3 | Enrolled: | 40 | Double-blind | Not specified
| | range: | 18–68 | Analyzed: | 35 | Parallel | [underlined: Route of Administration]
| | [underlined: Gender of Compliant (137)] | | [underlined: Control Group] | | | Not specified
| | female: | 67 | Enrolled: | 40 | | [underlined: Dosage and Timing]
| | male: | 70 | Analyzed: | 39 | | 5mg MLT taken on the return flight (eastbound) between 1700h and 2100h local time at the place of departure depending on the flight schedule
| | [underlined: Ethnicity: NS] | | | | | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: Jet-lag] | | | | | 1 dose/day for four consecutive days post-flight
Waldhauser | 1990 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 2 | mean (SD): | 26.4(4.8) | Enrolled: | 10 | Double-blind | Not specified
| | range: | NS | Analyzed: | 10 | Parallel | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 10 | Enrolled: | 10 | | [underlined: Dosage and Timing]
| | male: | 10 | Analyzed: | 10 | | 80mg MLTat 2100h
| | [underlined: Ethnicity: NS] | | | | | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: Induced insomnia] | | | | | Single dose
Wright, SW | 1998 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 4 | mean: | 38.6 | Enrolled: | 20 | Double-blind | Not specified
| | range: | 32–45 | Analyzed: | 15 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 3 | Enrolled: | 20 | | [underlined: Dosage and Timing]
| | male: | 12 | Analyzed: | 15 | | 5 mg MLT thirty minutes before bedtime in the evening
| | [underlined: Ethnicity: NS] | | | | | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: Night-shift disorder] | | | | | 5mg/night for 3 nights following shift work
Zhdanova, I | 2001 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 2 | mean: | NS | Enrolled: | NS | Double-blind | Not specified
| | range: | NS | Analyzed: | 30 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | NS | Enrolled: | NS | | [underlined: Dosage and Timing]
| | male: | NS | Analyzed: | 30 | | 0.1 mg, 0.3 mg, or 3.0 mg MLT, timing: NS
| | [underlined: Ethnicity: NS] | | | | | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: Insomnia] | | | | | 1 capsule/day for 4 days at home and then for 3 days as inpatients of the MIT Clinical Research Center.

Abbreviations: RCT: randomized controlled trial, CCT: controlled clinical trial, MLT: melatonin, FR: fast-release, SR: slow-release, SD: standard deviation, SE: standard error, mg: milligrams, h: hours, NS: not specified

Control group received placebo unless otherwise indicated

Evidence Table C-8: Safety of Malatonin: Study Characteristics

Author | Year | Population | | Sample Size | N | Study Design | Intervention
Andrade, C | 2001 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 25 | Treatment Group | | Enrolled: | 18 | Double-blind | Not specified
| | mean (SD): | 59.7(11.1) | Analyzed: | 18 | Parallel | [underlined: Route of Administration]
| | range: | 43–85 | [underlined: Control Group] | | | Oral
| | Control Group | | Enrolled: | 15 | | [underlined: Dosage and Timing]
| | mean (SD): | 51.4(14.2) | Analyzed: | 15 | | 3mg MLT taken at night
| | range: | 23–70 | | | | [underlined: Frequency]
| | [underlined: Gender] | | | | | 1 capsule/first two nights, 2 capsules every alternate night thereafter upto 4 capsules/night thereafter
| | Treatment Group | | | | | [underlined: Duration]
| | female: | 4 | | | | 21 patients (melatonin n=11, placebo n= 10) received treatment for 8 days; 8 patients (melatonin n= 5, placebo n= 3) received treatment for 10 days; and 4 patients (melatonin n=2 placebo n=2) received treatment for 16 days
| | male: | 14
| | Control Group
| | female: | 5
| | male: | 10
| | [underlined: Sleep Disorder: insomnia]
Arendt, J | 1984 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Formulation]
Quality Score | 19 | mean: | NS | Enrolled: | 12 | Double-blind | Not specified
| | range: | 22–46 | Analyzed: | 12 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 2 | Enrolled: | 12 | | [underlined: Dosage and Timing]
| | male: | 10 | Analyzed: | 12 | | 2mg MLT at 1700h
| | [underlined: Sleep Disorder: None] | | | | | [underlined: Frequency and Duration]
| | | | | | | 2mg/day for 4 weeks
Baskett, J | 2003 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 25 | [underlined: mean:] | NS | Enrolled: | 20 | Double-blind | Not specified
| | range: | 60–84 | Analyzed: | 14 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 16 | Enrolled: | 20 | | [underlined: Dosage and Timing]
| | male: | 4 | Analyzed: | 14 | | 5mg MLT at bedtime
| | | | | | | [underlined: Frequency and Duration]
| | | | | | | 1 capsule/day for 4 weeks
Claustrat, B | 1992 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 19 | mean (SD): | | Enrolled: | 15 | Double-blind | Not specified
| | Treatment group | 36.3(8.9) | Analyzed: | 15 | Cross-over | [underlined: Route of Administration]
| | Control group | 35.7(6.4) | [underlined: Control Group] | | | Oral
| | range: | NS | Enrolled: | 15 | | [underlined: Dosage and Timing]
| | [underlined: Gender] | | Analyzed: | 15 | | 8 mg MLT at 2200h
| | female: | | | | | [underlined: Frequency and Duration]
| | Treatment group | 7 | | | | 1 capsule/day for 4 days
| | Control group | 5
| | male:
| | Treatment group | 8
| | Control group | 10
| | [underlined: Sleep Disorder: Jet-lag]
Dahlitz, M | 1991 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 24 | mean: | NS | Enrolled: | 8 | Double-blind | Not specified
| | range: | 20–60 | Analyzed: | 8 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 0 | Enrolled: | 8 | | [underlined: Dosage and Timing]
| | male: | 8 | Analyzed: | 8 | | 5mg MLTat 2200h
| | [underlined: Sleep Disorder: Delayed sleep] | | | | | [underlined: Frequency and Duration]
| | phase insomnia | | | | | 1 capsule/day for 4 weeks
Dodge, N | 2000 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 22 | mean: | NS | Enrolled: | 20 | Double-blind | Not specified
| | range: | 1-Dec | Analyzed: | 17 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | NS | Enrolled: | 20 | | [underlined: Dosage and Timing]
| | male: | NS | Analyzed: | 17 | | 5mg MLT at 2000h
| | [underlined: Sleep Disorder: Sleep disturbance] | | | | | [underlined: Frequency and Duration]
| | accompanying severe developmental disability | | | | | 5mg/day on weeks 2–3 and 5–6 of a 6 week study
Edwards, BJ | 2000 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Formulation]
Quality Score | 22 | Treatment Group | | Enrolled: | 14 | Double-blind | Not specified
| | mean (SD): | 40(13) | Analyzed: | 13 | Parallel | [underlined: Route of Administration]
| | range: | NS | [underlined: Control Group] | | | Oral
| | Control Group | | Enrolled: | 17 | | [underlined: Dosage and Timing]
| | mean (SD): | 41(12) | Analyzed: | 13 | | 5mg MLT taken on the plane between 18:00–19:00h and between 22:00 and 23:00h, according to local time at destination and for the next three evenings.
| | range: | NS | | | | [underlined: Frequency and Duration]
| | [underlined: Gender] | | | | | 2 capsules/day for first day and then 1 capsule/day for 2 days
| | female: | 3
| | male: | 28
Ellis, C | 1194 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 20 | mean (SD): | 46(11) | Enrolled: | 15 | Double-blind | Not specified
| | range: | 32–67 | Analyzed: | 15 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 6 | Enrolled: | 15 | | [underlined: Dosage and Timing]
| | male: | 9 | Analyzed: | 15 | | 5mg MLT at 2000h
| | [underlined: Sleep Disorder: Psychophysiological] | | | | | [underlined: Frequency and Duration]
| | insomnia | | | | | 1 capsule/day for 7 consecutive days
Fraschini, F | 1999 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 18 | mean: | 32.5 | Enrolled: | 5 | Double-blind | Not specified
| | range: | NS | Analyzed: | 5 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Not specified
| | female: | 1 | Enrolled: | 5 | | [underlined: Dosage and Timing]
| | male: | 4 | Analyzed: | 5 | | 5mg, 10mg or 100mg MLT, timing: NS
| | [underlined: Sleep Disorder: None] | | | | | [underlined: Frequency and Duration]
| | | | | | | 1 dose/day for 1 to 3 days
Garfinkel, D | 1995 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 24 | mean: | 76 | Enrolled: | 12 | Double-blind | Controlled-release MLT
| | range: | 68–93 | Analyzed: | 12 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 5 | Enrolled: | 12 | | [underlined: Dosage and Timing]
| | male: | 7 | Analyzed: | 12 | | 2 mg MLT two hours before desired bedtime
| | [underlined: Sleep Disorder: Long-term insomnia] | | | | | [underlined: Frequency and Duration]
| | | | | | | 1 tablet/night for three weeks
Hood, E | 1999 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 12 | mean: | NS | Enrolled: | 15 | Double-blind | Not specified
| | range: | NS | Analyzed: | 9 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Not specified
| | female: | NS | Enrolled: | 15 | | [underlined: Dosage and Timing]
| | male: | NS | Analyzed: | 9 | | 1mg MLT at bedtime
| | [underlined: Sleep Disorder: None] | | | | | [underlined: Frequency and Duration]
| | | | | | | 1mg/day for 4 weeks
James, M | 1998 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 23 | mean (SD): | 29(8) | Enrolled: | 24 | Double-blind | Not specified
| | range: | 20–41 | Analyzed: | 22 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 5 | Enrolled: | 24 | | [underlined: Dosage and Timing]
| | male: | 17 | Analyzed: | 22 | | 6 mg MLT 30 minutes before each consecutive day sleep
| | [underlined: Sleep Disorder: Night-shift disorder] | | | | | [underlined: Frequency and Duration]
| | | | | | | 6mg/day for 8–12 consecutive night shifts
Jan, E | 1994 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 21 | mean: | NS | Enrolled: | 15 | Double-blind | Not specified
| | range: | 6mon–13yr | Analyzed: | 15 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Not specified
| | female: | 2 | Enrolled: | 15 | | [underlined: Dosage and Timing]
| | male: | 13 | Analyzed: | 15 | | 2–5mg MLT at desired bedtime
| | [underlined: Sleep Disorder: Severe sleep problems] | | | | | [underlined: Frequency and Duration]
| | | | | | | 2–5mg/day for 7–10 days
Jean-Louis, G | 1998 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Formulation]
Quality Score | 21 | mean (SD): | 68.8(15.8) | Enrolled: | 10 | Double-blind | Not specified
| | range: | NS | Analyzed: | NS | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Not specified
| | female: | 6 | Enrolled: | 10 | | [underlined: Dosage and Timing]
| | male: | 4 | Analyzed: | NS | | 6mg MLT two hours before bedtime
| | [underlined: Sleep Disorder: Sleep disturbance] | | | | | [underlined: Frequency and Duration]
| | accompanying mild cognitive impairment | | | | | 6mg/day for 10 days
Jockovich, M | 2000 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 22 | mean: | 28.2 | Enrolled: | 19 | Double-blind | Not specified
| | range: | NS | Analyzed: | 19 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 15 | Enrolled: | 19 | | [underlined: Dosage and Timing]
| | male: | 4 | Analyzed: | 19 | | 1 mg MLT thirty to sixty minutes before daytime sleep
| | [underlined: Sleep Disorder: Night-shift disorder] | | | | | [underlined: Frequency and Duration]
| | | | | | | 1 tablet/day for 3 consecutive days
Jorgensen | 1998 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 22 | mean: | 32 | Enrolled: | 20 | Double-blind | Not specified
| | range: | 25–40 | Analyzed: | 18 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 2 | Enrolled: | 20 | | [underlined: Dosage and Timing]
| | male: | 16 | Analyzed: | 18 | | 10 mg MLT the morning after each night shift
| | [underlined: Sleep Disorder: Night-shift disorder] | | | | | [underlined: Frequency and Duration]
| | | | | | | 1 tablet/day for varied amount of time
Kayumov, L | 2001 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 22 | mean (SD): | | Enrolled: | 22 | Double-blind | Not specified
| | female: | 30.8(12.4) | Analyzed: | 19 | Cross-over | [underlined: Route of Administration]
| | male: | 35.6(14.0) | [underlined: Control Group] | | | Oral
| | [underlined: Gender] | | Enrolled: | 22 | | [underlined: Dosage and Timing]
| | female: | 7 | Analyzed: | 19 | | 5 mg MLT, timing: NS
| | male: | 15 | | | | [underlined: Frequency and Duration]
| | [underlined: Sleep Disorder: Delayed sleep phase] | | | | | 5mg/day for 4 weeks
| | syndrome
Matsumomo M | 1999 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Formulation]
Quality Score | 19 | mean (SD): | 23.7(1.3) | Enrolled: | 6 | Single-blind | Not specified
| | range: | NS | Analyzed: | 6 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Not specified
| | female: | 0 | Enrolled: | 6 | | [underlined: Dosage and Timing]
| | male: | 6 | Analyzed: | 6 | | 10 mg MLT at 1000h
| | | | | | | [underlined: Frequency and Duration]
| | | | | | | Not specified
McArthur, A | 1998 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 21 | mean (SD): | 10.1(1.5) | Enrolled: | 9 | Double-blind | Immediate-release melatonin
| | range: | 4–17 yrs | Analyzed: | 9 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral or by gastrostomy tube
| | female: | 9 | Enrolled: | 9 | | [underlined: Dosage and Timing]
| | male: | 0 | Analyzed: | 9 | | Dosage based on individual body weight, range 2.5–7.5mg taken one hour before bedtime
| | [underlined: Sleep Disorder: Sleep dysfunction] | | | | | [underlined: Frequency and Duration]
| | accompanying Rett syndrome | | | | | 1 capsule/day for 4 weeks
Monti, J | 1999 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Formulation]
Quality Score | 21 | mean: | NS | Enrolled: | 10 | Single-blind | Not specified
| | range: | 66–86 | Analyzed: | 10 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 2 | Enrolled: | 10 | | [underlined: Dosage and Timing]
| | male: | 8 | Analyzed: | 10 | | 3 mg MLT taken in the evenings
| | [underlined: Sleep Disorder: Insomnia] | | | | | [underlined: Frequency and Duration]
| | | | | | | 3mg/day for 14 days
Naguib, M | 1999 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 25 | mean: | 29.7 | 5mg and 15mg MLT | | Double-blind | Not specified
| | range: | 19–44 | Enrolled: | 25 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | Analyzed: | 25 | | Oral
| | female: | 75 | [underlined: Control Group] | | | [underlined: Dosage and Timing]
| | male: | 0 | Enrolled: | 25 | | 5mg and 15 mg MLT taken approximately one and a half hours before induction of general anaesthesia
| | [underlined: Sleep Disorder: None] | | Analyzed: | 25 | | [underlined: Frequency and Duration]
| | | | | | | Single dose
O'Callaghan, F | 1999 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 20 | median: | 11 | Enrolled: | 7 | Double-blind | Not specified
| | range: | Feb-28 | Analyzed: | 7 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 4 | Enrolled: | 7 | | [underlined: Dosage and Timing]
| | male: | 3 | Analyzed: | 7 | | 5 mg MLT thirty minutes before usual bedtime
| | [underlined: Sleep Disorder: Sleep disorder] | | | | | [underlined: Frequency and Duration]
| | accompanying Tuberous Sclerosis | | | | | 1 capsule/day for 2 weeks
Paccoti, P | 1987 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Formulation]
Quality Score | 18 | mean: | NS | Enrolled: | 6 | Double-blind | Not stated
| | range: | 22–32 | Analyzed: | 6 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 0 | Enrolled: | 6 | | [underlined: Dosage and Timing]
| | male: | 6 | Analyzed: | 6 | | 100mg MLT, timing: NS
| | [underlined: Sleep Disorder: None] | | | | | [underlined: Frequency and Duration]
| | | | | | | Single dose
Petrie | 1989 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 20 | mean: | NS | Enrolled: | 20 | Double-blind | Not specified
| | range: | 28–68 | Analyzed: | 20 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Not specified
| | female: | 8 | Enrolled: | 20 | | [underlined: Dosage and Timing]
| | male: | 12 | Analyzed: | 20 | | 5 mg MLT taken between 1000h and 1200h local time
| | [underlined: Sleep Disorder: Jet-lag] | | | | | [underlined: Frequency and Duration]
| | | | | | | One dose for 3 days before flight, during flight, and once a day for 3 days after arrival
Petrie | 1993 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 20 | mean (SD): | 34.9(7.7) | Early MLT | | Double-blind | Not specified
| | range: | 25–52 | Enrolled: | NS | Parallel | [underlined: Route of Administration]
| | [underlined: Gender] | | Analyzed: | NS | | Oral
| | female: | 26 | Late MLT | | | [underlined: Dosage and Timing]
| | male: | 26 | Enrolled: | NS | | 5 mg MLT taken between 0700h–0800h
| | [underlined: Sleep Disorder: Jet lag] | | Analyzed: | NS | | [underlined: Frequency and Duration]
| | | | [underlined: Control Group] | | | 5 mg early MLT for 8 days, 5mg late MLT for 5 days
| | | | Enrolled: | NS
| | | | Analyzed: | NS
Seabra, M.L. | 2000 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 20 | mean (SD): | 29(1) | Enrolled: | 30 | Double-blind | Not specified
| | range: | 25–55 | Analyzed: | 30 | Parallel | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 0 | Enrolled: | 10 | | [underlined: Dosage and Timing]
| | male: | 40 | Analyzed: | 10 | | 10 mg MLT taken one hour before sleep time (approximately 2200h)
| | [underlined: Sleep Disorder: None] | | | | | [underlined: Frequency and Duration]
| | | | | | | 1 capsule/day for 28 days
Serfaty, M | 2002 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 22 | mean (SD): | 84.2(7.6) | Enrolled: | 44 | Double-blind | Slow-release
| | range: | NS | Analyzed: | 25 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 9 | Enrolled: | 44 | | [underlined: Dosage and Timing]
| | male: | 16 | Analyzed: | 25 | | 6 mg MLT taken at usual bedtime
| | [underlined: Sleep Disorder: Sleep disturbance] | | | | | [underlined: Frequency and Duration]
| | accompanying dementia | | | | | 1 tablet/day for two weeks
Shamir, E | 2000 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 22 | mean (SD): | 74.0 (9.5) | Enrolled: | 10 | Double-blind | Not specified
| | range: | 55–91 | Analyzed: | 10 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 11 | Enrolled: | 9 | | [underlined: Dosage and Timing]
| | male: | 8 | Analyzed: | 9 | | 2 mg MLT taken at 2000h
| | [underlined: Sleep Disorder: None] | | | | | [underlined: Frequency and Duration]
| | | | | | | 2 mg/day for 4 weeks
Shamir, E | 2001 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 24 | mean (SD): | 64.2(14.3) | Enrolled: | 10 | Double-blind | Controlled-release
| | range: | 28–82 | Analyzed: | 8 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Not specified
| | female: | 11 | Enrolled: | 12 | | [underlined: Dosage and Timing]
| | male: | 11 | Analyzed: | 12 | | 2.5 mg MLT, timing: NS
| | [underlined: Sleep Disorder: Jet-lag] | | | | | [underlined: Frequency and Duration]
| | | | | | | 2.5 mg/day for 6 weeks
Smits, MG | 2003 | [underlined: Age (Years)] | | 3 treatments | | RCT | [underlined: Formulation]
Quality Score | 25 | mean (SD): | | FR =0.5mg, 5mg | | Double-blind | Fast-release and controlled-release
| | Treatment group | 9.2 (2.1) | CR= 2mg | | Parallel | [underlined: Route of Administration]
| | Control group | 10.1 (1.7) | [underlined: Treatment Groups] | | | Oral
| | range: | NS | Enrolled: | NS | | [underlined: Dosage and Timing]
| | [underlined: Gender] | | Analyzed: | NS | | 5 mg MLT at 1900h
| | Treatment group | | [underlined: Control Group] | | | [underlined: Frequency and Duration]
| | female: | 20 | Enrolled: | NS | | 5mg/day for 4 weeks
| | male: | 6 | Analyzed: | NS
| | Control group
| | female: | 6
| | male: | 29
| | [underlined: Sleep Disorder: Idiopathic chronic]
| | sleep-onset insomnia
Suhner, A | 1998 | [underlined: Age (Years)] | | 3 treatment groups | | RCT | [underlined: Formulation]
Quality Score | 20 | mean: | 36 | 0.5 mg FR MLT | | Double-blind | Controlled-release or Fast-release
| | range: | 20–65 | 5.0 mg FR MLT | | Parallel | [underlined: Route of Administration]
| | [underlined: Gender] | | 2 mg CR MLT | | | Not specified
| | female: | 148 | [underlined: Treatment Groups] | | | [underlined: Dosage and Timing]
| | male: | 172 | Enrolled: | NS | | 0.5 mg FR, 5.0 mg FR, 2 mg CR at bedtime after an eastward flight on the first day post-flight at 2310(+/-1.52h) and on the following days at 2329h(+/-1.12h)
| | [underlined: Sleep Disorder: Jet-lag] | | Analyzed: | NS | | [underlined: Frequency and Duration]
| | | | [underlined: Control Group] | | | One dose/day for 4 days after eastward flight
| | | | Enrolled: | NS
| | | | Analyzed: | NS
Suhner, A | 2001 | [underlined: Age (Years) of Compliant (137)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 19 | mean: | 41.3 | Enrolled: | 40 | Double-blind | Not specified
| | range: | 18–68 | Analyzed: | 35 | Parallel | [underlined: Route of Administration]
| | [underlined: Gender of Compliant (137)] | | [underlined: Control Group] | | | Not specified
| | female: | 67 | Enrolled: | 40 | | [underlined: Dosage and Timing]
| | male: | 70 | Analyzed: | 39 | | 5mg MLT or 10mg zolpidem taken on the return flight (eastbound) between 1700h and 2100h local time at the place of departure depending on the flight schedule
| | [underlined: Sleep Disorder: Jet-lag] | | | | | [underlined: Frequency and Duration]
| | | | | | | 4 consecutive days post-flight at bedtime.
Van Wieringen | 2001 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 21 | mean (SD): | 33.4(10.7) | Enrolled: | 40 | Double-blind | Not specified
| | range: | NS | Analyzed: | 29 | Parallel | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 59 | Enrolled: | 41 | | [underlined: Dosage and Timing]
| | male: | 22 | Analyzed: | 21 | | 5mg MLT taken five hours before individual melatonin onset time
| | [underlined: Sleep Disorder: Delayed melatonin] | | | | | [underlined: Frequency and Duration]
| | onset as well as fatigue and sleep disturbance | | | | | 1 tablet/day for 4 weeks
Wright, SW | 1998 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | RCT | [underlined: Formulation]
Quality Score | 17 | mean: | 38.6 | Enrolled: | 20 | Double-blind | Not specified
| | range: | 32–45 | Analyzed: | 15 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Oral
| | female: | 3 | Enrolled: | 20 | | [underlined: Dosage and Timing]
| | male: | 12 | Analyzed: | 15 | | 5 mg MLT taken 30 minutes before bedtime in the evening
| | [underlined: Sleep Disorder: Night-shift disorder] | | | | | [underlined: Frequency and Duration]
| | | | | | | 5mg/night for 3 nights following shift work
Wright, J | 1986 | [underlined: Age (Years)] | | [underlined: Treatment Group] | | CCT | [underlined: Formulation]
Quality Score | 17 | mean: | NS | Enrolled: | 6 | Double-blind | Not specified
| | range: | 22–46 | Analyzed: | 6 | Cross-over | [underlined: Route of Administration]
| | [underlined: Gender] | | [underlined: Control Group] | | | Not specified
| | female: | 2 | Enrolled: | 6 | | [underlined: Dosage and Timing]
| | male: | 10 | Analyzed: | 6 | | 2mg MLT at 1700h
| | | | | | | [underlined: Frequency and Duration]
| | | | | | | 2mg/day for 4 weeks

Abbreviations: RCT: randomized controlled trial, CCT: controlled clinical trial, MLT: melatonin, FS: fast-release, SR: slow-release, SD: standard deviation, SE: standard error, mg: milligrams, h: hours, NS: not specified

Control group received placebo unless otherwise indicated

Evidence Table C-9: Melatonin Compared to Other Pharmacological Treatments for Sleep Disorders: Study Characteristics

Author | Year | Population | | Sample Size | N | Study Design | Intervention
Ferini-Strambi, L | 1993 | [underlined: Age (Years)] | | [underlined: MLT Group] | | CCT | [underlined: Comparison:]
Quality Score | 14 | Mean (SD): | 25.3 (3.6) | Enrolled: | 6 | | MLT vs.Triazolam vs. PLB
| | Range: | NS | Analyzed: | 6 | Double-blind | [underlined: Route of administration:]
| | [underlined: Gender:] | | [underlined: Triazolam Group] | | | Oral
| | Female: | 0 | Enrolled: | 6 | Cross-over | [underlined: Dosage and Timing:]
| | Male: | 6 | Analyzed: | 6 | | MLT: 100 mg; Triazolam: 0.125 mg; PLB (NS) at 2230 h
| | [underlined: Sleep disorder: None] | | [underlined: Placebo Group] | | | [underlined: Frequency and Duration:]
| | | | Enrolled: | 6 | | Single dose
| | | | Analyzed: | 6
Holmes, A | 2002 | [underlined: Age (Years)] | | [underlined: MLT Group] | | CCT | [underlined: Comparison:]
Quality Score | 15 | Mean (SEM): | 20.3 (0.6) | Enrolled: | 12 | Double-blind | MLT vs. Zopiclone vs. PLB (Lactose)
| | Range: | 19–25 | Analyzed: | 12 | Cross-over | [underlined: Route of administration:]
| | [underlined: Gender] | | [underlined: Zopiclone Group] | | | Oral
| | Female: | 5 | Enrolled: | 12 | | [underlined: Dosage and Timing:]
| | Male: | 7 | Analyzed: | 12 | | MLT: 5 mg; Zopiclone: 7.5 mg; PLB: 10 mg at 1400 h
| | [underlined: Sleep disorder: None] | | [underlined: PLB Group] | | | [underlined: Frequency and Duration:]
| | | | Enrolled: | 12 | | Single dose
Satomura, T | 2001 | [underlined: Age (Years)] | | [underlined: MLT Group] | | RCT | [underlined: Comparison:]
Quality Score | 11 | Mean (SD): | 23.7 (1.7) | Enrolled: | 7 | Double-blind | MLT vs.Triazolam vs. PLB (Lactose)
| | Range: | NS | Analyzed: | 7 | Cross-over | [underlined: Route of administration:]
| | [underlined: Gender:] | | [underlined: Triazolam Group] | | | Oral
| | Female: | 0 | Enrolled: | 7 | | [underlined: Dosage and Timing:]
| | Male: | 7 | Analyzed: | 7 | | MLT: 1 mg, 3 mg, 6 mg; Triazolam: NS; PLB: NS at 1330 h
| | [underlined: Sleep disorder: None] | | [underlined: PLB Group] | | | [underlined: Frequency and Duration:]
| | | | Enrolled: | 7 | | Single dose
| | | | Analyzed: | 7
Suhner, A | 2001 | [underlined: Age (Years)] | | [underlined: MLT Group] | | RCT | [underlined: Comparison:]
Quality Score | 20 | Mean (SD): | 41.3 (NS) | Enrolled: | 35 | Double-blind | MLT vs. Zolpidem vs. PLB
| | Range: | 18–68 | Analyzed: | 34 | Parallel | [underlined: Route of administration:]
| | [underlined: Gender:] | | [underlined: Zopiclone Group] | | | Oral
| | Female: | 67 | Enrolled: | 34 | | [underlined: Dosage and Timing:]
| | Male: | 70 | Analyzed: | 34 | | MLT: 5 mg; Zolpidem: 10 mg; PLB: NS between 1700–2100 h at departure time and then at local bedtime (Clock time: NS)
| | [underlined: Sleep disorder: Jet-lag] | | [underlined: PLB Group] | | | [underlined: Frequency and Duration:]
| | | | Enrolled: | 39 | | Single dose during flight and then once daily at bedtime for 4 [underlined: consecutive days]
| | | | Analyzed: | 37

Abbreviations: RCT: randomized controlled trial, CCT: controlled clinical trial, MLT: melatonin, FR: fast-release, SR: slow-release, SD: standard deviation, SEM: standard error of the mean, mg: milligrams, h: hours, NS: not specified