# Appendix B: Quality Assessment and Data Extraction Forms

## Form B-1: Jadad Scale and Allocation Concealment for Quality Assessment of RCTs

## Form B-2: Downs and Black Checklist for Quality Assessment of non- RCTs

## Form B-3: Data Extraction Form

GENERAL INFORMATION

To be extracted from all studies.
RECORD ID | QUESTIONS OF REVIEW TO WHICH STUDY IS RELEVANT | REVIEWER/ DATE | VERIFIER/ DATE | FIRST AUTHOR | YEAR OF PUBLICATION | LANGUAGE OF PUBLICATION
COUNTRY WHERE STUDY TOOK PLACE | FUNDING | | OBJECTIVE (S) | DESIGN AS REPORTED BY AUTHOR | PROTOCOL | DESIGN AS JUDGED BY REVIEWER
| PRIVATE | PUBLIC
POPULATION | INCLUSION CRITERIA | EXCLUSION CRITERIA | NUMBER OF PEOPLE ELIGIBLE FOR THE STUDY | NUMBER OF PEOPLE ENROLLED IN THE STUDY | NUMBER AND TYPE OF COMPARISON GROUPS | NUMBER OF PEOPLE ALLOCATED TO EACH COMPARISON GROUP
NUMBER OF PARTICIPANTS WHO WITHDREW FROM THE STUDY AND GROUP FROM WHICH THEY WITHDREW | INTERVENTION(S) | PRIMARY OUTCOME(S) | SECONDARY OUTCOME(S) | DO PARTICIPANTS SUFFER FROM A METABOLIC DISORDER? IF SO, WHAT TYPE? | ARE PARTICIPANTS ON ANY MEDICATION? IF SO, WHAT TYPE?
BASELINE CHARACTERISTICS OF PARTICIPANTS AS A WHOLE AND ACCORDING TO TREATMENT GROUP
GENDER | AGE | ETHNICITY | OTHER
TREATMENT PERIOD | FOLLOW-UP PERIOD | WAS AN INTENTION TO TREAT ANALYSIS PLANNED OR CONDUCTED? | OTHER | COMMENTS | CONCLUSION
To be extracted from studies relevant to the following questions of the review: 2, 5, 9, 12
FORMULATION OF MELATONIN ADMINISTERED TO PARTICIPANTS | CONTENT AND QUALITY OF FORMULATION OF MELATONIN ADMINISTERED TO PARTIPANTS | DOSAGE, REGIMEN AND ROUTE OF MELATONIN ADMINISTRATION
To be extracted from studies relevant to the following questions of the review: 2, 5, 9
TYPE OF SLEEP DISORDER FROM WHICH PARTICIPANTS SUFFER
PRIMARY SLEEP DISORDER | SECONDARY SLEEP DISORDER | SLEEP RESTRICTION

OUTCOME MEASURES

To be extracted from studies relevant to the following questions of the review: 2, 3, 6
[MLT] IN SERUM | [MLT] IN URINE | [MLT] IN SALIVA
To be extracted from studies relevant to the following questions of the review: 3, 5, 9
SLEEPINESS/ FATIGUE/ ALERTNESS/ MOOD IN THE EVENING | SLEEPINESS/ FATIGUE/ ALERTNESS/ MOOD IN THE DAYTIME | SLEEP ONSET LATENCY (SOL) | TOTAL SLEEP TIME (TST) | SLEEP QUALITY | WAKEFULNESS AFTER SLEEP ONSET (WASO)
SLEEP EFFICIENCY | SLEEP ARCHITECTURE | REM LATENCY | NUMBER OF REM EPISODES | REM DURATION | DIM LIGHT MELATONIN ONSET (DLMO) | OTHER