# Appendix A: Exact Search Strings

## Search Strategies

Evidence Table A-1: MEDLINE: melatonin and sleep disorders

Evidence Table A-1: MEDLINE: melatonin and sleep disorders

MEDLINE | 1966 to June, Week 3, 2003
Set # and Keyword Search
1. exp MELATONIN/
2. melatonin.mp.
3. melatonine.mp.
4. 73-31-4.rn.
5. 5-Methoxy-N-acetyltryptamine.mp.
6. N-Acetyl-5-methoxytryptamine.mp.
7. luzindole.mp.
8. or/1–7
9. exp Sleep Disorders/
10. sleep disorder$.mp.
11. dyssomnia$.mp.
12. insomnia$.mp.
13. narcoleps$.mp.
14. hypersomnia$.mp.
15. central alveolar hypoventilat$.mp.
16. periodic limb movement$.mp.
17. restless leg.mp.
18. nocturnal eating.mp.
19. nocturnal drinking.mp.
20. time-zone change$.mp.
21. jet lag.mp.
22. parasomnia$.mp.
23. confusional arousal$.mp.
24. rhythmic movement disorder$.mp.
25. nocturnal leg cramp$.mp.
26. nightmare$.mp.
27. nocturnal paroxysmal dystonia$.mp.
28. sudden unexplained nocturnal death syndrome.mp.
29. SUNDS.mp.
30. snoring.mp.
31. snore$.mp.
32. congenital central hypoventilation.mp.
33. sudden infant death syndrome$.mp.
34. exp Sudden Infant Death/
35. SIDS.mp.
36. subwakefulness.mp.
37. fragmentary myoclonus.mp.
38. hypnagogic hallucination$.mp.
39. (sleep$ or circadian$).mp.
40. exp Sleep/
41. exp arousal/
42. or/9–41
43. 8 and 42
44. RANDOMIZED CONTROLLED TRIAL.pt.
45. CONTROLLED CLINICAL TRIAL.pt.
46. RANDOMIZED CONTROLLED TRIALS/
47. RANDOM ALLOCATION/
48. DOUBLE BLIND METHOD/
49. SINGLE-BLIND METHOD/
50. or/44–49
51. ANIMAL/ not HUMAN/
52. 50 not 51
53. CLINICAL TRIAL.pt.
54. exp CLINICAL TRIALS/
55. (clin$ adj25 trial$).ti,ab.
56. ((singl$ or doubl$ or trebl$ or tripl$) adj25 (blind$ or mask$)).ti,ab.
57. PLACEBOS/
58. placebo$.ti,ab.
59. random$.ti,ab.
60. RESEARCH DESIGN/
61. or/53–60
62. 61 not 51
63. 62 not 52
64. COMPARATIVE STUDY/
65. exp EVALUATION STUDIES/
66. FOLLOW UP STUDIES/
67. PROSPECTIVE STUDIES/
68. (control$ or prospectiv$ or volunteer$ or cohort$ or case series).ti,ab,sh.
69. or/64–68
70. 69 not 51
71. 70 not (52 or 63)
72. 52 or 63 or 70
73. meta-analysis.pt.
74. (meta-anal$ or metaanal$).mp.
75. (((quantitativ$ adj3 review$1) or quantitativ$) adj3 overview$).mp.
76. (((systematic adj3 review$1) or systematic) adj3 overview$1).mp.
77. (((methodologic adj3 review$1) or methodologic) adj3 overview$).mp.
78. (integrat$ adj5 research).mp.
79. (quantitativ$ adj3 synthes$).mp.
80. or/73–79
81. review.pt. or (review$ or overview$).mp.
82. (medline or medlars or pubmed or index medicus or embase or cochrane).mp.
83. (scisearch or web of science or psycinfo or psychinfo or cinahl or cinhal).mp.
84. (excerpta medica or psychlit or psyclit or current contents or science citation index or sciences citation index).mp.
85. (hand search$ or manual search$).mp.
86. ((((electronic adj3 database$) or bibliographic) adj3 database$) or periodical index$).mp.
87. (pooling or pooled or mantel haenszel).mp.
88. (peto or der simonian or dersimonian or fixed effect$).mp.
89. ((combine$ or combining) adj5 (data or trial or trials or studies or study or result or results)).mp.
90. or/82–89
91. 81 and 90
92. 80 or 91
93. (hta$ or health technology assessment$ or biomedical technology assessment$).mp.
94. technology assessment, biomedical/ or biomedical technology asssessment/
95. 93 or 94
96. 92 or 95
97. limit 43 to review
98. 43 and 96
99. 97 or 98
100. 43 and 72
101. 99 not 100
102. limit 100 to human
103. limit 101 to human

Evidence Table A-2: EMBASE: melatonin and sleep disorders

Evidence Table A-2 : EMBASE: melatonin and sleep disorders

EMBASE | 1988 to Week 26, 2003
Set # and Keyword Search
1. exp MELATONIN/
2. melatonin.mp.
3. melatonine.mp.
4. 73-31-4.rn.
5. 5-Methoxy-N-acetyltryptamine.mp.
6. N-Acetyl-5-methoxytryptamine.mp.
7. luzindole.mp.
8. or/1–7
9. exp Sleep Disorders/
10. sleep disorder$.mp.
11. dyssomnia$.mp.
12. insomnia$.mp.
13. narcoleps$.mp.
14. hypersomnia$.mp.
15. central alveolar hypoventilat$.mp.
16. periodic limb movement$.mp.
17. restless leg.mp.
18. nocturnal eating.mp.
19. nocturnal drinking.mp.
20. time-zone change$.mp.
21. jet lag.mp.
22. parasomnia$.mp.
23. confusional arousal$.mp.
24. rhythmic movement disorder$.mp.
25. nocturnal leg cramp$.mp.
26. nightmare$.mp.
27. nocturnal paroxysmal dystonia$.mp.
28. sudden unexplained nocturnal death syndrome.mp.
29. SUNDS.mp.
30. snoring.mp.
31. snore$.mp.
32. congenital central hypoventilation.mp.
33. sudden infant death syndrome$.mp.
34. exp Sudden Infant Death/
35. SIDS.mp.
36. subwakefulness.mp.
37. fragmentary myoclonus.mp.
38. hypnagogic hallucination$.mp.
39. (sleep$ or circadian$).mp.
40. exp Sleep/
41. exp arousal/
42. exp wakefulness/
43. or/9–42
44. exp Melatonin Receptor/
45. exp MELATONIN DERIVATIVE/
46. or/8,44–45
47. 46 and 43
48. Randomized Controlled Trial/
49. exp Randomization/
50. Double Blind Procedure/
51. Single Blind Procedure/
52. or/48–51
53. Clinical Trial/
54. (clin$ adj25 trial$).mp.
55. ((singl$ or doubl$ or trebl$ or tripl$) adj25 (blind$ or mask$)).mp.
56. exp Placebo/
57. (placebo$ or random$).mp.
58. exp Methodology/
59. exp Comparative Study/
60. exp Evaluation/
61. exp Follow Up/
62. exp Prospective Study/
63. (control$ or prospectiv$ or volunteer$).mp.
64. or/53–63
65. 52 or 64
66. (cohort$ or case series).mp.
67. exp cohort analysis/
68. exp Case Study/
69. or/66–68
70. or/65,69
71. meta-analysis.pt.
72. (meta-anal$ or metaanal$).mp.
73. (((quantitativ$ adj3 review$1) or quantitativ$) adj3 overview$).mp.
74. (((systematic adj3 review$1) or systematic) adj3 overview$1).mp.
75. (((methodologic adj3 review$1) or methodologic) adj3 overview$).mp.
76. (integrat$ adj5 research).mp.
77. (quantitativ$ adj3 synthes$).mp.
78. or/71–77
79. review.pt. or (review$ or overview$).mp.
80. (medline or medlars or pubmed or index medicus or embase or cochrane).mp.
81. (scisearch or web of science or psycinfo or psychinfo or cinahl or cinhal).mp.
82. (excerpta medica or psychlit or psyclit or current contents or science citation index or sciences citation index).mp.
83. (hand search$ or manual search$).mp.
84. ((((electronic adj3 database$) or bibliographic) adj3 database$) or periodical index$).mp.
85. (pooling or pooled or mantel haenszel).mp.
86. (peto or der simonian or dersimonian or fixed effect$).mp.
87. ((combine$ or combining) adj5 (data or trial or trials or studies or study or result or results)).mp.
88. or/80–87
89. 79 and 88
90. 78 or 89
91. (hta$ or health technology assessment$ or biomedical technology assessment$).mp.
92. technology assessment, biomedical/ or biomedical technology asssessment/
93. 91 or 92
94. 90 or 93
95. Review/
96. 94 or 95
97. 47 and 70
98. 47 and 96
99. limit 97 to human
100. limit 98 to human
101. Nonhuman/
102. 99 not 101
103. 100 not 101

Evidence Table A-3: CINAHL: melatonin and sleep disorders

Evidence Table A-3: CINAHL: melatonin and sleep disorders

CINAHL | 1982 to June Week 4, 2003
Set # and Keyword Search
1. exp MELATONIN/
2. melatonin.mp.
3. melatonine.mp.
4. 73-31-4.rn.
5. 5-Methoxy-N-acetyltryptamine.mp.
6. N-Acetyl-5-methoxytryptamine.mp.
7. luzindole.mp.
8. or/1–7
9. exp Sleep Disorders/
10. sleep disorder$.mp.
11. dyssomnia$.mp.
12. insomnia$.mp.
13. narcoleps$.mp.
14. hypersomnia$.mp.
15. central alveolar hypoventilat$.mp.
16. periodic limb movement$.mp.
17. restless leg.mp.
18. nocturnal eating.mp.
19. nocturnal drinking.mp.
20. time-zone change$.mp.
21. jet lag.mp.
22. parasomnia$.mp.
23. confusional arousal$.mp.
24. rhythmic movement disorder$.mp.
25. nocturnal leg cramp$.mp.
26. nightmare$.mp.
27. nocturnal paroxysmal dystonia$.mp.
28. sudden unexplained nocturnal death syndrome.mp.
29. SUNDS.mp.
30. snoring.mp.
31. snore$.mp.
32. congenital central hypoventilation.mp.
33. sudden infant death syndrome$.mp.
34. exp Sudden Infant Death/
35. SIDS.mp.
36. subwakefulness.mp.
37. fragmentary myoclonus.mp.
38. hypnagogic hallucination$.mp.
39. (sleep$ or circadian$).mp.
40. exp Sleep/
41. exp arousal/
42. exp wakefulness/
43. or/9–42
44. 8 and 43
45. random assignment/
46. random sample/
47. crossover design/
48. exp clinical trials/
49. exp comparative studies/
50. “control (research)”.mp.
51. control group/
52. factorial design/
53. quasi-experimental studies/
54. nonrandomized trials/
55. placebos/
56. meta analysis/
57. clinical nursing research.mp. or clinical research/
58. community trials/ or experimental studies/ or one-shot case study/
59. community trials/ or experimental studies/ or one-shot case study/ or pretest-posttest design/ or solomon four-group design/ or static group comparison/ or study design/
60. (clinical trial or systematic review).pt.
61. random$.mp.
62. ((singl$ or doubl$ or tripl$ or trebl$) adj10 (blind$ or mask$)).mp.
63. (cross?over or placebo$ or control$ or factorial or sham$).mp.
64. ((clin$ or intervention$ or compar$ or experiment$ or preventive or therapeutic) adj10 trial$).mp.
65. (meta?analy$ or systematic review$).mp.
66. or/45–65
67. convenience sample/
68. exp research, allied health/ or research, medical/ or research, nursing/
69. research question/
70. nursing practice, research-based/
71. research methodology/
72. exp evaluation research/
73. [evaluation/mt]
74. concurrent prospective studies/ or prospective studies/
75. (nursing interventions or research).pt.
76. or/67–75
77. 66 or 76
78. 44 and 77
79. meta-analysis.pt.
80. (meta-anal$ or metaanal$).mp.
81. (((quantitativ$ adj3 review$1) or quantitativ$) adj3 overview$).mp.
82. (((systematic adj3 review$1) or systematic) adj3 overview$1).mp.
83. (((methodologic adj3 review$1) or methodologic) adj3 overview$).mp.
84. (integrat$ adj5 research).mp.
85. (quantitativ$ adj3 synthes$).mp.
86. or/79–85
87. review.pt. or (review$ or overview$).mp.
88. (medline or medlars or pubmed or index medicus or embase or cochrane).mp.
89. (scisearch or web of science or psycinfo or psychinfo or cinahl or cinhal).mp.
90. (excerpta medica or psychlit or psyclit or current contents or science citation index or sciences citation index).mp.
91. (hand search$ or manual search$).mp.
92. ((((electronic adj3 database$) or bibliographic) adj3 database$) or periodical index$).mp.
93. (pooling or pooled or mantel haenszel).mp.
94. (peto or der simonian or dersimonian or fixed effect$).mp.
95. ((combine$ or combining) adj5 (data or trial or trials or studies or study or result or results)).mp.
96. or/88–95
97. 87 and 96
98. 86 or 97
99. (hta$ or health technology assessment$ or biomedical technology assessment$).mp.
100. technology assessment, biomedical/ or biomedical technology asssessment/
101. 99 or 100
102. 98 or 101
103. limit 44 to (review or systematic review)
104. or/102–103
105. 44 and 104
106. cohort.mp.
107. case series.mp.
108. exp case studies/
109. case study.pt.
110. or/106–108
111. 44 and 110
112. 105 not 78
113. 78 or 111

Evidence Table A-4: CENTRAL: melatonin and sleep disorders

Evidence Table A-4: CENTRAL: melatonin and sleep disorders

CENTRAL - Issue 2 2003 | 3^rd^ Quarter, 2003
Set # and Keyword Search
1. MELATONIN single term (MeSH) 316
2. melatonin 454
3. melatonine 2
4. 73-31-4 0
5. 5-methoxy-n-acetyltryptamine 0
6. n-acetyl-5-methoxytryptamine 6
7. luzindole 0
8. (1 or 2 or 3 or 4 or 5 or 6 or 7) 456
9. SLEEP DISORDERS explode all trees (MeSH) 1643
10. dyssomnia* 3
11. insomnia* 1625
12. narcoleps* 73
13. hypersomnia* 66
14. (central next alveolar next hypoventilat*) 0
15. (periodic next limb next movement*) 30
16. (restless next leg) 9
17. (nocturnal next eating) 1
18. (nocturnal next drinking) 0
19. (time-zone next change*) 0
20. (jet next lag) 33
21. parasomnia* 12
22. (confusional next arousal*) 0
23. (rhythmic next movement next disorder*) 0
24. (nocturnal next leg next cramp*) 20
25. nightmare* 90
26. (nocturnal next paroxysmal next dystonia*) 1
27. (sudden next unexplained next nocturnal next death next syndrome) 0
28. sunds 0
29. snoring 156
30. snore* 76
31. (congential next central next hypoventilation) 0
32. (sudden next infant next death next syndrome*) 41
33. sids 27
34. subwakefulness 0
35. (fragmentary next myoclonus) 0
36. (hypnagogic next hallucination*) 2
37. sleep* or circadian* 8680
38. SLEEP explode all trees (MeSH) 2300
39. AROUSAL explode all trees (MeSH) 3330
40. (9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35 or 36 or 37 or 38 or 39) 12449
41. (8 and 40) 290

Evidence Table A-5: Science Citation Index: melatonin and sleep disorders

Evidence Table A-5: Science Citation Index: melatonin and sleep disorders

Science Citation Index | | | Search performed July 4, 2003
Set # | Results | Search History
28 | 265 | 21 OR 22 OR 23 OR 24 OR 25 OR 26 OR 27 DocType=All document types; Language=All languages; Database(s)=SCI-EXPANDED, SSCI, A&HCI; Timespan=1975-2003
27 | 44 | 8 AND 17 DocType=All document types; Language=All languages; Database(s)=SCI-EXPANDED, SSCI, A&HCI; Timespan=1975-2003
26 | 177 | 8 AND 16 DocType=All document types; Language=All languages; Database(s)=SCI-EXPANDED, SSCI, A&HCI; Timespan=1975-2003
25 | 27 | #8 AND #15 DocType=All document types; Language=All languages; Database(s)=SCI-EXPANDED, SSCI, A&HCI; Timespan=1975-2003
24 | 151 | 8 AND 14 DocType=All document types; Language=All languages; Database(s)=SCI-EXPANDED, SSCI, A&HCI; Timespan=1975-2003
23 | 9 | 8 AND 13 DocType=All document types; Language=All languages; Database(s)=SCI-EXPANDED, SSCI, A&HCI; Timespan=1975-2003
22 | 18 | 8 AND 12 DocType=All document types; Language=All languages; Database(s)=SCI-EXPANDED, SSCI, A&HCI; Timespan=1975-2003
21 | 12 | 8 AND 11 DocType=All document types; Language=All languages; Database(s)=SCI-EXPANDED, SSCI, A&HCI; Timespan=1975-2003
20 | 48 | #18 OR #19 DocType=All document types; Language=All languages; Database(s)=SCI-EXPANDED, SSCI, A&HCI; Timespan=1975-2003
19 | 13 | #8 AND #10 DocType=All document types; Language=All languages; Database(s)=SCI-EXPANDED, SSCI, A&HCI; Timespan=1975-2003
18 | 36 | #8 AND #9 DocType=All document types; Language=All languages; Database(s)=SCI-EXPANDED, SSCI, A&HCI; Timespan=1975-2003
17 | >100,000 | TS=random* DocType=All document types; Language=All languages; Database(s)=SCI-EXPANDED, SSCI, A&HCI; Timespan=1975-2003
16 | 67,296 | TS=placebo* DocType=All document types; Language=All languages; Database(s)=SCI-EXPANDED, SSCI, A&HCI; Timespan=1975-2003
15 | 69,106 | TS=clinical trial* DocType=All document types; Language=All languages; Database(s)=SCI-EXPANDED, SSCI, A&HCI; Timespan=1975-2003
14 | 69,590 | TS=(single-blind*) OR TS=(double-blind*) DocType=All document types; Language=All languages; Database(s)=SCI-EXPANDED, SSCI, A&HCI; Timespan=1975-2003
13 | 68,166 | TS=cohort* OR TS=case series DocType=All document types; Language=All languages; Database(s)=SCI-EXPANDED, SSCI, A&HCI; Timespan=1975-2003
12 | >100,000 | TS=follow up OR TS=prospective DocType=All document types; Language=All languages; Database(s)=SCI-EXPANDED, SSCI, A&HCI; Timespan=1975-2003
11 | 32,268 | TS=randomized controlled trial* OR TS=controlled clinical trial* OR TS=random allocation OR TS=randomly allocated OR TS=research design OR TS=comparative stud* OR TS=evaluation stud* DocType=All document types; Language=All languages; Database(s)=SCI-EXPANDED, SSCI, A&HCI; Timespan=1975-2003
10 | 74,601 | TS=quantitative synthes* OR TS=hta* OR TS=(health technology assessment*) OR TS=(biomedical technology assessment*) OR TS=meta analys* OR TS=meta-analys* OR TS=metaanalys* OR TS=(quantitativ* review*) OR TS=(quantitativ* overview*) OR TS=overview* DocType=All document types; Language=All languages; Database(s)=SCI-EXPANDED, SSCI, A&HCI; Timespan=1975-2003
9 | >100,000 | TS=review* DocType=All document types; Language=All languages; Database(s)=SCI-EXPANDED, SSCI, A&HCI; Timespan=1975-2003
8 | 1,468 | #6 AND #7 DocType=All document types; Language=All languages; Database(s)=SCI-EXPANDED, SSCI, A&HCI; Timespan=1975-2003
7 | 67,627 | TS=sleep disorder* OR TS=dyssomnia* OR TS=insomnia* OR TS=narcoleps* OR TS=hypersomnia* OR TS=central alveolar hypoventilat* OR TS=periodic limb movement* OR TS=restless leg OR TS=nocturnal eating OR TS=nocturnal drinking OR TS=time zone* OR TS=jet lag* OR TS=parasomnia* OR TS=confusional arousal* OR TS=rhythmic movement disorder* OR TS=nocturnal leg cramp* OR TS=nightmare* OR TS=nocturnal paroxysmal dystonia* OR TS=sudden unexplained nocturnal death syndrome* OR TS=SUNDS OR TS=snore* OR TS=snoring OR TS=congenital central hypoventilation OR TS=(sudden infant death syndrome) OR TS=SIDS OR TS=subwakefulness OR TS=fragmentary myoclonus OR TS=hypnagogic hallucination* OR TS=sleep* OR TS=circadian OR TS=arousal OR TS=arouse DocType=All document types; Language=All languages; Database(s)=SCI-EXPANDED, SSCI, A&HCI; Timespan=1975-2003
6 | 11,454 | #1 OR #2 OR #3 OR #4 OR #5 DocType=All document types; Language=All languages; Database(s)=SCI-EXPANDED, SSCI, A&HCI; Timespan=1975-2003
5 | 92 | TS=luzindole DocType=All document types; Language=All languages; Database(s)=SCI-EXPANDED, SSCI, A&HCI; Timespan=1975-2003
4 | 80 | TS=N-Acetyl-5-methoxytryptamine DocType=All document types; Language=All languages; Database(s)=SCI-EXPANDED, SSCI, A&HCI; Timespan=1975-2003
3 | 15 | TS=5-Methoxy-N-acetyltryptamine DocType=All document types; Language=All languages; Database(s)=SCI-EXPANDED, SSCI, A&HCI; Timespan=1975-2003
2 | 1 | TS=73-31-4 DocType=All document types; Language=All languages; Database(s)=SCI-EXPANDED, SSCI, A&HCI; Timespan=1975-2003
1 | 11,450 | TS=melatonin OR TS=melatonine DocType=All document types; Language=All languages; Database(s)=SCI-EXPANDED, SSCI, A&HCI; Timespan=1975-2003

Evidence Table A-6: Global Health [CAB Health]: melatonin and sleep disorders

Evidence Table A-6: Global Health [CAB Health]: melatonin and sleep disorders

Global Health [CAB Health] | | | Search performed July 8, 2003
Set # and Keyword Search
Set | Items | Description
S1 | 203 | MELATONIN OR MELATONINE OR 5?METHOXY?N?ACETYLTRYPTAMINE OR N?ACETYL?5?METHOXYTRYPTAMINE OR LUZINDOLE
S2 | 2735 | SLEEP? OR DYSSOMNIA? OR INSOMNIA? OR NARCOLEPS? OR HYPERSOmnia?
S3 | 287 | PARASOMNIA? OR NIGHTMARE? OR SUNDS OR SNORING OR SNORE? OR SIDS
S4 | 1502 | SUBWAKEFUL? OR AROUS? OR CIRCADIAN
S5 | 0 | CENTRAL(W)ALVEOLAR(W)HYPOVENTILAT?
S6 | 0 | PERIODIC(W)LIMB(W)MOVEMENT?
S7 | 6 | RESTLESS(W)LEG?
S8 | 13 | NOCTURNAL(W)EAT?
S9 | 5 | NOCTURNAL(W)DRINK?
S10 | 9 | TIME?ZONE? OR TIME(W)ZONE?
S11 | 17 | JET?LAG? OR JET(W)LAG?
S12 | 0 | CONFUSIONAL(W)AROUS?
S13 | 0 | RHYTHMIC(W)MOVEMENT(W)DISORDER?
S14 | 4 | NOCTURNAL(W)LEG(W)CRAMP?
S15 | 0 | NOCTURNAL(W)PAROXYSMAL(W)DYSTONIA?
S16 | 1 | SUDDEN(W)UNEXPLAINED(W)NOCTURNAL(W)DEATH(W)SYNDROME?
S17 | 0 | CONGENITAL(W)CENTRAL(W)HYPOVENTILAT?
S18 | 435 | SUDDEN(W)INFANT(W)DEATH?
S19 | 0 | FRAGMENTARY(W)MYOCLUNUS
S20 | 0 | HYPNAGOGIC(W)HALLUCINATION?
S21 | 3 | CATAPLEX? OR NIGHT(W)TERROR?
S22 | 4530 | S2 OR S3 OR S4 OR S7 OR S8 OR S9 OR S10 OR S11 OR S14 OR S16 OR S18 OR S 21
S23 | 36 | S1 AND S22

Evidence Table A-7: PubMed: melatonin and sleep disorders

Evidence Table A-7: PubMed: melatonin and sleep disorders

PubMed | | Search performed July 9, 2002
Set # and Keyword Search
Search | Most Recent Queries | | Time | Result
20 | Search 17 NOT 16 Field: All Fields, Limits: 180 Days, Human | | 14:53:23 | 7
18 | Search 17 NOT 16 | | 14:52:57 | 525
19 | Search 13 AND 14 Field: All Fields, Limits: 180 Days, Human | | 14:52:41 | 21
16 | Search 13 AND 14 | | 14:52:23 | 1146
17 | Search 13 AND 15 | | 14:51:59 | 729
15 | Search (meta analys*) OR (metaanalys*) OR (review*) OR (overview*) OR (quantitative synthes*) OR (HTA) OR (health technology assessment) OR (biomedical technology assessment) OR (systematic[sb]) | | 14:51:29 | 1287351
14 | Search (randomized controlled trial [PTYP] OR drug therapy [SH] OR therapeutic use [SH:NOEXP] OR random* [WORD]) OR (random allocation) OR (randomly allocated) OR (single blind*) OR (double blind*) OR (clinical trial*) OR (placebo*) OR (research design*) OR (comparative stud*) OR (evaluation stud*) OR (follow up stud*) OR (prospective stud*) OR (cohort*) OR (case series) | | 14:51:11 | 2845077
13 | Search #11 AND #12 | | 14:50:53 | 4218
12 | Search ((sleep [MESH]) OR (Sleep Disorders [MESH]) OR (Arousal [MESH]) OR (sleep*) OR (sleep disorder*) OR (dyssomnia*) OR (insomnia*) OR (narcoleps*) OR (hypersomnia*) OR (central alveolar hypoventilat*) OR (periodic limb movement*) OR (nocturnal eating) OR (nocturnal drinking) OR (time-zone*) OR (time zone*) OR (jet lag*) OR (parasomnia*) OR (confusional arousal*) OR (rhythmic movement disorder*) OR (nocturnal leg cramp*) OR (nightmare*) OR (nocturnal paroxysmal dystonia*) OR (sudden unexplained nocturnal death syndrome*) OR (SUNDS) OR (snoring) OR (snore*) OR (congential central hypoventilat*) OR (sudden infant death syndrome*) OR (SIDS) OR (subwakefulness) OR (fragmentary mycoclonus) OR (hypnagogic hallucination*) OR (arous*) OR (circadian)) | | 14:50:17 | 163039
11 | Search (Melatonin [MESH]) OR (Melatonin*) OR (73-31-4) OR (5-Methoxy-N-acetyltryptamine) OR (N-Acetyl-5-methoxytryptamine) OR (luzindole) OR (N-acetyl-methoxytryptamine)) | | 14:49:37 | 10374

BIO ABS

Keyword Search

Search performed July 4, 2003

((randomized controlled trial*) or (controlled clinical trial*) or (random allocation) or (randomly allocated) or (single blind*) or (double blind*) or (clinical trial*) or (placebo*) or (research design*) or (comparative stud*) or (evaluation stud*) or (follow up stud*) or (prospective stud*) or (cohort*) or (case series) or (meta analys*) or (metaanalys*) or (review*) or (overview*) or (quantitative synthes*) or (HTA) or (health technology assessment) or (biomedical technology assessment) or (random*)) and (((Melatonin*) or (73-31-4) or (5-Methoxy-N-acetyltryptamine) or (N-Acetyl-5-methoxytryptamine) or (luzindole) or (N-acetyl-methoxytryptamine) or (N-(2-(5-Methoxy-1H-indol-3-yl)ethyl)acetamide) or (3-(2-acetamidoethyl)-5-methoxyindole) or (N-(2-(5-Methyxyindol-3-yl)ethyl)acetamide)) and ((sleep*) or (sleep disorder*) or (dyssomnia*) or (insomnia*) or (narcoleps*) or (hypersomnia*) or (central alveolar hypoventilat*) or (periodic limb movement*) or (nocturnal eating) or (nocturnal drinking) or (time-zone*) or (time zone*) or (jet lag*) or (parasomnia*) or (confusional arousal*) or (rhythmic movement disorder*) or (nocturnal leg cramp*) or (nightmare*) or (nocturnal paroxysmal dystonia*) or (sudden unexplained nocturnal death syndrome*) or (SUNDS) or (snoring) or (snore*) or (congential central hypoventilat*) or (sudden infant death syndrome*) or (SIDS) or (subwakefulness) or (fragmentary mycoclonus) or (hypnagogic hallucination*) or (arous*) or (circadian)))

International Pharmaceutical Abstracts

1970 to August, 2003

This database was searched using the same strategy as for MEDLINE.

PreMEDLINE

Search performed June 30 and July 4, 2003

This database was searched using the same strategy as for MEDLINE.

NLM Gateway

Search performed August 13, 2003

Searched for books and conference proceedings using ‘melatonin*’ and ‘sleep’

OCLC Papers First and Proceedings First

Search performed July 11, 2003

Searched for conference proceedings using ‘melatonin*’ and ‘sleep’

TOXLINE

Keyword Search

Search performed July 4, 2003

(((((melatonin*) OR (73-31-4) OR (5-Methoxy-N-acetyltryptamine) OR (luzindole) OR (N-Acetyle-5-methyxoytryptamine)) AND (circadian*) AND ((randomized controlled trial*) or (controlled clinical trial*) or (random allocation) or (randomly allocated) or (single blind*) or (double blind*) or (clinical trial*) or (placebo*) or (research design*) or (comparative stud*) or (random*) or (evaluation stud*) or (follow up stud*) or (prospective stud*) or (cohort*) or (case series) or (meta analys*) or (metaanalys*) or (review*) or (overview*) or (quantitative synthes*) or (HTA) or (health technology assessment) or (biomedical technology assessment)))) NOT ((((melatonin*) OR (73-31-4) OR (5-Methoxy-N-acetyltryptamine) OR (luzindole) OR (N-Acetyle-5-methyxoytryptamine)) AND ((sleep*) OR (sleep disorder*) OR (dyssomnia*) OR (insomnia*) OR (narcoleps*) OR (hypersomnia*) OR (central alveolar hypoventilat*) OR (periodic limb movement*) OR (nocturnal eating) OR (nocturnal drinking) OR (time-zone*) OR (time zone*) OR (jet lag*) OR (parasomnia*) OR (confusional arousal*) OR (rhythmic movement disorder*) OR (nocturnal leg cramp*) OR (nightmare*) OR (nocturnal paroxysmal dystonia*) OR (sudden unexplained nocturnal death syndrome*) OR (SUNDS) OR (snoring) OR (snore*) OR (congential central hypoventilat*) OR (sudden infant death syndrome*) OR (SIDS) OR (subwakefulness) OR (fragmentary mycoclonus) OR (hypnagogic hallucination*) OR (arous*)) AND ((randomized controlled trial*) or (controlled clinical trial*) or (random allocation) or (randomly allocated) or (single blind*) or (double blind*) or (clinical trial*) or (placebo*) or (research design*) or (comparative stud*) or (random*) or (evaluation stud*) or (follow up stud*) or (prospective stud*) or (cohort*) or (case series) or (meta analys*) or (metaanalys*) or (review*) or (overview*) or (quantitative synthes*) or (HTA) or (health technology assessment) or (biomedical technology assessment)))))

Hand-searched Associated Professional Sleep Society abstracts

1999-2003