# Bibliography

Anonymous. Weapon-carrying among high school students--United States, 1990. MMWR Morb Mortal Wkly Rep 1991;40(40):681–4.
Anonymous. From the Centers for Disease Control. Physical fighting among high school students--United States, 1990. JAMA 1992;267(22):3009–10.
Anonymous. Physical fighting among high school students--United States, 1990. MMWR Morb Mortal Wkly Rep 1992;41(6):91–4.
Anonymous. Domestic violence. Am J Public Health 1993;83(3):458–63.
Anonymous. From the Centers for Disease Control and Prevention. Violence-related attitudes and behaviors of high school students--New York City, 1992. JAMA 1993;270(17):2032–3.
Anonymous. Adolescent homicide--Fulton County, Georgia, 1988-1992. MMWR Morb Mortal Wkly Rep 1994;43(40):728–30.
Anonymous. From the Centers for Disease Control and Prevention. Homicides among 15–19-year-old males--United States, 1963-1991. JAMA 1994;272(20):1572.
Anonymous. The role of the pediatrician in violence prevention. Proceedings of a conference. Chantilly, Virginia, March 4–5, 1994. Pediatrics 1994;94(4 Pt 2):576–651.
Anonymous. Sexual assault and the adolescent. American Academy of Pediatrics Committee on Adolescence. Pediatrics 1994;94(5):761–5.
Anonymous. Media violence. American Academy of Pediatrics Committee on Communications. Pediatrics 1995;95(6):949–51.
Anonymous. Defusing gang activity: different hospitals take different approaches. Hosp Secur Saf Manage 1999;19(11):1–4.
Anonymous. Firearm-associated deaths and hospitalizations--California, 1995-1996. MMWR Morb Mortal Wkly Rep 1999;48(23):485–8.
Anonymous. The WHO cross-national study on health behavior in school-aged children from 28 countries: findings from the United States. J Sch Health 2000;70(6):227–8.
Anonymous. JAMA patient page. Bullying. JAMA 2001;285(16):2156.
Anonymous. Children, youth and gun violence. Selected bibliography. Future Child 2002;12(2):Inside Back Cover.
Aber J, Lawrence, Brown J L, Jones S M. Developmental trajectories toward violence in middle childhood: course, demographic differences, and response to school-based intervention. Dev Psychol. 2003;39(2):324-48. [pmid: 12661889].
Aber J L, Brown J L, Chaudry N, et al. The evaluation of the resolving conflict creatively program: an overview. Am J Prev Med. 1996;12(5 Suppl):82-90. [pmid: 8909628].
Aber J L, Brown J L, Jones S M. Developmental trajectories toward violence in middle childhood: Course, demographic differences, and response to school-based intervention. Dev Psychol. 2003;39(2):324-48. [pmid: 12661889].
Aber J L, Jones S M, Brown J L, et al. Resolving conflict creatively: Evaluating the developmental effects of a school-based violence prevention program in neighborhood and classroom context. Dev Psychopathol. 1998;10(2):187-213. [pmid: 9635221].
Abram K M, Teplin L A. Drug disorder, mental illness, and violence. NIDA Res Monogr. 1990;103:222-38. [pmid: 2096289].
Achenbach T M, Howell C T, McConaughy S H, et al. Six-year predictors of problems in a national sample: III. Transitions to young adult syndromes. J Am Acad Child Adolesc Psychiatry. 1995;34(5):658-69. [pmid: 7775361].
Acton P A, Farley T, Freni L W, et al. Traumatic spinal cord injury in Arkansas, 1980 to 1989. Arch Phys Med Rehabil. 1993;74(10):1035-40. [pmid: 8215853].
Adams D, Allen D. Assessing the need for reactive behaviour management strategies in children with intellectual disability and severe challenging behaviour. J Intellect Disabil Res. 2001;45(4):335-43. [pmid: 11489055].
Adams J, McClellan J, Douglass D, et al. Sexually inappropriate behaviors in seriously mentally ill children and adolescents. Child Abuse Negl. 1995;19(5):555-68. [pmid: 7664136].
Adams PF, Schoenborn CA, Moss AJ, et al. Health-risk behaviors among our nation's youth: United States, 1992. Vital Health Stat 10 1995(192):1–51.
Adams P L, Arnow J. Children in violence. J Am Acad Psychoanal. 1996;24(1):179-86. [pmid: 8906719].
Adler N A, Schutz J. Sibling incest offenders. Child Abuse Negl. 1995;19(7):811-9. [pmid: 7583737].
Administration for Children and Families. Toward a blueprint for youth. Accessed: May 2004. http://www.acf.hhs.gov/programs/fysb/youthinfo/blueprint2.htm.
af Klinteberg B. Biology, norms, and personality: a developmental perspective. Neuropsychobiology. 1996;34(3):146-54. [pmid: 8916072].
af Klinteberg B, Andersson T, Magnusson D, et al. Hyperactive behavior in childhood as related to subsequent alcohol problems and violent offending: A longitudinal study of male subjects. Pers Individ Dif. 1993;15(4):381-8.
Agnew R. The techniques of neutralization and violence. Criminology. 1994;32:555-80.
Ahmed M B. High-risk adolescents and satanic cults. Tex Med. 1991;87(10):74-6. [pmid: 1962303].
Akhtar N, Bradley E J. Social information processing deficits of aggressive children: Present findings and implications for social skills training. Clin Psychol Rev. 1991;11(5):621-44.
Alaniz M L, Cartmill R S, Parker R N. Immigrants and violence: The importance of neighborhood context. Hisp J Behav Sci. 1998;20(2):155-74.
Alexander B. Violence: a public health problem. Am Fam Physician. 1992;46(1):67-8. [pmid: 1621642].
Allen J S, Rupert V, Spatafora K, et al. Differentiating violent from nonviolent female offenders using the Jesness Inventory. Pers Individ Dif. 2003;35(1):101-8.
Altemeier W A. Is the media friend or foe to our children?. Pediatr Ann. 1995;24(2):68-9. [pmid: 8747703].
Aluja-Fabregat A, Torrubia-Beltri R. Viewing of mass media violence, perception of violence, personality and academic achievement. Pers Individ Dif. 1998;25(5):973-89.
Alvarez A. Trends and patterns of justifiable homicide: a comparative analysis. Violence Vict. 1992;7(4):347-56. [pmid: 1308440].
Amen D G, Stubblefield M, Carmicheal B, et al. Brain SPECT findings and aggressiveness. Ann Clin Psychiatry. 1996;8(3):129-37. [pmid: 8899131].
Amodei N, Elkin B B, Burge S K, et al. Psychiatric problems experienced by primary care patients who misuse alcohol. Int J Addict. 1994;29(5):609-26. [pmid: 8034375].
Andershed H, Kerr M, Stattin H. Bullying in school and violence on the streets: Are the same people involved?. J Scand Stud Crim Crime Prev. 2001;2(1):31-49.
Andershed H A, Gustafson S B, Kerr M, et al. The usefulness of self-reported psychopathy-like traits in the study of antisocial behaviour among non-referred adolescents. Eur J Personal. 2002;16(5):383-402.
Anderson C A, Bushman B J, Groom R W. Hot years and serious and deadly assault: empirical tests of the heat hypothesis. J Pers Soc Psychol. 1997;73(6):1213-23. [pmid: 9418277].
Anderson N L, Roper J M. The interactional dynamics of violence, Part II: Juvenile detention. Arch Psychiatr Nurs. 1991;5(4):216-22. [pmid: 1953046].
Anderson N L, Roper J M. The interactional dynamics of violence: II. Juvenile detention. Arch Psychiatr Nurs. 1991;5(4):216-22. [pmid: 1953046].
Andre C, Jaber-Filho J A, Carvalho M, et al. Predictors of recovery following involuntary hospitalization of violent substance abuse patients. Am J Addict. 2003;12(1):84-9. [pmid: 12623743].
Andrews J A, Foster S L, Capaldi D, et al. Adolescent and family predictors of physical aggression, communication, and satisfaction in young adult couples: a prospective analysis. J Consult Clin Psychol. 2000;68(2):195-208. [pmid: 10780119].
Andrews T K, Rose F D, Johnson D A. Social and behavioural effects of traumatic brain injury in children. Brain Inj. 1998;12(2):133-8. [pmid: 9492960].
Ansevics N L, Doweiko H E. Serial murderers: Early proposed developmental model and typology. Psychother Priv Pract. 1991;9(2):107-22.
Archwamety T, Katsiyannis A. Factors related to recidivism among delinquent females at a state correctional facility. J Child Fam Stud. 1998;7(1):59-67.
Arluke A, Levin J, Luke C, et al. The relationship of animal abuse to violence and other forms of antisocial behavior. J Interpers Violence. 1999;14(9):963-75.
Armenteros J L, Lewis J E. Citalopram treatment for impulsive aggression in children and adolescents: An open pilot study. J Am Acad Child Adolesc Psychiatry. 2002;41(5):522-9. [pmid: 12014784].
Arria A, Borges G, Anthony J C. Fears and other suspected risk factors for carrying lethal weapons among urban youths of middle-school age. Arch Pediatr Adolesc Med. 1997;151(6):555-60. [pmid: 9193237].
Arria A M, Wood N P, Anthony J C. Prevalence of carrying a weapon and related behaviors in urban schoolchildren, 1989 to 1993. Arch Pediatr Adolesc Med. 1995;149(12):1345-50. [pmid: 7489072].
Artz S. Where have all the school girls gone? Violent girls in the school yard. Child Youth Care Forum. 1998;27(2):77-109.
Ash P, Kellermann A L, Fuqua-Whitley D, et al. Gun acquisition and use by juvenile offenders. JAMA. 1996;275(22):1754-8. [pmid: 8637174].
Askenazy F, Caci H, Myquel M, et al. Relationship between impulsivity and platelet serotonin content in adolescents. Psychiatry Res. 2000;94(1):19-28. [pmid: 10788674].
Askenazy F L, Sorci K, Benoit M, et al. Anxiety and impulsivity levels identify relevant subtypes in adolescents with at-risk behavior. J Affect Disord. 2003;74(3):219-27. [pmid: 12738040].
Asnis G M, Kaplan M L, van Praag H M, et al. Homicidal behaviors among psychiatric outpatients. Hosp Community Psychiatry. 1994;45(2):127-32. [pmid: 8168790].
Assaad J-M, Pihl R O, Seguin J R, et al. Aggressiveness, family history of alcoholism, and the heart rate response to alcohol intoxication. Exp Clin Psychopharmacol. 2003;11(2):158-66. [pmid: 12755460].
Astor R A, Behre W J. Violent and nonviolent children's and parents' reasoning about family and peer violence. Behav Disord. 1997;22(4):231-45.
Astor R A, Meyer H A, Behre W J. Unowned places and times: Maps and interviews about violence in high schools. Am Educ Res J. 1999;36(1):3-42.
Atkin C K, Smith S W, Roberto A J, et al. Correlates of verbally aggressive communication in adolescents. J Appl Commun Res. 2002;30(3):251-68.
Atlas R S, Pepler D J. Observations of bullying in the classroom. J Educ Res. 1998;92(2):86-99.
Attar B K, Guerra N G, Tolan P H. Neighborhood disadvantage, stressful life events, and adjustment in urban elementary-school children. J Clin Child Psychol. 1994;23(4):391-400.
Auffrey C, Fritz J M, Lin B, et al. Exploring differences between violent and nonviolent juvenile offenders using juvenile corrections facility client records. J Educ Psychol Consult. 1999;10(2):129-43.
August G J, Hektner J M, Egan E A, et al. The early risers longitudinal prevention trial: Examination of 3-year outcomes in aggressive children with intent-to treat and as-intended analyses. Psychol Addict Behav. 2002;16(Suppl4):S27-S39. [pmid: 12502275].
August G J, Realmuto G M, Hektner J M, et al. An integrated components preventive intervention for aggressive elementary school children: The Early Risers program. J Consult Clin Psychol. 2001;69(4):614-26. [pmid: 11550728].
Avakame E F. Intergenerational transmission of violence, self-control, and conjugal violence: a comparative analysis of physical violence and psychological aggression. Violence Vict. 1998;13(3):301-16. [pmid: 9836416].
Awad G A, Saunders E B. Male adolescent sexual assaulters: Clinical observations. J Interpers Violence. 1991;6(4):446-60.
Ayers S. The truth about underage drinking. J La State Med Soc. 2001;153(7):332-4. [pmid: 11519212].
Aylwin A S, Clelland S R, Kirkby L, et al. Sexual offense severity and victim gender preference: A comparison of adolescent and adult sex offenders. Int J Law Psychiatry. 2000;23(2):113-24. [pmid: 10813112].
Azrael D, Hemenway D. ‘In the safety of your own home’: results from a national survey on gun use at home. Soc Sci Med. 2000;50(2):285-91. [pmid: 10619696].
Baba Y. Vietnamese gangs, cliques and delinquents. J Gang Res. 2001;8(2):1-20.
Bachman R, Peralta R. The relationship between drinking and violence in an adolescent population: Does gender matter?. Deviant Behav. 2002;23(1):1-19.
Bagley C, Pritchard C. The reduction of problem behaviours and school exclusion in at-risk youth: An experimental study of school social work with cost-benefit analyses. Child Fam Soc Work. 1998;3(4):219-26.
Bagley C, Shewchuk-Dann D. Characteristics of 60 children and adolescents who have a history of sexual assault against others: Evidence from a controlled study. J Child Youth Care 1991:43–52.
Bailey S L, Flewelling R L, Rosenbaum D P. Characteristics of students who bring weapons to school. J Adolesc Health. 1997;20(4):261-70. [pmid: 9098729].
Bailey S M, Thornton L, Weaver A B. The first 100 admissions to an adolescent secure unit. J Adolesc. 1994;17(3):207-20.
Baker A J, Tabacoff R, Tornusciolo G, et al. Calculating number of offenses and victims of juvenile sexual offending: the role of posttreatment disclosures. Sex Abuse. 2001;13(2):79-90. [pmid: 11294126].
Baker K, Pollack M, Kohn I. Violence prevention through informal socialization: An evaluation of the South Baltimore Youth Center. Stud Crime Crime Prev. 1995;4(1):61-85.
Baker W, Bramston P. Attributional and emotional determinants of aggression in people with mild intellectual disabilities. J Intellect Dev Disabil. 1997;22(3):169-85.
Baldwin K. MSMS alliance focuses on violence prevention. Mich Med. 2001;100(4):53. [pmid: 11478086].
Bank L, Duncan T, Patterson G R, et al. Parent and teacher ratings in the assessment and prediction of antisocial and delinquent behaviors. J Pers. 1993;61(4):693-709. [pmid: 8151504].
Barkin S, Kreiter S, DuRant R H. Exposure to violence and intentions to engage in moralistic violence during early adolescence. J Adolesc. 2001;24(6):777-89. [pmid: 11790057].
Barnes A, Ephross P H. The impact of hate violence on victims: emotional and behavioral responses to attacks. Soc Work. 1994;39(3):247-51. [pmid: 8209286].
Barnow S, Schuckit M, Smith T L, et al. The real relationship between the family density of alcoholism and externalizing symptoms among 146 children. Alcohol Alcohol. 2002;37(4):383-7. [pmid: 12107042].
Baron S W. Risky lifestyles and the link between offending and victimization. Stud Crime Crime Prev. 1997;6(1):53-71.
Baron S W, Hartnagel T F. Street youth and criminal violence. J Res Crime Delinq. 1998;35(2):166-92.
Baron S W, Hartnagel T F. Street youth and labor market strain. J Crim Justice. 2002;30(6):519-33.
Barrios L C. Preventing school violence: a time for hard, solid thinking. Inj Prev. 2000;6(3):165-6. [pmid: 11003177].
Barry C T, Frick P J, Killian A L. The relation of narcissism and self-esteem to conduct problems in children: A preliminary investigation. J Clin Child Adolesc Psychol. 2003;32(1):139-52. [pmid: 12573939].
Barry D S. Screen violence and America's children. Spectrum. 1993;66:37-42.
Bars D R, Heyrend F L, Simpson C D, et al. Use of visual evoked-potential studies and EEG data to classify aggressive, explosive behavior of youths. Psychiatr Serv. 2001;52(1):81-6. [pmid: 11141533].
Barstow D G. An offender-friendly society. J Psychosoc Nurs Ment Health Serv. 1994;32(8):56. [pmid: 7965956].
Barylnik J. Psychopathology, psychosocial characteristics and family environment in juvenile delinquents. Ger J Psychol. 2003;6(2):30-2.
Beaudoin M N, Hodgins S, Lavoie F. Homicide, schizophrenia and substance abuse or dependency. Can J Psychiatry. 1993;38(8):541-6. [pmid: 8242528].
Beauford J E, McNiel D E, Binder R L. Utility of the initial therapeutic alliance in evaluating psychiatric patients' risk of violence. Am J Psychiatry. 1997;154(9):1272-6. [pmid: 9286188].
Beauvais F, Chavez E L, Oetting E R, et al. Drug use, violence, and victimization among White American, Mexican American, and American Indian dropouts, students with academic problems, and students in good academic standing. J Couns Psychol. 1996;43(3):292-9.
Becker D F, Edell W S, Fujioka T A. Attentional and intellectual deficits in unmedicated behavior-disordered adolescent inpatients. J Youth Adolesc. 1996;25:127-35.
Becker D F, Edell W S, Fujioka T A, et al. Attentional and intellectual deficits in unmedicated behavior-disordered adolescent inpatients. J Youth Adolesc. 1996;25(1):127-35.
Becker K B, McCloskey L A. Attention and conduct problems in children exposed to family violence. Am J Orthopsychiatry. 2002;72(1):83-91. [pmid: 14964597].
Beer J, Beer J. Aggression of youth as related to parental divorce and eye color. Percept Mot Skills. 1992;75(3 Pt 2):1066. [pmid: 1484766].
Beier S R, Rosenfeld W D, Spitalny K C, et al. The potential role of an adult mentor in influencing high-risk behaviors in adolescents. Arch Pediatr Adolesc Med. 2000;154(4):327-31. [pmid: 10768667].
Bell CC, Jenkins EJ. Traumatic stress and children. J Health Care Poor Underserved 1991;2(1):175–85; Discussion 86–8.
Bell C C, Jenkins E J. Community violence and children on Chicago's southside. Psychiatry. 1993;56(1):46-54. [pmid: 8488212].
Bell K. Female offenders of sexual assault. J Emerg Nurs. 1999;25(3):241-3. [pmid: 10346851].
Bellair P E, Roscigno V J. Local labor-market opportunity and adolescent delinquency. Soc Forces. 2000;78(4):1509-38.
Bellair P E, Roscigno V J, McNulty T L. Linking local labor market opportunity to violent adolescent delinquency. J Res Crime Delinq. 2003;40(1):6-33.
Bellair P E, Roscigno V J, McNulty T L. Linking local labor market opportunity to violent adolescent delinquency. J Res Crime Delinq. 2003;40(1):6-33.
Benda B B, Corwyn R F. The effect of abuse in childhood and in adolescence on violence among adolescents. Youth Soc. 2002;33(3):339-65.
Benda B B, Corwyn R F, Rodell D E. Alcohol and violence among youth in boot camps for non-violent offenders. Alcohol Treat Q. 2001;19(1):37-55.
Benda B B, Turney H M. Youthful violence: Problems and prospects. Child Adolesc Social Work J. 2002;19(1):5-34.
Bender D, Loesel F. Protective and risk effects of peer relations and social support on antisocial behaviour in adolescents from multi-problem milieus. J Adolesc. 1997;20(6):661-78. [pmid: 9417798].
Bennett L. Growing up with violence. Can Nurse. 1993;89(7):33-6. [pmid: 8348520].
Bennett L, Fineran S. Sexual and severe physical violence among high school students. Power beliefs, gender, and relationship. Am J Orthopsychiatry. 1998;68(4):645-52. [pmid: 9809124].
Bennett L W, Tolman R M, Rogalski C J, et al. Domestic abuse by male alcohol and drug addicts. Violence Vict. 1994;9(4):359-68. [pmid: 7577762].
Benoit J L, Kennedy W A. The abuse history of male adolescent sex offenders. J Interpers Violence. 1992;7(4):543-48.
Benoit M. Impact of violence on children and adolescents: Report from a community-based child psychiatry clinic. Psychiatry Interpers Biol Process. 1993;56(1):124-6.
Bentovim A. Trauma-organized systems in practice: Implications for work with abused and abusing children and young people. Clin Child Psychol Psychiatry. 1996;1(4):513-24.
Berenbaum S A, Resnick S M. Early androgen effects on aggression in children and adults with congenital adrenal hyperplasia. Psychoneuroendocrinology. 1997;22(7):505-15. [pmid: 9373884].
Bergeret J. Adolescence: the crossroads of violence. J Adolesc Health. 1992;13(5):418-9. [pmid: 1390802].
Bergman L. Dating violence among high school students. Soc Work. 1992;37(1):21-7.
Berman L H. The effects of living with violence. J Am Acad Psychoanal. 1992;20(4):671-5. [pmid: 1291552].
Bernstein D P, Stein J A, Handelsman L. Predicting personality pathology among adult patients with substance use disorders: effects of childhood maltreatment. Addictive Behaviors Addict Behav. 1998;23(6):855-68.
Berthhold K A, Hoover J H. Correlates of bullying and victimization among intermediate students in the Midwestern USA. Sch Psychol Int. 2000;21(1):65-78.
Beyers J M, Loeber R, Wikstrom P O, et al. What predicts adolescent violence in better-off neighborhoods?. J Abnorm Child Psychol. 2001;29(5):369-81. [pmid: 11695540].
Bickett L R, Milich R, Brown R T. Attributional styles of aggressive boys and their mothers. J Abnorm Child Psychol. 1996;24(4):457-72. [pmid: 8886942].
Bierman K L, Smoot D L, Aumiller K. Characteristics of aggressive-rejected, aggressive (nonrejected), and rejected (nonaggressive) boys. Child Dev. 1993;64(1):139-51. [pmid: 8436026].
Bihm E M, Poindexter A R, Warren E R. Aggression and psychopathology in persons with severe or profound mental retardation. Res Dev Disabil. 1998;19(5):423-38. [pmid: 9770254].
Billingham R E, Bland R, Leary A. Dating violence at three time periods: 1976, 1992, and 1996. Psychol Rep. 1999;85(2):574-8. [pmid: 10611789].
Billingham R E, Gilbert K R. Parental divorce during childhood and use of violence in dating relationships. Psychol Rep. 1990;66(3 Pt 1):1003-9. [pmid: 2377682].
Bincer W L. The tragedy of gun violence. Wis Med J. 1994;93(10):508-9. [pmid: 7810157].
Birmaher B, Stanley M, Greenhill L, et al. Platelet imipramine binding in children and adolescents with impulsive behavior. J Am Acad Child Adolesc Psychiatry. 1990;29(6):914-8. [pmid: 2177056].
Birnbaum A S, Lytle L A, Hannan P J, et al. School functioning and violent behavior among young adolescents: a contextual analysis. Health Educ Res. 2003;18(3):389-403. [pmid: 12828239].
Bischof G P, Stith S M, Whitney M L. Family environments of adolescent sex offenders and other juvenile delinquents. Adolescence. 1995;30(117):157-70. [pmid: 7625251].
Bischof G P, Stith S M, Wilson S M. A comparison of the family systems of adolescent sexual offenders and nonsexual offending delinquents. Fam Relat. 1992;41(3):318-23.
Bjoerkqvist K, Lagerspetz K M, Kaukiainen A. Do girls manipulate and boys fight? Developmental trends in regard to direct and indirect aggression. Aggress Behav. 1992;18(2):117-27.
Bjorkly S. SCL-90-R profiles in a sample of severely violent psychiatric inpatients. Aggress Behav. 2002;28(6):446-57.
Black M M, Ricardo I B. Drug use, drug trafficking, and weapon carrying among low-income, African-American, early adolescent boys. Pediatrics. 1994;93(6 Pt 2):1065-72. [pmid: 8197009].
Blake P Y, Pincus J H, Buckner C. Neurologic abnormalities in murderers. Neurology. 1995;45(9):1641-7. [pmid: 7675220].
Blum J, Ireland M, Blum R W. Gender differences in juvenile violence: A report from Add Health. J Adolesc Health. 2003;32(3):234-40. [pmid: 12606117].
Blum J, Ireland M, Blum R W. Gender differences in juvenile violence: A report from Add Health. J Adolesc Health. 2003;32(3):234-40. [pmid: 12606117].
Blum R W, Beuhring T, Shew M L, et al. The effects of race/ethnicity, income, and family structure on adolescent risk behaviors. Am J Public Health. 2000;90(12):1879-84. [pmid: 11111260]. [pmcid: 1446419].
Blumensohn R, Ratzoni G, Weizman A, et al. Reduction in serotonin 5HT-sub-2 receptor binding on platelets of delinquent adolescents. Psychopharmacology (Berl). 1995;118(3):354-6. [pmid: 7617829].
Blumensohn R, Ratzoni G, Weizman A, et al. Reduction in serotonin 5HT2 receptor binding on platelets of delinquent adolescents. Psychopharmacology (Berl). 1995;118(3):354-6. [pmid: 7617829].
Blumenthal S, Gudjonsson G, Burns J. Cognitive distortions and blame attribution in sex offenders against adults and children. Child Abuse Negl. 1999;23(2):129-43. [pmid: 10075183].
Blumstein A. Youth violence, guns and the illicit-drug industry. J Crim Law Criminol. 1995;86(1):10-36.
Bock G, Goode J. Genetics of criminal and antisocial behaviour. New York: Wiley; 1996.
Bodtker A. Conflict education and special-needs students, part two: Improving conflict competence and emotional competence. Mediat Q. 2001;18(4):377-95.
Bolger K E, Patterson C J. Developmental pathways from child maltreatment to peer rejection. Child Dev. 2001;72(2):549-68. [pmid: 11333084].
Bolland J M. Hopelessness and risk behaviour among adolescents living in high-poverty inner-city neighbourhoods. J Adolesc. 2003;26(2):145-58. [pmid: 12581723].
Bolland J M. Hopelessness and risk behaviour among adolescents living in high-poverty inner-city neighbourhoods. J Adolesc. 2003;26(2):145-58. [pmid: 12581723].
Bolland J M, McCallum D M, Lian B, et al. Hopelessness and violence among inner-city youths. Matern Child Health J. 2001;5(4):237-44. [pmid: 11822525].
Bond A J, Surguy S M. Relationship between attitudinal hostility and P300 latencies. Progr Neuro-Psychopharmacol Biol Psychiatr. 2000;24(8):1277-88.
Booker A L, Hoffschmidt S J, Ash E. Personality features and characteristics of violent events committed by juvenile offenders. Behav Sci Law. 2001;19(1):81-96. [pmid: 11241682].
Boone S L. Aggression in African-American boys: A discriminant analysis. Genet Soc Gen Psychol Monogr. 1991;117(2):203-28. [pmid: 1860670].
Booth R E, Zhang Y. Severe aggression and related conduct problems among runaway and homeless adolescents. Psychiatr Serv. 1996;47(1):75-80. [pmid: 8925350].
Borduin C M, Mann B J, Cone L T, et al. Multisystemic treatment of serious juvenile offenders: long-term prevention of criminality and violence. J Consult Clin Psychol. 1995;63(4):569-78. [pmid: 7673534].
Borgatti JC. Crisis at Columbine: a lesson learned? Nurs Spectr (N Engl Ed) 1999;9(11):6–7, 32.
Borowsky I W, Ireland M, Resnick M D, et al. Violence risk and protective factors among youth held back in school. Ambul Pediatr. 2002;2(6):475-84. [pmid: 12437395].
Boruch R F, Coleman D, Doria-Ortiz C, et al. Violence prevention strategies targeted at the general population of minority youth. Public Health Rep. 1991;106(3):247-50. [pmid: 1905036].
Borzekowski D L, Poussaint A F. Common themes from the extremes: using two methodologies to examine adolescents' perceptions of anti-violence public service announcements. J Adolesc Health. 2000;26(3):164-75. [pmid: 10706164].
Bosch X. Firearm-related homicides among teenagers and young adults. JAMA. 1999;281(4):324. [pmid: 10493190].
Bosworth K, Espelage D, DuBay T. A computer-based violence prevention intervention for young adolescents: pilot study. Adolescence. 1998;33(132):785-95. [pmid: 9886006].
Bosworth K, Espelage D, DuBay T, et al. Using multimedia to teach conflict-resolution skills to young adolescents. Am J Prev Med. 1996;12(5 Suppl):65-74. [pmid: 8909626].
Bosworth K, Espelage D, DuBay T, et al. Preliminary evaluation of a multimedia violence prevention program for adolescents. Am J Health Behav. 2000;24(4):268-80.
Bosworth K, Espelage D L, Simon T R. Factors associated with bullying behavior in middle school students. J Early Adolesc. 1999;19(3):341-62.
Boulton M J. A comparison of structural and contextual features of middle school children's playful and aggressive fighting. Ethol Sociobiol. 1991;12(2):119-45.
Boulton M J, Flemington I. The effects of a short video intervention on secondary school pupils' involvement in definitions of and attitudes towards bullying. Sch Psychol Int. 1996;17(4):331-45.
Boulton M J, Underwood K. Bully/victim problems among middle school children. Br J Educ Psychol. 1992;62(Pt 1):73-87. [pmid: 1558813].
Bowen N K, Flora D B. When is it appropriate to focus on protection in interventions for adolescents?. Am J Orthopsychiatry. 2002;72(4):526-38. [pmid: 15792038].
Bowers L, Smith P K, Binney V. Perceived family relationships of bullies, victims and bully/victims in middle childhood. J Soc Pers Relatsh. 1994;11(2):215-32.
Bownes I T, O'Gorman E C, Sayers A. Rape--a comparison of stranger and acquaintance assaults. Med Sci Law. 1991;31(2):102-9. [pmid: 2062190].
Boyatzis C J, Matillo G M, Nesbitt K M. Effects of the “Mighty Morphin Power Rangers” on children's aggression with peers. Child Study J. 1995;25(1):45-55.
Brady E C, Chrisler J C, Hosdale D C, et al. Date rape: expectations, avoidance strategies, and attitudes toward victims. J Soc Psychol. 1991;131(3):427-9. [pmid: 1875681].
Braga A A. Serious youth gun offenders and the epidemic of youth violence in Boston. J Quant Criminol. 2003;19(1):33-54.
Braga A A, Kennedy D M, Waring E J, et al. Problem-oriented policing, deterrence, and youth violence: An evaluation of Boston's Operation Ceasefire. J Res Crime Delinq. 2001;38(3):195-225.
Brame R, Mulvey E P, Piquero A R. On the development of different kinds of criminal activity. Sociol Methods Res. 2001;29(3):319-41.
Brannon J M, Troyer R. Peer group counseling: A normalized residential alternative to the specialized treatment of adolescent sex offenders. Int J Offender Ther Comp Criminol. 1991;35(3):225-34.
Brecklin L R. The role of perpetrator alcohol use in the injury outcomes of intimate assaults. J Fam Violence. 2002;17(3):185-97.
Bremer J F. Serious juvenile sex offenders: Treatment and long-term follow-up. Psychiatr Ann. 1992;22(6):326-32.
Brendgen M, Vitaro F, Tremblay R E, et al. Parent and peer effects on delinquency-related violence and dating violence: A test of two mediational models. Soc Dev. 2002;11(2):225-44.
Brendgen M, Vitaro R, Tremblay R E, et al. Reactive and proactive aggression: predictions to physical violence in different contexts and moderating effects of parental monitoring and caregiving behavior. J Abnorm Child Psychol. 2001;29(4):293-304. [pmid: 11523835].
Brener N D, Krug E G, Dahlberg L L, et al. Nurses' logs as an evaluation tool for school-based violence prevention programs. J Sch Health. 1997;67(5):171-4. [pmid: 9210101].
Brener N D, Simon T R, Krug E G, et al. Recent trends in violence-related behaviors among high school students in the United States. JAMA. 1999;282(5):440-6. [pmid: 10442659].
Brener N D, Wilson T W. Substance use on school property among students attending alternative high schools in the United States. J Drug Educ. 2001;31(4):329-42. [pmid: 11957389].
Brennan P A, Grekin E R, Mednick S A. Maternal smoking during pregnancy and adult male criminal outcomes. Arch Gen Psychiatry. 1999;56(3):215-9. [pmid: 10078497].
Breslow R E, Klinger B I, Erickson B J. The disruptive behavior disorders in the psychiatric emergency service. Gen Hosp Psychiatry. 1999;21(3):214-9. [pmid: 10378115].
Bretherton D, Collins L, Ferretti C. Dealing with conflict: Assessment of a course for secondary school students. Aust Psychol. 1993;28(2):105-11.
Breunlin D C, Bryant-Edwards T L, Hetherington J S, et al. Conflict resolution training as an alternative to suspension for violent behavior. J Educ Res. 2002;95(6):349-57.
Brezina T. Teenage violence toward parents as an adaptation to family strain: Evidence from a national survey of male adolescents. Youth Soc. 1999;30(4):416-44.
Brezina T, Piquero A R, Mazerolle. Student anger and aggressive behavior in school: An initial test of Agnew's macro-level strain theory. J Res Crime Delinq. 2001;38(4):362-86.
Briere J, Elliott D. Prevalence, characteristics, and long-term sequelae of natural disaster exposure in the general population. J Trauma Stress. 2000;13(4):661-79. [pmid: 11109238].
Briggs S, MacKay T, Miller S. The Edinbarnet Playground Project: Changing aggressive behavior through structured intervention. AEP J. 1995;11(2):37-44.
Briscoe J. Breaking the cycle of violence: A rational approach to at-risk youth. Fed Probat. 1997;61(3):3-13.
Brockenbrough K K, Cornell D G, Loper A B. Aggressive attitudes among victims of violence at school. Educ Treat Child. 2002;25(3):273-87.
Brody S L. Violence associated with acute cocaine use in patients admitted to a medical emergency department. NIDA Res Monogr. 1990;103:44-59. [pmid: 2096292].
Broidy L M, Nagin D S, Tremblay R E, et al. Developmental trajectories of childhood disruptive behaviors and adolescent delinquency: A six-site, cross-national study. Dev Psychol. 2003;39(2):222-45. [pmid: 12661883].
Broidy L M, Nagin D S, Tremblay R E, et al. Developmental trajectories of childhood disruptive behaviors and adolescent delinquency: a six-site, cross-national study. Dev Psychol. 2003;39(2):222-45. [pmid: 12661883].
Brondolo E, Baruch C, Conway E, et al. Aggression among inner-city minority youth: A biopsychosocial model for school-based evaluation and treatment. J Soc Distress Homeless. 1994;3(1):53-80.
Brooke M M, Questad K A, Patterson D R, et al. Agitation and restlessness after closed head injury: a prospective study of 100 consecutive admissions. Arch Phys Med Rehabil. 1992;73(4):320-3. [pmid: 1417466].
Brookoff D, O'Brien K K, Cook C S, et al. Characteristics of participants in domestic violence. Assessment at the scene of domestic assault. JAMA. 1997;277(17):1369-73. [pmid: 9134942].
Brooks J H, Reddon J R. Serum testosterone in violent and nonviolent young offenders. J Clin Psychol. 1996;52(4):475-83. [pmid: 8842886].
Brown T L, Henggeler S W, Brondino M J, et al. Trauma exposure, protective factors and mental health functioning of substance-abusing and dependent juvenile offenders. J Emot Behav Disord. 1999;7(2):94-102.
Buitelaar J K. Open-label treatment with risperidone of 26 psychiatrically-hospitalized children and adolescents with mixed diagnoses and aggressive behavior. J Child Adolesc Psychopharmacol. 2000;10(1):19-26. [pmid: 10755578].
Buitelaar J K, van der Gaag R J, Cohen-Kettenis P, et al. A randomized controlled trial of risperidone in the treatment of aggression in hospitalized adolescents with subaverage cognitive abilities. J Clin Psychiatry. 2001;62(4):239-48. [pmid: 11379837].
Burke E C. Youth violence. An epidemic vaccines can't treat. Minn Med. 1993;76(8):5. [pmid: 8127297].
Burks V S, Laird R D, Dodge K A, et al. Knowledge structures, social information processing, and children's aggressive behavior. Soc Dev. 1999;8(2):220-36. [pmid: 20011226].
Burrell B, Thompson B, Sexton D. Predicting child abuse potential across family types. Child Abuse Negl. 1994;18(12):1039-49. [pmid: 7850612].
Burt CW. Injury-related visits to hospital emergency departments: United States, 1992. Adv Data 1995(261):1–20.
Burton D, Foy D, Bwanausi C, et al. The relationship between traumatic exposure, family dysfunction, and post-traumatic stress symptoms in male juvenile offenders. J Trauma Stress. 1994;7(1):83-93. [pmid: 8044445].
Burton D L. An examination of social cognitive theory with differences among sexually aggressive, physically aggressive and nonaggressive children in state care. Violence Vict. 1999;14(2):161-78. [pmid: 10418769].
Burton D L, Nesmith A A, Badten L. Clinician's views on sexually aggressive children and their families: A theoretical exploration. Child Abuse Negl. 1997;21(2):157-70. [pmid: 9056095].
Busch K G, Zagar R, Hughes J R, et al. Adolescents who kill. J Clin Psychol. 1990;46(4):472-85. [pmid: 2212052].
Bushman B J, Baumeister R F. Threatened egotism, narcissism, self-esteem, and direct and displaced aggression: does self-love or self-hate lead to violence?. J Pers Soc Psychol. 1998;75(1):219-29. [pmid: 9686460].
Buss D M. Manipulation in close relationships: five personality factors in interactional context. J Pers. 1992;60(2):477-99. [pmid: 1635051].
Butchart A, Engstrom K, et al. Sex- and age- specific relations between economic development, economic inequality and homicide rates in people aged 0–24 years: a cross-sectional analysis. Bull World Health Organ. 2002;80(10):797-805. [pmid: 12471400].
Butts J A, Snyder H N. Youngest delinquents: Offenders under age 15. Sch Interv Rep. 1997;11(2):6-11.
Butz C, Spaccarelli S. Use of physical force as an offense characteristic in subtyping juvenile sexual offenders. Sex Abuse. 1999;11(3):217-32. [pmid: 10497781].
Bynum E G, Weiner R I. Self-concept and violent delinquency in urban African-American adolescent males. Psychol Rep. 2002;90(2):477-86. [pmid: 12061587].
Caggiano A D. Identifying violent-toward-staff juvenile delinquents via the Millon Adolescent Clinical Inventory and neuropsychological measures. J Offender Rehabil. 2000;32(12):147-65.
Cahn M D, Chamberlain B, Cross P O, et al. Forum on youth violence in minority communities. Interventions in early childhood. Public Health Rep. 1991;106(3):258-63. [pmid: 1905039].
Cairns R B, Coleman-Miller B, Greenwood P W, et al. Violence prevention strategies directed toward high-risk minority youths. Public Health Rep. 1991;106(3):250-4. [pmid: 1905037].
Caldwell J R. Interpersonal violence. Can political, sociologic or economic reform stem the epidemic?. J Fla Med Assoc. 1994;81(7):459-60. [pmid: 7798870].
Caldwell M F, Van Rybroek G J. Efficacy of a decompression treatment model in the clinical management of violent juvenile offenders. Int J Offender Ther Comp Criminol. 2001;45(4):469-77.
Calicchia J A, Moncata S J, Santostefano S. Cognitive control differences in violent juvenile inpatients. J Clin Psychol. 1993;49(5):731-40. [pmid: 8254083].
Callahan C M, Rivara F P, Farrow J A. Youth in detention and handguns. J Adolesc Health. 1993;14(5):350-5. [pmid: 8399245].
Calvert W J. Neighborhood disorder, individual protective factors, and the risk of adolescent delinquency. ABNF J. 2002;13(6):127-35. [pmid: 12592829].
Campanella S. Delinquency risk prediction. J Child Youth Care. 1990;4(5):73-83.
Campbell A. Representations, repertoires and power: Mother-child conflict. J Theory Soc Behav. 1995;25(1):35-57.
Campbell A, Muncer S, Odber J. Aggression and testosterone: Testing a bio-social model. Aggress Behav. 1997;23(4):229-38.
Campbell J S, Lerew C. Juvenile sex offenders in diversion. Sex Abuse. 2002;14(1):1-17. [pmid: 11803592].
Cano A, Avery-Leaf S, Cascardi M, et al. Dating violence in two high school samples: Discriminating variables. J Prim Prev. 1998;18(4):431-46.
Cantrell P J, MacIntyre D I, Sharkey K J, et al. Violence in the marital dyad as a predictor of violence in the peer relationships of older adolescents/young adults. Violence Vict. 1995;10(1):35-41. [pmid: 8555118].
Capaldi D M, Clark S. Prospective family predictors of aggression toward female partners for at-risk young men. Dev Psychol. 1998;34(6):1175-88. [pmid: 9823503].
Capaldi D M, Dishion T J, Stoolmiller M, et al. Aggression toward female partners by at-risk young men: the contribution of male adolescent friendships. Dev Psychol. 2001;37(1):61-73. [pmid: 11206434].
Capaldi D M, Owen L D. Physical aggression in a community sample of at-risk young couples: gender comparisons for high frequency, injury, and fear. J Fam Psychol. 2001;15(3):425-40. [pmid: 11584793].
Capaldi D M, Patterson G R. Can violent offenders be distinguished from frequent offenders: Prediction from childhood to adolescence. J Res Crime Delinq. 1996;33(2):206-31.
Capaldi D M, Shortt J W, Crosby L. Physical and psychological aggression in at-risk young couples: Stability and change in young adulthood. Merrill Palmer Q. 2003;49(1):1-27.
Cappell C, Heiner R B. The intergenerational transmission of family aggression. J Fam Violence. 1990;5(2):135-52.
Caprara G V, Barbaranelli C, Pastorelli C, et al. Prosocial foundations of children's academic achievement. Psychol Sci. 2000;11(4):302-6. [pmid: 11273389].
Caprara G V, Regalia C, Bandura A. Longitudinal impact of perceived self-regulatory eficacy on violent conduct. Eur Psychol. 2002;7(1):63-9.
Caputo A A, Frick P J, Brodsky S L. Family violence and juvenile sex offending: The potential mediating role of psychopathic traits and negative attitudes toward women. Crim Justice Behav. 1999;26(3):338-56.
Carbonneau R, Tremblay R E, Vitaro F, et al. Paternal alcoholism, paternal absence and the development of problem behaviors in boys from age six to twelve years. J Stud Alcohol. 1998;59(4):387-98. [pmid: 9647421].
Carlo G, Raffaelli M, Laible D J, et al. Why are girls less physically aggressive than boys? Personality and parenting mediators of physical aggression. Sex Roles. 1999;40(910):711-29.
Carlson B E. Adolescent observers of marital violence. J Fam Violence. 1990;5(4):285-99.
Carlson E A. A prospective longitudinal study of attachment disorganization/disorientation. Child Dev. 1998;69(4):1107-28. [pmid: 9768489].
Carpenter E M, Nangle D W. Effects of brief verbal instructions on aggression: A replication in a Head Start setting. Child Fam Behav Ther. 2002;24(4):21-38.
Carroll S T, Riffenburgh R H, Roberts T A, et al. Tattoos and body piercings as indicators of adolescent risk-taking behaviors. Pediatrics. 2002;109(6):1021-10217. [pmid: 12042538].
Carvajal S C, Hanson C E, Romero A J, et al. Behavioural risk factors and protective factors in adolescents: a comparison of Latinos and non-Latino whites. Ethn Health. 2002;7(3):181-93. [pmid: 12523944].
Caspi A, Begg D, Dickson N. Personality differences predict health-risk behaviors in young adulthood: evidence from a longitudinal study. J Pers Soc Psychol. 1997;73:1052-63. [pmid: 9364760].
Caspi A, Begg D, Dickson N, et al. Personality differences predict health-risk behaviors in young adulthood: evidence from a longitudinal study. J Pers Soc Psychol. 1997;73(5):1052-63. [pmid: 9364760].
Caspi A, McClay J, Moffitt T E, et al. Role of genotype in the cycle of violence in maltreated children. Science. 2002;297(5582):851-4. [pmid: 12161658].
Caspi A, Moffitt T E, Newman D L, et al. Behavioral observations at age 3 years predict adult psychiatric disorders. Longitudinal evidence from a birth cohort. Arch Gen Psychiatry. 1996;53(11):1033-9. [pmid: 8911226].
Cassetta RA. Children: a community in crisis. Am Nurse 1994;26(10):1, 20–1.
Cassetta R A. Nurses work to prevent violence in schools. Am Nurse. 1994;26(4):7. [pmid: 7810920].
Castiglia P T. Gangs. J Pediatr Health Care. 1993;7(1):39-41. [pmid: 8106927].
Cauffman E, Feldman S S, Waterman J, et al. Posttraumatic stress disorder among female juvenile offenders. J Am Acad Child Adolesc Psychiatry. 1998;37(11):1209-16. [pmid: 9808933].
Cavell T A, Hughes J N. Secondary prevention as context for assessing change processes in aggressive children. J Sch Psychol. 2000;38(3):199-235.
Centers for Disease Control. National youth violence prevention resource center. Accessed: May 2004. http://www.safeyouth.org/scripts/pros/community.asp.
Chang J, Jen, Chen J J, Brownson R C. The role of repeat victimization in adolescent delinquent behaviors and recidivism. J Adolesc Health. 2003;32(4):272-80. [pmid: 12667731].
Chang J J, Chen J J, Brownson R C. The role of repeat victimization in adolescent delinquent behaviors and recidivism. J Adolesc Health. 2003;32(4):272-80. [pmid: 12667731].
Chapple C L. Examining intergenerational violence: violent role modeling or weak parental controls?. Violence Vict. 2003;18(2):143-62. [pmid: 15109120].
Charlebois P, LeBlanc M, Gagnon C, et al. Age trends in early behavioral predictors of serious antisocial behaviors. J Psychopathol Behav Assess. 1993;15(1):23-41.
Chase K A, Treboux D, O'Leary K D. Characteristics of high-risk adolescents' dating violence. J Interpers Violence. 2002;17(1):33-49.
Chase K A, Treboux D, O'Leary K D, et al. Specificity of dating aggression and its justification among high-risk adolescents. J Abnorm Child Psychol. 1998;26(6):467-73. [pmid: 9915653].
Cheadle A, Wagner E, Anderman C, et al. Measuring community mobilization in the Seattle Minority Youth Health Project. Eval Rev. 1998;22(6):699-716. [pmid: 10345195].
Cheadle A, Wagner E, Walls M, et al. The effect of neighborhood-based community organizing: results from the Seattle Minority Youth Health Project. Health Serv Res. 2001;36(4):671-89. [pmid: 11508634]. [pmcid: 1089251].
Chen C, Greenberger E, Lester J, et al. A cross-cultural study of family and peer correlates of adolescent misconduct. Dev Psychol. 1998;34(4):770-81. [pmid: 9681269].
Cheng T L, Wright J L, Fields C B, et al. Violent injuries among adolescents: declining morbidity and mortality in an urban population. Ann Emerg Med. 2001;37(3):292-300. [pmid: 11223766].
Cheong J, Patock-Peckham J A, Nagoshi C T. Effects of alcoholic beverage, instigation, and inhibition on expectancies of aggressive behavior. Violence Vict. 2001;16(2):173-84. [pmid: 11345477].
Cherpitel C J. Alcohol and casualties: a comparison of emergency room and coroner data. Alcohol Alcohol. 1994;29(2):211-8. [pmid: 8080603].
Chesney-Lind M, Paramore V V. Are girls getting more violent? Exploring juvenile robbery trends. J Contemp Crim Justice. 2001;17(2):142-66.
Cheung P, Schweitzer I, Tuckwell V, et al. A prospective study of assaults on staff by psychiatric in-patients. Med Sci Law. 1997;37(1):46-52. [pmid: 9383945].
Child Trends. Child trends databank. Accessed: May 2004. http://www.childtrendsdatabank.org/.
Choi P Y, Pope H G. Violence toward women and illicit androgenic-anabolic steroid use. Ann Clin Psychiatry. 1994;6(1):21-5. [pmid: 7951641].
Christoffel K K. Violent death and injury in US children and adolescents. Am J Dis Child. 1990;144(6):697-706. [pmid: 2356796].
Christoffel K K. Firearm-related homicides among teenagers and young adults. JAMA. 1999;281(4):323-4. [pmid: 10442655].
Christoffel K K, Spivak H, Witwer M. Youth violence prevention: the physician's role. JAMA. 2000;283(9):1202-3. [pmid: 10703789].
Cirillo K J, Pruitt B E, Colwell B, et al. School violence: prevalence and intervention strategies for at-risk adolescents. Adolescence. 1998;33(130):319-30. [pmid: 9706319].
Clare P, Bailey S, Clark A. Relationship between psychotic disorders in adolescence and criminally violent behaviour. A retrospective examination. Br J Psychiatry. 2000;177:275-9. [pmid: 11040891].
Clark E, Beck D, Sloane H, et al. Self-modeling with preschoolers: Is it different?. Sch Psychol Int. 1993;14(1):83-9.
Clark J. Our youth, our future. J Ky Med Assoc. 1994;92(5):197-8. [pmid: 8027640].
Clarke J, Stein M D, Sobota M, et al. Victims as victimizers: physical aggression by persons with a history of childhood abuse. Arch Intern Med. 1999;159(16):1920-4. [pmid: 10493322].
Clarke R A, Murphy D L, Constantino J N. Serotonin and externalizing behavior in young children. Psychiatry Res. 1999;86(1):29-40. [pmid: 10359480].
Claussen A H, Crittenden P M. Physical and psychological maltreatment: relations among types of maltreatment. Child Abuse Negl. 1991;15(12):5-18. [pmid: 2029672].
Clemence A J, Hilsenroth M J, Sivec H J, et al. Hand Test AGG and AOS variables: Relation with teacher rating of aggressiveness. J Pers Assess. 1999;73(3):334-44. [pmid: 10689647].
Clubb P A, Browne D C, Humphrey A D, et al. Violent behaviors in early adolescent minority youth: results from a “middle school youth risk behavior survey”. Matern Child Health J. 2001;5(4):225-35. [pmid: 11822524].
Coccaro E F, Kavoussi R J, Hauger R L. Serotonin function and antiaggressive response to fluoxetine: a pilot study. Biol Psychiatry. 1997;42(7):546-52. [pmid: 9376450].
Cochran J K, Wood P B, Arneklev B J. Is the religiosity-delinquency relationship spurious? Social control theories. J Res Crime Delinq. 1994;31(1):92-123.
Cockburn A. The best years of their lives. New Statesman Soc. 1990;3:25-6.
Cohen E. The violent adolescent: theoretical and clinical considerations. Am J Psychoanal. 2002;62(3):209-12. [pmid: 12357679].
Cohen R A, Rosenbaum A, Kane R L, et al. Neuropsychological correlates of domestic violence. Violence Vict. 1999;14(4):397-411. [pmid: 10751047].
Cohen S, Lang C. Forum on youth violence in minority communities. Application of the principles of community-based programs. Public Health Rep. 1991;106(3):269-70. [pmid: 1905043].
Cohen S, Wilson-Brewer R. Violence Prevention for Young Adolescents: The State of the Art of Program Evaluation. Working Papers. In: Proceedings of the Carnegie Corporation Conference on Violence Prevention for Young Adolescents; 1990; Washington, D.C.; 1990.
Coie J D, Cillessen A H N, Dodge K A, et al. It takes two to fight: A test of relational factors and a method for assessing aggressive dyads. Dev Psychol. 1999;35(5):1179-88. [pmid: 10493644].
Coker A L, McKeown R E, Sanderson M, et al. Severe dating violence and quality of life among south carolina high school students. Am J Prev Med. 2000;19(4):220-7. [pmid: 11064224].
Colder C R, Lochman J E, Wells K C. The moderating effects of children's fear and activity level on relations between parenting practices and childhood symptomatology. J Abnorm Child Psychol. 1997;25(3):251-63. [pmid: 9212377].
Colder C R, Mott J, Levy S, et al. The relation of perceived neighborhood danger to childhood aggression: A test of mediating mechanisms. Am J Community Psychol. 2000;28(1):83-103. [pmid: 10824275].
Cole D A, Maxwell S E, Martin J M, et al. The development of multiple domains of child and adolescent self-concept: a cohort sequential longitudinal design. Child Dev. 2001;72(6):1723-46. [pmid: 11768142].
Coleman M, Pfeiffer S, Oakland T. Aggression replacement training with behaviorally disordered adolescents. Behav Disord. 1992;18(1):54-66.
Coles C J, Greene A F, Braithwaite H O. The relationship between personality, anger expression, and perceived family control among incarcerated male juveniles. Adolescence. 2002;37(146):395-409. [pmid: 12144167].
Collinsworth H J. Adolescent violence. J La State Med Soc. 2000;152(10):483-4. [pmid: 11059917].
Colsman M, Wulfert E. Conflict Resolution Style as an Indicator of Adolescents' Substance Use and Other Problem Behaviors. Addict Behav. 2002;27(4):633-48. [pmid: 12188597].
Commission for the Prevention of Youth Violence. Youth and violence. Medicine, nursing, and public health: connecting the dots to prevent violence. Accessed: May 2004. http://www.ama-assn.org/ama/upload/mm/386/fullreport.pdf
Compton R. Discovering the promise of curriculum integration: The National Curriculum Integration Project. Confl Resolut Q. 2002;19(4):447-64.
Connolly J, Pepler D, Craig W, et al. Dating experiences of bullies in early adolescence. Child Maltreat. 2000;5(4):299-310. [pmid: 11232258].
Connor D E, Edwards G, Fletcher K E, et al. Correlates of comorbid psychopathology in children with ADHD. J Am Acad Child Adolesc Psychiatry. 2003;42(2):193-200. [pmid: 12544179].
Connor D F, Barkley R A, Davis H T. A pilot study of methylphenidate, clonidine, or the combination in ADHD comorbid with aggressive oppositional defiant or conduct disorder. Clin Pediatr (Phila). 2000;39(1):15-25. [pmid: 10660814].
Connor D F, Melloni R H, Harrison R J. Overt categorical aggression in referred children and adolescents. J Am Acad Child Adolesc Psychiatry. 1998;37(1):66-73. [pmid: 9444902].
Connor D F, Melloni R H J, Harrison R J. Overt categorical aggression in referred children and adolescents. J Am Acad Child Adolesc Psychiatry. 1998;37(1):66-73. [pmid: 9444902].
Connor D F, Ozbayrak K R, Benjamin S, et al. A pilot study of nadolol for overt aggression in developmentally delayed individuals. J Am Acad Child Adolesc Psychiatry. 1997;36(6):826-34. [pmid: 9183139].
Conroy D E, Silva J M, Newcomer R R, et al. Personal and participatory socializers of the perceived legitimacy of aggressive behavior in sport. Aggress Behav. 2001;27(6):405-18.
Conseur A, Rivara F P, Barnoski R, et al. Maternal and perinatal risk factors for later delinquency. Pediatrics. 1997;99(6):785-90. [pmid: 9164769].
Constantino J N, Liberman M, Kincaid M. Effects of serotonin reuptake inhibitors on aggressive behavior in psychiatrically hospitalized adolescents: results of an open trial. J Child Adolesc Psychopharmacol. 1997;7(1):31-44. [pmid: 9192540].
Constantino J N, Liberman M, Kincaid M. Effects of serotonin reuptake inhibitors on aggressive behavior in psychiatrically hospitalized adolescents: results of an open trial. J Child Adolesc Psychopharmacol. 1997;7(1):31-44. [pmid: 9192540].
Conway K P, McCord J. A longitudinal examination of the relation between co-offending with violent accomplices and violent crime. Aggress Behav. 2002;28(2):97-108.
Coohey C. The role of friends, in-laws, and other kin in father-perpetrated child physical abuse. Child Welfare. 2000;79(4):373-402. [pmid: 10925765].
Cook P J, Juarez P, Lee R K, et al. Weapons and minority youth violence. Public Health Rep. 1991;106(3):254-8. [pmid: 1905038].
Cook PJ, Laub JH. The unprecedented epidemic in youth violence. In: Tonry M, Moore MH, editors. Youth violence: Crime and justice. Chicago: University of Chicago Press; 1998.
Cookson H M. Alcohol use and offence type in young offenders. Br J Criminol. 1992;32(3):352-60.
Cooley-Quille M R, Turner S M, Beidel D C. Emotional impact of children's exposure to community violence: a preliminary study. J Am Acad Child Adolesc Psychiatry. 1995;34(10):1362-8. [pmid: 7592274].
Cooper H, Hedges LV, editors. The handbook of research synthesis. New York: Russell Sage Foundation; 1994. Chapter 14, Vote-counting procedure in meta-analysis.
Coppens N M, Gentry L K. Video analysis of playground injury-risk situations. Res Nurs Health. 1991;14(2):129-36. [pmid: 2047534].
Corbett M, Duggan C, Larkin E. Substance misuse and violence: A comparison of special hospital inpatients diagnosed with either schizophrenia or personality disorder. Crim Behav Ment Health. 1998;8(4):311-21.
Cornell D G. Prior adjustment of violent juvenile offenders. Law Hum Behav. 1990;14(6):569-77.
Cornell D G. Juvenile homicide: A growing national problem. Behav Sci Law. 1993;11(4):389-96.
Cornell D G, Loper A B. Assessment of violence and other high-risk behaviors with a school survey. School Psych Rev. 1998;27(2):317-30.
Cornell D G, Peterson C S, Richards H. Anger as a predictor of aggression among incarcerated adolescents. J Consult Clin Psychol. 1999;67(1):108-15. [pmid: 10028214].
Cornell D G, Wilson L A. The PIQ greater than VIQ discrepancy in violent and nonviolent delinquents. J Clin Psychol. 1992;48(2):256-61. [pmid: 1573030].
Cortoni F, Marshall W L. Sex as a coping strategy and its relationship to juvenile sexual history and intimacy in sexual offenders. Sex Abuse. 2001;13(1):27-43.
Corwyn R F, Benda B B. Violent youths in southern public schools in America. Int J Adolesc Youth. 2001;10(12):69-90.
Costello B J, Dunaway R G. Egotism and delinquent behavior. J Interpers Violence. 2003;18(5):572-90.
Cota-Robles S, Neiss M, Rowe D C. The role of puberty in violent and nonviolent delinquency among Anglo American, Mexican American, and African American boys. J Adolesc Res. 2002;17(4):364-76.
Cotten N U, Resnick J, Browne D C, et al. Aggression and fighting behavior among African-American adolescents: individual and family factors. Am J Public Health. 1994;84(4):618-22. [pmid: 8154566]. [pmcid: 1614788].
Cotton P. Violence decreases with gang truce. JAMA. 1992;268(4):443-4. [pmid: 1280696].
Cottrol C, Frances R. Substance abuse, comorbid psychiatric disorder, and repeated traumatic injuries. Hosp Community Psychiatry. 1993;44(8):715-6. [pmid: 8375830].
Courtenay W H. Youth violence? Let's call it what it is. J Am Coll Health. 1999;48(3):141-2. [pmid: 10584450].
Cousins L H. Toward a sociocultural context for understanding violence and disruption in Black urban schools and communities. J Sociol Soc Welf. 1997;24(2):41-63.
Cousins L H. Moral markets for troubling youths: A disruption!. Child Glob J Child Res. 2001;8(2):193-211.
Cousins L H, Mabrey T. Re-gendering social work practice and education: The case for African-American girls. J Hum Behav Soc Environ. 1998;1(23):91-104.
Cowie H, Olafsson R. The role of peer support in helping the victims of bullying in a school with high levels of aggression. Sch Psychol Int. 2000;21(1):79-95.
Cox R D, Schopler E. Aggression and self-injurious behaviors in persons with autism: The TEACCH approach. Acta Paedopsychiatr. 1993;56(2):85-90. [pmid: 8135116].
Coyne-Beasley T, Schoenbach V J, Herman-Giddens M E. The epidemiology of adolescent homicide in North Carolina from 1990 to 1995. Arch Pediatr Adolesc Med. 1999;153(4):349-56. [pmid: 10201716].
Craig W M. The relationship among bullying, victimization, depression, anxiety, and aggression in elementary school children. Pers Individ Dif. 1998;24(1):123-30.
Craig W M, Pepler D, Atlas R. Observations of bullying in the playground and in the classroom. Sch Psychol Int. 2000;21(1):22-36.
Cramer E, McFarlane J. Pornography and abuse of women. Public Health Nurs. 1994;11(4):268-72. [pmid: 7937500].
Crane-Ross D, Tisak M S, Tisak J. Aggression and conventional rule violation among adolescents: Social-reasoning predictors of social behavior. Aggress Behav. 1998;24(5):347-65.
Crick N R. Engagement in gender normative versus nonnormative forms of aggression: Links to social-psychological adjustment. Dev Psychol. 1997;33(4):610-7. [pmid: 9232376].
Crick N R, Dodge K A. Social information-processing mechanisms on reactive and proactive aggression. Child Dev. 1996;67(3):993-1002. [pmid: 8706540].
Crick N R, Grotpeter J K, Bigbee M A. Relationally and physically aggressive children's intent attributions and feelings of distress for relational and instrumental peer provocations. Child Dev. 2002;73(4):1134-42. [pmid: 12146738].
Crimmins S, Langley S, Brownstein H H, et al. Convicted women who have killed children: A self-psychology perspective. J Interpers Violence. 1997;12(1):49-69.
Crimmins S M, Cleary S D, Brownstein H H, et al. Trauma, drugs and violence among juvenile offenders. J Psychoactive Drugs. 2000;32(1):43-54. [pmid: 10801067].
Crittenden P M, Craig S E. Developmental trends in the nature of child homicide. J Interpers Violence. 1990;5(2):202-16.
Crowley T J, Mikulich S K, MacDonald M, et al. Substance-dependent, conduct-disordered adolescent males: severity of diagnosis predicts 2-year outcome. Drug Alcohol Depend. 1998;49(3):225-37. [pmid: 9589270].
Crowner M L, Douyon R, Convit A, et al. Akathisia and violence. Psychopharmacol Bull. 1990;26(1):115-7. [pmid: 1973544].
Crowner M L, Douyon R, Convit A, et al. Videotape recording of assaults on a state hospital inpatient ward. J Neuropsychiatry Clin Neurosci. 1991;3(2):S9-S14. [pmid: 1821225].
Crowner M L, Stepcic F, Peric G, et al. Typology of patient-patient assaults detected by videocameras. Am J Psychiatry. 1994;151(11):1669-72. [pmid: 7943459].
Ctr NGCR. Bomb and arson crimes among American gang members: A behavioral science profile. J Gang Res 2001;9(1):1–38.
Cubbin C, Pickle L W, Fingerhut L. Social context and geographic patterns of homicide among US black and white males. Am J Public Health. 2000;90(4):579-87. [pmid: 10754973]. [pmcid: 1446205].
Cuddy M E, Frame C. Comparison of aggressive and nonaggressive boys' self-efficacy and outcome expectancy beliefs. Child Study J. 1991;21(2):135-52.
Cuffel B J, Shumway M, Chouljian T L, et al. A longitudinal study of substance use and community violence in schizophrenia. J Nerv Ment Dis. 1994;182(12):704-8. [pmid: 7989915].
Cummings A L, Leschied A W. Understanding aggression with adolescent girls: Implications for policy and practice. Can J Commun Ment Health. 2001;20(2):43-57. [pmid: 12051028].
Cummings P, Koepsell T D, Grossman D C, et al. The association between the purchase of a handgun and homicide or suicide. Am J Public Health. 1997;87(6):974-8. [pmid: 9224179]. [pmcid: 1380933].
Cunningham C E, Cunningham L J, Martorelli V, et al. The effects of primary division, student-mediated conflict resolution programs on playground aggression. J Child Psychol Psychiatry. 1998;39(5):653-62. [pmid: 9690929].
Cunningham P B, Henggeler S W. Implementation of an empirically based drug and violence prevention and intervention program in public school settings. J Clin Child Psychol. 2001;30(2):221-32. [pmid: 11393922].
Cunningham P B, Henggeler S W, Limber S P, et al. Patterns and correlates of gun ownership among nonmetropolitan and rural middle school students. J Clin Child Psychol. 2000;29(3):432-42. [pmid: 10969427].
Curtner-Smith M E. Mechanisms by which family processes contribute to school-age boy's bullying. Child Study J. 2000;30(3):169-86.
Dabbs J M, Jurkovic G J, Frady R L. Salivary testosterone and cortisol among late adolescent male offenders. J Abnorm Child Psychol. 1991;19(4):469-78. [pmid: 1757712].
Daderman A M, Edman G. Flunitrazepam abuse and personality characteristics in male forensic psychiatric patients. Psychiatry Res. 2001;103(1):27-42. [pmid: 11472788].
Dahlberg L L, Potter L B. Youth violence: Developmental pathways and prevention challenges. Am J Prev Med. 2001;20(Suppl1):3-14. [pmid: 11146255].
Daldin H. Assaultive behavior in the analysis of children. Psychoanal Psychol. 1992;9(4):477-88.
Daly M, Wilson M. Killing the competition: Female/female and male/male homicide. Hum Nat. 1990;1(1):81-107.
Daly M, Wilson M, Salmon C A, et al. Siblicide and seniority. Homicide Stud. 2001;5(1):30-45.
Daly R C, Su T-P, Schmidt P J, et al. Neuroendocrine and behavioral effects of high-dose anabolic steroid administration in male normal volunteers. Psychoneuroendocrinology. 2003;28(3):317-31. [pmid: 12573299].
Danov R, Bucci W. Attachment processes among violence-prone minority youths and their caretakers. NYS Psychol. 2002;14(1):28-32.
Darby P J, Allan W D, Kashani J H, et al. Analysis of 112 juveniles who committed homicide: Characteristics and a closer look at family abuse. J Fam Violence. 1998;13(4):365-75.
David C, Steele R, Forehand R, et al. The role of family conflict and marital conflict in adolescent functioning. J Fam Violence. 1996;11(1):81-91.
Davidson P, Koziol-McLain J, Harrison L, et al. Intoxicated ED patients: a 5-year follow-up of morbidity and mortality. Ann Emerg Med. 1997;30(5):593-7. [pmid: 9360567].
Davidson P W, Cain N N, Sloane-Reeves J E, et al. Characteristics of community-based individuals with mental retardation and aggressive behavioral disorders. Am J Ment Retard. 1994;98(6):704-16. [pmid: 8054199].
Davidson P W, Others A. Characteristics of children and adolescents with mental retardation and frequent outwardly directed aggressive behavior. Am J Ment Retard. 1996;101(3):244-55. [pmid: 8933899].
Davis B T, Hops H, Alpert A, et al. Child responses to parental conflict and their effect on adjustment: A study of triadic relations. J Fam Psychol. 1998;12(2):163-77.
Davis D L, Boster L H. Cognitive-behavioral-expressive interventions with aggressive and resistant youths. Child Welfare. 1992;71(6):557-73. [pmid: 1424948].
Davis D L, Boster L H. Cognitive-behavioral-expressive interventions with aggressive and resistant youth. Resid Treat Child Youth. 1993;10(4):55-68.
Davis E, Beverly C. Youth violence: An action research project. J Multicult Soc Work. 1991;1(3):33-44.
Davis T C, Byrd R S, Arnold C L, et al. Low literacy and violence among adolescents in a summer sports program. J Adolesc Health. 1999;24(6):403-11. [pmid: 10401968].
Davis T C, Peck G Q, Storment J M. Acquaintance rape and the high school student. J Adolesc Health. 1993;14(3):220-4. [pmid: 8323934].
Dawkins M P. Drug use and violent crime among adolescents. Adolescence. 1997;32(126):395-405. [pmid: 9179335].
Dawson D A. Alternative measures and models of hazardous consumption. J Subst Abuse. 2000;12(12):79-91. [pmid: 11288476].
Dawson J. Vortex of evil. New Statesman Soc. 1990;3:12-4.
Day D M, Bream L A, Pal A. Proactive and reactive aggression: An analysis of subtypes based on teacher perceptions. J Clin Child Psychol. 1992;21(3):210-7.
Day H D, Franklin J M, Marshall D D. Predictors of aggression in hospitalized adolescents. J Psychol. 1998;132(4):427-34. [pmid: 9637024].
Day K. Male mentally handicapped sex offenders. Br J Psychiatry. 1994;165(5):630-9. [pmid: 7866678].
de Anda D. A qualitative evaluation of a mentor program for at-risk youth: The participants' perspective. Child Adolesc Social Work J. 2001;18(2):97-117.
Deffenbacher J L, Swaim R C. Anger expression in Mexican American and White non-Hispanic adolescents. J Couns Psychol. 1999;46(1):61-9.
Deibert G R, Miethe T D. Character contests and dispute-related offenses. Deviant Behav. 2003;24(3):245-67.
Delva-Tauiliili J. Does brief Aikido training reduce aggression of youth?. Percept Mot Skills. 1995;80(1):297-8. [pmid: 7624209].
Delveaux K D, Daniels T. Children's social cognitions: Physically and relationally aggressive strategies and children's goals in peer conflict situations. Merrill Palmer Q. 2000;46(4):672-92.
Dembo R. Predictors of recidivism to a juvenile assessment center: An expanded analysis. J Child Adolesc Subst Abus. 1996;5(1):27-53.
Dembo R, Hughes P, Jackson L, et al. Crack cocaine dealing by adolescents in two public housing projects: A pilot study. Hum Organ. 1993;52(1):89-96.
Dembo R, Schmeidler J, Nini-Gough B, et al. Predictors of recidivism to a juvenile assessment center: A three year study. J Child Adolesc Subst Abus. 1998;7(3):57-77.
Dembo R, Turner G, Borden P, et al. Screening high risk youths for potential problems: Field application in the use of the Problem Oriented Screening Instrument for Teenagers (POSIT). J Child Adolesc Subst Abus. 1994;3(4):69-93.
Dembo R, Turner G, Sue C C, et al. Predictors of recidivism to a juvenile assessment center. Int J Addict. 1995;30(11):1425-52. [pmid: 8530214].
Dembo R, Williams L, La Voie L, et al. A longitudinal study of the relationships among alcohol use, marijuana/hashish use, cocaine use, and emotional/psychological functioning problems in a cohort of high-risk youths. Int J Addict. 1990;25(11):1341-82. [pmid: 2090630].
Dembo R, Williams L, Schmeidler J, et al. Recidivism in a cohort of juvenile detainees: a 3 1/2-year follow-up. Int J Addict. 1993;28(7):631-58. [pmid: 8407028].
Dembo R, Williams L, Wothke W, et al. The relationship between cocaine use, drug sales, and other delinquency among a cohort of high-risk youths over time. NIDA Res Monogr. 1990;103:112-35. [pmid: 2096284].
Dembo R, Wothke W, Shemwell M, et al. A structural model of the influence of family problems and child abuse factors on serious delinquency among youths processed at a juvenile assessment center. J Child Adolesc Subst Abus. 2000;10(1):17-31.
Dennis D, Massie J E, Wycoff-Horn M, et al. Weapon carrying among rural southern Illinois elementary school children. J Health Care Poor Underserved. 2002;13(4):413-24. [pmid: 12407960].
Denton JS, Filkins JA, Stephenson D, et al. Criminal consequences of commotio cordis. Am J Cardiol 2002;90(10):1181–2; Discussion 2.
Dery M, Toupin J, Pauze R, et al. Neuropsychological characteristics of adolescents with conduct disorder: association with attention-deficit-hyperactivity and aggression. J Abnorm Child Psychol. 1999;27(3):225-36. [pmid: 10438188].
Deschenes E P, Esbensen F-A. Violence and gangs: Gender differences in perceptions and behavior. J Quant Criminol. 1999;15(1):63-96.
DeVoe J, Peter K, Kaufman P, et al. Indicators of school crime and safety:2002. NCES Publication 2003009. Accessed: May 2004. http://nces.ed.gov/pubs2003/schoolcrime/
DiClemente R J, Wingood G M, Crosby R, et al. Parental monitoring: association with adolescents' risk behaviors. Pediatrics. 2001;107(6):1363-8. [pmid: 11694669].
Diego M A, Field T, Hernandez-Reif M, et al. Aggressive adolescents benefit from massage therapy. Adolescence. 2002;37(147):597-607. [pmid: 12458696].
DiLiberto L, Katz R C, Beauchamp K L, et al. Using Articulated Thoughts in Simulated Situations to assess cognitive activity in aggressive and nonaggressive adolescents. J Child Fam Stud. 2002;11(2):179-89.
DiLillo D, Giuffre D, Tremblay G C, et al. A closer look at the nature of intimate partner violence reported by women with a history of child sexual abuse. J Interpers Violence. 2001;16(2):116-32.
Dimsdale J E. The Nacirema revisited. Ann Behav Med. 2001;23(1):75-6. [pmid: 11761349].
DiNapoli P P. Adolescent violent behavior and ego development. J Adolesc Health. 2002;31(6):446-8. [pmid: 12457576].
DiNapoli P P. Guns and dolls: an exploration of violent behavior in girls. ANS Adv Nurs Sci. 2003;26(2):140-8. [pmid: 12795542].
Ding C S, Nelsen E A, Lassonde C T. Correlates of gun involvement and aggressiveness among adolescents. Youth Soc. 2002;34(2):195-213.
Dishion T J, Eddy M, Haas E, et al. Friendships and violent behavior during adolescence. Soc Dev. 1997;6(2):207-23.
Dodge K A, Bates J E, Pettit G S. Mechanisms in the cycle of violence. Science. 1990;250(4988):1678-83. [pmid: 2270481].
Dodge K A, Lansford J E, Burks V S, et al. Peer rejection and social information-processing factors in the development of aggressive behavior problems in children. Child Dev. 2003;74(2):374-93. [pmid: 12705561].
Dodge K A, Lochman J E, Harnish J D, et al. Reactive and proactive aggression in school children and psychiatrically impaired chronically assaultive youth. J Abnorm Psychol. 1997;106(1):37-51. [pmid: 9103716].
Dodge K A, Price J M, Bachorowski J-A. Hostile attributional biases in severely aggressive adolescents. J Abnorm Psychol. 1990;99:385-92. [pmid: 2266213].
Dodge K A, Price J M, Bachorowski J A, et al. Hostile attributional biases in severely aggressive adolescents. J Abnorm Psychol. 1990;99(4):385-92. [pmid: 2266213].
Dogra A, Veeraraghavan V. A study of psychological intervention of children with aggressive conduct disorder. Indian J Clin Psychol. 1994;21(1):28-32.
Dolin I H, Kelly D B, Beasley T M. Chronic self-destructive behavior in normative and delinquent adolescents. J Adolesc. 1992;15:57-66. [pmid: 1607425].
Dorn L D, Burgess E S, Dichek H L, et al. Thyroid hormone concentrations in depressed and nondepressed adolescents: Group differences and behavioral relations. J Am Acad Child Adolesc Psychiatry. 1996;35(3):299-306. [pmid: 8714317].
Dornbusch S M, Erickson K G, Laird J, et al. The relation of family and school attachment to adolescent deviance in diverse groups and communities. J Adolesc Res. 2001;16(4):396-422.
Dornbusch S M, Lin I-C, Munroe P T, et al. Adolescent polydrug use and violence in the United States. Int J Adolesc Med Health. 1999;11(34):197-219.
Doswell W M. After Littleton. Am J Nurs. 1999;99(10):9. [pmid: 10542833].
Doumas D, Margolin G, John R S. The intergenerational transmission of aggression across three generations. J Fam Violence. 1994;9(2):157-75.
Dowd M D. Consequences of violence. Premature death, violence recidivism, and violent criminality. Pediatr Clin North Am. 1998;45(2):333-40. [pmid: 9568013].
Dowd M D, Knapp J F, Fitzmaurice L S. Pediatric firearm injuries, Kansas City, 1992: a population-based study. Pediatrics. 1994;94(6 Pt 1):867-73. [pmid: 7971003].
Dowdell E, Burgess, Santucci M E. The relationship between health risk behaviors and fear in one urban seventh grade class. J Pediatr Nurs. 2003;18(3):187-94. [pmid: 12796861].
Downey G, Walker E. Distinguishing family-level and child-level influences on the development of depression and aggression in children at risk. Dev Psychopathol. 1992;4(1):81-95.
Drake M E, Hietter S A, Pakalnis A. EEG and evoked potentials in episodic-dyscontrol syndrome. Neuropsychobiology. 1992;26(3):125-8. [pmid: 1294892].
Dukarm C P, Byrd R S, Auinger P, et al. Illicit substance use, gender, and the risk of violent behavior among adolescents. Arch Pediatr Adolesc Med. 1996;150(8):797-801. [pmid: 8704884].
Dukes R L, Martinez R O, Stein J A. Precursors and consequences of membership in youth gangs. Youth Soc. 1997;29(2):139-65.
Duncan R D. Peer and sibling aggression: An investigation of intra- and extra-familial bullying. J Interpers Violence. 1999;14(8):871-86.
Duncan R D, Kennedy W A, Smith D W. Comparison of conduct-disordered behavior in crack-dealing versus nondealing juvenile offenders. Psychol Rep. 2000;86(3 Pt 2):1089-96. [pmid: 10932561].
Duncan S C, Duncan T E, Strycker L A, et al. Relations between youth antisocial and prosocial activities. J Behav Med. 2002;25(5):425-38. [pmid: 12442559].
Dunlap G, Robbins F R, Darrow M A. Parents' reports of their children's challenging behaviors: results of a statewide survey. Ment Retard. 1994;32(3):206-12. [pmid: 8084272].
Durant R H, Altman D, Wolfson M, et al. Exposure to violence and victimization, depression, substance use, and the use of violence by young adolescents. J Pediatr. 2000;137(5):707-13. [pmid: 11060539].
Durant R H, Barkin S, Krowchuk D P. Evaluation of a peaceful conflict resolution and violence prevention curriculum for sixth-grade students. J Adolesc Health. 2001;28(5):386-93. [pmid: 11336868].
DuRant R H, Cadenhead C, Pendergrast R A, et al. Factors associated with the use of violence among urban black adolescents. Am J Public Health. 1994;84(4):612-7. [pmid: 8154565]. [pmcid: 1614778].
Durant R H, Getts A G, Cadenhead C, et al. The association between weapon carrying and the use of violence among adolescents living in and around public housing. J Adolesc Health. 1995;17(6):376-80. [pmid: 8924444].
DuRant R H, Getts A G, Cadenhead C, et al. The association between weapon-carrying and the use of violence among adolescents living in or around public housing. J Adolesc. 1995;18(5):579-92.
DuRant R H, Kahn J, Beckford P H, et al. The association of weapon carrying and fighting on school property and other health risk and problem behaviors among high school students. Arch Pediatr Adolesc Med. 1997;151(4):360-6. [pmid: 9111434].
Durant R H, Knight J, Goodman E. Factors associated with aggressive and delinquent behaviors among patients attending an adolescent medicine clinic. J Adolesc Health. 1997;21(5):303-8. [pmid: 9358293].
DuRant R H, Krowchuk D P, Kreiter S, et al. Weapon carrying on school property among middle school students. Arch Pediatr Adolesc Med. 1999;153(1):21-6. [pmid: 10086407].
DuRant R H, Krowchuk D P, Sinal S H. Victimization, use of violence, and drug use at school among male adolescents who engage in same-sex sexual behavior. J Pediatr. 1998;133(1):113-8. [pmid: 9672522].
Durant R H, Pendergrast R A, Cadenhead C. Exposure to violence and victimization and fighting behavior by urban black adolescents. J Adolesc Health. 1994;15(4):311-8. [pmid: 7918504].
DuRant R H, Smith J A, Kreiter S R, et al. The relationship between early age of onset of initial substance use and engaging in multiple health risk behaviors among young adolescents. Arch Pediatr Adolesc Med. 1999;153(3):286-91. [pmid: 10086407].
DuRant R H, Treiber F, Getts A, et al. Comparison of two violence prevention curricula for middle school adolescents. J Adolesc Health. 1996;19(2):111-7. [pmid: 8863082].
Dutton D G, Hart S D. Risk markers for family violence in a federally incarcerated population. Int J Law Psychiatry. 1992;15(1):101-12. [pmid: 1582739].
Dykeman B F. The social cognitive treatment of anger and aggression in four adolescents with conduct disorder. J Instr Psychol. 1995;22(2):194-200.
Dykeman B F. The effects of family conflict resolution on children's classroom behavior. J Instr Psychol. 2003;30(1):41-6.
Dykeman C, Daehlin W, Doyle S, et al. Psychological predictors of school-based violence: Implications for school counselors. Sch Couns. 1996;44(1):35-47.
Eargle A E, Guerra N G, Tolan P H. Preventing aggression in inner-city children: Small group training to change cognitions, social skills, and behavior. J Child Adolesc Group Ther. 1994;4(4):229-42.
Earls F. Understanding and controlling violence. J Health Care Poor Underserved 1991;2(1):156–64; Discussion 65–6.
Easley M. Domestic violence. Ann Emerg Med. 1996;27(6):762-3. [pmid: 8644966].
Eckenrode J, Ganzel B, Henderson C R, et al. Preventing child abuse and neglect with a program of nurse home visitation: the limiting effects of domestic violence. JAMA. 2000;284(11):1385-91. [pmid: 10989400].
Eckstein M, Hutson HR. Street gangs: save yourself while saving a life. Emerg Med Serv 1994;23(7):18, 20, 2.
Eddy J M, Reid J B, Fetrow R A. An elementary school-based prevention program targeting modifiable antecedents of youth delinquency and violence: Linking the Interests of Families and Teachers (LIFT). J Emot Behav Disord. 2000;8(3):165-76.
Edens R M, Smryl T. Reducing disruptive classroom behaviors in physical education: A pilot study. J Real Ther. 1994;13(2):40-4.
Edwards W J. A measurement of delinquency differences between a delinquent and nondelinquent sample: what are the implications?. Adolescence. 1996;31(124):973-89. [pmid: 8970668].
Egan S K, Monson T C, Perry D G. Social-cognitive influences on change in aggression over time. Dev Psychol. 1998;34(5):996-1006. [pmid: 9779745].
Egeland B, Susman-Stillman A. Dissociation as a mediator of child abuse across generations. Child Abuse Negl. 1996;20(11):1123-32. [pmid: 8958463].
Egeland B, Yates T, Appleyard K, et al. The long-term consequences of maltreatment in the early years: A developmental pathway model to antisocial behavior. Child Serv (Mahwah NJ). 2002;5(4):249-60.
Einfeld S, Hall W, Levy F. Hyperactivity and the fragile x syndrome. J Abnorm Child Psychol. 1991;19(3):253-62. [pmid: 1865044].
Eisenman R. Denigration of a victim in group psychotherapy by violent vs seductive sex offenders. Psychol Rep. 1993;72(2):413-4. [pmid: 8302997].
Eitle D, Turner R J. Exposure to community violence and young adult crime: The effects of witnessing violence, traumatic victimization, and other stressful life events. J Res Crime Delinq. 2002;39(2):214-37.
Elander J, Simonoff E, Pickles A, et al. A longitudinal study of adolescent and adult conviction rates among children referred to psychiatric services for behavioural or emotional problems. Crim Behav Ment Health. 2000;10(1):40-59.
Elhassani S B. Domestic violence: a perinatal and pediatric risk factor. J S C Med Assoc. 1995;91(3):114-5. [pmid: 7474951].
Elias M J, Gara M A, Schuyler T F, et al. The promotion of social competence: Longitudinal study of a preventive school-based program. Am J Orthopsychiatry. 1991;61(3):409-17. [pmid: 1951648].
Ellickson P, Saner H, McGuigan K A. Profiles of violent youth: substance use and other concurrent problems. Am J Public Health. 1997;87(6):985-91. [pmid: 9224181]. [pmcid: 1380935].
Ellickson P L, McGuigan K A. Early predictors of adolescent violence. Am J Public Health. 2000;90(4):566-72. [pmid: 10754971]. [pmcid: 1446195].
Ellickson P L, Tucker J S, Klein D J. High-risk behaviors associated with early smoking: results from a 5-year follow-up. J Adolesc Health. 2001;28(6):465-73. [pmid: 11377990].
Ellickson P L, Tucker J S, Klein D J. Ten-year prospective study of public health problems associated with early drinking. Pediatrics. 2003;111(5 Pt 1):949-55. [pmid: 12728070].
Ellickson P L, Tucker J S, Klein D J. Ten-year prospective study of public health problems associated with early drinking. Pediatrics. 2003;111(5 Pt 1):949-55. [pmid: 12728070].
Ellis R A, Gormley M, Ellis G D, et al. Harm by her own hand: A study of internalized violence among female juveniles. J Hum Behav Soc Environ. 2003;6(3):75-90.
Ellis R A, Gormley M, Ellis G D, et al. Harm by her own hand: A study of internalized violence among female juveniles. J Hum Behav Soc Environ. 2003;6(3):75-90.
Elze D E, Stiffman A R, Dore P. The association between types of violence exposure and youths' mental health problems. Int J Adolesc Med Health. 1999;11(34):221-55.
Embry D D, Flannery D J, Vazsonyi A T, et al. Peacebuilders: a theoretically driven, school-based model for early violence prevention. Am J Prev Med. 1996;12(5 Suppl):91-100. [pmid: 8909629].
Emde K. Cops & docs: a gun violence injury prevention program. Int J Trauma Nurs. 2002;8(2):54-6. [pmid: 12000909].
Emerick R L, Dutton W A. The effect of polygraphy on the self report of adolescent sex offenders: Implications for risk assessment. Ann Sex Res. 1993;6(2):83-103.
Emerson E, Shelton D. Using creative arts to build coping skills to reduce domestic violence in the lives of female juvenile offenders. Issues Ment Health Nurs. 2001;22(2):181-95. [pmid: 11885222].
Epps K. The residential treatment of adolescent sex offenders. Issues Criminol Legal Psychol. 1991;1(17):58-67.
Epps K J, Haworth R, Swaffer T. Attitudes toward women and rape among male adolescents convicted of sexual versus nonsexual crimes. J Psychol. 1993;127(5):501-6. [pmid: 8271228].
Epstein J A, Botvin G J, Diaz T, et al. Aggression, victimization and problem behavior among inner-city minority adolescents. J Child Adolesc Subst Abus. 2000;9(3):51-66.
Epstein M H, Cullinan D, Quinn K P, et al. Characteristics of children with emotional and behavioral disorders in community-based programs designed to prevent placement in residential facilities. J Emot Behav Disord. 1994;2(1):51-7.
Erkut S, Szalacha L A, Alarcon O, et al. Stereotyped perceptions of adolescents' health risk behaviors. Cultur Divers Ethnic Minor Psychol. 1999;5(4):340-9.
Ernst M, Zametkin A J, Pascualvaca D, et al. Adrenergic and noradrenergic plasma levels in Lesch-Nyhan disease. Neuropsychopharmacology. 2000;22(3):320-6. [pmid: 10693160].
Eron L, Huesmann R, Spindler A, et al. A cognitive-ecological approach to preventing aggression in urban settings: Initial outcomes for high-risk children. J Consult Clin Psychol. 2002;70(1):179-94. [pmid: 11860044].
Eron L D. Media violence. Pediatr Ann. 1995;24(2):84-7. [pmid: 7724255].
Escarela G, Francis B, Soothill K. Competing risks, persistence and desistance in analyzing recidivism. J Quant Criminol. 2000;16(4):385-414.
Escobar-Chaves S L, Tortolero S R, Markham C, et al. Violent behavior among urban youth attending alternative schools. J Sch Health. 2002;72(9):357-62. [pmid: 12557630].
Eslea M, Smith P K. The long-term effectiveness of anti-bullying work in primary schools. Educ Res. 1998;40(2):203-18.
Espelage D L, Bosworth K, Simon T R. Examining the social context of bullying behaviors in early adolescence. J Couns Dev. 2000;78(3):326-33.
Espelage D L, Bosworth K, Simon T R. Short-term stability and prospective correlates of bullying in middle-school students: an examination of potential demographic, psychosocial, and environmental influences. Violence Vict. 2001;16(4):411-26. [pmid: 11506450].
Espelage D L, Holt M K, Henkel R R. Examination of peer-group contextual effects on aggression during early adolescence. Child Dev. 2003;74(1):205-20. [pmid: 12625446].
Espelage D L, Holt M K, Henkel R R. Examination of peer-group contextual effects on aggression during early adolescence. Child Dev. 2003;74(1):205-20. [pmid: 12625446].
Etscheidt S. Reducing aggressive behavior and improving self-control: A cognitive-behavioral training program for behaviorally disordered adolescents. Behav Disord. 1991;16(2):107-15.
Evans G D, Rey J, Hemphill M M, et al. Academic-community collaboration. An ecology for early childhood violence prevention. Am J Prev Med. 2001;20(1 Suppl):22-30. [pmid: 11146257].
Evans J P, Taylor J. Understanding violence in contemporary and earlier gangs: An exploratory application of the theory of reasoned action. J Black Psychol. 1995;21(1):71-81.
Evans W, Mason A. Factors associated with gang involvement among incarcerated youth. J Gang Res. 1996;3(4):31-40.
Evans W P, Fitzgerald C, Weigel D. Are rural gang members similar to their urban peers? Implications for rural communities. Youth Soc. 1999;30(3):267-82.
Evans W P, Fitzgerald C, Weigel D, et al. Are rural gang members similar to their urban peers? Implications for rural communities. Youth Soc. 1999;30(3):267-82.
Everett S A, Price J H. Students' perceptions of violence in the public schools: the MetLife survey. J Adolesc Health. 1995;17(6):345-52. [pmid: 8924440].
Ezell M E, Cohen L E. Age, crime, and crime control policies: A longitudinal analysis of youthful, serious, chronic offenders with implications for the “Three Strikes” legislation. Stud Crime Crime Prev. 1997;6(2):169-99.
Fackler M L. Firearm violence among youth. Ann Emerg Med. 1997;29(3):425-6. [pmid: 9055787].
Fagan J. Policing guns and youth violence. Future Child. 2002;12(2):132-51. [pmid: 12194607].
Fagan J, Chin K L. Violence as regulation and social control in the distribution of crack. NIDA Res Monogr. 1990;103:8-43. [pmid: 2096294].
Famularo R, Kinscherff R, Fenton T, et al. Child maltreatment histories among runaway and delinquent children. Clin Pediatr (Phila). 1990;29(12):713-8. [pmid: 2276248].
Fanshel D, Finch S J, Grundy J F. Testing the measurement properties of risk assessment instruments in child protective services. Child Abuse Negl. 1994;18(12):1073-84. [pmid: 7850615].
Farber E W, Burge-Callaway K. Differences in anger, hostility, and interpersonal aggressiveness in Type A and Type B adolescents. J Clin Psychol. 1998;54(7):945-52. [pmid: 9811131].
Farmer J A. Juvenile exploitation of juvenile correctional workers: A content analysis. J Correct Educ. 1990;41(3):118-19.
Farrell A D, Bruce S E. Impact of exposure to community violence on violent behavior and emotional distress among urban adolescents. J Clin Child Psychol. 1997;26(1):2-14. [pmid: 9118172].
Farrell A D, Kung E M, White K S, et al. The structure of self-reported aggression, drug use, and delinquent behaviors during early adolescence. J Clin Child Psychol. 2000;29(2):282-92. [pmid: 10802836].
Farrell A D, Meyer A L. The effectiveness of a school-based curriculum for reducing violence among urban sixth-grade students. Am J Public Health. 1997;87(6):979-84. [pmid: 9224180]. [pmcid: 1380934].
Farrell A D, Meyer A L, Dahlberg L L. Richmond youth against violence: a school-based program for urban adolescents. Am J Prev Med. 1996;12(5 Suppl):13-21. [pmid: 8909620].
Farrell A D, Meyer A L, Sullivan T N, et al. Evaluation of the responding in peaceful and positive ways (RIPP) seventh grade violence prevention curriculum. J Child Fam Stud. 2003;12(1):101-20.
Farrell A D, Meyer A L, Sullivan T N, et al. Evaluation of the responding in peaceful and positive ways (RIPP) seventh grade violence prevention curriculum. J Child Fam Stud. 2003;12(1):101-20.
Farrell A D, Meyer A L, White K S. Evaluation of Responding in Peaceful and Positive Ways (RIPP): a school-based prevention program for reducing violence among urban adolescents. J Clin Child Psychol. 2001;30(4):451-63. [pmid: 11708233].
Farrell M. Personality and anti-social behaviour among emotionally/behaviourally disturbed boys. Pers Individ Dif. 1992;13(5):511-7.
Fatum W R, Hoyle J C. Is it violence? School violence from the student perspective: Trends and interventions. Sch Couns. 1996;44(1):28-34.
Faulkner A H, Cranston K. Correlates of same-sex sexual behavior in a random sample of Massachusetts high school students. Am J Public Health. 1998;88(2):262-6. [pmid: 9491018]. [pmcid: 1508176].
Federal Bureau of Investigations. Uniform crime report. Accessed: May 2004. http://www.fbi.gov/ucr/99cius.htm.
Fehon D C, Grilo C M, Lipschitz D S. Gender differences in violence exposure and violence risk among adolescent inpatients. J Nerv Ment Dis. 2001;189(8):532-40. [pmid: 11531205].
Feigelman S, Howard D E, Li X, et al. Psychosocial and environmental correlates of violence perpetration among African-American urban youth. J Adolesc Health. 2000;27(3):202-9. [pmid: 10960219].
Feigelman W, Hyman M M, Amann K, et al. Correlates of persisting drug use among former youth multiple drug abuse patients. J Psychoactive Drugs. 1990;22(1):63-75. [pmid: 2324865].
Feiring C, Deblinger E, Hoch-Espada A, et al. Romantic relationship aggression and attitudes in high school students: The role of gender, grade, and attachment and emotional styles. J Youth Adolesc. 2002;31(5):373-85.
Feldman S S, Gowen L K. Conflict negotiation tactics in romantic relationships in high school students. J Youth Adolesc. 1998;27(6):691-717.
Felkenes G T, Becker H K. Female gang members: A growing issue for policy makers. J Gang Res. 1995;2(4):1-10.
Felson R B. “Kick 'em when they're down”: Explanations of the relationship between stress and interpersonal aggression and violence. Sociol Q. 1992;33(1):1-16.
Felson R B. Pubertal development, social factors, and delinquency among adolescent boys. Criminology. 2002;40(4):967-88.
Felson R B, Liska A E, South S J, et al. The subculture of violence and delinquency: Individual vs. school context effects. Soc Forces. 1994;73(1):155-73.
Felson R B, Messner S F. The control motive in intimate partner violence. Soc Psychol Q. 2000;63(1):86-94.
Fendrich M, Mackesy-Amiti M E, Goldstein P, et al. Substance involvement among juvenile murderers: comparisons with older offenders based on interviews with prison inmates. Int J Addict. 1995;30(11):1363-82. [pmid: 8530211].
Ferman J. Integrated mental health and substance abuse services to at-risk families. The Family Health Program of the Center for Mental Health, Inc., Washington, D. C. Psychiatr Serv. 1996;47(10):1112-4. [pmid: 8890341].
Fetsch R J, Schultz C J, Wahler J J. A preliminary evaluation of the Colorado RETHINK Parenting and Anger Management program. Child Abuse Negl. 1999;23(4):353-60. [pmid: 10321772].
Field T. American adolescents touch each other less and are more aggressive toward their peers as compared with French adolescents. Adolescence. 1999;34(136):753-8. [pmid: 10730699].
Fiester L, Nathanson S P, Visser L, et al. Lessons learned from three violence prevention projects. J Sch Health. 1996;66(9):344-6. [pmid: 8959596].
Figueroa E F, Silk K R, Huth A, et al. History of childhood sexual abuse and general psychopathology. Compr Psychiatry. 1997;38(1):23-30. [pmid: 8980868].
Fine P R, Roseman J M, Constandinou C M, et al. Homicide among black males in Jefferson County, Alabama 1978-1989. J Forensic Sci. 1994;39(3):674-84. [pmid: 8006616].
Finkelstein J W, Susman E J, Chinchilli V M, et al. Estrogen or testosterone increases self-reported aggressive behaviors in hypogonadal adolescents. J Clin Endocrinol Metab. 1997;82(8):2433-8. [pmid: 9253313].
Finkelstein J W, Von Eye A, Preece M A. The relationship between aggressive behavior and puberty in normal adolescents: a longitudinal study. J Adolesc Health. 1994;15(4):319-26. [pmid: 7918505].
Finzi R, Ram A, Har-Even D, et al. Attachment styles and aggression in physically abused and neglected children. J Youth Adolesc. 2001;30(6):769-86.
Firestone P, Bradford J M, Greenberg D M, et al. Homicidal sex offenders: psychological, phallometric, and diagnostic features. J Am Acad Psychiatry Law. 1998;26(4):537-52. [pmid: 9894211].
Firestone P, Bradford J M, Greenberg D M, et al. Differentiation of homicidal child molesters, nonhomicidal child molesters, and nonoffenders by phallometry. Am J Psychiatry. 2000;157(11):1847-50. [pmid: 11058484].
Fishbein D H, Reuland M. Psychological correlates of frequency and type of drug use among jail inmates. Addictive Behaviors Addict Behav. 1994;19(6):583-98.
Fitzmaurice L S, Gaddis G M, Knapp J F. Firearms injuries in children: an increase in violent intent, frequency and severity. Mo Med. 1993;90(5):233-7. [pmid: 8336687].
Fitzpatrick K M. Aggression and environmental risk among low-income African-American youth. J Adolesc Health. 1997;21(3):172-8. [pmid: 9283938].
Fitzpatrick K M. Fighting among America's youth: a risk and protective factors approach. J Health Soc Behav. 1997;38(2):131-48. [pmid: 9212535].
Flanagan P, Coll C G, Andreozzi L, et al. Predicting maltreatment of children of teenage mothers. Arch Pediatr Adolesc Med. 1995;149(4):451-5. [pmid: 7704176].
Flannery D J, Singer M, Williams L, et al. Adolescent violence exposure and victimization at home: Coping and psychological trauma symptoms. Int Rev Vict. 1998;6(1):29-48.
Flannery D J, Williams L L, Vazsonyi A T. Who are they with and what are they doing? Delinquent behavior, substance use, and early adolescents' after-school time. Am J Orthopsychiatry. 1999;69(2):247-53. [pmid: 10234390].
Flannery R B, Rachlin S, Walker A, et al. Characteristics of repetitively assaultive patients: ten year analysis of the Assaulted Staff Action Program (ASAP). Int J Emerg Ment Health. 2002;4(3):173-9. [pmid: 12387190].
Flannery R B, Rachlin S, Walker A P. Characteristics of assaultive patients with schizophrenia versus personality disorder: six year analysis of the Assaulted Staff Action Program (ASAP). J Forensic Sci. 2002;47(3):558-61. [pmid: 12051336].
Flannery R B, Stevens V, Juliano J, et al. Past violence and substance use disorder and subsequent violence towards others: six year analysis of the Assaulted Staff Action Program (ASAP). Int J Emerg Ment Health. 2000;2(4):241-7. [pmid: 11217155].
Flay B R, Allred C G, Ordway N. Effects of the Positive Action program on achievement and discipline: two matched-control comparisons. Prev Sci. 2001;2(2):71-89. [pmid: 11523754].
Fleming C B, Catalano R F, Oxford M L, et al. A test of generalizability of the social development model across gender and income groups with longitudinal data from the elementary school developmental period. J Quant Criminol. 2002;18(4):423-39.
Fleming J, Barner C I, Hudson B, et al. Anger, violence, and academic performance: A wtudy of troubled minority youth. Urban Educ. 2000;35(2):175-204.
Fling S, Smith L, Rodriguez T, et al. Videogames, aggression, and self-esteem: A survey. Soc Behav Pers. 1992;20(1):39-45.
Flitcraft A. Clinical violence intervention: opportunities and barriers. Bull N Y Acad Med. 1996;73(1):124-9. [pmid: 8804745].
Fontaine R G, Salzer Burks V, Dodge K A. Response decision processes and externalizing behavior problems in adolescents. Dev Psychopathol. 2002;14(1):107-22. [pmid: 11893088].
Ford M E, Linney J A. Comparative analysis of juvenile sexual offenders, violent nonsexual offenders, and status offenders. J Interpers Violence. 1995;10(1):56-70.
Forth AE. Psychopathy in adolescent offenders: Assessment, family background, and violence. Issues Criminol Legal Psychol 1995;No 24:42–4.
Forth AE, Mailloux DL. Psychopathy in youth: what do we know? In: Gacono CB, editor. The clinical and forensic assessment of psychopathy: a practitioners guide. Mahwah, New Jersey: Lawrence Erlbaum; 2000.
Foshee V A. Gender differences in adolescent dating abuse prevalence, types and injuries. Health Educ Res. 1996;11(3):275-86.
Foshee V A, Bauman K E, Arriaga X B, et al. An evaluation of Safe Dates, an adolescent dating violence prevention program. Am J Public Health. 1998;88(1):45-50. [pmid: 9584032]. [pmcid: 1508378].
Foshee V A, Bauman K E, Greene W F, et al. The Safe Dates program: 1-year follow-up results. Am J Public Health. 2000;90(10):1619-22. [pmid: 11029999]. [pmcid: 1446374].
Foshee V A, Bauman K E, Linder G F. Family violence and the perpetration of adolescent dating violence: examining social learning and social control processes. J Marriage Fam. 1999;61(2):331-42.
Foshee V A, Linder F, MacDougall J E, et al. Gender differences in the longitudinal predictors of adolescent dating violence. Prev Med. 2001;32(2):128-41. [pmid: 11162338].
Foshee V A, Linder G F, Bauman K E, et al. The Safe Dates Project: theoretical basis, evaluation design, and selected baseline findings. Am J Prev Med. 1996;12(5 Suppl):39-47. [pmid: 8909623].
Franke T M. The role of attachment as a protective factor in adolescent violent behavior. Adolesc Fam Health. 2000;1(1):40-51.
Franke T M. Adolescent violent behavior: an analysis across and within racial/ethnic groups. J Multicult Soc Work. 2000;8(1/2):47-70.
Franklin R D, Allison D B, Sutton T R. Alcohol, substance abuse, and violence among North Carolina prison admissions, 1988. J Offender Rehabil. 1992;17(34):101-11.
Fras I, Major L F. Clinical experience with risperidone. J Am Acad Child Adolesc Psychiatry. 1995;34(7):833. [pmid: 7544342].
French D C, Jansen E A, Pidada S. United States and Indonesian children's and adolescents' reports of relational aggression by disliked peers. Child Dev. 2002;73(4):1143-50. [pmid: 12146739].
Frey K S, Hirschstein M K, Guzzo B A. Second Step: Preventing aggression by promoting social competence. J Emot Behav Disord. 2000;8(2):102-12.
Friday J C. The psychological impact of violence in underserved communities. J Health Care Poor Underserved. 1995;6(4):403-9. [pmid: 7495934].
Fried S. Bullies & victims: Children abusing children. Am J Dance Ther. 1997;19(2):127-33.
Friedman A S, Kramer S, Kreisher C. Childhood predictors of violent behavior. J Clin Psychol. 1999;55(7):843-55. [pmid: 10866020].
Friedman A S, Terras A, Glassman K. Multimodel substance use intervention program for male delinquents. J Child Adolesc Subst Abus. 2002;11(4):43-65.
Friedman AS, Utada AT. Effects of two group interaction models on substance-using adjudicated adolescent males. J Community Psychol 1992:106–17.
Fritsch E J, Caeti T J, Taylor R W. Gang suppression through saturation patrol, aggressive curfew and truancy enforcement: A quasi-experimental test of the Dallas anti-gang initiative. Crime Delinq. 1999;45(1):122-39.
Fritsch R C, Heinssen R K, Delga I, et al. Predicting hospital adjustment by adolescent inpatients. Hosp Community Psychiatry. 1992;43(1):49-53. [pmid: 1544647].
Fromuth M E, Burkhart B R, Jones C W. Hidden child molestation: An investigation of adolescent perpetrators in a nonclinical sample. J Interpers Violence. 1991;6(3):376-84.
Frydman M. Television, aggressiveness and violence. Int J Adolesc Med Health. 1999;11(34):335-44.
Frye V, Wilt S. Femicide and social disorganization. Violence Against Women. 2001;7(3):335-51.
Fulginiti V A. Violence and children in the United States. Am J Dis Child. 1992;146(6):671-2. [pmid: 1595621].
Fulwiler C, Grossman H, Forbes C, et al. Early-onset substance abuse and community violence by outpatients with chronic mental illness. Psychiatr Serv. 1997;48(9):1181-5. [pmid: 9285980].
Fulwiler C, Ruthazer R. Premorbid risk factors for violence in adult mental illness. Compr Psychiatry. 1999;40(2):96-100. [pmid: 10080255].
Funk J B, Hagan J, Schimming J, et al. Aggression and psychopathology in adolescents with a preference for violent electronic games. Aggress Behav. 2002;28(2):134-44.
Furlong M, Casas J M, Corral C, et al. Drugs and school violence. Educ Treat Child. 1997;20(3):263-80.
Gabel S, Shindledecker R. Aggressive behavior in youth: characteristics, outcome, and psychiatric diagnoses. J Am Acad Child Adolesc Psychiatry. 1991;30(6):982-8. [pmid: 1757448].
Gabel S, Shindledecker R. Behavior problems in sons and daughters of substance abusing parents. Child Psychiatry Hum Dev. 1992;23(2):99-115. [pmid: 1490400].
Gabel S, Shindledecker R. Adolescent psychiatric inpatients: Characteristics, outcome, and comparison between discharged patients from a specialized adolescent unit and nonspecialized units. J Youth Adolesc. 1992;21(4):391-407.
Gabel S, Shindledecker R. Parental substance abuse and its relationship to severe aggression and antisocial behavior in youth. Am J Addict. 1993;2(1):48-58.
Gabel S, Swanson A J, Shindledecker R. Aggressive children in a day treatment program: Changed outcome and possible explanations. Child Abuse Negl. 1990;14(4):515-23. [pmid: 2289182].
Gabriel R M, Hopson T, Haskins M, et al. Building relationships and resilience in the prevention of youth violence. Am J Prev Med. 1996;12(5 Suppl):48-55. [pmid: 8909624].
Gadow K D, Nolan E E, Sverd J. Methylphenidate in hyperactive boys with comorbid tic disorder: II. Short-term behavioral effects in school settings. J Am Acad Child Adolesc Psychiatry. 1992;31(3):462-71. [pmid: 1592778].
Gadow K D, Nolan E E, Sverd J, et al. Methylphenidate in aggressive-hyperactive boys: I. Effects on peer aggression in public school settings. J Am Acad Child Adolesc Psychiatry. 1990;29(5):710-8. [pmid: 2228923].
Gaertner L, Foshee V. Commitment and the perpetration of relationship violence. Pers Relatsh. 1999;6(2):227-39.
Gagne M-H, Lavoie F. Young people's views on the causes of violence in adolescents' romantic relationships. Can Ment Health. 1993;41(3):11-5.
Gainer P S, Webster D W, Champion H R. A youth violence prevention program. Description and preliminary evaluation. Arch Surg. 1993;128(3):303-8. [pmid: 8442687].
Gardner W, Lidz C W, Mulvey E P, et al. Clinical versus actuarial predictions of violence of patients with mental illnesses. J Consult Clin Psychol. 1996;64(3):602-9. [pmid: 8698955].
Garnefski N, Okma S. Addiction-risk and aggressive/criminal behavior in adolescence: Influence of family, school and peers. J Adolesc. 1996;19(6):503-12. [pmid: 9245302].
Garrison J, Barry VJ. Family violence. J Am Dent Assoc 1994;125(4):360, 2.
Garrison W T, Ecker B, Friedman M, et al. Aggression and counteraggression during child psychiatric hospitalization. J Am Acad Child Adolesc Psychiatry. 1990;29(2):242-50. [pmid: 2324065].
Gartner R. Family structure, welfare spending, and child homicide in developed democracies. J Marriage Fam. 1991;53:231-40.
Gartstein M A, Noll R B, Vannatta K. Childhood aggression and chronic illness: Possible protective mechanisms. J Appl Dev Psychol. 2000;21(3):315-33.
Garvey K, et al. Alliance working to stop youth violence. WMJ. 2002;101(6):22-3. [pmid: 12355964].
Gelles R J. Poverty and violence toward children. Am Behav Sci. 1992;35(3):258-74.
Gentry J, Eron L D. American Psychological Association Commission on Violence and Youth. Am Psychol. 1993;48(2):89. [pmid: 8442577].
Gerra G, Zaimovic A, Ampollini R, et al. Experimentally induced aggressive behavior in subjects with 3,4-methylenedioxy-methamphetamine (“Ecstasy”) use history: psychobiological correlates. J Subst Abuse. 2001;13(4):471-91. [pmid: 11775077].
Gerstein L H, Briggs J R. Psychological and sociological discriminants of violent and nonviolent serious juvenile offenders. J Addict Offender Couns. 1993;14(1):2-13.
Giancola P R, Martin C S, Tarter R E, et al. Executive cognitive functioning and aggressive behavior in preadolescent boys at high risk for substance abuse/dependence. J Stud Alcohol. 1996;57(4):352-9. [pmid: 8776676].
Giancola P R, Mezzich A C. Executive cognitive functioning mediates the relation between language competence and antisocial behavior in conduct-disordered adolescent females. Aggress Behav. 2000;26(5):359-75.
Giancola P R, Mezzich A C, Clark D B, et al. Cognitive distortions, aggressive behavior, and drug use in adolescent boys with and without a family history of a substance use disorder. Psychol Addict Behav. 1999;13(1):22-32.
Giancola P R, Mezzich A C, Tarter R E. Disruptive, delinquent and aggressive behavior in female adolescents with a psychoactive substance use disorder: relation to executive cognitive functioning. J Stud Alcohol. 1998;59(5):560-7. [pmid: 9718109].
Giancola P R, Mezzich A C, Tarter R E. Executive cognitive functioning, temperament, and antisocial behavior in conduct-disordered adolescent females. J Abnorm Psychol. 1998;107(4):629-41. [pmid: 9830250].
Giancola P R, Moss H B, Martin C S, et al. Executive cognitive functioning predicts reactive aggression in boys at high risk for substance abuse: A prospective study. Alcoholism: Clinical & Experimental Research. 1996;20(4):740-4.
Giancola P R, Parker A M. A six-year prospective study of pathways toward drug use in adolescent boys with and without a family history of a substance use disorder. J Stud Alcohol. 2001;62(2):166-78. [pmid: 11327183].
Giancola P R, Shoal G D, Mezzich A C. Constructive thinking, executive functioning, antisocial behavior, and drug use involvement in adolescent females with a substance use disorder. Exp Clin Psychopharmacol. 2001;9(2):215-27. [pmid: 11518098].
Gierowski J K. The influence of the type and level of aggression on homicidal behavior. Psychiatr Pol. 1996;30(3, Suppl):27-37.
Ginsberg C. Violence-related attitudes and behaviors of high school students--New York City, 1992. MMWR Morb Mortal Wkly Rep. 1993;42(40):773-7. [pmid: 8413162].
Ginsberg C. Violence-related attitudes and behaviors of high school students--New York City, 1992. J Sch Health. 1993;63(10):438-40. [pmid: 8133649].
Giordano P C, Cernkovich S A, Groat H T, et al. The quality of adolescent friendships: long-term effects?. J Health Soc Behav. 1998;39(1):55-71. [pmid: 9575704].
Giordano P C, Millhollin T J, Cernkovich S A. Delinquency, identity, and women's involvement in relationship violence. Criminology. 1999;37(1):17-40.
Giuliano J D. A peer education program to promote the use of conflict resolution skills among at-risk school age males. Public Health Rep. 1994;109(2):158-61. [pmid: 8153266]. [pmcid: 1403470].
Gjone H, Stevenson J. A longitudinal twin study of temperament and behavior problems: Common genetic or environmental influences?. J Am Acad Child Adolesc Psychiatry. 1997;36(10):1448-56. [pmid: 9334559].
Glod C A, Teicher M H, Butler M, et al. Modifying quiet room design enhances calming of children and adolescents. J Am Acad Child Adolesc Psychiatry. 1994;33(4):558-66. [pmid: 8005909].
Goddard H W, Goff B G, Melancon M V, et al. Profiles of delinquency: A comparison of delinquent behavioral groups. J Soc Behav Pers. 2000;15(1):19-50.
Goetting A. Child victims of homicide: a portrait of their killers and the circumstances of their deaths. Violence Vict. 1990;5(4):287-96. [pmid: 2098092].
Goetting A. Female victims of homicide: a portrait of their killers and the circumstances of their deaths. Violence Vict. 1991;6(2):159-68. [pmid: 1742242].
Goldstein A P, Glick B. Aggression replacement training: Curriculum and evaluation. Simul Gaming. 1994;25(1):9-26.
Goodman G, Hull J W, Clarkin J F, et al. Childhood antisocial behaviors as predictors of psychotic symptoms and DSM-III-R borderline criteria among inpatients with borderline personality disorder. J Personal Disord. 1999;13(1):35-46. [pmid: 10228925].
Goodwin M P, Roscoe B. Sibling violence and agonistic interactions among middle adolescents. Adolescence. 1990;25(98):451-67. [pmid: 2375271].
Goren S, Singh N N, Best A M. The aggression-coercion cycle: Use of seclusion and restraint in a child psychiatric hospital. J Child Fam Stud. 1993;2(1):61-73.
Gorenstein E E. Neuropsychology of juvenile delinquency. Forensic Rep. 1990;3(1):15-48.
Gorman-Smith D, Tolan P. The role of exposure to community violence and developmental problems among inner-city youth. Dev Psychopathol. 1998;10(1):101-16. [pmid: 9524810].
Gorman-Smith D, Tolan P H, Sheidow A J, et al. Partner violence and street violence among urban adolescents: Do the same family factors relate?. J Res Adolesc. 2001;11(3):273-95.
Gorman-Smith D, Tolan P H, Zelli A, et al. The relation of family functioning to violence among inner-city minority youths. J Fam Psychol. 1996;10(2):115-29.
Gover A R. The effects of child maltreatment on violent offending among institutionalized youth. Violence Vict. 2002;17(6):655-68. [pmid: 12680681].
Graham S, Hudley C, Williams E. Attributional and emotional determinants of aggression among African-American and Latino young adolescents. Dev Psychol. 1992;28(4):731-40.
Graham-Bermann S A, Cutler S E, Litzenberger B W, et al. Perceived conflict and violence in childhood sibling relationships and later emotional adjustment. J Fam Psychol. 1994;8(1):85-97.
Grange J T, Corbett S W. Violence against emergency medical services personnel. Prehosp Emerg Care. 2002;6(2):186-90. [pmid: 11962565].
Granger D A, Weisz J R, McCracken J T, et al. Testosterone and conduct problems. J Am Acad Child Adolesc Psychiatry. 1994;33(6):908. [pmid: 8083150].
Granic I, Butler S. The relation between anger and antisocial beliefs in young offenders. Pers Individ Dif. 1998;24(6):759-65.
Granic I, Dishion T J. Deviant talk in adolescent friendships: A step toward measuring a pathogenic attractor process. Soc Dev. 2003;12(3):314-34.
Grann M. The PCL-R and gender. Eur J Psychol Assess. 2000;16(3):147-9.
Gray C, Chisholm D, Smith P, et al. The role of the child psychiatric ward in health care: Experiences with different types of admissions over a period of twenty-one years. Ir J Psychol Med. 1992;9(1):17-23.
Gray H M, Foshee V. Adolescent dating violence: Differences between one-sided and mutually violent profiles. J Interpers Violence. 1997;12(1):126-41.
Greco C M, Cornell D G. Rorschach object relations of adolescents who committed homicide. J Pers Assess. 1992;59(3):574-83. [pmid: 1487810].
Greenberg D M, Bradford J M, Curry S. A comparison of sexual victimization in the childhoods of pedophiles and hebephiles. J Forensic Sci. 1993;38(2):432-6. [pmid: 8455000].
Greene LW, Smith MS, Peters SR. “I have a future” comprehensive adolescent health promotion: cultural considerations in program implementation and design. J Health Care Poor Underserved 1995;6(2):267–81; Discussion 82–3.
Gretton H M, McBride M, Hare R D, et al. Psychopathy and recidivism in adolescent sex offenders. Crim Justice Behav. 2001;28(4):427-49.
Grietens H, Rink J, Hellinckx W. Nonbehavioral correlates of juvenile delinquency: Communications of detained and nondetained young people about social limits. J Adolesc Res. 2003;18(1):68-89.
Griffin K W, Botvin G J, Scheier L M, et al. Parenting practices as predictors of substance use, delinquency, and aggression among urban minority youth: Moderating effects of family structure and gender. Psychol Addict Behav. 2000;14(2):174-84. [pmid: 10860116].
Griffin K W, Scheier L M, Botvin G J, et al. Interpersonal aggression in urban minority youth: Mediators of perceived neighborhood, peer, and parental influences. J Community Psychol. 1999;27(3):281-98.
Grimm K T. Violence against infants. Mt Sinai J Med. 1996;63(2):101-2. [pmid: 8775139].
Grisso J A, Schwarz D F, Hirschinger N, et al. Violent injuries among women in an urban area. N Engl J Med. 1999;341(25):1899-905. [pmid: 10601510].
Grizenko N, Pawliuk N. Risk and protective factors for disruptive behavior disorders in children. Am J Orthopsychiatry. 1994;64(4):534-44. [pmid: 7847569].
Groebel J. Media violence and children. Educ Media Int. 1998;35(3):216-27.
Grossman L S, Haywood T W, Cavanaugh J L, et al. State psychiatric hospital patients with past arrests for violent crimes. Psychiatr Serv. 1995;46(8):790-5. [pmid: 7583479].
Gruber E, DiClemente R J, Anderson M M, et al. Early drinking onset and its association with alcohol use and problem behavior in late adolescence. Prev Med. 1996;25(3):293-300. [pmid: 8781007].
Grunbaum J A, Basen-Engquist K. Comparison of health risk behaviors between students in a regular high school and students in an alternative high school. J Sch Health. 1993;63(10):421-5. [pmid: 8133645].
Grunbaum J A, Basen-Engquist K, Pandey D. Association between violent behaviors and substance use among Mexican-American and non-Hispanic white high school students. J Adolesc Health. 1998;23(3):153-9. [pmid: 9730358].
Grunbaum J A, Kann L, Kinchen S A, et al. Youth risk behavior surveillance--United States, 2001. J Sch Health. 2002;72(8):313-28. [pmid: 12389372].
Grunbaum J A, Lowry R, Kann L. Prevalence of health-related behaviors among alternative high school students as compared with students attending regular high schools. J Adolesc Health. 2001;29(5):337-43. [pmid: 11691595].
Guagliardo M F, Huang Z, D'Angelo L J. Fathering pregnancies: marking health-risk behaviors in urban adolescents. J Adolesc Health. 1999;24(1):10-5. [pmid: 9890359].
Guarnaccia V, Curry K. Contingent reinforcement effects on movement responses of prison inmates to the Holtzman Inkblot Technique. J Pers Assess. 1990;55(12):263-9. [pmid: 2231246].
Guerra N G. Violence prevention. Prev Med. 1994;23(5):661-4. [pmid: 7845935].
Guerra N G, Huesmann L R, Tolan P H, et al. Stressful events and individual beliefs as correlates of economic disadvantage and aggression among urban children. J Consult Clin Psychol. 1995;63(4):518-28. [pmid: 7673529].
Guerra N G, Huesmann L R, Zelli A. Attributions for social failure and aggression in incarcerated delinquent youth. J Abnorm Child Psychol. 1990;18(4):347-55. [pmid: 2246428].
Guerra N G, Huesmann L R, Zelli A. Attributions for social failure and adolescent aggression. Aggress Behav. 1993;19(6):421-34.
Guilleminault C, Moscovitch A, Leger D. Forensic sleep medicine: nocturnal wandering and violence. Sleep. 1995;18(9):740-8. [pmid: 8638066].
Gundersen L. Intimate-partner violence: the need for primary prevention in the community. Ann Intern Med. 2002;136(8):637-40. [pmid: 11955043].
Gupta V B, Nwosa N M, Nadel T A, et al. Externalizing behaviors and television viewing in children of low-income minority parents. Clin Pediatr (Phila). 2001;40(6):337-41. [pmid: 11824177].
Guterman N B, Cameron M, Hahm H C. Community violence exposure and associated behavior problems among children and adolescents in residential treatment. J Aggress Maltreat Trauma. 2003;6(2):111-35.
Haapasalo J, Hamalainen T. Childhood family problems and current psychiatric problems among young violent and property offenders. J Am Acad Child Adolesc Psychiatry. 1996;35(10):1394-401. [pmid: 8885594].
Haapasalo J, Kankkonen M. Self-reported childhood abuse among sex and violent offenders. Arch Sex Behav. 1997;26(4):421-31. [pmid: 9251838].
Haapasalo J, Tremblay R E. Physically aggressive boys from ages 6 to 12: Family background, parenting behavior, and prediction of delinquency. J Consult Clin Psychol. 1994;62(5):1044-52. [pmid: 7806713].
Haemaelaeinen M, Pulkkinen L. Aggressive and non-prosocial behaviour as precursors of criminality. Stud Crime Crime Prev. 1995;4(1):6-21.
Haemaelaeinen M, Pulkkinen L. Problem behavior as a precursor of male criminality. Dev Psychopathol. 1996;8(2):443-55.
Hagan M P. An analysis of adolescent perpetrators of homicide and attempted homicide upon return to the community. Int J Offender Ther Comp Criminol. 1997;41:250-9.
Hagan M P, Cho M E. A comparison of treatment outcomes between adolescent rapists and child sexual offenders. Int J Offender Ther Comp Criminol. 1996;40(2):113-22.
Hagan M P, Cho M E, Jensen J A, et al. An assessment of the effectiveness of an intensive treatment program for severely mentally disturbed juvenile offenders. Int J Offender Ther Comp Criminol. 1997;41(4):340-50.
Hagan M P, Gust-Brey K L. A ten-year longitudinal study of adolescent rapists upon return to the community. Int J Offender Ther Comp Criminol. 1999;43(4):448-58.
Hagan M P, Gust-Brey K L. A ten-year longitudinal study of adolescent perpetrators of sexual assault against children. J Offender Rehabil. 2000;31(12):117-26.
Hagan M P, Gust-Brey K L, Cho M E. Eight-year comparative analyses of adolescent rapists, adolescent child molesters, other adolescent delinquents, and the general population. Int J Offender Ther Comp Criminol. 2001;45(3):314-24.
Hagan M P, Gust-Brey K L, Cho M E, et al. Eight-year comparative analyses of adolescent rapists, adolescent child molesters, other adolescent delinquents, and the general population. Int J Offender Ther Comp Criminol. 2001;45(3):314-24.
Hagan M P, King R P, Patros R L. Recidivism among adolescent perpetrators of sexual assault against children. J Offender Rehabil. 1994;21(12):127-37.
Hagan M P, King R P, Patros R L. The efficacy of a serious sex offenders treatment program for adolescent rapists. Int J Offender Ther Comp Criminol. 1994;38(2):141-50.
Hagan M P, King S L. Dx = extremely dangerous: Prognostic validity for future violence. J Offender Rehabil. 1998;27(12):23-35.
Hailer J A, Hart C B. A new breed of warrior: The emergence of American Indian youth gangs. J Gang Res. 1999;7(1):23-33.
Hallberg J. Boys and their toys. Minn Med. 2000;83(9):14-7. [pmid: 11059250].
Halliday-Boykins C A, Graham S. At both ends of the gun: testing the relationship between community violence exposure and youth violent behavior. J Abnorm Child Psychol. 2001;29(5):383-402. [pmid: 11695541].
Halperin J M, McKay K E, Newcorn J H. Development, reliability, and validity of the children's aggression scale-parent version. J Am Acad Child Adolesc Psychiatry. 2002;41(3):245-52. [pmid: 11886018].
Halperin J M, Newcorn J H, Matier K, et al. Impulsivity and the initiation of fights in children with disruptive behavior disorders. J Child Psychol Psychiatry. 1995;36(7):1199-211. [pmid: 8847380].
Halpern C T, Udry J R, Campbell B, et al. Relationships between aggression and pubertal increases in testosterone: A panel analysis of adolescent males. Soc Biol. 1993;40(12):8-24. [pmid: 8146696].
Halpern R. The role of after-school programs in the lives of inner-city children: a study of the “urban youth network”. Child Welfare. 1992;71(3):215-30. [pmid: 1606847].
Hammett M, Powell K E, O'Carroll P W, et al. Homicide surveillance--United States, 1979-1988. MMWR CDC Surveill Summ. 1992;41(3):1-33. [pmid: 1635547].
Hammig B J, Dahlberg L L, Swahn M H. Predictors of injury from fighting among adolescent males. Inj Prev. 2001;7(4):312-5. [pmid: 11770658].
Hammock G, O'Hearn R. Psychological aggression in dating relationships: predictive models for males and females. Violence Vict. 2002;17(5):525-40. [pmid: 12477096].
Hammond W R, Yung B R. Preventing violence in at-risk African-American youth. J Health Care Poor Underserved. 1991;2(3):359-73. [pmid: 1772948].
Hanlon T E, Bateman R W, Simon B D, et al. An early community-based intervention for the prevention of substance abuse and other delinquent behavior. J Youth Adolesc. 2002;31(6):459-71.
Hanna G L, Yuwiler A, Coates J K. Whole blood serotonin and disruptive behaviors in juvenile obsessive-compulsive disorder. J Am Acad Child Adolesc Psychiatry. 1995;34(1):28-35. [pmid: 7860453].
Hannon L. AFDC and homicide. J Sociol Soc Welf. 1997;24(4):125-36.
Hannon L, DeFronzo J, Prochnow J. Moral commitment and the effects of social influences on violent delinquency. Violence Vict. 2001;16(4):427-39. [pmid: 11506451].
Hanson R F. Adolescent dating violence: prevalence and psychological outcomes. Child Abuse Negl. 2002;26(5):449-53. [pmid: 12079083].
Hanson R K, Bussiere M T. Predicting relapse: a meta-analysis of sexual offender recidivism studies. J Consult Clin Psychol. 1998;66(2):348-62. [pmid: 9583338].
Harden P W, Pihl R O, Vitaro F, et al. Stress response in anxious and nonanxious disruptive boys. J Emot Behav Disord. 1995;3(3):183-90.
Hardy M S. Physical aggression and sexual behavior among siblings: A retrospective study. J Fam Violence. 2001;16(3):255-68.
Harmon-Jones E, Barratt E S, Wigg C. Impulsiveness, aggression, reading, and the P300 of the event-related potential. Pers Individ Dif. 1997;22(4):439-45.
Harper G W, Robinson W L. Pathways to risk among inner-city African-American adolescent females: the influence of gang membership. Am J Community Psychol. 1999;27(3):383-404. [pmid: 10492881].
Harrington N G, Giles S M, Hoyle R H, et al. Evaluation of the All Stars character education and problem behavior prevention program: effects on mediator and outcome variables for middle school students. Health Educ Behav. 2001;28(5):533-46. [pmid: 11575684].
Harris P. The nature and extent of aggressive behaviour amongst people with learning difficulites (mental handicap) in a single health district. J Intellect Disabil Res. 1993;37(3):221-4. [pmid: 8334316].
Harrison L D, Erickson P G, Adlaf E, et al. The drugs-violence nexus among American and Canadian youth. Subst Use Misuse. 2001;36(14):2065-86. [pmid: 11794584].
Harrison P A, Luxenberg M G. Comparisons of alcohol and other drug problems among Minnesota adolescents in 1989 and 1992. Arch Pediatr Adolesc Med. 1995;149(2):137-44. [pmid: 7849874].
Harry B, Pierson T R, Kuznetsov A. Correlates of sex offender and offense traits by victim age. J Forensic Sci. 1993;38(5):1068-74. [pmid: 8228878].
Harty-Golder B. Domestic violence. J Fla Med Assoc. 1994;81(10):697-8. [pmid: 7861112].
Hartz D T. Comparative conflict resolution patterns among parent-teen dyads of four ethnic groups in Hawaii. Child Abuse Negl. 1995;19(6):681-9. [pmid: 7552837].
Hastings T L, Kelley M L. Development and validation of the Screen for Adolescent Violence Exposure (SAVE). J Abnorm Child Psychol. 1997;25(6):511-20. [pmid: 9468111].
Hausman A, Pierce G, Briggs L. Evaluation of comprehensive violence prevention education: effects on student behavior. J Adolesc Health. 1996;19(2):104-10. [pmid: 8863081].
Hausman A J, Spivak H, Prothrow-Stith D. Adolescents' knowledge and attitudes about and experience with violence. J Adolesc Health. 1994;15(5):400-6. [pmid: 7947855].
Hawke J M, Jainchill N, De Leon G. Posttreatment victimization and violence among adolescents following residential drug treatment. Child Maltreat. 2003;8(1):58-71. [pmid: 12568505].
Hawke J M, Jainchill N, De Leon G. Posttreatment victimization and violence among adolescents following residential drug treatment. Child Maltreat. 2003;8(1):58-71. [pmid: 12568505].
Hawkins J D, Catalano R F, Kosterman R, et al. Preventing adolescent health-risk behaviors by strengthening protection during childhood. Arch Pediatr Adolesc Med. 1999;153(3):226-34. [pmid: 10086398].
Hawkins S R, Campanaro A, Pitts T B, et al. Weapons in an affluent suburban school. J Sch Violence. 2002;1(1):53-65.
Haynes N M. Creating safe and caring school communities: Comer School Development Program schools. J Negro Educ. 1996;65(3):308-14.
Haynie D L, Alexander C, Walters S R. Considering a decision-making approach to youth violence prevention programs. J Sch Health. 1997;67(5):165-70. [pmid: 9210100].
Haynie D L, Nansel T, Eitel P, et al. Bullies, victims, and bully/victims: Distinct groups of at-risk youth. J Early Adolesc. 2001;21(1):29-49.
Heads T C, Taylor P J, Leese M. Childhood experiences of patients with schizophrenia and a history of violence: A special hospital sample. Crim Behav Ment Health. 1997;7(2):117-30.
Heath E, Kosky R. Are children who steal different from those who are aggressive?. Child Psychiatry Hum Dev. 1992;23(1):9-18. [pmid: 1424943].
Heath L, Kruttschnitt C, Ward D. Television and violent criminal behavior: beyond the Bobo doll. Violence Vict. 1986;1(3):177-90. [pmid: 3154148].
Heaven P C L. Personality and self-reported delinquency: Analysis of the “Big Five” personality dimensions. Pers Individ Dif. 1996;20(1):47-54.
Heck C, Walsh A. The effects of maltreatment and family structure on minor and serious delinquency. Int J Offender Ther Comp Criminol. 2000;44(2):178-93.
Heide K M. Weapons used by juveniles and adults to kill parents. Behav Sci Law. 1993;11(4):397-405.
Heide K M. Parents who get killed and the children who kill them. J Interpers Violence. 1993;8(4):531-44.
Heide K M, Spencer E, Thompson A, et al. Who's in, who's out, and who's back: follow-up data on 59 juveniles incarcerated in adult prison for murder or attempted murder in the early 1980s. Behav Sci Law. 2001;19(1):97-108. [pmid: 11241683].
Heimer K. Socioeconomic status, subcultural definitions, and violent delinquency. Soc Forces. 1997;75(3):799-833.
Hemenway D. Lethal violence in the schools. J Health Polit Policy Law. 2002;27(2):267-71. [pmid: 12043899].
Hemmings A. Youth culture of hostility: Discourses of money, respect, and difference. Int J Qual Stud Educ. 2002;15(3):291-307.
Hendricks-Matthews M K. A survey on violence education: a report of the STFM Violence Education Task Force. Fam Med. 1991;23(3):194-7. [pmid: 2016010].
Hendrix K, Molloy P J. Forum on youth violence in minority communities. Interventions in early childhood. Public Health Rep. 1991;106(3):275-6. [pmid: 1905047].
Henggeler S W, Clingempeel W G, Brondino M J, et al. Four-year follow-up of multisystemic therapy with substance-abusing and substance-dependent juvenile offenders. J Am Acad Child Adolesc Psychiatry. 2002;41(7):868-74. [pmid: 12108813].
Henggeler S W, Melton G B, Brondino M J, et al. Multisystemic therapy with violent and chronic juvenile offenders and their families: The role of treatment fidelity in successful dissemination. J Consult Clin Psychol. 1997;65(5):821-33. [pmid: 9337501].
Henggeler S W, Melton G B, Smith L A, et al. Assessing violent offending in serious juvenile offenders. J Abnorm Child Psychol. 1993;21(3):233-43. [pmid: 8335762].
Hennes H. A review of violence statistics among children and adolescents in the United States. Pediatr Clin North Am. 1998;45(2):269-80. [pmid: 9568008].
Henry B, Others A. Temperamental and familial predictors of violent and nonviolent criminal convictions: Age 3 to age 18. Dev Psychol. 1996;32(4):614-23.
Henry D B, Tolan P H, Gorman-Smith D. Longitudinal family and peer group effects on violence and nonviolent delinquency. J Clin Child Psychol. 2001;30(2):172-86. [pmid: 11393918].
Herkimer County Rural Health Network. Communities that care: Identifying risk and protective factors that impact youth behaviors. Accessed: May 2004. http://www.herkimerhealthnet.com/dprofile/pdf/dprofile/CommunitiesThatCare.pdf.
Herkov M J, Gynther M D, Thomas S, et al. MMPI differences among adolescent inpatients, rapists, sodomists, and sexual abusers. J Pers Assess. 1996;66(1):81-90. [pmid: 8576837].
Hernandez J T, Lodico M, DiClemente R J. The effects of child abuse and race on risk-taking in male adolescents. J Natl Med Assoc. 1993;85(8):593-7. [pmid: 8371280].
Herrenkohl R C, Egolf B P, Herrenkohl E C. Preschool antecedents of adolescent assaultive behavior: a longitudinal study. Am J Orthopsychiatry. 1997;67(3):422-32. [pmid: 9250343].
Herrenkohl R C, Egolf B P, Herrenkohl E C. Preschool antecedents of adolescent assaultive behavior: a longitudinal study. Am J Orthopsychiatry. 1997;67:422-32. [pmid: 9250343].
Herrenkohl T I, Guo J, Kosterman R, et al. Early adolescent predictors of youth violence as mediators of childhood risks. J Early Adolesc. 2001;21(4):447-69.
Herrenkohl T I, Hill K G, Chung I-J, et al. Protective factors against serious violent behavior in adolescence: A prospective study of aggressive children. Soc Work Res. 2003;27(3):179-91.
Herrenkohl T I, Huang B, Kosterman R, et al. A comparison of social development processes leading to violent behavior in late adolescence for childhood initiators and adolescent initiators of violence. J Res Crime Delinq. 2001;38(1):45-63.
Herrenkohl T I, Huang B, Tajima E A, et al. Examining the link between child abuse and youth violence: An analysis of mediating mechanisms. J Interpers Violence. 2003;18(10):1189-208. [pmid: 19771716].
Herrenkohl T I, Maguin E, Hill K G, et al. Developmental risk factors for youth violence. J Adolesc Health. 2000;26(3):176-86. [pmid: 10706165].
Herrera V M, McCloskey L A. Gender differences in the risk for delinquency among youth exposed to family violence. Child Abuse Negl. 2001;25(8):1037-51. [pmid: 11601596].
Herrera V M, McCloskey L A. Sexual abuse, family violence, and female delinquency: Findings from a longitudinal study. Violence Vict. 2003;18(3):319-34. [pmid: 12968661].
Herrmann D S, McWhirter J J. Anger & aggression management in young adolescents: An experimental validation of the SCARE program. Educ Treat Child. 2003;26(3):273-302.
Hess P. The gang's all here. Emerg Med Serv 1994;23(7):44–5, 7–54, 6.
Hickey D C. Public health and violence. J Tenn Med Assoc. 1994;87(5):197-8. [pmid: 8041162].
Hicks M M, Rogers R, Cashel M. Predictions of violent and total infractions among institutionalized male juvenile offenders. J Am Acad Psychiatry Law. 2000;28(2):183-90. [pmid: 10888186].
Hill S C, Drolet J C. School-related violence among high school students in the United States, 1993-1995. J Sch Health. 1999;69(7):264-72. [pmid: 10529964].
Hillbrand M, Spitz R T, Foster H G, et al. Creatine kinase elevations and aggressive behavior in hospitalized forensic patients. Psychiatr Q. 1998;69(1):69-82. [pmid: 9536476].
Hilton N Z, Harris G T, Rice M E. The functions of aggression by male teenagers. J Pers Soc Psychol. 2000;79(6):988-94. [pmid: 11138767].
Hinshaw S P, Melnick S M. Peer relationships in boys with attention-deficit hyperactivity disorder with and without comorbid aggression. Dev Psychopathol. 1995;7(4):627-47.
Hinton P M. Domestic violence. J Fla Med Assoc. 1996;83(3):211-2. [pmid: 8920057].
Hirose S, Ashby J, Charles R, Mills M J. Effectiveness of ECT combined with risperidone against aggression in schizophrenia. J ECT. 2001;17(1):22-6. [pmid: 11281510].
Hixon AL. Preventing street gang violence. Am Fam Physician 1999;59(8):2121–2, 5, 32.
Hobbie C. Violence prevention. J Pediatr Health Care. 1995;9(5):234-6. [pmid: 7562316].
Hodge S, Canter D. Victims and perpetrators of male sexual assault. J Interpers Violence. 1998;13(2):222-39.
Hodges K. Domestic violence--a health crisis. N C Med J. 1993;54(5):213-6. [pmid: 8510776].
Hodgins S, Lapalme M, Toupin J. Criminal activities and substance use of patients with major affective disorders and schizophrenia: a 2-year follow-up. J Affect Disord. 1999;55(23):187-202. [pmid: 10628888].
Hoekelman R A. Causes of death among the young. Pediatr Ann. 1992;21(7):407-8. [pmid: 1480432].
Holden G W, Ritchie K L. Linking extreme marital discord, child rearing, and child behavior problems: evidence from battered women. Child Dev. 1991;62(2):311-27. [pmid: 2055124].
Holmes S R, Brandenburg-Ayres S J. Bullying behavior in school: A predictor of later gang involvement. J Gang Res. 1998;5(2):1-6.
Honig J. Perceived health status in urban minority young adolescents. MCN Am J Matern Child Nurs. 2002;27(4):233-7. [pmid: 12131275].
Hoover J H, Oliver R, Hazler R J. Bullying: Perceptions of adolescent victims in the Midwestern USA. Sch Psychol Int. 1992;13(1):5-16.
Hops H, Davis B, Leve C, et al. Cross-generational transmission of aggressive parent behavior: A prospective, mediational examination. J Abnorm Child Psychol. 2003;31(2):161-9. [pmid: 12735398].
Horner R H, Day H M, Sprague J R, et al. Interspersed requests: a nonaversive procedure for reducing aggression and self-injury during instruction. J Appl Behav Anal. 1991;24(2):265-78. [pmid: 1890047]. [pmcid: 1279572].
Horton A. The prevention of juvenile delinquency: New evidence to consider. J Hum Behav Soc Environ. 1998;1(4):1-10.
Horton A. The prevention of school violence: New evidence to consider. J Hum Behav Soc Environ. 2001;4(1):49-59.
Horton A. Violent crime: New evidence to consider. J Hum Behav Soc Environ. 2002;5(2):77-88.
Howard D, Qiu Y, Boekeloo B. Personal and social contextual correlates of adolescent dating violence. J Adolesc Health. 2003;33(1):9-17. [pmid: 12834992].
Howard D E, Cross S I, Li X, et al. Parent-youth concordance regarding violence exposure: relationship to youth psychosocial functioning. J Adolesc Health. 1999;25(6):396-406. [pmid: 10608579].
Howard D E, Wang M Q. Risk profiles of adolescent girls who were victims of dating violence. Adolescence. 2003;38(149):1-14. [pmid: 14768995].
Howard P E. Protecting our most precious resource. Del Med J. 1997;69(7):327-8. [pmid: 9260382].
Howell A J, Reddon J R, Enns R A. Immediate antecedents to adolescents' offenses. J Clin Psychol. 1997;53(4):355-60. [pmid: 9169390].
Howell A J, Reddon J R, Enns R A. Immediate antecedents to adolescents' offenses. J Clin Psychol. 1997;53:355-60. [pmid: 9169390].
Hsu L G, Starzynski J. Adolescent rapists and adolescent child sexual assaulters. Int J Offender Ther Comp Criminol. 1990;34(1):23-30.
Huang B, Kosterman R, Catalano R F. Modeling mediation in the etiology of violent behavior in adolescence: a test of the social development model. Criminology. 2001;39(1):75-107.
Huang B, White H R, Kosterman R, et al. Developmental associations between alcohol and interpersonal aggression during adolescence. J Res Crime Delinq. 2001;38(1):64-83.
Huang D B, Cherek D R, Lane S D. Laboratory measurement of aggression in high school age athletes: Provocation in a nonsporting context. Psychol Rep. 1999;85(3, Pt 2 Spec Issue):1251-62. [pmid: 10710982].
Hubbard J A, Dodge K A, Cillessen A H N, et al. The dyadic nature of social information processing in boys' reactive and proactive aggression. J Pers Soc Psychol. 2001;80(2):268-80. [pmid: 11220445].
Hudley C, Friday J. Attributional bias and reactive aggression. Am J Prev Med. 1996;12(5 Suppl):75-81. [pmid: 8909627].
Huefner DS. Another point of the suspension and expulsion cases. Except Child 1991;57(4):360–4; Discussion 4–8.
Huesmann L R, Maxwell C D, Eron L, et al. Evaluating a cognitive/ecological program for the prevention of aggression among urban children. Am J Prev Med. 1996;12(5 Suppl):120-8. [pmid: 8909632].
Hughes S A, Deville C, Chalhoub M, et al. The Rorschach human anatomy response: Predicting sexual offending behavior in juveniles. J Psychiatry Law. 1992;20(3):313-33.
Hulley SB, Cummings SR, Browner WS, et al. Designing clinical research: an epidemiologic approach, second edition. Philadelphia, PA: Lippincott Williams & Wilkins; 2001.
Hunt G, Joe-Laidler K. Situations of violence in the lives of girl gang members. Health Care Women Int. 2001;22(4):363-84. [pmid: 11813785].
Hunter J A, Figueredo A J. The influence of personality and history of sexual victimization in the prediction of juvenile perpetrated child molestation. Behav Modif. 2000;24(2):241-63. [pmid: 10804682].
Hunter J A, Figueredo A J, Malamuth N M, et al. Juvenile sex offenders: Toward the development of a typology. Sex Abuse. 2003;15(1):27-48. [pmid: 12616927].
Hunter J A, Hazelwood R R, Slesinger D. Juvenile-perpetrated sex crimes: Patterns of offending and predictors of violence. J Fam Violence. 2000;15(1):81-93.
Hutchins J J. Prevention of handgun deaths. N J Med. 1990;87(4):283-5. [pmid: 2352656].
Hutchison I W, Hirschel J D, Pesackis C E. Family violence and police utilization. Violence Vict. 1994;9(4):299-313. [pmid: 7577758].
Hutton M. Violence in America. Reaching epidemic proportions. J Fla Med Assoc. 1995;82(10):667-8. [pmid: 7500077].
Hwang S D, Segal S P. Criminality of the mentally ill in sheltered care: are they more dangerous?. Int J Law Psychiatry. 1996;19(1):93-105. [pmid: 8929663].
Hyde C E, Harrower-Wilson C, Morris J. Violence, dissatisfaction and rapid tranquillisation in psychiatric intensive care. Psychiatr Bull R Coll Psychiatr. 1998;22(8):477-80.
Ialongo N S, Vaden-Kiernan N, Kellam S. Early peer rejection and aggression: Longitudinal relations with adolescent behavior. J Dev Phys Disabil. 1998;10(2):199-213.
Inciardi J A. The crack-violence connection within a population of hard-core adolescent offenders. NIDA Res Monogr. 1990;103:92-111. [pmid: 2096295].
Ireland J L. Do juveniles bully more than young offenders?. J Adolesc. 2002;25(2):155-68. [pmid: 12490184].
Ireland J L. Official records of bullying incidents among young offenders: what can they tell us and how useful are they?. J Adolesc. 2002;25(6):669-79. [pmid: 12490184].
Jackson C, Foshee V A. Violence-related behaviors of adolescents: Relations with responsive and demanding parenting. J Adolesc Res. 1998;13(3):343-59.
Jacobs W L, Kennedy W A, Meyer J B. Juvenile delinquents: A between-group comparison study of sexual and nonsexual offenders. Sex Abuse. 1997;9(3):201-17.
Jaffee S, Caspi A, Moffitt T E, et al. Why are children born to teen mothers at risk for adverse outcomes in young adulthood? Results from a 20-yr longitudinal study. Dev Psychopathol. 2001;13(2):377-97. [pmid: 11393652].
Jaffee S, Caspi A, Moffitt T E, et al. Why are children born to teen mothers at risk for adverse outcomes in young adulthood? Results from a 20-year longitudinal study. Dev Psychopathol. 2001;13(2):377-97. [pmid: 11393652].
Jagers R J, Mock L O. Culture and social outcomes among inner-city African American children: An Afrographic exploration. J Black Psychol. 1993;19(4):391-405.
James E. Royal Society of Medicine: the roots of violence in children and young people. Med Confl Surviv. 1999;15(4):420-2. [pmid: 10605390].
James W H, West C, Deters K E, et al. Youth dating violence. Adolescence. 2000;35(139):455-65. [pmid: 11130591].
Jamieson S, Marshall W L. Attachment styles and violence in child molesters. J Sex Aggress. 2000;5(2):88-98.
Jarjoura G R, May D C. Integrating criminological theories to explain violent forms of delinquency. Caribb J Criminol Soc Psychol. 2000;5(12):81-102.
Jasinski J L. Physical violence among Anglo, African American, and Hispanic couples: Ethnic differences in persistence and cessation. Violence Vict. 2001;16(5):479-90. [pmid: 11688924].
Jenkins P H. School delinquency and the school social bond. J Res Crime Delinq. 1997;34:337-67.
Jenkins R S. Enhancing violence prevention in at-risk youth. J Health Care Poor Underserved. 1992;3(2):270-1. [pmid: 1420664].
Jenson J M, Howard M O. Youth crime, public policy, and practice in the juvenile justice system: recent trends and needed reforms. Soc Work. 1998;43(4):324-34. [pmid: 9663002].
Johnson C C, Myers L, Webber L S, et al. Assertiveness and cardiovascular disease risk factors in children and adolescents: The Bogalusa heart study. J Soc Behav Pers. 1997;12(1):243-55.
Johnson J G, Cohen P, Smailes E, et al. Adolescent personality disorders associated with violence and criminal behavior during adolescence and early adulthood. Am J Psychiatry. 2000;157(9):1406-12. [pmid: 10964855].
Johnson J G, Cohen P, Smailes E M, et al. Television viewing and aggressive behavior during adolescence and adulthood. Science. 2002;295(5564):2468-71. [pmid: 11923542].
Johnson S D. The social context of youth violence: A study of African American youth. Int J Adolesc Med Health. 1999;11(34):159-75.
Jones T S, Bodtker A M. Conflict education in a special needs population. Mediat Q. 1999;17(2):109-24.
Jonson-Reid M, Barth R P. From maltreatment report to juvenile incarceration: the role of child welfare services. Child Abuse Negl. 2000;24(4):505-20. [pmid: 10798840].
Jonson-Reid M, Barth R P. From placement to prison: the path to adolescent incarceration from child welfare supervised foster or group care. Child Youth Serv Rev. 2000;22(7):493-516.
Jonson-Reid M, Bivens L. Foster youth and dating violence. J Interpers Violence. 1999;14(12):1249-62.
Jonson-Reid M, Williams J H, Webster D. Severe emotional disturbance and violent offending among incarcerated adolescents. Soc Work Res. 2001;25(4):213-22.
Jordan E, Cowan A, Roberts J. Knowing the rules: Discursive strategies in young children's power struggles. Early Child Res Q. 1995;10(3):339-58.
Joshi P, Hamel L, Joshi A R T, et al. Use of droperidol in hospitalized children. J Am Acad Child Adolesc Psychiatry. 1998;37(2):228-30. [pmid: 9473921].
Jossi F. Stopping the violence. Healthplan. 1998;39(3):95-100. [pmid: 10181757].
Jouriles E N, Norwood W D, McDonald R, et al. Physical violence and other forms of marital aggression: Links with children's behavior problems. J Fam Psychol. 1996;10(2):223-34.
Kang S Y, Magura S, Shapiro J L. Correlates of cocaine/crack use among inner-city incarcerated adolescents. Am J Drug Alcohol Abuse. 1994;20(4):413-29. [pmid: 7832177].
Kann L, Kinchen S A, Williams B I, et al. Youth risk behavior surveillance--United States, 1999. State and local YRBSS coordinators. J Sch Health. 2000;70(7):271-85. [pmid: 10981282].
Kann L, Kinchen S A, Williams B I, et al. Youth risk behavior surveillance--United States, 1999. MMWR CDC Surveill Summ. 2000;49(5):1-32. [pmid: 12412614].
Kann L, Kinchen S A, Williams B I, et al. Youth risk behavior surveillance--United States, 1997. State and local YRBSS coordinators. J Sch Health. 1998;68(9):355-69. [pmid: 9854692].
Kann L, Kinchen S A, Williams B I, et al. Youth risk behavior surveillance--United States, 1997. MMWR CDC Surveill Summ. 1998;47(3):1-89. [pmid: 9750562].
Kann L, Warren C W, Harris W A, et al. Youth risk behavior surveillance--United States, 1995. J Sch Health. 1996;66(10):365-77. [pmid: 8981266].
Kann L, Warren W, Collins J L, et al. Results from the national school-based 1991 Youth Risk Behavior Survey and progress toward achieving related health objectives for the nation. Public Health Rep. 1993;108(Suppl 1):47-67. [pmid: 8210275]. [pmcid: 1403309].
Kaplan G A, Pamuk E R, Lynch J W, et al. Inequality in income and mortality in the United States: analysis of mortality and potential pathways. BMJ. 1996;312(7037):999-1003. [pmid: 8616393].
Kaplan H B, Peck B M. Self-rejection, coping style, and mode of deviant response. Soc Sci Q. 1992;73(4):903-19.
Kaplan H B, Tolle G C J, Yoshida T. Substance use-induced diminution of violence: a countervailing effect in longitudinal perspective. Criminology. 2001;39(1):205-24.
Kaplan S J, Labruna V, Pelcovitz D, et al. Physically abused adolescents: behavior problems, functional impairment, and comparison of informants' reports. Pediatrics. 1999;104(1 Pt 1):43-9. [pmid: 10390258].
Kaplan S J, Pelcovitz D, Salzinger S, et al. Adolescent physical abuse: risk for adolescent psychiatric disorders. Am J Psychiatry. 1998;155(7):954-9. [pmid: 9659863].
Kaplan S L, Busner J, Kupietz S, et al. Effects of methylphenidate on adolescents with aggressive conduct disorder and ADDH: A preliminary report. J Am Acad Child Adolesc Psychiatry. 1990;29(5):719-23. [pmid: 2228924].
Kashani J H, Darby P J, Allan W D, et al. Intrafamilial homicide committed by juveniles: Examination of a sample with recommendations for prevention. J Forensic Sci. 1997;42(5):873-8. [pmid: 9304834].
Kashani J H, Deuser W, Reid J C. Aggression and anxiety: a new look at an old notion. J Am Acad Child Adolesc Psychiatry. 1991;30(2):218-23. [pmid: 2016225].
Kashani J H, Jones M R, Borduin C M, et al. Individual characteristics and peer relations of psychiatrically hospitalized aggressive youths: Implications for treatment. Child Psychiatry Hum Dev. 2000;30(3):145-59. [pmid: 10851790].
Kashani J H, Shepperd J A. Aggression in adolescents: the role of social support and personality. Can J Psychiatry. 1990;35(4):311-5. [pmid: 2346896].
Kassirer J P. Private arsenals and public peril. N Engl J Med. 1998;338(19):1375-6. [pmid: 9862949].
Kastner J W. Clinical change in adolescent aggressive behavior: A group therapy approach. J Child Adolesc Group Ther. 1998;8(1):23-33.
Katz R C, Marquette j. Psychosocial characteristics of young violent offenders: A comparative study. Crim Behav Ment Health. 1996;6(4):339-48.
Kazdin A E, Crowley M J. Moderators of treatment outcome in cognitively based treatment of antisocial children. Cognit Ther Res. 1997;21(2):185-207.
Keiley M K, Howe T R, Dodge K A, et al. The timing of child physical maltreatment: a cross-domain growth analysis of impact on adolescent externalizing and internalizing problems. Dev Psychopathol. 2001;13(4):891-912. [pmid: 11771913].
Kelder S H, Orpinas P, McAlister A, et al. The students for peace project: a comprehensive violence-prevention program for middle school students. Am J Prev Med. 1996;12(5 Suppl):22-30. [pmid: 8909621].
Kellam S G, Ling X, Merisca R, et al. The effect of the level of aggression in the first grade classroom on the course and malleability of aggressive behavior into middle school. Dev Psychopathol. 1998;10(2):165-85. [pmid: 9635220].
Kellam S G, Ling X, Merisca R, et al. The effect of the level of aggression in the first grade classroom on the course and malleability of aggressive behavior into middle school: Erratum. Dev Psychopathol. 1999;11(1):193.
Kellam S G, Ling X, Merisca R, et al. The effect of the level of aggression in the first grade classroom on the course and malleability of aggressive behavior into middle school: Erratum. Dev Psychopathol. 2000;12(1):107.
Kellam S G, Rebok G W, Ialongo N, et al. The course and malleability of aggressive behavior from early first grade into middle school: results of a developmental epidemiologically-based preventive trial. J Child Psychol Psychiatry. 1994;35(2):259-81. [pmid: 8188798].
Kelley BR, Beauchesne MA. Interventions for violence in children and adolescents. School Nurse News 2002;19(3):36–9; Quiz 40.
Kelley D. Shots fired … children down. JEMS 1998;23(8):38–42, 5.
Keltikangas-Jaervinen L. Aggressive behaviour and social problem-solving strategies: A review of the findings of a seven-year follow-up from childhood to late adolescence. Crim Behav Ment Health. 2001;11(4):236-50.
Keltikangas-Jaervinen L. Aggressive problem-solving strategies, aggressive behavior, and social acceptance in early and late adolescence. J Youth Adolesc. 2002;31(4):279-87.
Keltikangas-Jaervinen L, Pakaslahti L. Development of social problem-solving strategies and changes in aggressive behavior: A 7-year follow-up from childhood to late adolescence. Aggress Behav. 1999;25(4):269-79.
Kemph J P, Braley R O, Ciotola P V. A comparison of youthful inmates who have committed violent versus nonviolent crimes. J Am Acad Psychiatry Law. 1998;26(1):67-74. [pmid: 9554711].
Kemph J P, DeVane C L, Levin G M, et al. Treatment of aggressive children with clonidine: results of an open pilot study. J Am Acad Child Adolesc Psychiatry. 1993;32(3):577-81. [pmid: 8496122].
Kempton T, Forehand R. Juvenile sex offenders: similar to, or different from, other incarcerated delinquent offenders?. Behav Res Ther. 1992;30(5):533-6. [pmid: 1520240].
Kennedy L W, Baron S W. Routine activities and a subculture of violence: A study of violence on the street. J Res Crime Delinq. 1993;30(1):88-112.
Kennedy M. What's the matter with kids today?. WMJ. 1998;97(8):40-3. [pmid: 9894436].
Kennedy M. Teens today facing familiar problems. WMJ. 2000;99(2):28-32. [pmid: 11089445].
Kent C. Perspectives. Public health attacks violence. Faulkner Grays Med Health 1992;46(25):Suppl 4 P.
Kesner J E, McKenry P C. The role of childhood attachment factors in predicting male violence toward female intimates. J Fam Violence. 1998;13(4):417-32.
Kettl P A. Homicide in Alaska Natives. Alaska Med. 1993;35(2):168-72. [pmid: 8238772].
Khatri P, Kupersmidt J B, Patterson C. Aggression and peer victimization as predictors of self-reported behavioral and emotional adjustment. Aggress Behav. 2000;26(5):345-58.
Kheder S, VandenBosch T. Intimate partner violence: a health system's response. Continuum Soc Soc Work Leadersh Health Care. 2001;21(1):15-22. [pmid: 11255844].
Kho K, Sensky T, Mortimer A, et al. Prospective study into factors associated with aggressive incidents in psychiatric acute admission wards. Br J Psychiatry. 1998;172:38-43. [pmid: 9534830].
Killeen M R. Ten years after: examination of adolescent screening questions that predict future violence-related injury. J Child Fam Nurs. 2000;3(2):115-6. [pmid: 11271147].
Kindlon D J, Tremblay R E, Mezzacappa E, et al. Longitudinal patterns of heart rate and fighting behavior in 9- through 12-year-old boys. J Am Acad Child Adolesc Psychiatry. 1995;34(3):371-7. [pmid: 7896679].
King K A, Vidourek R A, Davis B, et al. Increasing self-esteem and school connectedness through a multidimensional mentoring program. J Sch Health. 2002;72(7):294-9. [pmid: 12357911].
King S R. Acting on what they (may) know: children's culpability for violent behavior. J Dev Behav Pediatr. 2000;21(6):429-31. [pmid: 11132794].
Kingery P M, Biafora F A, Zimmerman R S. Risk factors for violent behaviors among ethnically diverse urban adolescents: Beyond race/ethnicity. Sch Psychol Int. 1996;17(2):171-88.
Kingery P M, McCoy-Simandle L, Clayton R. Risk factors for adolescent violence: The importance of vulnerability. Sch Psychol Int. 1997;18(1):49-60.
Kingery P M, Mirzaee E, Pruitt B E, et al. Rural communities near large metropolitan areas: Safe havens from adolescent violence and drug use?. Health Values. 1991;15(4):39-48.
Kingery P M, Pruitt B E, Heuberger G. A profile of rural Texas adolescents who carry handguns to school. J Sch Health. 1996;66(1):18-22. [pmid: 8907733].
Kingery P M, Pruitt B E, Heuberger G, et al. Violence in rural schools: An emerging problem near the United States^Mexico border. Sch Psychol Int. 1995;16(4):335-44.
Kingery P M, Pruitt B E, Hurley R S. Violence and illegal drug use among adolescents: evidence from the U.S. National Adolescent Student Health Survey. Int J Addict. 1992;27(12):1445-64. [pmid: 1452395].
Kipke M D, Simon T R, Montgomery S B, et al. Homeless youth and their exposure to and involvement in violence while living on the streets. J Adolesc Health. 1997;20(5):360-7. [pmid: 9168383].
Kirkish P, Sreenivasan S, Welsh R, et al. The future of criminal violence: juveniles tried as adults. J Am Acad Psychiatry Law. 2000;28(1):38-46. [pmid: 10774840].
Klevens J, Roca J. Nonviolent youth in a violent society: Resilience and vulnerability in the country of Columbia. Violence Vict. 1999;14(3):311-22. [pmid: 10606436].
Knox G W. The “get out of the gang thermometer”: An application to a large national sample of African-American male youths. J Gang Res. 1997;5(1):21-43.
Knox M, King C, Hanna G L, et al. Aggressive behavior in clinically depressed adolescents. J Am Acad Child Adolesc Psychiatry. 2000;39(5):611-8. [pmid: 10802979].
Kodjo C M, Auinger P, Ryan S A, et al. Demographic, intrinsic, and extrinsic factors associated with weapon carrying at school. Arch Pediatr Adolesc Med. 2003;157(1):96-103. [pmid: 12517202].
Kodjo C M, Auinger P, Ryan S A, et al. Demographic, intrinsic, and extrinsic factors associated with weapon carrying at school. Arch Pediatr Adolesc Med. 2003;157(1):96-103. [pmid: 12517202].
Kohn R. Homicide among adolescents in the Americas: a growing epidemic. Bull World Health Organ. 2001;79(2):172. [pmid: 11242824].
Kolko D J. Conduct disorder and attention deficit disorder with hyperactivity in child inpatients: Comparisons on home and hospital measures. J Emot Behav Disord. 1993;1(2):75-86.
Komro K A, Williams C L, Forster J L, et al. The relationship between adolescent alcohol use and delinquent and violent behaviors. J Child Adolesc Subst Abus. 1999;9(2):13-28.
Kosterman R, Graham J W, Hawkins J D, et al. Childhood risk factors for persistence of violence in the transition to adulthood: a social development perspective. Violence Vict. 2001;16(4):355-69. [pmid: 11506446].
Kostinsky S, Bixler E O, Kettl P A. Threats of school violence in Pennsylvania after media coverage of the Columbine High School massacre: examining the role of imitation. Arch Pediatr Adolesc Med. 2001;155(9):994-1001. [pmid: 11529800].
Krakowski M, Czobor P. Violence in psychiatric patients: the role of psychosis, frontal lobe impairment, and ward turmoil. Compr Psychiatry. 1997;38(4):230-6. [pmid: 9202880].
Krakowski M, Czobor P, Carpenter M D, et al. Community violence and inpatient assaults: neurobiological deficits. J Neuropsychiatry Clin Neurosci. 1997;9(4):549-55. [pmid: 9447495].
Kreiter S R, Krowchuk D P, Woods C R, et al. Gender differences in risk behaviors among adolescents who experience date fighting. Pediatrics. 1999;104(6):1286-92. [pmid: 10585979].
Kruesi M J, Hibbs E D, Zahn T P, et al. A 2-year prospective follow-up study of children and adolescents with disruptive behavior disorders. Prediction by cerebrospinal fluid 5-hydroxyindoleacetic acid, homovanillic acid, and autonomic measures?. Arch Gen Psychiatry. 1992;49(6):429-35. [pmid: 1376104].
Kruesi M J, Rapoport J L, Hamburger S, et al. Cerebrospinal fluid monoamine metabolites, aggression, and impulsivity in disruptive behavior disorders of children and adolescents. Arch Gen Psychiatry. 1990;47(5):419-26. [pmid: 1691910].
Krug E G, Brener N D, Dahlberg L L, et al. The impact of an elementary school-based violence prevention program on visits to the school nurse. Am J Prev Med. 1997;13(6):459-63. [pmid: 9415793].
Kruttschnitt C, Dornfeld M. Exposure to family violence: A partial explanation for initial and subsequent levels of delinquency?. Crim Behav Ment Health. 1993;3(2):61-75.
Kulig J, Valentine J, Griffith J, et al. Predictive model of weapon carrying among urban high school students: Results and validation. J Adolesc Health. 1998;22(4):312-9. [pmid: 9561463].
Kundu R, Basu J. Aggression in reaction to frustration among adolescent boys with depression and conduct disorder. SIS J Project Psychol Ment Health. 1998;5(2):119-26.
Kunitz S J, Levy J E, McCloskey J, et al. Alcohol dependence and domestic violence as sequelae of abuse and conduct disorder in childhood. Child Abuse Negl. 1998;22(11):1079-91. [pmid: 9827313].
Kyriacou D N, Hutson H R, Anglin D, et al. The relationship between socioeconomic factors and gang violence in the City of Los Angeles. J Trauma. 1999;46(2):334-9. [pmid: 10029043].
Labelle A, Bradford J M, Bourget D, et al. Adolescent murderers. Can J Psychiatry. 1991;36(8):583-7. [pmid: 1742712].
Lacourse E, Cote S, Nagin D S, et al. A longitudinal-experimental approach to testing theories of antisocial behavior development. Dev Psychopathol. 2002;14(4):909-24. [pmid: 12549709].
Lahey B B, Goodman S H, Waldman I D, et al. Relation of age of onset to the type and severity of child and adolescent conduct problems. J Abnorm Child Psychol. 1999;27(4):247-60. [pmid: 10503644].
Lahey B B, Loeber R, Quay H C, et al. Validity of DSM-IV subtypes of conduct disorder based on age of onset. J Am Acad Child Adolesc Psychiatry. 1998;37(4):435-42. [pmid: 9549965].
Lamberg L. Preventing school violence: no easy answers. JAMA. 1998;280(5):404-7. [pmid: 9863836].
Lamberg L. Younger children, more girls commit acts of violence: some get help, others receive only punishment. JAMA. 2002;288(5):566-8. [pmid: 12243626].
Lancaster W Jr, Compton D, White N, et al. MMPI-A and dissociative experiences scale responses of violent and non-violent youth offenders. J Offender Rehabil. 1997;26(12):45-52.
Lanclos N F, Gordon S T, Kelley M L. The effects of community violence exposure on Louisiana's children. J La State Med Soc. 2000;152(10):504-8. [pmid: 11059920].
Langhinrichsen-Rohling J, Neidig P. Violent backgrounds of economically disadvantaged youth: Risk factors for perpetrating violence?. J Fam Violence. 1995;10(4):379-97.
Langrock A M, Compas B E, Keller G, et al. Coping with the stress of parental depression: Parents' reports of children's coping, emotional, and behavioral problems. J Clin Child Adolesc Psychol. 2002;31(3):312-24. [pmid: 12149969].
Lansford J E, Dodge K A, Pettit G S, et al. A 12-year prospective study of the long-term effects of early child physical maltreatment on psychological, behavioral, and academic problems in adolescence. Arch Pediatr Adolesc Med. 2002;156(8):824-30. [pmid: 12144375].
Larson J D. Anger and aggression management techniques through the Think First curriculum. J Offender Rehabil. 1992;18(12):101-17.
Lattimore P K, Others A. Predicting rearrest for violence among serious youthful offenders. J Res Crime Delinq. 1995;32(1):54-83.
Lau M A, Pihl R O. Alcohol and the Taylor aggression paradigm: a repeated measures study. J Stud Alcohol. 1994;55(6):701-6. [pmid: 7861799].
Lavoie F, Hebert M, Tremblay R, et al. History of family dysfunction and perpetration of dating violence by adolescent boys; A longitudinal study. J Adolesc Health. 2002;30(5):375-83. [pmid: 11996786].
Lawrence L E. Perspectives on violence. J Natl Med Assoc. 1993;85(11):825-7. [pmid: 8126739].
Leenaars A A, Lester D. Suicide and homicide rates in Canada and the United States. Suicide Life Threat Behav. 1994;24(2):184-91. [pmid: 8053012].
Lego S. Children killing children. Perspect Psychiatr Care. 1998;34(3):3-4. [pmid: 10076425].
Lehman C. Striking back. Minn Med. 2000;83(9):24-6. [pmid: 11006684].
LeMarquand D G, Pihl R O, Young S N, et al. Tryptophan depletion, executive functions, and disinhibition in aggressive, adolescent males. Neuropsychopharmacology. 1998;19(4):333-41. [pmid: 9718596].
Lempp R. To the diagnostic of “incomprehensible” offences of adolescents and juveniles. Acta Paedopsychiatr. 1990;53(2):173-5. [pmid: 2178310].
Leon-Carrion J, Ramos F J C. Blows to the head during development can predispose to violent criminal behaviour: rehabilitation of consequences of head injury is a measure for crime prevention. Brain Inj. 2003;17(3):207-16. [pmid: 12623497].
Leon-Carrion J, Ramos F J C. Blows to the head during development can predispose to violent criminal behaviour: rehabilitation of consequences of head injury is a measure for crime prevention. Brain Inj. 2003;17(3):207-16. [pmid: 12623497].
Lester D. The Holinger/Easterlin cohort hypothesis about youth suicide and homicide rates. Percept Mot Skills. 1994;79(3 Pt 2):1545-6. [pmid: 7870542].
LeSure-Lester G E. Relation between empathy and aggression and behavior compliance among abused group home youth. Child Psychiatry Hum Dev. 2000;31(2):153-61. [pmid: 11089303].
LeSure-Lester G E. An application of cognitive-behavior principles in the reduction of aggression among abused African American adolescents. J Interpers Violence. 2002;17(4):394-402.
Leventhal J M, Horwitz S M, Rude C, et al. Maltreatment of children born to teenage mothers: a comparison between the 1960s and 1980s. J Pediatr. 1993;122(2):314-9. [pmid: 8429452].
Levine G N, Parra F. The gangbangers of East Los Angeles: Sociopsycho-analytic considerations. J Gang Res. 2000;7(4):9-12.
Lewin L M, Davis B, Hops H. Childhood social predictors of adolescent antisocial behavior: Gender differences in predictive accuracy and efficacy. J Abnorm Child Psychol. 1999;27(4):277-92. [pmid: 10503646].
Lewis DO, Lovely R, Yeager C, et al. Toward a theory of the genesis of violence: A follow-up study of delinquents. Annu Prog Child Psych Child Dev 1990:547–60.
Lewis D O, Yeager C A, Cobham-Portorreal C S, et al. A follow-up of female delinquents: maternal contributions to the perpetuation of deviance. J Am Acad Child Adolesc Psychiatry. 1991;30(2):197-201. [pmid: 2016222].
Lewis D O, Yeager C A, Gidlow B, et al. Six adoptees who murdered: Neuropsychiatric vulnerabilities and characteristics of biological and adoptive parents. J Am Acad Psychiatry Law. 2001;29(4):390-7. [pmid: 11785610].
Lewis S F, Travea L, Fremouw W J. Characteristics of female perpetrators and victims of dating violence. Violence Vict. 2002;17(5):593-606. [pmid: 12477100].
Li X, Feigelman S, Stanton B. Perceived parental monitoring and health risk behaviors among urban low-income African-American children and adolescents. J Adolesc Health. 2000;27(1):43-8. [pmid: 10867352].
Li X, Stanton B, Feigelman S. Exposure to drug trafficking among urban, low-income African American children and adolescents. Arch Pediatr Adolesc Med. 1999;153(2):161-8. [pmid: 10520613].
Lingle E A. Treating children by faith. Colliding constitutional issues. J Leg Med. 1996;17(2):301-30. [pmid: 8691058].
Litt I F. Violence among adolescents: don't overlook the girls. J Adolesc Health. 1995;17(6):333. [pmid: 8924438].
Little S A, Garber J. Interpersonal and achievement orientations and specific stressors predicting depressive and aggressive symptoms in children. Cognit Ther Res. 2000;24(6):651-70.
Livingston R, Lawson L, Jones J G. Predictors of self-reported psychopathology in children abused repeatedly by a parent. J Am Acad Child Adolesc Psychiatry. 1993;32(5):948-53. [pmid: 8407768].
Lochman J E, Dodge K A. Social-cognitive processes of severely violent, moderately aggressive, and nonaggressive boys. J Consult Clin Psychol. 1994;62(2):366-74. [pmid: 8201075].
Lochman J E, Wayland K K. Aggression, social acceptance, and race as predictors of negative adolescent outcomes. J Am Acad Child Adolesc Psychiatry. 1994;33(7):1026-35. [pmid: 7961341].
Lochman J E, Wells K C. Contextual social-cognitive mediators and child outcome: A test of the theoretical model in the Coping Power program. Dev Psychopathol. 2002;14(4):945-67. [pmid: 12549711].
Lockwood D. Violence prevention among African American middle school children. Res Middle Level Educ Q. 1998;21(3):33-49.
Lodico M A, Gruber E, DiClemente R J. Childhood sexual abuse and coercive sex among school-based adolescents in a midwestern state. J Adolesc Health. 1996;18(3):211-7. [pmid: 8777197].
Loeber R, Burke J D, Lahey B B. What are adolescent antecedents to antisocial personality disorder?. Crim Behav Ment Health. 2002;12(1):24-36. [pmid: 12357256].
Loeber R, Farrington D P, Stouthamer-Loeber M, et al. The development of male offending: Key findings from the first decade of the Pittsburgh Youth Study. Stud Crime Crime Prev. 1998;7(2):141-71.
Loeber R, Green S M, Keenan K, et al. Which boys will fare worse? Early predictors of the onset of conduct disorder in a six-year longitudinal study. J Am Acad Child Adolesc Psychiatry. 1995;34(4):499-509. [pmid: 7751264].
Loeber R, Wei E, Stouthamer-Loeber M, et al. Behavioral antecedents to serious and violent offending: Joint analyses from the Denver Youth Survey, Pittsburgh Youth Study and the Rochester Youth Development Study. Stud Crime Crime Prev. 1999;8(2):245-63.
Loeber R, Wung P, Keenan K, et al. Developmental pathways in disruptive child behavior. Dev Psychopathol. 1993;5(12):103-33.
Long J J, Fabricius W V, Musheno M, et al. Exploring the cognitive and affective capacities of child mediators in a “successful” inner-city peer mediation program. Mediat Q. 1998;15(4):289-302.
Loper A B, Cornell D G. Homicide by juvenile girls. J Child Fam Stud. 1996;5(3):323-36.
Loper A B, Hoffschmidt S J, Ash E. Personality features and characteristics of violent events committed by juvenile offenders. Behav Sci Law. 2001;19(1):81-96. [pmid: 11241682].
Lopez V A, Emmer E T. Adolescent male offenders: A grounded theory study of cognition, emotion, and delinquent crime contexts. Crim Justice Behav. 2000;27(3):292-311.
Lopez V A, Emmer E T. Influences of beliefs and values on male adolescents' decision to commit violent offenses. Psychol Men Masc. 2002;3(1):28-40.
Losada-Paisey G. Use of the MMPI-A to assess personality of juvenile male delinquents who are sex offenders and nonsex offenders. Psychol Rep. 1998;83(1):115-22. [pmid: 9775669].
Loskota M. G is for gangsta. Understanding gangs in Minnesota. Minn Med. 1998;81(4):28-32. [pmid: 9577535].
Lowenstein L F. Bullying: An intensive and multi-dimensional treatment approach in a therapeutic community. Educ Today. 1995;45(1):19-24.
Lowenstein L F. Perception and accuracy of perception by bullying children of potential victims. Educ Today. 1995;45(2):28-31.
Lowry R, Cohen L R, Modzeleski W, et al. School violence, substance use, and availability of illegal drugs on school property among US high school students. J Sch Health. 1999;69(9):347-55. [pmid: 10633319].
Lowry R, Powell K E, Kann L, et al. Weapon-carrying, physical fighting, and fight-related injury among U.S. adolescents. Am J Prev Med. 1998;14(2):122-9. [pmid: 9631164].
Lowry R, Sleet D, Duncan C, et al. Adolescents at risk for violence. Educ Psychol Rev. 1995;7(1):7-39.
Ludwig J, Duncan G J, Hirschfield P. Urban poverty and juvenile crime: evidence from a randomized housing-mobility experiment. Q J Econ. 2001;116(2):655-79.
Luengo M A, Otero J M, Carrillo-de-la-Pena M T, et al. Dimensions of antisocial behaviour in juvenile delinquency: A study of personality variables. Psychol Crime Law. 1994;1(1):27-37.
Luiselli J K, Arons M, Marchese N, et al. Incidence of law-violating behavior in a community sample of children and adolescents with traumatic brain injury. Int J Offender Ther Comp Criminol. 2000;44(6):647-56.
Lurie S. Child psychiatrists address problem of youth violence. JAMA. 1999;282(20):1906-7. [pmid: 10612311].
Lykken D T. The causes and costs of crime and a controversial cure. J Pers. 2000;68(3):559-605. [pmid: 10831312].
Lyons J S, Schaefer K. Mental health and dangerousness: Characteristics and outcomes of children and adolescents in residential placements. J Child Fam Stud. 2000;9(1):67-73.
Lysaker P H, Wright D E, Clements C A, et al. Neurocognitive and psychosocial correlates of hostility among persons in a post-acute phase of schizophrenia spectrum disorders. Compr Psychiatry. 2002;43(4):319-24. [pmid: 12107869].
Ma X. Bullying and being bullied: To what extent are bullies also victims?. Am Educ Res J. 2001;38(2):351-70.
Macgowan M J. An evaluation of a dating violence prevention program for middle school students. Violence Vict. 1997;12(3):223-35. [pmid: 9477538].
MacKinnon-Lewis C, Lofquist A. Antecedents and consequences of boys' depression and aggression: Family and school linkages. J Fam Psychol. 1996;10(4):490-500.
Madan A, Beech D J, Flint L. Drugs, guns, and kids: the association between substance use and injury caused by interpersonal violence. J Pediatr Surg. 2001;36(3):440-2. [pmid: 11226991].
Madsen P. Drive-by shootings in Los Angeles. N Engl J Med. 1994;330(25):1833. [pmid: 8190173].
Malek M K, Chang B H, Davis T C. Self-reported characterization of seventh-grade students' fights. J Adolesc Health. 1998;23(2):103-9. [pmid: 9714173].
Malek M K, Chang B H, Davis T C. Fighting and weapon-carrying among seventh-grade students in Massachusetts and Louisiana. J Adolesc Health. 1998;23(2):94-102. [pmid: 9714173].
Males M. Youth behavior: subcultural effect or mirror of adult behavior?. J Sch Health. 1990;60(10):505-8. [pmid: 2283870].
Males M. California trends reveal teenage violence myths. Am J Public Health. 1998;88(7):1123. [pmid: 9663169].
Males M A. America's youth violence hoax. Lancet. 1999;354(9189):1563-4. [pmid: 10551535].
Malik S, Sorenson S B, Aneshensel C S. Community and dating violence among adolescents: perpetration and victimization. J Adolesc Health. 1997;21(5):291-302. [pmid: 9358292].
Malmquist C P. Depression in homicidal adolescents. Bull Am Acad Psychiatry Law. 1990;18(1):23-36. [pmid: 2328331].
Malone R P, Bennett D S, Luebbert J F, et al. Aggression classification and treatment response. Psychopharmacol Bull. 1998;34(1):41-5. [pmid: 9564197].
Malone R P, Delaney M A, Leubbert J F, et al. A double-blind placebo-controlled study of lithium in hospitalized aggressive children and adolescents with conduct disorder. Arch Gen Psychiatry. 2000;57(7):649-54. [pmid: 10891035].
Malone R P, Luebbert J, Pena-Ariet M, et al. The Overt Aggression Scale in a study of lithium in aggressive conduct disorder. Psychopharmacol Bull. 1994;30(2):215-8. [pmid: 7831458].
Malone R P, Luebbert J F, Delaney M A, et al. Nonpharmacological response in hospitalized children with conduct disorder. J Am Acad Child Adolesc Psychiatry. 1997;36(2):242-7. [pmid: 9031577].
Malpique C, Barrias P, Morais L, et al. Violence and alcoholism in the family: How are the children affected?. Alcohol Alcohol. 1998;33(1):42-6. [pmid: 9539176].
Manning J T, Wood D. Fluctuating asymmetry and aggression in boys. Hum Nat. 1998;9(1):53-65.
Marans S, Berkowitz S J, Cohen D J. Police and mental health professionals. Collaborative responses to the impact of violence on children and families. Child Adolesc Psychiatr Clin N Am. 1998;7(3):635-51. [pmid: 9894059].
Marcelle D R, Melzer-Lange M D. Project UJIMA: working together to make things right. WMJ. 2001;100(2):22-5. [pmid: 11419365].
Marciniak L M. Adolescent attitudes toward victim precipitation of rape. Violence Vict. 1998;13(3):287-300. [pmid: 9836415].
Marcus B A, Vollmer T R, Swanson V, et al. An experimental analysis of aggression. Behav Modif. 2001;25(2):189-213. [pmid: 11317634].
Marcus N E, Lindahl K M, Malik N M. Interparental conflict, children's social cognitions, and child aggression: A test of a mediational model. J Fam Psychol. 2001;15(2):315-33. [pmid: 11458636].
Marcus R F. A gender-linked exploratory factor analysis of antisocial behavior in young adolescents. Adolescence. 1999;34(133):33-46. [pmid: 10234365].
Marcus R F, Gray L. Close relationships of violent and nonviolent African American delinquents. Violence Vict. 1998;13(1):31-46. [pmid: 9650244].
Margolin A, Youga J, Ballou M. Voices of violence: A study of male adolescent aggression. J Humanist Educ Dev. 2002;41(2):215-31.
Margolin L, Craft J L. Child abuse by adolescent caregivers. Child Abuse Negl. 1990;14(3):365-73. [pmid: 2207805].
Marlowe M, Schneider H G, Bliss L B. Hair mineral analysis in emotionally disturbed and violence prone children. Int J Biosoc Med Res. 1991;13(2):169-79.
Marsh H W, Parada R H, Yeung A S, et al. Aggressive school troublemakers and victims: A longitudinal model examining the pivotal role of self-concept. J Educ Psychol. 2001;93(2):411-9.
Marsh T Y, Cornell D G. The contribution of student experiences to understanding ethnic differences in high-risk behaviors at school. Behav Disord. 2001;26(2):152-63.
Marshall JE. Street Soldiers: violence prevention over the airwaves, a phenomenon. J Health Care Poor Underserved 1995;6(2):246–51; Discussion 52–3.
Martin C A, Milich R, Martin W R, et al. Gender differences in adolescent psychiatric outpatient substance use: associated behaviors and feelings. J Am Acad Child Adolesc Psychiatry. 1997;36(4):486-94. [pmid: 9100423].
Martin C S, Earleywine M, Blackson T C, et al. Aggressivity, inattention, hyperactivity, and impulsivity in boys at high and low risk for substance abuse. J Abnorm Child Psychol. 1994;22(2):177-203. [pmid: 8064028].
Martin J L, Ross H S. Do mitigating circumstances influence family reactions to physical aggression?. Child Dev. 1996;67(4):1455-66. [pmid: 8890494].
Martin S E, Bryant K. Gender differences in the association of alcohol intoxication and illicit drug abuse among persons arrested for violent and property offenses. J Subst Abuse. 2001;13(4):563-81. [pmid: 11775083].
Martin S E, Bryant K, Fitzgerald N. Self-reported alcohol use and abuse by arrestees in the 1998 Arrestee Drug Abuse Monitoring Program. Alcohol Res Health. 2001;25(1):72-9. [pmid: 11496970].
Marty F. Linking work: from violence to subjectivization. Am J Psychoanal. 2002;62(3):255-72. [pmid: 12357682].
Mason J O. Forum on youth violence in minority communities. Prevention of violence: a public health commitment. Public Health Rep. 1991;106(3):265-8. [pmid: 1910180].
Mason J O. The dimensions of an epidemic of violence. Public Health Rep. 1993;108(1):1-3. [pmid: 8434084].
Mathew T, Nordstrom K. On the equivalence of meta-analysis using literature and using individual patient data. Biometrics. 1999;55(4):1221-3. [pmid: 11315071].
Matthys W, Cuperus J M, Van Engeland H. Deficient social problem-solving in boys with ODD/CD, with ADHD, and with both disorders. J Am Acad Child Adolesc Psychiatry. 1999;38(3):311-21. [pmid: 10087693].
Matthys W, Van Engeland H. Social-cognitive research in children with aggressive behaviour: New perspectives. Eur Child Adolesc Psychiatry. 1992;1(3):178-85.
Matykiewicz L, La Grange L, Vance P, et al. Adjudicated adolescent males: Measures of urinary 5-hydroxyindoleacetic acid and reactive hypoglycemia. Pers Individ Dif. 1997;22(3):327-32.
Maughan B, Pickles A, Rowe R, et al. Developmental trajectories of aggressive and non-aggressive conduct problems. J Quant Criminol. 2000;16(2):199-221.
Maxfield M G, Widom C S. The cycle of violence. Revisited 6 years later. Arch Pediatr Adolesc Med. 1996;150(4):390-5. [pmid: 8634734].
McBurnett K, Harris S M, Swanson J M, et al. Neuropsychological and psychophysiological differentiation of inattention/overactivity and aggression/defiance symptom groups. J Clin Child Psychol. 1993;22(2):165-71.
McBurnett K, Lahey B B, Rathouz P J, et al. Low salivary cortisol and persistent aggression in boys referred for disruptive behavior. Arch Gen Psychiatry. 2000;57(1):38-43. [pmid: 10632231].
McCabe K M, Hough R, Wood P A, et al. Childhood and adolescent onset conduct disorder: a test of the developmental taxonomy. J Abnorm Child Psychol. 2001;29(4):305-16. [pmid: 11523836].
McCafferty C. Adolescent homicide. No quick fixes. Minn Med. 1998;81(11):25-6. [pmid: 9842232].
McCarthy-Tucker S, Gold A, Garcia E. Effects of anger management training on aggressive behavior in adolescent boys. J Offender Rehabil. 1999;29(34):129-41.
McCloskey L A, Lichter E L. The contribution of marital violence to adolescent aggression across different relationships. J Interpers Violence. 2003;18(4):390-412.
McCloskey L A, Lichter E L. The contribution of marital violence to adolescent aggression across different relationships. J Interpers Violence. 2003;18(4):390-412.
McColloch M A, Gilbert D G, Johnson S. Effects of situational variables on the interpersonal behavior of families with an aggressive adolescent. Pers Individ Dif. 1990;11(1):1-11.
McCord J, Widom CS, Crowell NA. Juvenile crime, juvenile justice. Washington, D. C.: National Academy Press; 2001.
McCormick K F. Corporal punishment and violence. Arch Fam Med. 1992;1(2):203-4. [pmid: 1341595].
McCurrie T F. White racist extremist gang members: A behavioral profile. J Gang Res. 1998;5(2):51-60.
McElroy S L. Recognition and treatment of DSM-IV intermittent explosive disorder. J Clin Psychiatry. 1999;60(Suppl 15):12-6. [pmid: 10418808].
McFarlane J M, Groff J Y, O'Brien J A, et al. Behaviors of children who are exposed and not exposed to intimate partner violence: an analysis of 330 black, white, and Hispanic children. Pediatrics. 2003;112(3 Pt 1):E202-7. [pmid: 12949313].
McGaha J E, Leoni E L. Family violence, abuse, and related family issues of incarcerated delinquents with alcoholic parents compared to those with nonalcoholic parents. Adolescence. 1995;30(118):473-82. [pmid: 7676881].
McGee J P, DeBernardo C R. The classroom avenger: A behavioral profile of school based shootings. Forensic Exam. 1999;8(56):16-8.
McGee R A, Wolfe D A, Wilson S K. Multiple maltreatment experiences and adolescent behavior problems: adolescents' perspectives. Dev Psychopathol. 1997;9(1):131-49. [pmid: 9089128].
McGee Z T, Davis B L, Brisbane T, et al. Urban stress and mental health among African-American youth: assessing the link between exposure to violence, problem behavior, and coping strategies. J Cult Divers. 2001;8(3):94-104. [pmid: 11855219].
McGloin J M, Widom C S. Resilience among abused and neglected children grown up. Dev Psychopathol. 2001;13(4):1021-38. [pmid: 11771905].
McGuffin P W. The effect of timeout duration on frequency of aggression in hospitalized children with conduct disorders. Behav Resid Treat. 1991;6(4):279-88.
McIntyre T, Cowell K. Effects of various music conditions on multiple dimensions of behavior of emotionally disturbed adolescents. Psychol Rep. 1991;69(3, Pt 1):1007-8. [pmid: 1784647].
McKenney A, Dattilo J. Effects of an intervention within a sport context on the prosocial behavior and antisocial behavior of adolescents with disruptive behavior disorders. Ther Recreation J. 2001;35(2):123-40.
McKeown R E, Jackson K L, Valois R F. The frequency and correlates of violent behaviors in a statewide sample of high school students. Fam Community Health. 1998;20(4):38-53.
Mclaughlin C R, Daniel J, Joost T F. The relationship between substance use, drug selling, and lethal violence in 25 juvenile murderers. J Forensic Sci. 2000;45(2):349-53. [pmid: 10782954].
McLaughlin C R, Reiner S M, Reams P N, et al. Factors associated with parenting among incarcerated juvenile offenders. Adolescence. 1999;34(136):665-70. [pmid: 10730691].
McLaughlin C R, Reiner S M, Smith B W, et al. Firearm injuries among Virginia juvenile drug traffickers, 1992 through 1994. Am J Public Health. 1996;86(5):751-2. [pmid: 8629738]. [pmcid: 1380497].
McNeal C, Amato P R. Parents' marital violence: Long-term consequences for children. J Fam Issues. 1998;19(2):123-39.
McNeil D E, Binder R L. The relationship between acute psychiatric symptoms, diagnosis, and short-term risk of violence. Hosp Community Psychiatry. 1994;45(2):133-7. [pmid: 8168791].
McNiel D E, Binder R L. Clinical assessment of the risk of violence among psychiatric inpatients. Am J Psychiatry. 1991;148(10):1317-21. [pmid: 1897611].
McNiel D E, Binder R L. Clinical assessment of the risk of violence among psychiatric inpatients. Am J Psychiatry. 1991;148(10):1317-21. [pmid: 1897611].
McNiel D E, Eisner J P, Binder R L. The relationship between command hallucinations and violence. Psychiatr Serv. 2000;51(10):1288-92. [pmid: 11013329].
McNulty T L, Bellair P E. Explaining racial and ethnic differences in adolescent violence: Structural disadvantage, family well-being, and social capital. Justice Q. 2003;20(1):1-31.
Meehan P J, O'Carroll P W. Gangs, drugs, and homicide in Los Angeles. Am J Dis Child. 1992;146(6):683-7. [pmid: 1595623].
Meller W H, Borchardt C M. Comorbidity of major depression and conduct disorder. J Affect Disord. 1996;39(2):123-6. [pmid: 8827421].
Meloy J R, Gacono G B, Kenney L. A Rorschach investigation of sexual homicide. J Pers Assess. 1994;62(1):58-67. [pmid: 8138887].
Meloy J R, Hempel A G, Mohandie K, et al. Offender and offense characteristics of a nonrandom sample of adolescent mass murderers. J Am Acad Child Adolesc Psychiatry. 2001;40(6):719-28. [pmid: 11392351].
Menard S, Mihalic S. The tripartite conceptual framework in adolescence and adulthood: Evidence from a national sample. J Drug Issues. 2001;31(4):905-39.
Menken M. Grappling with the enigma of violence. An educational approach. Arch Neurol. 1992;49(6):592-4. [pmid: 1524521].
Mercy J A, Potter L B. Combining analysis and action to solve the problem of youth violence. Am J Prev Med. 1996;12(5 Suppl):1-2. [pmid: 8909618].
Merrick J, Kessel S, Morad M, et al. Trends in school violence. Int J Adolesc Med Health. 2002;14(1):77-80. [pmid: 12476904].
Merrill L L, Hervig L K, Milner J S. Childhood parenting experiences, intimate partner conflict resolution, and adult risk for child physical abuse. Child Abuse Negl. 1996;20:1049-65. [pmid: 8958455].
Merrill L L, Thomsen C J, Gold S R, et al. Childhood abuse and premilitary sexual assault in male navy recruits. J Consult Clin Psychol. 2001;69(2):252-61. [pmid: 11777126].
Messer S C, Gross A M. Childhood depression and aggression: A covariance structure analysis. Behav Res Ther. 1994;32(6):663-77. [pmid: 8085997].
Metzler C W, Noell J, Biglan A, et al. The social context for risky sexual behavior among adolescents. J Behav Med. 1994;17(4):419-38. [pmid: 7966262].
Mezzich A C. Diagnostic formulations for violent delinquent adolescents. J Psychiatry Law. 1990;18(1):165-90.
Mezzich A C, Coffman G, Mezzich J E. A typology of violent delinquent adolescents. J Psychiatry Law. 1991;19(12):63-78.
Miccio-Fonseca L C. Comparative differences in the psychological histories of sex offenders, victims, and their families. J Offender Rehabil. 1996;23(34):71-83.
Miccio-Fonseca L C. Adult and adolescent female sex offenders: Experiences compared to other female and male sex offenders. J Psychol Human Sex. 2000;11(3):75-88.
Middleton M B, Cartledge G. The effects of social skills instruction and parental involvement on the aggressive behaviors of African American males. Behav Modif. 1995;19(2):192-210. [pmid: 7726817].
Mihalic S W, Elliott D. A social learning theory model of marital violence. J Fam Violence. 1997;12(1):21-47.
Miller D B. Treatment of adolescent interpersonal violence: A cognitive-behavioral group approach. J Child Adolesc Group Ther. 1995;5(4):191-200.
Miller F, Webb J. Theoretical perspectives on violence and youth. Med Health R I. 1996;79(7):261-3. [pmid: 8797328].
Miller J M, DiIorio C, Dudley W. Parenting style and adolescent's reaction to conflict: is there a relationship?. J Adolesc Health. 2002;31(6):463-8. [pmid: 12457579].
Miller K S, Knutson J F. Reports of severe physical punishment and exposure to animal cruelty by inmates convicted of felonies and by university students. Child Abuse Negl. 1997;21(1):59-82. [pmid: 9023023].
Miller M, Azrael D, Hemenway D. Firearm availability and unintentional firearm deaths, suicide, and homicide among 5–14 year olds. J Trauma 2002;52(2):267–74; Discussion 74–5.
Miller-Johnson S, Coie J D, Maumary-Gremaud A, et al. Peer rejection and aggression and early starter models of conduct disorder. J Abnorm Child Psychol. 2002;30(3):217-30. [pmid: 12041708].
Miller-Johnson S, Coie J D, Maumary-Gremaud A, et al. Relationship between childhood peer rejection and aggression and adolescent delinquency severity and type among African American youth. J Emot Behav Disord. 1999;7(3):137-46.
Millstein S G, Irwin C E, Adler N E, et al. Health-risk behaviors and health concerns among young adolescents. Pediatrics. 1992;89(3):422-8. [pmid: 1741215].
Minden J, Henry D B, Tolan P H, et al. Urban boys' social networks and school violence. Prof Sch Couns. 2000;4(2):95-104.
Mitka M. Hospital study offers hope of changing lives prone to violence. JAMA. 2002;287(5):576-7. [pmid: 12479741].
Moffit T E, Caspi A, Dickson N, et al. Childhood-onset versus adolescent-onset antisocial conduct problems in males: Natural history from ages 3 to 18 years. Dev Psychopathol. 1996;8(2):399-424.
Moise J F, Huesmann L R. Television violence viewing and aggression in females. Ann N Y Acad Sci. 1996;794:380-3. [pmid: 8853622].
Molidor C, Tolman R M. Gender and contextual factors in adolescent dating violence. Violence Against Women. 1998;4(2):180-94. [pmid: 12295440].
Molidor C E. Gender differences of psychological abuse in high school dating relationships. Child Adolesc Social Work J. 1995;12(2):119-34.
Molidor C E. Female gang members: A profile of aggression and victimization. Soc Work. 1996;41(3):251-7. [pmid: 8936081].
Molliconi S A, Runyan C W. Detecting domestic violence. A pilot study of family practitioners. N C Med J. 1996;57(3):136-8. [pmid: 8935358].
Mooney A, Creeser R, Blatchford P. Children's views on teasing and fighting in junior schools. Educ Res. 1991;33(2):103-12.
Moore E, Armsden G, Gogerty P L. A twelve-year follow-up study of maltreated and at-risk children who received early therapeutic child care. Child Maltreat. 1998;3(1):3-16.
Moore M H. Violence prevention: criminal justice or public health?. Health Aff (Millwood). 1993;12(4):34-45. [pmid: 8125447].
Moretti M M, Holland R, McKay S. Self-other representations and relational and overt aggression in adolescent girls and boys. Behav Sci Law. 2001;19(1):109-26. [pmid: 11241684].
Moretti M M, Holland R, Peterson S. Long term outcome of an attachment-based program for conduct disorder. Can J Psychiatry. 1994;39(6):360-70. [pmid: 7987773].
Moriarty N, Stough C, Tidmarsh P, et al. Deficits in emotional intelligence underlying adolescent sex offending. J Adolesc. 2001;24(6):743-51. [pmid: 11790054].
Morris R E, Anderson M M, Knox G W. Incarcerated adolescents' experiences as perpetrators of sexual assault. Arch Pediatr Adolesc Med. 2002;156(8):831-5. [pmid: 12144376].
Morrison E F. A coercive interactional style as an antecedent to aggression in psychiatric patients. Res Nurs Health. 1992;15(6):421-31. [pmid: 1448573].
Morrissey C. A multimodal approach to controlling inpatient assaultiveness among incarcerated juveniles. J Offender Rehabil. 1997;25(12):31-42.
Moscovitz H, Degutis L, Bruno G R, et al. Emergency department patients with assault injuries: previous injury and assault convictions. Ann Emerg Med. 1997;29(6):770-5. [pmid: 9174523].
Moscovitz H, Milzman D, Haywood Y. The Washington, DC, Youth Curfew: effect on transports of injured youth and homicides. Prehosp Emerg Care. 2000;4(4):294-8. [pmid: 11045406].
Moss H B, Mezzich A, Yao J K, et al. Aggressivity among sons of substance-abusing fathers: Association with psychiatric disorder in the father and son, paternal personality, pubertal development, and socioeconomic status. Am J Drug Alcohol Abuse. 1995;21(2):195-208. [pmid: 7639206].
Mulder R T, Joyce P R. Relationship of temperament and behaviour measures to the prolactin response to fenfluramine in depressed men. Psychiatry Res. 2002;109(3):221-8. [pmid: 11959359].
Mullen P E, Pathe M, Purcell R, et al. Study of stalkers. Am J Psychiatry. 1999;156(8):1244-9. [pmid: 10450267].
Mulvey E P, Lidz C W. Clinical prediction of violence as a conditional judgment. Soc Psychiatry Psychiatr Epidemiol. 1998;33(Suppl 1):s107-13. [pmid: 9857788].
Munroe R L, Hulefeld R, Rodgers J M, et al. Aggression among children in four cultures. Cross Cult Res. 2000;34(1):3-25.
Muris P, Merckelbach H, Walczak S. Aggression and threat perception abnormalities in children with learning and behavior problems. Child Psychiatry Hum Dev. 2002;33(2):147-63. [pmid: 12462352].
Murray N G, Kelder S H, Parcel G S, et al. Padres Trabajando por la Paz: a randomized trial of a parent education intervention to prevent violence among middle school children. Health Educ Res. 1999;14(3):421-6. [pmid: 10539232].
Murrey G J, Briggs D, Davis C. Psychopathic disordered, mentally ill, and mentally handicapped sex offenders: a comparative study. Med Sci Law. 1992;32(4):331-6. [pmid: 1435130].
Muscari M E, Phillips C, Bears T. Health beliefs and behaviors in rural high school juniors. Pediatr Nurs. 1997;23(4):380-9. [pmid: 9282050].
Myaard M J, Crawford C, Jackson M, et al. Applying behavior analysis within the wraparound process: A multiple baseline study. J Emot Behav Disord. 2000;8(4):216-29.
Myeroff R, Mertlich G, Gross J. Comparative effectiveness of holding therapy with aggressive children. Child Psychiatry Hum Dev. 1999;29(4):303-13. [pmid: 10422354].
Myers W C, Blashfield R. Psychopathology and personality in juvenile sexual homicide offenders. J Am Acad Psychiatry Law. 1997;25(4):497-508. [pmid: 9460037].
Myers W C, Burgess A W, Nelson J A. Criminal and behavioral aspects of juvenile sexual homicide. J Forensic Sci. 1998;43(2):340-7. [pmid: 9544541].
Myers W C, Burton P R, Sanders P D, et al. Project back-on-track at 1 year: a delinquency treatment program for early-career juvenile offenders. J Am Acad Child Adolesc Psychiatry. 2000;39(9):1127-34. [pmid: 10986809].
Myers W C, Kemph J P. DSM-III-R classification of murderous youth: help or hindrance?. J Clin Psychiatry. 1990;51(6):239-42. [pmid: 2347861].
Myers W C, Monaco L. Anger experience, styles of anger expression, sadistic personality disorder, and psychopathy in juvenile sexual homicide offenders. J Forensic Sci. 2000;45(3):698-701. [pmid: 10855983].
Myers W C, Mutch P J. Language disorders in disruptive behavior disordered homicidal youth. J Forensic Sci. 1992;37(3):919-22. [pmid: 1629686].
Myers W C, Scott K. Psychotic and conduct disorder symptoms in juvenile murderers. Homicide Stud. 1998;2(2):160-75.
Myers W C, Scott K, Burgess A W, et al. Psychopathology, biopsychosocial factors, crime characteristics, and classification of 25 homicidal youths. J Am Acad Child Adolesc Psychiatry. 1995;34(11):1483-9. [pmid: 8543516].
Mynard H, Joseph S. Bully/victim problems and their association with Eysenck's personality dimensions in 8 to 13 year-olds. Br J Educ Psychol. 1997;67(1):51-4. [pmid: 9114731].
Myner J, Santman J, Cappelletty G G, et al. Variables related to recidivism among juvenile offenders. Int J Offender Ther Comp Criminol. 1998;42(1):65-80.
Nadel H, Spellmann M, Alvarez-Canino T, et al. The cycle of violence and victimization: a study of the school-based intervention of a multidisciplinary youth violence-prevention program. Am J Prev Med. 1996;12(5 Suppl):109-19. [pmid: 8909631].
Nagin D, Tremblay R E. Trajectories of boys' physical aggression, opposition, and hyperactivity on the path to physically violent and nonviolent juvenile delinquency. Child Dev. 1999;70(5):1181-96. [pmid: 10546339].
Nagin D, Tremblay R E. Trajectories of boys' physical aggression, opposition, and hyperactivity on the path to physically violent and nonviolent juvenile delinquency. Child Dev. 1999;70(5):1181-96. [pmid: 10546339].
Nagy S, DiClemente R, Adcock A G. Adverse factors associated with forced sex among southern adolescent girls. Pediatrics. 1995;96(5 Pt 1):944-6. [pmid: 7478840].
Nagy S, Dunn M S. Alcohol behaviors and deviant behaviors among adolescents in a rural state. J Alcohol Drug Educ. 1999;44(3):1-9.
Nansel T R, Overpeck M D, Haynie D L, et al. Relationships between bullying and violence among US youth. Arch Pediatr Adolesc Med. 2003;157(4):348-53. [pmid: 12695230].
Nansel T R, Overpeck M D, Haynie D L, et al. Relationships between bullying and violence among US youth. Arch Pediatr Adolesc Med. 2003;157(4):348-53. [pmid: 12695230].
Nathanson A I. Parents versus peers: Exploring the significance of peer mediation of antisocial television. Commun Res. 2001;28(3):251-74.
National Center for Injury Prevention and Control. Youth violence: Overview. Accessed: May 2004. http://www.cdc.gov/ncipc/factsheets/yvfacts.htm.
Nelson B V, Patience T H, MacDonald D C. Adolescent risk behavior and the influence of parents and education. J Am Board Fam Pract. 1999;12(6):436-43. [pmid: 10612361].
Nelson C, Valliant P M. Personality dynamics of adolescent boys where the father was absent. Percept Mot Skills. 1993;76(2):435-43. [pmid: 8483653].
Nevin R. How lead exposure relates to temporal changes in IQ, violent crime, and unwed pregnancy. Environ Res. 2000;83(1):1-22. [pmid: 10845777].
New M J C, Stevenson J, Skuse D. Characteristics of mothers of boys who sexually abuse. Child Maltreat. 1999;4(1):21-31.
Newhill C E, Mulvey E P, Lidz C W. Characteristics of violence in the community by female patients seen in a psychiatric emergency service. Psychiatr Serv. 1995;46(8):785-9. [pmid: 7583478].
Nicol R, Stretch D, Whitney I. Mental health needs and services for severely troubled and troubling young people including young offenders in an N.H.S. region. J Adolesc. 2000;23(3):243-61. [pmid: 10837105].
Nijman H L I, Rector G. Crowding and aggression on inpatient psychiatric wards. Psychiatr Serv. 1999;50(6):830-1. [pmid: 10375156].
Ninness H A C, Ellis J, Miller W B, et al. The effect of a self-management training package on the transfer of aggression control procedures in the absence of supervision. Behav Modif. 1995;19(4):464-90. [pmid: 7487866].
Nock M K, Kazdin A E. Parent-directed physical aggression by clinic-referred youths. J Clin Child Adolesc Psychol. 2002;31(2):193-205. [pmid: 12056103].
Nolin M J, Davies E, Chandler K. Student victimization at school. J Sch Health. 1996;66(6):216-21. [pmid: 8866396].
Northrop D, Hamrick K. Weapons and minority youth violence. Public Health Rep. 1991;106(3):274-5. [pmid: 1905046].
Northrop D, Jacklin B, Cohen S, et al. Violence prevention strategies targeted towards high-risk minority youth. Public Health Rep. 1991;106(3):272-4. [pmid: 1905045].
Nugent W R, Bruley C, Allen P. The effects of aggression replacement training on antisocial behavior in a runaway shelter. Res Soc Work Pract. 1998;8(6):637-56.
Nugent W R, Bruley C, Allen P. The effects of Aggression Replacement Training on male and female antisocial behavior in a runaway shelter. Res Soc Work Pract. 1999;9(4):466-82.
Nutter D E, Kearns M E. Patterns of exposure to sexually explicit material among sex offenders, child molesters, and controls. J Sex Marital Ther. 1993;19(1):77-85. [pmid: 8468712].
O'Brien R M, Stockard J, Isaacson L. The enduring effects of cohort characteristics on age-specific homicide rates, 1960-1995. AJS. 1999;104(4):1061-95. [pmid: 11623716].
O'Connor B P, Dvorak T. Conditional associations between parental behavior and adolescent problems: A search for personality-environment interactions. J Res Pers. 2001;35(1):1-26.
O'Donnell L, Cohen S, Hausman A. Forum on youth violence in minority communities. Evaluation of community-based violence prevention programs. Public Health Rep. 1991;106(3):276-7. [pmid: 1905048].
O'Donnell L, Stueve A, San Doval A, et al. Violence prevention and young adolescents' participation in community youth service. J Adolesc Health. 1999;24(1):28-37. [pmid: 9890362].
ODS and OMAR. Procedures for EPC Reports for ODS and OMAR. 2003.
O'Keefe J J, Carr A, McQuaid P. Conduct disorder in girls and boys: The identification of distinct psychological profiles. Ir J Psychol. 1998;19(23):368-85.
O'Keefe M. Linking marital violence, mother^child/father^child aggression, and child behavior problems. J Fam Violence. 1994;9(1):63-78.
O'Keefe M. The differential effects of family violence on adolescent adjustment. Child Adolesc Social Work J. 1996;13(1):51-68.
O'Keefe M. Adolescents' exposure to community and school violence: prevalence and behavioral correlates. J Adolesc Health. 1997;20(5):368-76. [pmid: 9168384].
O'Keefe M. Predictors of dating violence among high school students. J Interpers Violence. 1997;12(4):546-68.
O'Keefe M. Factors mediating the link between witnessing interparental violence and dating violence. J Fam Violence. 1998;13(1):39-57.
Olds D, Henderson C R, Kitzman H, et al. Effects of prenatal and infancy nurse home visitation on surveillance of child maltreatment. Pediatrics. 1995;95(3):365-72. [pmid: 7862474].
Olds D, Pettitt L M, Robinson J, et al. Reducing risks for antisocial behavior with a program of prenatal and early childhood home visitation. J Community Psychol. 1998;26(1):65-83.
O'Leary K D, Malone J, Tyree A. Physical aggression in early marriage: prerelationship and relationship effects. J Consult Clin Psychol. 1994;62(3):594-602. [pmid: 8063986].
O'Leary K D, Slep A M S. A dyadic longitudinal model of adolescent dating aggression. J Clin Child Adolesc Psychol. 2003;32(3):314-27. [pmid: 12881021].
Oliver L L, Hall G C N, Neuhaus S M. A comparison of the personality and background characteristics of adolescent sex offenders and other adolescent offenders. Crim Justice Behav. 1993;20(4):359-70.
Olkin I, Sampson A. Comparison of meta-analysis versus analysis of variance of individual patient data. Biometrics. 1998;54(1):317-22. [pmid: 9544524].
Olweus D. Bully/victim problems in school: Facts and intervention. Eur J Psychol Educ. 1997;12(4):495-510.
Omar H A. Adolescent violence as viewed by high school students. Int J Adolesc Med Health. 1999;11(34):153-8.
Onwuachi-Saunders C, Forjuoh S N, West P, et al. Child death reviews: a gold mine for injury prevention and control. Inj Prev. 1999;5(4):276-9. [pmid: 10628916].
Orpinas P, Kelder S, Frankowski R, et al. Outcome evaluation of a multi-component violence-prevention program for middle schools: the Students for Peace project. Health Educ Res. 2000;15(1):45-58. [pmid: 10788201].
Orpinas P, Murray N, Kelder S. Parental influences on students' aggressive behaviors and weapon carrying. Health Educ Behav. 1999;26(6):774-87. [pmid: 10608570].
Orpinas P, Parcel G S, McAlister A, et al. Violence prevention in middle schools: a pilot evaluation. J Adolesc Health. 1995;17(6):360-71. [pmid: 8924442].
Orpinas P K, Basen-Engquist K, Grunbaum J A, et al. The co-morbidity of violence-related behaviors with health-risk behaviors in a population of high school students. J Adolesc Health. 1995;16(3):216-25. [pmid: 7779832].
Orwin R G, Maranda M, Ellis B. The effectiveness of substance abuse treatment in reducing violent behavior. J Psychopathol Behav Assess. 2000;22(4):309-24.
Osofsky J D. Community-based approaches to violence prevention. J Dev Behav Pediatr. 1997;18(6):405-7. [pmid: 9431503].
Pack R P, Wallander J L, Browne D. Health risk behaviors of African American adolescents with mild mental retardation: prevalence depends on measurement method. Am J Ment Retard. 1998;102(4):409-20. [pmid: 9475948].
Paikoff R L, Brooks-Gunn J, Warren M P. Effects of girls' hormonal status on depressive and aggressive symptoms over the course of one year. J Youth Adolesc. 1991;20(2):191-215.
Pakaslahti L, Keltikangas-Jaervinen L. Social acceptance and the relationship between aggressive problem-solving strategies and aggressive behaviour in 14-year-old adolescents. Eur J Personal. 1996;10(4):249-61.
Pakaslahti L, Keltikangas-Jaervinen L. The relationships between moral approval of aggression, aggressive problem-solving strategies, and aggressive behavior in 14-yr-old adolescents. J Soc Behav Pers. 1997;12(4):905-24.
Pakaslahti L, Keltikangas-Jaervinen L. Types of aggressive behavior among aggressive-preferred, aggressive non-preferred, non-aggressive preferred and non-aggressive non-preferred 14-year-old adolescents. Pers Individ Dif. 1998;24(6):821-8.
Pakaslahti L, Spoof I, Asplund-Peltola R-L, et al. Parents' social problem-solving strategies in families with aggressive and non-aggressive girls. Aggress Behav. 1998;24(1):37-51.
Pakiz B, Reinherz H Z, Giaconia R M. Early risk factors for serious antisocial behavior at age 21: a longitudinal community study. Am J Orthopsychiatry. 1997;67(1):92-101. [pmid: 9034025].
Palermo M T. Preventing filicide in families with autistic children. Int J Offender Ther Comp Criminol. 2003;47(1):47-57. [pmid: 14661382].
Pallone N J, Hennessy J J. Blacks and whites as victims and offenders in aggressive crime in the U.S. : myths and realities. J Offender Rehabil. 1999;30(1/2):1-33.
Palmer E J, Farmer S. Victimizing behaviour among juvenile and young offenders: How different are perpetrators?. J Adolesc. 2002;25(5):469-82. [pmid: 12234554].
Palmstierna T, Huitfeldt B, Wistedt B. The relationship of crowding and aggressive behavior on a psychiatric intensive care unit. Hosp Community Psychiatry. 1991;42(12):1237-40. [pmid: 1810862].
Palmstierna T, Wistedt B. Changes in the pattern of aggressive behaviour among inpatients with changed ward organization. Acta Psychiatr Scand. 1995;91(1):32-5. [pmid: 7754783].
Paschall M J, Ennett S T, Flewelling R L. Relationships among family characteristics and violent behavior by black and white male adolescents. J Youth Adolesc. 1996;25(2):177-97.
Paschall M J, Flewelling R L, Ennett S T. Racial differences in violent behavior among young adults: Moderating and confounding effects. J Res Crime Delinq. 1998;35(2):148-65.
Paschall M J, Hubbard M L. Effects of neighborhood and family stressors on African American male adolescents' self-worth and propensity for violent behavior. J Consult Clin Psychol. 1998;66(5):825-31. [pmid: 9803701].
Pate R R, Trost S G, Levin S, et al. Sports participation and health-related behaviors among US youth. Arch Pediatr Adolesc Med. 2000;154(9):904-11. [pmid: 10980794].
Paterson R, Luntz H, Perlesz A, et al. Adolescent violence towards parents: Maintaining family connections when the going gets tough. Aust N Z J Fam Ther. 2002;23(2):90-100.
Paulson M J, Coombs R H, Landsverk J. Youth who physically assault their parents. J Fam Violence. 1990;5(2):121-33.
Pedersen W, Wichstrom L, Blekesaune M. Violent behaviors, violent victimization, and doping agents: A normal population study of adolescents. J Interpers Violence. 2001;16(8):808-32.
Pellegrini A D, Long J D. A longitudinal study of bullying, dominance, and victimization during the transition from primary school through secondary school. Br J Dev Psychol. 2002;20(2):259-80.
Pellegrini R J, Roundtree T, Camagna T F, et al. On the epidemiology of violent juvenile crime in America: a total arrest-referenced approach. Psychol Rep. 2000;86(3 Pt 2):1171-86. [pmid: 10932576].
Pepler D, King G, Craig W, et al. The development and evaluation of a multisystem social skills group training program for aggressive children. Child Youth Care Forum. 1995;24(5):297-313.
Pepler D J, Craig W M, Roberts W L. Observations of aggressive and nonaggressive children on the school playground. Merrill Palmer Q. 1998;44(1):55-76.
Perez D M. Ethnic differences in property, violent, and sex offending for abused and nonabused adolescents. J Crim Justice. 2001;29(5):407-17.
Perry C L, Komro K A, Veblen-Mortenson S, et al. The Minnesota DARE PLUS Project: creating community partnerships to prevent drug use and violence. J Sch Health. 2000;70(3):84-8. [pmid: 10763475].
Perry C L, Komro K A, Veblen-Mortenson S, et al. A randomized controlled trial of the middle and junior high school D.A.R.E. and D.A.R.E. Plus programs. Arch Pediatr Adolesc Med. 2003;157(2):178-84. [pmid: 12580689].
Perry C L, Komro K A, Veblen-Mortenson S, et al. A randomized controlled trial of the middle and junior high school D.A.R.E. and D.A.R.E. Plus programs. Arch Pediatr Adolesc Med. 2003;157(2):178-84. [pmid: 12580689].
Peterson-Badali M, Koegl C J. Juveniles' experiences of incarceration: The role of correctional staff in peer violence. J Crim Justice. 2002;30(1):41-9.
Pharris M D. Coming to know ourselves as community through a nursing partnership with adolescents convicted of murder. ANS Adv Nurs Sci. 2002;24(3):21-42. [pmid: 11890193].
Phelps C E. Children's responses to overt and relational aggression. J Clin Child Psychol. 2001;30(2):240-52. [pmid: 11393924].
Phillips D R, Schwean V L, Saklofske D H. Treatment effect of a school based cognitive-behavioral program for aggressive children. Can J Sch Psychol. 1997;13(1):60-7.
Pickett W, Schmid H, Boyce W F, et al. Multiple risk behavior and injury: an international analysis of young people. Arch Pediatr Adolesc Med. 2002;156(8):786-93. [pmid: 12144369].
Pihl R O, Young S N, Harden P, et al. Acute effect of altered tryptophan levels and alcohol on aggression in normal human males. Psychopharmacology (Berl). 1995;119(4):353-60. [pmid: 7480513].
Pillmann F, Rohde A, Ullrich S, et al. Violence, criminal behavior, and the EEG: significance of left hemispheric focal abnormalities. J Neuropsychiatry Clin Neurosci. 1999;11(4):454-7. [pmid: 10570757].
Pine D S, Coplan J D, Wasserman G A, et al. Neuroendocrine response to fenfluramine challenge in boys: Associations with aggressive behavior and adverse rearing. Arch Gen Psychiatry. 1997;54(9):839-46. [pmid: 9294375].
Piquero A. Frequency, specialization, and violence in offending careers. J Res Crime Delinq. 2000;37(4):392-418.
Piquero A, Tibbetts S. The impact of pre/perinatal disturbances and disadvantaged familial environment in predicting criminal offending. Stud Crime Crime Prev. 1999;8(1):52-70.
Piquero A R, Brame R, Mazerolle P. Crime in Emerging Adulthood. Criminology. 2002;40(1):137-69.
Piquero A R, Buka S L. Linking juvenile and adult patterns of criminal activity in the Providence cohort of the National Collaborative Perinatal Project. J Crim Justice. 2002;30(4):259-72.
Piquero A R, MacDonald J M, Parker K F. Race, local life circumstances, and criminal activity. Soc Sci Q. 2002;83(3):654-70.
Pithers W D, Gray A, Busconi A, et al. Caregivers of children with sexual behavior problems: psychological and familial functioning. Child Abuse Negl. 1998;22(2):129-41. [pmid: 9504215].
Pittenger J. Domestic abuse: complicated by rural living. Wis Med J. 1997;96(8):22-4. [pmid: 9283261].
Pollard J A, Hawkins J D, Arthur M W. Risk and protection: Are both necessary to understand diverse behavioral outcomes in adolescence?. Soc Work Res. 1999;23(3):145-58.
Pope A W, Bierman K L. Predicting adolescent peer problems and antisocial activities: The relative roles of aggression and dysregulation. Dev Psychol. 1999;35(2):335-46. [pmid: 10082005].
Potthoff S J, Bearinger L H, Skay C L, et al. Dimensions of risk behaviors among American Indian youth. Arch Pediatr Adolesc Med. 1998;152(2):157-63. [pmid: 9491042].
Poulin F, Boivin M. The role of proactive and reactive aggression in the formation and development of boys' friendships. Dev Psychol. 2000;36(2):233-40. [pmid: 10749080].
Powell K B. Correlates of violent and nonviolent behavior among vulnerable inner-city youths. Fam Community Health. 1997;20(2):38-47.
Prentky R A, Knight R A, Lee A F. Risk factors associated with recidivism among extrafamilial child molesters. J Consult Clin Psychol. 1997;65(1):141-9. [pmid: 9103743].
Preski S, Shelton D. The role of contextual, child and parent factors in predicting criminal outcomes in adolescence. Issues Ment Health Nurs. 2001;22(2):197-205. [pmid: 11885223].
Prinstein M J, Boergers J, Spirito A. Adolescents' and their friends' health-risk behavior: Factors that alter or add to peer influence. J Pediatr Psychol. 2001;26(5):287-98. [pmid: 11390571].
Prinstein M J, Boergers J, Vernberg E M. Overt and relational aggression in adolescents: Social-psychological adjustment of aggressors and victims. J Community Psychol. 2001;30(4):479-91.
Pritchard C, Cox M. The criminality of former “special educational provision” permanently “excluded from school” adolescents as young adults (16–23): costs and practical implications. J Adolesc. 1998;21(5):609-20. [pmid: 9799551].
Proimos J, DuRant R H, Pierce J D, et al. Gambling and other risk behaviors among 8th- to 12th-grade students. Pediatrics. 1998;102(2):E23. [pmid: 9685469].
Pulkkinen L. Proactive and reactive aggression in early adolescence as precursors to anti- and prosocial behavior in young adults. Aggress Behav. 1996;22(4):241-57.
Pulkkinen L, Pitkaenen T. Continuities in aggressive behavior from childhood to adulthood. Aggress Behav. 1993;19(4):249-63.
Putnam F W, Hornstein N, Peterson G. Clinical Phenomenology of Child and Adolescent Dissociative Disorders: Gender and Age Effects. Child Adolesc Psychiatr Clin N Am. 1996;5(2):351-60.
Quiggle N L, Garber J, Panak W F, et al. Social information processing in aggressive and depressed children. Child Dev. 1992;63(6):1305-20. [pmid: 1446554].
Quinn J F, Downs B. Predictors of gang violence: The impact of drugs and guns on police perceptions in nine states. J Gang Res. 1995;2(3):15-27.
Quinn K P, Newman D L, Cumblad C. Behavioral characteristics of children and youth at risk for out-of-home placements. J Emot Behav Disord. 1995;3(3):166-73.
Racey B D, Lopez N L, Schneider H G. Sexually assaultive adolescents: Cue perception, interpersonal competence and cognitive distortions. Int J Adolesc Youth. 2000;8(23):229-39.
Rahey L, Craig W M. Evaluation of an ecological program to reduce bullying in schools. Can J Couns. 2002;36(4):281-96.
Raine A, Brennan P, Mednick B, et al. High rates of violence, crime, academic problems, and behavioral problems in males with both early neuromotor deficits and unstable family environments. Arch Gen Psychiatry. 1996;53(6):544-9. [pmid: 8639038].
Raine A, Brennan P, Mednick S A. Birth complications combined with early maternal rejection at age 1 year predispose to violent crime at age 18 years. Arch Gen Psychiatry. 1994;51(12):984-8. [pmid: 7979887].
Raine A, Phil D, Stoddard J, et al. Prefrontal glucose deficits in murderers lacking psychosocial deprivation. Neuropsychiatry Neuropsychol Behav Neurol. 1998;11(1):1-7. [pmid: 9560822].
Rakoff V M. Trauma and adolescent rites of initiation. Adolesc Psychiatry. 1995;20:109-23. [pmid: 7598181].
Ralph N, Morgan K A. Assessing differences in chemically dependent adolescent males using the Child Behavior Checklist. Adolescence. 1991;26(101):183-94. [pmid: 2048471].
Raine A. Biosocial studies of antisocial and violent behavior in children and adults: a review. J Abnorm Child Psychol. 2002;30(4):312-26. [pmid: 12403151].
Randall J, Henggeler S W, Pickrel S G, et al. Psychiatric comorbidity and the 16-month trajectory of substance-abusing and substance-dependent juvenile offenders. J Am Acad Child Adolesc Psychiatry. 1999;38(9):1118-24. [pmid: 10560218].
Rando R A, Rogers J R, Brittan-Powell C S. Gender role conflict and college men's sexually aggressive attitudes and behavior. J Ment Health Couns. 1998;20(4):359-69.
Rao U, Carlson G A, Rapport M D. Serum cholesterol and aggressive behavior in psychiatrically hospitalized children. Acta Psychiatr Scand. 1991;83(1):77-8. [pmid: 2011960].
Rapp-Paglicci L A, Wodarski J S. Antecedent behaviors of male youth victimization: An exploratory study. Deviant Behav. 2000;21(6):519-36.
Rasanen E, Hirvenoja R, Hakko H, et al. A portrait of the juvenile arsonist. Forensic Sci Int. 1995;73(1):41-7. [pmid: 7750881].
Ray J A, English D J. Comparison of female and male children with sexual behavior problems. J Youth Adolesc. 1995;24(4):439-51.
Reebye P, Moretti M M, Wiebe V J, et al. Symptoms of posttraumatic stress disorder in adolescents with conduct disorder: sex differences and onset patterns. Can J Psychiatry. 2000;45(8):746-51. [pmid: 11086558].
Reiss S, Rojahn J. Joint occurrence of depression and aggression in children and adults with mental retardation. J Intellect Disabil Res. 1993;37(3):287-94. [pmid: 8334320].
Remington P L, Stahlsmith L, Nashold R. Assessing the increase in firearm-related homicides in Wisconsin, 1979-1993. Wis Med J. 1995;94(2):88-90. [pmid: 7740823].
Resnick M D, Bearman P S, Blum R W, et al. Protecting adolescents from harm. Findings from the National Longitudinal Study on Adolescent Health. JAMA. 1997;278(10):823-32. [pmid: 9293990].
Resnick M D, Harris L J, Blum R W. The impact of caring and connectedness on adolescent health and well-being. J Paediatr Child Health. 1993;29(Suppl 1):s3-9. [pmid: 8268019].
Reynolds A J, Temple J A, Robertson D L, et al. Long-term effects of an early childhood intervention on educational achievement and juvenile arrest: A 15-year follow-up of low-income children in public schools. JAMA. 2001;285(18):2339-46. [pmid: 11343481].
Rhodes J E, Fischer K. Spanning the gender gap: gender differences in delinquency among inner-city adolescents. Adolescence. 1993;28(112):879-89. [pmid: 8266841].
Rican P, Klicperova M, Koucka Ta. Families of bullies and their victims: A children's view. Stud Psychol (Bratisl). 1993;35(3):261-6.
Rich J A, Sullivan L M. Correlates of violent assault among young male primary care patients. J Health Care Poor Underserved. 2001;12(1):103-12. [pmid: 11217223].
Riggs N, Houry D, Long G, et al. Analysis of 1,076 cases of sexual assault. Ann Emerg Med. 2000;35(4):358-62. [pmid: 10736122].
Riner M E, Saywell R M. Development of the social ecology model of adolescent interpersonal violence prevention (SEMAIVP). J Sch Health. 2002;72(2):65-70. [pmid: 11905131].
Ringwalt C L, Graham L A, Paschall M J, et al. Supporting Adolescents with Guidance and Employment (SAGE). Am J Prev Med. 1996;12(5 Suppl):31-8. [pmid: 8909622].
Risler E A, Sweatman T, Nackerud L. Evaluating the Georgia legislative Waiver's effectiveness in deterring juvenile crime. Res Soc Work Pract. 1998;8(6):657-67.
Ritter J, Stewart M, Bernet C, et al. Effects of childhood exposure to familial alcoholism and family violence on adolescent substance use, conduct problems, and self-esteem. J Trauma Stress. 2002;15(2):113-22. [pmid: 12013062].
Rivara F P. Injury research and violence: what's our contribution?. Inj Prev. 1996;2(4):249. [pmid: 9346085].
Rivara F P, Shepherd J P, Farrington D P, et al. Victim as offender in youth violence. Ann Emerg Med. 1995;26(5):609-14. [pmid: 7486371].
Rivera B, Widom C S. Childhood victimization and violent offending. Violence Vict. 1990;5(1):19-35. [pmid: 2278946].
Rivers I, Soutter A. Bullying and the Steiner School ethos: A case study analysis of a group-centered educational philosophy. Sch Psychol Int. 1996;17(4):359-77.
Roberto A J, Meyer G, Boster F J, et al. Adolescents' decisions about verbal and physical aggression: An application of the theory of reasoned action. Hum Commun Res. 2003;29(1):135-47.
Roberto A J, Meyer G, Boster F J, et al. Adolescents' decisions about verbal and physical aggression: An application of the theory of reasoned action. Hum Commun Res. 2003;29(1):135-47.
Roberts T A, Ryan S A, et al. Tattooing and high-risk behavior in adolescents. Pediatrics. 2002;110(6):1058-63. [pmid: 12456900].
Robertson S. Separating the men from the boys: masculinity, psychosexual development, and sex crime in the United States, 1930s-1960s. J Hist Med Allied Sci. 2001;56(1):3-35. [pmid: 11236235].
Rodney H E, Tachia H R, Rodney L W. The effect of family and social support on feelings and past acts of violence among African American college men. J Am Coll Health. 1997;46(3):103-8. [pmid: 9394087].
Rodney H E, Tachia H R, Rodney L W. The home environment and delinquency: A study of African American adolescents. Fam Soc. 1999;80(6):551-9.
Rodriguez MA, Solorio R, Hayes-Bautista DE, et al. Health risks of Latino children. JAMA 2002;288(16):1981; Discussion 3.
Roff J D. Childhood aggression, peer status, and social class as predictors of delinquency. Psychol Rep. 1992;70(1):31-4. [pmid: 1565737].
Roitberg T, Menard S. Adolescent violence: A test of integrated theory. Stud Crime Crime Prev. 1995;4(2):177-96.
Romi S, Itskowitz R. The relationship between locus of control and type of aggression in middle-class and culturally deprived children. Pers Individ Dif. 1990;11(4):327-33.
Ronen T. Imparting self-control skills in the school setting. Child Fam Behav Ther. 1994;16(1):1-20.
Rosen P M, Walsh B W, Rode S A. Interpersonal loss and self-mutilation. Suicide Life Threat Behav. 1990;20(2):177-84. [pmid: 2385860].
Rosenbaum J L. A violent few: Gang girls in the California Youth Authority. J Gang Res. 1996;3(3):17-23.
Rosenberg M F, Anthony J C. Aggressive behavior and opportunities to purchase drugs. Drug Alcohol Depend. 2001;63(3):245-52. [pmid: 11543982].
Rosenfeld R, Bray T M, Egley A. Facilitating violence: A comparison of gang-motivated, gang-affiliated and nongang youth homicides. J Quant Criminol. 1999;15(4):495-516.
Rossman B B R. Multiple risks for children exposed to parental violence: Family factors, psychological maltreatment, and trauma. J Aggress Maltreat Trauma. 1999;2(2):207-37.
Rowe D C, Almeida D M, Jacobson K C. School context and genetic influences on aggression in adolescence. Psychol Sci. 1999;10(3):277-80.
Rubenstein J L, Feldman S S. Conflict-resolution behavior in adolescent boys: Antecedents and adaptational correlates. J Res Adolesc. 1993;3(1):41-66.
Rubin K H, Chen X, McDougall P, et al. The Waterloo Longitudinal Project: Predicting internalizing and externalizing problems in adolescence. Dev Psychopathol. 1995;7(4):751-64.
Rubinstein M, Yeager C A, Goodstein C, et al. Sexually assaultive male juveniles: a follow-up. Am J Psychiatry. 1993;150(2):262-5. [pmid: 8422077].
Rucker N, Greene V. The myth of the invulnerable self of adolescence. Am J Psychoanal. 1995;55(4):369-79. [pmid: 8644892].
Russell A, Owens L. Peer estimates of school-aged boys' and girls' aggression to same- and cross-sex targets. Soc Dev. 1999;8(3):364-79.
Russell S T, Franz B T, Driscoll A K. Same-sex romantic attraction and experiences of violence in adolescence. Am J Public Health. 2001;91(6):903-6. [pmid: 11392932]. [pmcid: 1446466].
Rys G S, Bear G G. Relational aggression and peer relations: Gender and developmental issues. Merrill Palmer Q. 1997;43(1):87-106.
Sachs J J, Miller S R. The impact of a wilderness experience on the social interactions and social expectations of behaviorally disordered adolescents. Behav Disord. 1992;17(2):89-98.
Saigal S, Pinelli J, Hoult L, et al. Psychopathology and social competencies of adolescents who were extremely low birth weight. Pediatrics. 2003;111(5 Pt 1):969-75. [pmid: 12728073].
Salekin K L, Ogloff J R P, Ley R G, et al. The overcontrolled hostility scale: An evaluation of its applicability with an adolescent population. Crim Justice Behav. 2002;29(6):718-33.
Salfati C G, Canter D V. Differentiating stranger murders: Profiling offender characteristics from behavioral styles. Behav Sci Law. 1999;17(3):391-406. [pmid: 10481136].
Salmivalli C. Intelligent, attractive, well-behaving, unhappy: The structure of adolescents' self-concept and its relations to their social behavior. J Res Adolesc. 1998;8(3):333-54.
Salmivalli C, Karhunen J, Lagerspetz K M J. How do the victims respond to bullying?. Aggress Behav. 1996;22(2):99-109.
Salmivalli C, Kaukiainen A, Kaistaniemi L, et al. Self-evaluated self-esteem, peer-evaluated self-esteem, and defensive egotism as predictors of adolescents' participation in bullying situations. Pers Soc Psychol Bull. 1999;25(10):1268-78.
Salmivalli C, Kaukiainen A, Lagerspetz K. Aggression and sociometric status among peers: Do gender and type of aggression matter?. Scand J Psychol. 2000;41(1):17-24. [pmid: 10731839].
Salmivalli C, Nieminen E. Proactive and reactive aggression among school bullies, victims, and bully-victims. Aggress Behav. 2002;28(1):30-44.
Salts C J, Lindholm B W, Goddard H W, et al. Predictive variables of violent behavior in adolescent males. Youth Soc. 1995;26(3):377-99.
Salzinger S, Feldman R S, Hammer M, et al. Constellations of family violence and their differential effects on children's behavioral disturbance. Child Fam Behav Ther. 1992;14(4):23-41.
Salzinger S, Feldman R S, Ng-Mak D S, et al. Effects of partner violence and physical child abuse on child behavior: A study of abused and comparison children. J Fam Violence. 2002;17(1):23-52.
SAMHSA. The NHSDA report. Youth violence and substance use: 2001 update. Accessed: May 2004. http://www.oas.samhsa.gov/2k2/YouthViolence/YouthViolence.cfm.
Sampson R J, Morenoff J D, Gannon-Rowley T. Assessing “neighborhood effects”: social processes and new directions in research. Annu Rev Sociol. 2002;28:443-78.
Sandor P, Stephens R J. Risperidone treatment of aggressive behavior in children with Tourette syndrome. J Clin Psychopharmacol. 2000;20(6):710-2. [pmid: 11106151].
Saner H, Ellickson P. Concurrent risk factors for adolescent violence. J Adolesc Health. 1996;19(2):94-103. [pmid: 8863080].
Santman J, Myner J, Cappelletty G G, et al. California juvenile gang members: An analysis of case records. J Gang Res. 1997;5(1):45-53.
Sarigiani P A, Ryan L, Petersen A C. Prevention of high-risk behaviors in adolescent women. J Adolesc Health. 1999;25(2):109-19. [pmid: 10447038].
Sarne Y, Mandel J, Goncalves M H, et al. Imipramine binding to blood platelets and aggressive behavior in offenders, schizophrenics and normal volunteers. Neuropsychobiology. 1995;31(3):120-4. [pmid: 7609859].
Satcher D. Youth violence: A report of the surgeon general. Accessed: May 2004. http://www.surgeongeneral.gov/library/youthviolence/.
Satcher D, Powell K E, Mercy J A, et al. Violence prevention is as American as apple pie. Am J Prev Med. 1996;12(5 Suppl):V-Vi. [pmid: 8909617].
Satterfield J H, Swanson J, Schell A M, et al. Prediction of antisocial behavior in attention-deficit hyperactivity disorder boys from aggression/defiant scores. J Am Acad Child Adolesc Psychiatry. 1994;33(2):185-90. [pmid: 8150789].
Sayger T V, Horne A M, Glaser B A. Marital satisfaction and social learning family therapy for child conduct problems: Generalization of treatment effects. J Marital Fam Ther. 1993;19(4):393-402. [pmid: 21118477].
Scerbo A S, Kolko D J. Salivary testosterone and cortisol in disruptive children: Relationship to aggressive, hyperactive, and internalizing behaviors. J Am Acad Child Adolesc Psychiatry. 1994;33(8):1174-84. [pmid: 7982868].
Scerbo A S, Kolko D J. Child physical abuse and aggression: preliminary findings on the role of internalizing problems. J Am Acad Child Adolesc Psychiatry. 1995;34(8):1060-6. [pmid: 7665445].
Schaal B, Tremblay R E, Soussignan R, et al. Male testosterone linked to high social dominance but low physical aggression in early adolescence. J Am Acad Child Adolesc Psychiatry. 1996;35(10):1322-30. [pmid: 8885586].
Scheidlinger S. The centrality of the peer group's role in two aspects of school violence revisited. Int J Group Psychother. 2003;53(2):245-9. [pmid: 12712591].
Scherer D G, Brondino M J, Henggeler S W, et al. Multisystemic Family Preservation Therapy: Preliminary findings from a study of rural and minority serious adolescent offenders. J Emot Behav Disord. 1994;2(4):198-206.
Scherer D G, Others A. Multisystemic family preservation therapy: Preliminary findings from a study of rural and minority serious adolescent offenders. J Emot Behav Disord. 1994;2(4):198-206.
Scherzer T, Pinderhughes H L. Violence and gender: reports from an urban high school. Violence Vict. 2002;17(1):57-72. [pmid: 11991157].
Schiff M, Cavaiola A A. Child abuse, adolescent substance abuse, and “deadly violence”. J Adolesc Chem Depend. 1993;2(34):131-41.
Schinke S, Jansen M, Kennedy E, et al. Reducing risk-taking behavior among vulnerable youth: An intervention outcome study. Fam Community Health. 1994;16(4):49-56.
Schoenthaler S J, Bier I D. The effect of vitamin-mineral supplementation on juvenile delinquency among American schoolchildren: a randomized, double-blind placebo-controlled trial. J Altern Complement Med. 2000;6(1):7-17. [pmid: 10706232].
Scholte E M. Factors predicting continued violence into young adulthood. J Adolesc. 1999;22(1):3-20. [pmid: 10579893].
Schreiber E H. A study of the personality of violent children. N Am J Psychol. 1999;1(1):51-6.
Schreiber E L, Screiber K N. A study of parents of violent children. Psychol Rep. 2002;90(1):101-4. [pmid: 11898970].
Schreier H A. Risperidone for young children with mood disorders and aggressive behavior. J Child Adolesc Psychopharmacol. 1998;8(1):49-59. [pmid: 9639079].
Schubiner H, Scott R, Tzelepis A. Exposure to violence among inner-city youth. J Adolesc Health. 1993;14(3):214-9. [pmid: 8323933].
Schulenberg S E, Soundy T. Epidemiology of physical and sexual abuse in young persons diagnosed with conduct disorder: a retrospective chart review. S D J Med. 2000;53(1):29-32. [pmid: 10652863].
Schwab C W, Richmond T S, Cheney R A, et al. Risk factors for violent death in children. JAMA. 2002;287(8):983-4. [pmid: 11866633].
Schwab-Stone M, Chen C, Greenberger E, et al. No safe haven. II: The effects of violence exposure on urban youth. J Am Acad Child Adolesc Psychiatry. 1999;38(4):359-67. [pmid: 10199106].
Schwartz C E, Snidman N, Kagan J. Early childhood temperament as a determinant of externalizing behavior in adolescence. Dev Psychopathol. 1996;8(3):527-37.
Schwartz D. Subtypes of victims and aggressors in children's peer groups. J Abnorm Child Psychol. 2000;28(2):181-92. [pmid: 10834769].
Schwartz M, O'Leary S G, Kendziora K T. Dating aggression among high school students. Violence Vict. 1997;12(4):295-305. [pmid: 9591350].
Schwartz R H, Little D L. Let's party tonight: drinking patterns and breath alcohol values at high school parties. Fam Med. 1997;29(5):326-31. [pmid: 9165284].
Schwartzberg A Z. Risk factors for adolescent violence: Implications for prevention and treatment. Int J Adolesc Med Health. 1999;11(34):429-37.
Scott K D, Schafer J, Greenfield T K. The role of alcohol in physical assault perpetration and victimization. J Stud Alcohol. 1999;60(4):528-36. [pmid: 10463810].
Scott K K, Tepas J J, Frykberg E, et al. Turning point: rethinking violence--evaluation of program efficacy in reducing adolescent violent crime recidivism. J Trauma. 2002;53(1):21-7. [pmid: 12131384].
Sege R D, Kharasch S, Perron C, et al. Pediatric violence-related injuries in Boston: results of a city-wide emergency department surveillance program. Arch Pediatr Adolesc Med. 2002;156(1):73-6. [pmid: 11772194].
Sege R, Stringham P, Short S, et al. Ten years after: examination of adolescent screening questions that predict future violence-related injury. J Adolesc Health. 1999;24(6):395-402. [pmid: 10401967].
Seguin J R, Arseneault L, Boulerice B, et al. Response perseveration in adolescent boys with stable and unstable histories of physical aggression: The role of underlying processes. J Child Psychol Psychiatry. 2002;43(4):481-94. [pmid: 12030594].
Seguin J R, Boulerice B, Harden P W, et al. Executive functions and physical aggression after controlling for attention deficit hyperactivity disorder, general memory, and IQ. J Child Psychol Psychiatry. 1999;40(8):1197-208. [pmid: 10604398].
Seguin J R, Pihl R O, Boulerice B, et al. Low pain sensitivity and stability of physical aggression in boys. Ann N Y Acad Sci. 1996;794:408-10. [pmid: 8853627].
Seguin J R, Pihl R O, Harden P W, et al. Cognitive and neuropsychological characteristics of physically aggressive boys. J Abnorm Psychol. 1995;104(4):614-24. [pmid: 8530764].
Seidenwurm D, Pounds T R, Globus A, et al. Abnormal temporal lobe metabolism in violent subjects: correlation of imaging and neuropsychiatric findings. AJNR Am J Neuroradiol. 1997;18(4):625-31. [pmid: 9127022].
Seidman E, Yoshikawa H, Roberts A, et al. Structural and experiential neighborhood contexts, developmental stage, and antisocial behavior among urban adolescents in poverty. Dev Psychopathol. 1998;10(2):259-81. [pmid: 9635224].
Seifert K, Phillips S, Parker S. Child and Adolescent Risk for Violence (CARV): A tool to assess juvenile risk. J Psychiatry Law. 2001;29(3):329-46.
Selkurt J. Teens and domestic violence. Wis Med J. 1994;93(1):29. [pmid: 8160482].
Selner-O'Hagan M B, Kindlon D J, Buka S L, et al. Assessing exposure to violence in urban youth. J Child Psychol Psychiatry. 1998;39(2):215-24. [pmid: 9669234].
Sequeira H, Halstead S. “Is it meant to hurt, is it?”: Management of violence in women with developmental disabilities. Violence Against Women. 2001;7(4):462-76.
Shackelford T K. Risk of multiple-offender rape-murder varies with female age. J Crim Justice. 2002;30(2):135-41.
Shahinfar A, Kupersmidt J B, Matza L S. The relation between exposure to violence and social information processing among incarcerated adolescents. J Abnorm Psychol. 2001;110(1):136-41. [pmid: 11261387].
Shahpar C, Li G. Homicide mortality in the United States, 1935-1994: age, period, and cohort effects. Am J Epidemiol. 1999;150(11):1213-22. [pmid: 10588082].
Shapiro J P, Welker C J, Pierce J L. An evaluation of residential treatment for sexually aggressive youth. J Child Sex Abus. 2001;10(1):1-21. [pmid: 16221618].
Sharps P W, Campbell J, Campbell D, et al. The role of alcohol use in intimate partner femicide. Am J Addict. 2001;10(2):122-35. [pmid: 11444155].
Shaw J A, Campo-Bowen A E, Applegate B, et al. Young boys who commit serious sexual offenses: demographics, psychometrics, and phenomenology. Bull Am Acad Psychiatry Law. 1993;21(4):399-408. [pmid: 8054670].
Shechtman Z, Ben-David M. Individual and group psychotherapy of childhood aggression: A comparison of outcomes and processes. Group Dyn. 1999;3(4):263-74.
Sheehan K, DiCara J A, LeBailly S, et al. Adapting the gang model: peer mentoring for violence prevention. Pediatrics. 1999;104(1 Pt 1):50-4. [pmid: 10390259].
Sheley J F. Drugs and guns among inner-city high school students. J Drug Educ. 1994;24(4):303-21. [pmid: 7869222].
Sheley J F, Brewer V E. Possession and carrying of firearms among suburban youth. Public Health Rep. 1995;110(1):18-26. [pmid: 7838938]. [pmcid: 1382069].
Shepherd J P, Farrington D P. Preventing crime and violence. BMJ. 1995;310(6975):271-2. [pmid: 7866163].
Sheras P L, Cornell D G, Bostain D S. The Virginia Youth Violence Project: Transmitting psychological knowledge on youth violence to schools and communities. Prof Psychol Res Pract. 1996;27(4):401-6.
Sherman LW, Gottfredson D. Preventing crime: What works, what doesn't, what's promising. Appendix: Research methods. Accessed: May 2004. http://www.ncjrs.org/works/appendix.htm.
Shields A, Cicchetti D. Reactive aggression among maltreated children: The contributions of attention and emotion dysregulation. J Clin Child Psychol. 1998;27(4):381-95. [pmid: 9866075].
Shields A, Cicchetti D. Parental maltreatment and emotion dysregulation as risk factors for bullying and victimization in middle childhood. J Clin Child Psychol. 2001;30(3):349-63. [pmid: 11501252].
Shields E W. Intimidation and violence by males in high school athletics. Adolescence. 1999;34(135):503-21. [pmid: 10730694].
Shields N, Pierce L. Factors related to aggressive and violent behavior among preadolescent African-American boys. Int J Adolesc Youth. 2001;10(12):51-68.
Shoda Y, Mischel W, Wright J C. The role of situational demands and cognitive competencies in behavior organization and personality coherence. J Pers Soc Psychol. 1993;65(5):1023-35. [pmid: 8246110].
Shonkoff JP, Phillips D. From neurons to neighborhoods : the science of early child development. Washington, D.C.: National Academy Press; 2000.
Shumaker D M, McKee G R. Characteristics of homicidal and violent juveniles. Violence Vict. 2001;16(4):401-9. [pmid: 11506449].
Shumaker D M, Prinz R J. Children who murder: a review. Clin Child Fam Psychol Rev. 2000;3(2):97-115. [pmid: 11227064].
Sikand V K. A violence prevention program targeting adolescents. Conn Med. 1996;60(1):41. [pmid: 8821929].
Silverman R A, Kennedy L W. Women who kill their children. Violence Vict. 1988;3(2):113-27. [pmid: 3154174].
Simic M, Fombonne E. Depressive conduct disorder: symptom patterns and correlates in referred children and adolescents. J Affect Disord. 2001;62(3):175-85. [pmid: 11223105].
Simon T R, Sussman S, Dahlberg L L, et al. Influence of a substance-abuse-prevention curriculum on violence-related behavior. Am J Health Behav. 2002;26(2):103-10. [pmid: 11926674].
Simonoff E, Pickles A, Meyer J, et al. Genetic and environmental influences on subtypes of conduct disorder behavior in boys. J Abnorm Child Psychol. 1998;26(6):495-509. [pmid: 9915655].
Simons K J, Paternite C E, Shore C. Quality of parent/adolescent attachment and aggression in young adolescents. J Early Adolesc. 2001;21(2):182-203.
Simons R L, Johnson C, Conger R D. Harsh corporal punishment versus quality of parental involvement as an explanation of adolescent maladjustment. J Marriage Fam. 1994;56(3):591-607.
Simons R L, Lin K-H, Gordon L C. Socialization in the family of origin and male dating violence: A prospective study. J Marriage Fam. 1998;60(2):467-78.
Simons R L, Whitbeck L B, Beaman J, et al. The impact of mothers' parenting, involvement by nonresidential fathers, and parental conflict on the adjustment of adolescent children. J Marriage Fam. 1994;56(2):356-74.
Simonson H. Interaction effects of television and socioeconomic status on teenage aggression. Int J Adolesc Youth. 1992;3(34):333-43.
Singer M H. How central is the analysis of aggression to clinical psychoanalysis?. J Am Psychoanal Assoc. 1999;47(4):1179-89. [pmid: 10650556].
Singer M I, Flannery D J. The relationship between children's threats of violence and violent behaviors. Arch Pediatr Adolesc Med. 2000;154(8):785-90. [pmid: 10922274].
Singer M I, Miller D B, Guo S, et al. Contributors to violent behavior among elementary and middle school children. Pediatrics. 1999;104(4 Pt 1):878-84. [pmid: 10506229].
Singer M I, Slovak K, Frierson T, et al. Viewing preferences, symptoms of psychological trauma, and violent behaviors among children who watch television. J Am Acad Child Adolesc Psychiatry. 1998;37(10):1041-8. [pmid: 9785715].
Singleton E G, Dale G A J. Lack of co-occurring interpersonal violence-related emotional difficulties and alcohol or other drug problems among African American youth with conduct disorder. J Negro Educ. 1996;65(4):445-53.
Skeem J L, Mulvey E P. Psychopathy and community violence among civil psychiatric patients: results from the MacArthur Violence Risk Assessment Study. J Consult Clin Psychol. 2001;69(3):358-74. [pmid: 11495166].
Skelton D L, Glynn M A, Berta S M. Aggressive behavior as a function of taekwondo ranking. Percept Mot Skills. 1991;72(1):179-82. [pmid: 2038512].
Skiba R J, Knesting K, et al. Zero tolerance, zero evidence: an analysis of school disciplinary practice. New Dir Youth Dev. 2001;92:17-43. [pmid: 12170829].
Skinner M L, Elder G H, Conger R D. Linking economic hardship to adolescent aggression. J Youth Adolesc. 1992;21(3):259-76.
Skovholt T, Cognetta P, Ye G, et al. Violence prevention strategies of inner-city student experts. Prof Sch Couns. 1997;1(1):35-8.
Slabbekoorn D, Van Goozen SHM, Gooren LJG, et al. Effects of cross-sex hormone treatment on emotionality in transsexuals. Int J Transgenderism 2001;5(3):NP.
Slovak K, Singer M. Gun violence exposure and trauma among rural youth. Violence Vict. 2001;16(4):389-400. [pmid: 11506448].
Smith A M, Gacono C B, Kaufman L. A Rorschach comparison of psychopathic and nonpsychopathic conduct disordered adolescents. J Clin Psychol. 1997;53(4):289-300. [pmid: 9169383].
Smith A M, Gacono C B, Kaufman L. A Rorschach comparison of psychopathic and nonpsychopathic conduct disordered adolescents. J Clin Psychol. 1997;53:289-300. [pmid: 9169383].
Smith A T, Kuller L H, Perper J A, et al. Epidemiology of homicide in Allegheny County, Pennsylvania, between 1966-1974 and 1984-1993. Prev Med. 1998;27(3):452-60. [pmid: 9612836].
Smith C A. Dis-attachment. Aust N Z J Psychiatry. 1994;28(4):691-3. [pmid: 7794214].
Smith H, Thomas S. Violent and nonviolent girls: contrasting perceptions of anger experiences, school, and relationships. Issues Ment Health Nurs. 2000;21(5):547-75. [pmid: 11261077].
Smith J P, Williams J G. From abusive household to dating violence. J Fam Violence. 1992;7(2):153-65.
Smith M A, Jenkins J M. The effects of marital disharmony on prepubertal children. J Abnorm Child Psychol. 1991;19(6):625-44. [pmid: 1791270].
Smith M D, Feiler S M. Absolute and relative involvement in homicide offending: contemporary youth and the baby boom cohorts. Violence Vict. 1995;10(4):327-33. [pmid: 8703844].
Smith P, Flay B R, Bell C C, et al. The protective influence of parents and peers in violence avoidance among African-American youth. Matern Child Health J. 2001;5(4):245-52. [pmid: 11822526].
Smith S, Kern R M, Curlette W L, et al. Lifestyle profiles and interventions for aggressive adolescents. J Individ Psychol. 2001;57(3):224-45.
Smith S, Mullis F, Kern R M, et al. An Adlerian model for the etiology of aggression in adjudicated adolescents. Fam J. 1999;7(2):135-47.
Smith S L, Howard J A, Monroe A D. Issues underlying behavior problems in at-risk adopted children. Child Youth Serv Rev. 2000;22(7):539-62.
Snyder R, Turgay A, Aman M, et al. Effects of risperidone on conduct and disruptive behavior disorders in children with subaverage IQs. J Am Acad Child Adolesc Psychiatry. 2002;41(9):1026-36. [pmid: 12218423].
Soderstrom H, Blennow K, Manhem A, et al. CSF studies in violent offenders. II. Blood-brain barrier dysfunction without concurrent inflammation or structure degeneration. J Neural Transm. 2001;108(7):879-86. [pmid: 11515753].
Soderstrom H, Blennow K, Manhem A, et al. CSF studies in violent offenders. I. 5-HIAA as a negative and HVA as a positive predictor of psychopathy. J Neural Transm. 2001;108(7):869-78. [pmid: 11515753].
Sommers I, Baskin D R. Factors related to female adolescent initiation into violent street crime. Youth Soc. 1994;25:468-89.
Sommers I, Baskin D R. Situational or generalized violence in drug dealing networks. J Drug Issues. 1997;27(4):833-49.
Sommers I, Fagan J, Baskin D. Sociocultural influences on the explanation of delinquency for Puerto Rican youths. Hisp J Behav Sci. 1993;15(1):36-62.
Song L Y, Singer M I, Anglin T M. Violence exposure and emotional trauma as contributors to adolescents' violent behaviors. Arch Pediatr Adolesc Med. 1998;152(6):531-6. [pmid: 9641704].
Sosin D M, Koepsell T D, Rivara F P, et al. Fighting as a marker for multiple problem behaviors in adolescents. J Adolesc Health. 1995;16(3):209-15. [pmid: 7779831].
Sourander A, Aurela A, Piha J. Therapeutic holding in child and adolescent psychiatric inpatient treatment. Nord J Psychiatry. 1996;50(5):375-80.
Sourander A, Helstela L, Helenius H. Persistence of bullying from childhood to adolescence--a longitudinal 8-year follow-up study. Child Abuse Negl. 2000;24(7):873-81. [pmid: 10905413].
Spaccarelli S, Bowden B, Coatsworth J D, et al. Psychosocial correlates of male sexual aggression in a chronic delinquent sample. Crim Justice Behav. 1997;24(1):71-95.
Spaccarelli S, Coatsworth J D, Bowden B S. Exposure to serious family violence among incarcerated boys: its association with violent offending and potential mediating variables. Violence Vict. 1995;10(3):163-82. [pmid: 8777184].
Spergel I A, Grossman S F. The Little Village Project: A community approach to the gang problem. Soc Work. 1997;42(5):456-70. [pmid: 9311304].
Spigelman G, Spigelman A, Englesson I. Hostility, aggression, and anxiety levels of divorce and nondivorce children as manifested in their responses to projective tests. J Pers Assess. 1991;56(3):438-52. [pmid: 1865304].
Spillane-Grieco E. From parent verbal abuse to teenage physical aggression?. Child Adolesc Social Work J. 2000;17(6):411-30.
Spingarn R W, DuRant R H. Male adolescents involved in pregnancy: associated health risk and problem behaviors. Pediatrics. 1996;98(2 Pt 1):262-8. [pmid: 8692628].
Spitz R T, Hillbrand M, Foster H G, et al. Ethnicity, aggression and serum creatine kinase in hospitalized male forensic patients. Ethn Dis. 1997;7(3):259-70. [pmid: 9467709].
Sprague J, Walker H M, Stieber S, et al. Exploring the relationship between school discipline referrals and delinquency. Psychol Sch. 2001;38(2):197-206.
Spunt B, Goldstein P, Brownstein H, et al. The role of marijuana in homicide. Int J Addict. 1994;29(2):195-213. [pmid: 8144275].
St George D M, Thomas S B. Perceived risk of fighting and actual fighting behavior among middle school students. J Sch Health. 1997;67(5):178-81. [pmid: 9210103].
St. Lawrence J S, Crosby R A, Belcher L, et al. Sexual risk reduction and anger management interventions for incarcerated male adolescents: A randomized controlled trial of two interventions. J Sex Educ Ther. 1999;24(12):9-17.
Stafford E, Cornell D G. Psychopathy scores predict adolescent inpatient aggression. Assessment. 2003;10(1):102-12. [pmid: 12675389].
Stanislav S W, Fabre T, Crismon M L, et al. Buspirone's efficacy in organic-induced aggression. J Clin Psychopharmacol. 1994;14(2):126-30. [pmid: 8195453].
Stein D B. Outpatient behavioral management of aggressiveness in adolescents: A response cost paradigm. Aggress Behav. 1999;25(5):321-30.
Stein D J, Keating J, Zar H J, et al. A survey of the phenomenology and pharmacotherapy of compulsive and impulsive-aggressive symptoms in Prader-Willi Syndrome. J Neuropsychiatry Clin Neurosci. 1994;6(1):23-9. [pmid: 8148633].
Steiner H, Stone L A. Violence and related psychopathology. J Am Acad Child Adolesc Psychiatry. 1999;38(3):232-4. [pmid: 10087682].
Steinert T, Woelfle M, Gebhardt R P. No correlation of serum cholesterol levels with measures of violence in patients with schizophrenia and non-psychotic disorders. Eur Psychiatry. 1999;14(6):346-8. [pmid: 10572367].
Steinert T, Woelfle M, Gebhardt R P. No correlation of serum cholesterol levels with measures of violence in patients with schizophrenia and non-psychotic disorders. Eur Psychiatry. 1999;14(6):346-8. [pmid: 10572367].
Steinert T, Wolfle M, Gebhardt R P. Measurement of violence during in-patient treatment and association with psychopathology. Acta Psychiatr Scand. 2000;102(2):107-12. [pmid: 10937782].
Stephens R J, Sandor P. Aggressive behaviour in children with Tourette syndrome and comorbid attention-deficit hyperactivity disorder and obsessive-compulsive disorder. Can J Psychiatry. 1999;44(10):1036-42. [pmid: 10637683].
Stevens V, De Bourdeaudhuij I, Van Oost P. Relationship of the family environment to children's involvement in bully/victim problems at school. J Youth Adolesc. 2002;31(6):419-28.
Stevenson H C, Herrero-Taylor T, Cameron R, et al. “Mitigating instigation”: Cultural phenomenological influences of anger and fighting among "big-boned' and "baby-faced' African American youth. J Youth Adolesc. 2002;31(6):473-85.
Stewart E A, Simons R L, Conger R D. Assessing Neighborhood and Social Psychological Influences on Childhood Violence in an African-American Sample. Criminology. 2002;40(4):801-29.
Stewart L A, Clarke M J. Practical methodology of meta-analyses (overviews) using updated individual patient data. Cochrane Working Group. Stat Med. 1995;14(19):2057-79. [pmid: 8552887].
Stewart L A, Parmar M K. Meta-analysis of the literature or of individual patient data: is there a difference?. Lancet. 1993;341(8842):418-22. [pmid: 8094183].
Stier D M, Leventhal J M, Berg A T, et al. Are children born to young mothers at increased risk of maltreatment?. Pediatrics. 1993;91(3):642-8. [pmid: 8441574].
Stiffman A R, Dore P, Cunningham R M. Violent behavior in adolescents and young adults: A person and environment model. J Child Fam Stud. 1996;5(4):487-501.
Stoff D M, Pasatiempo A P, Yeung J, et al. Neuroendocrine responses to challenge with dl-fenfluramine and aggression in disruptive behavior disorders of children and adolescents. Psychiatry Res. 1992;43(3):263-76. [pmid: 1438624].
Stolzenberg L, D'Alessio S J. Gun availability and violent crime: New evidence from the National Incident-Based Reporting System. Soc Forces. 2000;78(4):1461-82.
Stouthamer-Loeber M, Loeber R. Lost opportunities for intervention: Undetected markers for the development of serious juvenile delinquency. Crim Behav Ment Health. 2002;12(1):69-82. [pmid: 12357260].
Stouthamer-Loeber M, Loeber R, Homish D L, et al. Maltreatment of boys and the development of disruptive and delinquent behavior. Dev Psychopathol. 2001;13(4):941-55. [pmid: 11771915].
Strain P S, Timm M A. Remediation and prevention of aggression: An evaluation of the Regional Intervention Program over a quarter century. Behav Disord. 2001;26(4):297-313.
Straus M A. Spanking and the making of a violent society. Pediatrics. 1996;98(4 Pt 2):837-42. [pmid: 8885984].
Straus M A, Kantor G K. Corporal punishment of adolescents by parents: A risk factor in the epidemiology of depression, suicide, alcohol abuse, child abuse, and wife beating. Adolescence. 1994;29(115):543-61. [pmid: 7832020].
Straus M A, Mouradian V E. Impulsive corporal punishment by mothers and antisocial behavior and impulsiveness of children. Behav Sci Law. 1998;16(3):353-74. [pmid: 9768466].
Straznickas K A, McNiel D E, Binder R L. Violence toward family caregivers by mentally ill relatives. Hosp Community Psychiatry. 1993;44(4):385-7. [pmid: 8462950].
Stricker S J, Volgas D A. Extremity handgun injuries in children and adolescents. Orthopedics. 1998;21(10):1095-110. [pmid: 9801233].
Strom J P. Breaking the cycle of violence. J S C Med Assoc. 1995;91(10):439. [pmid: 7474955].
Stueve A, O'Donnell L, Link B. Gender differences in risk factors for violent behavior among economically disadvantaged African American and Hispanic young adolescents. Int J Law Psychiatry. 2001;24(45):539-57. [pmid: 11521425].
Stulc J P. The cult of violence. J Ky Med Assoc. 1998;96(12):497-8. [pmid: 9879180].
Sullivan A M, Rivera J. Profile of a comprehensive psychiatric emergency program in a New York City municipal hospital. Psychiatr Q. 2000;71(2):123-38. [pmid: 10832155].
Surette R. Self-reported copycat crime among a population of serious and violent juvenile offenders. Crime Delinq. 2002;48(1):46-69.
Sussman S, Dent C W, McCullar W J. Group self-identification as a prospective predictor of drug use and violence in high-risk youth. Psychol Addict Behav. 2000;14(2):192-6. [pmid: 10860118].
Sussman S, Dent C W, Stacy A W. The association of current stimulant use with demographic, substance use, violence-related, social and intrapersonal variables among high risk youth. Addictive Behaviors Addict Behav. 1999;24(6):741-8.
Sussman S, Dent C W, Stacy A W, et al. Psychosocial variables as prospective predictors of violent events among adolescents. Health Values. 1994;18(3):29-40.
Sussman S, Simon T R, Dent C W, et al. One-year prediction of violence perpetration among high-risk youth. Am J Health Behav. 1999;23(5):332-44.
Swanson J W, Swartz M S, Borum R, et al. Involuntary out-patient commitment and reduction of violent behaviour in persons with severe mental illness. Br J Psychiatry. 2000;176:324-31. [pmid: 10827879].
Swartz M S, Swanson J W, Hiday V A, et al. Taking the wrong drugs: the role of substance abuse and medication noncompliance in violence among severely mentally ill individuals. Soc Psychiatry Psychiatr Epidemiol. 1998;33(Suppl 1):s75-80. [pmid: 9857785].
Swartz M S, Swanson J W, Hiday V A, et al. Violence and severe mental illness: the effects of substance abuse and nonadherence to medication. Am J Psychiatry. 1998;155(2):226-31. [pmid: 9464202].
Swett C. Inpatient seclusion: Description and causes. Bull Am Acad Psychiatry Law. 1994;22(3):421-30. [pmid: 7841514].
Swikert N. SAVE--school violence II. J Ky Med Assoc. 2000;98(10):459-60. [pmid: 11059218].
Swinford S P, DeMaris A, Cernkovich S A, et al. Harsh physical discipline in childhood and violence in later romantic involvements: The mediating role of problem behaviors. J Marriage Fam. 2000;62(2):508-19.
Talbott E, Celinska D, Simpson J, et al. “Somebody else making somebody else fight”: Aggression and the social context among urban adolescent girls. Exceptionality. 2002;10(3):203-20.
Taliaferro E, Smith D, Rogers J, et al. Violence intervention programs: the Parkland Domestic Violence Project. Tex Dent J. 2000;117(10):54-8. [pmid: 11857887].
Tannenhaus N. Violence in the streets. What can communities do?. Trustee. 1995;48(4):6-9. [pmid: 10141688].
Tarter R E, Kirisci L, Vanyukov M, et al. Predicting adolescent violence: impact of family history, substance use, psychiatric history, and social adjustment. Am J Psychiatry. 2002;159(9):1541-7. [pmid: 12202275].
Tashman N A, Weist M D, Nabors L A, et al. Involvement in meaningful activities and self-reported aggression and delinquency among inner-city teenagers. J Clin Psychol Med Settings. 1998;5(3):239-48.
Taub J. Evaluation of the Second Step Violence Prevention Program at a rural elementary school. School Psych Rev. 2002;31(2):186-200.
Taussig H N. Risk behaviors in maltreated youth placed in foster care: a longitudinal study of protective and vulnerability factors. Child Abuse Negl. 2002;26(11):1179-99. [pmid: 12398855].
Taylor E, Chadwick O, Heptinstall E. Hyperactivity and conduct problems as risk factors for adolescent development. J Am Acad Child Adolesc Psychiatry. 1996;35:1213-26. [pmid: 8824065].
Taylor E, Chadwick O, Heptinstall E, et al. Hyperactivity and conduct problems as risk factors for adolescent development. J Am Acad Child Adolesc Psychiatry. 1996;35(9):1213-26. [pmid: 8824065].
Taylor E R, Kelly J, Valescu S, et al. Is stealing a gateway crime?. Community Ment Health J. 2001;37(4):347-58. [pmid: 11482752].
Taylor H G. Family violence and the community pharmacist. Am Pharm. 1994;Ns34(4):41-4. [pmid: 8209831].
Tebbutt J, Swanston H, Oates R K, et al. Five years after child sexual abuse: persisting dysfunction and problems of prediction. J Am Acad Child Adolesc Psychiatry. 1997;36(3):330-9. [pmid: 9055513].
Teevan J J, Dryburgh H B. First person accounts and sociological explanations of delinquency. Can Rev Sociol Anthropol. 2000;37(1):77-93.
Tengstroem A, Grann M, Langstroem N, et al. Psychopathy (PCL-R) as a predictor of violent recidivism among criminal offenders with schizophrenia. Law Hum Behav. 2000;24(1):45-58. [pmid: 10693318].
Teplin L A, Abram K M, McClelland G M. Does psychiatric disorder predict violent crime among released jail detainees? A six-year longitudinal study. Am Psychol. 1994;49(4):335-42. [pmid: 8203805].
Thompson K M, Brownfield D, Sorenson A M. At-risk behavior and group fighting: A latent structure analysis. J Gang Res. 1998;5(3):1-14.
Thornberry T P, Freeman-Gallant A, Lizotte A J, et al. Linked lives: The intergenerational transmission of antisocial behavior. J Abnorm Child Psychol. 2003;31(2):171-84. [pmid: 12735399].
Thornberry T P, Krohn M D, Lizotte A J, et al. The role of juvenile gangs in facilitating delinquent behavior. J Res Crime Delinq. 1993;30(1):55-87.
Tiet Q Q, Wasserman G A, Loeber R, et al. Developmental and sex differences in types of conduct problems. J Child Fam Stud. 2001;10(2):181-97.
Tinklenberg J A, Steiner H, Huckaby W J, et al. Criminal recidivism predicted from narratives of violent juvenile delinquents. Child Psychiatry Hum Dev. 1996;27(2):69-79. [pmid: 8936793].
Tippins B S. Family violence: a national epidemic. J Med Assoc Ga. 1992;81(7):372-3. [pmid: 1402420].
Tobin T, Sugai G, Colvin G. Patterns in middle school discipline records. J Emot Behav Disord. 1996;4(2):82-94.
Tobin T J, Sugai G M. Using sixth-grade school records to predict school violence, chronic discipline problems, and high school outcomes. J Emot Behav Disord. 1999;7(1):40-53.
Todis B, Severson H H, Walker H M. The Critical Events Scale: Behavioral profiles of students with externalizing and internalizing behavior disorders. Behav Disord. 1990;15(2):75-86.
Tolan P H, Gorman-Smith D, Henry D B. Linking family violence to delinquency across generations?. Child Serv (Mahwah NJ). 2002;5(4):273-84.
Tolan P H, Gorman-Smith D, Henry D B. The developmental ecology of urban males' youth violence. Dev Psychol. 2003;39(2):274-91. [pmid: 12661886].
Tolan P H, Gorman-Smith D, Henry D B. The developmental ecology of urban males' youth violence. Dev Psychol. 2003;39(2):274-91. [pmid: 12661886].
Tolan P H, Gorman-Smith D, Loeber R. Developmental timing of onsets of disruptive behaviors and later delinquency of inner-city youth. J Child Fam Stud. 2000;9(2):203-20.
Tolan P H, Henry D. Patterns of psychopathology among urban poor children: Comorbidity and aggression effects. J Consult Clin Psychol. 1996;64(5):1094-9. [pmid: 8916642].
Tomori M. Personality characteristics of adolescents with alcoholic parents. Adolescence. 1994;29(116):949-59. [pmid: 7892805].
Tones K. Health education: evidence of effectiveness. Arch Dis Child. 1997;77(3):189-91. [pmid: 9370891].
Tong DA. Beyond prevention: healing the “sociomas”. Healthc Forum J 1996;39(3):39–40, 57.
Tontodonato P, Crew B K. Dating violence, social learning theory, and gender: a multivariate analysis. Violence Vict. 1992;7(1):3-14. [pmid: 1504032].
Toombs N J, Benda B, Corwyn R F. Violent youth in boot camps for non-violent offenders. J Offender Rehabil. 2000;31(34):113-33.
Totten M. Girlfriend abuse as a form of masculinity construction among violent, marginal male youth. Men Masc. 2003;6(1):70-92.
Toupin J, Morissette L. Juvenile homicide: a case control study. Med Law. 1990;9(3):986-94. [pmid: 2122166].
Tremblay R E, Schaal B. Physically aggressive boys from age 6 to 12 years. Their biopsychosocial status at puberty. Ann N Y Acad Sci. 1996;794:192-207. [pmid: 8853603].
Tremblay R E, Schaal B, Boulerice B, et al. Testosterone, physical aggression, dominance, and physical development in early adolescence. Int J Behav Dev. 1998;22(4):753-77.
Trickett P K, Noll J G, Reiffman A, et al. Variants of intrafamilial sexual abuse experience: implications for short- and long-term development. Dev Psychopathol. 2001;13(4):1001-19. [pmid: 11771904].
Trulson C, Triplett R, Snell C. Social control in a school setting: Evaluating a school-based boot camp. Crime Delinq. 2001;47(4):573-609.
Truscott D. Intergenerational transmission of violent behavior in adolescent males. Aggress Behav. 1992;18(5):327-35.
Truscott D. Adolescent offenders: comparison for sexual, violent, and property offences. Psychol Rep. 1993;73(2):657-8. [pmid: 8234618].
Tucker J B, Barone J E, Stewart J, et al. Violence prevention: reaching adolescents with the message. Pediatr Emerg Care. 1999;15(6):436-9. [pmid: 10608337].
Tuisku K, Virkkunen M, Holi M, et al. Antisocial violent offenders with attention deficit hyperactivity disorder demonstrate akathisia-like hyperactivity in three-channel actometry. J Neuropsychiatry Clin Neurosci. 2003;15(2):194-9. [pmid: 12724461].
Tuisku K, Virkkunen M, Holi M, et al. Antisocial violent offenders with attention deficit hyperactivity disorder demonstrate akathisia-like hyperactivity in three-channel actometry. J Neuropsychiatry Clin Neurosci. 2003;15(2):194-9. [pmid: 12724461].
Tuninger E E, Levander S, Bernce R, et al. Criminality and aggression among psychotic in-patients: frequency and clinical correlates. Acta Psychiatr Scand. 2001;103(4):294-300. [pmid: 11328244].
Tunzi M. Isn't this statutory rape? Am Fam Physician 2002;65(9):1950, 3–4.
Turnure C, Young P. Chemical abuse and family violence in Minnesota. Minn Med. 1994;77(10):24-6. [pmid: 7990774].
Twemlow S W. A crucible for murder: The social context of violent children and adolescents. Psychoanal Q. 2003;72(3):659-98. [pmid: 12901174].
Twemlow S W, Fonagy P, Sacco F C. An innovative psychodynamically influenced approach to reduce school violence. J Am Acad Child Adolesc Psychiatry. 2001;40(3):377-9. [pmid: 11288781].
Twemlow S W, Fonagy P, Sacco F C, et al. Premeditated mass shootings in schools: threat assessment. J Am Acad Child Adolesc Psychiatry. 2002;41(4):475-7. [pmid: 11931605].
Uberos D J, Gomez A, Munoz A, et al. Television and childhood injuries: is there a connection?. Arch Pediatr Adolesc Med. 1998;152(7):712-4. [pmid: 9667549].
Uehara E S, Chalmers D, Jenkins E J, et al. African American youth encounters with violence: Results from the Community Mental Health Council Violence Screening Project. J Black Stud. 1996;26(6):768-81.
Ullman S E. A comparison of gang and individual rape incidents. Violence Vict. 1999;14(2):123-33. [pmid: 10418766].
Ulman A, Straus M A. Violence by children against mothers in relation to violence between parents and corporal punishment by parents. J Comp Fam Stud. 2003;34(1):41-60.
Underwood R C, Patch P C. Siblicide: A descriptive analysis of sibling homicide. Homicide Stud. 1999;3(4):333-48.
Unger J B, Sussman S, Dent C W. Interpersonal conflict tactics and substance use among high-risk adolescents. Addictive Behaviors Addict Behav. 2003;28(5):979-87.
Unis A S, Cook E H, Vincent J G, et al. Platelet serotonin measures in adolescents with conduct disorder. Biol Psychiatry. 1997;42(7):553-9. [pmid: 9376451].
Valdez A, Kaplan C D, Codina E. Psychopathy among Mexican American gang members: A comparative study. Int J Offender Ther Comp Criminol. 2000;44(1):46-58.
Valliant P M, Bergeron T. Personality and criminal profile of adolescent sexual offenders, general offenders in comparison to nonoffenders. Psychol Rep. 1997;81(2):483-9. [pmid: 9354098].
Valois R F, McKeown R E, Garrison C Z, et al. Correlates of aggressive and violent behaviors among public high school adolescents. J Adolesc Health. 1995;16(1):26-34. [pmid: 7742333].
Valois R F, McKewon R E. Frequency and correlated of fighting and carrying weapons among public school adolescents. Am J Health Behav. 1998;22(1):8-17.
Valois R F, Oeltmann J E, Waller J, et al. Relationship between number of sexual intercourse partners and selected health risk behaviors among public high school adolescents. J Adolesc Health. 1999;25(5):328-35. [pmid: 10551663].
Valois R F, Vincent M L, McKeown R E, et al. Adolescent risk behaviors and the potential for violence: a look at what's coming to campus. J Am Coll Health. 1993;41(4):141-7. [pmid: 8436726].
Valois R F, Zullig K J, Huebner E S, et al. Relationship between life satisfaction and violent behaviors among adolescents. Am J Health Behav. 2001;25(4):353-66. [pmid: 11488546].
van Dis J, Mahmoodian M, Goddik S, et al. A survey of the prevalence of domestic violence in rural and Urban South Dakota. S D J Med. 2002;55(4):133-9. [pmid: 11977866].
van Goozen S H M, Matthys W, Cohen-Kettenis P T, et al. Plasma monoamine metabolites and aggression: Two studies of normal and oppositional defiant disorder children. Eur Neuropsychopharmacol. 1999;9(12):141-7. [pmid: 10082240].
van Goozen S H M, van den Ban E, Matthys W, et al. Increased adrenal androgen functioning in children with oppositional defiant disorder: A comparison with psychiatric and normal controls. J Am Acad Child Adolesc Psychiatry. 2000;39(11):1446-51. [pmid: 11068901].
Vance J E, Bowen N K, Fernandez G, et al. Risk and protective factors as predictors of outcome in adolescents with psychiatric disorder and aggression. J Am Acad Child Adolesc Psychiatry. 2002;41(1):36-43. [pmid: 11800203].
Vanderschmidt H F, Lang J M, Knight-Williams V, et al. Risks among inner-city young teens: the prevalence of sexual activity, violence, drugs, and smoking. J Adolesc Health. 1993;14(4):282-8. [pmid: 8347639].
Vartiainen H, Tiihonen J, Putkonen A, et al. Citalopram, a selective serotonin reuptake inhibitor, in the treatment of aggression in schizophrenia. Acta Psychiatr Scand. 1995;91(5):348-51. [pmid: 7639092].
Velsor-Friedrich B. Family violence: a growing epidemic. J Pediatr Nurs. 1994;9(4):272-4. [pmid: 7965595].
Veneziano C, Veneziano L. A typology of family social environments for institutionalized juvenile delinquents: Implications for research and treatment. J Youth Adolesc. 1992;21(5):593-607.
Vera Institute of Justice. Vera institute of justice. Accessed: May 2004. http://www.vera.org/.
Vernberg E M, Jacobs A K, Hershberger S L. Peer victimization and attitudes about violence during early adolescence. J Clin Child Psychol. 1999;28(3):386-95. [pmid: 10446688].
Vidyasagar P, Mishra H. Effect of modelling on aggression. Indian J Clin Psychol. 1993;20(1):50-2.
Viemeroe V. Factors in childhood that predict later criminal behavior. Aggress Behav. 1996;22(2):87-97.
Villani S. Violence in the media. J Am Acad Child Adolesc Psychiatry. 1999;38(10):1208. [pmid: 10517048].
Villani S. Impact of media on children and adolescents: a 10-year review of the research. J Am Acad Child Adolesc Psychiatry. 2001;40(4):392-401. [pmid: 11314564].
Villani S, Sharfstein S S. Evaluating and treating violent adolescents in the managed care era. Am J Psychiatry. 1999;156(3):458-64. [pmid: 10080564].
Violence CftSaPo. Blueprints for violence prevention. Accessed: May 2004. http://www.colorado.edu/cspv/blueprints/.
Virkkunen M. Reactive hypoglycemic tendency among habitually violent offenders. Nutr Rev. 1986;44(Suppl):94-103. [pmid: 2980863].
Vissing Y M, Straus M A, Gelles R J, et al. Verbal aggression by parents and psychosocial problems of children. Child Abuse Negl. 1991;15(3):223-38. [pmid: 2043974].
Vitacco M J, Rogers R. Predictors of adolescent psychopathy: the role of impulsivity, hyperactivity, and sensation seeking. J Am Acad Psychiatry Law. 2001;29(4):374-82. [pmid: 11785608].
Vitaro F, Gendreau P L, Tremblay R E, et al. Reactive and proactive aggression differentially predict later conduct problems. J Child Psychol Psychiatry. 1998;39(3):377-85. [pmid: 9670093].
Vitelli R. Comparison of early and late start models of delinquency in adult offenders. Int J Offender Ther Comp Criminol. 1997;41(4):351-7.
Vivona J M, Ecker B, Halgin R P. Self- and other-directed aggression in child and adolescent psychiatric inpatients. J Am Acad Child Adolesc Psychiatry. 1995;34:434-44. [pmid: 7751257].
Volavka J, Laska E, Baker S, et al. History of violent behaviour and schizophrenia in different cultures. Analyses based on the WHO study on Determinants of Outcome of Severe Mental Disorders. Br J Psychiatry. 1997;171:9-14. [pmid: 9328487].
Vowell P R, May D C. Another look at classic strain theory: poverty status, perceived blocked opportunity, and gang membership as predictors of adolescent violent behavior. Sociol Inq. 2000;70(1):42-60.
Vukelich M S. Stop the media violence. Minn Med. 1995;78(6):16-8. [pmid: 7623744].
Waite B M, Hillbrand M, Foster H G. Reduction of aggressive behavior after removal of music television. Hosp Community Psychiatry. 1992;43(2):173-5. [pmid: 1572616].
Waldner-Haugrud L K, Gratch L V, Magruder B. Victimization and perpetration rates of violence in gay and lesbian relationships: gender issues explored. Violence Vict. 1997;12(2):173-84. [pmid: 9403987].
Wallace J M, Forman T A. Religion's role in promoting health and reducing risk among American youth. Health Educ Behav. 1998;25(6):721-41. [pmid: 9813744].
Walsh A. Genetic and environmental explanations of juvenile violence in advantaged and disadvantaged environments. Aggress Behav. 1992;18(3):187-99.
Walsh D. Interactive media violence and children. Minn Med. 2000;83(9):42-4. [pmid: 11006686].
Walsh M M, Pepler D J, Levene K S. A Model Intervention for Girls with Disruptive Behaviour Disorders: The Earlscourt Girls Connection. Can J Couns. 2002;36(4):297-311.
Walsh W J, Isaacson H R, Rehman F, et al. Elevated blood copper/zinc ratios in assaultive young males. Physiol Behav. 1997;62(2):327-9. [pmid: 9251975].
Waschbusch D A, Pelham W E J, Jennings J R, et al. Reactive aggression in boys with disruptive behavior disorders: Behavior, physiology, and affect. J Abnorm Child Psychol. 2002;30(6):641-56. [pmid: 12481977].
Watts W D, Wright L S. The drug use-violent delinquency link among adolescent Mexican-Americans. NIDA Res Monogr. 1990;103:136-59. [pmid: 2096285].
Watts W D, Wright L S. The relationship of alcohol, tobacco, marijuana, and other illegal drug use to delinquency among Mexican-American, Black, and White adolescent males. Adolescence. 1990;25(97):171-81. [pmid: 2333795].
Watts W D, Wright L S. The relationships of alcohol, tobacco, marijuana, and other illegal drug use to delinquency among Mexican-American, black, and white adolescent males. Adolescence. 1990;25(97):171-81. [pmid: 2333795].
Way I, Chung S, Jonson-Reid M, et al. Maltreatment perpetrators: a 54-month analysis of recidivism. Child Abuse Negl. 2001;25(8):1093-108. [pmid: 11601599].
Weaver G M, Wootton R R. The use of the MMPI special scales in the assessment of delinquent personality. Adolescence. 1992;27(107):545-54. [pmid: 1414566].
Weber D O. Healing a violent society. Healthc Forum J. 1996;39(5):22-32. [pmid: 10162402].
Webster D W, Gainer P S, Champion H R. Weapon carrying among inner-city junior high school students: defensive behavior vs aggressive delinquency. Am J Public Health. 1993;83(11):1604-8. [pmid: 8238686]. [pmcid: 1694886].
Weiner M D, Pentz M A, Turner G E, et al. From early to late adolescence: alcohol use and anger relationships. J Adolesc Health. 2001;28(6):450-7. [pmid: 11377988].
Weisburd D, Lum C, Petrosino A. Does research design affect study outcomes in criminal justice?. Ann Am Acad Polit Soc Sci. 2001;578:50-70.
Weishew N L, Peng S S. Variables predicting students' problem behaviors. J Educ Res. 1993;87(1):5-17.
Weiss B, Dodge K A, Bates J E, et al. Some consequences of early harsh discipline: child aggression and a maladaptive social information processing style. Child Dev. 1992;63(6):1321-35. [pmid: 1446555].
Weisz J R, Martin S L, Walter B R, et al. Differential prediction of young adult arrests for property and personal crimes: findings of a cohort follow-up study of violent boys from North Carolina's Willie M Program. J Child Psychol Psychiatry. 1991;32(5):783-92. [pmid: 1918228].
Weisz J R, Suwanlert S, Chaiyasit W, et al. Behavioral and emotional problems among Thai and American adolescents: parent reports for ages 12–16. J Abnorm Psychol. 1993;102(3):395-403. [pmid: 8408951].
Weisz J R, Walter B R, Weiss B. Arrests among emotionally disturbed violent and assaultive individuals following minimal versus lengthy intervention through North Carolina's Willie M program. J Consult Clin Psychol. 1990;58:720-8. [pmid: 2292622].
Wekerle C, Wolfe D A. The role of child maltreatment and attachment style in adolescent relationship violence. Dev Psychopathol. 1998;10(3):571-86. [pmid: 9741683].
Wekerle C, Wolfe D A, Hawkins D L, et al. Childhood maltreatment, posttraumatic stress symptomatology, and adolescent dating violence: considering the value of adolescent perceptions of abuse and a trauma mediational model. Dev Psychopathol. 2001;13(4):847-71. [pmid: 11771911].
Weller N F, Tortolero S R, Kelder S H, et al. Health risk behaviors of Texas students attending dropout prevention/recovery schools in 1997. J Sch Health. 1999;69(1):22-8. [pmid: 10098115].
Welsh J. Children and torture. Lancet. 2000;356(9247):2093. [pmid: 11145508].
Welte J W, Wieczorek W F. Alcohol, intelligence and violent crime in young males. J Subst Abuse. 1998;10(3):309-19. [pmid: 10689662].
Welte J W, Zhang L, Wieczorek W F. The effects of substance use on specific types of criminal offending in young men. J Res Crime Delinq. 2001;38(4):416-38.
West C M, Rose S. Dating aggression among low income African American youth: An examination of gender differences and antagonistic beliefs. Violence Against Women. 2000;6(5):470-94.
West S, King V, Carey T, et al. Systems to rate the strength of scientific svidence. Evidence Report/Technology Assessment No. 47. AHRQ Publication No. 02-E016. Rockville, MD: Agency for Healthcare Research and Quality; 2002.
Westhoff W W, McDermott R J, Harokopos V. Acquisition of high-risk behavior by African-American, Latino, and Caucasian middle-school students. Psychol Rep. 1996;79(3, Pt 1):787-95. [pmid: 8969085].
Whipple E E, Webster-Stratton C. The role of parental stress in physically abusive families. Child Abuse Negl. 1991;15(3):279-91. [pmid: 2043979].
White HR, Brick J, Hansell S. A longitudinal investigation of alcohol use and aggression in adolescence. J Stud Alcohol 1993;Suppl 11:62–77.
White H R, Chen P-H, et al. Problem drinking and intimate partner violence. J Stud Alcohol. 2002;63(2):205-14. [pmid: 12033697].
White H R, Hansell S. The moderating effects of gender and hostility on the alcohol-aggression relationship. J Res Crime Delinq. 1996;33(4):450-70.
White H R, Hansell S. Acute and long-term effects of drug use on aggression from adolescence into adulthood. J Drug Issues. 1998;28(4):837-58.
White H R, Hansell S, Brick J. Alcohol use and aggression among youth. Alcohol Health Res World. 1993;17(2):144-50.
White H R, Loeber R, Stouthamer-Loeber M, et al. Developmental associations between substance use and violence. Dev Psychopathol. 1999;11(4):785-803. [pmid: 10624726].
White H R, Tice P C, Loeber R, et al. Illegal acts committed by adolescents under the influence of alcohol and drugs. J Res Crime Delinq. 2002;39(2):131-52.
Whitfield G W. Validating school social work: An evaluation of a cognitive-behavioral approach to reduce school violence. Res Soc Work Pract. 1999;9(4):399-426.
Widom C S. Child abuse, neglect, and adult behavior: research design and findings on criminality, violence, and child abuse. Amer J Orhopsychiat. 1989;59(3):355-67.
Widom C S. The role of placement experiences in mediating the criminal consequences of early childhood victimization. Am J Orthopsychiatry. 1991;61(2):195-209. [pmid: 2048635].
Widom C S. Motivation and mechanisms in the “cycle of violence”. Nebr Symp Motiv. 2000;46:1-37. [pmid: 11031734].
Widom C S, Ames M A. Criminal consequences of childhood sexual victimization. Child Abuse Negl. 1994;18(4):303-18. [pmid: 8187016].
Widom C S, Maxfield M G. A prospective examination of risk for violence among abused and neglected children. Ann N Y Acad Sci. 1996;794:224-37. [pmid: 8853605].
Widom C S, White H R. Problem behaviours in abused and neglected children grown up: Prevalence and co-occurrence of substance abuse, crime and violence. Crim Behav Ment Health. 1997;7(4):287-310.
Wieckowski E, Hartsoe P, Mayer A, et al. Deviant sexual behavior in children and young adolescents: Frequency and patterns. Sex Abuse. 1998;10(4):293-303.
Wiist W H, Jackson R H, Jackson K W. Peer and community leader education to prevent youth violence. Am J Prev Med. 1996;12(5 Suppl):56-64. [pmid: 8909625].
Willard JC, Schoenborn CA. Relationship between cigarette smoking and other unhealthy behaviors among our nation's youth: United States, 1992. Adv Data 1995(263):1–11.
Williams J H, Stiffman A R, O'Neal J L. Violence among urban African American youths: An analysis of environmental and behavioral risk factors. Soc Work Res. 1998;22(1):3-13.
Williams O. Spouse abuse: social learning, attribution and interventions. J Health Soc Policy. 1989;1(2):91-107. [pmid: 10304505].
Winpisinger K A, Hopkins R S, Indian R W, et al. Risk factors for childhood homicides in Ohio: a birth certificate-based case-control study. Am J Public Health. 1991;81(8):1052-4. [pmid: 1854000]. [pmcid: 1405732].
Wintemute G J, Wright M A, Parham C A, et al. Criminal activity and assault-type handguns: a study of young adults. Ann Emerg Med. 1998;32(1):44-50. [pmid: 9656948].
Witkowski M J, Homant R J, Barnes E. Work, workplace deviance, and criminal offenders: An analysis of Project GANGMILL. J Gang Res. 2002;10(1):1-10.
Wolfe D A, Feiring C. Dating violence through the lens of adolescent romantic relationships. Child Maltreat. 2000;5(4):360-3. [pmid: 11232263].
Wolfe D A, Wekerle C, Reitzel-Jaffe D, et al. Factors associated with abusive relationships among maltreated and nonmaltreated youth. Dev Psychopathol. 1998;10(1):61-85. [pmid: 9524808].
Wolfe D A, Wekerle C, Scott K, et al. Dating violence prevention with at-risk youth: A controlled outcome evaluation. J Consult Clin Psychol. 2003;71(2):279-91. [pmid: 12699022].
Wolfe D A, Wekerle C, Scott K, et al. Dating violence prevention with at-risk youth: a controlled outcome evaluation. J Consult Clin Psychol. 2003;71(2):279-91. [pmid: 12699022].
Wolfe L R. “Girl stabs boy at school”: girls and the cycle of violence. Womens Health Issues. 1994;4(2):109-16. [pmid: 8086808].
Wolfe T W, Shoemaker D J. Actor, situation, and context: A framework for delinquency theory integration. Am J Crim Justice. 1999;24(1):117-38.
Workman M, Beer J. Depression, suicide ideation, and aggression among high school students whose parents are divorced and use alcohol at home. Psychol Rep. 1992;70(2):503-11. [pmid: 1529069].
Worling J R. Sexual abuse histories of adolescent male sex offenders: differences on the basis of the age and gender of their victims. J Abnorm Psychol. 1995;104(4):610-3. [pmid: 8530763].
Worling J R. Adolescent sibling-incest offenders: differences in family and individual functioning when compared to adolescent nonsibling sex offenders. Child Abuse Negl. 1995;19(5):633-43. [pmid: 7664142].
Worling J R. Adolescent sex offenders against females: Differences based on the age of their victims. Int J Offender Ther Comp Criminol. 1995;39(3):276-93.
Worling J R. Sexual abuse histories of adolescent male sex offenders: differences on the basis of the age and gender of their victims. J Abnorm Psychol. 1995;104:610-13. [pmid: 8530763].
Worling J R. Personality-based typology of adolescent male sexual offenders: differences in recidivism rates, victim-selection characteristics, and personal victimization histories. Sex Abuse. 2001;13(3):149-66. [pmid: 11486710].
Worling J R, Curwen T. Adolescent sexual offender recidivism: success of specialized treatment and implications for risk prediction. Child Abuse Negl. 2000;24(7):965-82. [pmid: 10905420].
Wright S, Klee H. Violent crime, aggression and amphetamine: What are the implications for drug treatment services?. Drug Educ Prev Policy. 2001;8(1):73-90.
Xie H, Cairns R B, Cairns B D. The development of social aggression and physical aggression: A narrative analysis of interpersonal conflicts. Aggress Behav. 2002;28(5):341-55.
Xie H, Farmer T W, Cairns B D. Different forms of aggression among inner-city African-American children: Gender, configurations and school social networks. J Sch Psychol. 2003;41(5):355-75.
Xie H, Swift D J, Cairns B, et al. Aggressive behaviors in social interaction and developmental adaptation: A narrative analysis of interpersonal conflicts during early adolescence. Soc Dev. 2002;11(2):205-24.
Yarvis R M. Patterns of substance abuse and intoxication among murderers. Bull Am Acad Psychiatry Law. 1994;22(1):133-44. [pmid: 8193384].
Yates T M, Dodds M F, Sroufe L A, et al. Exposure to partner violence and child behavior problems: A prospective study controlling for child physical abuse and neglect, child cognitive ability, socioeconomic status, and life stress. Dev Psychopathol. 2003;15(1):199-218. [pmid: 12848442].
Yexley M, Borowsky I, Ireland M. Correlation between different experiences of intrafamilial physical violence and violent adolescent behavior. J Interpers Violence. 2002;17(7):707-20.
Young T J. Parricide rates and criminal street violence in the United States: is there a correlation?. Adolescence. 1993;28(109):171-2. [pmid: 8456605].
Young T J, French L A. Homicide rates among Native American children: the status integration hypothesis. Adolescence. 1997;32(125):57-9. [pmid: 9105491].
Youngstrom E, Weist M D, Albus K E. Exploring violence exposure, stress, protective factors and behavioral problems among inner-city youth. Am J Community Psychol. 2003;32(12):115-29. [pmid: 14570441].
Zagar R, Arbit J, Sylvies R, et al. Homicidal adolescents: a replication. Psychol Rep. 1990;67(3 Pt 2):1235-42. [pmid: 2084749].
Zgourides G, Monto M, Harris R. Correlates of adolescent male sexual offense: Prior adult sexual contact, sexual attitudes, and use of sexually explicit materials. Int J Offender Ther Comp Criminol. 1997;41(3):272-83.
Zhang L, Welte J W, Wieczorek W W, et al. The role of aggression-related alcohol expectancies in explaining the link between alcohol and violent behavior. Subst Use Misuse. 2002;37(4):457-71. [pmid: 12064429].
Zhang L, Wieczorek W F, Welte J W. The nexus between alcohol and violent crime. Alcohol Clin Exp Res. 1997;21(7):1264-71. [pmid: 9347088].
Zhang Q, Loeber R, Stouthamer-Loeber M. Developmental trends of delinquent attitudes and behaviors: Replications and synthesis across domains, time, and samples. J Quant Criminol. 1997;13(2):181-215.
Zivin G, Hassan N R, DePaula G F, et al. An effective approach to violence prevention: traditional martial arts in middle school. Adolescence. 2001;36(143):443-59. [pmid: 11817627].
Zoloth-Dorfman L. Audience and authority: the story in front of the story. J Clin Ethics. 1996;7(4):355-61. [pmid: 9029337].