# Listing of Excluded Studies

Anonymous. Weapon-carrying among high school students--United States, 1990. MMWR Morb Mortal Wkly Rep 1991;40(40):681–4. Excluded; Outcome is not violence.
Anonymous. From the Centers for Disease Control. Physical fighting among high school students--United States, 1990. JAMA 1992;267(22):3009–10. Excluded; Not a research study.
Anonymous. Physical fighting among high school students--United States, 1990. MMWR Morb Mortal Wkly Rep 1992;41(6):91–4. Excluded; Not addressing they key questions.
Anonymous. Domestic violence. Am J Public Health 1993;83(3):458–63. Excluded; Not a research study.
Anonymous. From the Centers for Disease Control and Prevention. Violence-related attitudes and behaviors of high school students--New York City, 1992. JAMA 1993;270(17):2032–3. Excluded; Study design not used.
Anonymous. Adolescent homicide--Fulton County, Georgia, 1988-1992. MMWR Morb Mortal Wkly Rep 1994;43(40):728–30. Excluded; Study does not focus on youth as perpetrators.
Anonymous. From the Centers for Disease Control and Prevention. Homicides among 15–19-year-old males--United States, 1963-1991. JAMA 1994;272(20):1572. Excluded; Study does not focus on youth as perpetrators.
Anonymous. The role of the pediatrician in violence prevention. Proceedings of a conference. Chantilly, Virginia, March 4–5, 1994. Pediatrics 1994;94(4 Pt 2):576–651. Excluded; Not a research study.
Anonymous. Sexual assault and the adolescent. American Academy of Pediatrics Committee on Adolescence. Pediatrics 1994;94(5):761–5. Excluded; Not a research study.
Anonymous. Media violence. American Academy of Pediatrics Committee on Communications. Pediatrics 1995;95(6):949–51. Excluded; Not a research study.
Anonymous. Defusing gang activity: different hospitals take different approaches. Hosp Secur Saf Manage 1999;19(11):1–4. Excluded; Not a research study.
Anonymous. Firearm-associated deaths and hospitalizations--California, 1995-1996. MMWR Morb Mortal Wkly Rep 1999;48(23):485–8. Excluded; Not addressing they key questions.
Anonymous. The WHO cross-national study on health behavior in school-aged children from 28 countries: findings from the United States. J Sch Health 2000;70(6):227–8. Excluded; Study does not focus on youth as perpetrators.
Anonymous. JAMA patient page. Bullying. JAMA 2001;285(16):2156. Excluded; Not a research study.
Anonymous. Children, youth and gun violence. Selected bibliography. Future Child 2002;12(2):Inside Back Cover. Excluded; Not a research study.
Aber J, Lawrence, Brown J L, Jones S M. Developmental trajectories toward violence in middle childhood: course, demographic differences, and response to school-based intervention. Dev Psychol. 2003;39(2):324-48. Excluded; Duplicated citation or findings. [pmid: 12661889].
Aber J L, Brown J L, Chaudry N, et al. The evaluation of the resolving conflict creatively program: an overview. Am J Prev Med. 1996;12(5 Suppl):82-90. Excluded; Study does not focus on youth as perpetrators. [pmid: 8909628].
Aber J L, Brown J L, Jones S M. Developmental trajectories toward violence in middle childhood: Course, demographic differences, and response to school-based intervention. Dev Psychol. 2003;39(2):324-48. Excluded; Study does not focus on youth as perpetrators. [pmid: 12661889].
Aber J L, Jones S M, Brown J L, et al. Resolving conflict creatively: Evaluating the developmental effects of a school-based violence prevention program in neighborhood and classroom context. Dev Psychopathol. 1998;10(2):187-213. Excluded; Outcome is not violence. [pmid: 9635221].
Abram K M, Teplin L A. Drug disorder, mental illness, and violence. NIDA Res Monogr. 1990;103:222-38. Excluded; Study does not focus on youth as perpetrators. [pmid: 2096289].
Achenbach T M, Howell C T, McConaughy S H, et al. Six-year predictors of problems in a national sample: III. Transitions to young adult syndromes. J Am Acad Child Adolesc Psychiatry. 1995;34(5):658-69. Excluded; Outcome is not violence. [pmid: 7775361].
Acton P A, Farley T, Freni L W, et al. Traumatic spinal cord injury in Arkansas, 1980 to 1989. Arch Phys Med Rehabil. 1993;74(10):1035-40. Excluded; Outcome is not violence. [pmid: 8215853].
Adams D, Allen D. Assessing the need for reactive behaviour management strategies in children with intellectual disability and severe challenging behaviour. J Intellect Disabil Res. 2001;45(4):335-43. Excluded; Not a U.S. study. [pmid: 11489055].
Adams J, McClellan J, Douglass D, et al. Sexually inappropriate behaviors in seriously mentally ill children and adolescents. Child Abuse Negl. 1995;19(5):555-68. Excluded; Study design not used. [pmid: 7664136].
Adams PF, Schoenborn CA, Moss AJ, et al. Health-risk behaviors among our nation's youth: United States, 1992. Vital Health Stat 10 1995(192):1–51. Excluded; Not addressing they key questions.
Adams P L, Arnow J. Children in violence. J Am Acad Psychoanal. 1996;24(1):179-86. Excluded; Not a research study. [pmid: 8906719].
Adler N A, Schutz J. Sibling incest offenders. Child Abuse Negl. 1995;19(7):811-9. Excluded; Study design not used. [pmid: 7583737].
af Klinteberg B. Biology, norms, and personality: a developmental perspective. Neuropsychobiology. 1996;34(3):146-54. Excluded; Not a U.S. study. [pmid: 8916072].
af Klinteberg B, Andersson T, Magnusson D, et al. Hyperactive behavior in childhood as related to subsequent alcohol problems and violent offending: A longitudinal study of male subjects. Pers Individ Dif. 1993;15(4):381-8. Excluded; Not a U.S. study.
Agnew R. The techniques of neutralization and violence. Criminology. 1994;32:555-80. Excluded; Study design not used.
Ahmed M B. High-risk adolescents and satanic cults. Tex Med. 1991;87(10):74-6. Excluded; Not a research study. [pmid: 1962303].
Akhtar N, Bradley E J. Social information processing deficits of aggressive children: Present findings and implications for social skills training. Clin Psychol Rev. 1991;11(5):621-44. Excluded; Not a research study.
Alaniz M L, Cartmill R S, Parker R N. Immigrants and violence: The importance of neighborhood context. Hisp J Behav Sci. 1998;20(2):155-74. Excluded; Data not abstractable.
Alexander B. Violence: a public health problem. Am Fam Physician. 1992;46(1):67-8. Excluded; Outcome is not violence. [pmid: 1621642].
Allen J S, Rupert V, Spatafora K, et al. Differentiating violent from nonviolent female offenders using the Jesness Inventory. Pers Individ Dif. 2003;35(1):101-8. Excluded; Study design not used.
Altemeier W A. Is the media friend or foe to our children?. Pediatr Ann. 1995;24(2):68-9. Excluded; Not a research study. [pmid: 8747703].
Aluja-Fabregat A, Torrubia-Beltri R. Viewing of mass media violence, perception of violence, personality and academic achievement. Pers Individ Dif. 1998;25(5):973-89. Excluded; Outcome is not violence.
Alvarez A. Trends and patterns of justifiable homicide: a comparative analysis. Violence Vict. 1992;7(4):347-56. Excluded; Not a research study. [pmid: 1308440].
Amen D G, Stubblefield M, Carmicheal B, et al. Brain SPECT findings and aggressiveness. Ann Clin Psychiatry. 1996;8(3):129-37. Excluded; Data not abstractable. [pmid: 8899131].
Amodei N, Elkin B B, Burge S K, et al. Psychiatric problems experienced by primary care patients who misuse alcohol. Int J Addict. 1994;29(5):609-26. Excluded; Age of study population greater than 17 years. [pmid: 8034375].
Andershed H, Kerr M, Stattin H. Bullying in school and violence on the streets: Are the same people involved?. J Scand Stud Crim Crime Prev. 2001;2(1):31-49. Excluded; Not a U.S. study.
Andershed H A, Gustafson S B, Kerr M, et al. The usefulness of self-reported psychopathy-like traits in the study of antisocial behaviour among non-referred adolescents. Eur J Personal. 2002;16(5):383-402. Excluded; Not a U.S. study.
Anderson C A, Bushman B J, Groom R W. Hot years and serious and deadly assault: empirical tests of the heat hypothesis. J Pers Soc Psychol. 1997;73(6):1213-23. Excluded; Data not abstractable. [pmid: 9418277].
Anderson N L, Roper J M. The interactional dynamics of violence, Part II: Juvenile detention. Arch Psychiatr Nurs. 1991;5(4):216-22. Excluded; Not addressing they key questions. [pmid: 1953046].
Anderson N L, Roper J M. The interactional dynamics of violence: II. Juvenile detention. Arch Psychiatr Nurs. 1991;5(4):216-22. Excluded; Outcome is not violence. [pmid: 1953046].
Andre C, Jaber-Filho J A, Carvalho M, et al. Predictors of recovery following involuntary hospitalization of violent substance abuse patients. Am J Addict. 2003;12(1):84-9. Excluded; Not a U.S. study. [pmid: 12623743].
Andrews J A, Foster S L, Capaldi D, et al. Adolescent and family predictors of physical aggression, communication, and satisfaction in young adult couples: a prospective analysis. J Consult Clin Psychol. 2000;68(2):195-208. Excluded; Age of study population greater than 17 years. [pmid: 10780119].
Andrews T K, Rose F D, Johnson D A. Social and behavioural effects of traumatic brain injury in children. Brain Inj. 1998;12(2):133-8. Excluded; Not a U.S. study. [pmid: 9492960].
Ansevics N L, Doweiko H E. Serial murderers: Early proposed developmental model and typology. Psychother Priv Pract. 1991;9(2):107-22. Excluded; Not a research study.
Archwamety T, Katsiyannis A. Factors related to recidivism among delinquent females at a state correctional facility. J Child Fam Stud. 1998;7(1):59-67. Excluded; Outcome is not violence.
Arluke A, Levin J, Luke C, et al. The relationship of animal abuse to violence and other forms of antisocial behavior. J Interpers Violence. 1999;14(9):963-75. Excluded; Data not abstractable.
Armenteros J L, Lewis J E. Citalopram treatment for impulsive aggression in children and adolescents: An open pilot study. J Am Acad Child Adolesc Psychiatry. 2002;41(5):522-9. Excluded; Data not abstractable. [pmid: 12014784].
Arria A, Borges G, Anthony J C. Fears and other suspected risk factors for carrying lethal weapons among urban youths of middle-school age. Arch Pediatr Adolesc Med. 1997;151(6):555-60. Excluded; Outcome is not violence. [pmid: 9193237].
Arria A M, Wood N P, Anthony J C. Prevalence of carrying a weapon and related behaviors in urban schoolchildren, 1989 to 1993. Arch Pediatr Adolesc Med. 1995;149(12):1345-50. Excluded; Outcome is not violence. [pmid: 7489072].
Artz S. Where have all the school girls gone? Violent girls in the school yard. Child Youth Care Forum. 1998;27(2):77-109. Excluded; Not a U.S. study.
Ash P, Kellermann A L, Fuqua-Whitley D, et al. Gun acquisition and use by juvenile offenders. JAMA. 1996;275(22):1754-8. Excluded; Outcome is not violence. [pmid: 8637174].
Askenazy F, Caci H, Myquel M, et al. Relationship between impulsivity and platelet serotonin content in adolescents. Psychiatry Res. 2000;94(1):19-28. Excluded; Outcome is not violence. [pmid: 10788674].
Askenazy F L, Sorci K, Benoit M, et al. Anxiety and impulsivity levels identify relevant subtypes in adolescents with at-risk behavior. J Affect Disord. 2003;74(3):219-27. Excluded; Outcome is not violence. [pmid: 12738040].
Asnis G M, Kaplan M L, van Praag H M, et al. Homicidal behaviors among psychiatric outpatients. Hosp Community Psychiatry. 1994;45(2):127-32. Excluded; Data not abstractable. [pmid: 8168790].
Assaad J-M, Pihl R O, Seguin J R, et al. Aggressiveness, family history of alcoholism, and the heart rate response to alcohol intoxication. Exp Clin Psychopharmacol. 2003;11(2):158-66. Excluded; Not a U.S. study. [pmid: 12755460].
Astor R A, Behre W J. Violent and nonviolent children's and parents' reasoning about family and peer violence. Behav Disord. 1997;22(4):231-45. Excluded; Outcome is not violence.
Astor R A, Meyer H A, Behre W J. Unowned places and times: Maps and interviews about violence in high schools. Am Educ Res J. 1999;36(1):3-42. Excluded; Not addressing they key questions.
Atkin C K, Smith S W, Roberto A J, et al. Correlates of verbally aggressive communication in adolescents. J Appl Commun Res. 2002;30(3):251-68. Excluded; Outcome is not violence.
Atlas R S, Pepler D J. Observations of bullying in the classroom. J Educ Res. 1998;92(2):86-99. Excluded; Outcome is not violence.
Attar B K, Guerra N G, Tolan P H. Neighborhood disadvantage, stressful life events, and adjustment in urban elementary-school children. J Clin Child Psychol. 1994;23(4):391-400. Excluded; Age of study population greater than 17 years.
Auffrey C, Fritz J M, Lin B, et al. Exploring differences between violent and nonviolent juvenile offenders using juvenile corrections facility client records. J Educ Psychol Consult. 1999;10(2):129-43. Excluded; Study design not used.
August G J, Hektner J M, Egan E A, et al. The early risers longitudinal prevention trial: Examination of 3-year outcomes in aggressive children with intent-to treat and as-intended analyses. Psychol Addict Behav. 2002;16(Suppl4):S27-S39. Excluded; Study does not focus on youth as perpetrators. [pmid: 12502275].
August G J, Realmuto G M, Hektner J M, et al. An integrated components preventive intervention for aggressive elementary school children: The Early Risers program. J Consult Clin Psychol. 2001;69(4):614-26. Excluded; Study does not focus on youth as perpetrators. [pmid: 11550728].
Avakame E F. Intergenerational transmission of violence, self-control, and conjugal violence: a comparative analysis of physical violence and psychological aggression. Violence Vict. 1998;13(3):301-16. Excluded; Age of study population greater than 17 years. [pmid: 9836416].
Awad G A, Saunders E B. Male adolescent sexual assaulters: Clinical observations. J Interpers Violence. 1991;6(4):446-60. Excluded; Not a U.S. study.
Ayers S. The truth about underage drinking. J La State Med Soc. 2001;153(7):332-4. Excluded; Not a research study. [pmid: 11519212].
Aylwin A S, Clelland S R, Kirkby L, et al. Sexual offense severity and victim gender preference: A comparison of adolescent and adult sex offenders. Int J Law Psychiatry. 2000;23(2):113-24. Excluded; Not a U.S. study. [pmid: 10813112].
Azrael D, Hemenway D. ‘In the safety of your own home’: results from a national survey on gun use at home. Soc Sci Med. 2000;50(2):285-91. Excluded; Age of study population greater than 17 years. [pmid: 10619696].
Baba Y. Vietnamese gangs, cliques and delinquents. J Gang Res. 2001;8(2):1-20. Excluded; Study design not used.
Bachman R, Peralta R. The relationship between drinking and violence in an adolescent population: Does gender matter?. Deviant Behav. 2002;23(1):1-19. Excluded; Data not abstractable.
Bagley C, Pritchard C. The reduction of problem behaviours and school exclusion in at-risk youth: An experimental study of school social work with cost-benefit analyses. Child Fam Soc Work. 1998;3(4):219-26. Excluded; Not a U.S. study.
Bagley C, Shewchuk-Dann D. Characteristics of 60 children and adolescents who have a history of sexual assault against others: Evidence from a controlled study. J Child Youth Care 1991:43–52. Excluded; Not a U.S. study.
Bailey S L, Flewelling R L, Rosenbaum D P. Characteristics of students who bring weapons to school. J Adolesc Health. 1997;20(4):261-70. Excluded; Outcome is not violence. [pmid: 9098729].
Bailey S M, Thornton L, Weaver A B. The first 100 admissions to an adolescent secure unit. J Adolesc. 1994;17(3):207-20. Excluded; Not a U.S. study.
Baker A J, Tabacoff R, Tornusciolo G, et al. Calculating number of offenses and victims of juvenile sexual offending: the role of posttreatment disclosures. Sex Abuse. 2001;13(2):79-90. Excluded; Outcome is not violence. [pmid: 11294126].
Baker K, Pollack M, Kohn I. Violence prevention through informal socialization: An evaluation of the South Baltimore Youth Center. Stud Crime Crime Prev. 1995;4(1):61-85. Excluded; Outcome is not violence.
Baker W, Bramston P. Attributional and emotional determinants of aggression in people with mild intellectual disabilities. J Intellect Dev Disabil. 1997;22(3):169-85. Excluded; Not a U.S. study.
Baldwin K. MSMS alliance focuses on violence prevention. Mich Med. 2001;100(4):53. Excluded; Not a research study. [pmid: 11478086].
Bank L, Duncan T, Patterson G R, et al. Parent and teacher ratings in the assessment and prediction of antisocial and delinquent behaviors. J Pers. 1993;61(4):693-709. Excluded; Not a research study. [pmid: 8151504].
Barkin S, Kreiter S, DuRant R H. Exposure to violence and intentions to engage in moralistic violence during early adolescence. J Adolesc. 2001;24(6):777-89. Excluded; Outcome is not violence. [pmid: 11790057].
Barnes A, Ephross P H. The impact of hate violence on victims: emotional and behavioral responses to attacks. Soc Work. 1994;39(3):247-51. Excluded; Age of study population greater than 17 years. [pmid: 8209286].
Barnow S, Schuckit M, Smith T L, et al. The real relationship between the family density of alcoholism and externalizing symptoms among 146 children. Alcohol Alcohol. 2002;37(4):383-7. Excluded; Data not abstractable. [pmid: 12107042].
Baron S W. Risky lifestyles and the link between offending and victimization. Stud Crime Crime Prev. 1997;6(1):53-71. Excluded; Not a U.S. study.
Baron S W, Hartnagel T F. Street youth and criminal violence. J Res Crime Delinq. 1998;35(2):166-92. Excluded; Not a U.S. study.
Baron S W, Hartnagel T F. Street youth and labor market strain. J Crim Justice. 2002;30(6):519-33. Excluded; Not a U.S. study.
Barrios L C. Preventing school violence: a time for hard, solid thinking. Inj Prev. 2000;6(3):165-6. Excluded; Not a research study. [pmid: 11003177].
Barry C T, Frick P J, Killian A L. The relation of narcissism and self-esteem to conduct problems in children: A preliminary investigation. J Clin Child Adolesc Psychol. 2003;32(1):139-52. Excluded; Outcome is not violence. [pmid: 12573939].
Barry D S. Screen violence and America's children. Spectrum. 1993;66:37-42. Excluded; Not a research study.
Bars D R, Heyrend F L, Simpson C D, et al. Use of visual evoked-potential studies and EEG data to classify aggressive, explosive behavior of youths. Psychiatr Serv. 2001;52(1):81-6. Excluded; Study design not used. [pmid: 11141533].
Barstow D G. An offender-friendly society. J Psychosoc Nurs Ment Health Serv. 1994;32(8):56. Excluded; Not a research study. [pmid: 7965956].
Barylnik J. Psychopathology, psychosocial characteristics and family environment in juvenile delinquents. Ger J Psychol. 2003;6(2):30-2. Excluded; Not addressing they key questions.
Beaudoin M N, Hodgins S, Lavoie F. Homicide, schizophrenia and substance abuse or dependency. Can J Psychiatry. 1993;38(8):541-6. Excluded; Not a U.S. study. [pmid: 8242528].
Beauford J E, McNiel D E, Binder R L. Utility of the initial therapeutic alliance in evaluating psychiatric patients' risk of violence. Am J Psychiatry. 1997;154(9):1272-6. Excluded; Age of study population greater than 17 years. [pmid: 9286188].
Beauvais F, Chavez E L, Oetting E R, et al. Drug use, violence, and victimization among White American, Mexican American, and American Indian dropouts, students with academic problems, and students in good academic standing. J Couns Psychol. 1996;43(3):292-9. Excluded; Study design not used.
Becker D F, Edell W S, Fujioka T A. Attentional and intellectual deficits in unmedicated behavior-disordered adolescent inpatients. J Youth Adolesc. 1996;25:127-35. Excluded; Duplicated citation or findings.
Becker D F, Edell W S, Fujioka T A, et al. Attentional and intellectual deficits in unmedicated behavior-disordered adolescent inpatients. J Youth Adolesc. 1996;25(1):127-35. Excluded; Data not abstractable.
Beer J, Beer J. Aggression of youth as related to parental divorce and eye color. Percept Mot Skills. 1992;75(3 Pt 2):1066. Excluded; Study design not used. [pmid: 1484766].
Beier S R, Rosenfeld W D, Spitalny K C, et al. The potential role of an adult mentor in influencing high-risk behaviors in adolescents. Arch Pediatr Adolesc Med. 2000;154(4):327-31. Excluded; Outcome is not violence. [pmid: 10768667].
Bell CC, Jenkins EJ. Traumatic stress and children. J Health Care Poor Underserved 1991;2(1):175–85; Discussion 86–8. Excluded; Not a research study.
Bell C C, Jenkins E J. Community violence and children on Chicago's southside. Psychiatry. 1993;56(1):46-54. Excluded; Not addressing they key questions. [pmid: 8488212].
Bell K. Female offenders of sexual assault. J Emerg Nurs. 1999;25(3):241-3. Excluded; Not a research study. [pmid: 10346851].
Bellair P E, Roscigno V J. Local labor-market opportunity and adolescent delinquency. Soc Forces. 2000;78(4):1509-38. Excluded; Study design not used.
Bellair P E, Roscigno V J, McNulty T L. Linking local labor market opportunity to violent adolescent delinquency. J Res Crime Delinq. 2003;40(1):6-33. Excluded; Study design not used.
Bellair P E, Roscigno V J, McNulty T L. Linking local labor market opportunity to violent adolescent delinquency. J Res Crime Delinq. 2003;40(1):6-33. Excluded; Duplicated citation or findings.
Benda B B, Corwyn R F. The effect of abuse in childhood and in adolescence on violence among adolescents. Youth Soc. 2002;33(3):339-65. Excluded; Study design not used.
Benda B B, Corwyn R F, Rodell D E. Alcohol and violence among youth in boot camps for non-violent offenders. Alcohol Treat Q. 2001;19(1):37-55. Excluded; Age of study population greater than 17 years.
Benda B B, Turney H M. Youthful violence: Problems and prospects. Child Adolesc Social Work J. 2002;19(1):5-34. Excluded; Study design not used.
Bender D, Loesel F. Protective and risk effects of peer relations and social support on antisocial behaviour in adolescents from multi-problem milieus. J Adolesc. 1997;20(6):661-78. Excluded; Not a U.S. study. [pmid: 9417798].
Bennett L. Growing up with violence. Can Nurse. 1993;89(7):33-6. Excluded; Not a research study. [pmid: 8348520].
Bennett L, Fineran S. Sexual and severe physical violence among high school students. Power beliefs, gender, and relationship. Am J Orthopsychiatry. 1998;68(4):645-52. Excluded; Study design not used. [pmid: 9809124].
Bennett L W, Tolman R M, Rogalski C J, et al. Domestic abuse by male alcohol and drug addicts. Violence Vict. 1994;9(4):359-68. Excluded; Age of study population greater than 17 years. [pmid: 7577762].
Benoit J L, Kennedy W A. The abuse history of male adolescent sex offenders. J Interpers Violence. 1992;7(4):543-48. Excluded; Study design not used.
Benoit M. Impact of violence on children and adolescents: Report from a community-based child psychiatry clinic. Psychiatry Interpers Biol Process. 1993;56(1):124-6. Excluded; Not a research study.
Bentovim A. Trauma-organized systems in practice: Implications for work with abused and abusing children and young people. Clin Child Psychol Psychiatry. 1996;1(4):513-24. Excluded; Not a research study.
Berenbaum S A, Resnick S M. Early androgen effects on aggression in children and adults with congenital adrenal hyperplasia. Psychoneuroendocrinology. 1997;22(7):505-15. Excluded; Outcome is not violence. [pmid: 9373884].
Bergeret J. Adolescence: the crossroads of violence. J Adolesc Health. 1992;13(5):418-9. Excluded; Not a research study. [pmid: 1390802].
Bergman L. Dating violence among high school students. Soc Work. 1992;37(1):21-7. Excluded; Study does not focus on youth as perpetrators.
Berman L H. The effects of living with violence. J Am Acad Psychoanal. 1992;20(4):671-5. Excluded; Not a research study. [pmid: 1291552].
Bernstein D P, Stein J A, Handelsman L. Predicting personality pathology among adult patients with substance use disorders: effects of childhood maltreatment. Addictive Behaviors Addict Behav. 1998;23(6):855-68. Excluded; Outcome is not violence.
Berthhold K A, Hoover J H. Correlates of bullying and victimization among intermediate students in the Midwestern USA. Sch Psychol Int. 2000;21(1):65-78. Excluded; Data not abstractable.
Bickett L R, Milich R, Brown R T. Attributional styles of aggressive boys and their mothers. J Abnorm Child Psychol. 1996;24(4):457-72. Excluded; Outcome is not violence. [pmid: 8886942].
Bierman K L, Smoot D L, Aumiller K. Characteristics of aggressive-rejected, aggressive (nonrejected), and rejected (nonaggressive) boys. Child Dev. 1993;64(1):139-51. Excluded; Study does not focus on youth as perpetrators. [pmid: 8436026].
Bihm E M, Poindexter A R, Warren E R. Aggression and psychopathology in persons with severe or profound mental retardation. Res Dev Disabil. 1998;19(5):423-38. Excluded; Age of study population greater than 17 years. [pmid: 9770254].
Billingham R E, Bland R, Leary A. Dating violence at three time periods: 1976, 1992, and 1996. Psychol Rep. 1999;85(2):574-8. Excluded; Age of study population greater than 17 years. [pmid: 10611789].
Billingham R E, Gilbert K R. Parental divorce during childhood and use of violence in dating relationships. Psychol Rep. 1990;66(3 Pt 1):1003-9. Excluded; Age of study population greater than 17 years. [pmid: 2377682].
Bincer W L. The tragedy of gun violence. Wis Med J. 1994;93(10):508-9. Excluded; Not a research study. [pmid: 7810157].
Birmaher B, Stanley M, Greenhill L, et al. Platelet imipramine binding in children and adolescents with impulsive behavior. J Am Acad Child Adolesc Psychiatry. 1990;29(6):914-8. Excluded; Data not abstractable. [pmid: 2177056].
Birnbaum A S, Lytle L A, Hannan P J, et al. School functioning and violent behavior among young adolescents: a contextual analysis. Health Educ Res. 2003;18(3):389-403. Excluded; Study design not used. [pmid: 12828239].
Bischof G P, Stith S M, Whitney M L. Family environments of adolescent sex offenders and other juvenile delinquents. Adolescence. 1995;30(117):157-70. Excluded; Study design not used. [pmid: 7625251].
Bischof G P, Stith S M, Wilson S M. A comparison of the family systems of adolescent sexual offenders and nonsexual offending delinquents. Fam Relat. 1992;41(3):318-23. Excluded; Study design not used.
Bjoerkqvist K, Lagerspetz K M, Kaukiainen A. Do girls manipulate and boys fight? Developmental trends in regard to direct and indirect aggression. Aggress Behav. 1992;18(2):117-27. Excluded; Outcome is not violence.
Bjorkly S. SCL-90-R profiles in a sample of severely violent psychiatric inpatients. Aggress Behav. 2002;28(6):446-57. Excluded; Not a U.S. study.
Black M M, Ricardo I B. Drug use, drug trafficking, and weapon carrying among low-income, African-American, early adolescent boys. Pediatrics. 1994;93(6 Pt 2):1065-72. Excluded; Data not abstractable. [pmid: 8197009].
Blake P Y, Pincus J H, Buckner C. Neurologic abnormalities in murderers. Neurology. 1995;45(9):1641-7. Excluded; Study does not focus on youth as perpetrators. [pmid: 7675220].
Blum J, Ireland M, Blum R W. Gender differences in juvenile violence: A report from Add Health. J Adolesc Health. 2003;32(3):234-40. Excluded; Study design not used. [pmid: 12606117].
Blum J, Ireland M, Blum R W. Gender differences in juvenile violence: A report from Add Health. J Adolesc Health. 2003;32(3):234-40. Excluded; Study design not used. [pmid: 12606117].
Blum R W, Beuhring T, Shew M L, et al. The effects of race/ethnicity, income, and family structure on adolescent risk behaviors. Am J Public Health. 2000;90(12):1879-84. Excluded; Data not abstractable. [pmid: 11111260]. [pmcid: 1446419].
Blumensohn R, Ratzoni G, Weizman A, et al. Reduction in serotonin 5HT-sub-2 receptor binding on platelets of delinquent adolescents. Psychopharmacology (Berl). 1995;118(3):354-6. Excluded; Not a U.S. study. [pmid: 7617829].
Blumensohn R, Ratzoni G, Weizman A, et al. Reduction in serotonin 5HT2 receptor binding on platelets of delinquent adolescents. Psychopharmacology (Berl). 1995;118(3):354-6. Excluded; Not a U.S. study. [pmid: 7617829].
Blumenthal S, Gudjonsson G, Burns J. Cognitive distortions and blame attribution in sex offenders against adults and children. Child Abuse Negl. 1999;23(2):129-43. Excluded; Not a U.S. study. [pmid: 10075183].
Bodtker A. Conflict education and special-needs students, part two: Improving conflict competence and emotional competence. Mediat Q. 2001;18(4):377-95. Excluded; Outcome is not violence.
Bolger K E, Patterson C J. Developmental pathways from child maltreatment to peer rejection. Child Dev. 2001;72(2):549-68. Excluded; Data not abstractable. [pmid: 11333084].
Bolland J M. Hopelessness and risk behaviour among adolescents living in high-poverty inner-city neighbourhoods. J Adolesc. 2003;26(2):145-58. Excluded; Study design not used. [pmid: 12581723].
Bolland J M. Hopelessness and risk behaviour among adolescents living in high-poverty inner-city neighbourhoods. J Adolesc. 2003;26(2):145-58. Excluded; Duplicated citation or findings. [pmid: 12581723].
Bolland J M, McCallum D M, Lian B, et al. Hopelessness and violence among inner-city youths. Matern Child Health J. 2001;5(4):237-44. Excluded; Study design not used. [pmid: 11822525].
Bond A J, Surguy S M. Relationship between attitudinal hostility and P300 latencies. Progr Neuro-Psychopharmacol Biol Psychiatr. 2000;24(8):1277-88. Excluded; Outcome is not violence.
Booker A L, Hoffschmidt S J, Ash E. Personality features and characteristics of violent events committed by juvenile offenders. Behav Sci Law. 2001;19(1):81-96. Excluded; Not addressing the key questions. [pmid: 11241682].
Boone S L. Aggression in African-American boys: A discriminant analysis. Genet Soc Gen Psychol Monogr. 1991;117(2):203-28. Excluded; Data not abstractable. [pmid: 1860670].
Booth R E, Zhang Y. Severe aggression and related conduct problems among runaway and homeless adolescents. Psychiatr Serv. 1996;47(1):75-80. Excluded; Data not abstractable. [pmid: 8925350].
Borgatti JC. Crisis at Columbine: a lesson learned? Nurs Spectr (N Engl Ed) 1999;9(11):6–7, 32. Excluded; Not a research study.
Boruch R F, Coleman D, Doria-Ortiz C, et al. Violence prevention strategies targeted at the general population of minority youth. Public Health Rep. 1991;106(3):247-50. Excluded; Not a research study. [pmid: 1905036].
Borzekowski D L, Poussaint A F. Common themes from the extremes: using two methodologies to examine adolescents' perceptions of anti-violence public service announcements. J Adolesc Health. 2000;26(3):164-75. Excluded; Outcome is not violence. [pmid: 10706164].
Bosch X. Firearm-related homicides among teenagers and young adults. JAMA. 1999;281(4):324. Excluded; Not a research study. [pmid: 10493190].
Bosworth K, Espelage D, DuBay T. A computer-based violence prevention intervention for young adolescents: pilot study. Adolescence. 1998;33(132):785-95. Excluded; Outcome is not violence. [pmid: 9886006].
Bosworth K, Espelage D, DuBay T, et al. Using multimedia to teach conflict-resolution skills to young adolescents. Am J Prev Med. 1996;12(5 Suppl):65-74. Excluded; Data not abstractable. [pmid: 8909626].
Bosworth K, Espelage D L, Simon T R. Factors associated with bullying behavior in middle school students. J Early Adolesc. 1999;19(3):341-62. Excluded; Outcome is not violence.
Boulton M J. A comparison of structural and contextual features of middle school children's playful and aggressive fighting. Ethol Sociobiol. 1991;12(2):119-45. Excluded; Not a U.S. study.
Boulton M J, Flemington I. The effects of a short video intervention on secondary school pupils' involvement in definitions of and attitudes towards bullying. Sch Psychol Int. 1996;17(4):331-45. Excluded; Outcome is not violence.
Boulton M J, Underwood K. Bully/victim problems among middle school children. Br J Educ Psychol. 1992;62(Pt 1):73-87. Excluded; Not a U.S. study. [pmid: 1558813].
Bowen N K, Flora D B. When is it appropriate to focus on protection in interventions for adolescents?. Am J Orthopsychiatry. 2002;72(4):526-38. Excluded; Study design not used. [pmid: 15792038].
Bowers L, Smith P K, Binney V. Perceived family relationships of bullies, victims and bully/victims in middle childhood. J Soc Pers Relatsh. 1994;11(2):215-32. Excluded; Not a U.S. study.
Bownes I T, O'Gorman E C, Sayers A. Rape--a comparison of stranger and acquaintance assaults. Med Sci Law. 1991;31(2):102-9. Excluded; Not a U.S. study. [pmid: 2062190].
Boyatzis C J, Matillo G M, Nesbitt K M. Effects of the “Mighty Morphin Power Rangers” on children's aggression with peers. Child Study J. 1995;25(1):45-55. Excluded; Study does not focus on youth as perpetrators.
Brady E C, Chrisler J C, Hosdale D C, et al. Date rape: expectations, avoidance strategies, and attitudes toward victims. J Soc Psychol. 1991;131(3):427-9. Excluded; Outcome is not violence. [pmid: 1875681].
Braga A A. Serious youth gun offenders and the epidemic of youth violence in Boston. J Quant Criminol. 2003;19(1):33-54. Excluded; Data not abstractable.
Braga A A, Kennedy D M, Waring E J, et al. Problem-oriented policing, deterrence, and youth violence: An evaluation of Boston's Operation Ceasefire. J Res Crime Delinq. 2001;38(3):195-225. Excluded; Study does not focus on youth as perpetrators.
Brame R, Mulvey E P, Piquero A R. On the development of different kinds of criminal activity. Sociol Methods Res. 2001;29(3):319-41. Excluded; Not a research study.
Brannon J M, Troyer R. Peer group counseling: A normalized residential alternative to the specialized treatment of adolescent sex offenders. Int J Offender Ther Comp Criminol. 1991;35(3):225-34. Excluded; Not addressing they key questions.
Brecklin L R. The role of perpetrator alcohol use in the injury outcomes of intimate assaults. J Fam Violence. 2002;17(3):185-97. Excluded; Age of study population greater than 17 years.
Bremer J F. Serious juvenile sex offenders: Treatment and long-term follow-up. Psychiatr Ann. 1992;22(6):326-32. Excluded; Study does not focus on youth as perpetrators.
Brendgen M, Vitaro F, Tremblay R E, et al. Parent and peer effects on delinquency-related violence and dating violence: A test of two mediational models. Soc Dev. 2002;11(2):225-44. Excluded; Not a U.S. study.
Brendgen M, Vitaro R, Tremblay R E, et al. Reactive and proactive aggression: predictions to physical violence in different contexts and moderating effects of parental monitoring and caregiving behavior. J Abnorm Child Psychol. 2001;29(4):293-304. Excluded; Not a U.S. study. [pmid: 11523835].
Brener N D, Krug E G, Dahlberg L L, et al. Nurses' logs as an evaluation tool for school-based violence prevention programs. J Sch Health. 1997;67(5):171-4. Excluded; Not a research study. [pmid: 9210101].
Brener N D, Simon T R, Krug E G, et al. Recent trends in violence-related behaviors among high school students in the United States. JAMA. 1999;282(5):440-6. Excluded; Study design not used. [pmid: 10442659].
Brener N D, Wilson T W. Substance use on school property among students attending alternative high schools in the United States. J Drug Educ. 2001;31(4):329-42. Excluded; Outcome is not violence. [pmid: 11957389].
Brennan P A, Grekin E R, Mednick S A. Maternal smoking during pregnancy and adult male criminal outcomes. Arch Gen Psychiatry. 1999;56(3):215-9. Excluded; Not a U.S. study. [pmid: 10078497].
Breslow R E, Klinger B I, Erickson B J. The disruptive behavior disorders in the psychiatric emergency service. Gen Hosp Psychiatry. 1999;21(3):214-9. Excluded; Study design not used. [pmid: 10378115].
Bretherton D, Collins L, Ferretti C. Dealing with conflict: Assessment of a course for secondary school students. Aust Psychol. 1993;28(2):105-11. Excluded; Not a U.S. study.
Brezina T, Piquero A R, Mazerolle. Student anger and aggressive behavior in school: An initial test of Agnew's macro-level strain theory. J Res Crime Delinq. 2001;38(4):362-86. Excluded; Data not abstractable.
Briere J, Elliott D. Prevalence, characteristics, and long-term sequelae of natural disaster exposure in the general population. J Trauma Stress. 2000;13(4):661-79. Excluded; Outcome is not violence. [pmid: 11109238].
Briggs S, MacKay T, Miller S. The Edinbarnet Playground Project: Changing aggressive behavior through structured intervention. AEP J. 1995;11(2):37-44. Excluded; Not a research study.
Briscoe J. Breaking the cycle of violence: A rational approach to at-risk youth. Fed Probat. 1997;61(3):3-13. Excluded; Not a research study.
Brockenbrough K K, Cornell D G, Loper A B. Aggressive attitudes among victims of violence at school. Educ Treat Child. 2002;25(3):273-87. Excluded; Study design not used.
Brody S L. Violence associated with acute cocaine use in patients admitted to a medical emergency department. NIDA Res Monogr. 1990;103:44-59. Excluded; Age of study population greater than 17 years. [pmid: 2096292].
Broidy L M, Nagin D S, Tremblay R E, et al. Developmental trajectories of childhood disruptive behaviors and adolescent delinquency: A six-site, cross-national study. Dev Psychol. 2003;39(2):222-45. Excluded; Not a research study. [pmid: 12661883].
Broidy L M, Nagin D S, Tremblay R E, et al. Developmental trajectories of childhood disruptive behaviors and adolescent delinquency: a six-site, cross-national study. Dev Psychol. 2003;39(2):222-45. Excluded; Duplicated citation or findings. [pmid: 12661883].
Brondolo E, Baruch C, Conway E, et al. Aggression among inner-city minority youth: A biopsychosocial model for school-based evaluation and treatment. J Soc Distress Homeless. 1994;3(1):53-80. Excluded; Outcome is not violence.
Brooke M M, Questad K A, Patterson D R, et al. Agitation and restlessness after closed head injury: a prospective study of 100 consecutive admissions. Arch Phys Med Rehabil. 1992;73(4):320-3. Excluded; Outcome is not violence. [pmid: 1417466].
Brookoff D, O'Brien K K, Cook C S, et al. Characteristics of participants in domestic violence. Assessment at the scene of domestic assault. JAMA. 1997;277(17):1369-73. Excluded; Age of study population greater than 17 years. [pmid: 9134942].
Brooks J H, Reddon J R. Serum testosterone in violent and nonviolent young offenders. J Clin Psychol. 1996;52(4):475-83. Excluded; Not a U.S. study. [pmid: 8842886].
Brown T L, Henggeler S W, Brondino M J, et al. Trauma exposure, protective factors and mental health functioning of substance-abusing and dependent juvenile offenders. J Emot Behav Disord. 1999;7(2):94-102. Excluded; Outcome is not violence.
Buitelaar J K. Open-label treatment with risperidone of 26 psychiatrically-hospitalized children and adolescents with mixed diagnoses and aggressive behavior. J Child Adolesc Psychopharmacol. 2000;10(1):19-26. Excluded; Not a research study. [pmid: 10755578].
Buitelaar J K, van der Gaag R J, Cohen-Kettenis P, et al. A randomized controlled trial of risperidone in the treatment of aggression in hospitalized adolescents with subaverage cognitive abilities. J Clin Psychiatry. 2001;62(4):239-48. Excluded; Not a U.S. study. [pmid: 11379837].
Burke E C. Youth violence. An epidemic vaccines can't treat. Minn Med. 1993;76(8):5. Excluded; Not a research study. [pmid: 8127297].
Burks V S, Laird R D, Dodge K A, et al. Knowledge structures, social information processing, and children's aggressive behavior. Soc Dev. 1999;8(2):220-36. Excluded; Data not abstractable. [pmid: 20011226].
Burrell B, Thompson B, Sexton D. Predicting child abuse potential across family types. Child Abuse Negl. 1994;18(12):1039-49. Excluded; Outcome is not violence. [pmid: 7850612].
Burt CW. Injury-related visits to hospital emergency departments: United States, 1992. Adv Data 1995(261):1–20. Excluded; Not a research study.
Burton D, Foy D, Bwanausi C, et al. The relationship between traumatic exposure, family dysfunction, and post-traumatic stress symptoms in male juvenile offenders. J Trauma Stress. 1994;7(1):83-93. Excluded; Outcome is not violence. [pmid: 8044445].
Burton D L. An examination of social cognitive theory with differences among sexually aggressive, physically aggressive and nonaggressive children in state care. Violence Vict. 1999;14(2):161-78. Excluded; Age of study population greater than 17 years. [pmid: 10418769].
Burton D L, Nesmith A A, Badten L. Clinician's views on sexually aggressive children and their families: A theoretical exploration. Child Abuse Negl. 1997;21(2):157-70. Excluded; Study does not focus on youth as perpetrators. [pmid: 9056095].
Busch K G, Zagar R, Hughes J R, et al. Adolescents who kill. J Clin Psychol. 1990;46(4):472-85. Excluded; Study design not used. [pmid: 2212052].
Bushman B J, Baumeister R F. Threatened egotism, narcissism, self-esteem, and direct and displaced aggression: does self-love or self-hate lead to violence?. J Pers Soc Psychol. 1998;75(1):219-29. Excluded; Age of study population greater than 17 years. [pmid: 9686460].
Buss D M. Manipulation in close relationships: five personality factors in interactional context. J Pers. 1992;60(2):477-99. Excluded; Outcome is not violence. [pmid: 1635051].
Butchart A, Engstrom K, et al. Sex- and age- specific relations between economic development, economic inequality and homicide rates in people aged 0–24 years: a cross-sectional analysis. Bull World Health Organ. 2002;80(10):797-805. Excluded; Study does not focus on youth as perpetrators. [pmid: 12471400].
Butts J A, Snyder H N. Youngest delinquents: Offenders under age 15. Sch Interv Rep. 1997;11(2):6-11. Excluded; Not a research study.
Butz C, Spaccarelli S. Use of physical force as an offense characteristic in subtyping juvenile sexual offenders. Sex Abuse. 1999;11(3):217-32. Excluded; Study design not used. [pmid: 10497781].
Bynum E G, Weiner R I. Self-concept and violent delinquency in urban African-American adolescent males. Psychol Rep. 2002;90(2):477-86. Excluded; Study design not used. [pmid: 12061587].
Caggiano A D. Identifying violent-toward-staff juvenile delinquents via the Millon Adolescent Clinical Inventory and neuropsychological measures. J Offender Rehabil. 2000;32(12):147-65. Excluded; Not addressing they key questions.
Cahn M D, Chamberlain B, Cross P O, et al. Forum on youth violence in minority communities. Interventions in early childhood. Public Health Rep. 1991;106(3):258-63. Excluded; Not a research study. [pmid: 1905039].
Cairns R B, Coleman-Miller B, Greenwood P W, et al. Violence prevention strategies directed toward high-risk minority youths. Public Health Rep. 1991;106(3):250-4. Excluded; Not a research study. [pmid: 1905037].
Caldwell J R. Interpersonal violence. Can political, sociologic or economic reform stem the epidemic?. J Fla Med Assoc. 1994;81(7):459-60. Excluded; Not a research study. [pmid: 7798870].
Caldwell M F, Van Rybroek G J. Efficacy of a decompression treatment model in the clinical management of violent juvenile offenders. Int J Offender Ther Comp Criminol. 2001;45(4):469-77. Excluded; Outcome is not violence.
Calicchia J A, Moncata S J, Santostefano S. Cognitive control differences in violent juvenile inpatients. J Clin Psychol. 1993;49(5):731-40. Excluded; Study design not used. [pmid: 8254083].
Callahan C M, Rivara F P, Farrow J A. Youth in detention and handguns. J Adolesc Health. 1993;14(5):350-5. Excluded; Outcome is not violence. [pmid: 8399245].
Calvert W J. Neighborhood disorder, individual protective factors, and the risk of adolescent delinquency. ABNF J. 2002;13(6):127-35. Excluded; Study design not used. [pmid: 12592829].
Campanella S. Delinquency risk prediction. J Child Youth Care. 1990;4(5):73-83. Excluded; Not a research study.
Campbell A. Representations, repertoires and power: Mother-child conflict. J Theory Soc Behav. 1995;25(1):35-57. Excluded; Outcome is not violence.
Campbell A, Muncer S, Odber J. Aggression and testosterone: Testing a bio-social model. Aggress Behav. 1997;23(4):229-38. Excluded; Not a U.S. study.
Campbell J S, Lerew C. Juvenile sex offenders in diversion. Sex Abuse. 2002;14(1):1-17. Excluded; Not addressing they key questions. [pmid: 11803592].
Cano A, Avery-Leaf S, Cascardi M, et al. Dating violence in two high school samples: Discriminating variables. J Prim Prev. 1998;18(4):431-46. Excluded; Study design not used.
Cantrell P J, MacIntyre D I, Sharkey K J, et al. Violence in the marital dyad as a predictor of violence in the peer relationships of older adolescents/young adults. Violence Vict. 1995;10(1):35-41. Excluded; Age of study population greater than 17 years. [pmid: 8555118].
Capaldi D M, Clark S. Prospective family predictors of aggression toward female partners for at-risk young men. Dev Psychol. 1998;34(6):1175-88. Excluded; Data not abstractable. [pmid: 9823503].
Capaldi D M, Dishion T J, Stoolmiller M, et al. Aggression toward female partners by at-risk young men: the contribution of male adolescent friendships. Dev Psychol. 2001;37(1):61-73. Excluded; Age of study population greater than 17 years. [pmid: 11206434].
Capaldi D M, Owen L D. Physical aggression in a community sample of at-risk young couples: gender comparisons for high frequency, injury, and fear. J Fam Psychol. 2001;15(3):425-40. Excluded; Study does not focus on youth as perpetrators. [pmid: 11584793].
Capaldi D M, Patterson G R. Can violent offenders be distinguished from frequent offenders: Prediction from childhood to adolescence. J Res Crime Delinq. 1996;33(2):206-31. Excluded; Data not abstractable.
Capaldi D M, Shortt J W, Crosby L. Physical and psychological aggression in at-risk young couples: Stability and change in young adulthood. Merrill Palmer Q. 2003;49(1):1-27. Excluded; Data not abstractable.
Cappell C, Heiner R B. The intergenerational transmission of family aggression. J Fam Violence. 1990;5(2):135-52. Excluded; Age of study population greater than 17 years.
Caprara G V, Barbaranelli C, Pastorelli C, et al. Prosocial foundations of children's academic achievement. Psychol Sci. 2000;11(4):302-6. Excluded; Outcome is not violence. [pmid: 11273389].
Caprara G V, Regalia C, Bandura A. Longitudinal impact of perceived self-regulatory eficacy on violent conduct. Eur Psychol. 2002;7(1):63-9. Excluded; Not a U.S. study.
Caputo A A, Frick P J, Brodsky S L. Family violence and juvenile sex offending: The potential mediating role of psychopathic traits and negative attitudes toward women. Crim Justice Behav. 1999;26(3):338-56. Excluded; Not addressing they key questions.
Carbonneau R, Tremblay R E, Vitaro F, et al. Paternal alcoholism, paternal absence and the development of problem behaviors in boys from age six to twelve years. J Stud Alcohol. 1998;59(4):387-98. Excluded; Not a U.S. study. [pmid: 9647421].
Carlo G, Raffaelli M, Laible D J, et al. Why are girls less physically aggressive than boys? Personality and parenting mediators of physical aggression. Sex Roles. 1999;40(910):711-29. Excluded; Data not abstractable.
Carlson B E. Adolescent observers of marital violence. J Fam Violence. 1990;5(4):285-99. Excluded; Study design not used.
Carlson E A. A prospective longitudinal study of attachment disorganization/disorientation. Child Dev. 1998;69(4):1107-28. Excluded; Outcome is not violence. [pmid: 9768489].
Carpenter E M, Nangle D W. Effects of brief verbal instructions on aggression: A replication in a Head Start setting. Child Fam Behav Ther. 2002;24(4):21-38. Excluded; Outcome is not violence.
Carroll S T, Riffenburgh R H, Roberts T A, et al. Tattoos and body piercings as indicators of adolescent risk-taking behaviors. Pediatrics. 2002;109(6):1021-10217. Excluded; Data not abstractable. [pmid: 12042538].
Carvajal S C, Hanson C E, Romero A J, et al. Behavioural risk factors and protective factors in adolescents: a comparison of Latinos and non-Latino whites. Ethn Health. 2002;7(3):181-93. Excluded; Study design not used. [pmid: 12523944].
Caspi A, Begg D, Dickson N. Personality differences predict health-risk behaviors in young adulthood: evidence from a longitudinal study. J Pers Soc Psychol. 1997;73:1052-63. Excluded; Duplicated citation or findings. [pmid: 9364760].
Caspi A, Begg D, Dickson N, et al. Personality differences predict health-risk behaviors in young adulthood: evidence from a longitudinal study. J Pers Soc Psychol. 1997;73(5):1052-63. Excluded; Not a U.S. study. [pmid: 9364760].
Caspi A, McClay J, Moffitt T E, et al. Role of genotype in the cycle of violence in maltreated children. Science. 2002;297(5582):851-4. Excluded; Not a U.S. study. [pmid: 12161658].
Caspi A, Moffitt T E, Newman D L, et al. Behavioral observations at age 3 years predict adult psychiatric disorders. Longitudinal evidence from a birth cohort. Arch Gen Psychiatry. 1996;53(11):1033-9. Excluded; Not a U.S. study. [pmid: 8911226].
Cassetta RA. Children: a community in crisis. Am Nurse 1994;26(10):1, 20–1. Excluded; Not a research study.
Cassetta R A. Nurses work to prevent violence in schools. Am Nurse. 1994;26(4):7. Excluded; Not a research study. [pmid: 7810920].
Castiglia P T. Gangs. J Pediatr Health Care. 1993;7(1):39-41. Excluded; Not a research study. [pmid: 8106927].
Cauffman E, Feldman S S, Waterman J, et al. Posttraumatic stress disorder among female juvenile offenders. J Am Acad Child Adolesc Psychiatry. 1998;37(11):1209-16. Excluded; Data not abstractable. [pmid: 9808933].
Cavell T A, Hughes J N. Secondary prevention as context for assessing change processes in aggressive children. J Sch Psychol. 2000;38(3):199-235. Excluded; Study does not focus on youth as perpetrators.
Chang J, Jen, Chen J J, Brownson R C. The role of repeat victimization in adolescent delinquent behaviors and recidivism. J Adolesc Health. 2003;32(4):272-80. Excluded; Duplicated citation or findings. [pmid: 12667731].
Chang J J, Chen J J, Brownson R C. The role of repeat victimization in adolescent delinquent behaviors and recidivism. J Adolesc Health. 2003;32(4):272-80. Excluded; Data not abstractable. [pmid: 12667731].
Chapple C L. Examining intergenerational violence: violent role modeling or weak parental controls?. Violence Vict. 2003;18(2):143-62. Excluded; Study design not used. [pmid: 15109120].
Charlebois P, LeBlanc M, Gagnon C, et al. Age trends in early behavioral predictors of serious antisocial behaviors. J Psychopathol Behav Assess. 1993;15(1):23-41. Excluded; Not a U.S. study.
Chase K A, Treboux D, O'Leary K D. Characteristics of high-risk adolescents' dating violence. J Interpers Violence. 2002;17(1):33-49. Excluded; Study design not used.
Chase K A, Treboux D, O'Leary K D, et al. Specificity of dating aggression and its justification among high-risk adolescents. J Abnorm Child Psychol. 1998;26(6):467-73. Excluded; Study does not focus on youth as perpetrators. [pmid: 9915653].
Cheadle A, Wagner E, Anderman C, et al. Measuring community mobilization in the Seattle Minority Youth Health Project. Eval Rev. 1998;22(6):699-716. Excluded; Not a research study. [pmid: 10345195].
Cheadle A, Wagner E, Walls M, et al. The effect of neighborhood-based community organizing: results from the Seattle Minority Youth Health Project. Health Serv Res. 2001;36(4):671-89. Excluded; Outcome is not violence. [pmid: 11508634]. [pmcid: 1089251].
Chen C, Greenberger E, Lester J, et al. A cross-cultural study of family and peer correlates of adolescent misconduct. Dev Psychol. 1998;34(4):770-81. Excluded; Data not abstractable. [pmid: 9681269].
Cheng T L, Wright J L, Fields C B, et al. Violent injuries among adolescents: declining morbidity and mortality in an urban population. Ann Emerg Med. 2001;37(3):292-300. Excluded; Outcome is not violence. [pmid: 11223766].
Cheong J, Patock-Peckham J A, Nagoshi C T. Effects of alcoholic beverage, instigation, and inhibition on expectancies of aggressive behavior. Violence Vict. 2001;16(2):173-84. Excluded; Outcome is not violence. [pmid: 11345477].
Cherpitel C J. Alcohol and casualties: a comparison of emergency room and coroner data. Alcohol Alcohol. 1994;29(2):211-8. Excluded; Age of study population greater than 17 years. [pmid: 8080603].
Chesney-Lind M, Paramore V V. Are girls getting more violent? Exploring juvenile robbery trends. J Contemp Crim Justice. 2001;17(2):142-66. Excluded; Outcome is not violence.
Cheung P, Schweitzer I, Tuckwell V, et al. A prospective study of assaults on staff by psychiatric in-patients. Med Sci Law. 1997;37(1):46-52. Excluded; Not a U.S. study. [pmid: 9383945].
Choi P Y, Pope H G. Violence toward women and illicit androgenic-anabolic steroid use. Ann Clin Psychiatry. 1994;6(1):21-5. Excluded; Data not abstractable. [pmid: 7951641].
Christoffel K K. Violent death and injury in US children and adolescents. Am J Dis Child. 1990;144(6):697-706. Excluded; Not a research study. [pmid: 2356796].
Christoffel K K. Firearm-related homicides among teenagers and young adults. JAMA. 1999;281(4):323-4. Excluded; Not a research study. [pmid: 10442655].
Christoffel K K, Spivak H, Witwer M. Youth violence prevention: the physician's role. JAMA. 2000;283(9):1202-3. Excluded; Not a research study. [pmid: 10703789].
Cirillo K J, Pruitt B E, Colwell B, et al. School violence: prevalence and intervention strategies for at-risk adolescents. Adolescence. 1998;33(130):319-30. Excluded; Outcome is not violence. [pmid: 9706319].
Clare P, Bailey S, Clark A. Relationship between psychotic disorders in adolescence and criminally violent behaviour. A retrospective examination. Br J Psychiatry. 2000;177:275-9. Excluded; Not a research study. [pmid: 11040891].
Clark E, Beck D, Sloane H, et al. Self-modeling with preschoolers: Is it different?. Sch Psychol Int. 1993;14(1):83-9. Excluded; Outcome is not violence.
Clark J. Our youth, our future. J Ky Med Assoc. 1994;92(5):197-8. Excluded; Not a research study. [pmid: 8027640].
Clarke J, Stein M D, Sobota M, et al. Victims as victimizers: physical aggression by persons with a history of childhood abuse. Arch Intern Med. 1999;159(16):1920-4. Excluded; Age of study population greater than 17 years. [pmid: 10493322].
Clarke R A, Murphy D L, Constantino J N. Serotonin and externalizing behavior in young children. Psychiatry Res. 1999;86(1):29-40. Excluded; Age of study population greater than 17 years. [pmid: 10359480].
Claussen A H, Crittenden P M. Physical and psychological maltreatment: relations among types of maltreatment. Child Abuse Negl. 1991;15(12):5-18. Excluded; Study does not focus on youth as perpetrators. [pmid: 2029672].
Clemence A J, Hilsenroth M J, Sivec H J, et al. Hand Test AGG and AOS variables: Relation with teacher rating of aggressiveness. J Pers Assess. 1999;73(3):334-44. Excluded; Data not abstractable. [pmid: 10689647].
Clubb P A, Browne D C, Humphrey A D, et al. Violent behaviors in early adolescent minority youth: results from a “middle school youth risk behavior survey”. Matern Child Health J. 2001;5(4):225-35. Excluded; Study design not used. [pmid: 11822524].
Coccaro E F, Kavoussi R J, Hauger R L. Serotonin function and antiaggressive response to fluoxetine: a pilot study. Biol Psychiatry. 1997;42(7):546-52. Excluded; Outcome is not violence. [pmid: 9376450].
Cochran J K, Wood P B, Arneklev B J. Is the religiosity-delinquency relationship spurious? Social control theories. J Res Crime Delinq. 1994;31(1):92-123. Excluded; Outcome is not violence.
Cockburn A. The best years of their lives. New Statesman Soc. 1990;3:25-6. Excluded; Not a research study.
Cohen E. The violent adolescent: theoretical and clinical considerations. Am J Psychoanal. 2002;62(3):209-12. Excluded; Not a research study. [pmid: 12357679].
Cohen R A, Rosenbaum A, Kane R L, et al. Neuropsychological correlates of domestic violence. Violence Vict. 1999;14(4):397-411. Excluded; Age of study population greater than 17 years. [pmid: 10751047].
Cohen S, Lang C. Forum on youth violence in minority communities. Application of the principles of community-based programs. Public Health Rep. 1991;106(3):269-70. Excluded; Not a research study. [pmid: 1905043].
Coie J D, Cillessen A H N, Dodge K A, et al. It takes two to fight: A test of relational factors and a method for assessing aggressive dyads. Dev Psychol. 1999;35(5):1179-88. Excluded; Study does not focus on youth as perpetrators. [pmid: 10493644].
Coker A L, McKeown R E, Sanderson M, et al. Severe dating violence and quality of life among south carolina high school students. Am J Prev Med. 2000;19(4):220-7. Excluded; Study design not used. [pmid: 11064224].
Colder C R, Lochman J E, Wells K C. The moderating effects of children's fear and activity level on relations between parenting practices and childhood symptomatology. J Abnorm Child Psychol. 1997;25(3):251-63. Excluded; Age of study population greater than 17 years. [pmid: 9212377].
Colder C R, Mott J, Levy S, et al. The relation of perceived neighborhood danger to childhood aggression: A test of mediating mechanisms. Am J Community Psychol. 2000;28(1):83-103. Excluded; Study does not focus on youth as perpetrators. [pmid: 10824275].
Cole D A, Maxwell S E, Martin J M, et al. The development of multiple domains of child and adolescent self-concept: a cohort sequential longitudinal design. Child Dev. 2001;72(6):1723-46. Excluded; Outcome is not violence. [pmid: 11768142].
Coleman M, Pfeiffer S, Oakland T. Aggression replacement training with behaviorally disordered adolescents. Behav Disord. 1992;18(1):54-66. Excluded; Data not abstractable.
Coles C J, Greene A F, Braithwaite H O. The relationship between personality, anger expression, and perceived family control among incarcerated male juveniles. Adolescence. 2002;37(146):395-409. Excluded; Outcome is not violence. [pmid: 12144167].
Collinsworth H J. Adolescent violence. J La State Med Soc. 2000;152(10):483-4. Excluded; Not a research study. [pmid: 11059917].
Colsman M, Wulfert E. Conflict Resolution Style as an Indicator of Adolescents' Substance Use and Other Problem Behaviors. Addict Behav. 2002;27(4):633-48. Excluded; Study design not used. [pmid: 12188597].
Compton R. Discovering the promise of curriculum integration: The National Curriculum Integration Project. Confl Resolut Q. 2002;19(4):447-64. Excluded; Not a research study.
Connolly J, Pepler D, Craig W, et al. Dating experiences of bullies in early adolescence. Child Maltreat. 2000;5(4):299-310. Excluded; Not a U.S. study. [pmid: 11232258].
Connor D E, Edwards G, Fletcher K E, et al. Correlates of comorbid psychopathology in children with ADHD. J Am Acad Child Adolesc Psychiatry. 2003;42(2):193-200. Excluded; Outcome is not violence. [pmid: 12544179].
Connor D F, Barkley R A, Davis H T. A pilot study of methylphenidate, clonidine, or the combination in ADHD comorbid with aggressive oppositional defiant or conduct disorder. Clin Pediatr (Phila). 2000;39(1):15-25. Excluded; Outcome is not violence. [pmid: 10660814].
Connor D F, Melloni R H, Harrison R J. Overt categorical aggression in referred children and adolescents. J Am Acad Child Adolesc Psychiatry. 1998;37(1):66-73. Excluded; Not addressing they key questions. [pmid: 9444902].
Connor D F, Melloni R H J, Harrison R J. Overt categorical aggression in referred children and adolescents. J Am Acad Child Adolesc Psychiatry. 1998;37(1):66-73. Excluded; Duplicated citation or findings. [pmid: 9444902].
Connor D F, Ozbayrak K R, Benjamin S, et al. A pilot study of nadolol for overt aggression in developmentally delayed individuals. J Am Acad Child Adolesc Psychiatry. 1997;36(6):826-34. Excluded; Data not abstractable. [pmid: 9183139].
Conroy D E, Silva J M, Newcomer R R, et al. Personal and participatory socializers of the perceived legitimacy of aggressive behavior in sport. Aggress Behav. 2001;27(6):405-18. Excluded; Outcome is not violence.
Conseur A, Rivara F P, Barnoski R, et al. Maternal and perinatal risk factors for later delinquency. Pediatrics. 1997;99(6):785-90. Excluded; Outcome is not violence. [pmid: 9164769].
Constantino J N, Liberman M, Kincaid M. Effects of serotonin reuptake inhibitors on aggressive behavior in psychiatrically hospitalized adolescents: results of an open trial. J Child Adolesc Psychopharmacol. 1997;7(1):31-44. Excluded; Duplicated citation or findings. [pmid: 9192540].
Conway K P, McCord J. A longitudinal examination of the relation between co-offending with violent accomplices and violent crime. Aggress Behav. 2002;28(2):97-108. Excluded; Study design not used.
Coohey C. The role of friends, in-laws, and other kin in father-perpetrated child physical abuse. Child Welfare. 2000;79(4):373-402. Excluded; Outcome is not violence. [pmid: 10925765].
Cook P J, Juarez P, Lee R K, et al. Weapons and minority youth violence. Public Health Rep. 1991;106(3):254-8. Excluded; Not a research study. [pmid: 1905038].
Cookson H M. Alcohol use and offence type in young offenders. Br J Criminol. 1992;32(3):352-60. Excluded; Not a U.S. study.
Cooley-Quille M R, Turner S M, Beidel D C. Emotional impact of children's exposure to community violence: a preliminary study. J Am Acad Child Adolesc Psychiatry. 1995;34(10):1362-8. Excluded; Outcome is not violence. [pmid: 7592274].
Coppens N M, Gentry L K. Video analysis of playground injury-risk situations. Res Nurs Health. 1991;14(2):129-36. Excluded; Outcome is not violence. [pmid: 2047534].
Corbett M, Duggan C, Larkin E. Substance misuse and violence: A comparison of special hospital inpatients diagnosed with either schizophrenia or personality disorder. Crim Behav Ment Health. 1998;8(4):311-21. Excluded; Not a U.S. study.
Cornell D G. Prior adjustment of violent juvenile offenders. Law Hum Behav. 1990;14(6):569-77. Excluded; Study design not used.
Cornell D G. Juvenile homicide: A growing national problem. Behav Sci Law. 1993;11(4):389-96. Excluded; Not addressing they key questions.
Cornell D G, Loper A B. Assessment of violence and other high-risk behaviors with a school survey. School Psych Rev. 1998;27(2):317-30. Excluded; Study design not used.
Cornell D G, Peterson C S, Richards H. Anger as a predictor of aggression among incarcerated adolescents. J Consult Clin Psychol. 1999;67(1):108-15. Excluded; Study design not used. [pmid: 10028214].
Cornell D G, Wilson L A. The PIQ greater than VIQ discrepancy in violent and nonviolent delinquents. J Clin Psychol. 1992;48(2):256-61. Excluded; Study design not used. [pmid: 1573030].
Cortoni F, Marshall W L. Sex as a coping strategy and its relationship to juvenile sexual history and intimacy in sexual offenders. Sex Abuse. 2001;13(1):27-43. Excluded; Outcome is not violence.
Corwyn R F, Benda B B. Violent youths in southern public schools in America. Int J Adolesc Youth. 2001;10(12):69-90. Excluded; Study design not used.
Costello B J, Dunaway R G. Egotism and delinquent behavior. J Interpers Violence. 2003;18(5):572-90. Excluded; Study design not used.
Cota-Robles S, Neiss M, Rowe D C. The role of puberty in violent and nonviolent delinquency among Anglo American, Mexican American, and African American boys. J Adolesc Res. 2002;17(4):364-76. Excluded; Study design not used.
Cotten N U, Resnick J, Browne D C, et al. Aggression and fighting behavior among African-American adolescents: individual and family factors. Am J Public Health. 1994;84(4):618-22. Excluded; Study design not used. [pmid: 8154566]. [pmcid: 1614788].
Cotton P. Violence decreases with gang truce. JAMA. 1992;268(4):443-4. Excluded; Not a research study. [pmid: 1280696].
Cottrol C, Frances R. Substance abuse, comorbid psychiatric disorder, and repeated traumatic injuries. Hosp Community Psychiatry. 1993;44(8):715-6. Excluded; Outcome is not violence. [pmid: 8375830].
Courtenay W H. Youth violence? Let's call it what it is. J Am Coll Health. 1999;48(3):141-2. Excluded; Not a research study. [pmid: 10584450].
Cousins L H. Toward a sociocultural context for understanding violence and disruption in Black urban schools and communities. J Sociol Soc Welf. 1997;24(2):41-63. Excluded; Not a research study.
Cousins L H. Moral markets for troubling youths: A disruption! Child Glob J Child Res. 2001;8(2):193-211. Excluded; Not a research study.
Cousins L H, Mabrey T. Re-gendering social work practice and education: The case for African-American girls. J Hum Behav Soc Environ. 1998;1(23):91-104. Excluded; Not a research study.
Cowie H, Olafsson R. The role of peer support in helping the victims of bullying in a school with high levels of aggression. Sch Psychol Int. 2000;21(1):79-95. Excluded; Outcome is not violence.
Cox R D, Schopler E. Aggression and self-injurious behaviors in persons with autism: The TEACCH approach. Acta Paedopsychiatr. 1993;56(2):85-90. Excluded; Not a research study. [pmid: 8135116].
Coyne-Beasley T, Schoenbach V J, Herman-Giddens M E. The epidemiology of adolescent homicide in North Carolina from 1990 to 1995. Arch Pediatr Adolesc Med. 1999;153(4):349-56. Excluded; Study does not focus on youth as perpetrators. [pmid: 10201716].
Craig W M. The relationship among bullying, victimization, depression, anxiety, and aggression in elementary school children. Pers Individ Dif. 1998;24(1):123-30. Excluded; Data not abstractable.
Craig W M, Pepler D, Atlas R. Observations of bullying in the playground and in the classroom. Sch Psychol Int. 2000;21(1):22-36. Excluded; Not a U.S. study.
Cramer E, McFarlane J. Pornography and abuse of women. Public Health Nurs. 1994;11(4):268-72. Excluded; Age of study population greater than 17 years. [pmid: 7937500].
Crane-Ross D, Tisak M S, Tisak J. Aggression and conventional rule violation among adolescents: Social-reasoning predictors of social behavior. Aggress Behav. 1998;24(5):347-65. Excluded; Outcome is not violence.
Crick N R. Engagement in gender normative versus nonnormative forms of aggression: Links to social-psychological adjustment. Dev Psychol. 1997;33(4):610-7. Excluded; Study does not focus on youth as perpetrators. [pmid: 9232376].
Crick N R, Dodge K A. Social information-processing mechanisms on reactive and proactive aggression. Child Dev. 1996;67(3):993-1002. Excluded; Outcome is not violence. [pmid: 8706540].
Crick N R, Grotpeter J K, Bigbee M A. Relationally and physically aggressive children's intent attributions and feelings of distress for relational and instrumental peer provocations. Child Dev. 2002;73(4):1134-42. Excluded; Study does not focus on youth as perpetrators. [pmid: 12146738].
Crimmins S, Langley S, Brownstein H H, et al. Convicted women who have killed children: A self-psychology perspective. J Interpers Violence. 1997;12(1):49-69. Excluded; Age of study population greater than 17 years.
Crimmins S M, Cleary S D, Brownstein H H, et al. Trauma, drugs and violence among juvenile offenders. J Psychoactive Drugs. 2000;32(1):43-54. Excluded; Study design not used. [pmid: 10801067].
Crittenden P M, Craig S E. Developmental trends in the nature of child homicide. J Interpers Violence. 1990;5(2):202-16. Excluded; Age of study population greater than 17 years.
Crowley T J, Mikulich S K, MacDonald M, et al. Substance-dependent, conduct-disordered adolescent males: severity of diagnosis predicts 2-year outcome. Drug Alcohol Depend. 1998;49(3):225-37. Excluded; Not addressing they key questions. [pmid: 9589270].
Crowner M L, Douyon R, Convit A, et al. Akathisia and violence. Psychopharmacol Bull. 1990;26(1):115-7. Excluded; Age of study population greater than 17 years. [pmid: 1973544].
Crowner M L, Douyon R, Convit A, et al. Videotape recording of assaults on a state hospital inpatient ward. J Neuropsychiatry Clin Neurosci. 1991;3(2):S9-S14. Excluded; Age of study population greater than 17 years. [pmid: 1821225].
Crowner M L, Stepcic F, Peric G, et al. Typology of patient-patient assaults detected by videocameras. Am J Psychiatry. 1994;151(11):1669-72. Excluded; Age of study population greater than 17 years. [pmid: 7943459].
Ctr N G C R. Bomb and arson crimes among American gang members: A behavioral science profile. J Gang Res. 2001;9(1):1-38. Excluded; Not a research study.
Cubbin C, Pickle L W, Fingerhut L. Social context and geographic patterns of homicide among US black and white males. Am J Public Health. 2000;90(4):579-87. Excluded; Study does not focus on youth as perpetrators. [pmid: 10754973]. [pmcid: 1446205].
Cuddy M E, Frame C. Comparison of aggressive and nonaggressive boys' self-efficacy and outcome expectancy beliefs. Child Study J. 1991;21(2):135-52. Excluded; Outcome is not violence.
Cuffel B J, Shumway M, Chouljian T L, et al. A longitudinal study of substance use and community violence in schizophrenia. J Nerv Ment Dis. 1994;182(12):704-8. Excluded; Age of study population greater than 17 years. [pmid: 7989915].
Cummings A L, Leschied A W. Understanding aggression with adolescent girls: Implications for policy and practice. Can J Commun Ment Health. 2001;20(2):43-57. Excluded; Outcome is not violence. [pmid: 12051028].
Cummings P, Koepsell T D, Grossman D C, et al. The association between the purchase of a handgun and homicide or suicide. Am J Public Health. 1997;87(6):974-8. Excluded; Study does not focus on youth as perpetrators. [pmid: 9224179]. [pmcid: 1380933].
Cunningham C E, Cunningham L J, Martorelli V, et al. The effects of primary division, student-mediated conflict resolution programs on playground aggression. Journal of Child Psychology and Psychiatry, and Allied Disciplines. 1998;39(5):653-62. Excluded; Not a U.S. study. [pmid: 9690929].
Cunningham P B, Henggeler S W. Implementation of an empirically based drug and violence prevention and intervention program in public school settings. J Clin Child Psychol. 2001;30(2):221-32. Excluded; Not a research study. [pmid: 11393922].
Cunningham P B, Henggeler S W, Limber S P, et al. Patterns and correlates of gun ownership among nonmetropolitan and rural middle school students. J Clin Child Psychol. 2000;29(3):432-42. Excluded; Not addressing they key questions. [pmid: 10969427].
Curtner-Smith M E. Mechanisms by which family processes contribute to school-age boy's bullying. Child Study J. 2000;30(3):169-86. Excluded; Study does not focus on youth as perpetrators.
Dabbs J M, Jurkovic G J, Frady R L. Salivary testosterone and cortisol among late adolescent male offenders. J Abnorm Child Psychol. 1991;19(4):469-78. Excluded; Study design not used. [pmid: 1757712].
Daderman A M, Edman G. Flunitrazepam abuse and personality characteristics in male forensic psychiatric patients. Psychiatry Res. 2001;103(1):27-42. Excluded; Not a U.S. study. [pmid: 11472788].
Daldin H. Assaultive behavior in the analysis of children. Psychoanal Psychol. 1992;9(4):477-88. Excluded; Not a research study.
Daly M, Wilson M. Killing the competition: Female/female and male/male homicide. Hum Nat. 1990;1(1):81-107. Excluded; Not a U.S. study.
Daly M, Wilson M, Salmon C A, et al. Siblicide and seniority. Homicide Stud. 2001;5(1):30-45. Excluded; Not a U.S. study.
Daly R C, Su T-P, Schmidt P J, et al. Neuroendocrine and behavioral effects of high-dose anabolic steroid administration in male normal volunteers. Psychoneuroendocrinology. 2003;28(3):317-31. Excluded; Outcome is not violence. [pmid: 12573299].
Danov R, Bucci W. Attachment processes among violence-prone minority youths and their caretakers. NYS Psychol. 2002;14(1):28-32. Excluded; Outcome is not violence.
Darby P J, Allan W D, Kashani J H, et al. Analysis of 112 juveniles who committed homicide: Characteristics and a closer look at family abuse. J Fam Violence. 1998;13(4):365-75. Excluded; Not addressing they key questions.
David C, Steele R, Forehand R, et al. The role of family conflict and marital conflict in adolescent functioning. J Fam Violence. 1996;11(1):81-91. Excluded; Outcome is not violence.
Davidson P, Koziol-McLain J, Harrison L, et al. Intoxicated ED patients: a 5-year follow-up of morbidity and mortality. Ann Emerg Med. 1997;30(5):593-7. Excluded; Outcome is not violence. [pmid: 9360567].
Davidson P W, Cain N N, Sloane-Reeves J E, et al. Characteristics of community-based individuals with mental retardation and aggressive behavioral disorders. Am J Ment Retard. 1994;98(6):704-16. Excluded; Data not abstractable. [pmid: 8054199].
Davidson P W, Others A. Characteristics of children and adolescents with mental retardation and frequent outwardly directed aggressive behavior. Am J Ment Retard. 1996;101(3):244-55. Excluded; Data not abstractable. [pmid: 8933899].
Davis B T, Hops H, Alpert A, et al. Child responses to parental conflict and their effect on adjustment: A study of triadic relations. J Fam Psychol. 1998;12(2):163-77. Excluded; Outcome is not violence.
Davis D L, Boster L H. Cognitive-behavioral-expressive interventions with aggressive and resistant youths. Child Welfare. 1992;71(6):557-73. Excluded; Not a research study. [pmid: 1424948].
Davis D L, Boster L H. Cognitive-behavioral-expressive interventions with aggressive and resistant youth. Resid Treat Child Youth. 1993;10(4):55-68. Excluded; Not a research study.
Davis E, Beverly C. Youth violence: An action research project. J Multicult Soc Work. 1991;1(3):33-44. Excluded; Not addressing they key questions.
Davis T C, Byrd R S, Arnold C L, et al. Low literacy and violence among adolescents in a summer sports program. J Adolesc Health. 1999;24(6):403-11. Excluded; Study design not used. [pmid: 10401968].
Davis T C, Peck G Q, Storment J M. Acquaintance rape and the high school student. J Adolesc Health. 1993;14(3):220-4. Excluded; Data not abstractable. [pmid: 8323934].
Dawkins M P. Drug use and violent crime among adolescents. Adolescence. 1997;32(126):395-405. Excluded; Not addressing they key questions. [pmid: 9179335].
Dawson D A. Alternative measures and models of hazardous consumption. Journal of Substance Abuse. 2000;12(12):79-91. Excluded; Outcome is not violence. [pmid: 11288476].
Dawson J. Vortex of evil. New Statesman Soc. 1990;3:12-4. Excluded; Not a research study.
Day D M, Bream L A, Pal A. Proactive and reactive aggression: An analysis of subtypes based on teacher perceptions. J Clin Child Psychol. 1992;21(3):210-7. Excluded; Not a U.S. study.
Day H D, Franklin J M, Marshall D D. Predictors of aggression in hospitalized adolescents. J Psychol. 1998;132(4):427-34. Excluded; Not addressing they key questions. [pmid: 9637024].
Day K. Male mentally handicapped sex offenders. Br J Psychiatry. 1994;165(5):630-9. Excluded; Study does not focus on youth as perpetrators. [pmid: 7866678].
de Anda D. A qualitative evaluation of a mentor program for at-risk youth: The participants' perspective. Child Adolesc Social Work J. 2001;18(2):97-117. Excluded; Outcome is not violence.
Deffenbacher J L, Swaim R C. Anger expression in Mexican American and White non-Hispanic adolescents. J Couns Psychol. 1999;46(1):61-9. Excluded; Study design not used.
Deibert G R, Miethe T D. Character contests and dispute-related offenses. Deviant Behav. 2003;24(3):245-67. Excluded; Age of study population greater than 17 years.
Delva-Tauiliili J. Does brief Aikido training reduce aggression of youth?. Percept Mot Skills. 1995;80(1):297-8. Excluded; Study does not focus on youth as perpetrators. [pmid: 7624209].
Delveaux K D, Daniels T. Children's social cognitions: Physically and relationally aggressive strategies and children's goals in peer conflict situations. Merrill Palmer Q. 2000;46(4):672-92. Excluded; Outcome is not violence.
Dembo R. Predictors of recidivism to a juvenile assessment center: An expanded analysis. J Child Adolesc Subst Abus. 1996;5(1):27-53. Excluded; Outcome is not violence.
Dembo R, Hughes P, Jackson L, et al. Crack cocaine dealing by adolescents in two public housing projects: A pilot study. Hum Organ. 1993;52(1):89-96. Excluded; Outcome is not violence.
Dembo R, Schmeidler J, Nini-Gough B, et al. Predictors of recidivism to a juvenile assessment center: A three year study. J Child Adolesc Subst Abus. 1998;7(3):57-77. Excluded; Not addressing they key questions.
Dembo R, Turner G, Borden P, et al. Screening high risk youths for potential problems: Field application in the use of the Problem Oriented Screening Instrument for Teenagers (POSIT). J Child Adolesc Subst Abus. 1994;3(4):69-93. Excluded; Not addressing they key questions.
Dembo R, Turner G, Sue C C, et al. Predictors of recidivism to a juvenile assessment center. Int J Addict. 1995;30(11):1425-52. Excluded; Not addressing they key questions. [pmid: 8530214].
Dembo R, Williams L, La Voie L, et al. A longitudinal study of the relationships among alcohol use, marijuana/hashish use, cocaine use, and emotional/psychological functioning problems in a cohort of high-risk youths. Int J Addict. 1990;25(11):1341-82. Excluded; Outcome is not violence. [pmid: 2090630].
Dembo R, Williams L, Schmeidler J, et al. Recidivism in a cohort of juvenile detainees: a 3 1/2-year follow-up. Int J Addict. 1993;28(7):631-58. Excluded; Study does not focus on youth as perpetrators. [pmid: 8407028].
Dembo R, Williams L, Wothke W, et al. The relationship between cocaine use, drug sales, and other delinquency among a cohort of high-risk youths over time. NIDA Res Monogr. 1990;103:112-35. Excluded; Study design not used. [pmid: 2096284].
Dembo R, Wothke W, Shemwell M, et al. A structural model of the influence of family problems and child abuse factors on serious delinquency among youths processed at a juvenile assessment center. J Child Adolesc Subst Abus. 2000;10(1):17-31. Excluded; Outcome is not violence.
Dennis D, Massie J E, Wycoff-Horn M, et al. Weapon carrying among rural southern Illinois elementary school children. J Health Care Poor Underserved. 2002;13(4):413-24. Excluded; Outcome is not violence. [pmid: 12407960].
Denton JS, Filkins JA, Stephenson D, et al. Criminal consequences of commotio cordis. Am J Cardiol 2002;90(10):1181–2; Discussion 2. Excluded; Not a research study.
Dery M, Toupin J, Pauze R, et al. Neuropsychological characteristics of adolescents with conduct disorder: association with attention-deficit-hyperactivity and aggression. J Abnorm Child Psychol. 1999;27(3):225-36. Excluded; Not a U.S. study. [pmid: 10438188].
Deschenes E P, Esbensen F-A. Violence and gangs: Gender differences in perceptions and behavior. J Quant Criminol. 1999;15(1):63-96. Excluded; Study design not used.
DiClemente R J, Wingood G M, Crosby R, et al. Parental monitoring: association with adolescents' risk behaviors. Pediatrics. 2001;107(6):1363-8. Excluded; Study design not used. [pmid: 11694669].
Diego M A, Field T, Hernandez-Reif M, et al. Aggressive adolescents benefit from massage therapy. Adolescence. 2002;37(147):597-607. Excluded; Data not abstractable. [pmid: 12458696].
DiLiberto L, Katz R C, Beauchamp K L, et al. Using Articulated Thoughts in Simulated Situations to assess cognitive activity in aggressive and nonaggressive adolescents. J Child Fam Stud. 2002;11(2):179-89. Excluded; Outcome is not violence.
DiLillo D, Giuffre D, Tremblay G C, et al. A closer look at the nature of intimate partner violence reported by women with a history of child sexual abuse. J Interpers Violence. 2001;16(2):116-32. Excluded; Age of study population greater than 17 years.
Dimsdale J E. The Nacirema revisited. Ann Behav Med. 2001;23(1):75-6. Excluded; Not a research study. [pmid: 11761349].
DiNapoli P P. Adolescent violent behavior and ego development. J Adolesc Health. 2002;31(6):446-8. Excluded; Study design not used. [pmid: 12457576].
DiNapoli P P. Guns and dolls: an exploration of violent behavior in girls. ANS Adv Nurs Sci. 2003;26(2):140-8. Excluded; Data not abstractable. [pmid: 12795542].
Ding C S, Nelsen E A, Lassonde C T. Correlates of gun involvement and aggressiveness among adolescents. Youth Soc. 2002;34(2):195-213. Excluded; Outcome is not violence.
Dodge K A, Bates J E, Pettit G S. Mechanisms in the cycle of violence. Science. 1990;250(4988):1678-83. Excluded; Study does not focus on youth as perpetrators. [pmid: 2270481].
Dodge K A, Lansford J E, Burks V S, et al. Peer rejection and social information-processing factors in the development of aggressive behavior problems in children. Child Dev. 2003;74(2):374-93. Excluded; Outcome is not violence. [pmid: 12705561].
Dodge K A, Lochman J E, Harnish J D, et al. Reactive and proactive aggression in school children and psychiatrically impaired chronically assaultive youth. J Abnorm Psychol. 1997;106(1):37-51. Excluded; Study does not focus on youth as perpetrators. [pmid: 9103716].
Dodge K A, Price J M, Bachorowski J-A. Hostile attributional biases in severely aggressive adolescents. J Abnorm Psychol. 1990;99:385-92. Excluded; Duplicated citation or findings. [pmid: 2266213].
Dodge K A, Price J M, Bachorowski J A, et al. Hostile attributional biases in severely aggressive adolescents. J Abnorm Psychol. 1990;99(4):385-92. Excluded; Study design not used. [pmid: 2266213].
Dogra A, Veeraraghavan V. A study of psychological intervention of children with aggressive conduct disorder. Indian J Clin Psychol. 1994;21(1):28-32. Excluded; Not a U.S. study.
Dolin I H, Kelly D B, Beasley T M. Chronic self-destructive behavior in normative and delinquent adolescents. J Adolesc. 1992;15:57-66. Excluded; Outcome is not violence. [pmid: 1607425].
Dorn L D, Burgess E S, Dichek H L, et al. Thyroid hormone concentrations in depressed and nondepressed adolescents: Group differences and behavioral relations. J Am Acad Child Adolesc Psychiatry. 1996;35(3):299-306. Excluded; Outcome is not violence. [pmid: 8714317].
Dornbusch S M, Erickson K G, Laird J, et al. The relation of family and school attachment to adolescent deviance in diverse groups and communities. J Adolesc Res. 2001;16(4):396-422. Excluded; Study design not used.
Doswell W M. After Littleton. Am J Nurs. 1999;99(10):9. Excluded; Not a research study. [pmid: 10542833].
Doumas D, Margolin G, John R S. The intergenerational transmission of aggression across three generations. J Fam Violence. 1994;9(2):157-75. Excluded; Study does not focus on youth as perpetrators.
Dowd M D, Knapp J F, Fitzmaurice L S. Pediatric firearm injuries, Kansas City, 1992: a population-based study. Pediatrics. 1994;94(6 Pt 1):867-73. Excluded; Study does not focus on youth as perpetrators. [pmid: 7971003].
Dowdell E, Burgess, Santucci M E. The relationship between health risk behaviors and fear in one urban seventh grade class. J Pediatr Nurs. 2003;18(3):187-94. Excluded; Study design not used. [pmid: 12796861].
Downey G, Walker E. Distinguishing family-level and child-level influences on the development of depression and aggression in children at risk. Dev Psychopathol. 1992;4(1):81-95. Excluded; Age of study population greater than 17 years.
Drake M E, Hietter S A, Pakalnis A. EEG and evoked potentials in episodic-dyscontrol syndrome. Neuropsychobiology. 1992;26(3):125-8. Excluded; Data not abstractable. [pmid: 1294892].
Dukarm C P, Byrd R S, Auinger P, et al. Illicit substance use, gender, and the risk of violent behavior among adolescents. Arch Pediatr Adolesc Med. 1996;150(8):797-801. Excluded; Outcome is not violence. [pmid: 8704884].
Dukes R L, Martinez R O, Stein J A. Precursors and consequences of membership in youth gangs. Youth Soc. 1997;29(2):139-65. Excluded; Outcome is not violence.
Duncan R D. Peer and sibling aggression: An investigation of intra- and extra-familial bullying. J Interpers Violence. 1999;14(8):871-86. Excluded; Data not abstractable.
Duncan R D, Kennedy W A, Smith D W. Comparison of conduct-disordered behavior in crack-dealing versus nondealing juvenile offenders. Psychol Rep. 2000;86(3 Pt 2):1089-96. Excluded; Study design not used. [pmid: 10932561].
Duncan S C, Duncan T E, Strycker L A, et al. Relations between youth antisocial and prosocial activities. J Behav Med. 2002;25(5):425-38. Excluded; Data not abstractable. [pmid: 12442559].
Dunlap G, Robbins F R, Darrow M A. Parents' reports of their children's challenging behaviors: results of a statewide survey. Ment Retard. 1994;32(3):206-12. Excluded; Study does not focus on youth as perpetrators. [pmid: 8084272].
Durant R H, Altman D, Wolfson M, et al. Exposure to violence and victimization, depression, substance use, and the use of violence by young adolescents. J Pediatr. 2000;137(5):707-13. Excluded; Not addressing they key questions. [pmid: 11060539].
DuRant R H, Cadenhead C, Pendergrast R A, et al. Factors associated with the use of violence among urban black adolescents. Am J Public Health. 1994;84(4):612-7. Excluded; Study design not used. [pmid: 8154565]. [pmcid: 1614778].
Durant R H, Getts A G, Cadenhead C, et al. The association between weapon carrying and the use of violence among adolescents living in and around public housing. J Adolesc Health. 1995;17(6):376-80. Excluded; Study design not used. [pmid: 8924444].
DuRant R H, Getts A G, Cadenhead C, et al. The association between weapon-carrying and the use of violence among adolescents living in or around public housing. J Adolesc. 1995;18(5):579-92. Excluded; Outcome is not violence.
DuRant R H, Kahn J, Beckford P H, et al. The association of weapon carrying and fighting on school property and other health risk and problem behaviors among high school students. Arch Pediatr Adolesc Med. 1997;151(4):360-6. Excluded; Data not abstractable. [pmid: 9111434].
Durant R H, Knight J, Goodman E. Factors associated with aggressive and delinquent behaviors among patients attending an adolescent medicine clinic. J Adolesc Health. 1997;21(5):303-8. Excluded; Outcome is not violence. [pmid: 9358293].
DuRant R H, Krowchuk D P, Kreiter S, et al. Weapon carrying on school property among middle school students. Arch Pediatr Adolesc Med. 1999;153(1):21-6. Excluded; Outcome is not violence. [pmid: 10086407].
DuRant R H, Krowchuk D P, Sinal S H. Victimization, use of violence, and drug use at school among male adolescents who engage in same-sex sexual behavior. J Pediatr. 1998;133(1):113-8. Excluded; Study design not used. [pmid: 9672522].
Durant R H, Pendergrast R A, Cadenhead C. Exposure to violence and victimization and fighting behavior by urban black adolescents. J Adolesc Health. 1994;15(4):311-8. Excluded; Study design not used. [pmid: 7918504].
DuRant R H, Smith J A, Kreiter S R, et al. The relationship between early age of onset of initial substance use and engaging in multiple health risk behaviors among young adolescents. Arch Pediatr Adolesc Med. 1999;153(3):286-91. Excluded; Data not abstractable. [pmid: 10086407].
Dutton D G, Hart S D. Risk markers for family violence in a federally incarcerated population. Int J Law Psychiatry. 1992;15(1):101-12. Excluded; Not a U.S. study. [pmid: 1582739].
Dykeman B F. The social cognitive treatment of anger and aggression in four adolescents with conduct disorder. J Instr Psychol. 1995;22(2):194-200. Excluded; Outcome is not violence.
Dykeman C, Daehlin W, Doyle S, et al. Psychological predictors of school-based violence: Implications for school counselors. Sch Couns. 1996;44(1):35-47. Excluded; Data not abstractable.
Eargle A E, Guerra N G, Tolan P H. Preventing aggression in inner-city children: Small group training to change cognitions, social skills, and behavior. J Child Adolesc Group Ther. 1994;4(4):229-42. Excluded; Not a research study.
Earls F. Understanding and controlling violence. J Health Care Poor Underserved 1991;2(1):156–64; Discussion 65–6. Excluded; Not a research study.
Easley M. Domestic violence. Ann Emerg Med. 1996;27(6):762-3. Excluded; Not a research study. [pmid: 8644966].
Eckenrode J, Ganzel B, Henderson C R, et al. Preventing child abuse and neglect with a program of nurse home visitation: the limiting effects of domestic violence. JAMA. 2000;284(11):1385-91. Excluded; Outcome is not violence. [pmid: 10989400].
Eckstein M, Hutson HR. Street gangs: save yourself while saving a life. Emerg Med Serv 1994;23(7):18, 20, 2. Excluded; Not a research study.
Eddy J M, Reid J B, Fetrow R A. An elementary school-based prevention program targeting modifiable antecedents of youth delinquency and violence: Linking the Interests of Families and Teachers (LIFT). J Emot Behav Disord. 2000;8(3):165-76. Excluded; Study does not focus on youth as perpetrators.
Edens R M, Smryl T. Reducing disruptive classroom behaviors in physical education: A pilot study. J Real Ther. 1994;13(2):40-4. Excluded; Outcome is not violence.
Edwards W J. A measurement of delinquency differences between a delinquent and nondelinquent sample: what are the implications?. Adolescence. 1996;31(124):973-89. Excluded; Outcome is not violence. [pmid: 8970668].
Egan S K, Monson T C, Perry D G. Social-cognitive influences on change in aggression over time. Dev Psychol. 1998;34(5):996-1006. Excluded; Study does not focus on youth as perpetrators. [pmid: 9779745].
Egeland B, Susman-Stillman A. Dissociation as a mediator of child abuse across generations. Child Abuse Negl. 1996;20(11):1123-32. Excluded; Outcome is not violence. [pmid: 8958463].
Egeland B, Yates T, Appleyard K, et al. The long-term consequences of maltreatment in the early years: A developmental pathway model to antisocial behavior. Child Serv (Mahwah NJ). 2002;5(4):249-60. Excluded; Outcome is not violence.
Einfeld S, Hall W, Levy F. Hyperactivity and the fragile x syndrome. J Abnorm Child Psychol. 1991;19(3):253-62. Excluded; Outcome is not violence. [pmid: 1865044].
Eisenman R. Denigration of a victim in group psychotherapy by violent vs seductive sex offenders. Psychol Rep. 1993;72(2):413-4. Excluded; Outcome is not violence. [pmid: 8302997].
Eitle D, Turner R J. Exposure to community violence and young adult crime: The effects of witnessing violence, traumatic victimization, and other stressful life events. J Res Crime Delinq. 2002;39(2):214-37. Excluded; Study does not focus on youth as perpetrators.
Elander J, Simonoff E, Pickles A, et al. A longitudinal study of adolescent and adult conviction rates among children referred to psychiatric services for behavioural or emotional problems. Crim Behav Ment Health. 2000;10(1):40-59. Excluded; Not a U.S. study.
Elhassani S B. Domestic violence: a perinatal and pediatric risk factor. J S C Med Assoc. 1995;91(3):114-5. Excluded; Not a research study. [pmid: 7474951].
Ellickson P, Saner H, McGuigan K A. Profiles of violent youth: substance use and other concurrent problems. Am J Public Health. 1997;87(6):985-91. Excluded; Not addressing they key questions. [pmid: 9224181]. [pmcid: 1380935].
Ellickson P L, McGuigan K A. Early predictors of adolescent violence. Am J Public Health. 2000;90(4):566-72. Excluded; Study design not used. [pmid: 10754971]. [pmcid: 1446195].
Ellickson P L, Tucker J S, Klein D J. Ten-year prospective study of public health problems associated with early drinking. Pediatrics. 2003;111(5 Pt 1):949-55. Excluded; Duplicated citation or findings. [pmid: 12728070].
Ellis R A, Gormley M, Ellis G D, et al. Harm by her own hand: A study of internalized violence among female juveniles. J Hum Behav Soc Environ. 2003;6(3):75-90. Excluded; Outcome is not violence.
Ellis R A, Gormley M, Ellis G D, et al. Harm by her own hand: A study of internalized violence among female juveniles. J Hum Behav Soc Environ. 2003;6(3):75-90. Excluded; Duplicated citation or findings.
Elze D E, Stiffman A R, Dore P. The association between types of violence exposure and youths' mental health problems. Int J Adolesc Med Health. 1999;11(34):221-55. Excluded; Outcome is not violence.
Embry D D, Flannery D J, Vazsonyi A T, et al. Peacebuilders: a theoretically driven, school-based model for early violence prevention. Am J Prev Med. 1996;12(5 Suppl):91-100. Excluded; Study does not focus on youth as perpetrators. [pmid: 8909629].
Emde K. Cops & docs: a gun violence injury prevention program. Int J Trauma Nurs. 2002;8(2):54-6. Excluded; Not a research study. [pmid: 12000909].
Emerick R L, Dutton W A. The effect of polygraphy on the self report of adolescent sex offenders: Implications for risk assessment. Ann Sex Res. 1993;6(2):83-103. Excluded; Not addressing they key questions.
Emerson E, Shelton D. Using creative arts to build coping skills to reduce domestic violence in the lives of female juvenile offenders. Issues Ment Health Nurs. 2001;22(2):181-95. Excluded; Not a research study. [pmid: 11885222].
Epps K. The residential treatment of adolescent sex offenders. Issues Criminol Legal Psychol. 1991;1(17):58-67. Excluded; Not a research study.
Epps K J, Haworth R, Swaffer T. Attitudes toward women and rape among male adolescents convicted of sexual versus nonsexual crimes. J Psychol. 1993;127(5):501-6. Excluded; Not a U.S. study. [pmid: 8271228].
Epstein J A, Botvin G J, Diaz T, et al. Aggression, victimization and problem behavior among inner-city minority adolescents. J Child Adolesc Subst Abus. 2000;9(3):51-66. Excluded; Study design not used.
Epstein M H, Cullinan D, Quinn K P, et al. Characteristics of children with emotional and behavioral disorders in community-based programs designed to prevent placement in residential facilities. J Emot Behav Disord. 1994;2(1):51-7. Excluded; Outcome is not violence.
Erkut S, Szalacha L A, Alarcon O, et al. Stereotyped perceptions of adolescents' health risk behaviors. Cultur Divers Ethnic Minor Psychol. 1999;5(4):340-9. Excluded; Outcome is not violence.
Ernst M, Zametkin A J, Pascualvaca D, et al. Adrenergic and noradrenergic plasma levels in Lesch-Nyhan disease. Neuropsychopharmacology. 2000;22(3):320-6. Excluded; Outcome is not violence. [pmid: 10693160].
Eron L, Huesmann R, Spindler A, et al. A cognitive-ecological approach to preventing aggression in urban settings: Initial outcomes for high-risk children. J Consult Clin Psychol. 2002;70(1):179-94. Excluded; Study does not focus on youth as perpetrators. [pmid: 11860044].
Eron L D. Media violence. Pediatr Ann. 1995;24(2):84-7. Excluded; Not a research study. [pmid: 7724255].
Escarela G, Francis B, Soothill K. Competing risks, persistence and desistance in analyzing recidivism. J Quant Criminol. 2000;16(4):385-414. Excluded; Not a U.S. study.
Escobar-Chaves S L, Tortolero S R, Markham C, et al. Violent behavior among urban youth attending alternative schools. J Sch Health. 2002;72(9):357-62. Excluded; Study design not used. [pmid: 12557630].
Eslea M, Smith P K. The long-term effectiveness of anti-bullying work in primary schools. Educ Res. 1998;40(2):203-18. Excluded; Not a U.S. study.
Espelage D L, Bosworth K, Simon T R. Examining the social context of bullying behaviors in early adolescence. J Couns Dev. 2000;78(3):326-33. Excluded; Outcome is not violence.
Espelage D L, Bosworth K, Simon T R. Short-term stability and prospective correlates of bullying in middle-school students: an examination of potential demographic, psychosocial, and environmental influences. Violence Vict. 2001;16(4):411-26. Excluded; Data not abstractable. [pmid: 11506450].
Espelage D L, Holt M K, Henkel R R. Examination of peer-group contextual effects on aggression during early adolescence. Child Dev. 2003;74(1):205-20. Excluded; Study design not used. [pmid: 12625446].
Espelage D L, Holt M K, Henkel R R. Examination of peer-group contextual effects on aggression during early adolescence. Child Dev. 2003;74(1):205-20. Excluded; Duplicated citation or findings. [pmid: 12625446].
Etscheidt S. Reducing aggressive behavior and improving self-control: A cognitive-behavioral training program for behaviorally disordered adolescents. Behav Disord. 1991;16(2):107-15. Excluded; Data not abstractable.
Evans G D, Rey J, Hemphill M M, et al. Academic-community collaboration. An ecology for early childhood violence prevention. Am J Prev Med. 2001;20(1 Suppl):22-30. Excluded; Not a research study. [pmid: 11146257].
Evans J P, Taylor J. Understanding violence in contemporary and earlier gangs: An exploratory application of the theory of reasoned action. J Black Psychol. 1995;21(1):71-81. Excluded; Outcome is not violence.
Evans W, Mason A. Factors associated with gang involvement among incarcerated youth. J Gang Res. 1996;3(4):31-40. Excluded; Not addressing they key questions.
Evans W P, Fitzgerald C, Weigel D. Are rural gang members similar to their urban peers? Implications for rural communities. Youth Soc. 1999;30(3):267-82. Excluded; Duplicated citation or findings.
Evans W P, Fitzgerald C, Weigel D, et al. Are rural gang members similar to their urban peers? Implications for rural communities. Youth Soc. 1999;30(3):267-82. Excluded; Outcome is not violence.
Everett S A, Price J H. Students' perceptions of violence in the public schools: the MetLife survey. J Adolesc Health. 1995;17(6):345-52. Excluded; Outcome is not violence. [pmid: 8924440].
Ezell M E, Cohen L E. Age, crime, and crime control policies: A longitudinal analysis of youthful, serious, chronic offenders with implications for the “Three Strikes” legislation. Stud Crime Crime Prev. 1997;6(2):169-99. Excluded; Age of study population greater than 17 years.
Fackler M L. Firearm violence among youth. Ann Emerg Med. 1997;29(3):425-6. Excluded; Not a research study. [pmid: 9055787].
Fagan J. Policing guns and youth violence. Future Child. 2002;12(2):132-51. Excluded; Not a research study. [pmid: 12194607].
Fagan J, Chin K L. Violence as regulation and social control in the distribution of crack. NIDA Res Monogr. 1990;103:8-43. Excluded; Outcome is not violence. [pmid: 2096294].
Famularo R, Kinscherff R, Fenton T, et al. Child maltreatment histories among runaway and delinquent children. Clin Pediatr (Phila). 1990;29(12):713-8. Excluded; Study design not used. [pmid: 2276248].
Fanshel D, Finch S J, Grundy J F. Testing the measurement properties of risk assessment instruments in child protective services. Child Abuse Negl. 1994;18(12):1073-84. Excluded; Outcome is not violence. [pmid: 7850615].
Farber E W, Burge-Callaway K. Differences in anger, hostility, and interpersonal aggressiveness in Type A and Type B adolescents. J Clin Psychol. 1998;54(7):945-52. Excluded; Outcome is not violence. [pmid: 9811131].
Farmer J A. Juvenile exploitation of juvenile correctional workers: A content analysis. J Correct Educ. 1990;41(3):118-19. Excluded; Outcome is not violence.
Farrell A D, Bruce S E. Impact of exposure to community violence on violent behavior and emotional distress among urban adolescents. J Clin Child Psychol. 1997;26(1):2-14. Excluded; Study design not used. [pmid: 9118172].
Farrell A D, Kung E M, White K S, et al. The structure of self-reported aggression, drug use, and delinquent behaviors during early adolescence. J Clin Child Psychol. 2000;29(2):282-92. Excluded; Data not abstractable. [pmid: 10802836].
Farrell A D, Meyer A L. The effectiveness of a school-based curriculum for reducing violence among urban sixth-grade students. Am J Public Health. 1997;87(6):979-84. Excluded; Study does not focus on youth as perpetrators. [pmid: 9224180]. [pmcid: 1380934].
Farrell A D, Meyer A L, Dahlberg L L. Richmond youth against violence: a school-based program for urban adolescents. Am J Prev Med. 1996;12(5 Suppl):13-21. Excluded; Not a research study. [pmid: 8909620].
Farrell A D, Meyer A L, Sullivan T N, et al. Evaluation of the responding in peaceful and positive ways (RIPP) seventh grade violence prevention curriculum. J Child Fam Stud. 2003;12(1):101-20. Excluded; Duplicated citation or findings.
Farrell A D, Meyer A L, White K S. Evaluation of Responding in Peaceful and Positive Ways (RIPP): a school-based prevention program for reducing violence among urban adolescents. J Clin Child Psychol. 2001;30(4):451-63. Excluded; Study does not focus on youth as perpetrators. [pmid: 11708233].
Farrell M. Personality and anti-social behaviour among emotionally/behaviourally disturbed boys. Pers Individ Dif. 1992;13(5):511-7. Excluded; Not a U.S. study.
Fatum W R, Hoyle J C. Is it violence? School violence from the student perspective: Trends and interventions. Sch Couns. 1996;44(1):28-34. Excluded; Not a research study.
Faulkner A H, Cranston K. Correlates of same-sex sexual behavior in a random sample of Massachusetts high school students. Am J Public Health. 1998;88(2):262-6. Excluded; Outcome is not violence. [pmid: 9491018]. [pmcid: 1508176].
Fehon D C, Grilo C M, Lipschitz D S. Gender differences in violence exposure and violence risk among adolescent inpatients. J Nerv Ment Dis. 2001;189(8):532-40. Excluded; Study design not used. [pmid: 11531205].
Feigelman S, Howard D E, Li X, et al. Psychosocial and environmental correlates of violence perpetration among African-American urban youth. J Adolesc Health. 2000;27(3):202-9. Excluded; Data not abstractable. [pmid: 10960219].
Feigelman W, Hyman M M, Amann K, et al. Correlates of persisting drug use among former youth multiple drug abuse patients. J Psychoactive Drugs. 1990;22(1):63-75. Excluded; Outcome is not violence. [pmid: 2324865].
Feiring C, Deblinger E, Hoch-Espada A, et al. Romantic relationship aggression and attitudes in high school students: The role of gender, grade, and attachment and emotional styles. J Youth Adolesc. 2002;31(5):373-85. Excluded; Study design not used.
Feldman S S, Gowen L K. Conflict negotiation tactics in romantic relationships in high school students. J Youth Adolesc. 1998;27(6):691-717. Excluded; Data not abstractable.
Felkenes G T, Becker H K. Female gang members: A growing issue for policy makers. J Gang Res. 1995;2(4):1-10. Excluded; Age of study population greater than 17 years.
Felson R B. Pubertal development, social factors, and delinquency among adolescent boys. Criminology. 2002;40(4):967-88. Excluded; Study design not used.
Felson R B, Liska A E, South S J, et al. The subculture of violence and delinquency: Individual vs. school context effects. Soc Forces. 1994;73(1):155-73. Excluded; Study design not used.
Felson R B, Messner S F. The control motive in intimate partner violence. Soc Psychol Q. 2000;63(1):86-94. Excluded; Study does not focus on youth as perpetrators.
Fendrich M, Mackesy-Amiti M E, Goldstein P, et al. Substance involvement among juvenile murderers: comparisons with older offenders based on interviews with prison inmates. Int J Addict. 1995;30(11):1363-82. Excluded; Not addressing they key questions. [pmid: 8530211].
Ferman J. Integrated mental health and substance abuse services to at-risk families. The Family Health Program of the Center for Mental Health, Inc., Washington, D.C. Psychiatr Serv. 1996;47(10):1112-4. Excluded; Not a research study. [pmid: 8890341].
Fetsch R J, Schultz C J, Wahler J J. A preliminary evaluation of the Colorado RETHINK Parenting and Anger Management program. Child Abuse Negl. 1999;23(4):353-60. Excluded; Outcome is not violence. [pmid: 10321772].
Field T. American adolescents touch each other less and are more aggressive toward their peers as compared with French adolescents. Adolescence. 1999;34(136):753-8. Excluded; Outcome is not violence. [pmid: 10730699].
Fiester L, Nathanson S P, Visser L, et al. Lessons learned from three violence prevention projects. J Sch Health. 1996;66(9):344-6. Excluded; Not a research study. [pmid: 8959596].
Figueroa E F, Silk K R, Huth A, et al. History of childhood sexual abuse and general psychopathology. Compr Psychiatry. 1997;38(1):23-30. Excluded; Age of study population greater than 17 years. [pmid: 8980868].
Fine P R, Roseman J M, Constandinou C M, et al. Homicide among black males in Jefferson County, Alabama 1978-1989. J Forensic Sci. 1994;39(3):674-84. Excluded; Study does not focus on youth as perpetrators. [pmid: 8006616].
Finkelstein J W, Susman E J, Chinchilli V M, et al. Estrogen or testosterone increases self-reported aggressive behaviors in hypogonadal adolescents. J Clin Endocrinol Metab. 1997;82(8):2433-8. Excluded; Study design not used. [pmid: 9253313].
Finkelstein J W, Von Eye A, Preece M A. The relationship between aggressive behavior and puberty in normal adolescents: a longitudinal study. J Adolesc Health. 1994;15(4):319-26. Excluded; Not a U.S. study. [pmid: 7918505].
Finzi R, Ram A, Har-Even D, et al. Attachment styles and aggression in physically abused and neglected children. J Youth Adolesc. 2001;30(6):769-86. Excluded; Not a U.S. study.
Firestone P, Bradford J M, Greenberg D M, et al. Homicidal sex offenders: psychological, phallometric, and diagnostic features. J Am Acad Psychiatry Law. 1998;26(4):537-52. Excluded; Not a U.S. study. [pmid: 9894211].
Firestone P, Bradford J M, Greenberg D M, et al. Differentiation of homicidal child molesters, nonhomicidal child molesters, and nonoffenders by phallometry. Am J Psychiatry. 2000;157(11):1847-50. Excluded; Age of study population greater than 17 years. [pmid: 11058484].
Fishbein D H, Reuland M. Psychological correlates of frequency and type of drug use among jail inmates. Addictive Behaviors Addict Behav. 1994;19(6):583-98. Excluded; Outcome is not violence.
Fitzmaurice L S, Gaddis G M, Knapp J F. Firearms injuries in children: an increase in violent intent, frequency and severity. Mo Med. 1993;90(5):233-7. Excluded; Study does not focus on youth as perpetrators. [pmid: 8336687].
Fitzpatrick K M. Aggression and environmental risk among low-income African-American youth. J Adolesc Health. 1997;21(3):172-8. Excluded; Data not abstractable. [pmid: 9283938].
Fitzpatrick K M. Fighting among America's youth: a risk and protective factors approach. J Health Soc Behav. 1997;38(2):131-48. Excluded; Study design not used. [pmid: 9212535].
Flanagan P, Coll C G, Andreozzi L, et al. Predicting maltreatment of children of teenage mothers. Arch Pediatr Adolesc Med. 1995;149(4):451-5. Excluded; Study does not focus on youth as perpetrators. [pmid: 7704176].
Flannery D J, Singer M, Williams L, et al. Adolescent violence exposure and victimization at home: Coping and psychological trauma symptoms. Int Rev Vict. 1998;6(1):29-48. Excluded; Study design not used.
Flannery D J, Williams L L, Vazsonyi A T. Who are they with and what are they doing? Delinquent behavior, substance use, and early adolescents' after-school time. Am J Orthopsychiatry. 1999;69(2):247-53. Excluded; Outcome is not violence. [pmid: 10234390].
Flannery R B, Rachlin S, Walker A, et al. Characteristics of repetitively assaultive patients: ten year analysis of the Assaulted Staff Action Program (ASAP). Int J Emerg Ment Health. 2002;4(3):173-9. Excluded; Age of study population greater than 17 years. [pmid: 12387190].
Flannery R B, Rachlin S, Walker A P. Characteristics of assaultive patients with schizophrenia versus personality disorder: six year analysis of the Assaulted Staff Action Program (ASAP). J Forensic Sci. 2002;47(3):558-61. Excluded; Age of study population greater than 17 years. [pmid: 12051336].
Flannery R B, Stevens V, Juliano J, et al. Past violence and substance use disorder and subsequent violence towards others: six year analysis of the Assaulted Staff Action Program (ASAP). Int J Emerg Ment Health. 2000;2(4):241-7. Excluded; Age of study population greater than 17 years. [pmid: 11217155].
Flay B R, Allred C G, Ordway N. Effects of the Positive Action program on achievement and discipline: two matched-control comparisons. Prev Sci. 2001;2(2):71-89. Excluded; Study does not focus on youth as perpetrators. [pmid: 11523754].
Fleming C B, Catalano R F, Oxford M L, et al. A test of generalizability of the social development model across gender and income groups with longitudinal data from the elementary school developmental period. J Quant Criminol. 2002;18(4):423-39. Excluded; Not a research study.
Fleming J, Barner C I, Hudson B, et al. Anger, violence, and academic performance: A wtudy of troubled minority youth. Urban Educ. 2000;35(2):175-204. Excluded; Outcome is not violence.
Fling S, Smith L, Rodriguez T, et al. Videogames, aggression, and self-esteem: A survey. Soc Behav Pers. 1992;20(1):39-45. Excluded; Data not abstractable.
Flitcraft A. Clinical violence intervention: opportunities and barriers. Bull N Y Acad Med. 1996;73(1):124-9. Excluded; Not a research study. [pmid: 8804745].
Fontaine R G, Salzer Burks V, Dodge K A. Response decision processes and externalizing behavior problems in adolescents. Dev Psychopathol. 2002;14(1):107-22. Excluded; Data not abstractable. [pmid: 11893088].
Ford M E, Linney J A. Comparative analysis of juvenile sexual offenders, violent nonsexual offenders, and status offenders. J Interpers Violence. 1995;10(1):56-70. Excluded; Study design not used.
Forth AE. Psychopathy in adolescent offenders: Assessment, family background, and violence. Issues Criminol Legal Psychol 1995;No 24:42–4. Excluded; Not a research study.
Forth AE, Mailloux DL. Psychopathy in youth: what do we know? In: Gacono CB, editor. The clinical and forensic assessment of psychopathy: a practitioners guide. Mahwah, New Jersey: Lawrence Erlbaum; 2000. Excluded; Not a research study.
Foshee V A. Gender differences in adolescent dating abuse prevalence, types and injuries. Health Educ Res. 1996;11(3):275-86. Excluded; Study design not used.
Foshee V A, Bauman K E, Linder G F. Family violence and the perpetration of adolescent dating violence: examining social learning and social control processes. J Marriage Fam. 1999;61(2):331-42. Excluded; Study design not used.
Foshee V A, Linder G F, Bauman K E, et al. The Safe Dates Project: theoretical basis, evaluation design, and selected baseline findings. Am J Prev Med. 1996;12(5 Suppl):39-47. Excluded; Not a research study. [pmid: 8909623].
Franke T M. The role of attachment as a protective factor in adolescent violent behavior. Adolesc Fam Health. 2000;1(1):40-51. Excluded; Study design not used.
Franke T M. Adolescent violent behavior: an analysis across and within racial/ethnic groups. J Multicult Soc Work. 2000;8(1/2):47-70. Excluded; Study design not used.
Franklin R D, Allison D B, Sutton T R. Alcohol, substance abuse, and violence among North Carolina prison admissions, 1988. J Offender Rehabil. 1992;17(34):101-11. Excluded; Not addressing they key questions.
Fras I, Major L F. Clinical experience with risperidone. J Am Acad Child Adolesc Psychiatry. 1995;34(7):833. Excluded; Not a research study. [pmid: 7544342].
French D C, Jansen E A, Pidada S. United States and Indonesian children's and adolescents' reports of relational aggression by disliked peers. Child Dev. 2002;73(4):1143-50. Excluded; Outcome is not violence. [pmid: 12146739].
Frey K S, Hirschstein M K, Guzzo B A. Second Step: Preventing aggression by promoting social competence. J Emot Behav Disord. 2000;8(2):102-12. Excluded; Study does not focus on youth as perpetrators.
Friday J C. The psychological impact of violence in underserved communities. J Health Care Poor Underserved. 1995;6(4):403-9. Excluded; Not a research study. [pmid: 7495934].
Fried S. Bullies & victims: Children abusing children. Am J Dance Ther. 1997;19(2):127-33. Excluded; Not a research study.
Friedman A S, Kramer S, Kreisher C. Childhood predictors of violent behavior. J Clin Psychol. 1999;55(7):843-55. Excluded; Study does not focus on youth as perpetrators. [pmid: 10866020].
Friedman AS, Utada AT. Effects of two group interaction models on substance-using adjudicated adolescent males. J Community Psychol 1992:106–17. Excluded; Outcome is not violence.
Fritsch E J, Caeti T J, Taylor R W. Gang suppression through saturation patrol, aggressive curfew and truancy enforcement: A quasi-experimental test of the Dallas anti-gang initiative. Crime Delinq. 1999;45(1):122-39. Excluded; Data not abstractable.
Fritsch R C, Heinssen R K, Delga I, et al. Predicting hospital adjustment by adolescent inpatients. Hosp Community Psychiatry. 1992;43(1):49-53. Excluded; Outcome is not violence. [pmid: 1544647].
Fromuth M E, Burkhart B R, Jones C W. Hidden child molestation: An investigation of adolescent perpetrators in a nonclinical sample. J Interpers Violence. 1991;6(3):376-84. Excluded; Age of study population greater than 17 years.
Frydman M. Television, aggressiveness and violence. Int J Adolesc Med Health. 1999;11(34):335-44. Excluded; Not a research study.
Frye V, Wilt S. Femicide and social disorganization. Violence Against Women. 2001;7(3):335-51. Excluded; Study does not focus on youth as perpetrators.
Fulginiti V A. Violence and children in the United States. Am J Dis Child. 1992;146(6):671-2. Excluded; Not a research study. [pmid: 1595621].
Fulwiler C, Grossman H, Forbes C, et al. Early-onset substance abuse and community violence by outpatients with chronic mental illness. Psychiatr Serv. 1997;48(9):1181-5. Excluded; Age of study population greater than 17 years. [pmid: 9285980].
Fulwiler C, Ruthazer R. Premorbid risk factors for violence in adult mental illness. Compr Psychiatry. 1999;40(2):96-100. Excluded; Age of study population greater than 17 years. [pmid: 10080255].
Funk J B, Hagan J, Schimming J, et al. Aggression and psychopathology in adolescents with a preference for violent electronic games. Aggress Behav. 2002;28(2):134-44. Excluded; Data not abstractable.
Furlong M, Casas J M, Corral C, et al. Drugs and school violence. Educ Treat Child. 1997;20(3):263-80. Excluded; Data not abstractable.
Gabel S, Shindledecker R. Aggressive behavior in youth: characteristics, outcome, and psychiatric diagnoses. J Am Acad Child Adolesc Psychiatry. 1991;30(6):982-8. Excluded; Outcome is not violence. [pmid: 1757448].
Gabel S, Shindledecker R. Behavior problems in sons and daughters of substance abusing parents. Child Psychiatry Hum Dev. 1992;23(2):99-115. Excluded; Data not abstractable. [pmid: 1490400].
Gabel S, Shindledecker R. Adolescent psychiatric inpatients: Characteristics, outcome, and comparison between discharged patients from a specialized adolescent unit and nonspecialized units. J Youth Adolesc. 1992;21(4):391-407. Excluded; Outcome is not violence.
Gabel S, Shindledecker R. Parental substance abuse and its relationship to severe aggression and antisocial behavior in youth. Am J Addict. 1993;2(1):48-58. Excluded; Data not abstractable.
Gabel S, Swanson A J, Shindledecker R. Aggressive children in a day treatment program: Changed outcome and possible explanations. Child Abuse Negl. 1990;14(4):515-23. Excluded; Study does not focus on youth as perpetrators. [pmid: 2289182].
Gabriel R M, Hopson T, Haskins M, et al. Building relationships and resilience in the prevention of youth violence. Am J Prev Med. 1996;12(5 Suppl):48-55. Excluded; Not a research study. [pmid: 8909624].
Gadow K D, Nolan E E, Sverd J. Methylphenidate in hyperactive boys with comorbid tic disorder: II. Short-term behavioral effects in school settings. J Am Acad Child Adolesc Psychiatry. 1992;31(3):462-71. Excluded; Study does not focus on youth as perpetrators. [pmid: 1592778].
Gadow K D, Nolan E E, Sverd J, et al. Methylphenidate in aggressive-hyperactive boys: I. Effects on peer aggression in public school settings. J Am Acad Child Adolesc Psychiatry. 1990;29(5):710-8. Excluded; Study does not focus on youth as perpetrators. [pmid: 2228923].
Gaertner L, Foshee V. Commitment and the perpetration of relationship violence. Pers Relatsh. 1999;6(2):227-39. Excluded; Study design not used.
Gagne M-H, Lavoie F. Young people's views on the causes of violence in adolescents' romantic relationships. Can Ment Health. 1993;41(3):11-5. Excluded; Outcome is not violence.
Gainer P S, Webster D W, Champion H R. A youth violence prevention program. Description and preliminary evaluation. Arch Surg. 1993;128(3):303-8. Excluded; Outcome is not violence. [pmid: 8442687].
Gardner W, Lidz C W, Mulvey E P, et al. Clinical versus actuarial predictions of violence of patients with mental illnesses. J Consult Clin Psychol. 1996;64(3):602-9. Excluded; Study does not focus on youth as perpetrators. [pmid: 8698955].
Garnefski N, Okma S. Addiction-risk and aggressive/criminal behavior in adolescence: Influence of family, school and peers. J Adolesc. 1996;19(6):503-12. Excluded; Not a U.S. study. [pmid: 9245302].
Garrison J, Barry VJ. Family violence. J Am Dent Assoc 1994;125(4):360, 2. Excluded; Not a research study.
Garrison W T, Ecker B, Friedman M, et al. Aggression and counteraggression during child psychiatric hospitalization. J Am Acad Child Adolesc Psychiatry. 1990;29(2):242-50. Excluded; Data not abstractable. [pmid: 2324065].
Gartner R-. Family structure, welfare spending, and child homicide in developed democracies. J Marriage Fam. 1991;53:231-40. Excluded; Not a U.S. study.
Gartstein M A, Noll R B, Vannatta K. Childhood aggression and chronic illness: Possible protective mechanisms. J Appl Dev Psychol. 2000;21(3):315-33. Excluded; Outcome is not violence.
Garvey K, et al. Alliance working to stop youth violence. WMJ. 2002;101(6):22-3. Excluded; Not a research study. [pmid: 12355964].
Gelles R J. Poverty and violence toward children. Am Behav Sci. 1992;35(3):258-74. Excluded; Outcome is not violence.
Gentry J, Eron L D. American Psychological Association Commission on Violence and Youth. Am Psychol. 1993;48(2):89. Excluded; Not a research study. [pmid: 8442577].
Gerra G, Zaimovic A, Ampollini R, et al. Experimentally induced aggressive behavior in subjects with 3,4-methylenedioxy-methamphetamine (“Ecstasy”) use history: psychobiological correlates. Journal of Substance Abuse. 2001;13(4):471-91. Excluded; Not a U.S. study. [pmid: 11775077].
Gerstein L H, Briggs J R. Psychological and sociological discriminants of violent and nonviolent serious juvenile offenders. J Addict Offender Couns. 1993;14(1):2-13. Excluded; Study design not used.
Giancola P R, Martin C S, Tarter R E, et al. Executive cognitive functioning and aggressive behavior in preadolescent boys at high risk for substance abuse/dependence. J Stud Alcohol. 1996;57(4):352-9. Excluded; Data not abstractable. [pmid: 8776676].
Giancola P R, Mezzich A C. Executive cognitive functioning mediates the relation between language competence and antisocial behavior in conduct-disordered adolescent females. Aggress Behav. 2000;26(5):359-75. Excluded; Study design not used.
Giancola P R, Mezzich A C, Clark D B, et al. Cognitive distortions, aggressive behavior, and drug use in adolescent boys with and without a family history of a substance use disorder. Psychol Addict Behav. 1999;13(1):22-32. Excluded; Outcome is not violence.
Giancola P R, Mezzich A C, Tarter R E. Disruptive, delinquent and aggressive behavior in female adolescents with a psychoactive substance use disorder: relation to executive cognitive functioning. J Stud Alcohol. 1998;59(5):560-7. Excluded; Study design not used. [pmid: 9718109].
Giancola P R, Mezzich A C, Tarter R E. Executive cognitive functioning, temperament, and antisocial behavior in conduct-disordered adolescent females. J Abnorm Psychol. 1998;107(4):629-41. Excluded; Data not abstractable. [pmid: 9830250].
Giancola P R, Moss H B, Martin C S, et al. Executive cognitive functioning predicts reactive aggression in boys at high risk for substance abuse: A prospective study. Alcoholism: Clinical & Experimental Research. 1996;20(4):740-4. Excluded; Outcome is not violence.
Giancola P R, Parker A M. A six-year prospective study of pathways toward drug use in adolescent boys with and without a family history of a substance use disorder. J Stud Alcohol. 2001;62(2):166-78. Excluded; Data not abstractable. [pmid: 11327183].
Giancola P R, Shoal G D, Mezzich A C. Constructive thinking, executive functioning, antisocial behavior, and drug use involvement in adolescent females with a substance use disorder. Exp Clin Psychopharmacol. 2001;9(2):215-27. Excluded; Data not abstractable. [pmid: 11518098].
Gierowski J K. The influence of the type and level of aggression on homicidal behavior. Psychiatr Pol. 1996;30(3, Suppl):27-37. Excluded; Outcome is not violence.
Ginsberg C. Violence-related attitudes and behaviors of high school students--New York City, 1992. J Sch Health. 1993;63(10):438-40. Excluded; Study design not used. [pmid: 8133649].
Giordano P C, Cernkovich S A, Groat H T, et al. The quality of adolescent friendships: long-term effects?. J Health Soc Behav. 1998;39(1):55-71. Excluded; Age of study population greater than 17 years. [pmid: 9575704].
Giordano P C, Millhollin T J, Cernkovich S A. Delinquency, identity, and women's involvement in relationship violence. Criminology. 1999;37(1):17-40. Excluded; Study does not focus on youth as perpetrators.
Giuliano J D. A peer education program to promote the use of conflict resolution skills among at-risk school age males. Public Health Rep. 1994;109(2):158-61. Excluded; Not a research study. [pmid: 8153266]. [pmcid: 1403470].
Gjone H, Stevenson J. A longitudinal twin study of temperament and behavior problems: Common genetic or environmental influences?. J Am Acad Child Adolesc Psychiatry. 1997;36(10):1448-56. Excluded; Not a U.S. study. [pmid: 9334559].
Glod C A, Teicher M H, Butler M, et al. Modifying quiet room design enhances calming of children and adolescents. J Am Acad Child Adolesc Psychiatry. 1994;33(4):558-66. Excluded; Study does not focus on youth as perpetrators. [pmid: 8005909].
Goddard H W, Goff B G, Melancon M V, et al. Profiles of delinquency: A comparison of delinquent behavioral groups. J Soc Behav Pers. 2000;15(1):19-50. Excluded; Data not abstractable.
Goetting A. Child victims of homicide: a portrait of their killers and the circumstances of their deaths. Violence Vict. 1990;5(4):287-96. Excluded; Age of study population greater than 17 years. [pmid: 2098092].
Goetting A. Female victims of homicide: a portrait of their killers and the circumstances of their deaths. Violence Vict. 1991;6(2):159-68. Excluded; Age of study population greater than 17 years. [pmid: 1742242].
Goldstein A P, Glick B. Aggression replacement training: Curriculum and evaluation. Simul Gaming. 1994;25(1):9-26. Excluded; Data not abstractable.
Goodman G, Hull J W, Clarkin J F, et al. Childhood antisocial behaviors as predictors of psychotic symptoms and DSM-III-R borderline criteria among inpatients with borderline personality disorder. J Personal Disord. 1999;13(1):35-46. Excluded; Outcome is not violence. [pmid: 10228925].
Goodwin M P, Roscoe B. Sibling violence and agonistic interactions among middle adolescents. Adolescence. 1990;25(98):451-67. Excluded; Study design not used. [pmid: 2375271].
Goren S, Singh N N, Best A M. The aggression-coercion cycle: Use of seclusion and restraint in a child psychiatric hospital. J Child Fam Stud. 1993;2(1):61-73. Excluded; Outcome is not violence.
Gorman-Smith D, Tolan P. The role of exposure to community violence and developmental problems among inner-city youth. Dev Psychopathol. 1998;10(1):101-16. Excluded; Not addressing they key questions. [pmid: 9524810].
Gorman-Smith D, Tolan P H, Sheidow A J, et al. Partner violence and street violence among urban adolescents: Do the same family factors relate?. J Res Adolesc. 2001;11(3):273-95. Excluded; Data not abstractable.
Gorman-Smith D, Tolan P H, Zelli A, et al. The relation of family functioning to violence among inner-city minority youths. J Fam Psychol. 1996;10(2):115-29. Excluded; Study design not used.
Gover A R. The effects of child maltreatment on violent offending among institutionalized youth. Violence Vict. 2002;17(6):655-68. Excluded; Study design not used. [pmid: 12680681].
Graham S, Hudley C, Williams E. Attributional and emotional determinants of aggression among African-American and Latino young adolescents. Dev Psychol. 1992;28(4):731-40. Excluded; Outcome is not violence.
Graham-Bermann S A, Cutler S E, Litzenberger B W, et al. Perceived conflict and violence in childhood sibling relationships and later emotional adjustment. J Fam Psychol. 1994;8(1):85-97. Excluded; Age of study population greater than 17 years.
Grange J T, Corbett S W. Violence against emergency medical services personnel. Prehosp Emerg Care. 2002;6(2):186-90. Excluded; Age of study population greater than 17 years. [pmid: 11962565].
Granger D A, Weisz J R, McCracken J T, et al. Testosterone and conduct problems. J Am Acad Child Adolesc Psychiatry. 1994;33(6):908. Excluded; Not a research study. [pmid: 8083150].
Granic I, Butler S. The relation between anger and antisocial beliefs in young offenders. Pers Individ Dif. 1998;24(6):759-65. Excluded; Outcome is not violence.
Granic I, Dishion T J. Deviant talk in adolescent friendships: A step toward measuring a pathogenic attractor process. Soc Dev. 2003;12(3):314-34. Excluded; Outcome is not violence.
Grann M. The PCL-R and gender. Eur J Psychol Assess. 2000;16(3):147-9. Excluded; Not a U.S. study.
Gray C, Chisholm D, Smith P, et al. The role of the child psychiatric ward in health care: Experiences with different types of admissions over a period of twenty-one years. Ir J Psychol Med. 1992;9(1):17-23. Excluded; Outcome is not violence.
Gray H M, Foshee V. Adolescent dating violence: Differences between one-sided and mutually violent profiles. J Interpers Violence. 1997;12(1):126-41. Excluded; Not addressing they key questions.
Greco C M, Cornell D G. Rorschach object relations of adolescents who committed homicide. J Pers Assess. 1992;59(3):574-83. Excluded; Study design not used. [pmid: 1487810].
Greenberg D M, Bradford J M, Curry S. A comparison of sexual victimization in the childhoods of pedophiles and hebephiles. J Forensic Sci. 1993;38(2):432-6. Excluded; Not a U.S. study. [pmid: 8455000].
Greene LW, Smith MS, Peters SR. “I have a future” comprehensive adolescent health promotion: cultural considerations in program implementation and design. J Health Care Poor Underserved 1995;6(2):267–81; Discussion 82–3. Excluded; Data not abstractable.
Gretton H M, McBride M, Hare R D, et al. Psychopathy and recidivism in adolescent sex offenders. Crim Justice Behav. 2001;28(4):427-49. Excluded; Not a U.S. study.
Grietens H, Rink J, Hellinckx W. Nonbehavioral correlates of juvenile delinquency: Communications of detained and nondetained young people about social limits. J Adolesc Res. 2003;18(1):68-89. Excluded; Not a U.S. study.
Griffin K W, Botvin G J, Scheier L M, et al. Parenting practices as predictors of substance use, delinquency, and aggression among urban minority youth: Moderating effects of family structure and gender. Psychol Addict Behav. 2000;14(2):174-84. Excluded; Study design not used. [pmid: 10860116].
Griffin K W, Scheier L M, Botvin G J, et al. Interpersonal aggression in urban minority youth: Mediators of perceived neighborhood, peer, and parental influences. J Community Psychol. 1999;27(3):281-98. Excluded; Study design not used.
Grimm K T. Violence against infants. Mt Sinai J Med. 1996;63(2):101-2. Excluded; Not a research study. [pmid: 8775139].
Grisso J A, Schwarz D F, Hirschinger N, et al. Violent injuries among women in an urban area. N Engl J Med. 1999;341(25):1899-905. Excluded; Study does not focus on youth as perpetrators. [pmid: 10601510].
Grizenko N, Pawliuk N. Risk and protective factors for disruptive behavior disorders in children. Am J Orthopsychiatry. 1994;64(4):534-44. Excluded; Not a U.S. study. [pmid: 7847569].
Groebel J. Media violence and children. Educ Media Int. 1998;35(3):216-27. Excluded; Not a U.S. study.
Grossman L S, Haywood T W, Cavanaugh J L, et al. State psychiatric hospital patients with past arrests for violent crimes. Psychiatr Serv. 1995;46(8):790-5. Excluded; Age of study population greater than 17 years. [pmid: 7583479].
Gruber E, DiClemente R J, Anderson M M, et al. Early drinking onset and its association with alcohol use and problem behavior in late adolescence. Prev Med. 1996;25(3):293-300. Excluded; Study design not used. [pmid: 8781007].
Grunbaum J A, Basen-Engquist K. Comparison of health risk behaviors between students in a regular high school and students in an alternative high school. J Sch Health. 1993;63(10):421-5. Excluded; Study does not focus on youth as perpetrators. [pmid: 8133645].
Grunbaum J A, Basen-Engquist K, Pandey D. Association between violent behaviors and substance use among Mexican-American and non-Hispanic white high school students. J Adolesc Health. 1998;23(3):153-9. Excluded; Study design not used. [pmid: 9730358].
Grunbaum J A, Kann L, Kinchen S A, et al. Youth risk behavior surveillance--United States, 2001. J Sch Health. 2002;72(8):313-28. Excluded; Study design not used. [pmid: 12389372].
Grunbaum J A, Lowry R, Kann L. Prevalence of health-related behaviors among alternative high school students as compared with students attending regular high schools. J Adolesc Health. 2001;29(5):337-43. Excluded; Study design not used. [pmid: 11691595].
Guagliardo M F, Huang Z, D'Angelo L J. Fathering pregnancies: marking health-risk behaviors in urban adolescents. J Adolesc Health. 1999;24(1):10-5. Excluded; Outcome is not violence. [pmid: 9890359].
Guarnaccia V, Curry K. Contingent reinforcement effects on movement responses of prison inmates to the Holtzman Inkblot Technique. J Pers Assess. 1990;55(12):263-9. Excluded; Age of study population greater than 17 years. [pmid: 2231246].
Guerra N G. Violence prevention. Prev Med. 1994;23(5):661-4. Excluded; Not a research study. [pmid: 7845935].
Guerra N G, Huesmann L R, Tolan P H, et al. Stressful events and individual beliefs as correlates of economic disadvantage and aggression among urban children. J Consult Clin Psychol. 1995;63(4):518-28. Excluded; Study does not focus on youth as perpetrators. [pmid: 7673529].
Guerra N G, Huesmann L R, Zelli A. Attributions for social failure and aggression in incarcerated delinquent youth. J Abnorm Child Psychol. 1990;18(4):347-55. Excluded; Not addressing they key questions. [pmid: 2246428].
Guerra N G, Huesmann L R, Zelli A. Attributions for social failure and adolescent aggression. Aggress Behav. 1993;19(6):421-34. Excluded; Not addressing they key questions.
Guilleminault C, Moscovitch A, Leger D. Forensic sleep medicine: nocturnal wandering and violence. Sleep. 1995;18(9):740-8. Excluded; Age of study population greater than 17 years. [pmid: 8638066].
Gundersen L. Intimate-partner violence: the need for primary prevention in the community. Ann Intern Med. 2002;136(8):637-40. Excluded; Not a research study. [pmid: 11955043].
Gupta V B, Nwosa N M, Nadel T A, et al. Externalizing behaviors and television viewing in children of low-income minority parents. Clin Pediatr (Phila). 2001;40(6):337-41. Excluded; Data not abstractable. [pmid: 11824177].
Guterman N B, Cameron M, Hahm H C. Community violence exposure and associated behavior problems among children and adolescents in residential treatment. J Aggress Maltreat Trauma. 2003;6(2):111-35. Excluded; Data not abstractable.
Haapasalo J, Hamalainen T. Childhood family problems and current psychiatric problems among young violent and property offenders. J Am Acad Child Adolesc Psychiatry. 1996;35(10):1394-401. Excluded; Data not abstractable. [pmid: 8885594].
Haapasalo J, Kankkonen M. Self-reported childhood abuse among sex and violent offenders. Arch Sex Behav. 1997;26(4):421-31. Excluded; Age of study population greater than 17 years. [pmid: 9251838].
Haapasalo J, Tremblay R E. Physically aggressive boys from ages 6 to 12: Family background, parenting behavior, and prediction of delinquency. J Consult Clin Psychol. 1994;62(5):1044-52. Excluded; Not a U.S. study. [pmid: 7806713].
Haemaelaeinen M, Pulkkinen L. Aggressive and non-prosocial behaviour as precursors of criminality. Stud Crime Crime Prev. 1995;4(1):6-21. Excluded; Not a U.S. study.
Haemaelaeinen M, Pulkkinen L. Problem behavior as a precursor of male criminality. Dev Psychopathol. 1996;8(2):443-55. Excluded; Not a U.S. study.
Hagan M P. An analysis of adolescent perpetrators of homicide and attempted homicide upon return to the community. Int J Offender Ther Comp Criminol. 1997;41:250-9. Excluded; Age of study population greater than 17 years.
Hagan M P, Cho M E. A comparison of treatment outcomes between adolescent rapists and child sexual offenders. Int J Offender Ther Comp Criminol. 1996;40(2):113-22. Excluded; Outcome is not violence.
Hagan M P, Cho M E, Jensen J A, et al. An assessment of the effectiveness of an intensive treatment program for severely mentally disturbed juvenile offenders. Int J Offender Ther Comp Criminol. 1997;41(4):340-50. Excluded; Outcome is not violence.
Hagan M P, Gust-Brey K L. A ten-year longitudinal study of adolescent rapists upon return to the community. Int J Offender Ther Comp Criminol. 1999;43(4):448-58. Excluded; Age of study population greater than 17 years.
Hagan M P, Gust-Brey K L. A ten-year longitudinal study of adolescent perpetrators of sexual assault against children. J Offender Rehabil. 2000;31(12):117-26. Excluded; Not addressing they key questions.
Hagan M P, Gust-Brey K L, Cho M E. Eight-year comparative analyses of adolescent rapists, adolescent child molesters, other adolescent delinquents, and the general population. Int J Offender Ther Comp Criminol. 2001;45(3):314-24. Excluded; Duplicated citation or findings.
Hagan M P, Gust-Brey K L, Cho M E, et al. Eight-year comparative analyses of adolescent rapists, adolescent child molesters, other adolescent delinquents, and the general population. Int J Offender Ther Comp Criminol. 2001;45(3):314-24. Excluded; Not addressing they key questions.
Hagan M P, King R P, Patros R L. Recidivism among adolescent perpetrators of sexual assault against children. J Offender Rehabil. 1994;21(12):127-37. Excluded; Not addressing they key questions.
Hagan M P, King S L. Dx = extremely dangerous: Prognostic validity for future violence. J Offender Rehabil. 1998;27(12):23-35. Excluded; Not addressing they key questions.
Hailer J A, Hart C B. A new breed of warrior: The emergence of American Indian youth gangs. J Gang Res. 1999;7(1):23-33. Excluded; Not a research study.
Hallberg J. Boys and their toys. Minn Med. 2000;83(9):14-7. Excluded; Not a research study. [pmid: 11059250].
Halliday-Boykins C A, Graham S. At both ends of the gun: testing the relationship between community violence exposure and youth violent behavior. J Abnorm Child Psychol. 2001;29(5):383-402. Excluded; Not addressing they key questions. [pmid: 11695541].
Halperin J M, McKay K E, Newcorn J H. Development, reliability, and validity of the children's aggression scale-parent version. J Am Acad Child Adolesc Psychiatry. 2002;41(3):245-52. Excluded; Not a research study. [pmid: 11886018].
Halperin J M, Newcorn J H, Matier K, et al. Impulsivity and the initiation of fights in children with disruptive behavior disorders. J Child Psychol Psychiatry. 1995;36(7):1199-211. Excluded; Study design not used. [pmid: 8847380].
Halpern R. The role of after-school programs in the lives of inner-city children: a study of the “urban youth network”. Child Welfare. 1992;71(3):215-30. Excluded; Outcome is not violence. [pmid: 1606847].
Hammett M, Powell K E, O'Carroll P W, et al. Homicide surveillance--United States, 1979-1988. MMWR CDC Surveill Summ. 1992;41(3):1-33. Excluded; Not a research study. [pmid: 1635547].
Hammig B J, Dahlberg L L, Swahn M H. Predictors of injury from fighting among adolescent males. Inj Prev. 2001;7(4):312-5. Excluded; Outcome is not violence. [pmid: 11770658].
Hammock G, O'Hearn R. Psychological aggression in dating relationships: predictive models for males and females. Violence Vict. 2002;17(5):525-40. Excluded; Age of study population greater than 17 years. [pmid: 12477096].
Hanna G L, Yuwiler A, Coates J K. Whole blood serotonin and disruptive behaviors in juvenile obsessive-compulsive disorder. J Am Acad Child Adolesc Psychiatry. 1995;34(1):28-35. Excluded; Outcome is not violence. [pmid: 7860453].
Hannon L. AFDC and homicide. J Sociol Soc Welf. 1997;24(4):125-36. Excluded; Not a research study.
Hannon L, DeFronzo J, Prochnow J. Moral commitment and the effects of social influences on violent delinquency. Violence Vict. 2001;16(4):427-39. Excluded; Study design not used. [pmid: 11506451].
Hanson R F. Adolescent dating violence: prevalence and psychological outcomes. Child Abuse Negl. 2002;26(5):449-53. Excluded; Not a research study. [pmid: 12079083].
Hanson R K, Bussiere M T. Predicting relapse: a meta-analysis of sexual offender recidivism studies. J Consult Clin Psychol. 1998;66(2):348-62. Excluded; Not a research study. [pmid: 9583338].
Harden P W, Pihl R O, Vitaro F, et al. Stress response in anxious and nonanxious disruptive boys. J Emot Behav Disord. 1995;3(3):183-90. Excluded; Not a U.S. study.
Hardy M S. Physical aggression and sexual behavior among siblings: A retrospective study. J Fam Violence. 2001;16(3):255-68. Excluded; Age of study population greater than 17 years.
Harmon-Jones E, Barratt E S, Wigg C. Impulsiveness, aggression, reading, and the P300 of the event-related potential. Pers Individ Dif. 1997;22(4):439-45. Excluded; Data not abstractable.
Harper G W, Robinson W L. Pathways to risk among inner-city African-American adolescent females: the influence of gang membership. Am J Community Psychol. 1999;27(3):383-404. Excluded; Study design not used. [pmid: 10492881].
Harris P. The nature and extent of aggressive behaviour amongst people with learning difficulites (mental handicap) in a single health district. J Intellect Disabil Res. 1993;37(3):221-4. Excluded; Not a U.S. study. [pmid: 8334316].
Harrison L D, Erickson P G, Adlaf E, et al. The drugs-violence nexus among American and Canadian youth. Subst Use Misuse. 2001;36(14):2065-86. Excluded; Study design not used. [pmid: 11794584].
Harrison P A, Luxenberg M G. Comparisons of alcohol and other drug problems among Minnesota adolescents in 1989 and 1992. Arch Pediatr Adolesc Med. 1995;149(2):137-44. Excluded; Study design not used. [pmid: 7849874].
Harry B, Pierson T R, Kuznetsov A. Correlates of sex offender and offense traits by victim age. J Forensic Sci. 1993;38(5):1068-74. Excluded; Age of study population greater than 17 years. [pmid: 8228878].
Harty-Golder B. Domestic violence. J Fla Med Assoc. 1994;81(10):697-8. Excluded; Not a research study. [pmid: 7861112].
Hartz D T. Comparative conflict resolution patterns among parent-teen dyads of four ethnic groups in Hawaii. Child Abuse Negl. 1995;19(6):681-9. Excluded; Data not abstractable. [pmid: 7552837].
Hastings T L, Kelley M L. Development and validation of the Screen for Adolescent Violence Exposure (SAVE). J Abnorm Child Psychol. 1997;25(6):511-20. Excluded; Outcome is not violence. [pmid: 9468111].
Hausman A, Pierce G, Briggs L. Evaluation of comprehensive violence prevention education: effects on student behavior. J Adolesc Health. 1996;19(2):104-10. Excluded; Data not abstractable. [pmid: 8863081].
Hausman A J, Spivak H, Prothrow-Stith D. Adolescents' knowledge and attitudes about and experience with violence. J Adolesc Health. 1994;15(5):400-6. Excluded; Study design not used. [pmid: 7947855].
Hawke J M, Jainchill N, De Leon G. Posttreatment victimization and violence among adolescents following residential drug treatment. Child Maltreat. 2003;8(1):58-71. Excluded; Data not abstractable. [pmid: 12568505].
Hawke J M, Jainchill N, De Leon G. Posttreatment victimization and violence among adolescents following residential drug treatment. Child Maltreat. 2003;8(1):58-71. Excluded; Duplicated citation or findings. [pmid: 12568505].
Hawkins S R, Campanaro A, Pitts T B, et al. Weapons in an affluent suburban school. J Sch Violence. 2002;1(1):53-65. Excluded; Outcome is not violence.
Haynes N M. Creating safe and caring school communities: Comer School Development Program schools. J Negro Educ. 1996;65(3):308-14. Excluded; Not a research study.
Haynie D L, Alexander C, Walters S R. Considering a decision-making approach to youth violence prevention programs. J Sch Health. 1997;67(5):165-70. Excluded; Outcome is not violence. [pmid: 9210100].
Haynie D L, Nansel T, Eitel P, et al. Bullies, victims, and bully/victims: Distinct groups of at-risk youth. J Early Adolesc. 2001;21(1):29-49. Excluded; Outcome is not violence.
Heads T C, Taylor P J, Leese M. Childhood experiences of patients with schizophrenia and a history of violence: A special hospital sample. Crim Behav Ment Health. 1997;7(2):117-30. Excluded; Not a U.S. study.
Heath E, Kosky R. Are children who steal different from those who are aggressive?. Child Psychiatry Hum Dev. 1992;23(1):9-18. Excluded; Not a U.S. study. [pmid: 1424943].
Heath L, Kruttschnitt C, Ward D. Television and violent criminal behavior: beyond the Bobo doll. Violence Vict. 1986;1(3):177-90. Excluded; Age of study population greater than 17 years. [pmid: 3154148].
Heaven P C L. Personality and self-reported delinquency: Analysis of the “Big Five” personality dimensions. Pers Individ Dif. 1996;20(1):47-54. Excluded; Not a U.S. study.
Heck C, Walsh A. The effects of maltreatment and family structure on minor and serious delinquency. Int J Offender Ther Comp Criminol. 2000;44(2):178-93. Excluded; Not addressing they key questions.
Heide K M. Weapons used by juveniles and adults to kill parents. Behav Sci Law. 1993;11(4):397-405. Excluded; Outcome is not violence.
Heide K M. Parents who get killed and the children who kill them. J Interpers Violence. 1993;8(4):531-44. Excluded; Age of study population greater than 17 years.
Heide K M, Spencer E, Thompson A, et al. Who's in, who's out, and who's back: follow-up data on 59 juveniles incarcerated in adult prison for murder or attempted murder in the early 1980s. Behav Sci Law. 2001;19(1):97-108. Excluded; Outcome is not violence. [pmid: 11241683].
Heimer K. Socioeconomic status, subcultural definitions, and violent delinquency. Soc Forces. 1997;75(3):799-833. Excluded; Data not abstractable.
Hemenway D. Lethal violence in the schools. J Health Polit Policy Law. 2002;27(2):267-71. Excluded; Not a research study. [pmid: 12043899].
Hemmings A. Youth culture of hostility: Discourses of money, respect, and difference. Int J Qual Stud Educ. 2002;15(3):291-307. Excluded; Not a research study.
Hendricks-Matthews M K. A survey on violence education: a report of the STFM Violence Education Task Force. Fam Med. 1991;23(3):194-7. Excluded; Outcome is not violence. [pmid: 2016010].
Hendrix K, Molloy P J. Forum on youth violence in minority communities. Interventions in early childhood. Public Health Rep. 1991;106(3):275-6. Excluded; Not a research study. [pmid: 1905047].
Henggeler S W, Melton G B, Brondino M J, et al. Multisystemic therapy with violent and chronic juvenile offenders and their families: The role of treatment fidelity in successful dissemination. J Consult Clin Psychol. 1997;65(5):821-33. Excluded; Data not abstractable. [pmid: 9337501].
Henggeler S W, Melton G B, Smith L A, et al. Assessing violent offending in serious juvenile offenders. J Abnorm Child Psychol. 1993;21(3):233-43. Excluded; Outcome is not violence. [pmid: 8335762].
Henry B, Others A. Temperamental and familial predictors of violent and nonviolent criminal convictions: Age 3 to age 18. Dev Psychol. 1996;32(4):614-23. Excluded; Not a U.S. study.
Henry D B, Tolan P H, Gorman-Smith D. Longitudinal family and peer group effects on violence and nonviolent delinquency. J Clin Child Psychol. 2001;30(2):172-86. Excluded; Included violent and non-violent behaviors. [pmid: 11393918].
Herkov M J, Gynther M D, Thomas S, et al. MMPI differences among adolescent inpatients, rapists, sodomists, and sexual abusers. J Pers Assess. 1996;66(1):81-90. Excluded; Not addressing they key questions. [pmid: 8576837].
Hernandez J T, Lodico M, DiClemente R J. The effects of child abuse and race on risk-taking in male adolescents. J Natl Med Assoc. 1993;85(8):593-7. Excluded; Study design not used. [pmid: 8371280].
Herrenkohl R C, Egolf B P, Herrenkohl E C. Preschool antecedents of adolescent assaultive behavior: a longitudinal study. Am J Orthopsychiatry. 1997;67:422-32. Excluded; Duplicated citation or findings. [pmid: 9250343].
Herrenkohl T I, Huang B, Kosterman R, et al. A comparison of social development processes leading to violent behavior in late adolescence for childhood initiators and adolescent initiators of violence. J Res Crime Delinq. 2001;38(1):45-63. Excluded; Not addressing they key questions.
Herrenkohl T I, Huang B, Tajima E A, et al. Examining the link between child abuse and youth violence: An analysis of mediating mechanisms. J Interpers Violence. 2003;18(10):1189-208. Excluded; Data not abstractable. [pmid: 19771716].
Herrera V M, McCloskey L A. Gender differences in the risk for delinquency among youth exposed to family violence. Child Abuse Negl. 2001;25(8):1037-51. Excluded; Included violent and non-violent behaviors. [pmid: 11601596].
Herrmann D S, McWhirter J J. Anger & aggression management in young adolescents: An experimental validation of the SCARE program. Educ Treat Child. 2003;26(3):273-302. Excluded; Data not abstractable.
Hess P. The gang's all here. Emerg Med Serv 1994;23(7):44–5, 7–54, 6. Excluded; Not a research study.
Hickey D C. Public health and violence. J Tenn Med Assoc. 1994;87(5):197-8. Excluded; Not a research study. [pmid: 8041162].
Hicks M M, Rogers R, Cashel M. Predictions of violent and total infractions among institutionalized male juvenile offenders. J Am Acad Psychiatry Law. 2000;28(2):183-90. Excluded; Data not abstractable. [pmid: 10888186].
Hill S C, Drolet J C. School-related violence among high school students in the United States, 1993-1995. J Sch Health. 1999;69(7):264-72. Excluded; Study design not used. [pmid: 10529964].
Hillbrand M, Spitz R T, Foster H G, et al. Creatine kinase elevations and aggressive behavior in hospitalized forensic patients. Psychiatr Q. 1998;69(1):69-82. Excluded; Age of study population greater than 17 years. [pmid: 9536476].
Hilton N Z, Harris G T, Rice M E. The functions of aggression by male teenagers. J Pers Soc Psychol. 2000;79(6):988-94. Excluded; Not a U.S. study. [pmid: 11138767].
Hinshaw S P, Melnick S M. Peer relationships in boys with attention-deficit hyperactivity disorder with and without comorbid aggression. Dev Psychopathol. 1995;7(4):627-47. Excluded; Outcome is not violence.
Hinton P M. Domestic violence. J Fla Med Assoc. 1996;83(3):211-2. Excluded; Not a research study. [pmid: 8920057].
Hirose S, Ashby J, Charles R, Mills M J. Effectiveness of ECT combined with risperidone against aggression in schizophrenia. J ECT. 2001;17(1):22-6. Excluded; Age of study population greater than 17 years. [pmid: 11281510].
Hixon AL. Preventing street gang violence. Am Fam Physician 1999;59(8):2121–2, 5, 32. Excluded; Not a research study.
Hobbie C. Violence prevention. J Pediatr Health Care. 1995;9(5):234-6. Excluded; Not a research study. [pmid: 7562316].
Hodge S, Canter D. Victims and perpetrators of male sexual assault. J Interpers Violence. 1998;13(2):222-39. Excluded; Not a U.S. study.
Hodges K. Domestic violence--a health crisis. N C Med J. 1993;54(5):213-6. Excluded; Not a research study. [pmid: 8510776].
Hodgins S, Lapalme M, Toupin J. Criminal activities and substance use of patients with major affective disorders and schizophrenia: a 2-year follow-up. J Affect Disord. 1999;55(23):187-202. Excluded; Not a U.S. study. [pmid: 10628888].
Hoekelman R A. Causes of death among the young. Pediatr Ann. 1992;21(7):407-8. Excluded; Not a research study. [pmid: 1480432].
Holden G W, Ritchie K L. Linking extreme marital discord, child rearing, and child behavior problems: evidence from battered women. Child Dev. 1991;62(2):311-27. Excluded; Age of study population greater than 17 years. [pmid: 2055124].
Holmes S R, Brandenburg-Ayres S J. Bullying behavior in school: A predictor of later gang involvement. J Gang Res. 1998;5(2):1-6. Excluded; Outcome is not violence.
Honig J. Perceived health status in urban minority young adolescents. MCN Am J Matern Child Nurs. 2002;27(4):233-7. Excluded; Outcome is not violence. [pmid: 12131275].
Hoover J H, Oliver R, Hazler R J. Bullying: Perceptions of adolescent victims in the Midwestern USA. Sch Psychol Int. 1992;13(1):5-16. Excluded; Outcome is not violence.
Hops H, Davis B, Leve C, et al. Cross-generational transmission of aggressive parent behavior: A prospective, mediational examination. J Abnorm Child Psychol. 2003;31(2):161-9. Excluded; Study does not focus on youth as perpetrators. [pmid: 12735398].
Horner R H, Day H M, Sprague J R, et al. Interspersed requests: a nonaversive procedure for reducing aggression and self-injury during instruction. J Appl Behav Anal. 1991;24(2):265-78. Excluded; Data not abstractable. [pmid: 1890047]. [pmcid: 1279572].
Horton A. The prevention of juvenile delinquency: New evidence to consider. J Hum Behav Soc Environ. 1998;1(4):1-10. Excluded; Outcome is not violence.
Horton A. The prevention of school violence: New evidence to consider. J Hum Behav Soc Environ. 2001;4(1):49-59. Excluded; Not addressing they key questions.
Horton A. Violent crime: New evidence to consider. J Hum Behav Soc Environ. 2002;5(2):77-88. Excluded; Age of study population greater than 17 years.
Howard D, Qiu Y, Boekeloo B. Personal and social contextual correlates of adolescent dating violence. J Adolesc Health. 2003;33(1):9-17. Excluded; Study does not focus on youth as perpetrators. [pmid: 12834992].
Howard D E, Cross S I, Li X, et al. Parent-youth concordance regarding violence exposure: relationship to youth psychosocial functioning. J Adolesc Health. 1999;25(6):396-406. Excluded; Study design not used. [pmid: 10608579].
Howard D E, Wang M Q. Risk profiles of adolescent girls who were victims of dating violence. Adolescence. 2003;38(149):1-14. Excluded; Study does not focus on youth as perpetrators. [pmid: 14768995].
Howard P E. Protecting our most precious resource. Del Med J. 1997;69(7):327-8. Excluded; Not a research study. [pmid: 9260382].
Howell A J, Reddon J R, Enns R A. Immediate antecedents to adolescents' offenses. J Clin Psychol. 1997;53(4):355-60. Excluded; Not a U.S. study. [pmid: 9169390].
Howell A J, Reddon J R, Enns R A. Immediate antecedents to adolescents' offenses. J Clin Psychol. 1997;53:355-60. Excluded; Duplicated citation or findings. [pmid: 9169390].
Hsu L G, Starzynski J. Adolescent rapists and adolescent child sexual assaulters. Int J Offender Ther Comp Criminol. 1990;34(1):23-30. Excluded; Not addressing they key questions.
Huang B, White H R, Kosterman R, et al. Developmental associations between alcohol and interpersonal aggression during adolescence. J Res Crime Delinq. 2001;38(1):64-83. Excluded; Study design not used.
Huang D B, Cherek D R, Lane S D. Laboratory measurement of aggression in high school age athletes: Provocation in a nonsporting context. Psychol Rep. 1999;85(3, Pt 2 Spec Issue):1251-62. Excluded; Outcome is not violence. [pmid: 10710982].
Hubbard J A, Dodge K A, Cillessen A H N, et al. The dyadic nature of social information processing in boys' reactive and proactive aggression. J Pers Soc Psychol. 2001;80(2):268-80. Excluded; Study does not focus on youth as perpetrators. [pmid: 11220445].
Hudley C, Friday J. Attributional bias and reactive aggression. Am J Prev Med. 1996;12(5 Suppl):75-81. Excluded; Study does not focus on youth as perpetrators. [pmid: 8909627].
Huefner DS. Another point of the suspension and expulsion cases. Except Child 1991;57(4):360–4; Discussion 4–8. Excluded; Not a research study.
Huesmann L R, Maxwell C D, Eron L, et al. Evaluating a cognitive/ecological program for the prevention of aggression among urban children. Am J Prev Med. 1996;12(5 Suppl):120-8. Excluded; Study does not focus on youth as perpetrators. [pmid: 8909632].
Hughes S A, Deville C, Chalhoub M, et al. The Rorschach human anatomy response: Predicting sexual offending behavior in juveniles. J Psychiatry Law. 1992;20(3):313-33. Excluded; Not addressing they key questions.
Hunt G, Joe-Laidler K. Situations of violence in the lives of girl gang members. Health Care Women Int. 2001;22(4):363-84. Excluded; Data not abstractable. [pmid: 11813785].
Hunter J A, Figueredo A J. The influence of personality and history of sexual victimization in the prediction of juvenile perpetrated child molestation. Behav Modif. 2000;24(2):241-63. Excluded; Study design not used. [pmid: 10804682].
Hunter J A, Figueredo A J, Malamuth N M, et al. Juvenile sex offenders: Toward the development of a typology. Sex Abuse. 2003;15(1):27-48. Excluded; Not addressing they key questions. [pmid: 12616927].
Hunter J A, Hazelwood R R, Slesinger D. Juvenile-perpetrated sex crimes: Patterns of offending and predictors of violence. J Fam Violence. 2000;15(1):81-93. Excluded; Not addressing they key questions.
Hutchins J J. Prevention of handgun deaths. N J Med. 1990;87(4):283-5. Excluded; Not a research study. [pmid: 2352656].
Hutchison I W, Hirschel J D, Pesackis C E. Family violence and police utilization. Violence Vict. 1994;9(4):299-313. Excluded; Outcome is not violence. [pmid: 7577758].
Hutton M. Violence in America. Reaching epidemic proportions. J Fla Med Assoc. 1995;82(10):667-8. Excluded; Not a research study. [pmid: 7500077].
Hwang S D, Segal S P. Criminality of the mentally ill in sheltered care: are they more dangerous?. Int J Law Psychiatry. 1996;19(1):93-105. Excluded; Age of study population greater than 17 years. [pmid: 8929663].
Hyde C E, Harrower-Wilson C, Morris J. Violence, dissatisfaction and rapid tranquillisation in psychiatric intensive care. Psychiatr Bull R Coll Psychiatr. 1998;22(8):477-80. Excluded; Not a U.S. study.
Ialongo N S, Vaden-Kiernan N, Kellam S. Early peer rejection and aggression: Longitudinal relations with adolescent behavior. J Dev Phys Disabil. 1998;10(2):199-213. Excluded; Data not abstractable.
Inciardi J A. The crack-violence connection within a population of hard-core adolescent offenders. NIDA Res Monogr. 1990;103:92-111. Excluded; Study design not used. [pmid: 2096295].
Ireland J L. Do juveniles bully more than young offenders?. J Adolesc. 2002;25(2):155-68. Excluded; Not a U.S. study. [pmid: 12490184].
Ireland J L. Official records of bullying incidents among young offenders: what can they tell us and how useful are they?. J Adolesc. 2002;25(6):669-79. Excluded; Not a U.S. study. [pmid: 12490184].
Jackson C, Foshee V A. Violence-related behaviors of adolescents: Relations with responsive and demanding parenting. J Adolesc Res. 1998;13(3):343-59. Excluded; Study design not used.
Jacobs W L, Kennedy W A, Meyer J B. Juvenile delinquents: A between-group comparison study of sexual and nonsexual offenders. Sex Abuse. 1997;9(3):201-17. Excluded; Study design not used.
Jaffee S, Caspi A, Moffitt T E, et al. Why are children born to teen mothers at risk for adverse outcomes in young adulthood? Results from a 20-yr longitudinal study. Dev Psychopathol. 2001;13(2):377-97. Excluded; Not a U.S. study. [pmid: 11393652].
Jaffee S, Caspi A, Moffitt T E, et al. Why are children born to teen mothers at risk for adverse outcomes in young adulthood? Results from a 20-year longitudinal study. Dev Psychopathol. 2001;13(2):377-97. Excluded; Not a U.S. study. [pmid: 11393652].
Jagers R J, Mock L O. Culture and social outcomes among inner-city African American children: An Afrographic exploration. J Black Psychol. 1993;19(4):391-405. Excluded; Outcome is not violence.
James E. Royal Society of Medicine: the roots of violence in children and young people. Med Confl Surviv. 1999;15(4):420-2. Excluded; Not a research study. [pmid: 10605390].
James W H, West C, Deters K E, et al. Youth dating violence. Adolescence. 2000;35(139):455-65. Excluded; Study design not used. [pmid: 11130591].
Jamieson S, Marshall W L. Attachment styles and violence in child molesters. J Sex Aggress. 2000;5(2):88-98. Excluded; Not a U.S. study.
Jarjoura G R, May D C. Integrating criminological theories to explain violent forms of delinquency. Caribb J Criminol Soc Psychol. 2000;5(12):81-102. Excluded; Not addressing they key questions.
Jasinski J L. Physical violence among Anglo, African American, and Hispanic couples: Ethnic differences in persistence and cessation. Violence Vict. 2001;16(5):479-90. Excluded; Age of study population greater than 17 years. [pmid: 11688924].
Jenkins P H. School delinquency and the school social bond. J Res Crime Delinq. 1997;34:337-67. Excluded; Data not abstractable.
Jenkins R S. Enhancing violence prevention in at-risk youth. J Health Care Poor Underserved. 1992;3(2):270-1. Excluded; Not a research study. [pmid: 1420664].
Jenson J M, Howard M O. Youth crime, public policy, and practice in the juvenile justice system: recent trends and needed reforms. Soc Work. 1998;43(4):324-34. Excluded; Not a research study. [pmid: 9663002].
Johnson C C, Myers L, Webber L S, et al. Assertiveness and cardiovascular disease risk factors in children and adolescents: The Bogalusa heart study. J Soc Behav Pers. 1997;12(1):243-55. Excluded; Outcome is not violence.
Johnson J G, Cohen P, Smailes E, et al. Adolescent personality disorders associated with violence and criminal behavior during adolescence and early adulthood. Am J Psychiatry. 2000;157(9):1406-12. Excluded; Data not abstractable. [pmid: 10964855].
Johnson J G, Cohen P, Smailes E M, et al. Television viewing and aggressive behavior during adolescence and adulthood. Science. 2002;295(5564):2468-71. Excluded; Data not abstractable. [pmid: 11923542].
Johnson S D. The social context of youth violence: A study of African American youth. Int J Adolesc Med Health. 1999;11(34):159-75. Excluded; Outcome is not violence.
Jones T S, Bodtker A M. Conflict education in a special needs population. Mediat Q. 1999;17(2):109-24. Excluded; Data not abstractable.
Jonson-Reid M, Barth R P. From maltreatment report to juvenile incarceration: the role of child welfare services. Child Abuse Negl. 2000;24(4):505-20. Excluded; Data not abstractable. [pmid: 10798840].
Jonson-Reid M, Barth R P. From placement to prison: the path to adolescent incarceration from child welfare supervised foster or group care. Child Youth Serv Rev. 2000;22(7):493-516. Excluded; Outcome is not violence.
Jonson-Reid M, Bivens L. Foster youth and dating violence. J Interpers Violence. 1999;14(12):1249-62. Excluded; Study design not used.
Jonson-Reid M, Williams J H, Webster D. Severe emotional disturbance and violent offending among incarcerated adolescents. Soc Work Res. 2001;25(4):213-22. Excluded; Not addressing they key questions.
Jordan E, Cowan A, Roberts J. Knowing the rules: Discursive strategies in young children's power struggles. Early Child Res Q. 1995;10(3):339-58. Excluded; Not a U.S. study.
Joshi P, Hamel L, Joshi A R T, et al. Use of droperidol in hospitalized children. J Am Acad Child Adolesc Psychiatry. 1998;37(2):228-30. Excluded; Not addressing they key questions. [pmid: 9473921].
Jossi F. Stopping the violence. Healthplan. 1998;39(3):95-100. Excluded; Not a research study. [pmid: 10181757].
Jouriles E N, Norwood W D, McDonald R, et al. Physical violence and other forms of marital aggression: Links with children's behavior problems. J Fam Psychol. 1996;10(2):223-34. Excluded; Outcome is not violence.
Kang S Y, Magura S, Shapiro J L. Correlates of cocaine/crack use among inner-city incarcerated adolescents. Am J Drug Alcohol Abuse. 1994;20(4):413-29. Excluded; Not addressing they key questions. [pmid: 7832177].
Kann L, Kinchen S A, Williams B I, et al. Youth risk behavior surveillance--United States, 1999. State and local YRBSS coordinators. J Sch Health. 2000;70(7):271-85. Excluded; Study design not used. [pmid: 10981282].
Kann L, Kinchen S A, Williams B I, et al. Youth risk behavior surveillance--United States, 1999. MMWR CDC Surveill Summ. 2000;49(5):1-32. Excluded; Not addressing they key questions. [pmid: 12412614].
Kann L, Kinchen S A, Williams B I, et al. Youth risk behavior surveillance--United States, 1997. State and local YRBSS coordinators. J Sch Health. 1998;68(9):355-69. Excluded; Study design not used. [pmid: 9854692].
Kann L, Kinchen S A, Williams B I, et al. Youth risk behavior surveillance--United States, 1997. MMWR CDC Surveill Summ. 1998;47(3):1-89. Excluded; Not addressing they key questions. [pmid: 9750562].
Kann L, Warren C W, Harris W A, et al. Youth risk behavior surveillance--United States, 1995. J Sch Health. 1996;66(10):365-77. Excluded; Study design not used. [pmid: 8981266].
Kann L, Warren W, Collins J L, et al. Results from the national school-based 1991 Youth Risk Behavior Survey and progress toward achieving related health objectives for the nation. Public Health Rep. 1993;108(Suppl 1):47-67. Excluded; Study design not used. [pmid: 8210275]. [pmcid: 1403309].
Kaplan G A, Pamuk E R, Lynch J W, et al. Inequality in income and mortality in the United States: analysis of mortality and potential pathways. BMJ. 1996;312(7037):999-1003. Excluded; Study does not focus on youth as perpetrators. [pmid: 8616393].
Kaplan H B, Peck B M. Self-rejection, coping style, and mode of deviant response. Soc Sci Q. 1992;73(4):903-19. Excluded; Study design not used.
Kaplan S J, Labruna V, Pelcovitz D, et al. Physically abused adolescents: behavior problems, functional impairment, and comparison of informants' reports. Pediatrics. 1999;104(1 Pt 1):43-9. Excluded; Outcome is not violence. [pmid: 10390258].
Kaplan S J, Pelcovitz D, Salzinger S, et al. Adolescent physical abuse: risk for adolescent psychiatric disorders. Am J Psychiatry. 1998;155(7):954-9. Excluded; Study does not focus on youth as perpetrators. [pmid: 9659863].
Kaplan S L, Busner J, Kupietz S, et al. Effects of methylphenidate on adolescents with aggressive conduct disorder and ADDH: A preliminary report. J Am Acad Child Adolesc Psychiatry. 1990;29(5):719-23. Excluded; Not addressing they key questions. [pmid: 2228924].
Kashani J H, Darby P J, Allan W D, et al. Intrafamilial homicide committed by juveniles: Examination of a sample with recommendations for prevention. J Forensic Sci. 1997;42(5):873-8. Excluded; Not addressing they key questions. [pmid: 9304834].
Kashani J H, Deuser W, Reid J C. Aggression and anxiety: a new look at an old notion. J Am Acad Child Adolesc Psychiatry. 1991;30(2):218-23. Excluded; Data not abstractable. [pmid: 2016225].
Kashani J H, Jones M R, Borduin C M, et al. Individual characteristics and peer relations of psychiatrically hospitalized aggressive youths: Implications for treatment. Child Psychiatry Hum Dev. 2000;30(3):145-59. Excluded; Data not abstractable. [pmid: 10851790].
Kashani J H, Shepperd J A. Aggression in adolescents: the role of social support and personality. Can J Psychiatry. 1990;35(4):311-5. Excluded; Study design not used. [pmid: 2346896].
Kassirer J P. Private arsenals and public peril. N Engl J Med. 1998;338(19):1375-6. Excluded; Not a research study. [pmid: 9862949].
Kastner J W. Clinical change in adolescent aggressive behavior: A group therapy approach. J Child Adolesc Group Ther. 1998;8(1):23-33. Excluded; Data not abstractable.
Katz R C, Marquette j. Psychosocial characteristics of young violent offenders: A comparative study. Crim Behav Ment Health. 1996;6(4):339-48. Excluded; Data not abstractable.
Kazdin A E, Crowley M J. Moderators of treatment outcome in cognitively based treatment of antisocial children. Cognit Ther Res. 1997;21(2):185-207. Excluded; Study does not focus on youth as perpetrators.
Keiley M K, Howe T R, Dodge K A, et al. The timing of child physical maltreatment: a cross-domain growth analysis of impact on adolescent externalizing and internalizing problems. Dev Psychopathol. 2001;13(4):891-912. Excluded; Outcome is not violence. [pmid: 11771913].
Kelder S H, Orpinas P, McAlister A, et al. The students for peace project: a comprehensive violence-prevention program for middle school students. Am J Prev Med. 1996;12(5 Suppl):22-30. Excluded; Not a research study. [pmid: 8909621].
Kellam S G, Ling X, Merisca R, et al. The effect of the level of aggression in the first grade classroom on the course and malleability of aggressive behavior into middle school. Dev Psychopathol. 1998;10(2):165-85. Excluded; Study does not focus on youth as perpetrators. [pmid: 9635220].
Kellam S G, Ling X, Merisca R, et al. The effect of the level of aggression in the first grade classroom on the course and malleability of aggressive behavior into middle school: Erratum. Dev Psychopathol. 1999;11(1):193. Excluded; Not a research study.
Kellam S G, Ling X, Merisca R, et al. The effect of the level of aggression in the first grade classroom on the course and malleability of aggressive behavior into middle school: Erratum. Dev Psychopathol. 2000;12(1):107. Excluded; Not a research study.
Kellam S G, Rebok G W, Ialongo N, et al. The course and malleability of aggressive behavior from early first grade into middle school: results of a developmental epidemiologically-based preventive trial. Journal of Child Psychology and Psychiatry, and Allied Disciplines. 1994;35(2):259-81. Excluded; Study does not focus on youth as perpetrators. [pmid: 8188798].
Kelley BR, Beauchesne MA. Interventions for violence in children and adolescents. School Nurse News 2002;19(3)36–9; Quiz 40. Excluded; Not a research study.
Kelley D. Shots fired … children down. JEMS 1998;23(8):38–42, 5. Excluded; Not a research study.
Keltikangas-Jaervinen L. Aggressive behaviour and social problem-solving strategies: A review of the findings of a seven-year follow-up from childhood to late adolescence. Crim Behav Ment Health. 2001;11(4):236-50. Excluded; Not a U.S. study.
Keltikangas-Jaervinen L. Aggressive problem-solving strategies, aggressive behavior, and social acceptance in early and late adolescence. J Youth Adolesc. 2002;31(4):279-87. Excluded; Not a U.S. study.
Keltikangas-Jaervinen L, Pakaslahti L. Development of social problem-solving strategies and changes in aggressive behavior: A 7-year follow-up from childhood to late adolescence. Aggress Behav. 1999;25(4):269-79. Excluded; Outcome is not violence.
Kemph J P, Braley R O, Ciotola P V. A comparison of youthful inmates who have committed violent versus nonviolent crimes. J Am Acad Psychiatry Law. 1998;26(1):67-74. Excluded; Data not abstractable. [pmid: 9554711].
Kemph J P, DeVane C L, Levin G M, et al. Treatment of aggressive children with clonidine: results of an open pilot study. J Am Acad Child Adolesc Psychiatry. 1993;32(3):577-81. Excluded; Data not abstractable. [pmid: 8496122].
Kempton T, Forehand R. Juvenile sex offenders: similar to, or different from, other incarcerated delinquent offenders?. Behav Res Ther. 1992;30(5):533-6. Excluded; Outcome is not violence. [pmid: 1520240].
Kennedy L W, Baron S W. Routine activities and a subculture of violence: A study of violence on the street. J Res Crime Delinq. 1993;30(1):88-112. Excluded; Not a research study.
Kennedy M. What's the matter with kids today?. WMJ. 1998;97(8):40-3. Excluded; Not a research study. [pmid: 9894436].
Kennedy M. Teens today facing familiar problems. WMJ. 2000;99(2):28-32. Excluded; Not a research study. [pmid: 11089445].
Kent C. Perspectives. Public health attacks violence. Faulkner Grays Med Health 1992;46(25):Suppl 4 P. Excluded; Not a research study.
Kesner J E, McKenry P C. The role of childhood attachment factors in predicting male violence toward female intimates. J Fam Violence. 1998;13(4):417-32. Excluded; Age of study population greater than 17 years.
Kettl P A. Homicide in Alaska Natives. Alaska Med. 1993;35(2):168-72. Excluded; Age of study population greater than 17 years. [pmid: 8238772].
Khatri P, Kupersmidt J B, Patterson C. Aggression and peer victimization as predictors of self-reported behavioral and emotional adjustment. Aggress Behav. 2000;26(5):345-58. Excluded; Study does not focus on youth as perpetrators.
Kheder S, VandenBosch T. Intimate partner violence: a health system's response. Continuum Soc Soc Work Leadersh Health Care. 2001;21(1):15-22. Excluded; Not a research study. [pmid: 11255844].
Kho K, Sensky T, Mortimer A, et al. Prospective study into factors associated with aggressive incidents in psychiatric acute admission wards. Br J Psychiatry. 1998;172:38-43. Excluded; Not a U.S. study. [pmid: 9534830].
Killeen M R. Ten years after: examination of adolescent screening questions that predict future violence-related injury. J Child Fam Nurs. 2000;3(2):115-6. Excluded; Data not abstractable. [pmid: 11271147].
Kindlon D J, Tremblay R E, Mezzacappa E, et al. Longitudinal patterns of heart rate and fighting behavior in 9- through 12-year-old boys. J Am Acad Child Adolesc Psychiatry. 1995;34(3):371-7. Excluded; Not a U.S. study. [pmid: 7896679].
King K A, Vidourek R A, Davis B, et al. Increasing self-esteem and school connectedness through a multidimensional mentoring program. J Sch Health. 2002;72(7):294-9. Excluded; Outcome is not violence. [pmid: 12357911].
King S R. Acting on what they (may) know: children's culpability for violent behavior. J Dev Behav Pediatr. 2000;21(6):429-31. Excluded; Not a research study. [pmid: 11132794].
Kingery P M, McCoy-Simandle L, Clayton R. Risk factors for adolescent violence: The importance of vulnerability. Sch Psychol Int. 1997;18(1):49-60. Excluded; Not addressing they key questions.
Kingery P M, Mirzaee E, Pruitt B E, et al. Rural communities near large metropolitan areas: Safe havens from adolescent violence and drug use?. Health Values. 1991;15(4):39-48. Excluded; Study design not used.
Kingery P M, Pruitt B E, Heuberger G. A profile of rural Texas adolescents who carry handguns to school. J Sch Health. 1996;66(1):18-22. Excluded; Study design not used. [pmid: 8907733].
Kingery P M, Pruitt B E, Heuberger G, et al. Violence in rural schools: An emerging problem near the United States^Mexico border. Sch Psychol Int. 1995;16(4):335-44. Excluded; Study design not used.
Kingery P M, Pruitt B E, Hurley R S. Violence and illegal drug use among adolescents: evidence from the U.S. National Adolescent Student Health Survey. Int J Addict. 1992;27(12):1445-64. Excluded; Study design not used. [pmid: 1452395].
Kipke M D, Simon T R, Montgomery S B, et al. Homeless youth and their exposure to and involvement in violence while living on the streets. J Adolesc Health. 1997;20(5):360-7. Excluded; Study does not focus on youth as perpetrators. [pmid: 9168383].
Kirkish P, Sreenivasan S, Welsh R, et al. The future of criminal violence: juveniles tried as adults. J Am Acad Psychiatry Law. 2000;28(1):38-46. Excluded; Age of study population greater than 17 years. [pmid: 10774840].
Klevens J, Roca J. Nonviolent youth in a violent society: Resilience and vulnerability in the country of Columbia. Violence Vict. 1999;14(3):311-22. Excluded; Not a U.S. study. [pmid: 10606436].
Knox G W. The “get out of the gang thermometer”: An application to a large national sample of African-American male youths. J Gang Res. 1997;5(1):21-43. Excluded; Outcome is not violence.
Knox M, King C, Hanna G L, et al. Aggressive behavior in clinically depressed adolescents. J Am Acad Child Adolesc Psychiatry. 2000;39(5):611-8. Excluded; Data not abstractable. [pmid: 10802979].
Kodjo C M, Auinger P, Ryan S A, et al. Demographic, intrinsic, and extrinsic factors associated with weapon carrying at school. Arch Pediatr Adolesc Med. 2003;157(1):96-103. Excluded; Duplicated citation or findings. [pmid: 12517202].
Kodjo C M, Auinger P, Ryan S A, et al. Demographic, intrinsic, and extrinsic factors associated with weapon carrying at school. Arch Pediatr Adolesc Med. 2003;157(1):96-103. Excluded; Outcome is not violence. [pmid: 12517202].
Kohn R. Homicide among adolescents in the Americas: a growing epidemic. Bull World Health Organ. 2001;79(2):172. Excluded; Not a research study. [pmid: 11242824].
Kolko D J. Conduct disorder and attention deficit disorder with hyperactivity in child inpatients: Comparisons on home and hospital measures. J Emot Behav Disord. 1993;1(2):75-86. Excluded; Study does not focus on youth as perpetrators.
Kosterman R, Graham J W, Hawkins J D, et al. Childhood risk factors for persistence of violence in the transition to adulthood: a social development perspective. Violence Vict. 2001;16(4):355-69. Excluded; Duplicated citation or findings. [pmid: 11506446].
Kostinsky S, Bixler E O, Kettl P A. Threats of school violence in Pennsylvania after media coverage of the Columbine High School massacre: examining the role of imitation. Arch Pediatr Adolesc Med. 2001;155(9):994-1001. Excluded; Outcome is not violence. [pmid: 11529800].
Krakowski M, Czobor P. Violence in psychiatric patients: the role of psychosis, frontal lobe impairment, and ward turmoil. Compr Psychiatry. 1997;38(4):230-6. Excluded; Age of study population greater than 17 years. [pmid: 9202880].
Krakowski M, Czobor P, Carpenter M D, et al. Community violence and inpatient assaults: neurobiological deficits. J Neuropsychiatry Clin Neurosci. 1997;9(4):549-55. Excluded; Age of study population greater than 17 years. [pmid: 9447495].
Kreiter S R, Krowchuk D P, Woods C R, et al. Gender differences in risk behaviors among adolescents who experience date fighting. Pediatrics. 1999;104(6):1286-92. Excluded; Study design not used. [pmid: 10585979].
Kruesi M J, Hibbs E D, Zahn T P, et al. A 2-year prospective follow-up study of children and adolescents with disruptive behavior disorders. Prediction by cerebrospinal fluid 5-hydroxyindoleacetic acid, homovanillic acid, and autonomic measures?. Arch Gen Psychiatry. 1992;49(6):429-35. Excluded; Study does not focus on youth as perpetrators. [pmid: 1376104].
Kruesi M J, Rapoport J L, Hamburger S, et al. Cerebrospinal fluid monoamine metabolites, aggression, and impulsivity in disruptive behavior disorders of children and adolescents. Arch Gen Psychiatry. 1990;47(5):419-26. Excluded; Data not abstractable. [pmid: 1691910].
Krug E G, Brener N D, Dahlberg L L, et al. The impact of an elementary school-based violence prevention program on visits to the school nurse. Am J Prev Med. 1997;13(6):459-63. Excluded; Study does not focus on youth as perpetrators. [pmid: 9415793].
Kruttschnitt C, Dornfeld M. Exposure to family violence: A partial explanation for initial and subsequent levels of delinquency?. Crim Behav Ment Health. 1993;3(2):61-75. Excluded; Outcome is not violence.
Kulig J, Valentine J, Griffith J, et al. Predictive model of weapon carrying among urban high school students: Results and validation. J Adolesc Health. 1998;22(4):312-9. Excluded; Outcome is not violence. [pmid: 9561463].
Kundu R, Basu J. Aggression in reaction to frustration among adolescent boys with depression and conduct disorder. SIS J Project Psychol Ment Health. 1998;5(2):119-26. Excluded; Not a U.S. study.
Kunitz S J, Levy J E, McCloskey J, et al. Alcohol dependence and domestic violence as sequelae of abuse and conduct disorder in childhood. Child Abuse Negl. 1998;22(11):1079-91. Excluded; Age of study population greater than 17 years. [pmid: 9827313].
Kyriacou D N, Hutson H R, Anglin D, et al. The relationship between socioeconomic factors and gang violence in the City of Los Angeles. J Trauma. 1999;46(2):334-9. Excluded; Age of study population greater than 17 years. [pmid: 10029043].
Labelle A, Bradford J M, Bourget D, et al. Adolescent murderers. Can J Psychiatry. 1991;36(8):583-7. Excluded; Not a U.S. study. [pmid: 1742712].
Lacourse E, Cote S, Nagin D S, et al. A longitudinal-experimental approach to testing theories of antisocial behavior development. Dev Psychopathol. 2002;14(4):909-24. Excluded; Not a U.S. study. [pmid: 12549709].
Lahey B B, Goodman S H, Waldman I D, et al. Relation of age of onset to the type and severity of child and adolescent conduct problems. J Abnorm Child Psychol. 1999;27(4):247-60. Excluded; Data not abstractable. [pmid: 10503644].
Lahey B B, Loeber R, Quay H C, et al. Validity of DSM-IV subtypes of conduct disorder based on age of onset. J Am Acad Child Adolesc Psychiatry. 1998;37(4):435-42. Excluded; Outcome is not violence. [pmid: 9549965].
Lamberg L. Preventing school violence: no easy answers. JAMA. 1998;280(5):404-7. Excluded; Not a research study. [pmid: 9863836].
Lamberg L. Younger children, more girls commit acts of violence: some get help, others receive only punishment. JAMA. 2002;288(5):566-8. Excluded; Not a research study. [pmid: 12243626].
Lancaster W Jr, Compton D, White N, et al. MMPI-A and dissociative experiences scale responses of violent and non-violent youth offenders. J Offender Rehabil. 1997;26(12):45-52. Excluded; Study design not used.
Lanclos N F, Gordon S T, Kelley M L. The effects of community violence exposure on Louisiana's children. J La State Med Soc. 2000;152(10):504-8. Excluded; Not a research study. [pmid: 11059920].
Langhinrichsen-Rohling J, Neidig P. Violent backgrounds of economically disadvantaged youth: Risk factors for perpetrating violence?. J Fam Violence. 1995;10(4):379-97. Excluded; Outcome is not violence.
Langrock A M, Compas B E, Keller G, et al. Coping with the stress of parental depression: Parents' reports of children's coping, emotional, and behavioral problems. J Clin Child Adolesc Psychol. 2002;31(3):312-24. Excluded; Outcome is not violence. [pmid: 12149969].
Lansford J E, Dodge K A, Pettit G S, et al. A 12-year prospective study of the long-term effects of early child physical maltreatment on psychological, behavioral, and academic problems in adolescence. Arch Pediatr Adolesc Med. 2002;156(8):824-30. Excluded; Data not abstractable. [pmid: 12144375].
Larson J D. Anger and aggression management techniques through the Think First curriculum. J Offender Rehabil. 1992;18(12):101-17. Excluded; Data not abstractable.
Lattimore P K, Others A. Predicting rearrest for violence among serious youthful offenders. J Res Crime Delinq. 1995;32(1):54-83. Excluded; Not addressing they key questions.
Lau M A, Pihl R O. Alcohol and the Taylor aggression paradigm: a repeated measures study. J Stud Alcohol. 1994;55(6):701-6. Excluded; Outcome is not violence. [pmid: 7861799].
Lavoie F, Hebert M, Tremblay R, et al. History of family dysfunction and perpetration of dating violence by adolescent boys; A longitudinal study. J Adolesc Health. 2002;30(5):375-83. Excluded; Not a U.S. study. [pmid: 11996786].
Lawrence L E. Perspectives on violence. J Natl Med Assoc. 1993;85(11):825-7. Excluded; Not a research study. [pmid: 8126739].
Leenaars A A, Lester D. Suicide and homicide rates in Canada and the United States. Suicide Life Threat Behav. 1994;24(2):184-91. Excluded; Study does not focus on youth as perpetrators. [pmid: 8053012].
Lego S. Children killing children. Perspect Psychiatr Care. 1998;34(3):3-4. Excluded; Not a research study. [pmid: 10076425].
Lehman C. Striking back. Minn Med. 2000;83(9):24-6. Excluded; Not a research study. [pmid: 11006684].
LeMarquand D G, Pihl R O, Young S N, et al. Tryptophan depletion, executive functions, and disinhibition in aggressive, adolescent males. Neuropsychopharmacology. 1998;19(4):333-41. Excluded; Outcome is not violence. [pmid: 9718596].
Lempp R. To the diagnostic of “incomprehensible” offences of adolescents and juveniles. Acta Paedopsychiatr. 1990;53(2):173-5. Excluded; Not a research study. [pmid: 2178310].
Leon-Carrion J, Ramos F J C. Blows to the head during development can predispose to violent criminal behaviour: rehabilitation of consequences of head injury is a measure for crime prevention. Brain Inj. 2003;17(3):207-16. Excluded; Not a U.S. study. [pmid: 12623497].
Leon-Carrion J, Ramos F J C. Blows to the head during development can predispose to violent criminal behaviour: rehabilitation of consequences of head injury is a measure for crime prevention. Brain Inj. 2003;17(3):207-16. Excluded; Duplicated citation or findings. [pmid: 12623497].
Lester D. The Holinger/Easterlin cohort hypothesis about youth suicide and homicide rates. Percept Mot Skills. 1994;79(3 Pt 2):1545-6. Excluded; Not a research study. [pmid: 7870542].
LeSure-Lester G E. Relation between empathy and aggression and behavior compliance among abused group home youth. Child Psychiatry Hum Dev. 2000;31(2):153-61. Excluded; Not addressing they key questions. [pmid: 11089303].
LeSure-Lester G E. An application of cognitive-behavior principles in the reduction of aggression among abused African American adolescents. J Interpers Violence. 2002;17(4):394-402. Excluded; Outcome is not violence.
Leventhal J M, Horwitz S M, Rude C, et al. Maltreatment of children born to teenage mothers: a comparison between the 1960s and 1980s. J Pediatr. 1993;122(2):314-9. Excluded; Study does not focus on youth as perpetrators. [pmid: 8429452].
Levine G N, Parra F. The gangbangers of East Los Angeles: Sociopsycho-analytic considerations. J Gang Res. 2000;7(4):9-12. Excluded; Outcome is not violence.
Lewin L M, Davis B, Hops H. Childhood social predictors of adolescent antisocial behavior: Gender differences in predictive accuracy and efficacy. J Abnorm Child Psychol. 1999;27(4):277-92. Excluded; Outcome is not violence. [pmid: 10503646].
Lewis DO, Lovely R, Yeager C, et al. Toward a theory of the genesis of violence: A follow-up study of delinquents. Annu Prog Child Psych Child Dev 1990:547–60. Excluded; Study does not focus on youth as perpetrators.
Lewis D O, Yeager C A, Cobham-Portorreal C S, et al. A follow-up of female delinquents: maternal contributions to the perpetuation of deviance. J Am Acad Child Adolesc Psychiatry. 1991;30(2):197-201. Excluded; Age of study population greater than 17 years. [pmid: 2016222].
Lewis D O, Yeager C A, Gidlow B, et al. Six adoptees who murdered: Neuropsychiatric vulnerabilities and characteristics of biological and adoptive parents. J Am Acad Psychiatry Law. 2001;29(4):390-7. Excluded; Not a research study. [pmid: 11785610].
Lewis S F, Travea L, Fremouw W J. Characteristics of female perpetrators and victims of dating violence. Violence Vict. 2002;17(5):593-606. Excluded; Age of study population greater than 17 years. [pmid: 12477100].
Li X, Feigelman S, Stanton B. Perceived parental monitoring and health risk behaviors among urban low-income African-American children and adolescents. J Adolesc Health. 2000;27(1):43-8. Excluded; Study design not used. [pmid: 10867352].
Li X, Stanton B, Feigelman S. Exposure to drug trafficking among urban, low-income African American children and adolescents. Arch Pediatr Adolesc Med. 1999;153(2):161-8. Excluded; Data not abstractable. [pmid: 10520613].
Lingle E A. Treating children by faith. Colliding constitutional issues. J Leg Med. 1996;17(2):301-30. Excluded; Not a research study. [pmid: 8691058].
Litt I F. Violence among adolescents: don't overlook the girls. J Adolesc Health. 1995;17(6):333. Excluded; Not a research study. [pmid: 8924438].
Little S A, Garber J. Interpersonal and achievement orientations and specific stressors predicting depressive and aggressive symptoms in children. Cognit Ther Res. 2000;24(6):651-70. Excluded; Data not abstractable.
Livingston R, Lawson L, Jones J G. Predictors of self-reported psychopathology in children abused repeatedly by a parent. J Am Acad Child Adolesc Psychiatry. 1993;32(5):948-53. Excluded; Study does not focus on youth as perpetrators. [pmid: 8407768].
Lochman J E, Dodge K A. Social-cognitive processes of severely violent, moderately aggressive, and nonaggressive boys. J Consult Clin Psychol. 1994;62(2):366-74. Excluded; Study design not used. [pmid: 8201075].
Lochman J E, Wayland K K. Aggression, social acceptance, and race as predictors of negative adolescent outcomes. J Am Acad Child Adolesc Psychiatry. 1994;33(7):1026-35. Excluded; Outcome is not violence. [pmid: 7961341].
Lochman J E, Wells K C. Contextual social-cognitive mediators and child outcome: A test of the theoretical model in the Coping Power program. Dev Psychopathol. 2002;14(4):945-67. Excluded; Data not abstractable. [pmid: 12549711].
Lockwood D. Violence prevention among African American middle school children. Res Middle Level Educ Q. 1998;21(3):33-49. Excluded; Not addressing they key questions.
Lodico M A, Gruber E, DiClemente R J. Childhood sexual abuse and coercive sex among school-based adolescents in a midwestern state. J Adolesc Health. 1996;18(3):211-7. Excluded; Not addressing they key questions. [pmid: 8777197].
Loeber R, Burke J D, Lahey B B. What are adolescent antecedents to antisocial personality disorder?. Crim Behav Ment Health. 2002;12(1):24-36. Excluded; Age of study population greater than 17 years. [pmid: 12357256].
Loeber R, Farrington D P, Stouthamer-Loeber M, et al. The development of male offending: Key findings from the first decade of the Pittsburgh Youth Study. Stud Crime Crime Prev. 1998;7(2):141-71. Excluded; Not addressing they key questions.
Loeber R, Green S M, Keenan K, et al. Which boys will fare worse? Early predictors of the onset of conduct disorder in a six-year longitudinal study. J Am Acad Child Adolesc Psychiatry. 1995;34(4):499-509. Excluded; Outcome is not violence. [pmid: 7751264].
Long J J, Fabricius W V, Musheno M, et al. Exploring the cognitive and affective capacities of child mediators in a “successful” inner-city peer mediation program. Mediat Q. 1998;15(4):289-302. Excluded; Outcome is not violence.
Loper A B, Cornell D G. Homicide by juvenile girls. J Child Fam Stud. 1996;5(3):323-36. Excluded; Not addressing they key questions.
Loper A B, Hoffschmidt S J, Ash E. Personality features and characteristics of violent events committed by juvenile offenders. Behav Sci Law. 2001;19(1):81-96. Excluded; Data not abstractable. [pmid: 11241682].
Lopez V A, Emmer E T. Adolescent male offenders: A grounded theory study of cognition, emotion, and delinquent crime contexts. Crim Justice Behav. 2000;27(3):292-311. Excluded; Not a research study.
Lopez V A, Emmer E T. Influences of beliefs and values on male adolescents' decision to commit violent offenses. Psychol Men Masc. 2002;3(1):28-40. Excluded; Outcome is not violence.
Losada-Paisey G. Use of the MMPI-A to assess personality of juvenile male delinquents who are sex offenders and nonsex offenders. Psychol Rep. 1998;83(1):115-22. Excluded; Not addressing they key questions. [pmid: 9775669].
Loskota M. G is for gangsta. Understanding gangs in Minnesota. Minn Med. 1998;81(4):28-32. Excluded; Not a research study. [pmid: 9577535].
Lowenstein L F. Bullying: An intensive and multi-dimensional treatment approach in a therapeutic community. Educ Today. 1995;45(1):19-24. Excluded; Not a U.S. study.
Lowenstein L F. Perception and accuracy of perception by bullying children of potential victims. Educ Today. 1995;45(2):28-31. Excluded; Data not abstractable.
Lowry R, Cohen L R, Modzeleski W, et al. School violence, substance use, and availability of illegal drugs on school property among US high school students. J Sch Health. 1999;69(9):347-55. Excluded; Study design not used. [pmid: 10633319].
Lowry R, Powell K E, Kann L, et al. Weapon-carrying, physical fighting, and fight-related injury among U.S. adolescents. Am J Prev Med. 1998;14(2):122-9. Excluded; Study design not used. [pmid: 9631164].
Luengo M A, Otero J M, Carrillo-de-la-Pena M T, et al. Dimensions of antisocial behaviour in juvenile delinquency: A study of personality variables. Psychol Crime Law. 1994;1(1):27-37. Excluded; Not a U.S. study.
Luiselli J K, Arons M, Marchese N, et al. Incidence of law-violating behavior in a community sample of children and adolescents with traumatic brain injury. Int J Offender Ther Comp Criminol. 2000;44(6):647-56. Excluded; Data not abstractable.
Lurie S. Child psychiatrists address problem of youth violence. JAMA. 1999;282(20):1906-7. Excluded; Not a research study. [pmid: 10612311].
Lykken D T. The causes and costs of crime and a controversial cure. J Pers. 2000;68(3):559-605. Excluded; Not a research study. [pmid: 10831312].
Lyons J S, Schaefer K. Mental health and dangerousness: Characteristics and outcomes of children and adolescents in residential placements. J Child Fam Stud. 2000;9(1):67-73. Excluded; Data not abstractable.
Lysaker P H, Wright D E, Clements C A, et al. Neurocognitive and psychosocial correlates of hostility among persons in a post-acute phase of schizophrenia spectrum disorders. Compr Psychiatry. 2002;43(4):319-24. Excluded; Age of study population greater than 17 years. [pmid: 12107869].
Ma X. Bullying and being bullied: To what extent are bullies also victims?. Am Educ Res J. 2001;38(2):351-70. Excluded; Not a U.S. study.
Macgowan M J. An evaluation of a dating violence prevention program for middle school students. Violence Vict. 1997;12(3):223-35. Excluded; Outcome is not violence. [pmid: 9477538].
MacKinnon-Lewis C, Lofquist A. Antecedents and consequences of boys' depression and aggression: Family and school linkages. J Fam Psychol. 1996;10(4):490-500. Excluded; Study does not focus on youth as perpetrators.
Madan A, Beech D J, Flint L. Drugs, guns, and kids: the association between substance use and injury caused by interpersonal violence. J Pediatr Surg. 2001;36(3):440-2. Excluded; Study does not focus on youth as perpetrators. [pmid: 11226991].
Madsen P. Drive-by shootings in Los Angeles. N Engl J Med. 1994;330(25):1833. Excluded; Not a research study. [pmid: 8190173].
Malek M K, Chang B H, Davis T C. Self-reported characterization of seventh-grade students' fights. J Adolesc Health. 1998;23(2):103-9. Excluded; Not addressing they key questions. [pmid: 9714173].
Malek M K, Chang B H, Davis T C. Fighting and weapon-carrying among seventh-grade students in Massachusetts and Louisiana. J Adolesc Health. 1998;23(2):94-102. Excluded; Study design not used. [pmid: 9714173].
Males M. Youth behavior: subcultural effect or mirror of adult behavior?. J Sch Health. 1990;60(10):505-8. Excluded; Not a research study. [pmid: 2283870].
Males M. California trends reveal teenage violence myths. Am J Public Health. 1998;88(7):1123. Excluded; Not a research study. [pmid: 9663169].
Males M A. America's youth violence hoax. Lancet. 1999;354(9189):1563-4. Excluded; Not a research study. [pmid: 10551535].
Malik S, Sorenson S B, Aneshensel C S. Community and dating violence among adolescents: perpetration and victimization. J Adolesc Health. 1997;21(5):291-302. Excluded; Study design not used. [pmid: 9358292].
Malmquist C P. Depression in homicidal adolescents. Bull Am Acad Psychiatry Law. 1990;18(1):23-36. Excluded; Outcome is not violence. [pmid: 2328331].
Malone R P, Bennett D S, Luebbert J F, et al. Aggression classification and treatment response. Psychopharmacol Bull. 1998;34(1):41-5. Excluded; Outcome is not violence. [pmid: 9564197].
Malone R P, Delaney M A, Leubbert J F, et al. A double-blind placebo-controlled study of lithium in hospitalized aggressive children and adolescents with conduct disorder. Arch Gen Psychiatry. 2000;57(7):649-54. Excluded; Duplicated citation or findings. [pmid: 10891035].
Malone R P, Luebbert J, Pena-Ariet M, et al. The Overt Aggression Scale in a study of lithium in aggressive conduct disorder. Psychopharmacol Bull. 1994;30(2):215-8. Excluded; Data not abstractable. [pmid: 7831458].
Malone R P, Luebbert J F, Delaney M A, et al. Nonpharmacological response in hospitalized children with conduct disorder. J Am Acad Child Adolesc Psychiatry. 1997;36(2):242-7. Excluded; Data not abstractable. [pmid: 9031577].
Malpique C, Barrias P, Morais L, et al. Violence and alcoholism in the family: How are the children affected?. Alcohol Alcohol. 1998;33(1):42-6. Excluded; Outcome is not violence. [pmid: 9539176].
Manning J T, Wood D. Fluctuating asymmetry and aggression in boys. Hum Nat. 1998;9(1):53-65. Excluded; Not a U.S. study.
Marans S, Berkowitz S J, Cohen D J. Police and mental health professionals. Collaborative responses to the impact of violence on children and families. Child Adolesc Psychiatr Clin N Am. 1998;7(3):635-51. Excluded; Not a research study. [pmid: 9894059].
Marcelle D R, Melzer-Lange M D. Project UJIMA: working together to make things right. WMJ. 2001;100(2):22-5. Excluded; Study does not focus on youth as perpetrators. [pmid: 11419365].
Marciniak L M. Adolescent attitudes toward victim precipitation of rape. Violence Vict. 1998;13(3):287-300. Excluded; Outcome is not violence. [pmid: 9836415].
Marcus B A, Vollmer T R, Swanson V, et al. An experimental analysis of aggression. Behav Modif. 2001;25(2):189-213. Excluded; Study does not focus on youth as perpetrators. [pmid: 11317634].
Marcus N E, Lindahl K M, Malik N M. Interparental conflict, children's social cognitions, and child aggression: A test of a mediational model. J Fam Psychol. 2001;15(2):315-33. Excluded; Data not abstractable. [pmid: 11458636].
Marcus R F. A gender-linked exploratory factor analysis of antisocial behavior in young adolescents. Adolescence. 1999;34(133):33-46. Excluded; Outcome is not violence. [pmid: 10234365].
Marcus R F, Gray L. Close relationships of violent and nonviolent African American delinquents. Violence Vict. 1998;13(1):31-46. Excluded; Study design not used. [pmid: 9650244].
Margolin A, Youga J, Ballou M. Voices of violence: A study of male adolescent aggression. J Humanist Educ Dev. 2002;41(2):215-31. Excluded; Outcome is not violence.
Margolin L, Craft J L. Child abuse by adolescent caregivers. Child Abuse Negl. 1990;14(3):365-73. Excluded; Study design not used. [pmid: 2207805].
Marlowe M, Schneider H G, Bliss L B. Hair mineral analysis in emotionally disturbed and violence prone children. Int J Biosoc Med Res. 1991;13(2):169-79. Excluded; Study does not focus on youth as perpetrators.
Marsh H W, Parada R H, Yeung A S, et al. Aggressive school troublemakers and victims: A longitudinal model examining the pivotal role of self-concept. J Educ Psychol. 2001;93(2):411-9. Excluded; Outcome is not violence.
Marsh T Y, Cornell D G. The contribution of student experiences to understanding ethnic differences in high-risk behaviors at school. Behav Disord. 2001;26(2):152-63. Excluded; Study design not used.
Marshall JE. Street Soldiers: violence prevention over the airwaves, a phenomenon. J Health Care Poor Underserved 1995;6(2):246–51; Discussion 52–3. Excluded; Not a research study.
Martin C A, Milich R, Martin W R, et al. Gender differences in adolescent psychiatric outpatient substance use: associated behaviors and feelings. J Am Acad Child Adolesc Psychiatry. 1997;36(4):486-94. Excluded; Data not abstractable. [pmid: 9100423].
Martin C S, Earleywine M, Blackson T C, et al. Aggressivity, inattention, hyperactivity, and impulsivity in boys at high and low risk for substance abuse. J Abnorm Child Psychol. 1994;22(2):177-203. Excluded; Study does not focus on youth as perpetrators. [pmid: 8064028].
Martin J L, Ross H S. Do mitigating circumstances influence family reactions to physical aggression?. Child Dev. 1996;67(4):1455-66. Excluded; Outcome is not violence. [pmid: 8890494].
Martin S E, Bryant K. Gender differences in the association of alcohol intoxication and illicit drug abuse among persons arrested for violent and property offenses. Journal of Substance Abuse. 2001;13(4):563-81. Excluded; Age of study population greater than 17 years. [pmid: 11775083].
Martin S E, Bryant K, Fitzgerald N. Self-reported alcohol use and abuse by arrestees in the 1998 Arrestee Drug Abuse Monitoring Program. Alcohol Res Health. 2001;25(1):72-9. Excluded; Age of study population greater than 17 years. [pmid: 11496970].
Marty F. Linking work: from violence to subjectivization. Am J Psychoanal. 2002;62(3):255-72. Excluded; Not a research study. [pmid: 12357682].
Mason J O. Forum on youth violence in minority communities. Prevention of violence: a public health commitment. Public Health Rep. 1991;106(3):265-8. Excluded; Not a research study. [pmid: 1910180].
Mason J O. The dimensions of an epidemic of violence. Public Health Rep. 1993;108(1):1-3. Excluded; Not a research study. [pmid: 8434084].
Matthys W, Cuperus J M, Van Engeland H. Deficient social problem-solving in boys with ODD/CD, with ADHD, and with both disorders. J Am Acad Child Adolesc Psychiatry. 1999;38(3):311-21. Excluded; Outcome is not violence. [pmid: 10087693].
Matykiewicz L, La Grange L, Vance P, et al. Adjudicated adolescent males: Measures of urinary 5-hydroxyindoleacetic acid and reactive hypoglycemia. Pers Individ Dif. 1997;22(3):327-32. Excluded; Outcome is not violence.
Maughan B, Pickles A, Rowe R, et al. Developmental trajectories of aggressive and non-aggressive conduct problems. J Quant Criminol. 2000;16(2):199-221. Excluded; Data not abstractable.
Maxfield M G, Widom C S. The cycle of violence. Revisited 6 years later. Arch Pediatr Adolesc Med. 1996;150(4):390-5. Excluded; Duplicated citation or findings. [pmid: 8634734].
McBurnett K, Harris S M, Swanson J M, et al. Neuropsychological and psychophysiological differentiation of inattention/overactivity and aggression/defiance symptom groups. J Clin Child Psychol. 1993;22(2):165-71. Excluded; Study does not focus on youth as perpetrators.
McBurnett K, Lahey B B, Rathouz P J, et al. Low salivary cortisol and persistent aggression in boys referred for disruptive behavior. Arch Gen Psychiatry. 2000;57(1):38-43. Excluded; Outcome is not violence. [pmid: 10632231].
McCabe K M, Hough R, Wood P A, et al. Childhood and adolescent onset conduct disorder: a test of the developmental taxonomy. J Abnorm Child Psychol. 2001;29(4):305-16. Excluded; Data not abstractable. [pmid: 11523836].
McCafferty C. Adolescent homicide. No quick fixes. Minn Med. 1998;81(11):25-6. Excluded; Not a research study. [pmid: 9842232].
McCarthy-Tucker S, Gold A, Garcia E. Effects of anger management training on aggressive behavior in adolescent boys. J Offender Rehabil. 1999;29(34):129-41. Excluded; Outcome is not violence.
McCloskey L A, Lichter E L. The contribution of marital violence to adolescent aggression across different relationships. J Interpers Violence. 2003;18(4):390-412. Excluded; Duplicated citation or findings.
McColloch M A, Gilbert D G, Johnson S. Effects of situational variables on the interpersonal behavior of families with an aggressive adolescent. Pers Individ Dif. 1990;11(1):1-11. Excluded; Outcome is not violence.
McCormick K F. Corporal punishment and violence. Arch Fam Med. 1992;1(2):203-4. Excluded; Not a research study. [pmid: 1341595].
McCurrie T F. White racist extremist gang members: A behavioral profile. J Gang Res. 1998;5(2):51-60. Excluded; Not a research study.
McElroy S L. Recognition and treatment of DSM-IV intermittent explosive disorder. J Clin Psychiatry. 1999;60(Suppl 15):12-6. Excluded; Study does not focus on youth as perpetrators. [pmid: 10418808].
McFarlane J M, Groff J Y, O'Brien J A, et al. Behaviors of children who are exposed and not exposed to intimate partner violence: an analysis of 330 black, white, and Hispanic children. Pediatrics. 2003;112(3 Pt 1):E202-7. Excluded; Outcome is not violence. [pmid: 12949313].
McGaha J E, Leoni E L. Family violence, abuse, and related family issues of incarcerated delinquents with alcoholic parents compared to those with nonalcoholic parents. Adolescence. 1995;30(118):473-82. Excluded; Outcome is not violence. [pmid: 7676881].
McGee J P, DeBernardo C R. The classroom avenger: A behavioral profile of school based shootings. Forensic Exam. 1999;8(56):16-8. Excluded; Not a research study.
McGee R A, Wolfe D A, Wilson S K. Multiple maltreatment experiences and adolescent behavior problems: adolescents' perspectives. Dev Psychopathol. 1997;9(1):131-49. Excluded; Outcome is not violence. [pmid: 9089128].
McGee Z T, Davis B L, Brisbane T, et al. Urban stress and mental health among African-American youth: assessing the link between exposure to violence, problem behavior, and coping strategies. J Cult Divers. 2001;8(3):94-104. Excluded; Outcome is not violence. [pmid: 11855219].
McGloin J M, Widom C S. Resilience among abused and neglected children grown up. Dev Psychopathol. 2001;13(4):1021-38. Excluded; Outcome is not violence. [pmid: 11771905].
McGuffin P W. The effect of timeout duration on frequency of aggression in hospitalized children with conduct disorders. Behav Resid Treat. 1991;6(4):279-88. Excluded; Study does not focus on youth as perpetrators.
McIntyre T, Cowell K. Effects of various music conditions on multiple dimensions of behavior of emotionally disturbed adolescents. Psychol Rep. 1991;69(3, Pt 1):1007-8. Excluded; Data not abstractable. [pmid: 1784647].
McKenney A, Dattilo J. Effects of an intervention within a sport context on the prosocial behavior and antisocial behavior of adolescents with disruptive behavior disorders. Ther Recreation J. 2001;35(2):123-40. Excluded; Data not abstractable.
McKeown R E, Jackson K L, Valois R F. The frequency and correlates of violent behaviors in a statewide sample of high school students. Fam Community Health. 1998;20(4):38-53. Excluded; Study design not used.
Mclaughlin C R, Daniel J, Joost T F. The relationship between substance use, drug selling, and lethal violence in 25 juvenile murderers. J Forensic Sci. 2000;45(2):349-53. Excluded; Study design not used. [pmid: 10782954].
McLaughlin C R, Reiner S M, Reams P N, et al. Factors associated with parenting among incarcerated juvenile offenders. Adolescence. 1999;34(136):665-70. Excluded; Outcome is not violence. [pmid: 10730691].
McLaughlin C R, Reiner S M, Smith B W, et al. Firearm injuries among Virginia juvenile drug traffickers, 1992 through 1994. Am J Public Health. 1996;86(5):751-2. Excluded; Not a research study. [pmid: 8629738]. [pmcid: 1380497].
McNeal C, Amato P R. Parents' marital violence: Long-term consequences for children. J Fam Issues. 1998;19(2):123-39. Excluded; Age of study population greater than 17 years.
McNeil D E, Binder R L. The relationship between acute psychiatric symptoms, diagnosis, and short-term risk of violence. Hosp Community Psychiatry. 1994;45(2):133-7. Excluded; Age of study population greater than 17 years. [pmid: 8168791].
McNiel D E, Binder R L. Clinical assessment of the risk of violence among psychiatric inpatients. Am J Psychiatry. 1991;148(10):1317-21. Excluded; Age of study population greater than 17 years. [pmid: 1897611].
McNiel D E, Binder R L. Clinical assessment of the risk of violence among psychiatric inpatients. Am J Psychiatry. 1991;148(10):1317-21. Excluded; Duplicated citation or findings. [pmid: 1897611].
McNiel D E, Eisner J P, Binder R L. The relationship between command hallucinations and violence. Psychiatr Serv. 2000;51(10):1288-92. Excluded; Age of study population greater than 17 years. [pmid: 11013329].
Meehan P J, O'Carroll P W. Gangs, drugs, and homicide in Los Angeles. Am J Dis Child. 1992;146(6):683-7. Excluded; Study does not focus on youth as perpetrators. [pmid: 1595623].
Meller W H, Borchardt C M. Comorbidity of major depression and conduct disorder. J Affect Disord. 1996;39(2):123-6. Excluded; Outcome is not violence. [pmid: 8827421].
Meloy J R, Gacono G B, Kenney L. A Rorschach investigation of sexual homicide. J Pers Assess. 1994;62(1):58-67. Excluded; Age of study population greater than 17 years. [pmid: 8138887].
Meloy J R, Hempel A G, Mohandie K, et al. Offender and offense characteristics of a nonrandom sample of adolescent mass murderers. J Am Acad Child Adolesc Psychiatry. 2001;40(6):719-28. Excluded; Not addressing they key questions. [pmid: 11392351].
Menard S, Mihalic S. The tripartite conceptual framework in adolescence and adulthood: Evidence from a national sample. J Drug Issues. 2001;31(4):905-39. Excluded; Data not abstractable.
Menken M. Grappling with the enigma of violence. An educational approach. Arch Neurol. 1992;49(6):592-4. Excluded; Not a research study. [pmid: 1524521].
Mercy J A, Potter L B. Combining analysis and action to solve the problem of youth violence. Am J Prev Med. 1996;12(5 Suppl):1-2. Excluded; Not a research study. [pmid: 8909618].
Merrick J, Kessel S, Morad M, et al. Trends in school violence. Int J Adolesc Med Health. 2002;14(1):77-80. Excluded; Not a research study. [pmid: 12476904].
Merrill L L, Hervig L K, Milner J S. Childhood parenting experiences, intimate partner conflict resolution, and adult risk for child physical abuse. Child Abuse Negl. 1996;20:1049-65. Excluded; Age of study population greater than 17 years. [pmid: 8958455].
Merrill L L, Thomsen C J, Gold S R, et al. Childhood abuse and premilitary sexual assault in male navy recruits. J Consult Clin Psychol. 2001;69(2):252-61. Excluded; Age of study population greater than 17 years. [pmid: 11777126].
Messer S C, Gross A M. Childhood depression and aggression: A covariance structure analysis. Behav Res Ther. 1994;32(6):663-77. Excluded; Outcome is not violence. [pmid: 8085997].
Metzler C W, Noell J, Biglan A, et al. The social context for risky sexual behavior among adolescents. J Behav Med. 1994;17(4):419-38. Excluded; Outcome is not violence. [pmid: 7966262].
Mezzich A C. Diagnostic formulations for violent delinquent adolescents. J Psychiatry Law. 1990;18(1):165-90. Excluded; Not addressing they key questions.
Mezzich A C, Coffman G, Mezzich J E. A typology of violent delinquent adolescents. J Psychiatry Law. 1991;19(12):63-78. Excluded; Not addressing they key questions.
Miccio-Fonseca L C. Comparative differences in the psychological histories of sex offenders, victims, and their families. J Offender Rehabil. 1996;23(34):71-83. Excluded; Study does not focus on youth as perpetrators.
Miccio-Fonseca L C. Adult and adolescent female sex offenders: Experiences compared to other female and male sex offenders. J Psychol Human Sex. 2000;11(3):75-88. Excluded; Age of study population greater than 17 years.
Middleton M B, Cartledge G. The effects of social skills instruction and parental involvement on the aggressive behaviors of African American males. Behav Modif. 1995;19(2):192-210. Excluded; Study does not focus on youth as perpetrators. [pmid: 7726817].
Mihalic S W, Elliott D. A social learning theory model of marital violence. J Fam Violence. 1997;12(1):21-47. Excluded; Age of study population greater than 17 years.
Miller D B. Treatment of adolescent interpersonal violence: A cognitive-behavioral group approach. J Child Adolesc Group Ther. 1995;5(4):191-200. Excluded; Not a research study.
Miller F, Webb J. Theoretical perspectives on violence and youth. Med Health R I. 1996;79(7):261-3. Excluded; Not a research study. [pmid: 8797328].
Miller J M, DiIorio C, Dudley W. Parenting style and adolescent's reaction to conflict: is there a relationship?. J Adolesc Health. 2002;31(6):463-8. Excluded; Not a research study. [pmid: 12457579].
Miller K S, Knutson J F. Reports of severe physical punishment and exposure to animal cruelty by inmates convicted of felonies and by university students. Child Abuse Negl. 1997;21(1):59-82. Excluded; Age of study population greater than 17 years. [pmid: 9023023].
Miller M, Azrael D, Hemenway D. Firearm availability and unintentional firearm deaths, suicide, and homicide among 5–14 year olds. J Trauma 2002;52(2):267–74; Discussion 74–5. Excluded; Study does not focus on youth as perpetrators.
Miller-Johnson S, Coie J D, Maumary-Gremaud A, et al. Peer rejection and aggression and early starter models of conduct disorder. J Abnorm Child Psychol. 2002;30(3):217-30. Excluded; Study does not focus on youth as perpetrators. [pmid: 12041708].
Millstein S G, Irwin C E, Adler N E, et al. Health-risk behaviors and health concerns among young adolescents. Pediatrics. 1992;89(3):422-8. Excluded; Outcome is not violence. [pmid: 1741215].
Minden J, Henry D B, Tolan P H, et al. Urban boys' social networks and school violence. Prof Sch Couns. 2000;4(2):95-104. Excluded; Study design not used.
Mitka M. Hospital study offers hope of changing lives prone to violence. JAMA. 2002;287(5):576-7. Excluded; Not a research study. [pmid: 12479741].
Moffit T E, Caspi A, Dickson N, et al. Childhood-onset versus adolescent-onset antisocial conduct problems in males: Natural history from ages 3 to 18 years. Dev Psychopathol. 1996;8(2):399-424. Excluded; Outcome is not violence.
Moise J F, Huesmann L R. Television violence viewing and aggression in females. Ann N Y Acad Sci. 1996;794:380-3. Excluded; Study does not focus on youth as perpetrators. [pmid: 8853622].
Molidor C, Tolman R M. Gender and contextual factors in adolescent dating violence. Violence Against Women. 1998;4(2):180-94. Excluded; Study does not focus on youth as perpetrators. [pmid: 12295440].
Molidor C E. Gender differences of psychological abuse in high school dating relationships. Child Adolesc Social Work J. 1995;12(2):119-34. Excluded; Outcome is not violence.
Molidor C E. Female gang members: A profile of aggression and victimization. Soc Work. 1996;41(3):251-7. Excluded; Outcome is not violence. [pmid: 8936081].
Molliconi S A, Runyan C W. Detecting domestic violence. A pilot study of family practitioners. N C Med J. 1996;57(3):136-8. Excluded; Outcome is not violence. [pmid: 8935358].
Mooney A, Creeser R, Blatchford P. Children's views on teasing and fighting in junior schools. Educ Res. 1991;33(2):103-12. Excluded; Not a U.S. study.
Moore M H. Violence prevention: criminal justice or public health?. Health Aff (Millwood). 1993;12(4):34-45. Excluded; Not a research study. [pmid: 8125447].
Moretti M M, Holland R, McKay S. Self-other representations and relational and overt aggression in adolescent girls and boys. Behav Sci Law. 2001;19(1):109-26. Excluded; Not a U.S. study. [pmid: 11241684].
Moretti M M, Holland R, Peterson S. Long term outcome of an attachment-based program for conduct disorder. Can J Psychiatry. 1994;39(6):360-70. Excluded; Not a U.S. study. [pmid: 7987773].
Moriarty N, Stough C, Tidmarsh P, et al. Deficits in emotional intelligence underlying adolescent sex offending. J Adolesc. 2001;24(6):743-51. Excluded; Not a U.S. study. [pmid: 11790054].
Morris R E, Anderson M M, Knox G W. Incarcerated adolescents' experiences as perpetrators of sexual assault. Arch Pediatr Adolesc Med. 2002;156(8):831-5. Excluded; Study design not used. [pmid: 12144376].
Morrison E F. A coercive interactional style as an antecedent to aggression in psychiatric patients. Res Nurs Health. 1992;15(6):421-31. Excluded; Age of study population greater than 17 years. [pmid: 1448573].
Moscovitz H, Degutis L, Bruno G R, et al. Emergency department patients with assault injuries: previous injury and assault convictions. Ann Emerg Med. 1997;29(6):770-5. Excluded; Study does not focus on youth as perpetrators. [pmid: 9174523].
Moscovitz H, Milzman D, Haywood Y. The Washington, DC, Youth Curfew: effect on transports of injured youth and homicides. Prehosp Emerg Care. 2000;4(4):294-8. Excluded; Outcome is not violence. [pmid: 11045406].
Moss H B, Mezzich A, Yao J K, et al. Aggressivity among sons of substance-abusing fathers: Association with psychiatric disorder in the father and son, paternal personality, pubertal development, and socioeconomic status. Am J Drug Alcohol Abuse. 1995;21(2):195-208. Excluded; Data not abstractable. [pmid: 7639206].
Mulder R T, Joyce P R. Relationship of temperament and behaviour measures to the prolactin response to fenfluramine in depressed men. Psychiatry Res. 2002;109(3):221-8. Excluded; Outcome is not violence. [pmid: 11959359].
Mullen P E, Pathe M, Purcell R, et al. Study of stalkers. Am J Psychiatry. 1999;156(8):1244-9. Excluded; Not a U.S. study. [pmid: 10450267].
Mulvey E P, Lidz C W. Clinical prediction of violence as a conditional judgment. Soc Psychiatry Psychiatr Epidemiol. 1998;33(Suppl 1):s107-13. Excluded; Study does not focus on youth as perpetrators. [pmid: 9857788].
Munroe R L, Hulefeld R, Rodgers J M, et al. Aggression among children in four cultures. Cross Cult Res. 2000;34(1):3-25. Excluded; Not a U.S. study.
Muris P, Merckelbach H, Walczak S. Aggression and threat perception abnormalities in children with learning and behavior problems. Child Psychiatry Hum Dev. 2002;33(2):147-63. Excluded; Not a U.S. study. [pmid: 12462352].
Murray N G, Kelder S H, Parcel G S, et al. Padres Trabajando por la Paz: a randomized trial of a parent education intervention to prevent violence among middle school children. Health Educ Res. 1999;14(3):421-6. Excluded; Outcome is not violence. [pmid: 10539232].
Murrey G J, Briggs D, Davis C. Psychopathic disordered, mentally ill, and mentally handicapped sex offenders: a comparative study. Med Sci Law. 1992;32(4):331-6. Excluded; Not addressing they key questions. [pmid: 1435130].
Muscari M E, Phillips C, Bears T. Health beliefs and behaviors in rural high school juniors. Pediatr Nurs. 1997;23(4):380-9. Excluded; Outcome is not violence. [pmid: 9282050].
Myaard M J, Crawford C, Jackson M, et al. Applying behavior analysis within the wraparound process: A multiple baseline study. J Emot Behav Disord. 2000;8(4):216-29. Excluded; Not a research study.
Myeroff R, Mertlich G, Gross J. Comparative effectiveness of holding therapy with aggressive children. Child Psychiatry Hum Dev. 1999;29(4):303-13. Excluded; Data not abstractable. [pmid: 10422354].
Myers W C, Blashfield R. Psychopathology and personality in juvenile sexual homicide offenders. J Am Acad Psychiatry Law. 1997;25(4):497-508. Excluded; Not addressing they key questions. [pmid: 9460037].
Myers W C, Burgess A W, Nelson J A. Criminal and behavioral aspects of juvenile sexual homicide. J Forensic Sci. 1998;43(2):340-7. Excluded; Not addressing they key questions. [pmid: 9544541].
Myers W C, Kemph J P. DSM-III-R classification of murderous youth: help or hindrance?. J Clin Psychiatry. 1990;51(6):239-42. Excluded; Not addressing they key questions. [pmid: 2347861].
Myers W C, Monaco L. Anger experience, styles of anger expression, sadistic personality disorder, and psychopathy in juvenile sexual homicide offenders. J Forensic Sci. 2000;45(3):698-701. Excluded; Not addressing they key questions. [pmid: 10855983].
Myers W C, Mutch P J. Language disorders in disruptive behavior disordered homicidal youth. J Forensic Sci. 1992;37(3):919-22. Excluded; Not addressing they key questions. [pmid: 1629686].
Myers W C, Scott K. Psychotic and conduct disorder symptoms in juvenile murderers. Homicide Stud. 1998;2(2):160-75. Excluded; Study design not used.
Myers W C, Scott K, Burgess A W, et al. Psychopathology, biopsychosocial factors, crime characteristics, and classification of 25 homicidal youths. J Am Acad Child Adolesc Psychiatry. 1995;34(11):1483-9. Excluded; Not addressing they key questions. [pmid: 8543516].
Mynard H, Joseph S. Bully/victim problems and their association with Eysenck's personality dimensions in 8 to 13 year-olds. Br J Educ Psychol. 1997;67(1):51-4. Excluded; Not a U.S. study. [pmid: 9114731].
Myner J, Santman J, Cappelletty G G, et al. Variables related to recidivism among juvenile offenders. Int J Offender Ther Comp Criminol. 1998;42(1):65-80. Excluded; Age of study population greater than 17 years.
Nadel H, Spellmann M, Alvarez-Canino T, et al. The cycle of violence and victimization: a study of the school-based intervention of a multidisciplinary youth violence-prevention program. Am J Prev Med. 1996;12(5 Suppl):109-19. Excluded; Not addressing they key questions. [pmid: 8909631].
Nagin D, Tremblay R E. Trajectories of boys' physical aggression, opposition, and hyperactivity on the path to physically violent and nonviolent juvenile delinquency. Child Dev. 1999;70(5):1181-96. Excluded; Not a U.S. study. [pmid: 10546339].
Nagy S, DiClemente R, Adcock A G. Adverse factors associated with forced sex among southern adolescent girls. Pediatrics. 1995;96(5 Pt 1):944-6. Excluded; Outcome is not violence. [pmid: 7478840].
Nagy S, Dunn M S. Alcohol behaviors and deviant behaviors among adolescents in a rural state. J Alcohol Drug Educ. 1999;44(3):1-9. Excluded; Study does not focus on youth as perpetrators.
Nansel T R, Overpeck M D, Haynie D L, et al. Relationships between bullying and violence among US youth. Arch Pediatr Adolesc Med. 2003;157(4):348-53. Excluded; Duplicated citation or findings. [pmid: 12695230].
Nansel T R, Overpeck M D, Haynie D L, et al. Relationships between bullying and violence among US youth. Arch Pediatr Adolesc Med. 2003;157(4):348-53. Excluded; Study design not used. [pmid: 12695230].
Nathanson A I. Parents versus peers: Exploring the significance of peer mediation of antisocial television. Commun Res. 2001;28(3):251-74. Excluded; Age of study population greater than 17 years.
Nelson B V, Patience T H, MacDonald D C. Adolescent risk behavior and the influence of parents and education. J Am Board Fam Pract. 1999;12(6):436-43. Excluded; Outcome is not violence. [pmid: 10612361].
Nelson C, Valliant P M. Personality dynamics of adolescent boys where the father was absent. Percept Mot Skills. 1993;76(2):435-43. Excluded; Outcome is not violence. [pmid: 8483653].
Nevin R. How lead exposure relates to temporal changes in IQ, violent crime, and unwed pregnancy. Environ Res. 2000;83(1):1-22. Excluded; Age of study population greater than 17 years. [pmid: 10845777].
New M J C, Stevenson J, Skuse D. Characteristics of mothers of boys who sexually abuse. Child Maltreat. 1999;4(1):21-31. Excluded; Not a U.S. study.
Newhill C E, Mulvey E P, Lidz C W. Characteristics of violence in the community by female patients seen in a psychiatric emergency service. Psychiatr Serv. 1995;46(8):785-9. Excluded; Age of study population greater than 17 years. [pmid: 7583478].
Nicol R, Stretch D, Whitney I. Mental health needs and services for severely troubled and troubling young people including young offenders in an N.H.S. region. J Adolesc. 2000;23(3):243-61. Excluded; Outcome is not violence. [pmid: 10837105].
Nijman H L I, Rector G. Crowding and aggression on inpatient psychiatric wards. Psychiatr Serv. 1999;50(6):830-1. Excluded; Not a U.S. study. [pmid: 10375156].
Ninness H A C, Ellis J, Miller W B, et al. The effect of a self-management training package on the transfer of aggression control procedures in the absence of supervision. Behav Modif. 1995;19(4):464-90. Excluded; Not a research study. [pmid: 7487866].
Nock M K, Kazdin A E. Parent-directed physical aggression by clinic-referred youths. J Clin Child Adolesc Psychol. 2002;31(2):193-205. Excluded; Study does not focus on youth as perpetrators. [pmid: 12056103].
Nolin M J, Davies E, Chandler K. Student victimization at school. J Sch Health. 1996;66(6):216-21. Excluded; Study does not focus on youth as perpetrators. [pmid: 8866396].
Northrop D, Hamrick K. Weapons and minority youth violence. Public Health Rep. 1991;106(3):274-5. Excluded; Not a research study. [pmid: 1905046].
Northrop D, Jacklin B, Cohen S, et al. Violence prevention strategies targeted towards high-risk minority youth. Public Health Rep. 1991;106(3):272-4. Excluded; Not a research study. [pmid: 1905045].
Nugent W R, Bruley C, Allen P. The effects of aggression replacement training on antisocial behavior in a runaway shelter. Res Soc Work Pract. 1998;8(6):637-56. Excluded; Outcome is not violence.
Nugent W R, Bruley C, Allen P. The effects of Aggression Replacement Training on male and female antisocial behavior in a runaway shelter. Res Soc Work Pract. 1999;9(4):466-82. Excluded; Outcome is not violence.
Nutter D E, Kearns M E. Patterns of exposure to sexually explicit material among sex offenders, child molesters, and controls. J Sex Marital Ther. 1993;19(1):77-85. Excluded; Age of study population greater than 17 years. [pmid: 8468712].
O'Brien RM, Stockard J, Isaacson L. The enduring effects of cohort characteristics on age-specific homicide rates, 1960-1995. AJS 1999;American Journal of Sociology; 104(4):1061–95. Excluded; Not addressing they key questions.
O'Connor B P, Dvorak T. Conditional associations between parental behavior and adolescent problems: A search for personality-environment interactions. J Res Pers. 2001;35(1):1-26. Excluded; Not a U.S. study.
O'Donnell L, Cohen S, Hausman A. Forum on youth violence in minority communities. Evaluation of community-based violence prevention programs. Public Health Rep. 1991;106(3):276-7. Excluded; Not a research study. [pmid: 1905048].
O'Keefe J J, Carr A, McQuaid P. Conduct disorder in girls and boys: The identification of distinct psychological profiles. Ir J Psychol. 1998;19(23):368-85. Excluded; Not a U.S. study.
O'Keefe M. Linking marital violence, mother^child/father^child aggression, and child behavior problems. J Fam Violence. 1994;9(1):63-78. Excluded; Study does not focus on youth as perpetrators.
O'Keefe M. The differential effects of family violence on adolescent adjustment. Child Adolesc Social Work J. 1996;13(1):51-68. Excluded; Data not abstractable.
O'Keefe M. Adolescents' exposure to community and school violence: prevalence and behavioral correlates. J Adolesc Health. 1997;20(5):368-76. Excluded; Outcome is not violence. [pmid: 9168384].
O'Keefe M. Predictors of dating violence among high school students. J Interpers Violence. 1997;12(4):546-68. Excluded; Study design not used.
O'Keefe M. Factors mediating the link between witnessing interparental violence and dating violence. J Fam Violence. 1998;13(1):39-57. Excluded; Study design not used.
Olds D, Henderson C R, Kitzman H, et al. Effects of prenatal and infancy nurse home visitation on surveillance of child maltreatment. Pediatrics. 1995;95(3):365-72. Excluded; Outcome is not violence. [pmid: 7862474].
Olds D, Pettitt L M, Robinson J, et al. Reducing risks for antisocial behavior with a program of prenatal and early childhood home visitation. J Community Psychol. 1998;26(1):65-83. Excluded; Not a research study.
O'Leary K D, Malone J, Tyree A. Physical aggression in early marriage: prerelationship and relationship effects. J Consult Clin Psychol. 1994;62(3):594-602. Excluded; Age of study population greater than 17 years. [pmid: 8063986].
Oliver L L, Hall G C N, Neuhaus S M. A comparison of the personality and background characteristics of adolescent sex offenders and other adolescent offenders. Crim Justice Behav. 1993;20(4):359-70. Excluded; Study design not used.
Olweus D. Bully/victim problems in school: Facts and intervention. Eur J Psychol Educ. 1997;12(4):495-510. Excluded; Not a research study.
Omar H A. Adolescent violence as viewed by high school students. Int J Adolesc Med Health. 1999;11(34):153-8. Excluded; Outcome is not violence.
Onwuachi-Saunders C, Forjuoh S N, West P, et al. Child death reviews: a gold mine for injury prevention and control. Inj Prev. 1999;5(4):276-9. Excluded; Study does not focus on youth as perpetrators. [pmid: 10628916].
Orpinas P, Murray N, Kelder S. Parental influences on students' aggressive behaviors and weapon carrying. Health Educ Behav. 1999;26(6):774-87. Excluded; Study design not used. [pmid: 10608570].
Orpinas P, Parcel G S, McAlister A, et al. Violence prevention in middle schools: a pilot evaluation. J Adolesc Health. 1995;17(6):360-71. Excluded; Data not abstractable. [pmid: 8924442].
Orpinas P K, Basen-Engquist K, Grunbaum J A, et al. The co-morbidity of violence-related behaviors with health-risk behaviors in a population of high school students. J Adolesc Health. 1995;16(3):216-25. Excluded; Study design not used. [pmid: 7779832].
Orwin R G, Maranda M, Ellis B. The effectiveness of substance abuse treatment in reducing violent behavior. J Psychopathol Behav Assess. 2000;22(4):309-24. Excluded; Age of study population greater than 17 years.
Osofsky J D. Community-based approaches to violence prevention. J Dev Behav Pediatr. 1997;18(6):405-7. Excluded; Not a research study. [pmid: 9431503].
Pack R P, Wallander J L, Browne D. Health risk behaviors of African American adolescents with mild mental retardation: prevalence depends on measurement method. Am J Ment Retard. 1998;102(4):409-20. Excluded; Outcome is not violence. [pmid: 9475948].
Paikoff R L, Brooks-Gunn J, Warren M P. Effects of girls' hormonal status on depressive and aggressive symptoms over the course of one year. J Youth Adolesc. 1991;20(2):191-215. Excluded; Data not abstractable.
Pakaslahti L, Keltikangas-Jaervinen L. Social acceptance and the relationship between aggressive problem-solving strategies and aggressive behaviour in 14-year-old adolescents. Eur J Personal. 1996;10(4):249-61. Excluded; Not a U.S. study.
Pakaslahti L, Keltikangas-Jaervinen L. The relationships between moral approval of aggression, aggressive problem-solving strategies, and aggressive behavior in 14-yr-old adolescents. J Soc Behav Pers. 1997;12(4):905-24. Excluded; Not a U.S. study.
Pakaslahti L, Keltikangas-Jaervinen L. Types of aggressive behavior among aggressive-preferred, aggressive non-preferred, non-aggressive preferred and non-aggressive non-preferred 14-year-old adolescents. Pers Individ Dif. 1998;24(6):821-8. Excluded; Not a U.S. study.
Pakaslahti L, Spoof I, Asplund-Peltola R-L, et al. Parents' social problem-solving strategies in families with aggressive and non-aggressive girls. Aggress Behav. 1998;24(1):37-51. Excluded; Not a U.S. study.
Pakiz B, Reinherz H Z, Giaconia R M. Early risk factors for serious antisocial behavior at age 21: a longitudinal community study. Am J Orthopsychiatry. 1997;67(1):92-101. Excluded; Age of study population greater than 17 years. [pmid: 9034025].
Palermo M T. Preventing filicide in families with autistic children. Int J Offender Ther Comp Criminol. 2003;47(1):47-57. Excluded; Not a research study. [pmid: 14661382].
Pallone N J, Hennessy J J. Blacks and whites as victims and offenders in aggressive crime in the U.S.: myths and realities. J Offender Rehabil. 1999;30(1/2):1-33. Excluded; Age of study population greater than 17 years.
Palmer E J, Farmer S. Victimizing behaviour among juvenile and young offenders: How different are perpetrators?. J Adolesc. 2002;25(5):469-82. Excluded; Not a U.S. study. [pmid: 12234554].
Palmstierna T, Huitfeldt B, Wistedt B. The relationship of crowding and aggressive behavior on a psychiatric intensive care unit. Hosp Community Psychiatry. 1991;42(12):1237-40. Excluded; Not a U.S. study. [pmid: 1810862].
Palmstierna T, Wistedt B. Changes in the pattern of aggressive behaviour among inpatients with changed ward organization. Acta Psychiatr Scand. 1995;91(1):32-5. Excluded; Age of study population greater than 17 years. [pmid: 7754783].
Paschall M J, Ennett S T, Flewelling R L. Relationships among family characteristics and violent behavior by black and white male adolescents. J Youth Adolesc. 1996;25(2):177-97. Excluded; Study design not used.
Paschall M J, Flewelling R L, Ennett S T. Racial differences in violent behavior among young adults: Moderating and confounding effects. J Res Crime Delinq. 1998;35(2):148-65. Excluded; Age of study population greater than 17 years.
Paschall M J, Hubbard M L. Effects of neighborhood and family stressors on African American male adolescents' self-worth and propensity for violent behavior. J Consult Clin Psychol. 1998;66(5):825-31. Excluded; Data not abstractable. [pmid: 9803701].
Pate R R, Trost S G, Levin S, et al. Sports participation and health-related behaviors among US youth. Arch Pediatr Adolesc Med. 2000;154(9):904-11. Excluded; Study design not used. [pmid: 10980794].
Paterson R, Luntz H, Perlesz A, et al. Adolescent violence towards parents: Maintaining family connections when the going gets tough. Aust N Z J Fam Ther. 2002;23(2):90-100. Excluded; Study does not focus on youth as perpetrators.
Paulson M J, Coombs R H, Landsverk J. Youth who physically assault their parents. J Fam Violence. 1990;5(2):121-33. Excluded; Study design not used.
Pedersen W, Wichstrom L, Blekesaune M. Violent behaviors, violent victimization, and doping agents: A normal population study of adolescents. J Interpers Violence. 2001;16(8):808-32. Excluded; Not a U.S. study.
Pellegrini A D, Long J D. A longitudinal study of bullying, dominance, and victimization during the transition from primary school through secondary school. Br J Dev Psychol. 2002;20(2):259-80. Excluded; Outcome is not violence.
Pellegrini R J, Roundtree T, Camagna T F, et al. On the epidemiology of violent juvenile crime in America: a total arrest-referenced approach. Psychol Rep. 2000;86(3 Pt 2):1171-86. Excluded; Data not abstractable. [pmid: 10932576].
Pepler D, King G, Craig W, et al. The development and evaluation of a multisystem social skills group training program for aggressive children. Child Youth Care Forum. 1995;24(5):297-313. Excluded; Not a U.S. study.
Pepler D J, Craig W M, Roberts W L. Observations of aggressive and nonaggressive children on the school playground. Merrill Palmer Q. 1998;44(1):55-76. Excluded; Not a U.S. study.
Perez D M. Ethnic differences in property, violent, and sex offending for abused and nonabused adolescents. J Crim Justice. 2001;29(5):407-17. Excluded; Study design not used.
Perry C L, Komro K A, Veblen-Mortenson S, et al. The Minnesota DARE PLUS Project: creating community partnerships to prevent drug use and violence. J Sch Health. 2000;70(3):84-8. Excluded; Not a research study. [pmid: 10763475].
Perry C L, Komro K A, Veblen-Mortenson S, et al. A randomized controlled trial of the middle and junior high school D.A.R.E. and D.A.R.E. Plus programs. Arch Pediatr Adolesc Med. 2003;157(2):178-84. Excluded; Duplicated citation or findings. [pmid: 12580689].
Peterson-Badali M, Koegl C J. Juveniles' experiences of incarceration: The role of correctional staff in peer violence. J Crim Justice. 2002;30(1):41-9. Excluded; Not a U.S. study.
Pharris M D. Coming to know ourselves as community through a nursing partnership with adolescents convicted of murder. ANS Adv Nurs Sci. 2002;24(3):21-42. Excluded; Not a research study. [pmid: 11890193].
Phelps C E. Children's responses to overt and relational aggression. J Clin Child Psychol. 2001;30(2):240-52. Excluded; Study does not focus on youth as perpetrators. [pmid: 11393924].
Phillips D R, Schwean V L, Saklofske D H. Treatment effect of a school based cognitive-behavioral program for aggressive children. Can J Sch Psychol. 1997;13(1):60-7. Excluded; Not a U.S. study.
Pickett W, Schmid H, Boyce W F, et al. Multiple risk behavior and injury: an international analysis of young people. Arch Pediatr Adolesc Med. 2002;156(8):786-93. Excluded; Outcome is not violence. [pmid: 12144369].
Pihl R O, Young S N, Harden P, et al. Acute effect of altered tryptophan levels and alcohol on aggression in normal human males. Psychopharmacology (Berl). 1995;119(4):353-60. Excluded; Age of study population greater than 17 years. [pmid: 7480513].
Pillmann F, Rohde A, Ullrich S, et al. Violence, criminal behavior, and the EEG: significance of left hemispheric focal abnormalities. J Neuropsychiatry Clin Neurosci. 1999;11(4):454-7. Excluded; Not a U.S. study. [pmid: 10570757].
Pine D S, Coplan J D, Wasserman G A, et al. Neuroendocrine response to fenfluramine challenge in boys: Associations with aggressive behavior and adverse rearing. Arch Gen Psychiatry. 1997;54(9):839-46. Excluded; Study does not focus on youth as perpetrators. [pmid: 9294375].
Piquero A. Frequency, specialization, and violence in offending careers. J Res Crime Delinq. 2000;37(4):392-418. Excluded; Study design not used.
Piquero A R, Brame R, Mazerolle P. Crime in Emerging Adulthood. Criminology. 2002;40(1):137-69. Excluded; Age of study population greater than 17 years.
Piquero A R, Buka S L. Linking juvenile and adult patterns of criminal activity in the Providence cohort of the National Collaborative Perinatal Project. J Crim Justice. 2002;30(4):259-72. Excluded; Age of study population greater than 17 years.
Piquero A R, MacDonald J M, Parker K F. Race, local life circumstances, and criminal activity. Soc Sci Q. 2002;83(3):654-70. Excluded; Study does not focus on youth as perpetrators.
Pithers W D, Gray A, Busconi A, et al. Caregivers of children with sexual behavior problems: psychological and familial functioning. Child Abuse Negl. 1998;22(2):129-41. Excluded; Outcome is not violence. [pmid: 9504215].
Pittenger J. Domestic abuse: complicated by rural living. Wis Med J. 1997;96(8):22-4. Excluded; Not a research study. [pmid: 9283261].
Pollard J A, Hawkins J D, Arthur M W. Risk and protection: Are both necessary to understand diverse behavioral outcomes in adolescence?. Soc Work Res. 1999;23(3):145-58. Excluded; Data not abstractable.
Pope A W, Bierman K L. Predicting adolescent peer problems and antisocial activities: The relative roles of aggression and dysregulation. Dev Psychol. 1999;35(2):335-46. Excluded; Outcome is not violence. [pmid: 10082005].
Potthoff S J, Bearinger L H, Skay C L, et al. Dimensions of risk behaviors among American Indian youth. Arch Pediatr Adolesc Med. 1998;152(2):157-63. Excluded; Data not abstractable. [pmid: 9491042].
Poulin F, Boivin M. The role of proactive and reactive aggression in the formation and development of boys' friendships. Dev Psychol. 2000;36(2):233-40. Excluded; Not a U.S. study. [pmid: 10749080].
Powell K B. Correlates of violent and nonviolent behavior among vulnerable inner-city youths. Fam Community Health. 1997;20(2):38-47. Excluded; Data not abstractable.
Prentky R A, Knight R A, Lee A F. Risk factors associated with recidivism among extrafamilial child molesters. J Consult Clin Psychol. 1997;65(1):141-9. Excluded; Age of study population greater than 17 years. [pmid: 9103743].
Preski S, Shelton D. The role of contextual, child and parent factors in predicting criminal outcomes in adolescence. Issues Ment Health Nurs. 2001;22(2):197-205. Excluded; Not addressing they key questions. [pmid: 11885223].
Prinstein M J, Boergers J, Spirito A. Adolescents' and their friends' health-risk behavior: Factors that alter or add to peer influence. J Pediatr Psychol. 2001;26(5):287-98. Excluded; Study design not used. [pmid: 11390571].
Prinstein M J, Boergers J, Vernberg E M. Overt and relational aggression in adolescents: Social-psychological adjustment of aggressors and victims. J Community Psychol. 2001;30(4):479-91. Excluded; Outcome is not violence.
Pritchard C, Cox M. The criminality of former “special educational provision” permanently “excluded from school” adolescents as young adults (16–23): costs and practical implications. J Adolesc. 1998;21(5):609-20. Excluded; Not a U.S. study. [pmid: 9799551].
Proimos J, DuRant R H, Pierce J D, et al. Gambling and other risk behaviors among 8th- to 12th-grade students. Pediatrics. 1998;102(2):E23. Excluded; Outcome is not violence. [pmid: 9685469].
Pulkkinen L. Proactive and reactive aggression in early adolescence as precursors to anti- and prosocial behavior in young adults. Aggress Behav. 1996;22(4):241-57. Excluded; Not a U.S. study.
Pulkkinen L, Pitkaenen T. Continuities in aggressive behavior from childhood to adulthood. Aggress Behav. 1993;19(4):249-63. Excluded; Not a U.S. study.
Putnam F W, Hornstein N, Peterson G. Clinical Phenomenology of Child and Adolescent Dissociative Disorders: Gender and Age Effects. Child Adolesc Psychiatr Clin N Am. 1996;5(2):351-60. Excluded; Outcome is not violence.
Quiggle N L, Garber J, Panak W F, et al. Social information processing in aggressive and depressed children. Child Dev. 1992;63(6):1305-20. Excluded; Outcome is not violence. [pmid: 1446554].
Quinn J F, Downs B. Predictors of gang violence: The impact of drugs and guns on police perceptions in nine states. J Gang Res. 1995;2(3):15-27. Excluded; Not a research study.
Quinn K P, Newman D L, Cumblad C. Behavioral characteristics of children and youth at risk for out-of-home placements. J Emot Behav Disord. 1995;3(3):166-73. Excluded; Outcome is not violence.
Racey B D, Lopez N L, Schneider H G. Sexually assaultive adolescents: Cue perception, interpersonal competence and cognitive distortions. Int J Adolesc Youth. 2000;8(23):229-39. Excluded; Study design not used.
Rahey L, Craig W M. Evaluation of an ecological program to reduce bullying in schools. Can J Couns. 2002;36(4):281-96. Excluded; Not a U.S. study.
Raine A, Brennan P, Mednick B, et al. High rates of violence, crime, academic problems, and behavioral problems in males with both early neuromotor deficits and unstable family environments. Arch Gen Psychiatry. 1996;53(6):544-9. Excluded; Not a U.S. study. [pmid: 8639038].
Raine A, Brennan P, Mednick S A. Birth complications combined with early maternal rejection at age 1 year predispose to violent crime at age 18 years. Arch Gen Psychiatry. 1994;51(12):984-8. Excluded; Not a U.S. study. [pmid: 7979887].
Raine A, Phil D, Stoddard J, et al. Prefrontal glucose deficits in murderers lacking psychosocial deprivation. Neuropsychiatry Neuropsychol Behav Neurol. 1998;11(1):1-7. Excluded; Study does not focus on youth as perpetrators. [pmid: 9560822].
Rakoff V M. Trauma and adolescent rites of initiation. Adolesc Psychiatry. 1995;20:109-23. Excluded; Not a research study. [pmid: 7598181].
Ralph N, Morgan K A. Assessing differences in chemically dependent adolescent males using the Child Behavior Checklist. Adolescence. 1991;26(101):183-94. Excluded; Outcome is not violence. [pmid: 2048471].
Randall J, Henggeler S W, Pickrel S G, et al. Psychiatric comorbidity and the 16-month trajectory of substance-abusing and substance-dependent juvenile offenders. J Am Acad Child Adolesc Psychiatry. 1999;38(9):1118-24. Excluded; Not addressing they key questions. [pmid: 10560218].
Rando R A, Rogers J R, Brittan-Powell C S. Gender role conflict and college men's sexually aggressive attitudes and behavior. J Ment Health Couns. 1998;20(4):359-69. Excluded; Age of study population greater than 17 years.
Rao U, Carlson G A, Rapport M D. Serum cholesterol and aggressive behavior in psychiatrically hospitalized children. Acta Psychiatr Scand. 1991;83(1):77-8. Excluded; Data not abstractable. [pmid: 2011960].
Rapp-Paglicci L A, Wodarski J S. Antecedent behaviors of male youth victimization: An exploratory study. Deviant Behav. 2000;21(6):519-36. Excluded; Not addressing they key questions.
Rasanen E, Hirvenoja R, Hakko H, et al. A portrait of the juvenile arsonist. Forensic Sci Int. 1995;73(1):41-7. Excluded; Not a U.S. study. [pmid: 7750881].
Ray J A, English D J. Comparison of female and male children with sexual behavior problems. J Youth Adolesc. 1995;24(4):439-51. Excluded; Outcome is not violence.
Reebye P, Moretti M M, Wiebe V J, et al. Symptoms of posttraumatic stress disorder in adolescents with conduct disorder: sex differences and onset patterns. Can J Psychiatry. 2000;45(8):746-51. Excluded; Outcome is not violence. [pmid: 11086558].
Reiss S, Rojahn J. Joint occurrence of depression and aggression in children and adults with mental retardation. J Intellect Disabil Res. 1993;37(3):287-94. Excluded; Data not abstractable. [pmid: 8334320].
Remington P L, Stahlsmith L, Nashold R. Assessing the increase in firearm-related homicides in Wisconsin, 1979-1993. Wis Med J. 1995;94(2):88-90. Excluded; Not a research study. [pmid: 7740823].
Resnick M D, Bearman P S, Blum R W, et al. Protecting adolescents from harm. Findings from the National Longitudinal Study on Adolescent Health. JAMA. 1997;278(10):823-32. Excluded; Study design not used. [pmid: 9293990].
Resnick M D, Harris L J, Blum R W. The impact of caring and connectedness on adolescent health and well-being. J Paediatr Child Health. 1993;29(Suppl 1):s3-9. Excluded; Outcome is not violence. [pmid: 8268019].
Rhodes J E, Fischer K. Spanning the gender gap: gender differences in delinquency among inner-city adolescents. Adolescence. 1993;28(112):879-89. Excluded; Study design not used. [pmid: 8266841].
Rican P, Klicperova M, Koucka Ta. Families of bullies and their victims: A children's view. Stud Psychol (Bratisl). 1993;35(3):261-6. Excluded; Not a U.S. study.
Rich J A, Sullivan L M. Correlates of violent assault among young male primary care patients. J Health Care Poor Underserved. 2001;12(1):103-12. Excluded; Age of study population greater than 17 years. [pmid: 11217223].
Riggs N, Houry D, Long G, et al. Analysis of 1,076 cases of sexual assault. Ann Emerg Med. 2000;35(4):358-62. Excluded; Study does not focus on youth as perpetrators. [pmid: 10736122].
Riner M E, Saywell R M. Development of the social ecology model of adolescent interpersonal violence prevention (SEMAIVP). J Sch Health. 2002;72(2):65-70. Excluded; Study design not used. [pmid: 11905131].
Ringwalt C L, Graham L A, Paschall M J, et al. Supporting Adolescents with Guidance and Employment (SAGE). Am J Prev Med. 1996;12(5 Suppl):31-8. Excluded; Not a research study. [pmid: 8909622].
Ritter J, Stewart M, Bernet C, et al. Effects of childhood exposure to familial alcoholism and family violence on adolescent substance use, conduct problems, and self-esteem. J Trauma Stress. 2002;15(2):113-22. Excluded; Data not abstractable. [pmid: 12013062].
Rivara F P. Injury research and violence: what's our contribution?. Inj Prev. 1996;2(4):249. Excluded; Not a research study. [pmid: 9346085].
Rivara F P, Shepherd J P, Farrington D P, et al. Victim as offender in youth violence. Ann Emerg Med. 1995;26(5):609-14. Excluded; Not a U.S. study. [pmid: 7486371].
Rivers I, Soutter A. Bullying and the Steiner School ethos: A case study analysis of a group-centered educational philosophy. Sch Psychol Int. 1996;17(4):359-77. Excluded; Not a U.S. study.
Roberto A J, Meyer G, Boster F J, et al. Adolescents' decisions about verbal and physical aggression: An application of the theory of reasoned action. Hum Commun Res. 2003;29(1):135-47. Excluded; Study design not used.
Roberto A J, Meyer G, Boster F J, et al. Adolescents' decisions about verbal and physical aggression: An application of the theory of reasoned action. Hum Commun Res. 2003;29(1):135-47. Excluded; Duplicated citation or findings.
Roberts T A, Ryan S A, et al. Tattooing and high-risk behavior in adolescents. Pediatrics. 2002;110(6):1058-63. Excluded; Study design not used. [pmid: 12456900].
Robertson S. Separating the men from the boys: masculinity, psychosexual development, and sex crime in the United States, 1930s-1960s. J Hist Med Allied Sci. 2001;56(1):3-35. Excluded; Not a research study. [pmid: 11236235].
Rodney H E, Tachia H R, Rodney L W. The effect of family and social support on feelings and past acts of violence among African American college men. J Am Coll Health. 1997;46(3):103-8. Excluded; Age of study population greater than 17 years. [pmid: 9394087].
Rodney H E, Tachia H R, Rodney L W. The home environment and delinquency: A study of African American adolescents. Fam Soc. 1999;80(6):551-9. Excluded; Study design not used.
Rodriguez MA, Solorio R, Hayes-Bautista DE, et al. Health risks of Latino children. JAMA 2002;288(16):1981; Discussion 3. Excluded; Not a research study.
Roff J D. Childhood aggression, peer status, and social class as predictors of delinquency. Psychol Rep. 1992;70(1):31-4. Excluded; Data not abstractable. [pmid: 1565737].
Romi S, Itskowitz R. The relationship between locus of control and type of aggression in middle-class and culturally deprived children. Pers Individ Dif. 1990;11(4):327-33. Excluded; Outcome is not violence.
Ronen T. Imparting self-control skills in the school setting. Child Fam Behav Ther. 1994;16(1):1-20. Excluded; Not a U.S. study.
Rosen P M, Walsh B W, Rode S A. Interpersonal loss and self-mutilation. Suicide Life Threat Behav. 1990;20(2):177-84. Excluded; Outcome is not violence. [pmid: 2385860].
Rosenbaum J L. A violent few: Gang girls in the California Youth Authority. J Gang Res. 1996;3(3):17-23. Excluded; Not addressing they key questions.
Rosenberg M F, Anthony J C. Aggressive behavior and opportunities to purchase drugs. Drug Alcohol Depend. 2001;63(3):245-52. Excluded; Data not abstractable. [pmid: 11543982].
Rosenfeld R, Bray T M, Egley A. Facilitating violence: A comparison of gang-motivated, gang-affiliated and nongang youth homicides. J Quant Criminol. 1999;15(4):495-516. Excluded; Not addressing they key questions.
Rossman B B R. Multiple risks for children exposed to parental violence: Family factors, psychological maltreatment, and trauma. J Aggress Maltreat Trauma. 1999;2(2):207-37. Excluded; Outcome is not violence.
Rowe D C, Almeida D M, Jacobson K C. School context and genetic influences on aggression in adolescence. Psychol Sci. 1999;10(3):277-80. Excluded; Study design not used.
Rubenstein J L, Feldman S S. Conflict-resolution behavior in adolescent boys: Antecedents and adaptational correlates. J Res Adolesc. 1993;3(1):41-66. Excluded; Outcome is not violence.
Rubin K H, Chen X, McDougall P, et al. The Waterloo Longitudinal Project: Predicting internalizing and externalizing problems in adolescence. Dev Psychopathol. 1995;7(4):751-64. Excluded; Not a U.S. study.
Rubinstein M, Yeager C A, Goodstein C, et al. Sexually assaultive male juveniles: a follow-up. Am J Psychiatry. 1993;150(2):262-5. Excluded; Age of study population greater than 17 years. [pmid: 8422077].
Rucker N, Greene V. The myth of the invulnerable self of adolescence. Am J Psychoanal. 1995;55(4):369-79. Excluded; Not a research study. [pmid: 8644892].
Russell A, Owens L. Peer estimates of school-aged boys' and girls' aggression to same- and cross-sex targets. Soc Dev. 1999;8(3):364-79. Excluded; Not a U.S. study.
Russell S T, Franz B T, Driscoll A K. Same-sex romantic attraction and experiences of violence in adolescence. Am J Public Health. 2001;91(6):903-6. Excluded; Study design not used. [pmid: 11392932]. [pmcid: 1446466].
Rys G S, Bear G G. Relational aggression and peer relations: Gender and developmental issues. Merrill Palmer Q. 1997;43(1):87-106. Excluded; Outcome is not violence.
Sachs J J, Miller S R. The impact of a wilderness experience on the social interactions and social expectations of behaviorally disordered adolescents. Behav Disord. 1992;17(2):89-98. Excluded; Data not abstractable.
Saigal S, Pinelli J, Hoult L, et al. Psychopathology and social competencies of adolescents who were extremely low birth weight. Pediatrics. 2003;111(5 Pt 1):969-75. Excluded; Outcome is not violence. [pmid: 12728073].
Salekin K L, Ogloff J R P, Ley R G, et al. The overcontrolled hostility scale: An evaluation of its applicability with an adolescent population. Crim Justice Behav. 2002;29(6):718-33. Excluded; Not a U.S. study.
Salfati C G, Canter D V. Differentiating stranger murders: Profiling offender characteristics from behavioral styles. Behav Sci Law. 1999;17(3):391-406. Excluded; Not a U.S. study. [pmid: 10481136].
Salmivalli C. Intelligent, attractive, well-behaving, unhappy: The structure of adolescents' self-concept and its relations to their social behavior. J Res Adolesc. 1998;8(3):333-54. Excluded; Not a U.S. study.
Salmivalli C, Karhunen J, Lagerspetz K M J. How do the victims respond to bullying?. Aggress Behav. 1996;22(2):99-109. Excluded; Not a U.S. study.
Salmivalli C, Kaukiainen A, Kaistaniemi L, et al. Self-evaluated self-esteem, peer-evaluated self-esteem, and defensive egotism as predictors of adolescents' participation in bullying situations. Pers Soc Psychol Bull. 1999;25(10):1268-78. Excluded; Not a U.S. study.
Salmivalli C, Kaukiainen A, Lagerspetz K. Aggression and sociometric status among peers: Do gender and type of aggression matter?. Scand J Psychol. 2000;41(1):17-24. Excluded; Not a U.S. study. [pmid: 10731839].
Salmivalli C, Nieminen E. Proactive and reactive aggression among school bullies, victims, and bully-victims. Aggress Behav. 2002;28(1):30-44. Excluded; Not a U.S. study.
Salts C J, Lindholm B W, Goddard H W, et al. Predictive variables of violent behavior in adolescent males. Youth Soc. 1995;26(3):377-99. Excluded; Study design not used.
Salzinger S, Feldman R S, Hammer M, et al. Constellations of family violence and their differential effects on children's behavioral disturbance. Child Fam Behav Ther. 1992;14(4):23-41. Excluded; Study does not focus on youth as perpetrators.
Salzinger S, Feldman R S, Ng-Mak D S, et al. Effects of partner violence and physical child abuse on child behavior: A study of abused and comparison children. J Fam Violence. 2002;17(1):23-52. Excluded; Outcome is not violence.
Sandor P, Stephens R J. Risperidone treatment of aggressive behavior in children with Tourette syndrome. J Clin Psychopharmacol. 2000;20(6):710-2. Excluded; Not a U.S. study. [pmid: 11106151].
Santman J, Myner J, Cappelletty G G, et al. California juvenile gang members: An analysis of case records. J Gang Res. 1997;5(1):45-53. Excluded; Not addressing they key questions.
Sarigiani P A, Ryan L, Petersen A C. Prevention of high-risk behaviors in adolescent women. J Adolesc Health. 1999;25(2):109-19. Excluded; Study does not focus on youth as perpetrators. [pmid: 10447038].
Sarne Y, Mandel J, Goncalves M H, et al. Imipramine binding to blood platelets and aggressive behavior in offenders, schizophrenics and normal volunteers. Neuropsychobiology. 1995;31(3):120-4. Excluded; Not a U.S. study. [pmid: 7609859].
Satcher D, Powell K E, Mercy J A, et al. Violence prevention is as American as apple pie. Am J Prev Med. 1996;12(5 Suppl):V-Vi. Excluded; Not a research study. [pmid: 8909617].
Satterfield J H, Swanson J, Schell A M, et al. Prediction of antisocial behavior in attention-deficit hyperactivity disorder boys from aggression/defiant scores. J Am Acad Child Adolesc Psychiatry. 1994;33(2):185-90. Excluded; Data not abstractable. [pmid: 8150789].
Sayger T V, Horne A M, Glaser B A. Marital satisfaction and social learning family therapy for child conduct problems: Generalization of treatment effects. J Marital Fam Ther. 1993;19(4):393-402. Excluded; Age of study population greater than 17 years. [pmid: 21118477].
Scerbo A S, Kolko D J. Salivary testosterone and cortisol in disruptive children: Relationship to aggressive, hyperactive, and internalizing behaviors. J Am Acad Child Adolesc Psychiatry. 1994;33(8):1174-84. Excluded; Outcome is not violence. [pmid: 7982868].
Scerbo A S, Kolko D J. Child physical abuse and aggression: preliminary findings on the role of internalizing problems. J Am Acad Child Adolesc Psychiatry. 1995;34(8):1060-6. Excluded; Data not abstractable. [pmid: 7665445].
Schaal B, Tremblay R E, Soussignan R, et al. Male testosterone linked to high social dominance but low physical aggression in early adolescence. J Am Acad Child Adolesc Psychiatry. 1996;35(10):1322-30. Excluded; Not a U.S. study. [pmid: 8885586].
Scheidlinger S. The centrality of the peer group's role in two aspects of school violence revisited. Int J Group Psychother. 2003;53(2):245-9. Excluded; Not a research study. [pmid: 12712591].
Scherer D G, Brondino M J, Henggeler S W, et al. Multisystemic Family Preservation Therapy: Preliminary findings from a study of rural and minority serious adolescent offenders. J Emot Behav Disord. 1994;2(4):198-206. Excluded; Data not abstractable.
Scherer D G, Others A. Multisystemic family preservation therapy: Preliminary findings from a study of rural and minority serious adolescent offenders. J Emot Behav Disord. 1994;2(4):198-206. Excluded; Duplicated citation or findings.
Scherzer T, Pinderhughes H L. Violence and gender: reports from an urban high school. Violence Vict. 2002;17(1):57-72. Excluded; Study design not used. [pmid: 11991157].
Schiff M, Cavaiola A A. Child abuse, adolescent substance abuse, and “deadly violence”. J Adolesc Chem Depend. 1993;2(34):131-41. Excluded; Outcome is not violence.
Schinke S, Jansen M, Kennedy E, et al. Reducing risk-taking behavior among vulnerable youth: An intervention outcome study. Fam Community Health. 1994;16(4):49-56. Excluded; Outcome is not violence.
Schoenthaler S J, Bier I D. The effect of vitamin-mineral supplementation on juvenile delinquency among American schoolchildren: a randomized, double-blind placebo-controlled trial. J Altern Complement Med. 2000;6(1):7-17. Excluded; Age of study population greater than 17 years. [pmid: 10706232].
Scholte E M. Factors predicting continued violence into young adulthood. J Adolesc. 1999;22(1):3-20. Excluded; Not a U.S. study. [pmid: 10579893].
Schreiber E H. A study of the personality of violent children. N Am J Psychol. 1999;1(1):51-6. Excluded; Study does not focus on youth as perpetrators.
Schreiber E L, Screiber K N. A study of parents of violent children. Psychol Rep. 2002;90(1):101-4. Excluded; Data not abstractable. [pmid: 11898970].
Schreier H A. Risperidone for young children with mood disorders and aggressive behavior. J Child Adolesc Psychopharmacol. 1998;8(1):49-59. Excluded; Not a research study. [pmid: 9639079].
Schubiner H, Scott R, Tzelepis A. Exposure to violence among inner-city youth. J Adolesc Health. 1993;14(3):214-9. Excluded; Study does not focus on youth as perpetrators. [pmid: 8323933].
Schulenberg S E, Soundy T. Epidemiology of physical and sexual abuse in young persons diagnosed with conduct disorder: a retrospective chart review. S D J Med. 2000;53(1):29-32. Excluded; Not addressing they key questions. [pmid: 10652863].
Schwab C W, Richmond T S, Cheney R A, et al. Risk factors for violent death in children. JAMA. 2002;287(8):983-4. Excluded; Not a research study. [pmid: 11866633].
Schwab-Stone M, Chen C, Greenberger E, et al. No safe haven. II: The effects of violence exposure on urban youth. J Am Acad Child Adolesc Psychiatry. 1999;38(4):359-67. Excluded; Outcome is not violence. [pmid: 10199106].
Schwartz C E, Snidman N, Kagan J. Early childhood temperament as a determinant of externalizing behavior in adolescence. Dev Psychopathol. 1996;8(3):527-37. Excluded; Outcome is not violence.
Schwartz D. Subtypes of victims and aggressors in children's peer groups. J Abnorm Child Psychol. 2000;28(2):181-92. Excluded; Outcome is not violence. [pmid: 10834769].
Schwartz M, O'Leary S G, Kendziora K T. Dating aggression among high school students. Violence Vict. 1997;12(4):295-305. Excluded; Study design not used. [pmid: 9591350].
Schwartz R H, Little D L. Let's party tonight: drinking patterns and breath alcohol values at high school parties. Fam Med. 1997;29(5):326-31. Excluded; Outcome is not violence. [pmid: 9165284].
Schwartzberg A Z. Risk factors for adolescent violence: Implications for prevention and treatment. Int J Adolesc Med Health. 1999;11(34):429-37. Excluded; Not a research study.
Scott K D, Schafer J, Greenfield T K. The role of alcohol in physical assault perpetration and victimization. J Stud Alcohol. 1999;60(4):528-36. Excluded; Age of study population greater than 17 years. [pmid: 10463810].
Sege R D, Kharasch S, Perron C, et al. Pediatric violence-related injuries in Boston: results of a city-wide emergency department surveillance program. Arch Pediatr Adolesc Med. 2002;156(1):73-6. Excluded; Study does not focus on youth as perpetrators. [pmid: 11772194].
Sege R, Stringham P, Short S, et al. Ten years after: examination of adolescent screening questions that predict future violence-related injury. J Adolesc Health. 1999;24(6):395-402. Excluded; Study does not focus on youth as perpetrators. [pmid: 10401967].
Seguin J R, Arseneault L, Boulerice B, et al. Response perseveration in adolescent boys with stable and unstable histories of physical aggression: The role of underlying processes. J Child Psychol Psychiatry. 2002;43(4):481-94. Excluded; Not a U.S. study. [pmid: 12030594].
Seguin J R, Boulerice B, Harden P W, et al. Executive functions and physical aggression after controlling for attention deficit hyperactivity disorder, general memory, and IQ. Journal of Child Psychology and Psychiatry, and Allied Disciplines. 1999;40(8):1197-208. Excluded; Not a U.S. study. [pmid: 10604398].
Seguin J R, Pihl R O, Boulerice B, et al. Low pain sensitivity and stability of physical aggression in boys. Ann N Y Acad Sci. 1996;794:408-10. Excluded; Data not abstractable. [pmid: 8853627].
Seguin J R, Pihl R O, Harden P W, et al. Cognitive and neuropsychological characteristics of physically aggressive boys. J Abnorm Psychol. 1995;104(4):614-24. Excluded; Not a U.S. study. [pmid: 8530764].
Seidenwurm D, Pounds T R, Globus A, et al. Abnormal temporal lobe metabolism in violent subjects: correlation of imaging and neuropsychiatric findings. AJNR Am J Neuroradiol. 1997;18(4):625-31. Excluded; Age of study population greater than 17 years. [pmid: 9127022].
Seidman E, Yoshikawa H, Roberts A, et al. Structural and experiential neighborhood contexts, developmental stage, and antisocial behavior among urban adolescents in poverty. Dev Psychopathol. 1998;10(2):259-81. Excluded; Outcome is not violence. [pmid: 9635224].
Seifert K, Phillips S, Parker S. Child and Adolescent Risk for Violence (CARV): A tool to assess juvenile risk. J Psychiatry Law. 2001;29(3):329-46. Excluded; Not a research study.
Selkurt J. Teens and domestic violence. Wis Med J. 1994;93(1):29. Excluded; Not a research study. [pmid: 8160482].
Selner-O'Hagan M B, Kindlon D J, Buka S L, et al. Assessing exposure to violence in urban youth. Journal of Child Psychology and Psychiatry, and Allied Disciplines. 1998;39(2):215-24. Excluded; Outcome is not violence. [pmid: 9669234].
Sequeira H, Halstead S. “Is it meant to hurt, is it?”: Management of violence in women with developmental disabilities. Violence Against Women. 2001;7(4):462-76. Excluded; Outcome is not violence.
Shackelford T K. Risk of multiple-offender rape-murder varies with female age. J Crim Justice. 2002;30(2):135-41. Excluded; Age of study population greater than 17 years.
Shahinfar A, Kupersmidt J B, Matza L S. The relation between exposure to violence and social information processing among incarcerated adolescents. J Abnorm Psychol. 2001;110(1):136-41. Excluded; Outcome is not violence. [pmid: 11261387].
Shahpar C, Li G. Homicide mortality in the United States, 1935-1994: age, period, and cohort effects. Am J Epidemiol. 1999;150(11):1213-22. Excluded; Study does not focus on youth as perpetrators. [pmid: 10588082].
Shapiro J P, Welker C J, Pierce J L. An evaluation of residential treatment for sexually aggressive youth. J Child Sex Abus. 2001;10(1):1-21. Excluded; Outcome is not violence. [pmid: 16221618].
Sharps P W, Campbell J, Campbell D, et al. The role of alcohol use in intimate partner femicide. Am J Addict. 2001;10(2):122-35. Excluded; Age of study population greater than 17 years. [pmid: 11444155].
Shaw J A, Campo-Bowen A E, Applegate B, et al. Young boys who commit serious sexual offenses: demographics, psychometrics, and phenomenology. Bull Am Acad Psychiatry Law. 1993;21(4):399-408. Excluded; Data not abstractable. [pmid: 8054670].
Shechtman Z, Ben-David M. Individual and group psychotherapy of childhood aggression: A comparison of outcomes and processes. Group Dyn. 1999;3(4):263-74. Excluded; Not a U.S. study.
Sheehan K, DiCara J A, LeBailly S, et al. Adapting the gang model: peer mentoring for violence prevention. Pediatrics. 1999;104(1 Pt 1):50-4. Excluded; Study does not focus on youth as perpetrators. [pmid: 10390259].
Sheley J F. Drugs and guns among inner-city high school students. J Drug Educ. 1994;24(4):303-21. Excluded; Study design not used. [pmid: 7869222].
Sheley J F, Brewer V E. Possession and carrying of firearms among suburban youth. Public Health Rep. 1995;110(1):18-26. Excluded; Data not abstractable. [pmid: 7838938]. [pmcid: 1382069].
Shepherd J P, Farrington D P. Preventing crime and violence. BMJ. 1995;310(6975):271-2. Excluded; Not a research study. [pmid: 7866163].
Sheras P L, Cornell D G, Bostain D S. The Virginia Youth Violence Project: Transmitting psychological knowledge on youth violence to schools and communities. Prof Psychol Res Pract. 1996;27(4):401-6. Excluded; Outcome is not violence.
Shields A, Cicchetti D. Reactive aggression among maltreated children: The contributions of attention and emotion dysregulation. J Clin Child Psychol. 1998;27(4):381-95. Excluded; Outcome is not violence. [pmid: 9866075].
Shields A, Cicchetti D. Parental maltreatment and emotion dysregulation as risk factors for bullying and victimization in middle childhood. J Clin Child Psychol. 2001;30(3):349-63. Excluded; Study does not focus on youth as perpetrators. [pmid: 11501252].
Shields E W. Intimidation and violence by males in high school athletics. Adolescence. 1999;34(135):503-21. Excluded; Study design not used. [pmid: 10730694].
Shields N, Pierce L. Factors related to aggressive and violent behavior among preadolescent African-American boys. Int J Adolesc Youth. 2001;10(12):51-68. Excluded; Study does not focus on youth as perpetrators.
Shoda Y, Mischel W, Wright J C. The role of situational demands and cognitive competencies in behavior organization and personality coherence. J Pers Soc Psychol. 1993;65(5):1023-35. Excluded; Study does not focus on youth as perpetrators. [pmid: 8246110].
Shumaker D M, McKee G R. Characteristics of homicidal and violent juveniles. Violence Vict. 2001;16(4):401-9. Excluded; Outcome is not violence. [pmid: 11506449].
Sikand V K. A violence prevention program targeting adolescents. Conn Med. 1996;60(1):41. Excluded; Not a research study. [pmid: 8821929].
Silverman R A, Kennedy L W. Women who kill their children. Violence Vict. 1988;3(2):113-27. Excluded; Not a U.S. study. [pmid: 3154174].
Simic M, Fombonne E. Depressive conduct disorder: symptom patterns and correlates in referred children and adolescents. J Affect Disord. 2001;62(3):175-85. Excluded; Outcome is not violence. [pmid: 11223105].
Simonoff E, Pickles A, Meyer J, et al. Genetic and environmental influences on subtypes of conduct disorder behavior in boys. J Abnorm Child Psychol. 1998;26(6):495-509. Excluded; Outcome is not violence. [pmid: 9915655].
Simons K J, Paternite C E, Shore C. Quality of parent/adolescent attachment and aggression in young adolescents. J Early Adolesc. 2001;21(2):182-203. Excluded; Outcome is not violence.
Simons R L, Johnson C, Conger R D. Harsh corporal punishment versus quality of parental involvement as an explanation of adolescent maladjustment. J Marriage Fam. 1994;56(3):591-607. Excluded; Outcome is not violence.
Simons R L, Whitbeck L B, Beaman J, et al. The impact of mothers' parenting, involvement by nonresidential fathers, and parental conflict on the adjustment of adolescent children. J Marriage Fam. 1994;56(2):356-74. Excluded; Data not abstractable.
Simonson H. Interaction effects of television and socioeconomic status on teenage aggression. Int J Adolesc Youth. 1992;3(34):333-43. Excluded; Study design not used.
Singer M H. How central is the analysis of aggression to clinical psychoanalysis?. J Am Psychoanal Assoc. 1999;47(4):1179-89. Excluded; Not a research study. [pmid: 10650556].
Singer M I, Flannery D J. The relationship between children's threats of violence and violent behaviors. Arch Pediatr Adolesc Med. 2000;154(8):785-90. Excluded; Data not abstractable. [pmid: 10922274].
Singer M I, Miller D B, Guo S, et al. Contributors to violent behavior among elementary and middle school children. Pediatrics. 1999;104(4 Pt 1):878-84. Excluded; Data not abstractable. [pmid: 10506229].
Singer M I, Slovak K, Frierson T, et al. Viewing preferences, symptoms of psychological trauma, and violent behaviors among children who watch television. J Am Acad Child Adolesc Psychiatry. 1998;37(10):1041-8. Excluded; Data not abstractable. [pmid: 9785715].
Singleton E G, Dale G A J. Lack of co-occurring interpersonal violence-related emotional difficulties and alcohol or other drug problems among African American youth with conduct disorder. J Negro Educ. 1996;65(4):445-53. Excluded; Outcome is not violence.
Skeem J L, Mulvey E P. Psychopathy and community violence among civil psychiatric patients: results from the MacArthur Violence Risk Assessment Study. J Consult Clin Psychol. 2001;69(3):358-74. Excluded; Outcome is not violence. [pmid: 11495166].
Skelton D L, Glynn M A, Berta S M. Aggressive behavior as a function of taekwondo ranking. Percept Mot Skills. 1991;72(1):179-82. Excluded; Study does not focus on youth as perpetrators. [pmid: 2038512].
Skiba R J, Knesting K, et al. Zero tolerance, zero evidence: an analysis of school disciplinary practice. New Dir Youth Dev. 2001;92:17-43. Excluded; Not a research study. [pmid: 12170829].
Skinner M L, Elder G H, Conger R D. Linking economic hardship to adolescent aggression. J Youth Adolesc. 1992;21(3):259-76. Excluded; Outcome is not violence.
Skovholt T, Cognetta P, Ye G, et al. Violence prevention strategies of inner-city student experts. Prof Sch Couns. 1997;1(1):35-8. Excluded; Not a research study.
Slabbekoorn D, Van Goozen SHM, Gooren LJG, et al. Effects of cross-sex hormone treatment on emotionality in transsexuals. Int J Transgenderism 2001;5(3):NP. Excluded; Outcome is not violence.
Slovak K, Singer M. Gun violence exposure and trauma among rural youth. Violence Vict. 2001;16(4):389-400. Excluded; Data not abstractable. [pmid: 11506448].
Smith A M, Gacono C B, Kaufman L. A Rorschach comparison of psychopathic and nonpsychopathic conduct disordered adolescents. J Clin Psychol. 1997;53(4):289-300. Excluded; Outcome is not violence. [pmid: 9169383].
Smith A M, Gacono C B, Kaufman L. A Rorschach comparison of psychopathic and nonpsychopathic conduct disordered adolescents. J Clin Psychol. 1997;53:289-300. Excluded; Duplicated citation or findings. [pmid: 9169383].
Smith A T, Kuller L H, Perper J A, et al. Epidemiology of homicide in Allegheny County, Pennsylvania, between 1966-1974 and 1984-1993. Prev Med. 1998;27(3):452-60. Excluded; Study does not focus on youth as perpetrators. [pmid: 9612836].
Smith C A. Dis-attachment. Aust N Z J Psychiatry. 1994;28(4):691-3. Excluded; Not a research study. [pmid: 7794214].
Smith H, Thomas S. Violent and nonviolent girls: contrasting perceptions of anger experiences, school, and relationships. Issues Ment Health Nurs. 2000;21(5):547-75. Excluded; Data not abstractable. [pmid: 11261077].
Smith J P, Williams J G. From abusive household to dating violence. J Fam Violence. 1992;7(2):153-65. Excluded; Study design not used.
Smith M A, Jenkins J M. The effects of marital disharmony on prepubertal children. J Abnorm Child Psychol. 1991;19(6):625-44. Excluded; Not a U.S. study. [pmid: 1791270].
Smith M D, Feiler S M. Absolute and relative involvement in homicide offending: contemporary youth and the baby boom cohorts. Violence Vict. 1995;10(4):327-33. Excluded; Not a research study. [pmid: 8703844].
Smith P, Flay B R, Bell C C, et al. The protective influence of parents and peers in violence avoidance among African-American youth. Matern Child Health J. 2001;5(4):245-52. Excluded; Data not abstractable. [pmid: 11822526].
Smith S, Kern R M, Curlette W L, et al. Lifestyle profiles and interventions for aggressive adolescents. J Individ Psychol. 2001;57(3):224-45. Excluded; Not addressing they key questions.
Smith S, Mullis F, Kern R M, et al. An Adlerian model for the etiology of aggression in adjudicated adolescents. Fam J. 1999;7(2):135-47. Excluded; Not addressing they key questions.
Smith S L, Howard J A, Monroe A D. Issues underlying behavior problems in at-risk adopted children. Child Youth Serv Rev. 2000;22(7):539-62. Excluded; Outcome is not violence.
Snyder R, Turgay A, Aman M, et al. Effects of risperidone on conduct and disruptive behavior disorders in children with subaverage IQs. J Am Acad Child Adolesc Psychiatry. 2002;41(9):1026-36. Excluded; Outcome is not violence. [pmid: 12218423].
Soderstrom H, Blennow K, Manhem A, et al. CSF studies in violent offenders. II. Blood-brain barrier dysfunction without concurrent inflammation or structure degeneration. J Neural Transm. 2001;108(7):879-86. Excluded; Not a U.S. study. [pmid: 11515753].
Soderstrom H, Blennow K, Manhem A, et al. CSF studies in violent offenders. I 5-HIAA as a negative and HVA as a positive predictor of psychopathy. J Neural Transm. 2001;108(7):869-78. Excluded; Not a U.S. study. [pmid: 11515753].
Sommers I, Baskin D R. Factors related to female adolescent initiation into violent street crime. Youth Soc. 1994;25:468-89. Excluded; Not addressing they key questions.
Sommers I, Baskin D R. Situational or generalized violence in drug dealing networks. J Drug Issues. 1997;27(4):833-49. Excluded; Age of study population greater than 17 years.
Sommers I, Fagan J, Baskin D. Sociocultural influences on the explanation of delinquency for Puerto Rican youths. Hisp J Behav Sci. 1993;15(1):36-62. Excluded; Study design not used.
Song L Y, Singer M I, Anglin T M. Violence exposure and emotional trauma as contributors to adolescents' violent behaviors. Arch Pediatr Adolesc Med. 1998;152(6):531-6. Excluded; Study design not used. [pmid: 9641704].
Sosin D M, Koepsell T D, Rivara F P, et al. Fighting as a marker for multiple problem behaviors in adolescents. J Adolesc Health. 1995;16(3):209-15. Excluded; Outcome is not violence. [pmid: 7779831].
Sourander A, Aurela A, Piha J. Therapeutic holding in child and adolescent psychiatric inpatient treatment. Nord J Psychiatry. 1996;50(5):375-80. Excluded; Not a U.S. study.
Sourander A, Helstela L, Helenius H. Persistence of bullying from childhood to adolescence--a longitudinal 8-year follow-up study. Child Abuse Negl. 2000;24(7):873-81. Excluded; Outcome is not violence. [pmid: 10905413].
Spaccarelli S, Bowden B, Coatsworth J D, et al. Psychosocial correlates of male sexual aggression in a chronic delinquent sample. Crim Justice Behav. 1997;24(1):71-95. Excluded; Study design not used.
Spaccarelli S, Coatsworth J D, Bowden B S. Exposure to serious family violence among incarcerated boys: its association with violent offending and potential mediating variables. Violence Vict. 1995;10(3):163-82. Excluded; Study design not used. [pmid: 8777184].
Spergel I A, Grossman S F. The Little Village Project: A community approach to the gang problem. Soc Work. 1997;42(5):456-70. Excluded; Study does not focus on youth as perpetrators. [pmid: 9311304].
Spigelman G, Spigelman A, Englesson I. Hostility, aggression, and anxiety levels of divorce and nondivorce children as manifested in their responses to projective tests. J Pers Assess. 1991;56(3):438-52. Excluded; Not a U.S. study. [pmid: 1865304].
Spillane-Grieco E. From parent verbal abuse to teenage physical aggression?. Child Adolesc Social Work J. 2000;17(6):411-30. Excluded; Data not abstractable.
Spingarn R W, DuRant R H. Male adolescents involved in pregnancy: associated health risk and problem behaviors. Pediatrics. 1996;98(2 Pt 1):262-8. Excluded; Study design not used. [pmid: 8692628].
Spitz R T, Hillbrand M, Foster H G, et al. Ethnicity, aggression and serum creatine kinase in hospitalized male forensic patients. Ethn Dis. 1997;7(3):259-70. Excluded; Age of study population greater than 17 years. [pmid: 9467709].
Sprague J, Walker H M, Stieber S, et al. Exploring the relationship between school discipline referrals and delinquency. Psychol Sch. 2001;38(2):197-206. Excluded; Outcome is not violence.
Spunt B, Goldstein P, Brownstein H, et al. The role of marijuana in homicide. Int J Addict. 1994;29(2):195-213. Excluded; Age of study population greater than 17 years. [pmid: 8144275].
St George D M, Thomas S B. Perceived risk of fighting and actual fighting behavior among middle school students. J Sch Health. 1997;67(5):178-81. Excluded; Study design not used. [pmid: 9210103].
St. Lawrence J S, Crosby R A, Belcher L, et al. Sexual risk reduction and anger management interventions for incarcerated male adolescents: A randomized controlled trial of two interventions. J Sex Educ Ther. 1999;24(12):9-17. Excluded; Outcome is not violence.
Stafford E, Cornell D G. Psychopathy scores predict adolescent inpatient aggression. Assessment. 2003;10(1):102-12. Excluded; Study design not used. [pmid: 12675389].
Stanislav S W, Fabre T, Crismon M L, et al. Buspirone's efficacy in organic-induced aggression. J Clin Psychopharmacol. 1994;14(2):126-30. Excluded; Study does not focus on youth as perpetrators. [pmid: 8195453].
Stein D J, Keating J, Zar H J, et al. A survey of the phenomenology and pharmacotherapy of compulsive and impulsive-aggressive symptoms in Prader-Willi Syndrome. J Neuropsychiatry Clin Neurosci. 1994;6(1):23-9. Excluded; Outcome is not violence. [pmid: 8148633].
Steiner H, Stone L A. Violence and related psychopathology. J Am Acad Child Adolesc Psychiatry. 1999;38(3):232-4. Excluded; Not a research study. [pmid: 10087682].
Steinert T, Woelfle M, Gebhardt R P. No correlation of serum cholesterol levels with measures of violence in patients with schizophrenia and non-psychotic disorders. Eur Psychiatry. 1999;14(6):346-8. Excluded; Age of study population greater than 17 years. [pmid: 10572367].
Steinert T, Woelfle M, Gebhardt R P. No correlation of serum cholesterol levels with measures of violence in patients with schizophrenia and non-psychotic disorders. Eur Psychiatry. 1999;14(6):346-8. Excluded; Duplicated citation or findings. [pmid: 10572367].
Steinert T, Wolfle M, Gebhardt R P. Measurement of violence during in-patient treatment and association with psychopathology. Acta Psychiatr Scand. 2000;102(2):107-12. Excluded; Not a U.S. study. [pmid: 10937782].
Stephens R J, Sandor P. Aggressive behaviour in children with Tourette syndrome and comorbid attention-deficit hyperactivity disorder and obsessive-compulsive disorder. Can J Psychiatry. 1999;44(10):1036-42. Excluded; Not a U.S. study. [pmid: 10637683].
Stevens V, De Bourdeaudhuij I, Van Oost P. Relationship of the family environment to children's involvement in bully/victim problems at school. J Youth Adolesc. 2002;31(6):419-28. Excluded; Not a U.S. study.
Stevenson H C, Herrero-Taylor T, Cameron R, et al. “Mitigating instigation”: Cultural phenomenological influences of anger and fighting among “big-boned” and “baby-faced” African American youth. J Youth Adolesc. 2002;31(6):473-85. Excluded; Outcome is not violence.
Stewart E A, Simons R L, Conger R D. Assessing Neighborhood and Social Psychological Influences on Childhood Violence in an African-American Sample. Criminology. 2002;40(4):801-29. Excluded; Study does not focus on youth as perpetrators.
Stier D M, Leventhal J M, Berg A T, et al. Are children born to young mothers at increased risk of maltreatment?. Pediatrics. 1993;91(3):642-8. Excluded; Study does not focus on youth as perpetrators. [pmid: 8441574].
Stiffman A R, Dore P, Cunningham R M. Violent behavior in adolescents and young adults: A person and environment model. J Child Fam Stud. 1996;5(4):487-501. Excluded; Data not abstractable.
Stoff D M, Pasatiempo A P, Yeung J, et al. Neuroendocrine responses to challenge with dl-fenfluramine and aggression in disruptive behavior disorders of children and adolescents. Psychiatry Res. 1992;43(3):263-76. Excluded; Study design not used. [pmid: 1438624].
Stolzenberg L, D'Alessio S J. Gun availability and violent crime: New evidence from the National Incident-Based Reporting System. Soc Forces. 2000;78(4):1461-82. Excluded; Age of study population greater than 17 years.
Strain P S, Timm M A. Remediation and prevention of aggression: An evaluation of the Regional Intervention Program over a quarter century. Behav Disord. 2001;26(4):297-313. Excluded; Outcome is not violence.
Straus M A. Spanking and the making of a violent society. Pediatrics. 1996;98(4 Pt 2):837-42. Excluded; Not a research study. [pmid: 8885984].
Straus M A, Kantor G K. Corporal punishment of adolescents by parents: A risk factor in the epidemiology of depression, suicide, alcohol abuse, child abuse, and wife beating. Adolescence. 1994;29(115):543-61. Excluded; Age of study population greater than 17 years. [pmid: 7832020].
Straus M A, Mouradian V E. Impulsive corporal punishment by mothers and antisocial behavior and impulsiveness of children. Behav Sci Law. 1998;16(3):353-74. Excluded; Data not abstractable. [pmid: 9768466].
Straznickas K A, McNiel D E, Binder R L. Violence toward family caregivers by mentally ill relatives. Hosp Community Psychiatry. 1993;44(4):385-7. Excluded; Study does not focus on youth as perpetrators. [pmid: 8462950].
Stricker S J, Volgas D A. Extremity handgun injuries in children and adolescents. Orthopedics. 1998;21(10):1095-110. Excluded; Outcome is not violence. [pmid: 9801233].
Strom J P. Breaking the cycle of violence. J S C Med Assoc. 1995;91(10):439. Excluded; Not a research study. [pmid: 7474955].
Stueve A, O'Donnell L, Link B. Gender differences in risk factors for violent behavior among economically disadvantaged African American and Hispanic young adolescents. Int J Law Psychiatry. 2001;24(45):539-57. Excluded; Study design not used. [pmid: 11521425].
Stulc J P. The cult of violence. J Ky Med Assoc. 1998;96(12):497-8. Excluded; Not a research study. [pmid: 9879180].
Sullivan A M, Rivera J. Profile of a comprehensive psychiatric emergency program in a New York City municipal hospital. Psychiatr Q. 2000;71(2):123-38. Excluded; Not a research study. [pmid: 10832155].
Surette R. Self-reported copycat crime among a population of serious and violent juvenile offenders. Crime Delinq. 2002;48(1):46-69. Excluded; Not addressing they key questions.
Sussman S, Dent C W, McCullar W J. Group self-identification as a prospective predictor of drug use and violence in high-risk youth. Psychol Addict Behav. 2000;14(2):192-6. Excluded; Data not abstractable. [pmid: 10860118].
Sussman S, Dent C W, Stacy A W. The association of current stimulant use with demographic, substance use, violence-related, social and intrapersonal variables among high risk youth. Addictive Behaviors Addict Behav. 1999;24(6):741-8. Excluded; Data not abstractable.
Sussman S, Dent C W, Stacy A W, et al. Psychosocial variables as prospective predictors of violent events among adolescents. Health Values. 1994;18(3):29-40. Excluded; Outcome is not violence.
Sussman S, Simon T R, Dent C W, et al. One-year prediction of violence perpetration among high-risk youth. Am J Health Behav. 1999;23(5):332-44. Excluded; Data not abstractable.
Swanson J W, Swartz M S, Borum R, et al. Involuntary out-patient commitment and reduction of violent behaviour in persons with severe mental illness. Br J Psychiatry. 2000;176:324-31. Excluded; Age of study population greater than 17 years. [pmid: 10827879].
Swartz M S, Swanson J W, Hiday V A, et al. Taking the wrong drugs: the role of substance abuse and medication noncompliance in violence among severely mentally ill individuals. Soc Psychiatry Psychiatr Epidemiol. 1998;33(Suppl 1):s75-80. Excluded; Age of study population greater than 17 years. [pmid: 9857785].
Swartz M S, Swanson J W, Hiday V A, et al. Violence and severe mental illness: the effects of substance abuse and nonadherence to medication. Am J Psychiatry. 1998;155(2):226-31. Excluded; Age of study population greater than 17 years. [pmid: 9464202].
Swett C. Inpatient seclusion: Description and causes. Bull Am Acad Psychiatry Law. 1994;22(3):421-30. Excluded; Outcome is not violence. [pmid: 7841514].
Swikert N. SAVE--school violence II. J Ky Med Assoc. 2000;98(10):459-60. Excluded; Not a research study. [pmid: 11059218].
Swinford S P, DeMaris A, Cernkovich S A, et al. Harsh physical discipline in childhood and violence in later romantic involvements: The mediating role of problem behaviors. J Marriage Fam. 2000;62(2):508-19. Excluded; Age of study population greater than 17 years.
Talbott E, Celinska D, Simpson J, et al. “Somebody else making somebody else fight”: Aggression and the social context among urban adolescent girls. Exceptionality. 2002;10(3):203-20. Excluded; Not a research study.
Taliaferro E, Smith D, Rogers J, et al. Violence intervention programs: the Parkland Domestic Violence Project. Tex Dent J. 2000;117(10):54-8. Excluded; Not a research study. [pmid: 11857887].
Tannenhaus N. Violence in the streets. What can communities do?. Trustee. 1995;48(4):6-9. Excluded; Not a research study. [pmid: 10141688].
Tarter R E, Kirisci L, Vanyukov M, et al. Predicting adolescent violence: impact of family history, substance use, psychiatric history, and social adjustment. Am J Psychiatry. 2002;159(9):1541-7. Excluded; Age of study population greater than 17 years. [pmid: 12202275].
Tashman N A, Weist M D, Nabors L A, et al. Involvement in meaningful activities and self-reported aggression and delinquency among inner-city teenagers. J Clin Psychol Med Settings. 1998;5(3):239-48. Excluded; Data not abstractable.
Taub J. Evaluation of the Second Step Violence Prevention Program at a rural elementary school. School Psych Rev. 2002;31(2):186-200. Excluded; Age of study population greater than 17 years.
Taussig H N. Risk behaviors in maltreated youth placed in foster care: a longitudinal study of protective and vulnerability factors. Child Abuse Negl. 2002;26(11):1179-99. Excluded; Outcome is not violence. [pmid: 12398855].
Taylor E, Chadwick O, Heptinstall E. Hyperactivity and conduct problems as risk factors for adolescent development. J Am Acad Child Adolesc Psychiatry. 1996;35:1213-26. Excluded; Duplicated citation or findings. [pmid: 8824065].
Taylor E, Chadwick O, Heptinstall E, et al. Hyperactivity and conduct problems as risk factors for adolescent development. J Am Acad Child Adolesc Psychiatry. 1996;35(9):1213-26. Excluded; Not a U.S. study. [pmid: 8824065].
Taylor E R, Kelly J, Valescu S, et al. Is stealing a gateway crime?. Community Ment Health J. 2001;37(4):347-58. Excluded; Data not abstractable. [pmid: 11482752].
Taylor H G. Family violence and the community pharmacist. Am Pharm. 1994;Ns34(4):41-4. Excluded; Not a research study. [pmid: 8209831].
Tebbutt J, Swanston H, Oates R K, et al. Five years after child sexual abuse: persisting dysfunction and problems of prediction. J Am Acad Child Adolesc Psychiatry. 1997;36(3):330-9. Excluded; Outcome is not violence. [pmid: 9055513].
Teevan J J, Dryburgh H B. First person accounts and sociological explanations of delinquency. Can Rev Sociol Anthropol. 2000;37(1):77-93. Excluded; Not a U.S. study.
Tengstroem A, Grann M, Langstroem N, et al. Psychopathy (PCL-R) as a predictor of violent recidivism among criminal offenders with schizophrenia. Law Hum Behav. 2000;24(1):45-58. Excluded; Not a U.S. study. [pmid: 10693318].
Teplin L A, Abram K M, McClelland G M. Does psychiatric disorder predict violent crime among released jail detainees? A six-year longitudinal study. Am Psychol. 1994;49(4):335-42. Excluded; Age of study population greater than 17 years. [pmid: 8203805].
Thompson K M, Brownfield D, Sorenson A M. At-risk behavior and group fighting: A latent structure analysis. J Gang Res. 1998;5(3):1-14. Excluded; Study design not used.
Thornberry T P, Freeman-Gallant A, Lizotte A J, et al. Linked lives: The intergenerational transmission of antisocial behavior. J Abnorm Child Psychol. 2003;31(2):171-84. Excluded; Data not abstractable. [pmid: 12735399].
Thornberry T P, Krohn M D, Lizotte A J, et al. The role of juvenile gangs in facilitating delinquent behavior. J Res Crime Delinq. 1993;30(1):55-87. Excluded; Included violent and non-violent behaviors.
Tiet Q Q, Wasserman G A, Loeber R, et al. Developmental and sex differences in types of conduct problems. J Child Fam Stud. 2001;10(2):181-97. Excluded; Data not abstractable.
Tinklenberg J A, Steiner H, Huckaby W J, et al. Criminal recidivism predicted from narratives of violent juvenile delinquents. Child Psychiatry Hum Dev. 1996;27(2):69-79. Excluded; Age of study population greater than 17 years. [pmid: 8936793].
Tippins B S. Family violence: a national epidemic. J Med Assoc Ga. 1992;81(7):372-3. Excluded; Not a research study. [pmid: 1402420].
Tobin T, Sugai G, Colvin G. Patterns in middle school discipline records. J Emot Behav Disord. 1996;4(2):82-94. Excluded; Outcome is not violence.
Tobin T J, Sugai G M. Using sixth-grade school records to predict school violence, chronic discipline problems, and high school outcomes. J Emot Behav Disord. 1999;7(1):40-53. Excluded; Study design not used.
Todis B, Severson H H, Walker H M. The Critical Events Scale: Behavioral profiles of students with externalizing and internalizing behavior disorders. Behav Disord. 1990;15(2):75-86. Excluded; Study does not focus on youth as perpetrators.
Tolan P H, Gorman-Smith D, Henry D B. Linking family violence to delinquency across generations?. Child Serv (Mahwah NJ). 2002;5(4):273-84. Excluded; Age of study population greater than 17 years.
Tolan P H, Gorman-Smith D, Henry D B. The developmental ecology of urban males' youth violence. Dev Psychol. 2003;39(2):274-91. Excluded; Age of study population greater than 17 years. [pmid: 12661886].
Tolan P H, Gorman-Smith D, Henry D B. The developmental ecology of urban males' youth violence. Dev Psychol. 2003;39(2):274-91. Excluded; Duplicated citation or findings. [pmid: 12661886].
Tolan P H, Gorman-Smith D, Loeber R. Developmental timing of onsets of disruptive behaviors and later delinquency of inner-city youth. J Child Fam Stud. 2000;9(2):203-20. Excluded; Not addressing they key questions.
Tolan P H, Henry D. Patterns of psychopathology among urban poor children: Comorbidity and aggression effects. J Consult Clin Psychol. 1996;64(5):1094-9. Excluded; Outcome is not violence. [pmid: 8916642].
Tomori M. Personality characteristics of adolescents with alcoholic parents. Adolescence. 1994;29(116):949-59. Excluded; Outcome is not violence. [pmid: 7892805].
Tones K. Health education: evidence of effectiveness. Arch Dis Child. 1997;77(3):189-91. Excluded; Not a research study. [pmid: 9370891].
Tong DA. Beyond prevention: healing the “sociomas”. Healthc Forum J 1996;39(3):39–40, 57. Excluded; Not a research study.
Tontodonato P, Crew B K. Dating violence, social learning theory, and gender: a multivariate analysis. Violence Vict. 1992;7(1):3-14. Excluded; Age of study population greater than 17 years. [pmid: 1504032].
Toombs N J, Benda B, Corwyn R F. Violent youth in boot camps for non-violent offenders. J Offender Rehabil. 2000;31(34):113-33. Excluded; Outcome is not violence.
Totten M. Girlfriend abuse as a form of masculinity construction among violent, marginal male youth. Men Masc. 2003;6(1):70-92. Excluded; Not a U.S. study.
Toupin J, Morissette L. Juvenile homicide: a case control study. Med Law. 1990;9(3):986-94. Excluded; Not a U.S. study. [pmid: 2122166].
Tremblay R E, Schaal B. Physically aggressive boys from age 6 to 12 years. Their biopsychosocial status at puberty. Ann N Y Acad Sci. 1996;794:192-207. Excluded; Not a U.S. study. [pmid: 8853603].
Tremblay R E, Schaal B, Boulerice B, et al. Testosterone, physical aggression, dominance, and physical development in early adolescence. Int J Behav Dev. 1998;22(4):753-77. Excluded; Not a U.S. study.
Trickett P K, Noll J G, Reiffman A, et al. Variants of intrafamilial sexual abuse experience: implications for short- and long-term development. Dev Psychopathol. 2001;13(4):1001-19. Excluded; Outcome is not violence. [pmid: 11771904].
Trulson C, Triplett R, Snell C. Social control in a school setting: Evaluating a school-based boot camp. Crime Delinq. 2001;47(4):573-609. Excluded; Data not abstractable.
Truscott D. Intergenerational transmission of violent behavior in adolescent males. Aggress Behav. 1992;18(5):327-35. Excluded; Not a U.S. study.
Truscott D. Adolescent offenders: comparison for sexual, violent, and property offences. Psychol Rep. 1993;73(2):657-8. Excluded; Not addressing they key questions. [pmid: 8234618].
Tucker J B, Barone J E, Stewart J, et al. Violence prevention: reaching adolescents with the message. Pediatr Emerg Care. 1999;15(6):436-9. Excluded; Outcome is not violence. [pmid: 10608337].
Tuisku K, Virkkunen M, Holi M, et al. Antisocial violent offenders with attention deficit hyperactivity disorder demonstrate akathisia-like hyperactivity in three-channel actometry. J Neuropsychiatry Clin Neurosci. 2003;15(2):194-9. Excluded; Outcome is not violence. [pmid: 12724461].
Tuisku K, Virkkunen M, Holi M, et al. Antisocial violent offenders with attention deficit hyperactivity disorder demonstrate akathisia-like hyperactivity in three-channel actometry. J Neuropsychiatry Clin Neurosci. 2003;15(2):194-9. Excluded; Duplicated citation or findings. [pmid: 12724461].
Tuninger E E, Levander S, Bernce R, et al. Criminality and aggression among psychotic in-patients: frequency and clinical correlates. Acta Psychiatr Scand. 2001;103(4):294-300. Excluded; Not a U.S. study. [pmid: 11328244].
Tunzi M. Isn't this statutory rape? Am Fam Physician 2002;65(9):1950, 3–4. Excluded; Not a research study.
Turnure C, Young P. Chemical abuse and family violence in Minnesota. Minn Med. 1994;77(10):24-6. Excluded; Not a research study. [pmid: 7990774].
Twemlow S W. A crucible for murder: The social context of violent children and adolescents. Psychoanal Q. 2003;72(3):659-98. Excluded; Not a research study. [pmid: 12901174].
Twemlow S W, Fonagy P, Sacco F C. An innovative psychodynamically influenced approach to reduce school violence. J Am Acad Child Adolesc Psychiatry. 2001;40(3):377-9. Excluded; Not a research study. [pmid: 11288781].
Twemlow S W, Fonagy P, Sacco F C, et al. Premeditated mass shootings in schools: threat assessment. J Am Acad Child Adolesc Psychiatry. 2002;41(4):475-7. Excluded; Not a research study. [pmid: 11931605].
Uberos D J, Gomez A, Munoz A, et al. Television and childhood injuries: is there a connection?. Arch Pediatr Adolesc Med. 1998;152(7):712-4. Excluded; Not a research study. [pmid: 9667549].
Uehara E S, Chalmers D, Jenkins E J, et al. African American youth encounters with violence: Results from the Community Mental Health Council Violence Screening Project. J Black Stud. 1996;26(6):768-81. Excluded; Study design not used.
Ullman S E. A comparison of gang and individual rape incidents. Violence Vict. 1999;14(2):123-33. Excluded; Age of study population greater than 17 years. [pmid: 10418766].
Ulman A, Straus M A. Violence by children against mothers in relation to violence between parents and corporal punishment by parents. J Comp Fam Stud. 2003;34(1):41-60. Excluded; Data not abstractable.
Underwood R C, Patch P C. Siblicide: A descriptive analysis of sibling homicide. Homicide Stud. 1999;3(4):333-48. Excluded; Not addressing they key questions.
Unger J B, Sussman S, Dent C W. Interpersonal conflict tactics and substance use among high-risk adolescents. Addictive Behaviors Addict Behav. 2003;28(5):979-87. Excluded; Study design not used.
Unis A S, Cook E H, Vincent J G, et al. Platelet serotonin measures in adolescents with conduct disorder. Biol Psychiatry. 1997;42(7):553-9. Excluded; Outcome is not violence. [pmid: 9376451].
Valdez A, Kaplan C D, Codina E. Psychopathy among Mexican American gang members: A comparative study. Int J Offender Ther Comp Criminol. 2000;44(1):46-58. Excluded; Data not abstractable.
Valliant P M, Bergeron T. Personality and criminal profile of adolescent sexual offenders, general offenders in comparison to nonoffenders. Psychol Rep. 1997;81(2):483-9. Excluded; Not a U.S. study. [pmid: 9354098].
Valois R F, McKeown R E, Garrison C Z, et al. Correlates of aggressive and violent behaviors among public high school adolescents. J Adolesc Health. 1995;16(1):26-34. Excluded; Study design not used. [pmid: 7742333].
Valois R F, McKewon R E. Frequency and correlated of fighting and carrying weapons among public school adolescents. Am J Health Behav. 1998;22(1):8-17. Excluded; Study design not used.
Valois R F, Oeltmann J E, Waller J, et al. Relationship between number of sexual intercourse partners and selected health risk behaviors among public high school adolescents. J Adolesc Health. 1999;25(5):328-35. Excluded; Study design not used. [pmid: 10551663].
Valois R F, Vincent M L, McKeown R E, et al. Adolescent risk behaviors and the potential for violence: a look at what's coming to campus. J Am Coll Health. 1993;41(4):141-7. Excluded; Study design not used. [pmid: 8436726].
Valois R F, Zullig K J, Huebner E S, et al. Relationship between life satisfaction and violent behaviors among adolescents. Am J Health Behav. 2001;25(4):353-66. Excluded; Study design not used. [pmid: 11488546].
van Dis J, Mahmoodian M, Goddik S, et al. A survey of the prevalence of domestic violence in rural and Urban South Dakota. S D J Med. 2002;55(4):133-9. Excluded; Outcome is not violence. [pmid: 11977866].
van Goozen S H M, Matthys W, Cohen-Kettenis P T, et al. Plasma monoamine metabolites and aggression: Two studies of normal and oppositional defiant disorder children. Eur Neuropsychopharmacol. 1999;9(12):141-7. Excluded; Not a U.S. study. [pmid: 10082240].
van Goozen S H M, van den Ban E, Matthys W, et al. Increased adrenal androgen functioning in children with oppositional defiant disorder: A comparison with psychiatric and normal controls. J Am Acad Child Adolesc Psychiatry. 2000;39(11):1446-51. Excluded; Not a U.S. study. [pmid: 11068901].
Vance J E, Bowen N K, Fernandez G, et al. Risk and protective factors as predictors of outcome in adolescents with psychiatric disorder and aggression. J Am Acad Child Adolesc Psychiatry. 2002;41(1):36-43. Excluded; Outcome is not violence. [pmid: 11800203].
Vanderschmidt H F, Lang J M, Knight-Williams V, et al. Risks among inner-city young teens: the prevalence of sexual activity, violence, drugs, and smoking. J Adolesc Health. 1993;14(4):282-8. Excluded; Data not abstractable. [pmid: 8347639].
Vartiainen H, Tiihonen J, Putkonen A, et al. Citalopram, a selective serotonin reuptake inhibitor, in the treatment of aggression in schizophrenia. Acta Psychiatr Scand. 1995;91(5):348-51. Excluded; Age of study population greater than 17 years. [pmid: 7639092].
Velsor-Friedrich B. Family violence: a growing epidemic. J Pediatr Nurs. 1994;9(4):272-4. Excluded; Not a research study. [pmid: 7965595].
Veneziano C, Veneziano L. A typology of family social environments for institutionalized juvenile delinquents: Implications for research and treatment. J Youth Adolesc. 1992;21(5):593-607. Excluded; Outcome is not violence.
Vernberg E M, Jacobs A K, Hershberger S L. Peer victimization and attitudes about violence during early adolescence. J Clin Child Psychol. 1999;28(3):386-95. Excluded; Outcome is not violence. [pmid: 10446688].
Vidyasagar P, Mishra H. Effect of modelling on aggression. Indian J Clin Psychol. 1993;20(1):50-2. Excluded; Not a U.S. study.
Viemeroe V. Factors in childhood that predict later criminal behavior. Aggress Behav. 1996;22(2):87-97. Excluded; Not a U.S. study.
Villani S. Violence in the media. J Am Acad Child Adolesc Psychiatry. 1999;38(10):1208. Excluded; Not a research study. [pmid: 10517048].
Villani S, Sharfstein S S. Evaluating and treating violent adolescents in the managed care era. Am J Psychiatry. 1999;156(3):458-64. Excluded; Not a research study. [pmid: 10080564].
Virkkunen M. Reactive hypoglycemic tendency among habitually violent offenders. Nutr Rev. 1986;44(Suppl):94-103. Excluded; Not a research study. [pmid: 2980863].
Vissing Y M, Straus M A, Gelles R J, et al. Verbal aggression by parents and psychosocial problems of children. Child Abuse Negl. 1991;15(3):223-38. Excluded; Data not abstractable. [pmid: 2043974].
Vitacco M J, Rogers R. Predictors of adolescent psychopathy: the role of impulsivity, hyperactivity, and sensation seeking. J Am Acad Psychiatry Law. 2001;29(4):374-82. Excluded; Outcome is not violence. [pmid: 11785608].
Vitaro F, Gendreau P L, Tremblay R E, et al. Reactive and proactive aggression differentially predict later conduct problems. J Child Psychol Psychiatry. 1998;39(3):377-85. Excluded; Not a U.S. study. [pmid: 9670093].
Vitelli R. Comparison of early and late start models of delinquency in adult offenders. Int J Offender Ther Comp Criminol. 1997;41(4):351-7. Excluded; Age of study population greater than 17 years.
Vivona J M, Ecker B, Halgin R P. Self- and other-directed aggression in child and adolescent psychiatric inpatients. J Am Acad Child Adolesc Psychiatry. 1995;34:434-44. Excluded; Data not abstractable. [pmid: 7751257].
Volavka J, Laska E, Baker S, et al. History of violent behaviour and schizophrenia in different cultures. Analyses based on the WHO study on Determinants of Outcome of Severe Mental Disorders. Br J Psychiatry. 1997;171:9-14. Excluded; Outcome is not violence. [pmid: 9328487].
Vowell P R, May D C. Another look at classic strain theory: poverty status, perceived blocked opportunity, and gang membership as predictors of adolescent violent behavior. Sociol Inq. 2000;70(1):42-60. Excluded; Study design not used.
Vukelich M S. Stop the media violence. Minn Med. 1995;78(6):16-8. Excluded; Not a research study. [pmid: 7623744].
Waite B M, Hillbrand M, Foster H G. Reduction of aggressive behavior after removal of music television. Hosp Community Psychiatry. 1992;43(2):173-5. Excluded; Age of study population greater than 17 years. [pmid: 1572616].
Waldner-Haugrud L K, Gratch L V, Magruder B. Victimization and perpetration rates of violence in gay and lesbian relationships: gender issues explored. Violence Vict. 1997;12(2):173-84. Excluded; Age of study population greater than 17 years. [pmid: 9403987].
Wallace J M, Forman T A. Religion's role in promoting health and reducing risk among American youth. Health Educ Behav. 1998;25(6):721-41. Excluded; Outcome is not violence. [pmid: 9813744].
Walsh A. Genetic and environmental explanations of juvenile violence in advantaged and disadvantaged environments. Aggress Behav. 1992;18(3):187-99. Excluded; Study design not used.
Walsh D. Interactive media violence and children. Minn Med. 2000;83(9):42-4. Excluded; Not a research study. [pmid: 11006686].
Walsh M M, Pepler D J, Levene K S. A Model Intervention for Girls with Disruptive Behaviour Disorders: The Earlscourt Girls Connection. Can J Couns. 2002;36(4):297-311. Excluded; Not a U.S. study.
Walsh W J, Isaacson H R, Rehman F, et al. Elevated blood copper/zinc ratios in assaultive young males. Physiol Behav. 1997;62(2):327-9. Excluded; Data not abstractable. [pmid: 9251975].
Waschbusch D A, Pelham W E J, Jennings J R, et al. Reactive aggression in boys with disruptive behavior disorders: Behavior, physiology, and affect. J Abnorm Child Psychol. 2002;30(6):641-56. Excluded; Outcome is not violence. [pmid: 12481977].
Watts W D, Wright L S. The drug use-violent delinquency link among adolescent Mexican-Americans. NIDA Res Monogr. 1990;103:136-59. Excluded; Data not abstractable. [pmid: 2096285].
Watts W D, Wright L S. The relationship of alcohol, tobacco, marijuana, and other illegal drug use to delinquency among Mexican-American, Black, and White adolescent males. Adolescence. 1990;25(97):171-81. Excluded; Data not abstractable. [pmid: 2333795].
Watts W D, Wright L S. The relationships of alcohol, tobacco, marijuana, and other illegal drug use to delinquency among Mexican-American, black, and white adolescent males. Adolescence. 1990;25(97):171-81. Excluded; Data not abstractable. [pmid: 2333795].
Way I, Chung S, Jonson-Reid M, et al. Maltreatment perpetrators: a 54-month analysis of recidivism. Child Abuse Negl. 2001;25(8):1093-108. Excluded; Study does not focus on youth as perpetrators. [pmid: 11601599].
Weaver G M, Wootton R R. The use of the MMPI special scales in the assessment of delinquent personality. Adolescence. 1992;27(107):545-54. Excluded; Outcome is not violence. [pmid: 1414566].
Weber D O. Healing a violent society. Healthc Forum J. 1996;39(5):22-32. Excluded; Not a research study. [pmid: 10162402].
Webster D W, Gainer P S, Champion H R. Weapon carrying among inner-city junior high school students: defensive behavior vs aggressive delinquency. Am J Public Health. 1993;83(11):1604-8. Excluded; Study design not used. [pmid: 8238686]. [pmcid: 1694886].
Weiner M D, Pentz M A, Turner G E, et al. From early to late adolescence: alcohol use and anger relationships. J Adolesc Health. 2001;28(6):450-7. Excluded; Outcome is not violence. [pmid: 11377988].
Weishew N L, Peng S S. Variables predicting students' problem behaviors. J Educ Res. 1993;87(1):5-17. Excluded; Study design not used.
Weiss B, Dodge K A, Bates J E, et al. Some consequences of early harsh discipline: child aggression and a maladaptive social information processing style. Child Dev. 1992;63(6):1321-35. Excluded; Outcome is not violence. [pmid: 1446555].
Weisz J R, Martin S L, Walter B R, et al. Differential prediction of young adult arrests for property and personal crimes: findings of a cohort follow-up study of violent boys from North Carolina's Willie M Program. Journal of Child Psychology and Psychiatry, and Allied Disciplines. 1991;32(5):783-92. Excluded; Age of study population greater than 17 years. [pmid: 1918228].
Weisz J R, Suwanlert S, Chaiyasit W, et al. Behavioral and emotional problems among Thai and American adolescents: parent reports for ages 12–16. J Abnorm Psychol. 1993;102(3):395-403. Excluded; Outcome is not violence. [pmid: 8408951].
Weisz J R, Walter B R, Weiss B. Arrests among emotionally disturbed violent and assaultive individuals following minimal versus lengthy intervention through North Carolina's Willie M program. J Consult Clin Psychol. 1990;58:720-8. Excluded; Age of study population greater than 17 years. [pmid: 2292622].
Wekerle C, Wolfe D A. The role of child maltreatment and attachment style in adolescent relationship violence. Dev Psychopathol. 1998;10(3):571-86. Excluded; Not a U.S. study. [pmid: 9741683].
Wekerle C, Wolfe D A, Hawkins D L, et al. Childhood maltreatment, posttraumatic stress symptomatology, and adolescent dating violence: considering the value of adolescent perceptions of abuse and a trauma mediational model. Dev Psychopathol. 2001;13(4):847-71. Excluded; Not a U.S. study. [pmid: 11771911].
Weller N F, Tortolero S R, Kelder S H, et al. Health risk behaviors of Texas students attending dropout prevention/recovery schools in 1997. J Sch Health. 1999;69(1):22-8. Excluded; Not addressing they key questions. [pmid: 10098115].
Welsh J. Children and torture. Lancet. 2000;356(9247):2093. Excluded; Not a research study. [pmid: 11145508].
Welte J W, Zhang L, Wieczorek W F. The effects of substance use on specific types of criminal offending in young men. J Res Crime Delinq. 2001;38(4):416-38. Excluded; Data not abstractable.
West C M, Rose S. Dating aggression among low income African American youth: An examination of gender differences and antagonistic beliefs. Violence Against Women. 2000;6(5):470-94. Excluded; Data not abstractable.
Westhoff W W, McDermott R J, Harokopos V. Acquisition of high-risk behavior by African-American, Latino, and Caucasian middle-school students. Psychol Rep. 1996;79(3, Pt 1):787-95. Excluded; Outcome is not violence. [pmid: 8969085].
Whipple E E, Webster-Stratton C. The role of parental stress in physically abusive families. Child Abuse Negl. 1991;15(3):279-91. Excluded; Outcome is not violence. [pmid: 2043979].
White HR, Brick J, Hansell S. A longitudinal investigation of alcohol use and aggression in adolescence. J Stud Alcohol 1993;Suppl 11:62–77. Excluded; Data not abstractable.
White H R, Chen P-H, et al. Problem drinking and intimate partner violence. J Stud Alcohol. 2002;63(2):205-14. Excluded; Study does not focus on youth as perpetrators. [pmid: 12033697].
White H R, Hansell S. The moderating effects of gender and hostility on the alcohol-aggression relationship. J Res Crime Delinq. 1996;33(4):450-70. Excluded; Data not abstractable.
White H R, Hansell S. Acute and long-term effects of drug use on aggression from adolescence into adulthood. J Drug Issues. 1998;28(4):837-58. Excluded; Study does not focus on youth as perpetrators.
White H R, Hansell S, Brick J. Alcohol use and aggression among youth. Alcohol Health Res World. 1993;17(2):144-50. Excluded; Not addressing they key questions.
White H R, Loeber R, Stouthamer-Loeber M, et al. Developmental associations between substance use and violence. Dev Psychopathol. 1999;11(4):785-803. Excluded; Data not abstractable. [pmid: 10624726].
White H R, Tice P C, Loeber R, et al. Illegal acts committed by adolescents under the influence of alcohol and drugs. J Res Crime Delinq. 2002;39(2):131-52. Excluded; Study design not used.
Whitfield G W. Validating school social work: An evaluation of a cognitive-behavioral approach to reduce school violence. Res Soc Work Pract. 1999;9(4):399-426. Excluded; Outcome is not violence.
Widom C S. The role of placement experiences in mediating the criminal consequences of early childhood victimization. Am J Orthopsychiatry. 1991;61(2):195-209. Excluded; Age of study population greater than 17 years. [pmid: 2048635].
Widom C S. Motivation and mechanisms in the “cycle of violence”. Nebr Symp Motiv. 2000;46:1-37. Excluded; Not a research study. [pmid: 11031734].
Widom C S, Ames M A. Criminal consequences of childhood sexual victimization. Child Abuse Negl. 1994;18(4):303-18. Excluded; Age of study population greater than 17 years. [pmid: 8187016].
Widom C S, Maxfield M G. A prospective examination of risk for violence among abused and neglected children. Ann N Y Acad Sci. 1996;794:224-37. Excluded; Data not abstractable. [pmid: 8853605].
Widom C S, White H R. Problem behaviours in abused and neglected children grown up: Prevalence and co-occurrence of substance abuse, crime and violence. Crim Behav Ment Health. 1997;7(4):287-310. Excluded; Age of study population greater than 17 years.
Wieckowski E, Hartsoe P, Mayer A, et al. Deviant sexual behavior in children and young adolescents: Frequency and patterns. Sex Abuse. 1998;10(4):293-303. Excluded; Not addressing they key questions.
Wiist W H, Jackson R H, Jackson K W. Peer and community leader education to prevent youth violence. Am J Prev Med. 1996;12(5 Suppl):56-64. Excluded; Study does not focus on youth as perpetrators. [pmid: 8909625].
Willard JC, Schoenborn CA. Relationship between cigarette smoking and other unhealthy behaviors among our nation's youth: United States, 1992. Adv Data 1995(263):1–11. Excluded; Not addressing they key questions.
Williams J H, Stiffman A R, O'Neal J L. Violence among urban African American youths: An analysis of environmental and behavioral risk factors. Soc Work Res. 1998;22(1):3-13. Excluded; Study design not used.
Williams O. Spouse abuse: social learning, attribution and interventions. J Health Soc Policy. 1989;1(2):91-107. Excluded; Age of study population greater than 17 years. [pmid: 10304505].
Winpisinger K A, Hopkins R S, Indian R W, et al. Risk factors for childhood homicides in Ohio: a birth certificate-based case-control study. Am J Public Health. 1991;81(8):1052-4. Excluded; Study does not focus on youth as perpetrators. [pmid: 1854000]. [pmcid: 1405732].
Wintemute G J, Wright M A, Parham C A, et al. Criminal activity and assault-type handguns: a study of young adults. Ann Emerg Med. 1998;32(1):44-50. Excluded; Age of study population greater than 17 years. [pmid: 9656948].
Witkowski M J, Homant R J, Barnes E. Work, workplace deviance, and criminal offenders: An analysis of Project GANGMILL. J Gang Res. 2002;10(1):1-10. Excluded; Outcome is not violence.
Wolfe D A, Feiring C. Dating violence through the lens of adolescent romantic relationships. Child Maltreat. 2000;5(4):360-3. Excluded; Not a research study. [pmid: 11232263].
Wolfe D A, Wekerle C, Reitzel-Jaffe D, et al. Factors associated with abusive relationships among maltreated and nonmaltreated youth. Dev Psychopathol. 1998;10(1):61-85. Excluded; Not a U.S. study. [pmid: 9524808].
Wolfe D A, Wekerle C, Scott K, et al. Dating violence prevention with at-risk youth: A controlled outcome evaluation. J Consult Clin Psychol. 2003;71(2):279-91. Excluded; Not a U.S. study. [pmid: 12699022].
Wolfe D A, Wekerle C, Scott K, et al. Dating violence prevention with at-risk youth: a controlled outcome evaluation. J Consult Clin Psychol. 2003;71(2):279-91. Excluded; Duplicated citation or findings. [pmid: 12699022].
Wolfe L R. “Girl stabs boy at school”: girls and the cycle of violence. Womens Health Issues. 1994;4(2):109-16. Excluded; Not a research study. [pmid: 8086808].
Wolfe T W, Shoemaker D J. Actor, situation, and context: A framework for delinquency theory integration. Am J Crim Justice. 1999;24(1):117-38. Excluded; Not addressing they key questions.
Workman M, Beer J. Depression, suicide ideation, and aggression among high school students whose parents are divorced and use alcohol at home. Psychol Rep. 1992;70(2):503-11. Excluded; Data not abstractable. [pmid: 1529069].
Worling J R. Sexual abuse histories of adolescent male sex offenders: differences on the basis of the age and gender of their victims. J Abnorm Psychol. 1995;104(4):610-3. Excluded; Not a U.S. study. [pmid: 8530763].
Worling J R. Adolescent sibling-incest offenders: differences in family and individual functioning when compared to adolescent nonsibling sex offenders. Child Abuse Negl. 1995;19(5):633-43. Excluded; Not a U.S. study. [pmid: 7664142].
Worling J R. Adolescent sex offenders against females: Differences based on the age of their victims. Int J Offender Ther Comp Criminol. 1995;39(3):276-93. Excluded; Not addressing they key questions.
Worling J R. Sexual abuse histories of adolescent male sex offenders: differences on the basis of the age and gender of their victims. J Abnorm Psychol. 1995;104:610-13. Excluded; Duplicated citation or findings. [pmid: 8530763].
Worling J R. Personality-based typology of adolescent male sexual offenders: differences in recidivism rates, victim-selection characteristics, and personal victimization histories. Sex Abuse. 2001;13(3):149-66. Excluded; Not a U.S. study. [pmid: 11486710].
Worling J R, Curwen T. Adolescent sexual offender recidivism: success of specialized treatment and implications for risk prediction. Child Abuse Negl. 2000;24(7):965-82. Excluded; Not a U.S. study. [pmid: 10905420].
Wright S, Klee H. Violent crime, aggression and amphetamine: What are the implications for drug treatment services?. Drug Educ Prev Policy. 2001;8(1):73-90. Excluded; Not a U.S. study.
Xie H, Cairns R B, Cairns B D. The development of social aggression and physical aggression: A narrative analysis of interpersonal conflicts. Aggress Behav. 2002;28(5):341-55. Excluded; Study design not used.
Xie H, Farmer T W, Cairns B D. Different forms of aggression among inner-city African-American children: Gender, configurations and school social networks. J Sch Psychol. 2003;41(5):355-75. Excluded; Study design not used.
Xie H, Swift D J, Cairns B, et al. Aggressive behaviors in social interaction and developmental adaptation: A narrative analysis of interpersonal conflicts during early adolescence. Soc Dev. 2002;11(2):205-24. Excluded; Duplicated citation or findings.
Yarvis R M. Patterns of substance abuse and intoxication among murderers. Bull Am Acad Psychiatry Law. 1994;22(1):133-44. Excluded; Age of study population greater than 17 years. [pmid: 8193384].
Yates T M, Dodds M F, Sroufe L A, et al. Exposure to partner violence and child behavior problems: A prospective study controlling for child physical abuse and neglect, child cognitive ability, socioeconomic status, and life stress. Dev Psychopathol. 2003;15(1):199-218. Excluded; Outcome is not violence. [pmid: 12848442].
Yexley M, Borowsky I, Ireland M. Correlation between different experiences of intrafamilial physical violence and violent adolescent behavior. J Interpers Violence. 2002;17(7):707-20. Excluded; Study design not used.
Young T J. Parricide rates and criminal street violence in the United States: is there a correlation?. Adolescence. 1993;28(109):171-2. Excluded; Age of study population greater than 17 years. [pmid: 8456605].
Young T J, French L A. Homicide rates among Native American children: the status integration hypothesis. Adolescence. 1997;32(125):57-9. Excluded; Age of study population greater than 17 years. [pmid: 9105491].
Youngstrom E, Weist M D, Albus K E. Exploring violence exposure, stress, protective factors and behavioral problems among inner-city youth. Am J Community Psychol. 2003;32(12):115-29. Excluded; Outcome is not violence. [pmid: 14570441].
Zagar R, Arbit J, Sylvies R, et al. Homicidal adolescents: a replication. Psychol Rep. 1990;67(3 Pt 2):1235-42. Excluded; Study design not used. [pmid: 2084749].
Zgourides G, Monto M, Harris R. Correlates of adolescent male sexual offense: Prior adult sexual contact, sexual attitudes, and use of sexually explicit materials. Int J Offender Ther Comp Criminol. 1997;41(3):272-83. Excluded; Study design not used.
Zhang L, Welte J W, Wieczorek W W, et al. The role of aggression-related alcohol expectancies in explaining the link between alcohol and violent behavior. Subst Use Misuse. 2002;37(4):457-71. Excluded; Study design not used. [pmid: 12064429].
Zhang L, Wieczorek W F, Welte J W. The nexus between alcohol and violent crime. Alcohol Clin Exp Res. 1997;21(7):1264-71. Excluded; Data not abstractable. [pmid: 9347088].
Zoloth-Dorfman L. Audience and authority: the story in front of the story. J Clin Ethics. 1996;7(4):355-61. Excluded; Not a research study. [pmid: 9029337].