# References and Included Studies

Administration for Children and Families. Toward a blueprint for youth. Accessed: May 2004. http://www.acf.hhs.gov/programs/fysb/youthinfo/blueprint2.htm.
Becker K B, McCloskey L A. Attention and conduct problems in children exposed to family violence. Am J Orthopsychiatry. 2002;72(1):83-91. [pmid: 14964597].
Beyers J M, Loeber R, Wikstrom P O, et al. What predicts adolescent violence in better-off neighborhoods?. J Abnorm Child Psychol. 2001;29(5):369-81. [pmid: 11695540].
Bock G, Goode J. Genetics of criminal and antisocial behaviour. New York: Wiley; 1996.
Borduin C M, Mann B J, Cone L T, et al. Multisystemic treatment of serious juvenile offenders: long-term prevention of criminality and violence. J Consult Clin Psychol. 1995;63(4):569-78. [pmid: 7673534].
Borowsky I W, Ireland M, Resnick M D, et al. Violence risk and protective factors among youth held back in school. Ambul Pediatr. 2002;2(6):475-84. [pmid: 12437395].
Bosworth K, Espelage D, DuBay T, et al. Preliminary evaluation of a multimedia violence prevention program for adolescents. Am J Health Behav. 2000;24(4):268-80.
Breunlin D C, Bryant-Edwards T L, Hetherington J S, et al. Conflict resolution training as an alternative to suspension for violent behavior. J Educ Res. 2002;95(6):349-57.
Brezina T. Teenage violence toward parents as an adaptation to family strain: Evidence from a national survey of male adolescents. Youth Soc. 1999;30(4):416-44.
Constantino J N, Liberman M, Kincaid M. Effects of serotonin reuptake inhibitors on aggressive behavior in psychiatrically hospitalized adolescents: results of an open trial. J Child Adolesc Psychopharmacol. 1997;7(1):31-44. [pmid: 9192540].
Cook PJ, Laub JH. The unprecedented epidemic in youth violence. In: Tonry M, Moore MH, editors. Youth violence: Crime and justice. Chicago: University of Chicago Press; 1998.
Cooper H, Hedges LV, editors. The handbook of research synthesis. New York: Russell Sage Foundation; 1994. Chapter 14, Vote-counting procedure in meta-analysis.
Dahlberg L L, Potter L B. Youth violence: Developmental pathways and prevention challenges. Am J Prev Med. 2001;20(Suppl1):3-14. [pmid: 11146255].
DeVoe J, Peter K, Kaufman P, et al. Indicators of school crime and safety:2002. NCES Publication 2003009. Accessed: May 2004. (http://nces.ed.gov/pubs2003/schoolcrime/).
Dornbusch S M, Lin I-C, Munroe P T, et al. Adolescent polydrug use and violence in the United States. Int J Adolesc Med Health. 1999;11(34):197-219.
Dowd M D. Consequences of violence. Premature death, violence recidivism, and violent criminality. Pediatr Clin North Am. 1998;45(2):333-40. [pmid: 9568013].
Durant R H, Barkin S, Krowchuk D P. Evaluation of a peaceful conflict resolution and violence prevention curriculum for sixth-grade students. J Adolesc Health. 2001;28(5):386-93. [pmid: 11336868].
DuRant R H, Treiber F, Getts A, et al. Comparison of two violence prevention curricula for middle school adolescents. J Adolesc Health. 1996;19(2):111-7. [pmid: 8863082].
Dykeman B F. The effects of family conflict resolution on children's classroom behavior. J Instr Psychol. 2003;30(1):41-6.
Elias M J, Gara M A, Schuyler T F, et al. The promotion of social competence: Longitudinal study of a preventive school-based program. Am J Orthopsychiatry. 1991;61(3):409-17. [pmid: 1951648].
Ellickson P L, Tucker J S, Klein D J. High-risk behaviors associated with early smoking: results from a 5-year follow-up. J Adolesc Health. 2001;28(6):465-73. [pmid: 11377990].
Ellickson P L, Tucker J S, Klein D J. Ten-year prospective study of public health problems associated with early drinking. Pediatrics. 2003;111(5 Pt 1):949-55. [pmid: 12728070].
Farrell A D, Meyer A L, Sullivan T N, et al. Evaluation of the responding in peaceful and positive ways (RIPP) seventh grade violence prevention curriculum. J Child Fam Stud. 2003;12(1):101-20.
Federal Bureau of Investigations. Uniform crime report. Accessed: May 2004. http://www.fbi.gov/ucr/99cius.htm.
Felson R B. “Kick 'em when they're down”: Explanations of the relationship between stress and interpersonal aggression and violence. Sociol Q. 1992;33(1):1-16.
Foshee V A, Bauman K E, Arriaga X B, et al. An evaluation of Safe Dates, an adolescent dating violence prevention program. Am J Public Health. 1998;88(1):45-50. [pmid: 9584032]. [pmcid: 1508378].
Foshee V A, Bauman K E, Greene W F, et al. The Safe Dates program: 1-year follow-up results. Am J Public Health. 2000;90(10):1619-22. [pmid: 11029999]. [pmcid: 1446374].
Foshee V A, Linder F, MacDougall J E, et al. Gender differences in the longitudinal predictors of adolescent dating violence. Prev Med. 2001;32(2):128-41. [pmid: 11162338].
Friedman A S, Terras A, Glassman K. Multimodel substance use intervention program for male delinquents. J Child Adolesc Subst Abus. 2002;11(4):43-65.
Ginsberg C. Violence-related attitudes and behaviors of high school students--New York City, 1992. MMWR Morb Mortal Wkly Rep. 1993;42(40):773-7. [pmid: 8413162].
Hagan M P, King R P, Patros R L. The efficacy of a serious sex offenders treatment program for adolescent rapists. Int J Offender Ther Comp Criminol. 1994;38(2):141-50.
Halpern C T, Udry J R, Campbell B, et al. Relationships between aggression and pubertal increases in testosterone: A panel analysis of adolescent males. Soc Biol. 1993;40(12):8-24. [pmid: 8146696].
Hammond W R, Yung B R. Preventing violence in at-risk African-American youth. J Health Care Poor Underserved. 1991;2(3):359-73. [pmid: 1772948].
Hanlon T E, Bateman R W, Simon B D, et al. An early community-based intervention for the prevention of substance abuse and other delinquent behavior. J Youth Adolesc. 2002;31(6):459-71.
Harrington N G, Giles S M, Hoyle R H, et al. Evaluation of the All Stars character education and problem behavior prevention program: effects on mediator and outcome variables for middle school students. Health Educ Behav. 2001;28(5):533-46. [pmid: 11575684].
Hawkins J D, Catalano R F, Kosterman R, et al. Preventing adolescent health-risk behaviors by strengthening protection during childhood. Arch Pediatr Adolesc Med. 1999;153(3):226-34. [pmid: 10086398].
Heimer K. Socioeconomic status, subcultural definitions, and violent delinquency. Soc Forces. 1997;75(3):799-833.
Henggeler S W, Clingempeel W G, Brondino M J, et al. Four-year follow-up of multisystemic therapy with substance-abusing and substance-dependent juvenile offenders. J Am Acad Child Adolesc Psychiatry. 2002;41(7):868-74. [pmid: 12108813].
Hennes H. A review of violence statistics among children and adolescents in the United States. Pediatr Clin North Am. 1998;45(2):269-80. [pmid: 9568008].
Herrenkohl R C, Egolf B P, Herrenkohl E C. Preschool antecedents of adolescent assaultive behavior: a longitudinal study. Am J Orthopsychiatry. 1997;67(3):422-32. [pmid: 9250343].
Herrenkohl T I, Guo J, Kosterman R, et al. Early adolescent predictors of youth violence as mediators of childhood risks. J Early Adolesc. 2001;21(4):447-69.
Herrenkohl T I, Hill K G, Chung I-J, et al. Protective factors against serious violent behavior in adolescence: A prospective study of aggressive children. Soc Work Res. 2003;27(3):179-91.
Herrenkohl T I, Maguin E, Hill K G, et al. Developmental risk factors for youth violence. J Adolesc Health. 2000;26(3):176-86. [pmid: 10706165].
Herrera V M, McCloskey L A. Gender differences in the risk for delinquency among youth exposed to family violence. Child Abuse Negl. 2001;25(8):1037-51. [pmid: 11601596].
Herrera V M, McCloskey L A. Sexual abuse, family violence, and female delinquency: Findings from a longitudinal study. Violence Vict. 2003;18(3):319-34. [pmid: 12968661].
Huang B, Kosterman R, Catalano R F. Modeling mediation in the etiology of violent behavior in adolescence: a test of the social development model. Criminology. 2001;39(1):75-107.
Hulley SB, Cummings SR, Browner WS, et al. Designing clinical research: an epidemiologic approach, second edition. Philadelphia, PA: Lippincott Williams & Wilkins; 2001.
Kaplan H B, Tolle G C J, Yoshida T. Substance use-induced diminution of violence: a countervailing effect in longitudinal perspective. Criminology. 2001;39(1):205-24.
Kann L, Kinchen S A, Williams B I, et al. Youth risk behavior surveillance--United States, 1999. MMWR CDC Surveill Summ. 2000;49(5):1-32. [pmid: 12412614].
Kingery P M, Biafora F A, Zimmerman R S. Risk factors for violent behaviors among ethnically diverse urban adolescents: Beyond race/ethnicity. Sch Psychol Int. 1996;17(2):171-88.
Komro K A, Williams C L, Forster J L, et al. The relationship between adolescent alcohol use and delinquent and violent behaviors. J Child Adolesc Subst Abus. 1999;9(2):13-28.
Loeber R, Wei E, Stouthamer-Loeber M, et al. Behavioral antecedents to serious and violent offending: Joint analyses from the Denver Youth Survey, Pittsburgh Youth Study and the Rochester Youth Development Study. Stud Crime Crime Prev. 1999;8(2):245-63.
Loeber R, Wung P, Keenan K, et al. Developmental pathways in disruptive child behavior. Dev Psychopathol. 1993;5(12):103-33.
Lowry R, Sleet D, Duncan C, et al. Adolescents at risk for violence. Educ Psychol Rev. 1995;7(1):7-39.
Ludwig J, Duncan G J, Hirschfield P. Urban poverty and juvenile crime: evidence from a randomized housing-mobility experiment. Q J Econ. 2001;116(2):655-79.
Mathew T, Nordstrom K. On the equivalence of meta-analysis using literature and using individual patient data. Biometrics. 1999;55(4):1221-3. [pmid: 11315071].
McCloskey L A, Lichter E L. The contribution of marital violence to adolescent aggression across different relationships. J Interpers Violence. 2003;18(4):390-412.
McCord J, Widom CS, Crowell NA. Juvenile crime, juvenile justice. Washington, D. C.: National Academy Press; 2001.
McNulty T L, Bellair P E. Explaining racial and ethnic differences in adolescent violence: Structural disadvantage, family well-being, and social capital. Justice Q. 2003;20(1):1-31.
Moore E, Armsden G, Gogerty P L. A twelve-year follow-up study of maltreated and at-risk children who received early therapeutic child care. Child Maltreat. 1998;3(1):3-16.
Morrissey C. A multimodal approach to controlling inpatient assaultiveness among incarcerated juveniles. J Offender Rehabil. 1997;25(12):31-42.
Myers W C, Burton P R, Sanders P D, et al. Project back-on-track at 1 year: a delinquency treatment program for early-career juvenile offenders. J Am Acad Child Adolesc Psychiatry. 2000;39(9):1127-34. [pmid: 10986809].
Nagin D, Tremblay R E. Trajectories of boys' physical aggression, opposition, and hyperactivity on the path to physically violent and nonviolent juvenile delinquency. Child Dev. 1999;70(5):1181-96. [pmid: 10546339].
National Center for Injury Prevention and Control. Youth violence: Overview. Accessed: May 2004. http://www.cdc.gov/ncipc/factsheets/yvfacts.htm.
O'Donnell L, Stueve A, San Doval A, et al. Violence prevention and young adolescents' participation in community youth service. J Adolesc Health. 1999;24(1):28-37. [pmid: 9890362].
ODS and OMAR. Procedures for EPC Reports for ODS and OMAR. 2003
O'Leary K D, Slep A M S. A dyadic longitudinal model of adolescent dating aggression. J Clin Child Adolesc Psychol. 2003;32(3):314-27. [pmid: 12881021].
Olkin I, Sampson A. Comparison of meta-analysis versus analysis of variance of individual patient data. Biometrics. 1998;54(1):317-22. [pmid: 9544524].
Orpinas P, Kelder S, Frankowski R, et al. Outcome evaluation of a multi-component violence-prevention program for middle schools: the Students for Peace project. Health Educ Res. 2000;15(1):45-58. [pmid: 10788201].
Perry C L, Komro K A, Veblen-Mortenson S, et al. A randomized controlled trial of the middle and junior high school D.A.R.E. and D.A.R.E. Plus programs. Arch Pediatr Adolesc Med. 2003;157(2):178-84. [pmid: 12580689].
Piquero A, Tibbetts S. The impact of pre/perinatal disturbances and disadvantaged familial environment in predicting criminal offending. Stud Crime Crime Prev. 1999;8(1):52-70.
Raine A. Biosocial studies of antisocial and violent behavior in children and adults: a review. J Abnorm Child Psychol. 2002;30(4):312-26. [pmid: 12403151].
Reynolds A J, Temple J A, Robertson D L, et al. Long-term effects of an early childhood intervention on educational achievement and juvenile arrest: A 15-year follow-up of low-income children in public schools. JAMA. 2001;285(18):2339-46. [pmid: 11343481].
Risler E A, Sweatman T, Nackerud L. Evaluating the Georgia legislative Waiver's effectiveness in deterring juvenile crime. Res Soc Work Pract. 1998;8(6):657-67.
Rivera B, Widom C S. Childhood victimization and violent offending. Violence Vict. 1990;5(1):19-35. [pmid: 2278946].
Roitberg T, Menard S. Adolescent violence: A test of integrated theory. Stud Crime Crime Prev. 1995;4(2):177-96.
Sampson R J, Morenoff J D, Gannon-Rowley T. Assessing “neighborhood effects”: social processes and new directions in research. Annu Rev Sociol. 2002;28:443-78.
Saner H, Ellickson P. Concurrent risk factors for adolescent violence. J Adolesc Health. 1996;19(2):94-103. [pmid: 8863080].
Satcher D. Youth violence: A report of the surgeon general. Accessed: May 2004. http://www.surgeongeneral.gov/library/youthviolence/.
Scott K K, Tepas J J, Frykberg E, et al. Turning point: rethinking violence--evaluation of program efficacy in reducing adolescent violent crime recidivism. J Trauma. 2002;53(1):21-7. [pmid: 12131384].
Simon T R, Sussman S, Dahlberg L L, et al. Influence of a substance-abuse-prevention curriculum on violence-related behavior. Am J Health Behav. 2002;26(2):103-10. [pmid: 11926674].
Shonkoff JP, Phillips D. From neurons to neighborhoods : the science of early child development. Washington, D.C.: National Academy Press; 2000.
Stein D B. Outpatient behavioral management of aggressiveness in adolescents: A response cost paradigm. Aggress Behav. 1999;25(5):321-30.
Stewart L A, Clarke M J. Practical methodology of meta-analyses (overviews) using updated individual patient data. Cochrane Working Group. Stat Med. 1995;14(19):2057-79. [pmid: 8552887].
Stewart L A, Parmar M K. Meta-analysis of the literature or of individual patient data: is there a difference?. Lancet. 1993;341(8842):418-22. [pmid: 8094183].
Stouthamer-Loeber M, Loeber R. Lost opportunities for intervention: Undetected markers for the development of serious juvenile delinquency. Crim Behav Ment Health. 2002;12(1):69-82. [pmid: 12357260].
Stouthamer-Loeber M, Loeber R, Homish D L, et al. Maltreatment of boys and the development of disruptive and delinquent behavior. Dev Psychopathol. 2001;13(4):941-55. [pmid: 11771915].
Villani S. Impact of media on children and adolescents: a 10-year review of the research. J Am Acad Child Adolesc Psychiatry. 2001;40(4):392-401. [pmid: 11314564].
West S, King V, Carey T, et al. Systems to rate the strength of scientific svidence. Evidence Report/Technology Assessment No. 47. AHRQ Publication No. 02-E016. Rockville, MD: Agency for Healthcare Research and Quality; 2002.
Zhang Q, Loeber R, Stouthamer-Loeber M. Developmental trends of delinquent attitudes and behaviors: Replications and synthesis across domains, time, and samples. J Quant Criminol. 1997;13(2):181-215.
Zivin G, Hassan N R, DePaula G F, et al. An effective approach to violence prevention: traditional martial arts in middle school. Adolescence. 2001;36(143):443-59. [pmid: 11817627].