# Acknowledgments

This study was supported by Contract 290-02-0003 from the Agency for Healthcare Research and Quality (AHRQ). We acknowledge the support of Jacqueline Besteman J.D., MA, the former Director of the EPC Program and the continuing support of Kenneth Fink, M.D., M.G.A., M.P.H., Director of the EPC Program and Marian James, Ph.D., the Task Order Officer for this project.

We deeply appreciate the support, commitment, and guidance of our Technical Expert Group (TEG), who served as vital resources throughout our process. They are Sonia Chessen from the Department of Health and Human Services, Sandra Graham, Ph.D., from the University of California at Los Angeles, Nancy Guerra, Ed.D., from the University of California at Riverside, Ron Haskins, Ph.D., from the Brookings Institute, Darnell Hawkins J.D., Ph.D., from the University of Illinois at Chicago, Doug Kirby, Ph.D., from ETR Associates, Georgine Pion, Ph.D., from Vanderbilt University, Cathy Widom, Ph.D., from New Jersey School of Medicine, and Franklin Zimring, J.D., from the University of California at Berkeley.

We would also like to extend our appreciation to our external peer reviewers, who provided constructive feedback and insightful suggestions for the improvement of our report. They are Paula Duncan M.D. from the Vermont Child Health Improvement Program, Kathy Grasso, J.D., from the United States Department of Justice, Lynne Havenkos, M.D., M.P.H., from the National Institute on Child Health and Human Development, Joan Sera Hoffman, Ph.D., from the Centers for Disease Control and Prevention, Patrick Kanary from the Center for Innovative Practices, and Danielle Laraque, M.D., from Mount Sinai School of Medicine.

We owe our thanks to our librarian, Melissa L. Just, M.L.I.S., who conducted preliminary searches and retrieved 100% of the full-length articles and to the members of our research team who tirelessly screened, reviewed, and abstracted the articles within an extremely tight time frame. They include Michael Chan, M.P.H.,and medical student, Sergui Grozavu M.A., Michele Mouttapa, Ph.D., candidate, Laura Parks M.P.H., Bettsy Santana B.A., and M.P.H. student, Ida Shihady M.P.H., and Robin Toblin M.A. and Ph.D. student.

Finally, we are indebted to Robert Johnson, M.D., Chair of the Conference Panel, who provided invaluable guidance throughout our project.